# List of Excluded Studies

## EXCLUDED STUDIES (N = 438)

The following studies failed to meet at least one of the pre-specified inclusion criteria.

### Study design (N = 129)

The following studies were excluded because they were not reports of primary research.

1 Miller E, Uleryk E, Doria AS. Evidence-based outcomes of studies addressing diagnostic accuracy of MRI of juvenile idiopathic arthritis. AJR. American. 2009;(5):1209-18. [pmid: 19380543].
2 Kallel-Sellami M, Baili-Klila L, Zerzeri Y, et al. Pediatric systemic lupus erythematosus with C1q deficiency. Annals of the New York Academy of Sciences. 2007;1108:193-6. [pmid: 17893985].
3 Melegari A, Mascia MT, Sandri G, et al. Immunodeficiency and autoimmune phenomena in female hyper-IgM syndrome. Annals of the New York Academy of Sciences. 2007;1109:106-8. [pmid: 17785295].
4 Mseddi M, Dammak A, Marrekchi S, et al. Subacute cutaneous lupus erythematosus in childhood: a case report. [French]. Archives de Pediatrie. 2007;14(2):164-6. [pmid: 17207613].
5 Gough-Palmer A, McHugh K. Investigating hip pain in a well child. BMJ: British Medical Journal. 2007;334(7605):1216-7.
6 Banerjee P, Crain B. 2-year-old girl with right leg weakness. Brain Pathology. 2008;18(4):608-10. [pmid: 18782176].
7 Abbassian A. The limping child: a clinical approach to diagnosis. British Journal of Hospital Medicine. 2007;68(5):246-50. [pmid: 17554942].
8 Trueman CA. Joint disease: the future arthritis burden. Caring. 2009;28(2):8-13. [pmid: 19953858].
9 Gilbert NF, Deavers MT, Madewell JE, et al. A 16-year-old girl with pain and swelling in the medial clavicle. CLIN ORTHOP RELATED RES. 2008;466(12):3158-62.
10 Brown RJ. Introduction to the special issue on medically unexplained symptoms: background and future directions. Clinical Psychology Review. 2007;27(7):769-80. [pmid: 17707564].
11 Wyndham M. The limping child. Community Practitioner. 2007;80(9):42. [pmid: 17900028].
12 Syed RH, Gilliam BE, Moore TL. Rheumatoid factors and anticyclic citrullinated peptide antibodies in pediatric rheumatology. Current Rheumatology Reports. 2008;10(2):156-63. [pmid: 18460272].
13 Yokota S, Mori M, Imagawa T, et al. Proposal for juvenile idiopathic arthritis guidance on diagnosis and treatment for primary care pediatricians and nonpediatric rheumatologists. Modern Rheumatology. 2007;17(5):353-63. [pmid: 17929125].
14 Iwata N, Mori M, Miyamae T, et al. Sjogren’s syndrome associated with childhood-onset systemic lupus erythematosus. [Japanese]. Nihon Rinsho Meneki Gakkai Kaishi. 2008;31(3):166-71. [pmid: 18587227].
15 van Holsbeeck MT. A role for US screening in juvenile idiopathic arthritis. Pediatric Radiology. 2007;37(7):623-4. [pmid: 17530239].
16 Gottlieb BS, Ilowite NT. Systemic lupus erythematosus in children and adolescents. Pediatrics in Review. 2006;27(9):323-30. [pmid: 16950937].
17 Al-Mendalawi MD. Juvenile systemic lupus erythematosus in Bahrain. A tertiary referral center experience. Saudi Medical Journal. 2009;30(9):1240-1. [pmid: 19750278].
18 Quartier P, Prieur AM. Systemic lupus erythematosus. [French]. Archives de Pediatrie. 2003;10(4):367-73. [pmid: 12818767].
19 Gandon-Laloum S. Growth and limb pains. [French]. Archives de Pediatrie. 2006;13(6):550-2. [pmid: 16697588].
20 Bizzaro N, Wiik A. Appropriateness in anti-nuclear antibody testing: from clinical request to strategic laboratory practice. Clinical & Experimental Rheumatology. 2004;22(3):349-55. [pmid: 15144133].
21 Jarvis JN. The unique clinical presentation of children with chronic arthritis: putting the pediatrics in pediatric rheumatology. Current Problems in Pediatric & Adolescent Health Care. 2006;36(3):80-2. [pmid: 16473283].
22 Kaur S, Thami GP. Antinuclear antibody-negative systemic lupus erythematosus: revisited. INDIAN J PEDIATR. 2003;70(2):185-6. [pmid: 12661819].
23 Leung AK, Lemay JF. The limping child. Journal of Pediatric Health Care. 2004;18(5):219-23. [pmid: 15337915].
24 Gunther KP, Thielemann F, Bottesi M. Anterior knee pain in children and adolescents. Diagnosis and conservative treatment. [German]. Orthopade. 2003;32(2):110-8. [pmid: 12607076].
25 Shea KG, Pfeiffer R, Curtin M. Idiopathic anterior knee pain in adolescents. Orthopedic Clinics of North America. 7 A.D.;34(3):377-83. [pmid: 12974487].
26 Siegel DM. Antinuclear Antibody (ANA) Testing. Pediatrics in Review. 2003;24(9):320-1. [pmid: 12949270].
27 Ganley TJ, Gaugles RL, Moroz LA. Consultation with the specialist: patellofemoral conditions in childhood. Pediatrics in Review. 70 A.D.;27(7):264-9. [pmid: 16815995].
28 Kashikar-Zuck S, Graham TB, Huenefeld MD, et al. A review of biobehavioral research in juvenile primary fibromyalgia syndrome. ARTHRITIS CARE RES. 2000;13(6):388-97. [pmid: 14635315].
29 Locham KK, Singh J, Garg R, et al. ANA negative lupus erythematosus. Indian Pediatrics. 2000;37(5):540-2. [pmid: 10820549].
30 Solomon DH, Shmerling RH, Schur PH, et al. A computer based intervention to reduce unnecessary serologic testing. J RHEUMATOL. 1999;26(12):2578-84. [pmid: 10606365].
31 Carreno PL. Practical value of immunologic changes in juvenile chronic arthritis. [Spanish]. Anales Espanoles de Pediatria. 1993;39. Suppl-30.
32 Modesto CC. Antinuclear antibodies and juvenile chronic rheumatoid arthritis. [Spanish]. Anales Espanoles de Pediatria. 1996;44(4):305-9. [pmid: 8849075].
33 Lightfoot RW Jr. Cost effective use of laboratory tests in rheumatology. Bulletin on the Rheumatic Diseases. 1997;46(6):1-3. [pmid: 9336998].
34 Martinez-Cordero E, Orozco BG, Martinez ME. Evaluation of disease activity by laboratory tests in juvenile rheumatoid arthritis. Journal of Investigational Allergology & Clinical Immunology. 1995;5(4):216-20. [pmid: 8705012].
35 Brady M. The child with a limp. Journal of Pediatric Health Care. 1993;7(5):226-8. [pmid: 8410589].
36 Leak AM. Autoantibody profile in juvenile chronic arthritis. ANN RHEUM DIS. 1988;47(3):178-82. [pmid: 3281608].
37 Southwood TR, Malleson PN. Antinuclear antibodies and juvenile chronic arthritis (JCA): search for a specific autoantibody associated with JCA. ANN RHEUM DIS. 1991;50(9):595-8. [pmid: 1929579].
38 Schaller JG. Juvenile rheumatoid arthritis: Series 1. Arthritis & Rheumatism. 1977;20(2:Suppl):70.
39 Chamberlain MA. Referral of chronic arthritics. British Medical Journal Clinical Research Ed. 1984;288(6414):347-8. [pmid: 6419922].
40 Ballardini P, Busachi CA, Amoresano A, et al. Prevalence of rheumatoid factors in juvenile rheumatoid arthritis. Clinical & Experimental Rheumatology. 2010;9(5):548. [pmid: 1954710].
41 Kanski JJ. Juvenile arthritis and uveitis. Survey of Ophthalmology. 1990;34(4):253-67. [pmid: 2188388].
42 Mayet WJ, Bachmann M, Hermann E, et al. The Ro/SS-A antigen-antibody system. [German]. Zeitschrift fur Rheumatologie. 1988;47(2):80-5. [pmid: 3291481].
43 Sievers K, Nissila M, Sievers UM. Cerebral vasculitis visualized by angiography in juvenile rheumatoid arthritis simulating brain tumor. Acta Rheumatologica Scandinavica. 1968;14(3):222-32. [pmid: 5306097].
44 Oppermann J. Phagocytized aggregates in joint effusion cells of children with rheumatoid arthritis. [German]. Allergie und Asthma. 1969;15(4):218-22. [pmid: 5400707].
45 Irias JJ. Hydralazine-induced lupus erythematosus-like syndrome. American Journal of Diseases of Children. 1975;129(7):862-4. [pmid: 50009].
46 Bloch-Michel H, Waltzing P, Brauner M, et al. The rosette rheumatoid test in seronegative juvenile-infantile polyarthritis. [French]. Annales de Medecine Interne. 1972;123(4):375-9. [pmid: 5077043].
47 Yodfat Y, Yossipovitch Z, Cohen I, et al. A family with a high incidence of juvenile rheumatoid arthritis. ANN RHEUM DIS. 1972;31(2):92-4. [pmid: 4111641].
48 Bresnihan FP, Ansell BM. Effect of penicillamine treatment on immune complexes in two cases of seropositive juvenile rheumatoid arthritis. ANN RHEUM DIS. 1975;35(5):463-5. [pmid: 1086656].
49 Gregg S. Rheumatoid arthritis in childhood. Arizona Medicine. 1971;28(8):577-85. [pmid: 4947582].
50 Baum J, Fink C. Juvenile rheumatoid arthritis in monozygotic twins: a case report and review of the literature. Arthritis & Rheumatism. 1968;11(1):33-6. [pmid: 4966598].
51 Brizard J. Chronic inflammatory rheumatism in children. [French]. Cahiers de Medecine. 1972;13(3):167-79. [pmid: 4537787].
52 Bruneau CD, Edmonds JP, Hughes GR, et al. Detection and characterization of DNA-anti-DNA complexes in a patient with systemic lupus erythematosus. Clinical & Experimental Immunology. 1977;28(3):433-6. [pmid: 302166].
53 Ansell BA. Rheumatoid disease, laboratory data. CRC Critical Reviews in Clinical Laboratory Sciences. 1972;3(2):193-201. [pmid: 4562916].
54 Day NK, Geiger H, McLean R, et al. C2 deficiency. Development of lupus erythematosus. Journal of Clinical Investigation. 1973;52(7):1601-7. [pmid: 4578155].
55 Kornreich H, Malouf NN, Hanson V. Acute hepatic dysfunction in juvenile rheumatoid arthritis. J Pediatric. 1971;79(1):27-35.
56 Mackay IR. Autoimmune disease. Medical Journal of Australia. 1969;1(13):696-9. [pmid: 4890055].
57 Schaller JG. Diagnosis and treatment of arthritis in children. Medical Times. 1977;105(11):65-74. [pmid: 916861].
58 Kolle G. Juvenile rheumatoid arthritis and related collagen diseases. Clinical aspects. [German]. Monatsschrift fur Kinderheilkunde. 1976;124(12):779-85. [pmid: 12466].
59 Haustein UF, Sonnichsen N. Lupus erythematodes in childhood--a virus-induced autoimmune disease?. [German]. Padiatrie und Grenzgebiete. 1974;13(2–3):163-76. [pmid: 4605775].
60 Boone JE, Baldwin J, Levine C. Juvenile rheumatoid arthritis. Pediatric Clinics of North America. 1974;21(4):885-915. [pmid: 4610493].
61 Levinson JE. Juvenile rheumatoid arthritis. POSTGRAD MED. 1972;51(6):88-94. [pmid: 4537350].
62 Dumas M, Loyau G. Diagnostic problems raised by polyarthritis of an inflammatory nature. [French]. Semaine des Hopitaux. 1972;48(9):645-8. [pmid: 4114412].
63 Smiley WK. The eye in juvenile rheumatoid arthritis. Transactions of the Ophthalmological Societies of the United Kingdom. 1974;94(3):817-29. [pmid: 4549593].
64 Macaubas C, Nguyen K, Milojevic D, et al. Oligoarticular and polyarticular JIA: Epidemiology and pathogenesis. Nature Reviews Rheumatology. 2009;5(11):616-26.
65 Goldenberg DL. Diagnosis and Differential Diagnosis of Fibromyalgia. American Journal of Medicine. 2009;122(12 SUPPL):S14-S21. [pmid: 19962492].
66 Hunter PJ, Wedderburn LR. Pediatric rheumatic disease: Can molecular profiling predict the future in JIA?. Nature Reviews Rheumatology. 2009;5(11):593-4.
67 Ortega-Hernandez O-D, Shoenfeld Y. Infection, vaccination, and autoantibodies in chronic fatigue syndrome, cause or coincidence. Contemporary Challenges in Autoimmunity Annals of the New York Academy of Sciences. 2009;1173:600-9.
68 McGonagle D, Benjamin M. Towards a new clinico-immunopathological classification of juvenile inflammatory arthritis. J RHEUMATOL. 2009;36(8):1573-4. [pmid: 19671809].
69 Ringold S, Cron RQ. The temporomandibular joint in juvenile idiopathic arthritis: Frequently used and frequently arthritic. Pediatric Rheumatology. 2009;7(11).
70 Nandi M, Ganguli SK, Mondal R, et al. Clinico-serological profile of juvenile idiopathic arthritis. Indian Pediatrics. 2009;46(7):640-1. [pmid: 19638666].
71 Goeb V, Jouen F, Gilbert D, et al. Diagnostic and prognostic usefulness of antibodies to citrullinated peptides. Joint Bone Spine. 2009;76(4):343-9. [pmid: 19524474].
72 Gomez AP, Atrio AIS, Nieves AIT, et al. Differential diagnostic protocol of arthritis in infancy and adolescence. [Spanish]. Medicine. 2009;10(29):1972-5.
73 Gomez AP, Atrio AIS, Hernandez FA, et al. Juvenile idiopathic arthritis. [Spanish]. Medicine. 2009;10(29):1933-41.
74 Syed RH, Gilliam BE, Moore TL. Rheumatoid factors and anticyclic citrullinated peptide antibodies in pediatric rheumatology. Current Rheumatology Reports. 2008;10(2):156-63. [pmid: 18460272].
75 Unsal E, Arli AO, Akman H. Rhupus arthropathy as the presenting manifestation in Juvenile SLE: A case report. Pediatric Rheumatology. 2007;5(7).
76 Hinze C, Brunner HI. Pediatric rheumatology - Its own specialty. Nature Clinical Practice Rheumatology. 2008;4(6):279.
77 Olsen NJ, Wandstrat AE, Karp DR. Development of risk profiles for systemic lupus erythematosus. Future Rheumatology. 2007;2(5):507-14.
78 Silverman E. Pediatric systemic lupus erythematosus. Future Rheumatology. 2007;2(1):23-50.
79 Weiss JE, Ilowite NT. Juvenile Idiopathic Arthritis. Rheumatic Disease Clinics of North America. 2007;33(3):441-70. [pmid: 17936173].
80 Yildiz B, Kural N. IgG1 deficiency and high IgA level with juvenile idiopathic arthritis. European Journal of Pediatrics. 2007;166(11):1179-80. [pmid: 17136352].
81 Buc M, Parnicka Z, Rovensky J, et al. Juvenile idiopatic arthritis an overview of current status in immunopathogenesis, immunogenetic, and immunotherapy. [Slovak]. Rheumatologia. 2006;20(4):209-14.
82 Gottlieb BS, Ilowite NT. Systemic lupus erythematosus in children and adolescents. Pediatrics in Review. 2006;27(9):323-30. [pmid: 16950937].
83 Lopez-Longo F-J, Rodriguez-Mahou M, Sanchez-Ramon S, et al. Anti-cyclic citrullinated peptide versus anti-Sa antibodies in diagnosis of rheumatoid arthritis in an outpatient clinic for connective tissue disease and spondyloarthritis. J RHEUMATOL. 2006;33(8):1476-81. [pmid: 16881106].
84 Ravelli A, Martini A. Remission in juvenile idiopathic arthritis. Clinical and experimental rheumatology. 2006;24(6 SUPPL 43):S105-S110. [pmid: 17083772].
85 Uma SA. Systemic lupus erythematosus in children-clinical spectrum and management. Indian Journal of Practical Pediatrics. 2005;7(4):352-8.
86 Childhood SLE. South African Medical Journal. 2005;95(6):363.
87 Kamoun M. Diagnostic performance and predictive value of anti-citrullinated peptide antibodies for diagnosis of rheumatoid arthritis: Toward more accurate detection?. Clinical Chemistry. 2005;51(1):12-3. [pmid: 15613706].
88 Migliorini P, Baldini C, Rocchi V, et al. Anti-Sm and anti-RNP antibodies. Autoimmunity. 2005;38(1):47-54. [pmid: 15804705].
89 Symmons D. Commentary: Juvenile idiopathic arthritis - Issues of definition and causation. International Journal of Epidemiology. 2005;34(3):671-2. [pmid: 15851394].
90 Vander CB, Peene I, Cantaert T, et al. Anti-citrullinated protein/peptide antibodies (ACPA) in rheumatoid arthritis: Specificity and relation with rheumatoid factor. Autoimmunity Reviews. 2005;4(7):468-74. [pmid: 16137613].
91 Wiik AS. Anti-nuclear autoantibodies: Clinical utility for diagnosis, prognosis, monitoring, and planning of treatment strategy in systemic immunoinflammatory diseases. Scandinavian Journal of Rheumatology. 2005;34(4):260-8. [pmid: 16195158].
92 Yablanski K, Yordanova V. Diagnostic significance of the antibodies to cyclic citrullinated peptides in patients with rheumatoid arthritis. Clinical Application of Immunology. 2005;4(1–2):435-40.
93 Maddison PJ. Is it SLE?. Best Practice and Research in Clinical Rheumatology. 2002;16(2):167-80.
94 Agarwal V, Mahajan A. Laboratory tests in rheumatology: Rational utilization and interpretation. JK Science. 2004;6(1):52-5.
95 Bodman-Smith MD, Fife MF, Wythe H, et al. Anti-BiP antibody levels in juvenile idiopathic arthritis (JIA). Rheumatology. 2004;43(10):1305-6. [pmid: 15448213].
96 Klein-Gitelman M. Pediatric lupus versus adult lupus role of the laboratory. Clinical and Applied Immunology Reviews. 2004;4(5):333-50.
97 Petty RE, Southwood TR, Manners P, et al. International League of Associations for Rheumatology Classification of Juvenile Idiopathic Arthritis: Second Revision, Edmonton, 2001. J RHEUMATOL. 2004;31(2):390-2. [pmid: 14760812].
98 Ravelli A. Toward an understanding of the long-term outcome of juvenile idiopathic arthritis. Clinical and experimental rheumatology. 2004;22(3):271-5. [pmid: 15144118].
99 van Venrooij WJ, Hazes JM, Visser H. Anticitrullinated protein/peptide antibody and its role in the diagnosis and prognosis of early rheumatoid arthritis. Netherlands Journal of Medicine. 2002;60(10):383-8. [pmid: 12607587].
100 Lewis JG, Florkowski CM, Elder PA, et al. Rheumatoid factor and false positive sex-hormone binding globulin. Clinica Chimica Acta. 2003;332(1–2):139-44.
101 Slettjord CN, Nossent HC, Goodson NJ, et al. Increased mortality in early inflammatory polyarthritis: Comment on the article by Goodson et al. Arthritis and rheumatism. 2003;48(5):1462-3. [pmid: 12746924].
102 Goumy L. Idiopathic juvenile polyarthritis. [French]. Presse Medicale. 2001;30(3):137-42.
103 Hull RG. Guidelines for management of childhood arthritis. Rheumatology. 2001;40(11):1309-12. [pmid: 11709617].
104 Malleson PN, Beauchamp RD. Rheumatology: 16. Diagnosing musculoskeletal pain in children. Canadian Medical Association Journal. 2001;165(2):183-8. [pmid: 11501459].
105 Rauz S, Murray PI, Southwood TR. Juvenile idiopathic arthritis and uveitis: The classification conundrum. Eye. 2000;14(6):817-20. [pmid: 11584835].
106 Diagnosis, development and treatment principles of systemic lupus erythematosus. [French]. Annales de Dermatologie et de Venereologie. 2000;127(SPEC.ISS. 1):A167-A173. [pmid: 11474518].
107 Illei GG, Klippel JH. Why is the ANA result positive?. Bulletin on the Rheumatic Diseases. 1999;48(1):1-4. [pmid: 10028188].
108 Pelkonen PM. Juvenile arthritis with oligoarticular onset. Bailliere’s Clinical Rheumatology. 1998;12(2):273-86. [pmid: 9890098].
109 Rosenberg AM. Systemic lupus erythematosus in children. Springer Seminars in Immunopathology. 1994;16(2–3):261-79. [pmid: 7716708].
110 Tibbitts GM. Juvenile rheumatoid arthritis: Old challenges, new insights. POSTGRAD MED. 1994;96(2):75-87. [pmid: 8041686].
111 Tucker LB. Juvenile rheumatoid arthritis. Current Opinion in Rheumatology. 1993;5(5):619-28. [pmid: 7691139].
112 Hanson V. The subtypes of juvenile rheumatoid arthritis and their significance. Ryumachi. 1991;31(6):592-8.
113 Bonagura VR, Ilowite NT, Hatam L, et al. Expression of the major rheumatoid factor cross-reactive idiotype in pediatric patients with systemic lupus erythematosus. Clinical Immunology and Immunopathology. 1991;60(2):232-43. [pmid: 2070569].
114 Laxer RM. Introduction. J RHEUMATOL. 1990;17(SUPPL 26):1. [pmid: 2179547].
115 Rhodes VJ. Physical therapy management of patients with juvenile rheumatoid arthritis. Physical Therapy. 1991;71(12):910-9. [pmid: 1946625].
116 Southwood TR, Malleson PN. Antinuclear antibodies and juvenile chronic arthritis (JCA): Search for a specific autoantibody associated with JCA. ANN RHEUM DIS. 1991;50(9):593-8.
117 Ansell BM. Juvenile chronic arthritis, juvenile rheumatoid arthritis, and inflammatory arthropathies of childhood. Current Opinion in Rheumatology. 1990;2(5):799-803. [pmid: 2265077].
118 Miller JJ III. Immunologic abnormalities of juvenile arthritis. Clinical Orthopaedics and Related Research. 1990;(259):23-30. [pmid: 2208861].
119 Martini A. Immunological approach to juvenile rheumatoid arthritis. [French]. Annales de Pediatrie. 1988;35(8):555-8. [pmid: 3059960].
120 John M, John V, Oppermann J. Laboratorial findings in the case of juvenile chronic arthritis. [German]. Zeitschrift fur Klinische Medizin. 1985;40(19):1445-8.
121 Wahn V. Anti-immunoglobulins (rheumatoid factors) - Immunobiology and relevance in pediatric practice. [German]. Monatsschrift fur Kinderheilkunde. 1985;133(4):196-200.
122 Moore TL, Weiss TD. Immunologic studies in juvenile arthritis. Bulletin on the Rheumatic Diseases. 1982;32(3):25-9. [pmid: 6982089].
123 Gupta K, Chintu C, Raghu MB. Juvenile rheumatoid arthritis in Zambian children. East African Medical Journal. 1981;58(5):344-53. [pmid: 7285834].
124 Ulybina OV, Shakhbazyan IE, Komissarova IA. Significance of some cytochemical and immunological indices in the clinical characteristics of rheumatoid arthritis children. [Russian]. Pediatriya - Zhurnal im G N Speranskogo. 1980;59(4):40-4.
125 Keren DF. Antinuclear antibody testing. CLIN LAB MED. 2002;22(2):447-74. [pmid: 12134471].
126 Price S. Autoantibody profiles linked to ethnicity in pediatric SLE. Nature Reviews Rheumatology. 2009;5(4):182.
127 Schaller J, Wedgwood RJ. Juvenile rheumatoid arthritis: a review. Pediatrics. 1972;50(6):940. [pmid: 4564600].
128 De AT, Davey R, Solanki K, et al. Systemic lupus erythematosus (SLE) in a paediatric unit. New Zealand Medical Journal. 2010;123(1313):77-9.
129 Kobayashi R, Mii S, Nakano T, et al. Neonatal lupus erythematosus in Japan: A review of the literature. Autoimmunity Reviews. 2009;8(6):462-6. [pmid: 19162245].

### Population (N = 77)

The following studies were excluded because the study population was not consisted primarily of individuals ≤ 18 years with a diagnosis of JIA, SLE, or with undiagnosed MSK pain .

1 Allen RC, Dewez P, Stuart L, et al. Antinuclear antibodies using HEp-2 cells in normal children and in children with common infections. Journal of Paediatrics & Child Health. 1991;27(1):39-42. [pmid: 2043388].
2 Alpigiani MG, Cerboni M, Bertini I, et al. Endocrine autoimmunity in young patients with juvenile chronic arthritis. Clinical & Experimental Rheumatology. 2002;20(4):565-8. [pmid: 12175117].
3 Arinola OG, Salimonu LS. Rheumatoid factor in sera of Nigerian school children with unrinary schistosomiasis. African Journal of Medicine & Medical Sciences. 2000;29(3–4):329-30. [pmid: 11714018].
4 Attar SM, Bunting PS, Smith CD, et al. Comparison of the anti-cyclic citrullinated peptide and rheumatoid factor in rheumatoid arthritis at an arthritis center. Saudi Medical Journal. 2009;30(3):446-7. [pmid: 19271083].
5 Awoyinfa JD, Batubo TA, McFarlane H, et al. Rheumatoid factor in Nigerians. African Journal of Medical Sciences. 1971;2(1):49-55. [pmid: 4106444].
6 Barone C, Bartoloni C, Gentiloni N, et al. Systemic lupus erythematosus with only IgE-class antinuclear antibodies. Arthritis & Rheumatism. 1981;24(11):1441-3. [pmid: 6976171].
7 Berkun Y, Zandman-Goddard G, Barzilai O, et al. Infectious antibodies in systemic lupus erythematosus patients. Lupus. 2009;18(13):1129-35. [pmid: 19880558].
8 Bonaguri C, Melegari A, Dall’Aglio P, et al. An italian multicenter study for application of a diagnostic algorithm in autoantibody testing. Annals of the New York Academy of Sciences. 2009;1173:124-9. [pmid: 19758140].
9 Bortolotti F, Vajro P, Balli F, et al. Non-organ specific autoantibodies in children with chronic hepatitis C. Journal of Hepatology. 1996;25(5):614-20. [pmid: 8938535].
10 Carreno L, Lopez-Longo FJ, Monteagudo I, et al. Immunological and clinical differences between juvenile and adult onset of systemic lupus erythematosus. Lupus. 1999;8(4):287-92. [pmid: 10413207].
11 Che Maraina CH, Rusni D, Azwany YN. Do antibodies against modified citrullinated vimentin have a value in the ACR criteria for rheumatoid arthritis?. 2010:62.
12 Correia ML, Carvalho S, Fortuna J, et al. Comparison of three anti-CCP antibody tests and rheumatoid factor in RA and control patients. Clinical Reviews in Allergy and Immunology. 2008;34(1):21-5. [pmid: 18270853].
13 DeHoratius RJ, Pillarisetty R, Messner RP, et al. Anti-nucleic acid antibodies in systemic lupus erythematosus patients and their families. Incidence and correlation with lymphocytotoxic antibodies. Journal of Clinical Investigation. 1975;56(5):1149-54. [pmid: 1081099].
14 Dias BL, Imamura EU, Izumi AP, et al. Juvenile idiopathic arthritis with dry synovitis: clinical case and review of literature. [Portuguese]. Acta Reumatologica Portuguesa. 2009;34(3):541-5. [pmid: 19820678].
15 El-Awady HM, El-Wakkad ASE-D, Saleh MT, et al. Serum Melatonin in Juvenile Rheumatoid Arthritis: Correlation with Disease Activity. Pakistan Journal of Biological Sciences. 2007;10(9):1471-6. [pmid: 19069959].
16 El-Chennawi FA, Mosaad YM, Habib HM, et al. Comparative study of antinuclear antibody detection by indirect immunofluorescence and enzyme immunoassay in lupus patients. Immunological Investigations. 2009;38(8):839-50. [pmid: 19860592].
17 El-Sehemy MS, Al-Saaran AM, Baddour NM, et al. Comparative clinical prospective therapeutic study between cyclophosphamide, cyclosporine and azathioprine in the treatment of lupus nephritis. The Egyptian journal of immunology / Egyptian Association of Immunologists. 2006;13:39-52. [pmid: 17974149].
18 Ferreira M, Salgueiro AB, Estrada J, et al. Lupus erythematosus. [Portuguese]. Acta Medica Portuguesa. 2008;21(2):199-204. [pmid: 18625099].
19 Frot AS, Barbarot S, Poignant S, et al. Ecchymotic angioedema revealing childhood systemic lupus erythematosus with anti-C1q antibodies. [French]. Annales de Dermatologie et de Venereologie. 2008;135(8–9):584-6. [pmid: 18789294].
20 Ganesh R, Ramalingam V, Eswara RT, et al. Antinuclear antibodies in Mycobacterium tuberculosis infection. INDIAN J PEDIATR. 2008;75(11):1188. [pmid: 18810350].
21 Gillespie JP, Lindsley CB, Linshaw MA, et al. Childhood systemic lupus erythematosus with negative antinuclear antibody test. J Pediatric. 1981;98(4):578-81.
22 Gregorio GV, Jones H, Choudhuri K, et al. Autoantibody prevalence in chronic hepatitis B virus infection: effect in interferon alfa. Hepatology. 1996;24(3):520-3. [pmid: 8781317].
23 Gregorio GV, Pensati P, Iorio R, et al. Autoantibody prevalence in children with liver disease due to chronic hepatitis C virus (HCV) infection. Clinical & Experimental Immunology. 1998;112(3):471-6. [pmid: 9649217].
24 Gregorio GV, Davies ET, Mieli-Vergani G, et al. Significance of extractable nuclear antigens in childhood autoimmune liver disease. Clinical & Experimental Immunology. 1995;102(2):308-13. [pmid: 7586683].
25 Hafez M, El-Battoty MF, Hawas S, et al. Susceptibility to and severity of rheumatoid arthritis in multicase families. British Journal of Rheumatology. 1991;30(3):181-5. [pmid: 2049577].
26 Hamade IH, Al Shamsi HN, Al DH, et al. Uveitis survey in children. British Journal of Ophthalmology. 2009;93(5):569-72. [pmid: 19074918].
27 Hazzan R, Mukamel M, Yacobovich J, et al. Risk factors for future development of systemic lupus erythematosus in children with idiopathic thrombocytopenic purpura. Pediatric Blood & Cancer. 2006;47(5):657-9. [pmid: 16933242].
28 Hedberg H. The total complement activity of synovial fluid in juvenile forms of arthritis. Acta Rheumatologica Scandinavica. 1971;17(4):279-85. [pmid: 5156884].
29 Hodkinson B, Meyer PW, Musenge E, et al. The diagnostic utility of the anti-CCP antibody test is no better than rheumatoid factor in South Africans with early rheumatoid arthritis. Clinical Rheumatology. 2010;29(6):615-8. [pmid: 20127131].
30 Itoh Y, Fukunaga Y, Igarashi T, et al. Autoimmunity in chronic fatigue syndrome in children. Japanese Journal of Rheumatology. 1998;8(4):429-37.
31 Jundt JW, Creager AH. Star Complexes - Febrile Illnesses Associated with Sore Throat, Arthritis, and Rash. Southern Medical Journal. 1993;86(5):521-8. [pmid: 8488398].
32 Kang M, Wang HW, Cheng PX, et al. Lack of association between mannose-binding lectin gene polymorphisms and juvenile idiopathic arthritis in a Han population from the Hubei province of China. Arthritis Research & Therapy. 2006;8(4):R85. [pmid: 16681863].
33 Kasapcopur O, Ozbakir F, Arisoy N, et al. Frequency of antinuclear antibodies and rheumatoid factor in healthy Turkish children. Turkish Journal of Pediatrics. 1999;41(1):67-71. [pmid: 10770678].
34 Kenesi-Laurent M-A, Kaplan G, Kahn M-F. Oligoarthritis with antinuclear antibodies. A new syndrome equivalent to juvenile oligoarthritis with ANA. [French]. Revue du Rhumatisme et des Maladies Osteo-Articulaires. 1991;58(1):1-6. [pmid: 1871514].
35 Kotaniemi K, Kaipiainen-Seppanen O, Savolainen A, et al. A population-based study on uveitis in juvenile rheumatoid arthritis. Clinical & Experimental Rheumatology. 1999;17(1):119-22. [pmid: 10084046].
36 Krishnan C, Kaplan MH. Immunopathologic studies of systemic lupus erythematosus. II. Antinuclear reaction of gamma-globulin eluted from homogenates and isolated glomeruli of kidneys from patients with lupus nephritis. Journal of Clinical Investigation. 1967;46(4):569-79. [pmid: 4164260].
37 Kurahara D, Tokuda A, Grandinetti A, et al. Ethnic differences in risk for pediatric rheumatic illness in a culturally diverse population. J RHEUMATOL. 2002;29(2):379-83. [pmid: 11838859].
38 Kuwabara N, Itoh Y, Igarshi T, et al. Autoantibodies to lens epithelium-derived growth factor/transcription co-activator P75 (LEDGF/P75) in children with chronic nonspecific complaints and with positive antinuclear antibodies. Autoimmunity. 2009;42(6):492-6. [pmid: 19657776].
39 Lehman TJ, Curd JG, Zvaifler NJ, et al. The association of antinuclear antibodies, antilymphocyte antibodies, and C4 activation among the relatives of children with systemic lupus erythematosus. Arthritis & Rheumatism. 1982;25(5):556-61. [pmid: 6979340].
40 Levcovitz H, Fletcher MA, Phillips P, et al. Segragation of lymphocyte low-molecular-weight DNA and antinuclear-antibodies in a family with systemic lupus erythematosus in first cousins. Human Genetics. 1988;80(3):253-8. [pmid: 3263937].
41 Limaye S, Carr V, Kirkpatrich P, et al. Antibodies to cyclic citrullinated peptide in patients with chronic arthritis attending an arthritis-monitoring clinic. Journal of Clinical Rheumatology. 2005;11(3):150-2. [pmid: 16357734].
42 Linnik MD, Hu JZ, Heilbrunn KR, et al. Relationship between anti-double-stranded DNA antibodies and exacerbation of renal disease in patients with systemic lupus erythematosus. Arthritis and rheumatism. 2005;52:1129-37. [pmid: 15818711].
43 Lu M-C, Hsieh S-C, Lai N-S, et al. Comparison of anti-agalactosyl IgC antibodies, rheumatoid factors, and anti-cyclic citrullinated peptide antibodies in the differential diagnosis of rheumatoid arthritis and its mimics. Clinical and experimental rheumatology. 2007;25(5):716-21. [pmid: 18078619].
44 Macarthur C, Wright JG, Srivastava R, et al. Variability in physicians’ reported ordering and perceived reassurance value of diagnostic tests in children with ‘growing pains’. ARCH PEDIATR ADOLESC MED. 1996;150(10):1072-6. [pmid: 8859141].
45 Maury CP, Teppo AM, Wafin F, et al. Class-specific rheumatoid factors, DR antigens, and amyloidosis in patients with rheumatoid arthritis. ANN RHEUM DIS. 1988;47(7):546-52. [pmid: 3401051].
46 Menard HA. Anti-CCP versus anti-Sa antibodies for the diagnosis of RA: Commentary. Nature Clinical Practice Rheumatology. 2007;3(2):76-7.
47 Milde EJ, Tonder O. Demonstration of rheumatoid factor in tissue by mixed agglutination with tissue sections. Arthritis & Rheumatism. 1968;11(4):537-45. [pmid: 4877799].
48 Mine T, Tanaka H, Ishida Y, et al. Juvenile rheumatoid arthritis manifesting in only limping due to flexion contraction of the knee. Clinical Rheumatology. 2007;26(3):433-5. [pmid: 16440136].
49 Moore TL, Bandlamudi R, Alam SM, et al. Parvovirus infection mimicking systemic lupus erythematosus in a pediatric population. SEMIN ARTHRITIS RHEUM. 1999;28(5):314-8. [pmid: 10342388].
50 Nair JR, Mewar D. Evaluation of the clinical utility of anti-CCP antibody test in daily clinical practice. 2010:i166.
51 Oen K, El-Gabalawy HS, Canvin JMG, et al. HLA associations of seropositive rheumatoid arthritis in a Cree and Ojibway population. J RHEUMATOL. 1998;25(12):2319-23. [pmid: 9858424].
52 Orme A, Luthy KE. The case of the silent crippler. Journal of Pediatric Health Care. 2009;23(3):180-5. [pmid: 19401251].
53 Pachman LM, Jayanetra P, Rothberg RM. Rheumatoid sera and soluble complexes: nitroblue tetrazolium dye test and hexose monophosphate shunt activation. Pediatrics. 1973;52(6):823. [pmid: 4769001].
54 Pottel H, Wiik A, Locht H, et al. Clinical optimization and multicenter validation of antigen-specific cut-off values on the INNO-LIA[trademark] ANA update for the detection of autoantibodies in connective tissue disorders. Clinical and experimental rheumatology. 2004;22(5):579-88. [pmid: 15485011].
55 Prinz JC, Kutasi Z, Weisenseel P, et al. “Borrelia-associated early-onset morphea”: A particular type of scleroderma in childhood and adolescence with high titer antinuclear antibodies? Results of a cohort analysis and presentation of three cases”. Journal of the American Academy of Dermatology. 2009;60(2):248-55. [pmid: 19022534].
56 Reiff A, Takei S, Sadeghi S, et al. Etanercept therapy in children with treatment-resistant uveitis. Arthritis & Rheumatism. 2001;44(6):1411-5. [pmid: 11407702].
57 Sarma PK, Agrawal S, Aggarwal A, et al. Systemic lupus erythematosus with major organ involvement in a patient with systemic-onset juvenile idiopathic arthritis. J RHEUMATOL. 2007;34(4):893-4. [pmid: 17407252].
58 Savolainen E, Kaipiainen-Seppanen O, Kroger L, et al. Total incidence and distribution of inflammatory joint diseases in a defined population: results from the Kuopio 2000 arthritis survey. J RHEUMATOL. 2003;30(11):2460-8. [pmid: 14677193].
59 Shen JY, Chen SL, Wu YX, et al. Pulmonary hypertension in systemic lupus erythematosus. Rheumatology International. 1999;18:147-51. [pmid: 10220835].
60 Slater CA, Davis RB, Shmerling RH. Antinuclear antibody testing. A study of clinical utility. Arch Int Med. 1996;156(13):1421-5. [pmid: 8678710].
61 Southwood TR, Petty RE, Malleson PN, et al. Psoriatic arthritis in children. Arthritis & Rheumatism. 1989;32(8):1007-13. [pmid: 2765001].
62 Souza LDL, Gallinaro AL, Abdo CHN, et al. Effect of Musculoskeletal Pain on Sexuality of Male Adolescents and. Adults with Juvenile Idiopathic Arthritis. J RHEUMATOL. 2009;36(6):1337-42. [pmid: 19411396].
63 Szanto A, Szodoray P, Kiss E, et al. Clinical, serologic, and genetic profiles of patients with associated Sjogren’s syndrome and systemic lupus erythematosus. Human Immunology. 2006;67(11):924-30. [pmid: 17145372].
64 Tampoia M, Brescia V, Fontana A, et al. Application of a combined protocol for rational request and utilization of antibody assays improves clinical diagnostic efficacy in autoimmune rheumatic disease. ARCH PATHOL LAB MED. 2007;131(1):112-6. [pmid: 17227110].
65 Tsiakalou V, Tsangaridou E, Polioudaki H, et al. Optimized detection of circulating anti-nuclear envelope autoantibodies by immunofluorescence. BMC Immunology. 2006;7:20. [pmid: 16956395].
66 Ursum J, Bos WH, van de Stadt RJ, et al. Different properties of ACPA and IgM-RF derived from a large dataset: further evidence of two distinct autoantibody systems. Arthritis Research & Therapy. 2009;11(3):R75. [pmid: 19460147].
67 Valladares GC, Rus MA, Sanchez-Molina Acosta MI, et al. Measurement of anti-CCP antibodies for the diagnosis of rheumatoid arthritis. [Spanish]. Quimica Clinica. 2003;22(6):397-402.
68 van-Jaarsveld CH, ter-Borg EJ, Jacobs JW, et al. The prognostic value of the antiperinuclear factor, anti-citrullinated peptide antibodies and rheumatoid factor in early rheumatoid arthritis. Clinical and experimental rheumatology. 1999;17:689-97. [pmid: 10609067].
69 Vojdani A. Antibodies as predictors of complex autoimmune diseases. International Journal of Immunopathology and Pharmacology. 2008;21(2):267-78. [pmid: 18547471].
70 Waller M. Correlation between diagnosis and results of serologic tests for antiglobulin antibodies. American Journal of Medicine. 1973;54(6):731-4. [pmid: 4540947].
71 Wandstrat AE, Carr-Johnson F, Branch V, et al. Autoantibody profiling to identify individuals at risk for systemic lupus erythematosus. Journal of Autoimmunity. 2006;27(3):153-60. [pmid: 17052888].
72 Wijeyesinghe U, Russell AS. Outcome of high titer antinuclear antibody positivity in individuals without connective tissue disease: A 10-year follow-up. Clinical Rheumatology. 2008;27(11):1399-402. [pmid: 18500432].
73 Willemze A, Ioan-Facsinay A, El-Gabalawy H. Anti-citrullinated protein antibody response associated with synovial immune deposits in a patient with suspected early rheumatoid arthritis. J RHEUMATOL. 2008;35(11):2282-4. [pmid: 19004060].
74 Yachha SK, Srivastava A, Chetri K, et al. Autoimmune liver disease in children. Journal of Gastroenterology & Hepatology. 2001;16(6):674-7. [pmid: 11422621].
75 Yi Z, Xin T, Zhanguo L. Prevalence and clinical significance of antibodies to citrullinated fibrinogen (ACF) in Chinese patients with rheumatoid arthritis. Clinical Rheumatology. 2007;26(9):1505-12. [pmid: 17661121].
76 Zha QL, He YT, Yu JP. Correlations between diagnostic information and therapeutic efficacy in rheumatoid arthritis analyzed with decision tree model. Chinese journal of integrated traditional and Western medicine. 2006;26:871-6. [pmid: 17121034].
77 Zierhut M, Doycheva D, Biester S, et al. How to manage therapy-resistant rheumatic uveitis. [German]. Aktuelle Rheumatologie. 2007;32(5):278-80.

### Index test (N = 64)

The following studies were excluded because the index tests were not ANA, RF, and/or CCP.

1 Adib N, Silman A, Thomson W. Outcome following onset of juvenile idiopathic inflammatory arthritis: II. predictors of outcome in juvenile arthritis. Rheumatology. 2005;44(8):1002-7. [pmid: 15827044].
2 Anderson CJ, Neas BR, Uchiumi T, et al. Autoantibodies to the 20-kDa ribosomal proteins: Identification, characterization, and new aspects on prevalence in systemic lupus erythematosus. Clin Immunol. 2001;98(2):249-57. [pmid: 11161982].
3 Ansell BM, Holborow J, Zutshi D, et al. Comparison of three serological tests in adult rheumatoid arthritis and Still’s disease (juvenile rheumatoid arthritis). Ann N Y Acad Sci. 1969;168(1):21-9. [pmid: 5310583].
4 Bader-Meunier B, Armengaud JB, Haddad E, et al. Initial presentation of childhood-onset systemic lupus erythematosus: a French multicenter study. J Pediatr. 2005;146(5):648-53. [pmid: 15870669].
5 Barnes MG, Grom AA, Thompson SD, et al. Subtype-specific peripheral blood gene expression profiles in recent-onset juvenile idiopathic arthritis. Arthritis Rheum. 2009;60(7):2102-12. [pmid: 19565513].
6 Barnett EV, NORTH AF Jr, CONDEMI JJ, et al. Antinuclear factors in systemic lupus erythematosus and rheumatoid arthritis. Ann Intern Med. 1965;63:100-8. [pmid: 14305956].
7 Barraclough D, Russell AS, Percy JS. Diagnosis and follow-up of children referred to a rheumatic disease unit. Med J Aust. 1977;1(25):920-3. [pmid: 301982].
8 Beresford MW, Cleary G, Sills JA, et al. Delayed diagnosis: JIA in children with learning difficulties. Rheumatology. 2005;44:292.
9 Boone MI, Moore TL, Cruz OA. Screening for uveitis in juvenile rheumatoid arthritis. J Pediatr Ophthalmol Strabismus. 1998;35(1):41-3. [pmid: 9503315].
10 Calabro JJ, Parrino GR, Atchoo PD, et al. Chronic iridocyclitis in juvenile rheumatoid arthritis. Arthritis Rheum. 1970;13(4):406-13. [pmid: 5310717].
11 Chen Y-S, Yang Y-H, Lin Y-T, et al. Risk of infection in hospitalised children with systemic lupus erythematosus: A 10-year follow-up. Clin Rheumatol. 2004;23(3):235-8. [pmid: 15168152].
12 Chudwin DS, Ammann AJ, Cowan MJ, et al. Significance of a positive antinuclear antibody test in a pediatric population. Am J Dis Child. 1983;137(11):1103-6. [pmid: 6356882].
13 Cleary AG, Lancaster GA, Annan F, et al. Nutritional impairment in juvenile idiopathic arthritis. Rheumatology. 2004;43(12):1569-73. [pmid: 15466896].
14 Craft AW, Eastham EJ, Bell JI, et al. Serum ferritin in juvenile chronic polyarthritis. Ann Rheum Dis. 1977;36(3):271-3. [pmid: 879866].
15 De IJ. Epidemiology of musculoskeletal pain in primary care. Arch Dis Child. 2004;89(5):431-4. [pmid: 15102634].
16 Dippell J. Hidden IgM rheumatoid factor in chronic juvenile arthritis. An open multicenter diagnostic study. [German]. Monatsschr Kinderheilkd. Organ. 1989;(9):606-9. [pmid: 2811884].
17 Ehrmann FD, Bernatsky S, Abrahamowicz M, et al. Consultation with an arthritis specialist for children with suspected juvenile rheumatoid arthritis: a population-based study. Arch Pediatr Adolesc Med. 2008;162(6):538-43. [pmid: 18524744].
18 Foster HE, Eltringham MS, Kay LJ, et al. Delay in access to appropriate care for children presenting with musculoskeletal symptoms and ultimately diagnosed with juvenile idiopathic arthritis. Arthritis Rheum. 2007;57(6):921-7. [pmid: 17665486].
19 Fujikawa S, Okuni M. Clinical analysis of 570 cases with juvenile rheumatoid arthritis: results of a nationwide retrospective survey in Japan. Acta Paediatr Jpn. 1997;39(2):245-9. [pmid: 9141266].
20 Goel KM, Shanks RA. Follow-up study of 100 cases of juvenile rheumatoid arthritis. Ann Rheum Dis. 1974;33(1):25-31. [pmid: 4856607].
21 Griffiths B, Mosca M, Gordon C. Assessment of patients with systemic lupus erythematosus and the use of lupus disease activity indices. Best Pract Res Clin Rheumatol. 2005;19(5 SPEC. ISS):685-708. [pmid: 16150398].
22 Guillaume S, Prieur AM, Coste J, et al. Long-term outcome and prognosis in oligoarticular-onset juvenile idiopathic arthritis. Arthritis Rheum. 2000;43(8):1858-65. [pmid: 10943877].
23 Heinlen LD, McClain MT, Kim X, et al. Anti-Ro and anti-nRNP response in unaffected family members of SLE patients. Lupus. 2003;12(4):335-7. [pmid: 12729062].
24 Ilowite NT, Wedgwood JF, Bonagura VR. Expression of the major rheumatoid factor cross-reactive idiotype in juvenile rheumatoid arthritis. Arthritis Rheum. 1989;32(3):265-70. [pmid: 2930601].
25 Jesus AA, Silva CA, Carneiro-Sampaio M, et al. Anti-C1q antibodies in juvenile-onset systemic lupus erythematosus. Ann N Y Acad Sci. 2009;1173:235-8. [pmid: 19758156].
26 Kobayashi S, Wada N, Kubo M. Autoantibodies to native human type II collagen in the sera of patients with juvenile rheumatoid arthritis. Japan J Rheumatol. 1991;3(4):265-74.
27 Konijnenberg AY, De Graeff-Meeder ER, Kimpen JL, et al. Children with unexplained chronic pain: do pediatricians agree regarding the diagnostic approach and presumed primary cause?. Pediatrics. 2004;114(5):1220-6. [pmid: 15520099].
28 Kornreich HK, Drexler E, Hanson V. Antinulear factors in childhood rheumatic diseases. J Pediatr. 1966;69(6):1039-45. [pmid: 5297059].
29 Kotaniemi K, Savolainen A, Karma A, et al. Recent advances in uveitis of juvenile idiopathic arthritis. Surv Ophthalmol. 2003;48(5):489-502. [pmid: 14499817].
30 Kotaniemi K. Uveitis in juvenile idiopathic arthritis. Acta Ophthalmol Scand. 2002;80(2):226.
31 Krumrey-Langkammerer M, Hafner R. Evaluation of the ILAR criteria for juvenile idiopathic arthritis. J Rheumol. 2001;28(11):2544-7.
32 Len CA, Terreri MT, Puccini RF, et al. Development of a tool for early referral of children and adolescents with signs and symptoms suggestive of chronic arthropathy to pediatric rheumatology centers. Arthritis Rheum. 2006;55(3):373-7. [pmid: 16739205].
33 Maeno N, Takei S, Fujikawa S, et al. Antiagalactosyl IgG antibodies in juvenile idiopathic arthritis, juvenile onset Sjogren’s syndrome, and healthy children. J Rheumol. 2004;31(6):1211-7.
34 Marini R, Costallat LT. Young age at onset, renal involvement, and arterial hypertension are of adverse prognostic significance in juvenile systemic lupus erythematosus. Rev Rhum (English Edition). 1999;66(6):303-9.
35 Mason T, Reed AM, Nelson AM, et al. Radiographic progression in children with polyarticular juvenile rheumatoid arthritis: a pilot study. Ann Rheum Dis. 2005;64(3):491-3. [pmid: 15708901].
36 McBride JD, Gabriel FG, Fordham J, et al. Screening autoantibody profiles in systemic rheumatic disease with a diagnostic protein microarray that uses a filtration-assisted nanodot array luminometric immunoassay (NALIA). Clin Chem. 2008;54(5):883-90. [pmid: 18356243].
37 Mikkelsson M, Sourander A, Salminen JJ, et al. Widespread pain and neck pain in schoolchildren. A prospective one-year follow-up study. Acta Paediatr. 1999;88(10):1119-24. [pmid: 10565460].
38 Minden K, Mingels A, Niewerth M, et al. Juvenile idiopathic arthritis and uveitis: Epidemiology including data from a national database. [German]. Klin Monbl Augenheilkd. 2007;224(6):469-72. [pmid: 17594614].
39 Miller JJ. Immunologic abnormalities of juvenile arthritis. Clin Orthop Relat Res. 1990;(259):23-30. [pmid: 2208861].
40 Moore T, Dorner RW, Zuckner J. Hidden rheumatoid factor in seronegative juvenile rheumatoid arthritis. Ann Rheum Dis. 1974;33(3):255-7. [pmid: 4546351].
41 Moore TL, Dorner RW, Zuckner J. Complement-fixing hidden rheumatoid factor in children with benign rheumatoid nodules. Arthritis Rheum. 1978;21(8):930-4. [pmid: 737016].
42 Moore TL, Dorner RW, Weiss TD, et al. Hidden 19S IgM rheumatoid factor in juvenile rheumatoid arthritis. Pediatr Res. 1980;14(10):1135-8. [pmid: 7465283].
43 Moore TL, Dorner RW, Osborn TG, et al. Hidden 19S IgM rheumatoid factors. Semin Arthritis Rheum. 1988;18(1):72-5. [pmid: 3187544].
44 Moore TL, el-Najdawi E, Dorner RW. IgM rheumatoid factor plaque-forming cells in juvenile rheumatoid arthritis. Arthritis Rheum. 1987;30(3):335-8. [pmid: 3551966].
45 Moore TL, Dorner RW, Sheridan PW, et al. Precipitation of 19S IgM rheumatoid factor-IgG circulating immune complexes in patients with juvenile arthritis by polyethylene glycol and separation by immobilized protein A. Clin Exp Immunol. 1984;56(2):247-52. [pmid: 6733970].
46 Moore TL, Dorner RW, Weiss TD, et al. Specificity of hidden 19S IgM rheumatoid factor in patients with juvenile rheumatoid arthritis. Arthritis Rheum. 1981;24(10):1283-90. [pmid: 7306229].
47 Moore TL, Zuckner J, Baldassare AR, Weiss TD, Dorner RW. Complement-fixing hidden rheumatoid factor in juvenile rheumatoid arthritis. ARTHRITIS RHEUM. 1978;21(8):935-941. [pmid: 737017].
48 Nesher G, Moore TL, Grisanti MW, et al. Antiperinuclear factor in juvenile rheumatoid arthritis. Ann Rheum Dis. 1992;51(3):350-2. [pmid: 1575580].
49 Neuer G, Bustin M, Michels H, et al. Autoantibodies to the chromosomal protein HMG-17 in juvenile rheumatoid arthritis. Arthritis Rheum. 1992;35(4):472-5. [pmid: 1567496].
50 Oen K, Reed M, Malleson PN, et al. Radiologic outcome and its relationship to functional disability in juvenile rheumatoid arthritis. J Rheumol. 2003;30(4):832-40.
51 Okano T, Satoh M, Akizuki M. Immunologic tests: Anti SS-A/Ro, anti SS-B/La antibody. [Japanese]. Nippon Rinsho - Nippon Rinsho. 2005;63. Suppl-8.
52 Perilloux BC, Shetty AK, Leiva LE, et al. Antinuclear antibody (ANA) and ANA profile tests in children with autoimmune disorders: a retrospective study. Clin Rheumatol. 2000;19(3):200-3. [pmid: 10870654].
53 Petty RE, Cassidy JT, Sullivan DB. Clinical correlates of antinuclear antibodies in juvenile rheumatoid arthritis. J Pediatr. 1973;83(3):386-9. [pmid: 4579718].
54 Pongpanich B, Daengroongroj P. Juvenile rheumatoid arthritis: clinical characteristics in 100 Thai patients. Clin Rheumatol. 1988;7(2):257-61. [pmid: 3416569].
55 Rangel L, Garralda ME, Hall A, et al. Psychiatric adjustment in chronic fatigue syndrome of childhood and in juvenile idiopathic arthritis. Psychol Med. 2003;33(2):289-97. [pmid: 12622307].
56 Rask CU, Olsen EM, Elberling H, et al. Functional somatic symptoms and associated impairment in 5–7-year-old children: the Copenhagen Child Cohort 2000. Eur J Epidemiol. 2009;24(10):625-34. [pmid: 19633995].
57 Rood MJ, ten CR, Van Suijlekom-Smit LWA, et al. Childhood-onset systemic lupus erythematosus. Scand J Rheumatol. 1999;28(4):222-6. [pmid: 10503558].
58 Schur PH, Sandson J. Immunologic factors and clinical activity in systemic lupus erythematosus. N Engl J Med. 1968;278(10):533-8. [pmid: 4866347].
59 Shapiro C, Maenz L, Hossain A, et al. Onset to first visit intervals in childhood rheumatic diseases. J Rheumol. 2007;34(9):1913-7.
60 Steffen C, Sanger L, Menzel J. Demonstration of antibodies to denatured type I and type II collagen in juvenile rheumatoid arthritis, Still’s syndrome and controls by [14C] collagen radioimmunoassay. Scand J Rheumatol. 1980;9(2):69-76. [pmid: 7001617].
61 Takei S, Maeno N, Shigemori M, et al. Clinical features of Japanese children and adolescents with systemic lupus erythematosus: results of 1980–1994 survey. Acta Paediatr Jpn. 1997;39(2):250-6. [pmid: 9141267].
62 Walker SM, McCurdy DK, Shaham B, Brik R, Wietting H, Arora Y, et al. High prevalence of IgA rheumatoid factor in severe polyarticular-onset juvenile rheumatoid arthritis, but not in systemic-onset or pauciarticular-onset disease. Arthritis Rheum. 1990;33(2):199-204. [pmid: 2306290].
63 Wu JF, Yang YH, Wang LC, et al. Antinucleosome antibodies correlate with the disease severity in children with systemic lupus erythematosus. J Autoimmun. 2006;27(2):119-24. [pmid: 16919912].
64 Yanni G, Bresnihan B. Experience with a juvenile rheumatology clinic. Ir J Med Sci Science. 1991;160(7):197-8.

### Reference standard (N = 7)

The following studies did not have JIA or SLE as the reference standard.

1 Adib N, Davies K, Grahame R, et al. Joint hypermobility syndrome in childhood. A not so benign multisystem disorder?. Rheumatology. 2005;44(6):744-50. [pmid: 15728418].
2 Cabral DA, Petty RE, Fung M, et al. Persistent antinuclear antibodies in children without identifiable inflammatory rheumatic or autoimmune disease. Pediatrics. 1992;89(3):441-4. [pmid: 1741219].
3 Freed GL, Jee S, Stein L, et al. Comparing the self-reported referral and management preferences of pediatricians and family physicians for children with juvenile rheumatoid arthritis. J Rheumol. 2003;30(12):2700-4.
4 Goel KM, Logan RW, Barnard WP, et al. Serum immunoglobulin and beta 1C-beta 1A globulin concentrations in juvenile rheumatoid arthritis. Ann Rheum Dis. 1974;33(1):35-8. [pmid: 4132378].
5 Gulez N, Karaca NE, Aksu G, et al. Increased percentages of autoantibodies in immunoglobulin A-deficient children do not correlate with clinical manifestations. Autoimmunity. 2009;42(1):74-9. [pmid: 19127458].
6 Rosenberg AM. Longitudinal analysis of a pediatric rheumatology clinic population. J Rheumol. 2005;32(10):1992-2001.
7 sadi-Pooya AA, Bordbar MR. Are laboratory tests necessary in making the diagnosis of limb pains typical for growing pains in children?. Pediatr Int. 2007;49(6):833-5. [pmid: 18045281].

### Outcome data (N = 155)

The following studies were excluded because they did not report sufficient numeric data on test result.

1 Abdwani R, Rizvi SG, El-Nour I. Childhood systemic lupus erythematosus in Sultanate of Oman: demographics and clinical analysis. Lupus. 2008;17(7):683-6. [pmid: 18625643].
2 Agarwal I, Kumar TS, Ranjini K, et al. Clinical features and outcome of systemic lupus erythematosus. Indian Pediatrics. 2009;46(8):711-5. [pmid: 19213981].
3 Agarwal V, Misra R, Aggarwal A. Immune complexes contain immunoglobulin A rheumatoid factor in serum and synovial fluid of patients with polyarticular juvenile rheumatoid arthritis. Rheumatology. 2002;41(4):466-7. [pmid: 11961181].
4 Aggarwal A, Misra R. Juvenile chronic arthritis in India: is it different from that seen in Western countries?. Rheumatology International. 1994;14(2):53-6. [pmid: 7529938].
5 Aggarwal A, Misra RN. Juvenile rheumatoid arthritis in India--rarity of antinuclear antibody and uveitis. INDIAN J PEDIATR. 1996;63(3):301-4. [pmid: 10830005].
6 Aggarwal A, Dabadghao S, Naik S, et al. Serum IgM rheumatoid factor by enzyme linked immunosorbent assay (ELISA) delineates a subset of patients with deforming joint disease in seronegative juvenile rheumatoid arthritis. Rheumatology International. 1994;14(4):135-8. [pmid: 7871331].
7 Akinci A, Cakar N, Uncu N, et al. Keratoconjunctivitis sicca in juvenile rheumatoid arthritis. Cornea. 2007;26(8):941-4. [pmid: 17721292].
8 Al-Matar MJ, Petty RE, Tucker LB, et al. The early pattern of joint involvement predicts disease progression in children with oligoarticular (pauciarticular) juvenile rheumatoid arthritis. ARTHRITIS RHEUM. 2002;46(10):2708-15. [pmid: 12384930].
9 Al-Mosawi Z, Al-Hermi BE, Al-Saad KK, et al. Juvenile systemic lupus erythematosus in Bahrain. A tertiary referral center experience. Saudi Medical Journal. 2009;30(5):667-72. [pmid: 19417967].
10 Al-Wahadneh AM, bu-Zeid AF, Khreisat WH. Juvenile idiopathic oligoarthritis: analysis of 42 cases in Jordan. EAST MEDITERRANEAN HEALTH J. 2007;13(2):461-4.
11 Alsaeid K, Kamal H, Haider MZ, et al. Systemic lupus erythematosus in Kuwaiti children: organ system involvement and serological findings. Lupus. 2004;13(8):613-7. [pmid: 15462494].
12 Alsaeid K, Haider MZ, Sharma PN, et al. The prevalence of human leukocyte antigen (HLA) DR/DQ/DP alleles in Kuwaiti children with oligoarticular juvenile idiopathic arthritis. Rheumatology International. 2006;26(3):224-8. [pmid: 15703957].
13 Alspaugh MA, Miller JJ. A study of specificities of antinuclear antibodies in juvenile rheumatoid arthritis. J PEDIATR. 1977;90(3):391-5. [pmid: 300101].
14 Alvarez MC, Gonzalez FA, Lisbona MM, et al. Thyroid disorders and childhood rheumatic diseases. [Spanish]. Anales de Pediatria. 2009;70(1):53-6. [pmid: 19174120].
15 Andersson GB, Fasth A, Andersson J, et al. Incidence and prevalence of juvenile chronic arthritis: a population survey. ANN RHEUM DIS. 1987;46(4):277-81. [pmid: 3592782].
16 Arguedas O, Fasth A, ndersson-Gare B. A prospective population based study on outcome of juvenile chronic arthritis in Costa Rica. J RHEUMATOL. 2002;29(1):174-83. [pmid: 11824957].
17 Arguedas O, Porras O, Fasth A. Juvenile chronic arthritis in Costa Rica. A pilot referral study. Clinical & Experimental Rheumatology. 1995;13(1):119-23. [pmid: 7774091].
18 Arguedas O, Fasth A, ndersson-Gare B, et al. Juvenile chronic arthritis in urban San Jose, Costa Rica: a 2 year prospective study. J RHEUMATOL. 1998;25(9):1844-50. [pmid: 9733470].
19 Avcin T, Ambrozic A, Bozic B, et al. Estimation of anticardiolipin antibodies, anti-beta2 glycoprotein I antibodies and lupus anticoagulant in a prospective longitudinal study of children with juvenile idiopathic arthritis. Clinical & Experimental Rheumatology. 2002;20(1):101-8. [pmid: 11892692].
20 Bahabri S, Al-Sewairi W, Al-Mazyad A, et al. Juvenile rheumatoid arthritis: The Saudi experience. Annals of Saudi Medicine. 1997;17(4):413-8. [pmid: 17353592].
21 Bakr A. Epidemiology treatment and outcome of childhood systemic lupus erythematosus in Egypt. PEDIATR NEPHROL. 2005;20(8):1081-6. [pmid: 15940546].
22 Balkaran BN, Roberts LA, Ramcharan J. Systemic lupus erythematosus in Trinidadian children. Annals of Tropical Paediatrics. 2004;24(3):241-4. [pmid: 15479574].
23 Bardare M, De VM, Giani M, et al. Systemic lupus erythematosus in childhood: review of the literature and personal observations on 32 cases. [Italian]. Pediatria Medica e Chirurgica. 1990;12(6):577-86. [pmid: 2093878].
24 Berk AT, Kocak N, Unsal E. Uveitis in juvenile arthritis. Ocular Immunology & Inflammation. 2001;9(4):243-51. [pmid: 11935434].
25 Bernatsky S, Duffy C, Malleson P, et al. Economic impact of juvenile idiopathic arthritis. ARTHRITIS RHEUM. 2007;57(1):44-8. [pmid: 17266088].
26 Bharadwaj A, Aggarwal A, Misra R. Clinical relevance of IgA rheumatoid factor (RF) in children with juvenile rheumatoid arthritis. Rheumatology International. 1999;19(1–2):47-9. [pmid: 10651082].
27 Blockey NJ, Gibson AA, Goel KM. Monarticular juvenile rheumatoid arthritis. Journal of Bone & Joint Surgery - British Volume. 1980;62(3):368-71.
28 Bluestone RH, Goldberg LS, Katz R, et al. Juvenile rheumatoid arthritis: a serological survey of 200 consecutive patients. ANN RHEUM DIS. 1970;29(3):337-8. [pmid: 5310929].
29 Bolt IB, Cannizzaro E, Seger R, et al. Risk factors and longterm outcome of juvenile idiopathic arthritis-associated uveitis in Switzerland. J RHEUMATOL. 2008;35(4):703-6. [pmid: 18278829].
30 Buoncompagni A, Barbano GC, Pistoia V, et al. Childhood systemic lupus erythematosus: A review of 30 cases. Clinical and experimental rheumatology. 1991;9(4):425-30. [pmid: 1934695].
31 Burlingame RW, Rubin RL, Rosenberg AM. Autoantibodies to chromatin components in juvenile rheumatoid arthritis. ARTHRITIS RHEUM. 1993;36(6):836-41. [pmid: 8507226].
32 Butbul YA, Tyrrell PN, Schneider R, et al. Comparison of patients with juvenile psoriatic arthritis and nonpsoriatic juvenile idiopathic arthritis: how different are they?. J RHEUMATOL. 2009;36(9):2033-41. [pmid: 19648305].
33 Cerna M, Vavrincova P, Havelka S. HLA and juvenile rheumatoid arthritis. Acta Universitatis Carolinae - Medica. 1994;40(1–4):69-73. [pmid: 9355676].
34 Chacon DP, Quintero V, Chavez MEF, et al. Pediatric systemic lupus erythematosus: Characterization of 30 cases. [Spanish]. Salus. 2009;13(2):11-20.
35 Chandrasekaran AN, Rajendran CP, Madhavan R. Juvenile rheumatoid arthritis--Madras experience. INDIAN J PEDIATR. 1996;63(4):501-10. [pmid: 10832470].
36 Chen C-Y, Chen L-C, Yeh K-W, et al. Sequential changes to clinical parameters and adhesion molecules following intravenous pulse cyclophosphamide and methylprednisolone treatment of refractory juvenile idiopathic arthritis. Clinical and experimental rheumatology. 2004;22(2):259-64. [pmid: 15083898].
37 Crowe WE, Hug G, Chuck G. A study of the relationship of alpha_1_-antitrypsin phenotype to the occurrence and severity of juvenile rheumatoid arthritis. Arthritis and rheumatism. 1982;25(8):1010-2. [pmid: 6981415].
38 Cuesta IA, Kerr K, Simpson P, et al. Subspecialty referrals for pauciarticular juvenile rheumatoid arthritis. ARCH PEDIATR ADOLESC MED. 2000;154(2):122-5. [pmid: 10665597].
39 Deane PM, Liard G, Siegel DM, et al. The outcome of children referred to a pediatric rheumatology clinic with a positive antinuclear antibody test but without an autoimmune disease. Pediatrics. 1995;95(6):892-5. [pmid: 7761217].
40 Dolman KM, Brouwer N, Frakking FN, et al. Mannose-binding lectin deficiency is associated with early onset of polyarticular juvenile rheumatoid arthritis: a cohort study. Arthritis Research & Therapy. 2008;10(2):R32. [pmid: 18334024].
41 Dracou C, Constantinidou N, Constantopoulos A. Juvenile chronic arthritis profile in Greek children. Acta Paediatrica Japonica. 1998;40(6):558-63. [pmid: 9893290].
42 Edelsten C, Lee V, Bentley CR, et al. An evaluation of baseline risk factors predicting severity in juvenile idiopathic arthritis associated uveitis and other chronic anterior uveitis in early childhood. British Journal of Ophthalmology. 2002;86(1):51-6. [pmid: 11801504].
43 Egeskjold EM, Hoyeraal HM, Permin H, et al. Immunoglobulins, anti-IgG antibodies and antinuclear antibodies in paired serum and synovial fluid samples. A comparison between juvenile and adult rheumatoid arthritis. Scandinavian Journal of Rheumatology. 1985;14(1):51-7. [pmid: 3873693].
44 Emad Y, Ragab Y, Shaarawy A, et al. Can magnetic resonance imaging differentiate undifferentiated arthritis based on knee imaging?. J RHEUMATOL. 2009;36(9):1963-70. [pmid: 19648303].
45 Fantini F, Gerloni V, Gattinara M, et al. Remission in juvenile chronic arthritis: A cohort study of 683 consecutive cases with a mean 10 year followup. J RHEUMATOL. 2003;30(3):579-84. [pmid: 12610820].
46 Ferraz MB, Goldenberg J, Hilario MO, et al. Evaluation of the 1982 ARA lupus criteria data set in pediatric patients. Committees of Pediatric Rheumatology of the Brazilian Society of Pediatrics and the Brazilian Society of Rheumatology. Clinical & Experimental Rheumatology. 1994;12(1):83-7. [pmid: 7741825].
47 Galea P, D’amato B, Goel KM. Ocular complications in juvenile chronic arthritis (JCA). Scottish Medical Journal. 1985;30(3):164-7. [pmid: 3877342].
48 Gao JS, Wu H, Tian J. Treatment of patients with juvenile rheumatoid arthritis with combination of leflunomide and methotrexate. [Chinese]. Zhonghua Erke Zazhi. 2003;41(6):435-8. [pmid: 14748999].
49 Gedalia A, Molina JF, Molina J, et al. Childhood-onset systemic lupus erythematosus: a comparative study of African Americans and Latin Americans. Journal of the National Medical Association. 1999;91(9):497-501. [pmid: 10517068].
50 Giannini EH, Ilowite NT, Lovell DJ, et al. Long-term safety and effectiveness of etanercept in children with selected categories of juvenile idiopathic arthritis. ARTHRITIS RHEUM. 2009;60(9):2794-804. [pmid: 19714630].
51 Grassi A, Corona F, Casellato A, et al. Prevalence and outcome of juvenile idiopathic arthritis-associated uveitis and relation to articular disease. J RHEUMATOL. 2007;34(5):1139-45. [pmid: 17343317].
52 Griffin TA, Barnes MG, Ilowite NT, et al. Gene expression signatures in polyarticular juvenile idiopathic arthritis demonstrate disease heterogeneity and offer a molecular classification of disease subsets. ARTHRITIS RHEUM. 2009;60(7):2113-23. [pmid: 19565504].
53 Gutowska-Grzegorczyk G, Baum J. Serum immunoglobulin and complement interrelationships in juvenile rheumatoid arthritis. J RHEUMATOL. 1977;4(2):179-85. [pmid: 881695].
54 Haber PL, Osborn TG, Moore TL. Antinuclear antibody in juvenile rheumatoid arthritis sera reacts with 50–40 kDa antigen(s) found in HeLa nuclear extracts. J RHEUMATOL. 1989;16(7):949-54. [pmid: 2671367].
55 Han T-X. Combined examination of antikeratin antibody, antiperinuclear factor and anti-cyclic citrullinated peptide antibody in the diagnosis and evaluation of juvenile rheumatoid arthritis. [Chinese]. Journal of Clinical Rehabilitative Tissue Engineering Research. 2007;11(27):5285-90.
56 Heiligenhaus A, Niewerth M, Ganser G, et al. Prevalence and complications of uveitis in juvenile idiopathic arthritis in a population-based nation-wide study in Germany: suggested modification of the current screening guidelines. Rheumatology. 2007;46(6):1015-9. [pmid: 17403710].
57 Heinz C, Mingels A, Goebel C, et al. Chronic uveitis in children with and without juvenile idiopathic arthritis: differences in patient characteristics and clinical course. J RHEUMATOL. 2008;35(7):1403-7. [pmid: 18484686].
58 Heshmat NM, El-Kerdany TH. Serum levels of vascular endothelial growth factor in children and adolescents with systemic lupus erythematosus. Pediatric Allergy & Immunology. 2007;18(4):346-53. [pmid: 17346298].
59 Ilowite NT, Wedgwood JF, Moore TL, et al. Hidden rheumatoid factor and Wa idiotype expression in juvenile rheumatoid arthritis. Scandinavian Journal of Immunology. 1991;34(4):453-60. [pmid: 1925410].
60 Ince A, Akhter IM, Moore TL, et al. Hidden 19S IgM rheumatoid factors in Turkish patients with juvenile rheumatoid arthritis. J RHEUMATOL. 1998;25(1):190-2. [pmid: 9458234].
61 Ingegnoli F, Del PN, Lupi E, et al. Anti-chromatin antibodies in juvenile rheumatoid arthritis. [Italian]. Reumatismo. 2003;55(4):240-4. [pmid: 14872223].
62 Iqbal S, Sher MR, Good RA, et al. Diversity in presenting manifestations of systemic lupus erythematosus in children. J PEDIATR. 1999;135(4):500-5. [pmid: 10518085].
63 Itoh Y, Hamada H, Imai T, et al. Antinuclear antibodies in children with chronic nonspecific complaints. Autoimmunity. 1997;25(4):243-50. [pmid: 9344332].
64 Jarvis JN, Pousak T, Krenz M. Detection of IgM rheumatoid factors by enzyme-linked immunosorbent assay in children with juvenile rheumatoid arthritis: correlation with articular disease and laboratory abnormalities. Pediatrics. 1992;90(6):945-9. [pmid: 1437439].
65 Jurencak R, Fritzler M, Tyrrell P, et al. Autoantibodies in pediatric systemic lupus erythematosus: ethnic grouping, cluster analysis, and clinical correlations. J RHEUMATOL. 2009;36(2):416-21. [pmid: 19208567].
66 Kanski JJ. Clinical and immunological study of anterior uveitis in juvenile chronic polyarthritis. Transactions of the Ophthalmological Societies of the United Kingdom. 1976;96(1):123-30. [pmid: 1070839].
67 Karhulahti T, Ylijoki H, Ronning O. Mandibular condyle lesions related to age at onset and subtypes of juvenile rheumatoid arthritis in 15-year-old children. Scandinavian Journal of Dental Research. 1993;101(5):332-8. [pmid: 8248736].
68 Kasapcopur O, Yologlu N, Ozyazgan Y, et al. Uveitis and anti nuclear antibody positivity in children with juvenile idiopathic arthritis. Indian Pediatrics. 2004;41(10):1035-9. [pmid: 15523130].
69 Katargina LA, Khvatova AV, Krichevskaia GI, et al. Clinical variants and immunologic features of rheumatoid uveitis in children of different age. [Russian]. Vestnik Oftalmologii. 2001;117(1):30-3. [pmid: 11339037].
70 Kump LI, Castaneda RA, Androudi SN, et al. Visual outcomes in children with juvenile idiopathic arthritis-associated uveitis. Ophthalmology. 2006;113(10):1874-7. [pmid: 16884776].
71 Kuna AT, Lamot L, Miler M, et al. Antibodies to mutated citrullinated vimentin and antibodies to cyclic citrullinated peptides in juvenile idiopathic arthritis. Clin Chem Lab Med. 2009;47(12):1525-30. [pmid: 19842993].
72 Kunnamo I, Kallio P, Pelkonen P, et al. Clinical signs and laboratory tests in the differential diagnosis of arthritis in children. American Journal of Diseases of Children. 1987;141(1):34-40. [pmid: 3491537].
73 Leak AM, Ansell BM, Burman SJ. Antinuclear antibody studies in juvenile chronic arthritis. ARCH DIS CHILD. 1986;61(2):168-72. [pmid: 3485405].
74 Lee DH, Daud U, Wipfl J, et al. The Decreasing Prevalence of Uveitis Associated with Juvenile Rheumatoid Arthritis: Do NSAIDs Play a Role?. Journal of Clinical Rheumatology. 2003;9(3):151-5. [pmid: 17041450].
75 Lehman TJ, Hanson V, Zvaifler N, et al. Antibodies to nonhistone nuclear antigens and antilymphocyte antibodies among children and adults with systemic lupus erythematosus and their relatives. J RHEUMATOL. 1984;11(5):644-7. [pmid: 6392551].
76 Lepore L, Del SM, Malorgio C, et al. Treatment of juvenile idiopathic arthritis with intra-articular triamcinolone hexacetonide: evaluation of clinical effectiveness correlated with circulating ANA and T gamma/delta + and B CD5+ lymphocyte populations of synovial fluid. Clinical & Experimental Rheumatology. 2002;20(5):719-22. [pmid: 12412208].
77 Lepvrier-Guibal N, Tiret A, Prieur AM, et al. Uveitis in juvenile chronic arthritis. [French]. Journal Francais d Opthalmologie. 1994;17(8–9):489-95.
78 Lepvrier-Guibal N, Tiret A, Prieur AM, et al. Uveitis in juvenile chronic arthritis. [French]. Journal Francais d’Ophtalmologie. 1994;17(8–9):489-95. [pmid: 7989655].
79 Li CW, Hu J, Pi SH. Clinical characteristics of children with enthesitis related arthritis. [Chinese]. Zhonghua Erke Zazhi. 2003;41(11):835-8. [pmid: 14728890].
80 Lin SJ, Huang JL, Chao HC, et al. A follow-up study of systemic-onset juvenile rheumatoid arthritis in children. Acta Paediatrica Taiwanica. 1999;40(3):176-81. [pmid: 10910610].
81 Machado SH, von Muhlen CA, Brenol JC, et al. The prevalence of anti-cyclic citrullinated peptide antibodies in juvenile idiopathic arthritis. [Portuguese]. Jornal de Pediatria. 2005;81(6):491-4. [pmid: 16385368].
82 Machado SH, von Muhlen CA, Brenol JCT, et al. The prevalence of anti-cyclic citrullinated peptide antibodies in juvenile idiopathic arthritis. Jornal de Pediatria. 2005;81(6):491-4. [pmid: 16385368].
83 Magsaam J, Ferjencik P, Tempels M, et al. A new method for the detection of hidden IgM rheumatoid factor in patients with juvenile rheumatoid arthritis. J RHEUMATOL. 1987;14(5):964-7. [pmid: 3430524].
84 Malleson PN, Fung MY, Petty RE, et al. Autoantibodies in chronic arthritis of childhood: relations with each other and with histocompatibility antigens. ANN RHEUM DIS. 1992;51(12):1301-6. [pmid: 1485811].
85 Malleson PN, Sailer M, Mackinnon MJ. Usefulness of antinuclear antibody testing to screen for rheumatic diseases. ARCH DIS CHILD. 1997;77(4):299-304. [pmid: 9389231].
86 Manzotti F, Orsoni JG, Zavota L, et al. Autoimmune uveitis in children: clinical correlation between antinuclear antibody positivity and ocular recurrences. Rheumatology International. 2002;21(4):127-32. [pmid: 11843166].
87 Marks SD, Pilkington C, Woo P, et al. The use of the British Isles Lupus Assessment Group (BILAG) index as a valid tool in assessing disease activity in childhood-onset systemic lupus erythematosus. Rheumatology. 2004;43(9):1186-9. [pmid: 15226518].
88 Martinez-Cairo CS, Antonio OD, Frati A. Juvenile rheumatoid arthritis. Study of 46 cases. [Spanish]. Boletin Medico del Hospital Infantil de Mexico. 1978;35(4):711-7. [pmid: 646890].
89 Martinez-Cordero E, Martinez-Miranda E, Negrete-Garcia MC, et al. Autoantibodies in juvenile rheumatoid arthritis. Clinical and serologic study. [Spanish]. Boletin Medico del Hospital Infantil de Mexico. 1989;46(5):316-21. [pmid: 2757772].
90 Martinez-Rojano H, Juarez HE, Ladron de GG, et al. Rheumatologic manifestations of pediatric HIV infection. AIDS PATIENT CARE STDS. 2001;15(10):519-26. [pmid: 11689139].
91 Matsaniotis N, Kattamis C, Paidousis M, et al. The direct coombs test in juvenile rheumatoid arthritis. Helvetica Paediatrica Acta. 1974;29(6):609-13. [pmid: 4457520].
92 McCarthy PL, Wasserman D, Spiesel SZ, et al. Evaluation of arthritis and arthralgia in the pediatric patient. CLIN PEDIATR. 1980;19(3):183-90.
93 McGhee JL, Kickingbird LM, Jarvis JN. Clinical utility of antinuclear antibody tests in children. BMC Pediatrics. 2004;4:13. [pmid: 15245579].
94 McGhee JL, Burks FN, Sheckels JL, et al. Identifying children with chronic arthritis based on chief complaints: absence of predictive value for musculoskeletal pain as an indicator of rheumatic disease in children. Pediatrics. 2002;110(2:Pt 1):9.
95 McMurray RW, Allen SH, Pepmueller PH, et al. Elevated serum prolactin levels in children with juvenile rheumatoid arthritis and antinuclear antibody seropositivity. J RHEUMATOL. 1995;22(8):1577-80. [pmid: 7473487].
96 Mihailova D, Grigorova R, Vassileva B, et al. Autoimmune thyroid disorders in juvenile chronic arthritis and systemic lupus erythematosus. Advances in Experimental Medicine & Biology. 1999;455:55-60. [pmid: 10599323].
97 Minden K, Niewerth M, Listing J, et al. Long-term outcome in patients with juvenile idiopathic arthritis. ARTHRITIS RHEUM. 2002;46(9):2392-401. [pmid: 12355487].
98 Mo N, Amos N, Negi A, et al. The use of different ELISA kits to determine prevalence of anti-cyclic citrullinated peptide (anti-CCP) antibodies in children with juvenile idiopathic arthritis (JIA). Rheumatology. 2008;47:II26.
99 Moe N, Rygg M. Epidemiology of juvenile chronic arthritis in northern Norway: a ten-year retrospective study. Clinical & Experimental Rheumatology. 1998;16(1):99-101. [pmid: 9543575].
100 Moore TL, Osborn TG, Dorner RW. 19S IgM rheumatoid factor-7S IgG rheumatoid factor immune complexes isolated in sera of patients with juvenile rheumatoid arthritis. Pediatric Research. 1986;20(10):977-81. [pmid: 3095782].
101 Moore TL, Osborn TG, Weiss TD, et al. Autoantibodies in juvenile arthritis. SEMIN ARTHRITIS RHEUM. 1984;13(4):329-36. [pmid: 6610217].
102 Moore TL, Dorner RW, Alexander RL, et al. Enzyme linked (ELISA) immunoabsorbent assay for the detection of hidden 19S IgM rheumatoid factors in juvenile rheumatoid arthritis. J RHEUMATOL. 1988;15(1):87-90. [pmid: 3351844].
103 Moore TL, Dorner RW, Sheridan PW, et al. Longitudinal study of the presence of hidden 19S IgM rheumatoid factor in juvenile rheumatoid arthritis. J RHEUMATOL. 1982;9(4):599-602. [pmid: 6215487].
104 Moore TL, Dorner RW. Separation and characterization of complement-fixing immune complexes in juvenile rheumatoid arthritis patients. Rheumatology International. 1986;6(2):49-52. [pmid: 3532285].
105 Moradinejad MH, Zamani GR, Kiani AR, et al. Clinical features of juvenile lupus erythematosus in Iranian children. Acta Reumatologica Portuguesa. 2008;33(1):63-7. [pmid: 18344923].
106 Moradinejad MH. Lupus headaches in 55 childhood-onset SLE. Iranian Journal of Pediatrics. 2007;17(2):135-9.
107 Munthe E. Anti-IgG and antinuclear antibodies in juvenile rheumatoid arthritis. Scandinavian Journal of Rheumatology. 1972;1(4):161-70. [pmid: 4541440].
108 Nassberger L, Truedsson L, Svantesson H. Occurrence of autoantibodies against neutrophil granulocyte components in juvenile chronic arthritis. Clinical & Experimental Rheumatology. 1991;9(1):79-83. [pmid: 1647282].
109 Oen K, Schroeder M, Jacobson K, et al. Juvenile rheumatoid arthritis in a Canadian First Nations (aboriginal) population: onset subtypes and HLA associations. J RHEUMATOL. 1998;25(4):783-90. [pmid: 9558186].
110 Oen K, Tucker L, Huber AM, et al. Predictors of early inactive disease in a juvenile idiopathic arthritis cohort: results of a Canadian multicenter, prospective inception cohort study. ARTHRITIS RHEUM. 2009;61(8):1077-86. [pmid: 19644903].
111 Ozdogan H, Kasapcopur O, Dede H, et al. Juvenile chronic arthritis in a Turkish population. Clinical & Experimental Rheumatology. 1991;9(4):431-5. [pmid: 1934696].
112 Pagan TM, Arroyo IL. Juvenile rheumatoid arthritis in Caribbean children: a clinical characterization. Boletin - Asociacion Medica de Puerto Rico. 1991;83(12):527-9. [pmid: 1811603].
113 Pedersen TK, Jensen JJ, Melsen B, et al. Resorption of the temporomandibular condylar bone according to subtypes of juvenile chronic arthritis. J RHEUMATOL. 2001;28(9):2109-15. [pmid: 11550983].
114 Peralta JL, Prieur AM. Juvenile chronic arthritis with antinuclear antibodies in 136 patients. [French]. Archives Francaises de Pediatrie. 1990;47(7):497-502. [pmid: 2256788].
115 Pluchinotta FR, Schiavo B, Vittadello F, et al. Distinctive clinical features of pediatric systemic lupus erythematosus in three different age classes. Lupus. 2007;16(8):550-5. [pmid: 17711887].
116 Pope RM, Yoshinoya S, McDuffy SJ. Detection of immune complexes and their relationship to rheumatoid factor in a variety of autoimmune disorders. Clinical and Experimental Immunology. 1981;46(2):259-67. [pmid: 7337971].
117 Pratsidou-Gertsi P, Kanakoudi-Tsakalidou F, Spyropoulou M, et al. Nationwide collaborative study of HLA class II associations with distinct types of juvenile chronic arthritis (JCA) in Greece. European Journal of Immunogenetics. 1999;26(4):299-310. [pmid: 10457895].
118 Ravelli A, Felici E, Magni-Manzoni S, et al. Patients with antinuclear antibody-positive juvenile idiopathic arthritis constitute a homogeneous subgroup irrespective of the course of joint disease. ARTHRITIS RHEUM. 2005;52(3):826-32. [pmid: 15751057].
119 Riise OR, Handeland KS, Cvancarova M, et al. Incidence and characteristics of arthritis in Norwegian children: a population-based study. Pediatrics. 2008;121(2):e299-e306. [pmid: 18227193].
120 Roberts-Thomson PJ, Shepherd K, Southwood TR, et al. Low molecular weight IgM in juvenile chronic arthritis. ARCH DIS CHILD. 1988;63(12):1453-6. [pmid: 3266068].
121 Rondeel JM, van GW, van der LH, et al. Different strategies in the laboratory diagnosis of autoimmune disease: immunofluorescence, enzyme-linked immunosorbent assay or both?. Annals of Clinical Biochemistry. 1999;36(Pt 2):189-95. [pmid: 10370735].
122 Rosenberg AM, Romanchuk KG. Antinuclear antibodies in arthritic and nonarthritic children with uveitis. J RHEUMATOL. 1990;17(1):60-1. [pmid: 2313675].
123 Rosenberg AM, Cordeiro DM. Relationship between sex and antibodies to high mobility group proteins 1 and 2 in juvenile idiopathic arthritis. J RHEUMATOL. 2000;27(10):2489-93. [pmid: 11036848].
124 Rosenberg AM, Hauta SA, Prokopchuk PA, et al. Studies on associations of antinuclear antibodies with antibodies to an uveitogenic peptide of retinal S antigen in children with uveitis. J RHEUMATOL. 1996;23(2):370-3. [pmid: 8882049].
125 Rossen RD, Brewer EJ, Person DA, et al. Circulating immune complexes and antinuclear antibodies in juvenile rheumatoid arthritis. ARTHRITIS RHEUM. 1977;20e(8):1485-90. [pmid: 303520].
126 Rudolf MCJ, Genel M, Tamborlane J, et al. Juvenile rheumatoid arthritis in children with diabetes mellitus. J PEDIATR. 1981;99(4):519-24. [pmid: 6974234].
127 Ruperto N, Ravelli A, Levinson JE, et al. Longterm health outcomes and quality of life in American and Italian inception cohorts of patients with juvenile rheumatoid arthritis .2. Early predictors of outcome. J RHEUMATOL. 1997;24(5):952-8. [pmid: 9150088].
128 Salah S, Hamshary A, Lotfy H, et al. Juvenile Idiopathic Arthritis, the Egyptian Experience. Journal of Medical Sciences. 2009;9(2):98-102.
129 Saulsbury FT. Antibody to ribonucleoprotein in pauciarticular juvenile rheumatoid arthritis. J RHEUMATOL. 1988;15(2):295-7. [pmid: 3258919].
130 Saurenmann RK, Rose JB, Tyrrell P, et al. Epidemiology of juvenile idiopathic arthritis in a multiethnic cohort: ethnicity as a risk factor. ARTHRITIS RHEUM. 2007;56(6):1974-84. [pmid: 17530723].
131 Schaller J, Wedgwood RJ. Juvenile rheumatoid arthritis: a review. Pediatrics. 1972;50(6):940-53. [pmid: 4564600].
132 Schaller JG, Ochs HD, Thomas ED, et al. Histocompatibility antigens in childhood-onset arthritis. J PEDIATR. 1976;88(6):926-30. [pmid: 1271190].
133 Schwartz MM, Simpson P, Kerr KL, et al. Juvenile rheumatoid arthritis in African Americans. J RHEUMATOL. 1997;24(9):1826-9. [pmid: 9292811].
134 Sendagorta E, Peralta J, Romero R, et al. Uveitis and idiopathic juvenile arthritis in Spain. Epidemiological and therapeutic aspects. [Spanish]. Archivos de la Sociedad Espanola de Oftalmologia. 2009;84(3):133-8. [pmid: 19340718].
135 Serra CR, Rodrigues SH, Silva NP, et al. Clinical significance of anticardiolipin antibodies in juvenile idiopathic arthritis. Clinical & Experimental Rheumatology. 1999;17(3):375-80. [pmid: 10410276].
136 Seth V, Kabra SK, Semwal OP, et al. Clinico-immunological profile in juvenile rheumatoid arthritis--an Indian experience. INDIAN J PEDIATR. 1996;63(3):293-300. [pmid: 10830004].
137 Sharma S, Sherry DD. Joint distribution at presentation in children with pauciarticular arthritis. J PEDIATR. 1999;134(5):642-3. [pmid: 10228303].
138 Shin JI, Kim KH, Chun JK, et al. Prevalence and patterns of anti-nuclear antibodies in Korean children with juvenile idiopathic arthritis according to ILAR criteria. Scandinavian Journal of Rheumatology. 2008;37(5):348-51. [pmid: 18666025].
139 Singh S, Salaria M, Kumar L, et al. Clinico-immunological profile of juvenile rheumatoid arthritis at Chandigarh. Indian Pediatrics. 1999;36(5):449-54. [pmid: 10728033].
140 Smerdel A, Ploski R, Flato B, et al. Juvenile idiopathic arthritis (JIA) is primarily associated with HLA-DR8 but not DQ4 on the DR8-DQ4 haplotype. ANN RHEUM DIS. 2002;61(4):354-7. [pmid: 11874841].
141 Southwood TR, Roberts-Thomson PJ, Ahern MJ, et al. Autoantibodies in patients with juvenile chronic arthritis and their immediate family relatives. ANN RHEUM DIS. 1990;49(12):968-72. [pmid: 2270968].
142 Spadaro A, Riccieri V, Sili SA, et al. Interleukin-6 and soluble interleukin-2 receptor in juvenile chronic arthritis: correlations with clinical and laboratory parameters. Revue du Rhumatisme (English Edition). 1996;63(3):171-7.
143 Syed RH, Gilliam BE, Moore TL. Prevalence and significance of isotypes of anti-cyclic citrullinated peptide antibodies in juvenile idiopathic arthritis. ANN RHEUM DIS. 2008;67(7):1049-51. [pmid: 18556446].
144 Thomas E, Barrett JH, Donn RP, et al. Subtyping of juvenile idiopathic arthritis using latent class analysis. British Paediatric Rheumatology Group. ARTHRITIS RHEUM. 2000;43(7):1496-503. [pmid: 10902751].
145 Thomas E, Barrett JH, Donn RP, et al. Subtyping of juvenile idiopathic arthritis using latent class analysis. Arthritis and rheumatism. 2000;43(7):1496-503. [pmid: 10902751].
146 Thorsteinsson L, Abrahamsen TG, Froland SS, et al. Monocyte cytotoxicity in connective tissue diseases. Correlation with disease groups. Scandinavian Journal of Rheumatology. 1981;10(1):49-54. [pmid: 6971489].
147 Tsitsami E, Bozzola E, Magni-Manzoni S, et al. Positive family history of psoriasis does not affect the clinical expression and course of juvenile idiopathic arthritis patients with oligoarthritis. Arthritis Care and Research. 2003;49(4):488-93. [pmid: 12910554].
148 Valverde GJ, Garrigosa PR, Pastor SF, et al. Chronic juvenile arthritis. A study of 46 patients. [Spanish]. Revista Espanola de Reumatologia. 1980;7(2):86-94.
149 van RM, Van SR, De KS, et al. Anti-cyclic citrullinated peptide (anti-CCP) antibodies in children with juvenile idiopathic arthritis. J RHEUMATOL. 2003;30(4):825-8. [pmid: 12672206].
150 Walker SM, Shaham B, McCurdy DK, et al. Prevalence and concentration of IgM rheumatoid factor in polyarticular onset disease as compared to systemic or pauciarticular onset disease in active juvenile rheumatoid arthritis as measured by ELISA. J RHEUMATOL. 1990;17(7):936-40. [pmid: 2213760].
151 Wu CJ, Huang JL, Yang MH, et al. Clinical characteristics of juvenile rheumatoid arthritis in Taiwan. Journal of Microbiology, Immunology & Infection. 2001;34(3):211-4.
152 Xu M, Roberts BB, Busby BA, et al. Evaluation of multiplex antinuclear antibody assay in pediatric patients. Laboratory Medicine. 2007;38(11):671-5.
153 Yilmaz M, Kendirli SG, Altintas DU, et al. Juvenile idiopathic arthritis profile in Turkish children. PEDIATR INT. 2008;50(2):154-8. [pmid: 18353049].
154 Zak M, Fledelius H, Pedersen FK. Ocular complications and visual outcome in juvenile chronic arthritis: A 25 year follow-up study. Acta Ophthalmologica Scandinavica. 2003;81(3):211-5. [pmid: 12780395].
155 Zerin JM, Sullivan DB, Martel W. Distal interphalangeal joint abnormalities in children with polyarticular juvenile rheumatoid arthritis. J RHEUMATOL. 1991;18(6):889-92. [pmid: 1895269].

### Duplicates (N = 6)

The following studies were excluded because they were duplicates.

1 Agarwal I, Kumar TS, Ranjini K, et al. Clinical features and outcome of systemic lupus erythematosus. Indian Pediatrics. 2009;46(8):711-5. [pmid: 19213981].
2 Al-Mendalawi MD. Juvenile systemic lupus erythematosus in Bahrain. A tertiary referral center experience. Saudi Medical Journal. 2009;30(9):1240. [pmid: 19750278].
3 Brunner J, Sitzmann FC. The diagnostic value of anti-cyclic citrullinated peptide (CCP) antibodies in children with Juvenile Idiopathic Arthritis. Clinical & Experimental Rheumatology. 2006;24(4):449-51. [pmid: 16956438].
4 Lipinska J, Smolewska E, Brozik H, et al. Diagnostic value of selected immunological markers in children with JIA. [Polish]. Alergia Astma Immunologia. 2005;10(2):75-82. Date of Publication: 2005 2005;(2):75–82.
5 Nandi M, Ganguli SK, Mondal R, et al. Clinico-serological profile of juvenile idiopathic arthritis. Indian Pediatrics. 2009;46(7):640-1. [pmid: 19638666].
6 Varbanova B, Kolarov Z, Baleva M. IgA-RF as a marker of progressing of rheumatoid arthritis and juvenile idiopathic arthritis. [Bulgarian]. Rheumatology. 2002;10(2):49-53. Date of Publication: 2002 2002;(2):49–53.