# Forms

ANA, RF, and CCP Testing in Pediatric Populations INCLUSION/EXCLUSION FORM

QUADAS CODING GUIDE