# Literature Search Strings

Title: ANA RF Anti CCP Testing Search Strategies

Database: MEDLINE , 1950 - present

Search name: ANA RF Anti CCP Testing -MEDLINE -

Notes: limits: human, 1960–2009

Date searched: Jan 21, 2010

Results: 5,389

1. citrulline/ 2. exp Peptides, Cyclic/ 3. 1 and 2 4. ((anti adj ccp) or (citrullinated adj peptide*)).mp. 5. ((citrulline adj antibod*) or (anti-citrulline adj antibod*)).ti,ab. 6. exp Antibodies, Antinuclear/ 7. ((antinuclear adj antibod*) or (antinuclear adj factor*)).ti,ab. 8. (ana adj titer).ti,ab. 9. (ANA adj2 test*).ti,ab. 10. (FANA adj2 test*).ti,ab. 11. exp Rheumatoid Factor/ 12. (rheumatoid adj factor*).ti,ab. 13. or/3–12 14. exp Lupus Erythematosus, Systemic/ 15. (JSLE or SLE or “lupus erythematosus”).ti,ab. 16. exp Pain/di, et 17. Growth/ph 18. (grow* and (pain or pains)).ti,ab. 19. 16 and (17 or 18) 20. musculoskeletal diseases/ or arm/ or leg/ or extremities/ 21. 16 and 20 22. Fibromyalgia/ 23. fibromyalgia.ti,ab. 24. exp arthralgia/ 25. arthralgia.ti,ab. 26. ((joint* adj pain*) or (limb* adj pain*)).ti,ab. 27. limp*.ti,ab. 28. benign.ti,ab. 29. exp Joint Instability/ 30. (joint adj (instability or hypermobility)).ti,ab. 31. 28 and (29 or 30) 32. Patellofemoral Pain Syndrome/ 33. (patellofemoral adj pain adj syndrome).ti,ab. 34. exp Synovitis/ or synovitis.mp. 71. exp demography/ 72. age factors/ or “age of onset”/ 73. sex factors/ 74. infection/ or infection*.ti,ab. 75. anxiety/ or (anxious* or anxiety).ti,ab. 76. comorbidity/ 77. or/71–76 78. exp Rheumatic Diseases/di, co, et, im, pa, pp 79. exp Connective Tissue Diseases/di, co, et, im, pa, pp 80. exp arthritis/di, co, et, im, pa, pp 81. arthritis, rheumatoid/di, co, et, im, pa, pp 82. arthritis, juvenile rheumatoid/di, co, et, im, pa, pp 83. exp Lupus Erythematosus, Systemic/di, co, et, im, pa, pp 84. or/78–83 85. exp infant/ 86. (Infant* or infancy or Newborn* or Baby* or Babies or Neonat* or Preterm* or Prematur* or Postmatur*).mp. 87. exp Child/ 88. (Child* or Schoolchild* or School age* or Preschool* or Kid or kids or Toddler*).mp. 89. exp Adolescent/ 90. Adoles*.mp. 91. (Teen* or Boy* or Girl*).mp. 92. exp Minors/ 93. minors*.mp. 94. exp Puberty/ | 35. or/14–15,19–27,31–34 36. Arthritis/ 37. ($arthritis or ($articular adj arthritis)).ti,ab. 38. or/36–37 39. exp child/ or (adolesc* or early or juvenile).ti,ab. 40. (JIA or JRA).ti,ab. 41. or/39–40 42. 38 and 41 43. exp Arthritis, Juvenile Rheumatoid/ 44. ((juvenile or early) adj (rheumatoid or idiopathic) adj arthritis).ti,ab. 45. or/42–44 46. or/14–15,19,21–27,31–34,45 47. incidence/ 48. prevalence/ 49. exp disease progression/ 50. Natural History/ 51. natural history.ti,ab. 52. or/47–51 53. exp Mass Screening/ 54. exp “referral and consultation”/ 55. (screen* or refer*).ti,ab. 56. or/53–55 57. exp “Reproducibility of Results”/ 58. exp “Sensitivity and Specificity”/ 59. Predictive Value of Tests/ 60. (di or bl or cl or im).fs. 61. exp Diagnostic Errors/ 62. early diagnosis/ 63. exp delayed diagnosis/ 64. Diagnosis, Differential/ 65. or/57–64 66. (cost or costs or economic*).ti,ab. 67. exp “Costs and Cost Analysis”/ 68. cost-benefit analysis/ 69. ec.fs. 70. or/66–68 95. (Pubert* or Pubescen* or Prepubescen*).mp. 96. exp Pediatrics/ 97. (Pediatric* or Paediatric* or Peadiatric*).mp. 98. exp Schools/ 99. (Nursery school* or Kindergar* or Primary school* or Secondary school* or Elementary school* or High school* or Highschool*).mp. 100. or/85–99 101. adolescent/ and adult/ 102. 100 not 101 103. (52 or 56) and 35 and 102 104. 13 and 102 and 65 and (84 or 46) 105. 13 and 46 and 102 106. 13 and (56 or 65) and 46 and 102 107. 13 and 77 and 102 108. (13 or 84) and 70 109. 13 and (35 or 45) and 102 110. 77 and 65 and 13 and 102 111. (52 or 56) and (45 or 84) and 102 112. 13 and (56 or 65) and 70 113. 13 and 70 114. or/103–113 115. humans/ NOT (humans/ and animals/) 116. 114 AND 115

Topic: ANA RF Anti CCP Testing Search Strategies

Database: EMBASE, 1980 - present

Search name: ANA RF Anti CCP Testing - EMBASE-amy

Notes: limits of: human, 1980–2009

Date searched: Jan 21, 2010

Results: 4,849

1. cyclic citrullinated peptide/ 2. ((anti adj ccp) or (citrullinated adj peptide*)).mp. 3. ((citrulline adj antibod*) or (anti-citrulline adj antibod*)).ti,ab. 4. exp Antinuclear Antibody/ 5. ((antinuclear adj antibod*) or (antinuclear adj factor*)).ti,ab. 6. (ana adj titer).ti,ab. 7. (ANA adj2 test*).ti,ab. 8. (FANA adj2 test*).ti,ab. 9. exp Rheumatoid Factor/ 10. rheumatoid factor*.ti,ab. 11. or/1–10 12. exp Systemic Lupus Erythematosus/ 13. (JSLE or SLE or “lupus erythematosus”).ti,ab. 14. (grow* and (pain or pains)).ti,ab. 15. musculoskeletal diseases/ or arm/ or leg/ or extremities/ 16. pain/di, et 17. 15 and 16 18. exp arthralgia/ 19. arthralgia.ti,ab. 20. ((joint* adj pain*) or (limb* adj pain*)).ti,ab. 21. limp*.ti,ab. 22. Fibromyalgia/ 23. fibromyalgia.ti,ab. 24. benign.ti,ab. 25. exp Joint Instability/ or Joint hypermobility/ 26. (joint adj (instability or hypermobility)).ti,ab. 27. 24 and (25 or 26) 28. Patellofemoral Pain Syndrome/ 29. patellofemoral joint/ and pain/ 30. (patellofemoral adj pain adj syndrome).ti,ab. 31. knee pain/ or ankle pain/ 32. exp Synovitis/ or synovitis.mp. 33. “complex regional pain syndrome”/ 34. or/12–23,27–33 35. Arthritis/ 36. ($arthritis or ($articular adj arthritis)).ti,ab. 75. gender/ or sex difference/ 76. infection/ or infection*.ti,ab. 77. anxiety/ or (anxious* or anxiety).ti,ab. 78. comorbidity/ 79. or/73–78 80. exp newborn/ 81. (Infant* or infancy or Newborn* or Baby* or Babies or Neonat* or Preterm* or Prematur* or Postmatur*).mp. 82. exp Child/ 83. (Child* or Schoolchild* or School age* or Preschool* or Kid or kids or Toddler*).mp. 84. exp Adolescent/ 85. Adoles*.mp. 86. (Teen* or Boy* or Girl*).mp. 87. (minors* or juvenil*).mp. 88. exp Adolescence/ 89. (Pubert* or Pubescen* or Prepubescen*).mp. 90. exp Pediatrics/ | 37. or/35–36 38. exp child/ or (adolesc* or early or juvenile).ti,ab. 39. (JIA or JRA).ti,ab. 40. or/38–39 41. 37 and 40 42. exp Juvenile Rheumatoid Arthritis/ 43. ((juvenile or early) adj (rheumatoid or idiopathic) adj arthritis).ti,ab. 44. or/41–43 45. incidence/ or prevalence/ or seasonal variation/ 46. exp disease course/ 47. natural history.ti,ab. 48. or/45–47 49. exp mass screening/ or screening/ 50. exp “referral and consultation”/ 51. (screen* or refer*).ti,ab. 52. or/49–51 53. Differential Diagnosis/ 54. exp Reproducibility/ 55. exp “sensitivity and specificity”/ 56. Predictive Value of Tests/ 57. serodiagnosis/ 58. (di or bl or cl or im).fs. 59. exp Diagnostic Error/ 60. “diagnostic techniques and procedures”/ 61. diagnostic procedure/ 62. early diagnosis/ 63. Diagnostic Accuracy/ 64. physical examination/ 65. blood examination/ 66. “Pain Assessment”/ 67. or/53–66 68. (cost or costs or economic*).ti,ab. 69. exp economic aspect/ 70. cost-benefit analysis/ 71. ec.fs. 72. or/68–70 73. exp demography/ or geographic distribution/ 74. age/ 91. (Pediatric* or Paediatric* or Peadiatric*).mp. 92. exp school/ or high school/ or kindergarten/ or middle school/ or nursery school/ or primary school/ 93. (Nursery school* or Kindergar* or Primary school* or Secondary school* or Elementary school* or High school* or Highschool*).mp. 94. or/80–93 95. (48 or 52) and 67 and 34 and 94 96. 11 and 94 and 67 and (34 or 44) 97. 11 and 94 and (34 or 44) 98. 11 and (67 or 52) and (34 or 44) and 94 99. 11 and 79 and 94 100. 11 and 79 and 67 101. 11 and 72 and (44 or 94) 102. 11 and 72 and (34 or 44) and 94 and 67 103. 11 and 94 and 67 104. or/95–103 105. adolescent/ and adult/ 106. 104 not 105 107. humans/ and animals/ 108. 106 not 107

Topic: ANA RF Anti CCP Testing Search Strategies

Database: CINAHL, 1960-present

Notes: limits of: human, 1980–2009

Date searched: Jan 21, 2010

Topic: ANA RF Anti CCP Testing Search Strategies

Database: Cochrane Library – CDSR and CENTRAL

Notes: limits: human, 1960–2009

Date searched: Feb 2010

Results: 216

- #1(citrulline OR anti-ccp) or (rheumatoid factor) or (citrullinated peptide) or (antinuclear AND (antibod* OR factor*)) or (ANA OR FANA) and test* in Cochrane Reviews and Clinical Trials; - #2 (lupus) or (JSLE OR SLE) or (limb or grow*) AND pain or (fibromyalgia) or (arthralgia) in Cochrane Reviews and Clinical Trials; - #3 (joint AND (instability OR hypermobility)) or (patellofemoral pain syndrome) or (synovitis) or (JRA OR JIA) or (juvenile OR early) AND (rheumatoid OR idiopathic) AND arthritis in Cochrane Reviews and Clinical Trials; - #4 (#2 OR #3); - #5 (incidence OR prevalence) or (disease AND (progression OR history)) or (natural history) in Cochrane Reviews and Clinical Trials; - #6 (mass screening) or (screen*) or (refer*) or (consultation) or (referral and consultation) in Cochrane Reviews and Clinical Trials; - #7 (sensitivity OR specificity) or (diagnostic error*) or (early diagnosis) or (delayed diagnosis) or (differential diagnosis) in Cochrane Reviews and Clinical Trials; - #8 (demography) or (age of onset) OR (age factors) or (sex factors) or (infection) or (anxiety OR anxious*) in Cochrane Reviews and Clinical Trials; - #9 child*) or (adolescen*) or (infant* OR infancy OR newborn* OR baby OR babies) or (pediatric* OR paediatric*) in Cochrane Reviews and Clinical Trials; - #10 (#1 AND #4 AND #7 AND #9) 42 [underlined: edit] delete #11 (#1 AND #4 AND #9); - #12 (#1 AND #8 AND #9) 185 [underlined: edit] delete #13 (#1 AND #4 AND #6 AND #9); - #14 (#4 AND #6 AND #9) 642 [underlined: edit] delete #15 ((#5 OR #6 ) AND #4 AND #9); - #16 (#10 OR #11 OR #12 OR #13 OR #14 OR #15); - #17 (#16), from 1960 to 2009; - #18 (#10 OR #11 OR #12 OR #13); - #19 (#10 OR #11 OR #12 OR #13), from 1960 to 2009

Topic: ANA RF Anti CCP Testing Search Strategies

Database: Web of Science (ISI): Science Expanded, Social Sciences Expanded

Notes: limits: english only, human, 1980

Date searched: 9Feb10

Results: 856 (line #17)a

#17= #14 OR #13 OR #12 OR #10 OR #8 Refined by: Languages=( ENGLISH ) Databases=SCI-EXPANDED, SSCI Timespan=1960–2009 # 16= #14 OR #13 OR #12 OR #10 OR #8 Databases=SCI-EXPANDED, SSCI Timespan=1960–2009 # 15= #14 OR #12 OR #10 OR #8 Databases=SCI-EXPANDED, SSCI Timespan=1960–2009 # 14= #7 AND #6 AND #5 AND #1 Databases=SCI-EXPANDED, SSCI Timespan=1960–2009 # 13= #7 AND #6 AND #1 Databases=SCI-EXPANDED, SSCI Timespan=1960–2009 # 12= #11 AND #7 AND #5 AND #2 Databases=SCI-EXPANDED, SSCI Timespan=1960–2009 # 11= #4 OR #3 Databases=SCI-EXPANDED, SSCI Timespan=1960–2009 # 10= #9 AND #7 AND #2 AND #1 Databases=SCI-EXPANDED, SSCI Timespan=1960–2009 # 9= #5 OR #4 Databases=SCI-EXPANDED, SSCI Timespan=1960–2009 # 8= #7 AND #5 AND #2 AND #1 Databases=SCI-EXPANDED, SSCI Timespan=1960–2009 # 7= Topic=(infant*) OR Topic=(child*) OR Topic=(adolescen*) OR Topic=(pediatric* OR paediatric*) Databases=SCI-EXPANDED, SSCI Timespan=1960–2009 # 6= Topic=(demography) OR Topic=((age factor*) OR (age of onset)) OR Topic=(sex factor* OR gender) OR Topic=(infection*) OR Topic=(anxiety*) OR Topic=(comorbid*) Databases=SCI-EXPANDED, SSCI Timespan=1960–2009 # 5= Topic=(early diagnos*) OR Topic=(differential diagnos*) OR Topic=(delayed diagnos*) OR Topic=(diagnostic error*) Databases=SCI-EXPANDED, SSCI Timespan=1960–2009 # 4= Topic=(screen*) OR Topic=(referral OR refer*) OR Topic=(consultation OR consult*) Databases=SCI-EXPANDED, SSCI Timespan=1960–2009 # 3= Topic=(incidence) OR Topic=(prevalence) OR Topic=(disease progression) OR Topic=(disease history) OR Topic=(natural history) Databases=SCI-EXPANDED, SSCI Timespan=1960–2009 # 2= Topic=(JSLE OR SLE OR lupus OR JIA OR JRA) OR Topic=((limb pain) OR (grow* pain)) OR Topic=(fibromyalgia OR arthralgia) OR Topic=(joint AND (instability OR hypermobility)) OR Topic=((patellofemoral pain syndrome) OR synovitis) OR Topic=((juvenile OR early) AND (rheumatoid OR idiopathic) and arthritis) Databases=SCI-EXPANDED, SSCI Timespan=1960–2009 # 1= Topic=(antinuclear AND (antibod* OR factor* OR test*)) OR Topic=(anti-ccp OR (citrullinated peptide)) OR Topic=((ANA OR FANA) AND (test*)) OR Topic=(rheumatoid factor*) Databases=SCI-EXPANDED, SSCI Timespan=1960–2009

Topic: ANA RF Anti CCP Testing Search Strategies

Database: Academic Science Complete (EBSCO)

Notes: Limits: human, 1960

Date searched: 9Feb10

Results: 226

S20= S17 or S18 Limiters - Published Date from: 19600101-20091231
S19= S17 or S18
S18= S14 NOT S16
S17= S14 and S15
S16= Animal
S15= Human
S14= S8 or S9 or S10 or S11 or S12 or S13
S13= S2 and S5 and S7
S12= S2 and S4 and S7
S11= S1 and S2 and S4 and S7
S10= S1 and S2 and S7
S9= S1 and S3 and S6 and S8
S8= S1 and S2 and S3 and S7
S7= Children or Pediatric or Paediatric or Infant or Adolescent or Adolescence
S6= Demography or Gender or Anxiety or Infection
S5= Incidence or Prevalence or Natural history
S4= Screening or Referral or Consultation
S3= Diagnostic errors or Diagnosis
S2= Lupus or Rheumatoid arthritis or Fibromyalgia or Synovitis
S1= citrulline or anti-ccp or Rheumatoid factor

Database | Dates searched | Date search ran | Number of results
MEDLINE (OVID) | 1960–2009 | 14Jan10 | 5,389
EMBASE (OVID) | 1980–2009 | 14Jan10 | 4,849
CINAHL (EBSCO) | 1960–2009 | 14Jan10 | 374
CDSR & CENTRAL (Cochrane) | 1960–2009 | 9Feb10 | 216
Web of Science (ISI) | 1960–2009 | 9Feb10 | 856
Academic Search Complete (EBSCO) | 1960–2009 | 9Feb10 | 226
TOTAL RESULTS | | | 11,910

Search alerts:

1. PubMed
2. Web of Science
3. Scopus – Forward searching only