# Appendixes

Appendix A American College of Rheumatology Criteria for Classification of Systemic Lupus Erythematosus

Appendix B Literature Search Strings

Appendix C Forms

Appendix D List of Excluded Studies

Appendix E Methodological Quality of Included Studies

Appendix F Evidence Tables

Appendix G Subgroup Analyses by Onset Type of Juvenile Idiopathic Arthritis