# Acronyms

ACR: American College of Rheumatology
AHRQ: Agency for Healthcare Research and Quality
ANA: Antinuclear antibody
ARA: American Rheumatism Association
CCP: Cyclic-citrullinated peptide
CDSR: Cochrane Database of Systematic Reviews
CINAHL: Cumulative Index to Nursing and Allied Health Literature
ELISA: Enzyme linked immunosorbent assay
EPC: Evidence-based Practice Center
EULAR: European League Against Rheumatism
FANA: Fluorescent antinuclear antibody test
FN: False negative
FP: False positive
Ig: Immunoglobulin
IIF: Indirect immunofluorescence
ILAR: International League of Associations for Rheumatology
IU: International unit
JIA: Juvenile idiopathic arthritis
JRA: Juvenile rheumatoid arthritis
KQ: Key Question
LST: Latex slide test
MSK: Musculoskeletal
NIAMSK: National Institute of Arthritis and Musculoskeletal and Skin Diseases
NPV: Negative predictive value
NRG: Nonrheumatic disease group
OD: Optical density
ORG: Other rheumatic diseases group
PPV: Positive predictive value
pSLE: Pediatric systemic lupus erythematosus
RF: Rheumatoid factor
SD: Standard deviation
Sn: Sensitivity
Sp: Specificity
SSC: Standard sensitized test
TN: True negative
TP: True positive
WHO: World Health Organization