# Acknowledgements

We are grateful to members of the Technical Expert Panel who provided direction for the scope and content of the review. We also thank all the individuals at AHRQ, the Scientific Resource Center, and the peer reviewers for their comments and suggestions.

We also thank the following University of Alberta Evidence-based Practice Center staff for their assistance: Amy Beaith (designed and conducted literature searches), Ben Vandermeer (statistical consultation), Heather McPhee (screening and inclusion/exclusion), and Teodora Radisic (literature retrieval).