# Key Informants and Technical Expert Panel

Craig Della Valle, M.D.

Associate Professor of Orthopaedic Surgery

Rush University Medical Center

Chicago, IL

Charles W. Francis, M.D.

Director, Hemostasis and Thrombosis Program

University of Rochester School of Medicine & Dentistry

Rochester, NY

Jay Lieberman, M.D.

Director of the New England Musculoskeletal Institute

Chairman of the Department of Orthopaedic Surgery

University of Connecticut Health Center

Farmington, CT

Charles M. Turkelson, M.D.

Director, Department of Research and Scientific Affairs

American Academy of Orthopaedic Surgery

Rosemont, IL

Yngve Falck-Ytter, M.D.

Assistant Professor of Medicine

Case Western Reserve University School of Medicine

Director of Hepatology, Gastroenterology Section, Department of Medicine

Louis Stokes VA Medical Center

Cleveland, OH

Joshua J. Jacobs, M.D.

The William A. Hark, M.D. - Susanne G. Swift Professor and Chairman

Department of Orthopaedic Surgery

Rush Medical College

Chicago, IL

J. Samuel Pope, M.D.

Department of Pulmonary Medicine

Hartford Hospital

Hartford, CT

Sandra Zelman Lewis, Ph.D.

Assisstant Vice President, Health & Science Policy

American College of Chest Physicians

Northbrook, IL