# Results

## Results of the Literature Search

Two literature searches were conducted as previously described in the methods. The first search was used to identify literature to answer Key Questions 1 through 9. Upon conducting this literature search, we retrieved 3,464 unique citations from the database search, 120 citations from a manual review of the literature, and two citations added manually from the gray literature search conducted by the Scientific Resource Center. Upon updating the literature search in May 2011, a total of 165 citations were retrieved. After duplicate citations were removed, 3,079 citations remained. A total of 2,426 citations were excluded at the title and abstract level while 656 citations were excluded at the full text level. A total of 177 articles were found to match our inclusion criteria. A summary of search results is presented in Figure 2. All citations excluded at the full text level are listed in Appendix C along with the reason for exclusion.

Figure 2 PRISMA flow diagram for search one

Figure 2 shows the flow of study identification and slection for literature search one. The initial database search resulted in 1144 records from Medline, 435 records from Central, and 1885 records from Scopus. An additional 120 records were identified from other sources and 2 records were identified from gray literature search. From the updated literature search, 165 citatiosn were identified. After duplicates were removed, there were 3079 unique citations eligible for title and abstract screening. The first phase of screening excluded 2246 records for the following reasons: 1301 records were not a systematic review, study or trial; 55 records were reports conducted outside of humans; 381 records were reports not conducted in major orthopedic surgery; 473 records were reports that did not evaluate a comparison of interest; 36 records were reports published prior to 1980. This process left 833 records to be assessed for eligibility by screening the full-text articles. The second phase of screening excluded 656 records for the following reasons: 21 records were duplicate publications; 4 records were reports published prior to 1980; 196 record were not a full text systematic review, study, or trial; 74 record were reports not conducted in major orthopedic surgery; 70 records were not controlled studies; 138 records did not evaluate a comparison of interest; 117 records were not randomized controlled trials or observational studies with more than 750 study population; 21 records did not report an outcome of interest; 15 record were reports that did not meet diagnostic inclusion criteria for outcomes of interest. The full text screening left 177 records to be included in the report. Of the 177 records included, 41 records were either systematic review or meta-analyses,15 records were observational studies, and 121 were randomized controlled trials.

Of the 177 articles included in search one, 121 articles represented 98 unique randomized controlled trials (n=44,469).18-27,27-135Fifteen articles represented 14 unique controlled observational studies (n=480,241).136-150 Further details regarding the included trials and studies are provided per Key Question for those included in answering the Key Question. The study characteristics and quality of randomized controlled trials and observational studies are included in Appendix D and the baseline and procedural characteristics of enrolled patients in these trials and studies are in Appendix E. An overview of the results for Key Questions 1 through 10 can be found in Table 4. Evaluations for Key Questions 9 through 11 had insufficient strength of evidence and are not included. Evidence tables for final and intermediate health outcomes and harms are presented in Appendix F.

Table 4 Summary of results from base case analyses in patients who had major orthopedic surgery^*^

Endpoint/Comparison | Type and Number of Studies | Pooled | Conclusion/Result | SOE | AOE
KQ 1. Incidence of health outcomes in total hip replacement
PE | 5 RCT | Yes | Pooled incidence of 6% (0.3% to 18%) | L | L
DVT | 8 RCT | Yes | Pooled incidence of 39% (25% to 53%) | L | L
DVT | 1 RCT | No | One trial not suitable for pooling had an incidence of 24% | L | L
Proximal DVT | 4 RCT | Yes | Pooled incidence of 32% (14% to 54%) | L | L
Proximal DVT | 1RCT | No | One trial not suitable for pooling had an incidence of 14% | L | L
Distal DVT | 2 RCT | Yes | Pooled incidence of 30% (4% to 68%) | L | L
Distal DVT | 1 RCT | No | One trial not suitable for pooling had in incidence of 17.3% | L | L
Major bleeding | 6 RCT | Yes | Pooled incidence of 1% (0.2% to 2%) | M | L
Minor bleeding | 6 RCT | Yes | Pooled incidence of 5% (1% to 13%) | L | M
KQ 1. Incidence of health outcomes in total knee replacement
PE | 2 RCT | Yes | Pooled incidence of 1% (0.07% to 4%) | L | L
PE | 1 OBS | No | The observational study had an incidence of 0.3% | L | L
DVT | 2 RCT | Yes | Pooled incidence of 46% (5% to 91%) | L | L
DVT | 1 RCT, 1 OBS | No | One trial not suitable for pooling had an incidence of 68.8% and the observational study had an incidence of 0% | L | L
Proximal DVT | 2 RCT | Yes | Pooled incidence of 17% (1% to 66%) | L | L
Proximal DVT | 1 RCT | No | One trial not suitable for pooling had an incidence of 18.8% | L | L
Distal DVT | 2 RCT | Yes | Pooled incidence of 22% (12% to 35%) | L | L
Distal DVT | 1 RCT | No | One trial not suitable for pooling had an incidence of 40.6% | L | L
Major bleeding | 2 RCT | Yes | Pooled incidence of 3% (0.2% to 8%) | L | L
Minor bleeding | 2 RCT | Yes | Pooled incidence of 5% (3% to 8%) | M | L
KQ 2. Impact of surgical characteristics on outcomes – general vs. regional anesthesia
DVT | 4 RCT, 2 OBS | No | The majority of trials showed that regional anesthesia was associated with a decrease in the risk of DVT while observational data were conflicting | L | L
Symptomatic DVT | 2 RCT | No | No significant difference | L | L
Proximal DVT | 5 RCT | No | No significant difference | L | L
KQ 2. Impact of surgical characteristics on outcomes - cemented vs. noncemented arthroplasty
DVT | 2 RCT, 3 OBS | No | No significant difference | L | L
pDVT | 2 RCT | No | No significant difference | L | L
KQ 2. Impact of patient characteristics on outcomes – congestive heart failure
Symptomatic objectively confirmed VTE | 2 OBS | No | Significantly increases odds | M | M
KQ 2. Impact of patient characteristics on outcomes – age
Symptomatic objectively confirmed VTE | 2 OBS | No | No significant impact | L | M
DVT | 3 OBS | No | Significantly increased risk | L | L
KQ 4–8. Symptomatic objectively confirmed VTE
LMWH vs. FXaI | 5 RCTs | Yes | No significant difference, OR 0.70 (0.48 to 1.02) | L | M
LMWH vs. VKA | 2 RCTs | Yes | No significant difference, OR 1.00 (0.69 to 1.46) | L | M
Prolonged vs. standard duration prophylaxis | 4 RCTs | Yes | Significantly decreased risk, RR 0.38 (0.19 to 0.77), NNT 8 to 54 | M | L
KQ 4–8. Major VTE
Pharmacologic vs. no prophylaxis | 1 RCT (2 comp) | Yes | Significantly decreased risk, RR 0.21 (0.05 to 0.95), NNT 19 to 22 | L | L
LMWH vs. DTI | 3 RCTs | Yes | No significant difference, RR 1.26 (0.98 to 1.62) | M | L
KQ 4–8. PE
Pharmacologic vs. no prophylaxis | 12 RCTs | Yes | No significant difference, OR 0.38 (0.13 to 1.07) | L | L
LMWH vs. UFH | 10 RCTs | Yes | Significantly decreased odds, OR 0.48 (0.24 to 0.95), NNT 8 | M | L
LMWH vs. DTI | 3 RCTs | Yes | No significant difference, RR 1.18 (0.41 to 3.39) | M | L
LMWH vs. VKA | 5 RCTs | Yes | No significant difference, OR 1.11 (0.57 to 2.19) | M | M
UFH vs. DTI | 2 RCTs | Yes | No significant difference, OR 3.23 (0.56 to 18.98) | L | L
Pharmacologic + mechanical vs. pharmacologic | 2 RCTs | Yes | No significant difference, OR 1.03 (0.14 to 7.34) | L | M
Prolonged vs. standard duration prophylaxis | 6 RCTs | Yes | Significantly decreased odds, OR 0.13 (0.04 to 0.47), NNT 24 to 232 | H | L
Prolonged vs. standard duration prophylaxis | 1 RCT | No | One trial ineligible for pooling showed OR 0.54 (0.16 to 1.80) | H | L
KQ 4–8. Fatal PE
LMWH vs. FXaI | 5 RCTs | Yes | No significant difference, OR 0.90 (0.38 to 2.13) | L | L
LMWH vs. DTI | 2 RCTs | Yes | No significant difference, OR 1.43 (0.08 to 24.82) | L | L
KQ 4–8. Nonfatal PE
Pharmacologic vs. no prophylaxis | 6 RCTs 1 OBS | Yes (RCT) | No significant difference, OR 0.21 (0.04 to 1.30). Observational data were supportive | L | L
LMWH vs. UFH | 10 RCTs | Yes | No significant difference, OR 0.50 (0.25 to 1.00) | L | L
LMWH vs. FXaI | 5 RCTs | Yes | No significant difference, OR 0.68 (0.34 to 1.37) | M | L
LMWH vs. DTI | 2 RCTs | Yes | No significant difference, OR 0.93 (0.23 to 3.66) | L | L
LMWH vs. VKA | 3 RCTs | Yes | No significant difference, OR 1.00 (0.20 to 4.95) | L | L
UFH vs. DTI | 2 RCTs | Yes | No significant difference, OR 3.27 (0.56 to 18.98) | L | L
Pharmacologic + mechanical vs. pharmacologic | 2 RCTs | Yes | No significant difference, OR 1.03 (0.14 to 7.34) | L | M
Prolonged vs. standard duration prophylaxis | 5 RCTs | Yes | Significantly decreased odds, OR 0.13 (0.03 to 0.54), NNT 58 | M | L
Prolonged vs. standard duration prophylaxis | 1 RCT | No | One trial ineligible for pooling showed OR 0.13 (0.01 to 2.06) | M | L
KQ 4–8. Mortality
Pharmacologic vs. no prophylaxis | 10 RCTs 3 OBS | Yes (RCT) | No significant difference, OR 1.23 (0.54 to 2.78). One observational study supported this finding but another study suggested decrease in number of deaths with prophylaxis | M | L
LMWH vs. UFH | 8 RCTs | Yes | No significant difference, OR 0.39 (0.10 to 1.49) | M | L
LMWH vs. FXaI | 5 RCTs 2 OBS | Yes (RCT) | No significant difference, OR 1.08 (0.72 to 1.60). One observational study suggested significantly higher percent of deaths in patients who received LMWH vs. factor Xa inhibitors while the other study suggested no significant difference | M | L
LMWH vs. DTI | 4 RCTs | Yes | No significant difference, RR 0.45 (0.15 to 1.36) | M | L
LMWH vs. VKA | 6 RCTs | Yes | No significant difference, OR 0.79 (0.42 to 1.50) | M | M
LMWH vs. mechanical | 2 RCTs | Yes | No significant difference, OR 0.31 (0.05 to 1.80) | L | L
UFH vs. DTI | 2 RCTs | Yes | No significant difference, OR 7.13 (0.74 to 68.80) | L | L
KQ 4–8. DVT
Pharmacologic vs. no prophylaxis | 17 RCTs | Yes | Significantly decreased risk, RR: 0.56 (0.47 to 0.68), NNT 3 to 33 | M | L
Antiplatelet vs. mechanical | 2 RCTs | Yes | Significantly increased risk, RR 1.63 (1.11 to 2.39), NNH 4 to 27 | M | L
LMWH vs. UFH | 13 RCTs | Yes | Significantly decreased risk, RR 0.80 (0.65 to 0.99), NNT 12 to 100 | M | L
LMWH vs. UFH | 1 RCT (2 comp) | Yes | 1 trial ineligible for original pooled analysis showed RR 3.37 (0.70 to 16.17) | M | L
LMWH vs. FXaI | 5 RCTs | Yes | Significantly increased risk, RR 1.99 (1.57 to 2.51), NNH 13 to 26 | M | L
LMWH vs. VKA | 5 RCTs | Yes | Significantly decreased risk, RR 0.66 (0.55 to 0.79), NNT 6 to 13 | L | M
LMWH vs. mechanical | 3 RCTs | Yes | No significant difference, RR 0.90 (0.71 to 1.14) | M | L
UFH vs. DTI | 2 RCTs | Yes | Significantly increased risk, RR 2.31 (1.34 to 4.00), NNH 5 to 11 | M | L
VKA vs. mechanical | 3 RCTs | Yes | No significant difference, RR 1.45 (0.75 to 2.82) | L | L
Enoxaparin vs. other LMWH | 2 RCTs | Yes | No significant difference, RR 1.05 (0.64 to 1.71) | L | L
IPC vs. GCS | 1 RCT (2 comp) | Yes | Significantly decreased risk, RR 0.06 (0.01 to 0.41), NNT 3 to 7 | L | L
Pharmacologic + mechanical vs. pharmacologic | 3 RCTs | Yes | Significantly decreased risk, RR 0.48 (0.32 to 0.72), NNT 3 to 67 | M | M
Pharmacologic + mechanical vs. pharmacologic | 1 RCT | No | One trial ineligible for pooling showed RR 0.09 (0.01 to 0.85), NNT 5 | M | M
Prolonged vs. standard duration prophylaxis | 7 RCTs | Yes | Significantly decreased risk, RR 0.37 (0.21 to 0.64), NNT 5 to 32 | M | M
Prolonged vs. standard duration prophylaxis | 1 RCT | No | One trial ineligible for pooling showed RR 0.61 (0.38 to 0.97) | M | M
KQ 4–8. Asymptomatic DVT
Pharmacologic vs. no prophylaxis | 3 RCTs | Yes | Significantly decreased risk, RR 0.52 (0.40 to 0.69), NNT 4 to 6 | M | L
LMWH vs. UFH | 2 RCTs | Yes | No significant difference, RR 0.70 (0.43 to 1.16) | L | L
LMWH vs. DTI | 2 RCTs | Yes | No significant difference, RR 0.97 (0.85 to 1.10) | M | M
Prolonged vs. standard duration prophylaxis | 4 RCTs | Yes | Significantly decreased risk, RR 0.48 (0.31 to 0.75), NNT 8 to 65 | H | L
KQ 4–8. Symptomatic DVT
Pharmacologic vs. no prophylaxis | 4 RCTs 1 OBS | Yes (RCT) | No significant difference, OR 1.07 (0.25 to 4.52). Observational study data were supportive | M | L
LMWH vs. UFH | 3 RCTs | Yes | No significant difference, OR 0.62 (0.22 to 1.75) | L | L
LMWH vs. FXaI | 6 RCTs | Yes | No significant difference, OR 0.48 (0.21 to 1.21) | M | M
LMWH vs. DTI | 3 RCTs | Yes | No significant difference, RR 0.98 (0.34 to 2.87) | M | L
LMWH vs. VKA | 3 RCTs | Yes | No significant difference, OR 0.87 (0.61 to 1.24) | M | L
Prolonged vs. standard duration prophylaxis | 4 RCTs | Yes | Significantly decreased odds, OR 0.36 (0.16 to 0.81), NNT 27 to 79 | H | M
Prolonged vs. standard duration prophylaxis | 1 RCT | No | One trial ineligible for pooling showed OR 1.83 (0.57 to 5.87) | H | M
KQ 4–8. Proximal DVT
Pharmacologic vs. no prophylaxis | 12 RCTs | Yes | Significantly decreased risk, RR 0.53 (0.39 to 0.74), NNT 4 to 213 | H | L
LMWH vs. UFH | 9 RCTs | Yes | Significantly decreased risk, RR 0.60 (0.38 to 0.93), NNT 14 to 50 | H | L
LMWH vs. FXaI | 5 RCTs | Yes | Significantly increased risk, OR 2.19 (1.52 to 3.16), NNH 44 to 122 | L | L
LMWH vs. DTI | 2 RCTs | Yes | No significant difference, RR 0.91 (0.40 to 2.11) | L | M
LMWH vs. VKA | 6 RCTs | Yes | No significant difference, RR 0.63 (0.39 to 1.00) | L | M
LMWH vs. mechanical | 3 RCTs | Yes | No significant difference, RR 0.65 (0.34 to 1.26) | M | L
UFH vs. DTI | 2 RCTs | Yes | Significantly increased odds, OR 4.74 (2.99 to 7.49), NNH 11 | M | L
VKA vs. mechanical | 3 RCTs | Yes | Significantly decreased risk, RR 0.34 (0.16 to 0.73), NNT 11 to 31 | M | L
Enoxaparin vs. other LMWH | 2 RCTs | Yes | No significant difference, RR 1.06 (0.62 to 1.81) | L | L
IPC vs. GCS | 2 RCTs | No | No significant difference, one trial showed RR 0.36 (0.13 to 1.00) while the second trial, which compared enoxaparin plus IPC versus enoxaparin plus GCS, showed OR 0.12 (0.01 to 1.99) | L | M
Pharmacologic + mechanical vs. pharmacologic | 3 RCTs | Yes | No significant difference, RR 0.33 (0.09 to 1.22) | L | M
Pharmacologic + mechanical vs. pharmacologic | 2 RCTs | No | Two trials ineligible for pooling were evaluated separately and showed OR 0.14 (0.003 to 6.93) in one trial and RR 0.09 (0.01 to 0.85) in the other trial
Pharmacologic + mechanical vs. mechanical | 2 RCTs | Yes | No significant difference, RR 0.78 (0.35 to 1.74) | L | L
Prolonged vs. standard duration prophylaxis | 6 RCTs | Yes | Significantly decreased risk, RR 0.29 (0.16 to 0.52), NNT 9 to 71 | H | M
Prolonged vs. standard duration prophylaxis | 1 RCT | No | One trial ineligible for pooling showed RR 0.65 (0.31 to 1.38) | H | M
KQ 4–8. Distal DVT
Pharmacologic vs. no prophylaxis | 7 RCTs | Yes | Significantly decreased risk, RR 0.59 (0.42 to 0.82), NNT 8 to 35 | H | L
LMWH vs. UFH | 8 RCTs | Yes | No significant difference, RR 0.95 (0.74 to 1.23) | H | L
LMWH vs. FXaI | 5 RCTs | Yes | Significantly increased risk, RR 2.02 (1.65 to 2.48), NNH 11 to 33 | H | L
LMWH vs. VKA | 2 RCTs | Yes | Significantly decreased risk, RR 0.56 (0.43 to 0.73), NNT 6 to 10 | M | L
LMWH vs. mechanical | 3 RCTs | Yes | No significant difference, RR 1.00 (0.77 to 1.29) | M | L
IPC vs. GCS | 1 RCT (2 comp) | Yes | Significantly decreased risk, RR 0.07 (0.01 to 0.54), NNT 3 to 11 | L | M
Pharmacologic + mechanical vs. pharmacologic | 2 RCTs | Yes | No significant difference, one trial had no events and the remaining trial had two comparisons that were pooled to show RR 0.45 (0.16 to 1.26) | M | L
Pharmacologic + mechanical vs. pharmacologic | 1 RCT | No | One trial ineligible for pooling showed RR 0.89 (0.34 to 2.29) | M | L
Prolonged vs. standard duration prophylaxis | 4 RCTs | Yes | No significant difference, RR 0.39 (0.15 to 1.04) | L | M
KQ 4–8. Major bleeding
Pharmacologic vs. no prophylaxis | 8 RCTs 1 OBS | Yes (RCT) | No significant difference, RR 0.74 (0.36 to 1.51) Observational data were supportive | M | L
LMWH vs. UFH | 7 RCTs | Yes | Significantly decreased odds, OR 0.57 (0.37 to 0.88), NNT 41 | H | L
LMWH vs. FXaI | 5 RCTs 2 OBS | Yes (RCT) | Significantly decreased odds, OR 0.65 (0.48 to 0.89), NNT 74 to 145; observational data suggested no significant difference | M | L
LMWH vs. DTI | 4 RCTs | Yes | No significant difference, RR 1.12 (0.80 to 1.57) | M | L
LMWH vs. VKA | 7 RCTs | Yes | Significantly increased odds, OR 1.92 (1.27 to 2.91), NNH 57 to 220 | H | M
LMWH vs. VKA | 1 RCT (2 comp) | Yes | 1 trial ineligible for pooling showed an RR 1.51 (0.92 to 2.48) for major bleeding days 0–1 and a RR 3.41 (0.77 to 15.18) for major bleeding on days 2–8 | H | M
Enoxaparin vs. other LMWH | 2 RCT | Yes | No significant difference, RR 1.98 (0.53 to 7.37) | M | L
Prolonged vs. standard duration prophylaxis | 5 RCTs | Yes | No significant difference, OR 2.18 (0.73 to 6.51) | L | L
KQ 4–8. Major bleeding leading to reoperation
LMWH vs. FXaI | 4 RCTs | Yes | No significant difference, OR 0.67 (0.28 to 1.61) | M | L
LMWH vs. DTI | 3 RCTs | Yes | No significant difference, RR 1.27 (0.43 to 3.75) | M | L
UFH vs. DTI | 2 RCTs | No | No significant difference, one trial had no events and the other trial showed OR 0.51 (0.10 to 2.55) | L | L
KQ 4–8. Minor bleeding
Pharmacologic prophylaxis vs. no prophylaxis | 6 RCTs | Yes | Significantly increased risk, RR 1.67 (1.18 to 2.38), NNT 30 to 75 | H | M
LMWH vs. UFH | 5 RCTs | Yes | No significant difference, RR 0.90 (0.63 to 1.28) | M | L
LMWH vs. FXaI | 2 RCTs | Yes | Significantly decreased odds, OR 0.57 (0.35 to 0.94), NNT 31 to 60 | L
LMWH vs. DTI | 3 RCTs | Yes | No significant difference, RR: 1.07 (0.89 to 1.29) | M | L
LMWH vs. VKA | 7 RCTs | Yes | Significantly increased risk, RR 1.23 (1.06 to 1.43), NNH 18 to 218 | M | M
LMWH vs. VKA | 1 RCT (2 comp) | Yes | One trial ineligible for the original pooled analysis showed a RR 1.49 (0.30 to 7.37) on days 0–1 and a RR 0.87 (0.37 to 2.06) on days 2–8 | M | M
VKA vs. mechanical | 2 RCTs | Yes | No significant difference, OR 0.80 (0.26 to 2.41) | L | L
Prolonged vs. standard duration prophylaxis | 3 RCTs | Yes | Significantly increased odds, OR 2.44 (1.41 to 4.20), NNH 11 to 118 | H | M
KQ 4–8. Surgical site bleeding
LMWH vs. UFH | 3 RCTs | Yes | No significant difference, OR 0.92 (0.46 to 1.82) | L | L
LMWH vs. VKA | 2 RCT | Yes | Significantly increased odds OR 2.63 (1.31 to 5.28), NNH 23 to 64 | L | L
Enoxaparin vs. other LMWH | 2 RCT | Yes | No significant difference, RR 1.35 (0.30 to 5.97) | L | L
KQ 4–8. Bleeding leading to transfusion
LMWH vs. DTI | 2 RCTs | Yes | No significant difference, RR 1.00 (0.59 to 1.69) | H | L
KQ 4–8 HIT
LMWH vs. UFH | 3 RCTs | Yes | Significantly decreased odds, OR 0.12 (0.03 to 0.43), NNT 34 to 202 | M | L
KQ 4–8. Readmission
LMWH vs. UFH | 2 RCT | Yes | No significant difference, RR 0.82 (0.20 to 3.38) | L | L
LMWH vs. mechanical | 2 RCT | Yes | No significant difference, OR 0.83 (0.22 to 3.11) | L | L
Prolonged vs. standard duration prophylaxis | 1 RCT (2 comp) | Yes | No significant difference, RR 0.29 (0.06 to 1.34) | L | L

AOE = applicability of evidence; DTI = direct thrombin inhibitor; DVT = deep vein thrombosis; FXaI = factor Xa inhibitor; H = high; IPC = intermittent pneumatic compression; KQ = Key Question; L = low; LMWH = low molecular weight heparin; M = moderate; NNH = number needed to harm; NNT = number needed to treat; OBS = observational; OR = Peto's Odds Ratio; PE = pulmonary embolism; RCT = randomized controlled trial; RR = relative risk; SOE = strength of evidence; UFH = unfractionated heparin; VKA = vitamin K antagonists; VTE = venous thromboembolism

* Denotes that all base case analyses with at least one randomized controlled trial or one controlled observational study and a strength of evidence of low, moderate, or high evaluating the given outcome are represented in this table.

Forty-one articles represented 39 unique systematic reviews or meta-analyses.151-190 Of these, five meta-analyses were deemed relevant for comparison to the results of Key Question 1 and are described in Table 5. 153,159,164,169,171 Nineteen meta-analyses were deemed relevant for comparison to other Key Questions and are described in Table 6. The remaining systematic reviews and meta-analyses were used to manually search for additional literature which met our inclusion criteria.

Table 5 Summary of previous meta-analyses evaluating the pooled incidence of outcomes of interest in patients who had major orthopedic surgery

Author, Year | N studies (N Participants) | Population | Outcome and Pooled Incidence/Risk in Placebo or Control Arms (Confidence Interval)
Brookenthal, 2001^153^ | 14 (3482) | TKA | Symptomatic PE: AR 0% (0 to 10.9%) Fatal PE: AR 0% (0% to 4.2%)^*^ DVT: AR 60.2% (55.7% to 64.5%)
Freedman, 2000^159^ | 52 (10,929) | THA | Symptomatic PE: AR 1.51% (0.81% to 2.57%) Fatal PE: AR 0% (0% to 43%) DVT: AR 48.5% (43.4% to 53.7%) pDVT: AR 25.8% (21.4% to 30.7%) dDVT: AR 22.4% (18.8% to 26.6%) Major Bleeding: AR 0.56% (0.15% to 1.43%) Minor Bleeding: AR 3.0% (1.1% to 8.2%)
Murray, 1996^171^ | 181 papers (930,000) | THA | Fatal PE: 12% (3% to 30%)^*^
Imperiale, 1994^164^ | 56 (NR) | THA | DVT: 47% (40% to 53%)^†^ pDVT: 23% (17% to 29%)^†^ PE: 2.4% (1.3% to 3.5%)^†^
Mohr, 1993^169^ | 21 (3052) | THA | DVT: WMR 50% (NR) pDVT: WMR 24% (NR)

AR = absolute risk; CI = confidence interval; DVT = deep vein thrombosis; HFS = hip fracture surgery; NR = not reported; dDVT = distal deep vein thrombosis; N = number; pDVT = proximal DVT; PE = pulmonary embolism; sDVT = symptomatic DVT; THA = total hip arthroplasty; TKA = total knee arthroplasty; WMR = weighted mean risk

* Rates with 95% confidence interval using Poisson distribution.

† Unadjusted pooled risk.

Table 6 Summary of results from previous meta-analyses relevant to Key Questions 2 through 8

Author, Year | N studies (N Subjects) | Population and Interventions | Final Health Outcomes | Intermediate Outcomes | Adverse Outcomes
Friedman, 2010^185^ | 3 (8,210) | Population: THA and TKA Intervention 1: Dabigatran 220mg po QD Intervention 2: Dabigatran 150mg po QD Intervention 3: Enoxaparin 40mg SQ QD or 30mg SQ BID | --- | --- | Dabigatran 220mg versus enoxaparin Major bleeding: RD -0.2% (-0.8 to 0.5) Dabigatran 150mg versus enoxaparin Major bleeding: RD -0.4% (-1.0 to 0.2)
Tasker, 2010^179^ | 5 (1,847) | Population: THR Intervention: LMWH Comparator: Placebo | Nonfatal PE: OR 0.14 (0.03 to 0.74) Mortality: OR 0.77 (0.15 to 3.99) | --- | Major bleeding: OR 0.74 (0.23 to 2.4)
Hu, 2009^162^ | 21 (NR) | Population: THR and TKR Intervention: RA Comparator: GA | PE: OR 0.46 (0.21 to 1.02) Mortality: OR 0.94 (0.14 to 6.52) | DVT: OR 0.45 (0.24 to 0.84) | ----
Wolowacz, 2009^*,182^ | 3 (8,210) | Population: THA and TKA Intervention: Dabigatran 220mg po QD Comparator: Enoxaparin 40mg SQ QD or 30mg SQ BID | VTE: RR 0.94 (0.61 to 1.44) | --- | Major bleeding: RR 0.94 (0.51 to 1.75)
Mismetti, 2004^168^ | 29 (NR) | Population: THR, TKR, and HFS Intervention 1: VKA Intervention 2: Antiplatelet agent Intervention 4: IPC Intervention 5: UFH Intervention 6: LMWH Intervention 7: Placebo/control | VKA versus placebo/control PE: RR 0.23 (0.09 to 0.59) Death: RR 0.78 (0.56 to 1.09) VKA versus IPC Death: RR 1.58 (0.21 to 11.7) VKA versus UFH PE: RR 0.09 (0.004 to 2.40) VKA versus LMWH PE: RR 1.10 (0.59 to 2.05) Death: RR 1.30 (0.72 to 2.36) | VKA versus placebo/control DVT: RR 0.56 (0.37 to 0.84) VKA versus antiplatelet DVT: RR 0.84 (0.55 to 1.28) pDVT: RR 1.15 (0.67 to 1.98) VKA versus IPC aDVT: RR 1.21 (0.88 to 1.66) pDVT: RR 0.46 (0.25 to 0.82) VKA versus UFH aDVT: RR 1.25 (0.87 to 1.81) VKA versus LMWH DVT: RR 1.51 (1.27 to 1.79) pDVT: RR 1.51 (1.04 to 2.17) | VKA versus placebo/control Major Hemorrhage: RR 1.53 (0.68 to 3.45) VKA versus antiplatelet Major Hemorrhage: RR 0.98 (0.04 to 25) VKA versus IPC Major Hemorrhage: RR 1.77 (0.14 to 23) VKA versus LMWH Major Hemorrhage: RR 0.78 (0.49 to 1.26)
Muntz, 2004^170^ | 21 (20,523) | Population: THR, TKR, or HFS Intervention 1: LMWH Intervention 2: VKAs (warfarin and other coumarin derivatives) Intervention 3: UFH | --- | --- | VKAs versus LMWH Major Bleeding: RR 0.59 (0.44 to 0.80) UFH versus LMWH Major Bleeding: RR 1.52 (1.04 to 2.23)
Turpie, 2004^189^ and 2002^180^ | 4 (7,344) | Population: TKR, THR and HFS Intervention: Fondaparinux 2.5mg SQ QD Comparator: Enoxaparin (approved regimens) | VTE: Odds reduction: 49.6% (27.3 to 65.5) VTE: Odds reduction: 48.0% (27.3 to 63.2) | pDVT: Odds reduction: 57.4% (35.6 to 72.3)
O'Donnell, 2003^174^ | 2 (907)^†^ 5 (1,917) 7 (2,425) | Population: THA Intervention 1: Extended LMWH therapy after completion of an initial 7 to 12 days of prophylaxis after surgery Intervention 2: placebo/control | sVTE (3m): OR 0.39 (0.14 to 1.11) sPE (3m): ARR 0.36% (-.3% to 1.36%) Fatal PE (3m): ARR 0.09% (-0.08% to 0.27%) | --- | ---
Zufferey, 2003^184^ | 13 (1,925) | Population: THR, TKR, and HFS Intervention: LMWH (3000 anti-Xa IU to 6000 anti-Xa IU daily) Comparator: Placebo | --- | aDVT: RR 0.51 (0.45 to 0.59) | Major hemorrhage: RR 0.80 (0.36 to 1.79)
Handoll, 2002^‡,160^ | 31 (2,958) | Population: HFS Intervention 1: LMWH Intervention 2: UFH Intervention 3: LMWH or UFH Intervention 4: Mechanical methods (IPC and VFP) Intervention 5: Placebo or control | LMWH or UFH versus placebo/control PE: RR 1.00 (0.49 to 2.02) Nonfatal PE: RR 4.94 (1.10 to 22.07) Fatal PE: RR 0.47 (0.19 to 1.14) Death: RR 1.16 (0.77 to 1.74) Mechanical versus control PE: RR 0.40 (0.17 to 0.96) Fatal PE: RR 0.27 (0.07 to 1.08) Death: RR 0.50 (0.22 to 1.14) LMWH versus UFH PE: RR 3.29 (0.82 to 13.32) Nonfatal PE: RR 12.42 (0.72 to 213.88) Death: RR 0.85 (0.31 to 2.36) | LMWH or UFH versus placebo/control DVT: RR 0.60 (0.50 to 0.71) pDVT: RR 0.45 (0.28 to 0.73) dDVT: RR 0.65 (0.47 to 0.89) UFH versus placebo/control DVT: OR 0.41 (0.30 to 0.56) Mechanical versus control DVT: RR 0.31 (0.19 to 0.51) pDVT: RR 0.22 (0.10 to 0.53) dDVT: RR 0.45 (0.23 to 0.85) LMWH versus UFH DVT: RR 0.67 (0.48 to 0.94) pDVT: RR 0.84 (0.47 to 1.48) dDVT: RR 0.68 (0.23 to 2.00) | ---
Cohen, 2001^186^ | 6 (NR) | Population: Hip or knee arthroplasty Intervention: LMWH or warfarin followed by additional LMWH prophylaxis (total 4-5 weeks) Comparator: LMWH or warfarin (7-15 d) followed by placebo | VTE: OR 0.50 (0.30 o 0.83) | --- | ---
Eikelboom, 2001^156^ | 9 (3,999) | Population: THR and TKR Intervention: Extended-duration prophylaxis with LMWH or UFH (30d-42d) Comparator: Standard-duration prophylaxis with LMWH or UFH | PE: OR 0.43 (0.17 to 1.06) Death: OR 0.68 (0.25 to 1.88) | sDVT: OR 0.41 (0.24 to 0.68) aDVT: OR 0.48 (0.36 to 0.63) | Major bleeding: OR 0.62 (0.22 to 1.75) Minor bleeding: OR 1.56 (1.08 to 2.26)
Hull, 2001^163^ | 6 (1,953) | Population: Elective hip arthroplasty Intervention: LMWH in and out of hospital Comparator: LMWH inhospital then placebo | --- | DVT: RR 0.41 (0.32 to 0.54) pDVT: RR 0.31 (0.20 to 0.47) sDVT: RR 0.36 (0.20 to 0.67) | ---
Westrich, 2000^181^ | 23 (6,001) | Population: TKA Intervention 1: ASA 325mg to 650mg po QD Intervention 2: Warfarin (PT 1.3 to 1.5 of normal) Intervention 3: LMWH Intervention 4: IPC | ASA versus warfarin aPE: OR 1.2 (NR) sPE: OR 2.1 (0.9 to 4.8) ASA versus LMWH sPE: OR 2.7 (0.5 to 14) ASA versus IPC aPE: OR 2.5 (1.7 to 3.8) sPE: OR 6.5 (0.4 to 106) Warfarin versus LMWH sPE: OR 1.8 (0.2 to 14) Warfarin versus IPC aPE: OR 1.7 (1.1 to 2.6) sPE:OR 3.0 (0.2 to 53) LMWH versus IPC sPE: OR 2.4 (0.1 to 59) | ASA versus warfarin DVT: OR 1.7 (1.5 to 1.9) ASA versus LMWH DVT: OR 3.47 (3.04 to 3.96) ASA versus IPC DVT: OR 3.2 (2.7 to 3.8) Warfarin versus LMWH DVT: OR 2.05 (1.76 to 2.39) Warfarin versus IPC DVT: OR 1.9 (1.6 to 2.3) LMWH versus IPC DVT: OR 1.09 (0.9 to 1.33) | ---
Howard, 1998^161^ | 10 (3,079) | Population: TKA Intervention 1: LMWH Intervention 2: Warfarin Intervention 3: UFH Intervention 4: Placebo | --- | LMWH versus placebo DVT: RR 0.42 (0.26 to 0.67) pDVT: RR 0.11 (0.03 to 0.40) LMWH versus warfarin DVT: RR 0.71 (0.64 to 0.80) pDVT: RR 0.67 (0.43 to 1.04) LMWH versus UFH DVT: RR 0.76 (0.60 to 0.95) pDVT: RR 0.32 (0.13 to 0.80) | ---
Anderson, 1993^152^ | 6 (1,420) | Population: THA Intervention: LMWH Comparator: UFH | sPE: OR 0.22 (0.05 to 0.88) | DVT: OR 0.72 (0.53 to 0.95) pDVT: OR 0.40 (0.28 to 0.59) dDVT: OR 1.21 (0.86 to 1.74) | Major bleeding: OR 0.64 (0.34 to 1.23) Minor bleeding: OR 0.92 (0.61 to 1.33)
Leizorovicz, 1992^188^ | 23 (3,976)^§^ 5 (595) 14 (2,692) | Population: Elective or nonelective orthopedic surgery Intervention 1: LMWH SQ QD Intervention 2: UFH Intervention 3: Placebo | LMWH versus placebo PE: OR 0.64 (0.08 to 5.03) Mortality: OR 0.92 (0.18 to 4.62) LMWH versus UFH PE: OR 0.53 (0.27 to 1.03) Mortality: OR 0.88 (0.37 to 2.07) | LMWH versus placebo DVT: OR 0.32 (0.22 to 0.46) LMWH versus UFH DVT: OR 0.83 (0.68 to 1.02) | LMWH versus placebo Bleeding: OR 0.69 (0.22 to 2.11) LMWH versus UFH Bleeding: OR 1.09 (0.76 to 1.58)
Nurmohamed, 1992^187^ | 6 (1,294) | Population: Elective or traumatic hip surgery Intervention: LMWH Comparator: UFH | PE: RR 0.43 (0.22 to 0.82) | DVT: RR 0.68 (0.54 to 0.86) | Major bleeding: RR 0.75 (0.26 to 2.14)

aDVT = asymptomatic deep vein thrombosis; aPE = asymptomatic pulmonary embolism; ARR = absolute risk reduction; ASA = aspirin; d = days; dDVT = distal deep vein thrombosis; DVT = deep vein thrombosis; GA = general anesthesia; HFS = hip fracture surgery; IPC = intermittent pneumatic compression; IU = international units; LMWH = low molecular weight heparin; m = months; mg = milligram; NR = not reported; OR = odds ratio; PE = pulmonary embolism; pDVT = proximal deep vein thrombosis; po = by mouth; PT = prothrombin time; QD = daily; RA = regional anesthesia; sDVT = symptomatic deep vein thrombosis; sPE = symptomatic pulmonary embolism; SQ = subcutaneous; sVTE = symptomatic venous thromboembolism; THA = total hip arthroplasty; THR = total hip replacement; TKA = total knee arthroplasty; TKR = total knee replacement; UFH = unfractionated heparin; VFP = venous foot pump; VKA = vitamin K antagonist; VTE = venous thromboembolism; WMI = weighted mean incidence; Xa = factor 10a

* Results of random effects model.

† The number of studies and subjects varied based on the outcome reported and follows this order: sVTE, sPE, fatal PE.

‡ Results are presented with 99% confidence intervals.

§ The number of studies and subjects varied based on the comparison and follows this order: LMWH versus placebo, LMWH versus UFH.

--- Not reported.

The second literature search was used to identify literature to answer Key Questions 10 through 11. Upon conducting this literature search, we retrieved 529 unique citations from the database search and 24 citations from a manual review of the literature. Upon updating the literature search in May 2011, a total of 42 citations were retrieved. After removal of duplicate citations, 559 citations remained. A total of 462 citations were excluded at the title and abstract level while 91 citations were excluded at the full text level. A total of six articles met our inclusion criteria. A summary of search results is presented in Figure 3. All citations excluded at the full text level are listed in Appendix C along with the reason for exclusion. Of the six articles included in search two, two articles represented two unique randomized controlled trials (n=235).191,192 The trial characteristics and quality of the trials as well as the baseline and procedural characteristic of enrolled patients can be found in Appendixes D and E. Four articles represented three unique meta-analyses which were used to manually search for additional literature which met our inclusion criteria as well as to summarize findings pertinent to Key Questions 10 and 11.^193-196^

Figure 3 PRISMA flow diagram for search two

Figure 3 shows the flow of study identification and selection for literature search 2. The initial database search resulted in 113 records from Medline, 31 records from Central, 385 records from Scopus. An additional 24 records were identified through manual searching from other sources and the updated litertature search identified 42 records. After duplicates were removed, there were 559 unique citations eligible for title and abstract screening. The first phase of screening excluded 462 records for the following reasons: 144 records were not systematic review, study or trial; 18 records were reports conducted outside of humans; 34 records were reports which did not evaluate orthopedic surgeries of interest; 264 records were reports which did not evaluate a comparison of interest; 2 records were publications prior to 1980. This process left 97 records to be assessed for eligibility by screening the full-text articles. The second phase of screening excluded 91 articles for the following reasons: 1 record was a duplicate publication; 25 records were not systematic review, study or trial; 1 record was a report conducted outside of humans; 24 records were reports which did not evaluate orthopedic surgeries of interest; 9 records were uncontrolled studies; 27 records were reports which did not evaluate a comparison of interest; 4 records did not report outcomes of interest. 6 articles were included in the report. Of the 6 articles included, 4 were meta-analyses and 2 were randomized control trial.

## Key Question 1

In patients undergoing major orthopedic surgery (total hip replacement, total knee replacement or hip fracture surgery) what is the baseline postoperative risk of venous thromboembolism outcomes (symptomatic objectively confirmed venous thromboembolism, major venous thromboembolism, pulmonary embolism, fatal pulmonary embolism, nonfatal pulmonary embolism, deep vein thrombosis, asymptomatic deep vein thrombosis, symptomatic deep vein thrombosis, proximal deep vein thrombosis, distal deep vein thrombosis) and bleeding outcomes (major bleeding, major bleeding leading to reoperation, minor bleeding, surgical site bleeding, bleeding leading to infection, and bleeding leading to transfusion) in contemporary practice?

### Key Points

- The impact of orthopedic surgery on pulmonary embolism, deep vein thrombosis, and bleeding is most extensively evaluated in clinical trials for total hip replacement followed by total knee replacement and then hip fracture surgery. To determine the impact of surgery on venous thromboembolism, pulmonary embolism, or deep vein thrombosis we only allowed trial arms where no prophylaxis was given (either control or placebo) but for bleeding outcomes we also allowed trial arms with mechanical prophylaxis since the risk of bleeding is not impacted by these methods.
- Only evaluating trials and studies conducted from 1980 to the present limits the available literature base but likely reflects more contemporary practice. Only evaluating trials and studies with rigorous definitions of pulmonary embolism and deep vein thrombosis limits the available literature base and decreases the number of events that might be reported through the use of laxer definitions.
- We still had high statistical heterogeneity between trials for most endpoints which likely reflects several study characteristics. The majority of trials did not specifically define the duration of followup and implied an immediate postoperative followup, although this could vary between studies. Additionally, the followup period may not reflect the period of highest risk for venous thromboembolic events after major orthopedic surgery. The year in which studies were conducted ranged from 1980 to 2011, with most studies published prior to 2000, and may reflect changes in patient care and clinical practice. The countries and ethnicities where the trials were conducted in and when or how rigorously the endpoints were assessed for also varied.
- Not all three surgeries had incidence data reported in clinical trials for each outcome therefore when no data were available for an outcome and surgery, the symbol “--“ is used. In total hip arthroplasty, total knee arthroplasty, and hip fracture surgery, respectively, the postoperative incidence of pulmonary embolism (6 percent, 1 percent, 3 percent), deep vein thrombosis (39 percent, 46 percent, 47 percent), proximal deep vein thrombosis (32 percent, 17 percent, --), distal deep vein thrombosis (30 percent, 22 percent, --), major bleeding (1 percent, 3 percent, 8 percent), minor bleeding (5 percent, 5 percent, --) major bleeding leading to reoperation (0 percent, 0 percent, --), and major bleeding leading to transfusion (0 percent, 0 percent, ---) are reported in clinical trials. While the incidence of deep vein thrombosis events is relatively high, pulmonary embolism and bleeding events are rarer.
- The strength of the evidence is predominately low for hip and knee replacement surgery, however was insufficient for all outcomes within hip fracture surgery.
- No trials evaluated the following venous thromboembolism outcomes (symptomatic objectively confirmed venous thromboembolism, major venous thromboembolism, asymptomatic deep vein thrombosis, symptomatic deep vein thrombosis), and bleeding outcomes (surgical site bleeding, bleeding leading to infection).

### Detailed Analysis

#### Study Design and Characteristics

Nineteen randomized controlled trials (N=1325) and three controlled observational studies (N=1036) evaluated the overall baseline risk of venous thromboembolism outcomes and bleeding outcomes in contemporary practice.21,34-36,38,40,41,43,44,47,49-51,53,76,90,132,133,135,144,146,150 All nineteen randomized controlled trials were published as full text manuscripts. Thirteen randomized controlled trials evaluated the overall baseline risk of venous thromboembolism or bleeding outcomes in patients undergoing total hip arthroplasty.21,34,35,38,41,44,47,49,50,76,90,133,135 Five randomized controlled trials evaluated the overall baseline risk of venous thromboembolism or bleeding outcomes in patients undergoing total knee arthroplasty.36,38,43,51,53 Two randomized controlled trials evaluated the overall baseline risk of venous thromboembolism or bleeding outcomes in patients undergoing hip fracture surgery. The earliest trial was published in 1980 while the most recent published in 2011.^43,135^ The duration of followup ranged from the postoperative period to 2.4 years. Three trials received funding from industry,38,53,133 five trials received funding from government and foundation,34,49,50,76,90 one trial received funding from industry and government,132 one trial received funding from government,35 and in nine trials the funding source was not reported.21,36,40,41,43,44,47,51,135

The mean age of enrolled patients ranged from 54.9 years to 80 years. Females represented between 18.0 to 91.81 percent of the enrolled populations. The mean weight ranged from 56 to 71.4 kilograms. Few patients enrolled had a history of venous thromboembolism, with the majority of trials reporting 0 to 10.0 percent. Presence of varicosity was ranged from no varicosity to 33.3 percent. The percent of patients with a history of malignancy ranged from 0 to 7.14 percent. None of the trials reported the percent of patients who had previously undergone orthopedic surgery.

Eighty to 100 percent of patients underwent primary surgery and the percent of patients who had cemented fixation during surgery ranged from 0 to 100 percent. Mean duration of surgery ranged from 60 to 147 minutes and the mean duration of anesthesia was only reported by one trial with 205 minutes for the control group. Use of general versus regional anesthesia varied, with general anesthesia use ranging from 0 to 100 percent of patients and regional anesthesia use ranging from 0 to 100 percent of patients. The mean length of hospital stay was infrequently reported, and when it was ranged from 7.9 to 16 days.

Three controlled observational studies (N=1036) evaluated the overall baseline risk of venous thromboembolism outcomes and bleeding outcomes in contemporary practice.144,146,150 All of these unfunded observational studies were published as full text manuscripts. First study was conducted in people undergoing total hip or total knee arthroplasty and those without chemical prophylaxis (N=136) all had contraindications to receive aspirin therapy which may not be representative of the natural course of embolization or bleeding.144 It was not explicitly stated whether or not mechanical approaches could have been used in these patients. The second study was conducted in people undergoing total knee arthroplasty and those with no pharmacological or mechanical prophylaxis (N=785). Since they were derived mostly from orthopedic practices where a lack of prophylaxis is routine, it is not subject to the same confounds as the first observational study.146 The third study was conducted among patients who underwent total hip arthroplasty, total knee arthroplasty, or hip fracture surgery (N=115). Episodes of major bleeding were identified using ICD-90-CM diagnosis codes.150

#### Outcome Evaluation

A summary of the baseline risk of venous thromboembolism and bleeding outcomes during the postoperative period from included trials is presented in Table 7 to Table 9. The majority of trials did not specifically define the duration of followup and implied an immediate postoperative followup therefore the period for which these incidences reflect is likely the immediate postoperative period rather than longer term. Five trials evaluated the occurrence of pulmonary embolism among patients undergoing total hip arthroplasty who received no pharmacologic or mechanical prophylaxis (patients were randomly allocated to control or placebo).21,34,35,49,50 In these trials, the pooled incidence of pulmonary embolism was 6 percent [0.06 (95 percent CI=0.003 to 0.18)]. A high level of statistical heterogeneity was detected (I^2^=88.8 percent), but publication bias was not found (Egger's P=0.106). Only one trial evaluated the occurrence of fatal and nonfatal pulmonary embolism.49 In this trial, 0 out of 50 patients (0 percent) developed fatal pulmonary embolism and 1 out of 50 patients (2 percent) developed nonfatal pulmonary embolism.

Table 7 The overall baseline risk of venous thromboembolism and bleeding outcomes in patients undergoing major orthopedic surgery limited to hip replacement surgery

Author, Year | PE | Fatal PE | Nonfatal PE | DVT | Proximal DVT | Distal DVT | Major Bleeding | Minor Bleeding | Major Bleeding Leading to Reoperation | Bleeding Leading to Transfusion
Yokote, 2011^135^ | --- | --- | --- | --- | --- | --- | 0/85 (0.0%) | 2/85 (2.4%) | --- | ---
Fuji, 2008^38^ | --- | --- | --- | --- | --- | --- | 0/101 (0.0%) | 2/101 (2.0%) | --- | ---
Kim, 2003^21^ | 0/200 (0.0%) | --- | --- | 20/100 (20.0%) | 12/100 (12.0%) | 14/100 (14.0%) | --- | --- | --- | ---
Kim, 1998^41^ | --- | --- | --- | 10/50 (20.0%) | --- | --- | 0/50 (0.0%) | --- | --- | ---
Samama, 1997^44^ | --- | --- | --- | --- | --- | --- | 1/75 (1.3%) | 21/75 (28.0%) | 0/75 (0.0%) | ---
Kalodiki, 1996^133^ | --- | --- | --- | 13/14 (92.9%) | 8/14 (57.1%) | --- | --- | --- | --- | ---
Francis, 1992^76^ | --- | --- | --- | --- | --- | --- | --- | 4/98 (4.1%) | 0/98 (0.0%) | 0/98 (0.0%)
Torholm, 1991^47^ | --- | --- | --- | 16/54 (29.6%) | --- | --- | --- | --- | --- | ---
Paiment, 1987^90^ | --- | --- | --- | --- | --- | --- | 0/66 (0.0%) | 3/66 (4.5%) | --- | ---
Alfaro, 1986^35^ | 1/30 (3.3%) | --- | --- | 9/30 (30.0%) | --- | --- | --- | --- | --- | ---
Turpie, 1986^49^ | 1/50 (2.0%) | 0/50 (0.0%) | 1/50 (2.0%) | 20/39 (51.3%) | 9/39 (23.1%) | --- | 2/50 (4.0%) | 0/50 (0.0%) | --- | ---
Welin-Berger, 1982^50^ | 1/20 (5.0%) | --- | --- | 5/20 (25.0%) | --- | --- | --- | --- | --- | ---
Modig, 1981^34^ | 9/30 (30.0%) | --- | --- | 16/30 (53.3%) | 14/30 (46.7%) | 15/30 (50.0%) | --- | --- | --- | ---

DVT = deep vein thrombosis; PE = pulmonary embolism

--- No data.

Table 8 The overall baseline risk of venous thromboembolism and bleeding outcomes in patients undergoing major orthopedic surgery limited to knee replacement surgery

Author, Year | PE | Fatal PE | Nonfatal PE | DVT | Proximal DVT | Distal DVT | Major Bleeding | Minor Bleeding | Major Bleeding Leading to Reoperation | Bleeding Leading to Transfusion
Fuji, 2010^53^ | --- | --- | --- | --- | --- | --- | 1/124 (0.8%) | 6/124 (4.8%) | 0/124 (0.0%) | 0/124 (0.0%)
Chin, 2009 36 | 1/110 (0.9%) | --- | --- | 24/110 (21.8%) | 3/110 (2.7%) | 21/110 (19.1%) | --- | --- | --- | ---
Fuji, 2008 38 | --- | --- | --- | --- | --- | --- | 4/89 (4.5%) | 4/89 (4.5%) | --- | ---
Wilson, 1992^51^ | 0/32 (0.0%) | 0/32 (0.0%) | 0/32 (0.0%) | 22/32 (68.8%)^*^ | 6/32 (18.8%)^*^ | 13/32 (40.6%)^*^ | --- | --- | --- | ---
McKenna, 1980^43^ | --- | --- | --- | 9/12 (75.0%) | 5/12 (41.7%) | 4/12 (33.3%) | --- | --- | --- | ---

DVT = deep vein thrombosis; PE = pulmonary embolism

* Denotes events per total number of legs operated on rather than total number of people

--- No data.

Table 9 The overall baseline risk of venous thromboembolism and bleeding outcomes in patients undergoing major orthopedic surgery limited to hip fracture surgery

Author, Year | PE | Fatal PE | Nonfatal PE | DVT | Proximal DVT | Distal DVT | Major Bleeding | Minor Bleeding | Major Bleeding Leading to Reoperation | Bleeding Leading to Transfusion
Jorgensen, 1992^40^ | --- | --- | --- | 18/38 (47.4%) | --- | --- | --- | --- | --- | ---
Powers, 1989^132^ | 2/63 (3.2%) | 0/63 (0.0%) | 2/63 (3.2%) | --- | --- | --- | 5/63 (7.9%) | --- | --- | ---

DVT = deep vein thrombosis; PE = pulmonary embolism

--- No data.

Two trials evaluated the occurrence of pulmonary embolism among patients undergoing total knee arthroplasty who received no pharmacologic or mechanical prophylaxis (patients were randomly allocated to control or placebo).36,51 In these trials, the pooled incidence of pulmonary embolism was 1 percent [0.01 (95 percent CI=0.0007 to 0.04)]. Out of these trials, one trial also evaluated the occurrence of fatal and nonfatal pulmonary embolism.51 In this trial no patients developed fatal or nonfatal pulmonary embolism.

In hip fracture surgery, 2 of 63 patients (3 percent) who received no pharmacologic or mechanical prophylaxis developed pulmonary embolism in the only available trial.132 Both of the pulmonary embolism events were nonfatal.

Eight trials evaluated the occurrence of deep vein thrombosis among patients who received no pharmacologic or mechanical prophylaxis undergoing total hip arthroplasty.21,34,35,41,47,49,50,133 In these trials, the pooled incidence of deep vein thrombosis was 39 percent [0.39 (95 percent CI=0.25 to 0.53)]. A high level of statistical heterogeneity was detected (I^2^=85.6 percent), but publication bias was not found (Egger's P=0.118). Four trials evaluated the occurrence of proximal deep vein thrombosis among patients undergoing total hip arthroplasty who received no pharmacologic or mechanical prophylaxis.21,34,49,133 In these trials, the pooled incidence of proximal deep vein thrombosis was 32 percent [0.32 (95 percent CI=0.14 to 0.54)]. A high level of statistical heterogeneity and publication bias were detected (I^2^=87.2 percent, Egger's P=0.030), although the directionality of the publication bias was unclear. Two trials evaluated the occurrence of distal deep vein thrombosis among patients undergoing total hip arthroplasty who received no pharmacologic or mechanical prophylaxis.21,34 In these trials, the pooled incidence of distal deep vein thrombosis was 30 percent [0.30 (95 percent CI=0.04 to 0.68)]. In the trial by Kim and colleagues in 2003, the authors also determined the risk of deep vein thrombosis among patients who could have had more than one hip operated on. These data were not suitable for pooling but deep vein thrombosis, proximal deep vein thrombosis, and distal deep vein thrombosis occurred in 72 of 300 hips (24 percent), 42 of 300 hips (14 percent), and 52 of 300 hips (17.3 percent) operated on.21

Three trials evaluated the occurrence of deep vein thrombosis among patients undergoing total knee arthroplasty who received no pharmacologic or mechanical prophylaxis.36,43,51 However the trial by Wilson and colleagues was not suitable for pooling because the incidence was reported out of legs rather than patients. In the remaining two trials, the pooled incidence of deep vein thrombosis was 46 percent [0.46 (95 percent CI=0.05 to 0.91)]. The same two trials evaluated the occurrence of proximal deep vein thrombosis and distal deep vein thrombosis among patients undergoing total knee arthroplasty who received no prophylaxis.36,43 In these trials, the pooled incidence of proximal deep vein thrombosis was 17 percent [0.17 (95 percent CI=0.01 to 0.66)] and the pooled incidence of distal deep vein thrombosis was 22 percent [0.22 (95 percent CI=0.12 to 0.35)].36,43 In a trial by Wilson and colleagues, patients who had one or more total knee replacements had a deep vein thrombosis, proximal deep vein thrombosis and distal deep vein thrombosis in 22 of 32 legs (68.8 percent), 6 of 32 legs (18.8 percent), and 13 of 32 legs (40.6 percent), respectively.51

One trial evaluated the occurrence of deep vein thrombosis among patients undergoing hip fracture surgery who received no pharmacologic or mechanical prophylaxis.40 The pooled incidence of deep vein thrombosis could not be calculated because only one study was available. In this trial, 18 out of 38 patients (47 percent) undergoing hip fracture surgery developed deep vein thrombosis. No trials evaluated the occurrence of proximal or distal deep vein thrombosis among patients undergoing hip fracture surgery who received no pharmacologic or mechanical prophylaxis.

Six trials evaluated the occurrence of major bleeding among patients undergoing total hip arthroplasty who received either no prophylaxis or only mechanical prophylaxis.38,41,44,49,90,135 In these trials, the pooled incidence of major bleeding was 1 percent [0.01 (95 percent CI=0.002 to 0.02)]. A low level of statistical heterogeneity was detected as was the presence of publication bias detected (I^2^=12.3 percent, Egger's P=0.040). The direction of publication bias suggests that there may be underestimation of the occurrence of major bleeding. Six trials evaluated the occurrence of minor bleeding among patients undergoing total hip arthroplasty who received either no prophylaxis or only mechanical prophylaxis.38,44,49,76,90,135 In these trials, the pooled incidence of minor bleeding was 5 percent [0.05 (95 percent CI=0.01 to 0.13)]. A high level of statistical heterogeneity was detected (I^2^=88.1 percent). Publication bias was detected as well, suggesting an underestimation in the incidence of minor bleeding (Egger's P=0.008). In the two trials that evaluated the occurrence of major bleeding leading to reoperation among patients undergoing total hip arthroplasty who received either no prophylaxis or only mechanical prophylaxis, no events occurred.44,76 In the one trial that evaluated bleeding leading to transfusion no events occurred.76

Two trials evaluated the occurrence of major bleeding among patients undergoing total knee arthroplasty who received either no prophylaxis or only mechanical prophylaxis.38,53 In these two trials, the pooled incidence of major bleeding was 3 percent [0.03 (95 percent CI=0.002 to 0.08)]. Two trials evaluated the occurrence of minor bleeding among patients undergoing total knee arthroplasty who received either no prophylaxis or only mechanical prophylaxis.38,53 In these two trials, the pooled incidence of minor bleeding was 5 percent [0.05 (95 percent CI=0.03 to 0.08)]. In the one trial that evaluated the occurrence of major bleeding leading to reoperation among patients undergoing total knee arthroplasty who received either no prophylaxis or only mechanical prophylaxis, no events occurred.53 In the one trial that evaluated bleeding leading to transfusion no events occurred.53

One trial evaluated the occurrence of major bleeding among patients undergoing hip fracture surgery who received either no prophylaxis or only mechanical prophylaxis.132 In this trial, 5 out of 63 patients (8 percent) undergoing hip fracture surgery developed major bleeding. No trials evaluated the occurrence of minor bleeding, major bleeding leading to reoperation or major bleeding leading to transfusion in this population.

In the first observational study, incidence of fatal pulmonary embolism, nonfatal pulmonary embolism, and deep venous thrombosis after total hip or total knee arthroplasty were 0 percent, 0 percent, and 1.5 percent, respectively.144 However, these patients all had contraindications to aspirin prophylaxis and might not be representative of the overall population undergoing orthopedic surgery. It is also not clear whether or not mechanical prophylaxis was allowed. In the second observational study, there was no occurrence of deep vein thrombosis but 2 of 785 patients (0.3 percent) undergoing total knee arthroplasty developed pulmonary embolism, both episodes were nonfatal.146 In the third observational study, the incidence of major bleeding was 0.9 percent among patients undergoing total hip arthroplasty, total knee arthroplasty, or hip fracture surgery.

#### Strength of Evidence and Applicability of the Body of Evidence

The majority of incidences of health outcomes and adverse events in the major orthopedic surgery population presented in Key Question 1 had strength of evidence rating of low or insufficient. All outcomes evaluated for hip fracture surgery were rated with insufficient evidence. As randomization was broken to pool data from placebo and control arms the risk of bias was inherently higher. Although each major orthopedic surgery was considered separately, high statistical heterogeneity was observed between trials for most endpoints which likely reflect the different time periods of followup, the countries and ethnicities where the trials were conducted in and when or how rigorously the endpoints were assessed for. In total hip replacement, there was moderate strength of evidence for the incidence of major bleeding although the strength of evidence was low for incidence of pulmonary embolism, deep vein thrombosis, proximal deep vein thrombosis, distal deep vein thrombosis, and minor bleeding. In total knee replacement surgery, the strength of evidence was moderate for the incidence of minor bleeding while low for the incidences of pulmonary embolism, deep vein thrombosis, proximal deep vein thrombosis, distal deep vein thrombosis, and major bleeding. For all outcomes evaluated in hip fracture surgery, data were insufficient while in total hip and knee replacement surgery data were insufficient for symptomatic objectively confirmed venous thromboembolism, major venous thromboembolism, fatal or nonfatal pulmonary embolism, asymptomatic or symptomatic deep vein thrombosis, major bleeding leading to reoperation, surgical site bleeding, bleeding leading to infection or leading to transfusion in either total hip or knee replacement surgery.

The overall applicability was low for all outcomes with exception of major bleeding, minor bleeding and bleeding leading to transfusion in total hip replacement surgery which had moderate applicability. Although each major orthopedic surgery was considered separately when estimating the incidence of outcomes, the majority of trials and in many cases the only trials available were conducted outside of the United States. Surgical and post surgical characteristics, training, and expertise in other countries may not reflect that within the United States. Additionally, some trials were conducted in the 1980s as opposed to the 1990s or within the 2000's, which may be subject changes in surgical techniques and patient care over time. Given the general description of the followup period in the majority of trials, the presented incidences likely reflect a more immediate postoperative period rather than a long term followup.

## Key Question 2

In patients undergoing major orthopedic surgery (total hip replacement, total knee replacement or hip fracture surgery) what patient, surgical or postsurgical characteristics predict or differentiate patient risk of venous thromboembolic and bleeding outcomes in contemporary practice?

### Key Points

- Sixteen randomized controlled trials and four observational studies evaluated the impact of surgical characteristics on venous thromboembolic or bleeding outcomes.
- Data were insufficient for all surgical or postsurgical characteristics with the exception of two comparisons; general versus regional anesthesia and cemented versus noncemented arthroplasty, in which there was a low strength of evidence.
  ○ There was low strength of evidence that patients who had general anesthesia had a higher risk of deep vein thrombosis compared with regional anesthesia while there was no difference in the risk of proximal or distal deep vein thrombosis compared with regional anesthesia. Data were insufficient to evaluate the impact on the risk of pulmonary embolism, asymptomatic deep vein thrombosis, symptomatic deep vein thrombosis, major bleeding and minor bleeding or the comparison of spinal versus regional anesthesia and the risk of deep vein thrombosis.
  ○ There was also low strength of evidence that patients who had cemented arthroplasty had no difference in the risk of deep vein thrombosis or proximal deep vein thrombosis compared with noncemented arthroplasty. Data were insufficient to evaluate the impact on pulmonary embolism and on the risk of deep vein thrombosis.
  ○ Data were insufficient to evaluate the following relationships: bone vacuum cement versus standard procedure and the risk of deep vein thrombosis, proximal or distal deep vein thrombosis, major bleeding, and minor bleeding; tourniquet use versus no use on the risk of asymptomatic or symptomatic or distal deep vein thrombosis; early versus late tourniquet release on the risk of deep vein thrombosis; modified limb position on the risk of deep vein thrombosis, proximal deep vein thrombosis, or pulmonary embolism; tissue fibrin use versus no tissue fibrin on the risk of fatal pulmonary embolism or deep vein thrombosis; primary versus revision surgery on the odds of deep vein thrombosis, perioperative blood loss, operative time, or blood transfusions.
- Eleven observational studies evaluated the impact of patient characteristics on venous thromboembolic or bleeding outcomes all using multivariate regression analysis. Overall few patient characteristics were evaluated by more than one study for each outcome of interest.
- Overall data were insufficient for all patient characteristics with the exception of two; congestive heart failure and age.
  ○ There was moderate strength of evidence that congestive heart failure increased the odds of symptomatic objectively confirmed venous thromboembolism.
  ○ There was low strength of evidence that age did not impact the odds of symptomatic objectively confirmed venous thromboembolism and increased the odds of deep vein thrombosis, in major orthopedic surgery.
- Data were insufficient to evaluate most patient characteristics including the following:
  ○ The odds of symptomatic objectively confirmed venous thromboembolism were increased by inactive malignancy (one study), hormone replacement therapy (one study), living at home (one study), intertrochanteric or subtrochanteric fractures (one study), increased hemoglobin on admission (one study), personal or familial history of venous thromboembolism (one study), and varicose veins (one study) while those showing no effect on the odds included male gender (one study).
  ○ The odds of pulmonary embolism were increased by age and genitourinary tract infection, decreased by cardiovascular disease, and unaffected by a history of phlebitis, phlebitis in the opposite extremity, thyroid hormone replacement therapy, history of pulmonary embolism, varicosity, or peripheral vascular disease, each evaluated in one study.
  ○ The odds of deep vein thrombosis were uninfluenced by height, weight, Factor V Leiden mutation (each evaluated in one study), and mixed effects were seen with age (three studies), obesity (two studies), and gender (two studies). Smoking was reported in one study to have little to no effect although magnitude and direction of effect was not reported.
  ○ The odds of symptomatic deep vein thrombosis were consistently increased by metabolic syndrome while were consistently unaffected by age, gender, education, diabetes mellitus, hypertension, hyperlipidemia, body mass index, and presence of comorbidities.
  ○ The odds of proximal deep vein thrombosis were increased by congestive heart failure (one study) while were unaffected by age (two studies), prior deep vein thrombosis (one study), inactive malignancy (one study), current hormone replacement therapy (one study), chronic tobacco use (one study), and blood disorders defined as sickle-cell trait, polycthymia vera, and thrombocytopenia (one study).
  ○ The one study which evaluated major bleeding suggested that age, gender, risk of bleeding, specific surgical procedure (total hip, knee replacement or hip fracture surgery), and prophylaxis administered in the hospital significantly impacted the risk of major bleeding. However, the magnitude and direction of the effect was not specified.

### Detailed Analysis

#### Study Design and Characteristics

Sixteen randomized controlled trials (N=1777), seven controlled observational studies (N=18152) and four nested observational studies (N=2469) evaluated the impact of patient, surgical, or postsurgical characteristics on the risk of venous thromboembolic or bleeding outcomes.18-24,26,28-34,56,68,73,117,136-141,150,197 All sixteen randomized controlled trials evaluated surgical characteristics and were published as full text manuscripts. Six trials compared general with regional anesthesia,20,24,30,32,34,197 one trial compared spinal with epidural anesthesia,19 three trials evaluated cemented arthroplasty techniques,21,22,26,68 three trials evaluated aspects of tourniquet use during surgery,28,31,33 two trials evaluated limb positioning18,29 and one trial evaluated tissue fibrin adhesive.23 Six trial enrolled patients who had total hip replacement surgery (n=773),18,21,22,26,34,197 nine trials enrolled patients who had total knee replacement surgery (n=964),19,20,23,24,28-31,33 and one trial enrolled patients who had hip fracture surgery (n=40).32 The earliest trial was published 1981 while the most recent in 2008. The duration of followup ranged from the postoperative time period to one year. One trial was funded by industry,26 two trials were funded by government/foundation,22,30 two trials were funded by government/foundation and industry20,34 two trials were unfunded,23,33 seven trials did not disclose funding source,18,19,21,24,28,31,32,197

The mean age of patients ranged from 54.9 to 73.9 years.21,32 Females represented between 37.5 to 81.0 percent of the enrolled population.19,24 Mean weight ranged from 68.7 to 100 kilograms.19,197 History of venous thromboembolism ranged from zero percent to 10 percent.20,26,28-30,33,34 Other baseline characteristics were scarcely reported. Eight studies evaluated exclusively patients who had primary surgery.18,22,24,26,29-31,197 Mean hospital length of stay was reported in four trials and ranged from 10.4 to 12.7 days.24,26,30,31 Mean duration of surgery ranged from 51 to 161.3 minutes.28,34

Eleven controlled observational studies evaluated the impact of patient and surgical characteristics on the incidence of venous thromboembolic or bleeding outcomes. Four were nested in randomized controlled trials56,68,73,117 while seven were controlled observational studies.136-141 All four nested studies evaluated patients who had total hip replacement surgery (n=2469), one study evaluated patients who had total knee replacement surgery (n=1460), one study evaluated patients who had hip fracture surgery (n=5300), three studies evaluated patients who had either total knee or hip replacement surgery (n=2035) and two studies evaluated all three major orthopedic surgeries (n=9357). The most recent study was published in 2010 while the earliest was published in 1991. Four studies did not report funding source,137,139,140,150 two were funded by industry,136,138 and one was funded by academia and foundation.141

The mean age of patients ranged from 62.3 to 80 years.117,140 Females represented between 47.0 to 82.91 percent of the enrolled population.140,141 Mean weight was rarely reported and ranged from 71 to 83.9 kilograms.117,136 Five studies evaluated exclusively patients who had primary surgery68,73,136-138 while two evaluated revision surgery as well.56,117 Mean hospital length of stay was reported in three studies and ranged from 4.4 to 10 days.117,139,141 Other baseline and procedural characteristics were scarcely reported.

#### Outcome Evaluations

We qualitatively summarized the findings from our literature search of surgical and postsurgical characteristics which may predict or differentiate patient risk of venous thromboembolic or bleeding outcomes in contemporary practice according to covariate. The qualitative summarization of patient characteristics follows according to the outcome evaluated.

##### Surgical Characteristics

###### Anesthesia Regimens

Seven randomized controlled trials and two observational studies evaluated the anesthesia regimen used during major orthopedic surgery. One of the randomized controlled trials compared spinal anesthesia with epidural anesthesia19 while the other six trials and the two nested observational studies compared general anesthesia with regional anesthesia.20,24,30,32,34,56,73,197

One randomized controlled trial by Farag and colleagues compared spinal versus epidural anesthesia in 38 patients who had total hip replacement surgery.19 All patients received bilateral antiembolism compression stockings while patients in the spinal anesthesia group also received prophylaxis with a low molecular weight heparin. Presence of deep vein thrombosis was assessed on days 3 and 10 postoperatively and there were no events at either time point.

Six randomized controlled trials compared general versus regional anesthesia in patients who had major orthopedic surgery.20,24,30,32,34,197 Two trials did not provide patients with mechanical or pharmacologic venous thromboembolism prophylaxis.32,34 The first of these trials by McKenzie and colleagues randomized 40 patients who had hip fracture surgery to receive general anesthesia or subarachnoid blockade. The incidence of deep vein thrombosis and of asymptomatic deep vein thrombosis was significantly higher in those who received general anesthesia as opposed to subarachnoid blockade (75 percent versus 40 percent, p <0.05; 75 percent versus 25 percent, p=0.004). No deep vein thromboses were symptomatic in the group that received general anesthesia while three symptomatic events occurred in the subarachnoid blockade group (0 percent versus15 percent, p=0.230). The second of these trials by Modig and colleagues randomized 30 patients who had total hip replacement surgery to receive general anesthesia versus epidural anesthesia.34 There was no significant difference in the incidence of pulmonary embolism in the general versus epidural anesthesia groups 14 days after surgery (46.7 percent versus 13.3 percent, p=0.111). Although there was no significant difference in the incidence of deep vein thrombosis in the regional versus general anesthesia groups (33.3 percent versus 73.3 percent, p=0.067), significantly less patients had a proximal deep vein thrombosis defined as an isolated femoral or calf and femoral vein thrombosis (20 percent versus 73.3 percent, p <0.05) or a distal deep vein thrombosis defined as an isolated calf or calf and femoral vein thrombosis (26.67 percent versus 73.3 percent, p=0.028) in the regional versus general anesthesia group.

The remaining four trials that compared general with regional anesthesia allowed the use of mechanical or pharmacological prophylaxis for venous thromboembolism.20,24,30,197 The first trial by Williams-Russo and colleagues randomized 262 patients who had total knee replacement surgery to receive general versus epidural anesthesia.30 All patients received elastic stockings on postoperative day 1 as well as pharmacologic prophylaxis based on physician preference, which was aspirin 325mg twice daily in the majority of cases (71.8 percent). However, some patients received warfarin prophylaxis and the investigators reported outcomes only for those patients who received aspirin. There was no significant difference in the incidence of deep vein thrombosis in the general versus epidural anesthesia groups (48 percent versus 40 percent, p=0.300). All deep vein thromboses were distal in location. The second trial by Mitchell and colleagues randomized 72 patients who had total knee replacement surgery to receive general versus epidural anesthesia.24 Additionally, male patients received aspirin 650mg twice daily while female patients received low dose warfarin prophylaxis. Investigators reported there was no significant difference in gender between the two groups, with the majority of enrolled subjects being male (62.5 percent). There was no significant difference in the incidence of proximal deep vein thrombosis between the general and regional anesthesia groups (63 percent versus 46 percent, p=0.256). The third trial by Jorgensen and colleagues randomized 48 patients who had total knee replacement surgery to general anesthesia versus epidural anesthesia.20 All patients also wore graded compression stockings. Significantly fewer patients had a deep vein thrombosis in the epidural anesthesia group versus the general anesthesia group (17.6 percent versus 59.1 percent, p=0.02). When comparing general versus epidural anesthesia, there was no significant difference in symptomatic deep vein thrombosis (9.1 percent versus 0 percent, p=0.586), asymptomatic deep vein thrombosis (50 percent versus 17.6 percent , p=0.080), proximal deep vein thrombosis (13.6 percent versus 5.9 percent, p=0.795) or distal deep vein thrombosis (45.5 percent versus 11.8 percent, p=0.056). A fourth trial by Planes and colleagues randomized 194 patients who had total hip replacement surgery to receive general anesthesia plus enoxaparin 40mg 12 hours prior to surgery, spinal anesthesia plus enoxaparin 20mg one hour after the onset of anesthesia, or spinal anesthesia with no immediate use of enoxaparin.197 Patients in all three groups continued enoxparin 40mg 12 hours after surgery and then daily thereafter. This study was not found to be very useful to this review as the general anesthesia group received enoxaparin using a different regiment as one spinal anesthesia group and the other spinal anesthesia group received no enoxaparin at all. No patients had symptoms of a pulmonary embolism. There was no significant difference in the incidence of proximal deep vein thrombosis between the three groups, respectively (6.5 percent, 6.6 percent, 6 percent, p=0.993). However, there was a significant difference in the incidence of distal deep vein thrombosis when comparing the three groups, respectively (0 percent, 5 percent, 11 percent, p=0.007) and when comparing general anesthesia plus immediate enoxaparin versus epidural anesthesia without immediate enoxaparin (0 percent versus 11 percent, p=0.013). Major bleeding was not significantly different between the three groups, respectively (3.2 percent, 1.6 percent, 1.5 percent, p=0.764) and there were no episodes of minor bleeding.

Two nested observational studies evaluated the impact of general versus regional anesthesia on the incidence of deep vein thrombosis. The first study was nested in a randomized controlled trial comparing the direct thrombin inhibitor desirudin to the low molecular weight heparin enoxaparin in patients who underwent total hip replacement surgery.73 The influence of age, gender, type of anesthesia (general versus regional), type of prosthesis (cemented versus noncemented) and presence of obesity on the incidence of deep vein thrombosis were evaluated in a multivariate regression model. Authors report that general anesthesia versus regional anesthesia significantly influenced the risk of deep vein thrombosis although they did not report the magnitude or direction of the effect. The second study was nested in a randomized controlled trial which compared low-dose warfarin with intermittent pneumatic compression in patients who had total hip arthroplasty.56 Multivariate regression was used to evaluate the influence of age, gender, prophylactic regimen (warfarin versus intermittent pneumatic compression), perioperative blood loss, revision or primary surgery, height, weight, operative time, blood transfusions, type of anesthesia (general versus regional) and type of stem (cemented versus noncemented) on the incidence of deep vein thrombosis. The authors reported that the type of anesthesia did not significantly influence the incidence of deep vein thrombosis.

###### Cemented Arthroplasty

Three randomized controlled trials and three nested observational study evaluated aspects of cemented arthroplasty during total hip replacement surgery.21,22,26,68 The first trial evaluated 200 patients who had unilateral or bilateral primary total hip replacement surgery and were randomized to undergo cemented versus cementless arthroplasty.21 Patients who had bilateral surgery were randomized by knee, therefore outcomes were reported out of the number of knees operated on (n=300). No concurrent pharmacologic or mechanical prophylaxis was allowed. When comparing cemented versus cementless procedures, there was no significant difference in the rate of deep vein thrombosis (20.7 percent versus 27.3 percent, p=0.654), proximal deep vein thrombosis (12.7 percent versus 15.3 percent, p=0.618) or distal deep vein thrombosis (14.7 percent versus 20 percent, p=0.286). The second trial evaluated 250 patients who had unilateral total hip replacement and randomized to receive cemented versus noncemented Mallory head prosthesis.22 The majority of patients received prophylaxis with aspirin (46.4 to 58.9 percent) although some patients received warfarin (28.8 to 43.5 percent), both (8.2 to 10.1 percent), or neither (0.0 to 4.1 percent). When comparing cemented arthroplasty to cementless arthroplasty, there was no significant difference in the rate of pulmonary embolism (2.4 percent versus 0.8 percent, p=0.37), deep vein thrombosis (50.0 percent versus 47.1 percent, p=0.73), proximal deep vein thrombosis (3.0 percent versus 4.8 percent, p=0.67) or distal deep vein thrombosis (50.0 percent versus 46.4 percent, p=0.67).

The third trial evaluated 130 patients who had primary total hip replacement surgery and were randomized to undergo the surgical procedure with a bone vacuum cementing technique versus a standard cementing technique.26 All patients also received prophylaxis with the low molecular weight heparin nadroparin and bilateral thigh-high antithromboembolic stockings. There were no clinically suspected pulmonary emboli in the groups compared during the 45 day followup. There was a significantly lower rate of deep vein thrombosis in the group that received bone vacuum cementing versus standard cementing (3 percent versus 18 percent, p=0.009) as well as a significantly lower rate of proximal deep vein thrombosis (0 percent versus 11 percent, p=0.020). There was no difference in the rate of distal deep vein thrombosis between the intervention and control groups (3 percent versus 8 percent, p=0.437). This trial also evaluated major and minor bleeding. No major bleeding episodes occurred in the groups compared and the rate of minor bleeding was not significantly different between the intervention and control groups (8 percent versus 6 percent, p =1.00).

Three nested observational studies evaluated the impact of cemented prosthesis on the risk of deep vein thrombosis. The first study was nested in a randomized controlled trial comparing the direct thrombin inhibitor desirudin to unfractionated heparin in patients who had total hip replacement surgery.68 In the patients who received desirudin therapy, risk factors associated with the development of deep vein thrombosis were analyzed with multiple regression analysis and adjusted for peak partial thromboplastin time, age, gender, obesity, smoking habits and cemented surgery. Authors reported that cemented prosthesis had little to no influence on the risk of deep vein thrombosis although the magnitude or direction of effect was not reported. The second study was nested in a randomized controlled trial comparing the direct thrombin inhibitor desirudin to the low molecular weight heparin enoxaparin in patients who underwent total hip replacement surgery.73 The influence of age, gender, type of anesthesia (general versus regional), type of prosthesis (cemented versus noncemented) and presence of obesity on the incidence of deep vein thrombosis were evaluated in a multiple regression model. The authors reported that cemented versus noncemented prosthesis significantly influenced the risk of deep vein thrombosis (p < 0.02) although the magnitude and direction of the effect were not reported. The third study was nested in a randomized controlled trial which compared low-dose warfarin with intermittent pneumatic compression in patients who had total hip arthroplasty.56 Multiple regression was used to evaluate the influence of age, gender, prophylactic regimen (warfarin versus intermittent pneumatic compression), perioperative blood loss, revision or primary surgery, height, weight, operative time, blood transfusions, type of anesthesia (general versus regional) and type of stem (cemented versus noncemented) on the incidence of deep vein thrombosis. The authors reported that the type of stem did not influence the incidence of deep vein thrombosis.

###### Tourniquet Use

Three randomized controlled trials evaluated aspects of tourniquet use during total knee replacement surgery.28,31,33 The first trial evaluated 80 patients who had primary, cemented total knee replacement surgery and were randomized to have a pneumatic tourniquet placed around the thigh and inflated versus a pneumatic tourniquet placed around the thigh but not inflated.31 All patients received prophylaxis with dalteparin as well. Four symptomatic deep vein thromboses, all femoral in location, occurred 8 to 21 days postoperatively in the group whose tourniquet was inflated while none occurred in the control group (10 percent versus 0 percent, p= 0.116) although the difference was not significant. No distal deep vein thromboses occurred in the groups compared. In a second trial, 77 patients who also underwent cemented total knee replacement surgery were randomized to undergo surgery with an inflated tourniquet versus no tourniquet use.33 One asymptomatic deep vein thrombosis in the popliteal vein was diagnosed during the postoperative ultrasound on day 10 in a patient who had surgery with the use of a tourniquet while none occurred in the control group (2.7 percent versus 0 percent, p=0.481) and this finding was not significant. No distal deep vein thrombosis occurred in the groups compared.

The third trial evaluated 20 patients who had bilateral cemented total knee replacement surgery with the use of a tourniquet. Within a patient, each knee was randomized to be operated on with tourniquet release and hemostasis prior to wound closure versus tourniquet release after wound closure and pressure dressing.28 All patients also received low molecular weight heparin prophylaxis with nadroparin. No deep vein thromboses occurred in the groups compared.

###### Limb Positioning

Two randomized controlled trials evaluated variations of limb position during major orthopedic surgery.18,29 The first trial evaluated 118 patients who had primary, cemented total knee replacement and were randomized to two groups.29 The intervention group underwent the surgical procedure with a time limit for flexion and dislocation of the knee in order to minimize the total time the knee was in extreme flexion. The control group underwent the surgical procedure with the knee maintained in flexion and dislocation for the duration of the surgery. All patients received aspirin postoperatively for venous thromboembolism prophylaxis and the outcomes were reported out of the number of knees operated on. There was no significant difference in the rate of deep vein thrombosis between the intervention and control group (38 percent versus 42 percent, p=0.60) or in the rate of proximal deep vein thrombosis between the intervention and control groups (16 percent versus 12 percent, p=0.40).

The second trial evaluated 160 patients who had primary, cemented total hip replacement surgery and were randomized into two groups.18 The intervention group underwent the surgical procedure in a modified position to maintain femoral blood flow monitored with ultrasound whereas the control group underwent the surgical procedure without femoral blood flow monitoring in a full figure-of-four positioning of the leg. All patients received prophylaxis with the low molecular weight heparin nadroparin and customized anti-thrombosis stockings. No clinically suspected pulmonary emboli occurred in the groups compared. There was no significant difference in the rate of symptomatic deep vein thrombosis between the intervention and control groups (0 percent versus 4 percent, p > 0.05). All deep vein thrombosis occurred in patients who were in the control group, one of which was femoral, one in the lower leg, and one patient had involvement of the popliteal vein and lower leg.

###### Tissue Fibrin Adhesive

One randomized controlled trial evaluated 58 patients who had unilateral, cemented, total knee replacement surgery and randomized patients to receive treatment with tissue fibrin adhesive (Octacol F15) versus standard methods of hemostasis.23 All patients received enoxaparin 40mg subcutaneously every 12 hours prior to surgery and then every 12 hours after surgery. This trial did not report any bleeding outcomes of interest. No patients developed an ultrasound confirmed deep vein thrombosis and one patient in the control group suffered from a fatal pulmonary embolism while none occurred in the group that received tissue fibrin adhesive (3.5 percent versus 0 percent, p =1.00).

###### Primary or Revision Surgery, Perioperative Blood Loss, Operative Time, and Blood Transfusions

One nested observational study evaluated the impact of additional surgical characteristics on their impact on the incidence of deep vein thrombosis. This study was nested in a randomized controlled trial which compared low-dose warfarin with intermittent pneumatic compression in patients who had total hip arthroplasty.56 Multiple regression analysis was used to evaluate the influence of age, gender, prophylactic regimen (warfarin versus intermittent pneumatic compression), perioperative blood loss, revision or primary surgery, height, weight, operative time, blood transfusions, type of anesthesia (general versus regional) and type of stem (cemented versus noncemented) on the incidence of deep vein thrombosis. The authors reported that revision versus primary surgery significantly influenced the incidence of deep vein thrombosis although perioperative blood loss, operative time, and blood transfusions did not.

##### Patient Characteristics

###### Symptomatic Objectively Confirmed Venous Thromboembolism

Three controlled observational studies evaluated the impact of patient specific characteristics on the incidence of symptomatic objectively confirmed venous thromboembolism.136,138,140 The first study by Dorr and colleagues evaluated patients who had total hip or knee replacement surgery and compared patients who were considered high risk to those considered low risk to evaluate the incidence of thromboembolism.136 Low risk was defined as having none or at least one of the following: congestive heart failure, prior deep vein thrombosis more than 5 years ago, inactive malignant disease, current use of hormone replacement therapy, chronic tobacco use, blood disorders of the sickle-cell trait, polycythemia vera or thrombocytopenia. Within the low risk group, multivariate analysis of the risk factors for symptomatic objectively confirmed venous thromboembolism, adjusted for age was conducted. Congestive heart failure [adjusted odds ratio (AOR) 7.7, p=0.0001), inactive malignant disease (AOR 3.1, p=0.014), and hormone replacement therapy (AOR 3.2, p=0.008) increased the odds of symptomatic objectively confirmed venous thromboembolism. Authors reported that age was not a significant risk factor in the analysis and did not evaluate the high risk subgroup for risk factors for symptomatic objectively confirmed venous thromboembolism. The second study by McNamara and colleagues evaluated patients who had hip fracture surgery and compared patients with and without symptomatic objectively confirmed venous thromboembolism to assess for risk factors.140 Multivariate analysis adjusted for age, gender, residence on admission (own home versus institution), mean hemoglobin on admission and type of fracture (intracapsular, intertrochanteric, subtrochanteric) showed that patients who lived in their own home [AOR 2.24 (1.32 to 3.82), p=0.003], those who presented with intertrochanteric fractures [AOR 2.15 (1.46 to 3.17), p=0.001] or subtrochanteric fractures [AOR 1.51 (0.53 to 4.30), p=0.001], or those with elevated hemoglobin on admission [AOR 1.01 (1.0 to 1.03, p=0.01] had an increased odds of symptomatic objectively confirmed venous thromboembolism. Male gender [AOR 0.64 (0.38 to 1.07), p=0.09] and age [AOR 1.0 (0.98 to 1.02), p=0.9] did not significantly impact the risk of symptomatic objectively confirmed venous thromboembolism. The third study by Liezorovicz and colleagues evaluated Asian patients who had total hip or knee replacement surgery or hip fracture surgery and compared patients with or without the primary outcome to evaluate for risk factors.138 The primary outcome was symptomatic objectively confirmed venous thromboembolism or sudden death at hospital discharge. Upon multivariate analysis adjusted for age, personal or familial history of venous thromboembolism, history of cancer or active cancer, varicose veins and chronic heart failure, personal or familial history of venous thromboembolism [AOR 26.9 (2.9 to 250.1)], chronic heart failure [AOR 5.1 (1.5 to 17.8)] and varicose veins [AOR3.6 (1.2 to 10.6)] were significant independent risk factors for the primary outcome. At the 1 month followup, personal or familial history of venous thromboembolism [AOR 18.1 (2.0 to 167.0)] and chronic heart failure [AOR 6.3 (2.1 to 18.6)] remained significant predictors of the primary outcome.

###### Pulmonary Embolism

One nested case-controlled observational study evaluated the impact of patient specific characteristics on the incidence of pulmonary embolism.139 This study by Lemos and colleagues evaluated patients who received warfarin prophylaxis as part of a larger trial and underwent total knee or hip replacement surgery. Patients with pulmonary embolism were compared with gender and procedure-matched controls without pulmonary embolism to determine risk factors for pulmonary embolism. Upon multivariate analysis, factors that increased the risk of pulmonary embolism included advancing age (p=0.008) and genitourinary infection (p=0.017) while the presence of cardiovascular disease decreased the risk of pulmonary embolism (p=0.011). History of phlebitis, use of thyroid replacement medication, history of pulmonary embolism, varicosities, phlebitis in the opposite extremity, or peripheral vascular disease were not found to be significant factors.

###### Deep Vein Thrombosis

Four observational studies evaluated the impact of patient characteristics on the incidence of deep vein thrombosis.56,68,73,141 Three studies were nested within randomized controlled trials which compared different pharmacologic prophylaxis regimens.56,68,73 The first study was nested in a randomized controlled trial comparing the direct thrombin inhibitor desirudin to the low molecular weight heparin enoxaparin in patients who underwent total hip replacement surgery.73 The influence of age, gender, type of anesthesia (general versus regional), type of prosthesis (cemented versus noncemented) and presence of obesity on the incidence of deep vein thrombosis were evaluated in a logistic regression model. The patient characteristics significantly influenced the risk of deep vein thrombosis, including age (p < 0.001) and presence of obesity (p < 0.01). The second study was nested in a randomized controlled trial comparing the direct thrombin inhibitor desirudin to unfractionated heparin in patients who had total hip replacement surgery.68 In the patients who received desirudin therapy, risk factors associated with the development of deep vein thrombosis were analyzed with multiple regression analysis and adjusted for peak partial thromboplastin time, age, gender, obesity, smoking habits and cemented surgery. Patients over the age of 65 and females were at increased risk of deep vein thrombosis (p < 0.01 for each) and obesity was not a significant risk factor (p > 0.2). Authors also reported that smoking had little to no influence on the risk of deep vein thrombosis. The third study was nested in a randomized controlled trial which compared low-dose warfarin with intermittent pneumatic compression in patients who had total hip arthroplasty.56 Logistic regression was used to evaluate the influence of age, gender, prophylactic regimen (warfarin versus intermittent pneumatic compression), perioperative blood loss, revision or primary surgery, height, weight, operative time, blood transfusions, type of anesthesia (general versus regional) and type of stem (cemented versus noncemented) on the incidence of deep vein thrombosis. The authors reported that aside from the treatment regimen, none of the patient characteristics (age, gender, height, and weight) significantly influenced the incidence of deep vein thrombosis.

One controlled observational study evaluated the impact of the factor V Leiden mutation on the incidence of deep vein thrombosis.141 Logistic regression analysis adjusted for the presence of factor V Leiden mutation, surgical site, anticoagulant prophylaxis, and medical center. This study showed that factor V Leiden mutation did not significantly contribute to the risk of deep vein thrombosis.

###### Proximal Deep Vein Thrombosis

Two controlled observational studies evaluated the impact of patient specific characteristics on the incidence of proximal deep vein thrombosis.117,136 The first study by Dorr and colleagues evaluated patients who had total hip or knee replacement surgery and compared patients who were considered high risk with those considered low risk to evaluate the incidence of thromboembolism.136 Low risk was defined as having none or at least one of the following: congestive heart failure, prior deep vein thrombosis more than 5 years ago, inactive malignant disease, current use of hormone replacement therapy, chronic tobacco use, blood disorders of the sickle-cell trait, polycythemia vera, or thrombocytopenia. Within the low risk group, multivariate analysis of the risk factors for proximal deep vein thrombosis, adjusted for age and the listed risk factors was conducted. Only the presence of congestive heart failure (AOR 6.2, p=0.0005) increased the odds of proximal deep vein thrombosis. The second study was nested in a randomized controlled trial which compared intermittent pneumatic compression alone or in combination with aspirin or warfarin in patients who had total hip replacement surgery.117 Authors report that upon multiple regression analysis for the presence of proximal deep vein thrombosis adjusted for age, history of deep vein thrombosis, or revision surgery that age was a significant risk factor although the magnitude and direction of effect were not reported.

###### Symptomatic Deep Vein Thrombosis

One controlled observational study evaluated patients who had total knee replacement to determine if the presence of metabolic syndrome impacted the incidence of symptomatic deep vein thrombosis.137 Multivariate analysis adjusted for age, gender, education, body mass index, Charlson index, diabetes, hypertension, hypercholesterolemia, and metabolic syndrome showed that metabolic syndrome increased the odds of symptomatic deep vein thrombosis [AOR 3.0 (1.1 to 12.4)]. Age [AOR 0.9 (0.87 to 1.0)], gender [AOR 3.4 (0.4 to 18.5)], education [AOR 4.1 (0.8 to 20.6)], diabetes [AOR 3.1 (0.4 to 21.9)], hypertension [AOR 2.3 (0.6 to 32.2)], hypercholesterolemia [AOR 1.6 (0.2 to 33.5)], body mass index [AOR 1.1 (0.9 to 1.3)], and comorbidity [AOR 1.3 (0.9 to 2.2)] did not significantly impact the odds of proximal deep vein thrombosis.

###### Major Bleeding

One controlled observational study evaluated patients who had total knee or hip replacement or hip fracture surgery and whether age, gender, obesity, risk of bleeding, specific surgery, or type of prophylaxis administered affected the risk of major bleeding.150 All characteristics were suggested to significantly impact the risk of major bleeding except obesity, although the magnitude and direction of effect were not reported.

#### Strength of Evidence and Applicability of the Body of Evidence

Key Question 2 evaluated the impact of patient, surgical or postsurgical characteristics on outcomes of interest. Overall data were insufficient for all patient characteristics with the exception of two; congestive heart failure and age. There was moderate strength of evidence that congestive heart failure increased the odds of symptomatic objectively confirmed venous thromboembolism and there was low strength of evidence that age did not impact the odds of symptomatic objectively confirmed venous thromboembolism and increased the odds of deep vein thrombosis, in major orthopedic surgery. Similarly, data were insufficient for all surgical or postsurgical characteristics with the exception of two comparisons; general versus regional anesthesia and cemented versus noncemented arthroplasty. There was low strength of evidence that patients who had general anesthesia had a higher risk of deep vein thrombosis compared with regional anesthesia while there was no difference in the risk of proximal or distal deep vein thrombosis compared with regional anesthesia. There was also low strength of evidence that patients who had cemented arthroplasty had no difference in the risk of deep vein thrombosis or proximal deep vein thrombosis compared with noncemented arthroplasty.

In Key Question 2, surgical characteristics were rated with low applicability because the majority of trials were conducted outside of the United States, had shorter duration of followup to adequately evaluate the outcomes of interest, and often represented one of the three major orthopedic surgeries but not all. Additionally, for comparisons of general versus regional anesthesia, many trials used anesthetics that are not currently available on the U.S. market. Patient characteristics were rated low to moderate in applicability. Limitations included the country in which studies were conducted and representation of the three major orthopedic surgeries. Many patient characteristics are not applicable to hip fracture surgery as few studies included this surgical population.

## Key Question 3

In patients undergoing major orthopedic surgery (total hip replacement, total knee replacement or hip fracture surgery), in the absence of final health outcomes, can the risk for such outcomes reliably be estimated by measuring surrogate outcomes, such as deep vein thrombosis (asymptomatic or symptomatic, proximal or distal) as detected by venography or ultrasound?

### Key Points

- There were no reliable data concerning the relationship between final health outcomes other than pulmonary embolism and the occurrence of deep venous thrombosis in patients undergoing major orthopedic surgery.
- No trials or studies were available assessing whether deep venous thrombosis was correlated with or a multivariate predictor of pulmonary embolism in patients undergoing major orthopedic surgery.
- In the available studies, the routine use of prophylaxis reduced the occurrence rate of deep venous thrombosis and the scheduled anticoagulant treatment for deep venous thrombosis once it was detected may have diminished the number that developed into pulmonary embolism.
- In one observational study in total knee replacement surgery, the overall occurrence of pulmonary embolism and the subset with symptomatic pulmonary embolism occurred more frequently in those with deep venous thromboses. However the data were not adjusted for confounders and we could not discern whether these things are correlated or collinear.
- The available clinical trials provided insufficient data to determine the association between deep venous thrombosis and pulmonary embolism in major orthopedic surgery.

### Detailed Analysis

#### Study Design and Characteristics

Eight randomized controlled trials (N=2114) and two controlled observational studies (N=2299) evaluated the relationship between surrogate outcomes, such as deep vein thrombosis (asymptomatic or symptomatic, proximal or distal) and patient important outcomes in patients undergoing major orthopedic surgery.20,85,110,114,115,117,132,134,142,143 However, none of the trials and only one observational study was designed to evaluate the relationship between surrogate and patient important outcomes.142 All eight randomized controlled trials were published as full text manuscripts. The first trial compared injectable low molecular weight heparin with combination of injectable low molecular weight heparin and mechanical prophylaxis.114 The second trial compared injectable low molecular weight heparin agents with oral vitamin K antagonists.85 The third trial compared oral antiplatelet agents with a combination of oral antiplatelet agents and mechanical prophylaxis.115 The fourth trial reported comparisons between injectable unfractionated heparin, mechanical prophylaxis and combination of both these modalities.134 The fifth trial compared mechanical prophylaxis with a combination of mechanical and oral vitamin K antagonists.117 The sixth trial reported comparisons between oral vitamin K antagonists, oral antiplatelet agents and placebo.132 The seventh trial compared two intermittent pneumatic compression devices.110 The eight trial compared general with epidural anesthesia.20 Three trials enrolled patients who had total hip replacement surgery (N=502),115,117,134 three trials enrolled patients who had total knee replacement surgery (N=1141),20,85,110 one trial enrolled patients with either total hip replacement or total knee replacement surgery,114 and one trial enrolled patients who had hip fracture surgery (N=194).132 The earliest trial was published in 1989^132^ and the most recent trial was published in 2008.^114^ The duration of followup ranged from postoperative period to 180 days. Four trials received funding from the industry,20,85,110,114 one trial received funding from industry and government,132 two trials were unfunded115,117 and in one trial funding source was not reported.134

The mean age of enrolled patients ranged from 62.3 years to 76.6 year.117,132 Females represented between 50.0 and 81.0 percent of the enrolled populations.117,132 The mean weight ranged from 71.0 to 88.0 kilograms.114,117Few patients enrolled had a history of venous thromboembolism ranging from 0.0 to 14.0 percent.20,114,115,117 Two trials reported presence of varicosity ranging from 7.0 to 14.0 percent.20,117 One trial reported the percent of patients with a history of malignancy ranging from 15.6 to 18.6 percent.114

Sixty eight to 100 percent of patients underwent primary surgery.115,117,134 The percent of patients who had cemented fixation during surgery ranged from 0.0 to 89.2 percent.85,134 Mean duration of surgery ranged from 86.0 to 126.2 minutes85,115 and the mean duration of anesthesia was not reported. One trial directly compared general with epidural anesthesia.20 Otherwise, the use of general anesthesia was reported by three trials and ranged from 12.0 to 87.2 percent of patients.85,110,134 Four trials reported regional anesthesia use which ranged from 12.8 to 100 percent of patients.85,110,115,134 One trial reported combination of general and regional anesthesia ranging from 0.46 to 0.49 percent.110 The mean length of hospital stay was reported by two trials ranging from 3 to 10 days.114,117

Of the two controlled observational studies one study (N=1257), published in 1992, compared patients who had total knee arthroplasty with and without calf thrombi to compare the risk of pulmonary embolism.142 The second study (N=1042), published in 1997, evaluated patients who had total hip replacement surgery for the development of pulmonary embolism before and after discharge along with complications of low-dose warfarin use. One study did not report the funding source142 while the other study reported being unfunded.143

Baseline and procedural characteristics of the patients enrolled in these studies were scarcely reported. One study reported the average age of patients was 59 years, 61.87 percent of the surgeries were primary, 2.13 percent of patients had a history of venous thromboembolism and the average duration of hospitalization was 11 days.143 The other study did not report specific baseline or procedural characteristics.142

##### Outcome Evaluations

Given the paucity of data that were available to answer this Key Question and the fact that we did not statistically pool any trials or studies in this Key Question, we allowed outcomes (such as deep venous thromboses and pulmonary embolism) that were not as clearly defined or defined using tests that would not otherwise fit our methodology.

###### Total Knee Arthroplasty

The most compelling evaluation of the link between deep venous thrombosis and pulmonary embolism was an observational study of 1257 patients (having 1625 total knee arthroplasty surgeries) undergoing total knee arthroplasty surgery at one hospital in the United States between 1974 and 1986.^142^ Patients in this study had preoperative and postoperative perfusion lung scans and postoperative venograms per standard hospital practice. Those found to have calf thrombi (asymptomatic or symptomatic), asymptomatic proximal thrombi or asymptomatic lung scans were treated with warfarin to maintain prothrombin 1.3 to 1.6 times control. Patients diagnosed with large or symptomatic proximal thrombi or symptomatic pulmonary emboli were treated with intravenous heparin followed by warfarin fir six months. There were positive lung scans for pulmonary embolism (symptomatic and asymptomatic) in 6.9 percent of patients with calf thrombi versus 2.0 percent of patients without calf thrombi (p<0.001). Symptomatic pulmonary embolism occurred in 1.6 percent of patients with calf thrombi versus 0.2 percent of patients with negative venograms (p=0.034). When patients with proximal thrombi were compared against those with no thrombi, 4.8 percent versus 2.0 percent (p=NS) had pulmonary embolism and 1.9 percent versus 0.2 percent (p=NS) had symptomatic pulmonary embolism.

Four trials evaluated the occurrence of pulmonary embolism among patients with deep venous thrombosis after undergoing total knee arthroplasty. In the first trial, 417 patients undergoing total knee arthroplasty received either warfarin or enoxaparin prophylaxis.85 Venography was done on postoperative day 14 or earlier if the patient was to be discharged or had suspected deep venous thrombosis via ultrasonography or impedance plethysmography. Patients who were diagnosed with venous thromboembolism were treated with heparin followed by oral anticoagulants as per local practice. Overall, 185 patients developed a deep vein thrombosis of which 46 were proximal. Four patients developed pulmonary embolism with the three of the patients not having venography and one of these patients having a normal ultrasonography evaluation. The fourth patient had bilateral deep venous thromboses in both calves. In the second trial, 153 patients had total knee arthroplasty and received a low molecular weight heparin with or without a leg mechanical compression device.114 Patients received a duplex ultrasound of the legs before discharge and were followed up for 3 months for signs and symptoms of pulmonary embolism. Treatment of positive venous thromboembolic findings was not described. From this group, 19 had deep venous thrombosis (12.4 percent) of which one had developed a distal deep venous thrombosis detected by ultrasound at discharge and subsequently developed a pulmonary embolism 29 days later. Another patient with a negative ultrasound for deep venous thrombosis developed pulmonary embolism on postoperative day 2. In the third trial, 423 patients undergoing total knee arthroplasty received one of two pneumatic compression devices for prophylaxis.110 Ultrasonography of the calf and thigh was performed 3-5 days after the operation and when symptoms of deep venous thrombosis were detected. Spiral computed tomography was used to detect pulmonary embolism in symptomatic patients. Patients diagnosed with femoral or proximal popliteal thrombi were treated with either heparin or low molecular weight heparin followed by warfarin for three months. In this trial, 52 of 423 patients (12.3 percent) had deep venous thrombosis of which one patient (0.2 percent) developed pulmonary embolism. In this patient, the routine ultrasonography on the fourth postoperative day was negative for thrombi but a repeat test on day twelve was positive. No other pulmonary emboli occurred during the trial. In the fourth trial, 48 patients who had primary or revision knee arthroplasty were randomized to receive either general or epidural anesthesia. No pharmacologic prophylaxis was administered but all patients wore thigh-length compression stockings.20 All patients were screened on day 9-11 for deep vein thrombosis with bilateral ascending venography. Treatment of positive venous thromboembolic findings was not described. A total of 16 patients developed a deep vein thrombosis, 13 in the general anesthesia group and three in the epidural anesthesia group. One patient with deep vein thrombosis confined to the lower leg in the general anesthesia group developed a nonfatal pulmonary embolism (confirmed with ventilation-perfusion scan) on postoperative day five.

###### Total hip Arthroplasty

An observational study of 1042 patients (1244 hips) was conducted at a single medical center in the United States between 1987 and 1993.^143^ All patients received prophylaxis with low dose warfarin (goal prothrombin time between 14 and 17 seconds). Followup continued for three months in this study but they did not define the monitoring schedule to determine the occurrence of pulmonary embolism or deep venous thrombosis. It appears that the investigators only scanned for deep venous thrombosis of pulmonary embolism when the patients had symptomatic complaints. Those diagnosed with proximal thrombi were treated with intravenous heparin followed by warfarin for three months while patients with distal thrombi were treated with warfarin only. Five total hip arthroplasties were followed by the development of symptomatic deep venous thrombosis (0.5 percent of hips). Four were proximal deep venous thromboses and one was distal, as confirmed by venography or ultrasonography. Three of the five hips (60 percent) with deep venous thrombosis occurred in patients who concurrently or subsequently developed pulmonary embolism. Overall, 12 total hip arthroplasties, including the three described above, resulted in symptomatic pulmonary embolism and 10 of 12 were diagnosed with a ventilation perfusion scan.

Four trials evaluated the occurrence of pulmonary embolism among patients with deep venous thrombosis after total hip arthroplasty. In the first trial, 30 patients undergoing hip replacement surgery did not receive pharmacologic or mechanical prophylaxis but were randomized to receive general versus epidural anesthesia.34 Bilateral venography was conducted 14 days prior to and after surgery in all patients as was perfusion lung scanning and chest radiography. Treatment of positive venous thromboembolic findings was not described. A total of 16 patients (53.3 percent) developed a deep vein thrombosis, 11 in the general anesthesia group (36.7 percent) and five in the epidural anesthesia group (33.3 percent). Nine of the patients with a deep vein thrombosis (56.3 percent) were diagnosed with a pulmonary embolism [seven in the general anesthesia group (63.6 percent) and two in the epidural anesthesia group (40 percent)]. In the second trial 231 patients had total hip arthroplasty (a total of 250 hips) and received aspirin with or without a pneumatic compression boot.115 Patients received venography of the thigh or calf on the sixth, seventh, or eighth postoperative days. Patients diagnosed with a deep vein thrombosis were treated with warfarin for three months. One proximal thrombus (popliteal vein), 15 distal thrombi, and two pulmonary emboli occurred. The patients with pulmonary emboli had negative venograms before discharge but late pulmonary embolism approximately 3 weeks postoperatively. In the third trial, 75 patients undergoing total hip arthroplasty received heparin with aspirin, pneumatic pump compression, or both strategies.134 Duplex ultrasonography was conducted at baseline, 1 and 2 weeks after surgery with venograms confirming positive results. Patients diagnosed with a deep vein thrombosis were treated with heparin and warfarin. Five of the patients developed deep venous thrombosis, three patients were symptomatic, two were asymptomatic, and one developed pulmonary embolism. No pulmonary embolism was found aside for the patient with deep venous thrombosis. In the fourth trial, 212 patients (217 hips) undergoing total hip arthroplasty received pneumatic compression alone, with aspirin, or with warfarin.117 Venography, ultrasonography, or both were conducted just before the patient was about to be discharged (4 to 13 days postoperatively). Patients diagnosed with a proximal thrombus were treated heparin, warfarin or both and patients diagnosed with calf thrombi were treated with warfarin if they were symptomatic. Twenty-two of the 217 arthroplasties (10.1 percent) resulted in deep venous thrombosis. The only pulmonary embolism occurred in a patient who also had a deep venous thrombosis detected by ultrasonography of the thigh.

###### Hip Fracture Surgery

One trial evaluated the occurrence of pulmonary embolism among patients with deep venous thrombosis after hip fracture surgery. In one trial, 194 patients undergoing hip fracture surgery received warfarin, aspirin, or placebo.132 Patients had venography on day 21 or at the time of discharge. Venography was performed sooner if an iodine fibrinogen leg scan or impedance plethysmography was found to be positive. Patients diagnosed with a deep vein thrombosis were treated with intravenous heparin followed by oral anticoagulation therapy. Sixty nine patients developed deep venous thrombosis or pulmonary embolism. Of the three patients with pulmonary embolism, one patient developed a deep venous thrombosis on postoperative day 10, was not treated with heparin but discharged and died of autopsy reported pulmonary embolism on day 20. Another patient had a positive impedance plethysmography test and pulmonary embolism on day 14 but the venogram was said to be inadequate while the final patient had a pulmonary embolism on day seven with a calf vein thrombus found in the left leg on day 10.

#### Strength of Evidence and Applicability of the Body of Evidence

There was insufficient evidence to determine the relationship between deep vein thrombosis and pulmonary embolism. Key Question 3 had moderate applicability as most of the data were derived from trials and studies conducted in the United States and within the 1990's although two limitations were that the majority of data were in knee replacement surgery with little from hip fracture surgery and the duration of followup is generically stated as postoperative in the majority of trials.

## Key Question 4

In patients who had major orthopedic surgery (total hip or knee replacement, hip fracture surgery), what is the relative impact of thromboprophylaxis compared with no thromboprophylaxis on symptomatic objectively confirmed venous thromboembolism, major venous thromboembolism (proximal deep vein thrombosis, pulmonary embolism or venous thromboembolism-related mortality), pulmonary embolism, fatal pulmonary embolism, nonfatal pulmonary embolism, post thrombotic syndrome, mortality, mortality due to bleeding, deep vein thrombosis (asymptomatic or symptomatic, proximal or distal deep vein thrombosis), asymptomatic deep vein thrombosis, symptomatic deep vein thrombosis, proximal deep thrombosis, distal deep vein thrombosis, major bleeding, major bleeding leading to re-operation, minor bleeding, surgical site bleeding, bleeding leading to infection, bleeding leading to transfusion, heparin-induced thrombocytopenia, discomfort, re-admission, and re-operation? Thromboprophylaxis includes any pharmacologic agent within the defined classes (oral antiplatelet agents, injectable low molecular weight heparins, injectable unfractionated heparin, injectable or oral factor Xa inhibitors, injectable or oral direct thrombin inhibitors, oral vitamin K antagonists) or any external mechanical intervention within the defined classes (graduated compression, intermittent pneumatic compression, or venous foot pump)].

### Key Points

#### Pharmacologic Prophylaxis

- There is a high level of evidence that pharmacologic prophylaxis versus no prophylaxis significantly decreases the occurrence of proximal deep vein thrombosis [RR 0.53 (0.39 to 0.74)] and distal deep vein thrombosis [RR 0.59 (0.42 to 0.82)] while significantly increasing minor bleeding [RR 1.67 (1.18 to 2.38)].
  ○ The analyses of deep vein thrombosis have higher levels of heterogeneity; this is likely due in part, to the inclusion of trials evaluating multiple classes of pharmacologic therapy within the analysis and the inclusion of trials that were published prior to 2001 within the analysis.
- There is a moderate level of evidence that pharmacologic prophylaxis versus no prophylaxis significantly decreases the occurrence of deep vein thrombosis [RR 0.56 (0.47 to 0.68)] and asymptomatic deep vein thrombosis [RR 0.52 (0.40 to 0.69)].
- There is a low level of evidence that pharmacologic prophylaxis versus no prophylaxis significantly decreases major venous thromboembolism [RR 0.21 (0.05 to 0.95)].
- Pharmacologic prophylaxis did not significantly impact the occurrence of symptomatic objectively confirmed venous thromboembolism although this was based on a single randomized controlled trial.
- Pharmacologic prophylaxis did not significantly impact pulmonary embolism in the base case analysis but did significantly reduce the risk of pulmonary embolism in the trials not allowing any background prophylaxis in both groups.
- Pharmacologic prophylaxis versus no prophylaxis did not significantly impact nonfatal pulmonary embolism, mortality, symptomatic deep vein thrombosis or major bleeding in patients undergoing major orthopedic surgery.
- No clinical trials evaluated the impact of pharmacologic prophylaxis versus no prophylaxis on reoperation and readmission. A single observational study evaluated the impact of pharmacologic prophylaxis versus no prophylaxis on reoperation and readmission. Pharmacologic prophylaxis increased reoperation but did not impact readmission.
- Pharmacologic prophylaxis versus no prophylaxis did not significantly impact fatal pulmonary embolism, mortality due to bleeding, major bleeding leading to reoperation and bleeding leading to transfusion in patients undergoing major orthopedic surgery, however the impact is based on the results of a single trial for each endpoint because the rest of the trials evaluating these endpoints reported no events in the two comparative groups.
- No data are available to evaluate the comparative effect of pharmacologic prophylaxis versus no prophylaxis on post thrombotic syndrome, health related quality of life, surgical site bleeding, bleeding leading to infection, heparin induced thrombocytopenia and discomfort in patients undergoing major orthopedic surgery.

#### Mechanical Prophylaxis

- One randomized controlled trial showed that mechanical prophylaxis versus no prophylaxis significantly decreased deep vein thrombosis in patients undergoing major orthopedic surgery.
- Mechanical prophylaxis versus no prophylaxis does not significantly impact proximal deep vein thrombosis or distal deep vein thrombosis in patients undergoing major orthopedic surgery.
- No data are available to evaluate the comparative effect of mechanical prophylaxis versus no prophylaxis on symptomatic objectively confirmed venous thromboembolism, major venous thromboembolism, post thrombotic syndrome, mortality, mortality due to bleeding, health related quality of life, asymptomatic deep vein thrombosis, symptomatic deep vein thrombosis, major bleeding, major bleeding leading to reoperation, minor bleeding, surgical site bleeding, bleeding leading to infection, bleeding leading to transfusion, heparin induced thrombocytopenia, discomfort, reoperation and readmission in patients undergoing major orthopedic surgery.
- The comparative impact of mechanical prophylaxis versus no prophylaxis on pulmonary embolism, fatal pulmonary embolism and nonfatal pulmonary embolism could not be determined since no events occurred in the two comparative groups in the available trials.

### Detailed Analysis

#### Study Design and Characteristics

Twenty randomized controlled trials (N=2868) and three controlled observational studies (N=12866) evaluated the impact of combined pharmacologic and mechanical modalities versus no thromboprophylaxis on final health, intermediate and adverse outcomes.35-38,40-45,47,49-53,132,133,135,144,146,150 All 20 randomized controlled trials were published as full text manuscripts. One full text manuscript included two independent randomized controlled trials.38 Eighteen randomized controlled trials compared pharmacologic prophylaxis to no prophylaxis, 35,36,38,40-45,47,49,50,52,53,132,133,135 and of these 11 compared pharmacologic prophylaxis with a truly no prophylaxis.35,36,40,43,47,49-51,132,133 Two randomized controlled trials compared mechanical prophylaxis with no prophylaxis37,51 and of these one compared mechanical prophylaxis with truly no prophylaxis.51 To qualify as being “truly no prophylaxis” the trials had to compare pharmacologic or mechanical prophylaxis with placebo or no prophylaxis without the use of any concurrent prophylaxis in the groups compared; whereas in the broader category of studies comparing pharmacologic or mechanical prophylaxis versus placebo or no prophylaxis along with concurrent use of graduated compression stockings in the groups compared were also included. Fourteen trials exclusively enrolled patients who had total hip replacement surgery (N=2069),35,37,38,41,42,44,45,47,49,50,52,53,133,135 four trials enrolled patients who had total knee replacement surgery (N=537),36,38,43,51 and two trials enrolled patients who had hip fracture surgery (N=262).40,132 The earliest trial was published in 1980 while the most recent published in 2011.^43,135^ The duration of followup ranged from the postoperative period to 90 days. Four trials received funding from industry,38,53,133 two trials received funding from government and foundation,49,50 one trial received funding from industry and government,132 two trials received funding from government,35,52 one trial did not receive funding from any commercial party,37 and in nine trials the funding source was not reported.36,40-42,44,45,47,51,135

The mean age of enrolled patients ranged from 60.6 to years to 79 years. Females represented between 18.0 to 91.82 percent of the enrolled populations. The mean weight ranged from 54.2 to 74.0 kilograms with only one trial reporting obesity which ranged from 21.43 to 59.4 percent. Few patients enrolled had a history of venous thromboembolism, with the majority of trials reporting 0 to 10.0 percent. Presence of varicosity was ranged from no varicosity to 55.0 percent. The percent of patients with a history of malignancy ranged from 0.0 to 7.1 percent. None of the trials reported the percent of patients who had previously undergone orthopedic surgery.

Seventy-six to 100.0 percent of patients underwent primary surgery and the percent of patients who had cemented fixation during surgery ranged from 0.0 to 100.0. Mean duration of surgery ranged from 57.0 to 139.2 minutes and the mean duration of anesthesia was only reported by one trial with 104.5 minutes as the mean duration for the intervention group and 112.6 minutes as the mean duration for the control group. Use of general versus regional anesthesia varied, with general anesthesia use ranging from 7.69 to 100.0 percent of patients and regional anesthesia use ranging from 0.0 to 45.0 percent of patients. The mean length of hospital stay was infrequently reported, and when it was ranged from 7.9 to 16.0 days.

Three controlled observational studies (N=12866) evaluated the impact of pharmacologic prophylaxis versus no prophylaxis in patients who had major orthopedic surgery.144,146,150 All studies were published as full text manuscripts. Two studies compared patients who received warfarin versus no prophylaxis144,146 while one study also compared patients who received aspirin versus no prophylaxis.144 The third study compared multiple regimens although the only comparison which fit our inclusion criteria was between enoxaparin and no prophylaxis.150 One study reported the outcomes separately for total hip replacement (N=2203) and then for total knee replacement (N=2050).144 The second trial was limited to total knee replacement (N=1742).146 The third trial collectively reported total hip replacement, knee replacement and hip fracture surgery.150 The studies were published in 2010, 2009, and 2003‥ The duration of followup for one study was until discharge150 while the other two studies was 90 days.144,146. One trial was unfunded146 while the other two did not disclose the funding source.144,150

The mean age of patients ranged from 68 to 71 years. Other baseline characteristics were not reported in these studies. The majority of patients underwent primary surgery. One study reported the surgical approach. For patients who had total hip replacement, the posterior approach was used while for the patients who had total knee replacement the medial parapatellar approach was used.144 One study reported the mean hospital length of stay of 15.8 days.150 Other procedural characteristics as well as the mean hospital length of stay were not reported in these studies.

#### Outcome Evaluations

A summary of the results for Key Question 4 is presented in Table 10.

Table 10 Summary of results for Key Question 4: what is the comparative efficacy and safety of pharmacologic or mechanical prophylaxis versus no prophylaxis on outcomes in patients who had major orthopedic surgery^*^

| Endpoint/Comparison | Type and Number of Studies | Pooled | Result | Statistical Heterogeneity: I^2^ (%)
Symptomatic objectively confirmed VTE | Pharmacologic versus no prophylaxis | 1 RCT (2 comp) | No | No events in the groups compared in one comparison; the remaining comparison showed OR: 7.30 (0.14 to 368.00) | NA
Symptomatic objectively confirmed VTE | - 2001-present | 1 RCT (2 comp) | No | No events in the groups compared in one comparison; the remaining comparison showed OR: 7.30 (0.14 to 368.00) | NA
Symptomatic objectively confirmed VTE | - THR | 1 RCT (2 comp) | No | No events in the groups compared in one comparison; the remaining comparison showed OR: 7.30 (0.14 to 368.00) | NA
Symptomatic objectively confirmed VTE | Injectable low molecular weight heparin versus no prophylaxis | 1 RCT (1 comp) | No | No events in the groups compared | NA
Symptomatic objectively confirmed VTE | Injectable or oral factor Xa inhibitors versus no prophylaxis | 1 RCT (1 comp) | No | OR: 7.30 (0.14 to 368.00) | NA
Symptomatic objectively confirmed VTE | Mechanical versus no prophylaxis | 0 | --- | --- | ---
Major VTE | Pharmacologic versus no prophylaxis | 1 RCT (2 comp) | Yes | RR: 0.21 (0.05 to 0.95)^†^ | NA
Major VTE | - 2001-present | 1 RCT (2 comp) | Yes | RR: 0.21 (0.05 to 0.95)^†^ | NA
Major VTE | - TKR | 1 RCT (2 comp) | Yes | RR: 0.21 (0.05 to 0.95)^†^ | NA
Major VTE | Injectable or oral direct thrombin inhibitors versus no prophylaxis | 1 RCT (2 comp) | Yes | RR: 0.21 (0.05 to 0.95)^†^ | NA
Major VTE | Mechanical versus no prophylaxis | 0 | --- | --- | ---
PE | Pharmacologic versus no prophylaxis | 12 RCTs | Yes | 3 trials had no events; the remaining trials showed OR 0.38 (0.13 to 1.07) | 0
PE | - Comparing to truly no prophylaxis | 5 RCTs | Yes | RR 0.30 (0.09 to 0.99)^†^ | 0
PE | - 2001-present | 5 RCTs | Yes | 2 trials and one comparison from one trial had no events; the remaining trials showed OR 0.40 (0.04 to 3.68) | 73.8
PE | - THR | 8 RCTs | Yes | 2 trials and one comparison from one trial had no events; the remaining trials showed OR 0.48 (0.13 to 1.78) | 0
PE | - TKR | 3 RCTs | Yes | 1 trial had no events; the remaining trials showed OR 0.31 (0.03 to 3.23) | 0
PE | - HFS | 1 RCT (2 comp) | Yes | RR 0.30 (0.04 to 2.42) | NA
PE | Oral antiplatelet agents versus no prophylaxis | 2 RCTs | Yes | RR 0.35 (0.07 to 1.87) | 0
PE | Injectable low molecular weight heparin versus no prophylaxis | 7 RCTs + 1 comp | Yes | 1 trial and 2 comparisons from 2 trials had no events; the remaining trials showed OR 0.59 (0.17 to 2.08) | 0
PE | Injectable unfractionated heparin versus no prophylaxis | 1 RCT | No | RR 0.33 (0.03 to 3.84) | NA
PE | Injectable or oral factor Xa inhibitors versus no prophylaxis | 1 RCT (1 comp) | No | No events in the groups compared | NA
PE | Injectable or oral direct thrombin inhibitors versus no prophylaxis | 1 RCT (2 comp) | No | No events in groups compared | NA
PE | Oral vitamin K antagonists versus no prophylaxis | 1 RCT (1 comp) | No | OR 0.13 (0.01 to 2.09) | NA
PE | Mechanical versus no prophylaxis | 1 RCT | No | No events in the groups compared | NA
PE | Venous foot pumps versus no prophylaxis | 1 RCT | No | No events in the groups compared | NA
Fatal PE | Pharmacologic versus no prophylaxis | 6 RCTs 1 OBS | No | Five trials and 1 comparison from one trial had no events; the remaining comparison showed OR 7.06 (0.14 to 356.21). The observational study was inconclusive. | NA
Fatal PE | - Comparing to truly no prophylaxis | 2 RCTs | No | One trial and one comparison of one trial had no events; the remaining comparison showed OR 7.06 (0.14 to 356.21). | NA
Fatal PE | - 2001-present | 2 RCT 1 OBS | No | No events in the groups compared. The observational study was inconclusive. | NA
Fatal PE | - THR | 4 RCTs 1 OBS | No | No events in the groups compared. The observational study was inconclusive. | NA
Fatal PE | - TKR | 1 RCT 1 OBS | No | No events in the groups compared. The observational study was inconclusive. | NA
Fatal PE | - HFS | 1 RCT (2 comp) | No | One arm of the trial had no events; the remaining arm showed OR 7.06 (0.14 to 356.21). | NA
Fatal PE | Oral antiplatelet agents versus no prophylaxis | 1 RCT (1 comp) 1 OBS | No | OR 7.06 (0.14 to 356.21). The observational study was inconclusive. | NA
Fatal PE | Injectable low molecular weight heparin versus no prophylaxis | 3 RCTs + 1 comp | No | No events in the groups compared | NA
Fatal PE | Injectable or oral factor Xa inhibitors versus no prophylaxis | 1 RCT (1 comp) | No | No events in the groups compared | NA
Fatal PE | Injectable or oral direct thrombin inhibitors versus no prophylaxis | 1 RCT (2 comp) | No | No events in the groups compared | NA
Fatal PE | Oral vitamin K antagonists versus no prophylaxis | 1 RCT (1 comp) 1 OBS | No | No events in the groups compared. The observational study was inconclusive. | NA
Fatal PE | Mechanical prophylaxis versus no prophylaxis | 1 RCT | No | No events in the groups compared | NA
Fatal PE | Venous foot pumps versus no prophylaxis | 1 RCT | No | No events in the groups compared | NA
Nonfatal PE | Pharmacologic versus no prophylaxis | 6 RCTs 1 OBS | Yes (RCT) | Three trials had no event; the remaining trials showed OR 0.21 (0.04 to 1.30); Observational data suggest no significant difference | 0
Nonfatal PE | - Comparing to truly no prophylaxis | 2 RCTs | Yes | RR 0.21 (0.03 to 1.29) | 0
Nonfatal PE | - 2001-present | 2 RCT | No | No events in the groups compared | NA
Nonfatal PE | - THR | 4 RCTs | Yes | Two trials had no events ; the remaining trials showed OR 0.53 (0.05 to 5.09) | NA
Nonfatal PE | - TKR | 1 RCT | No | No events in the groups compared | NA
Nonfatal PE | - HFS | 1 RCT (2 comp) | Yes | RR 0.16 (0.02 to 1.53) | NA
Nonfatal PE | Oral antiplatelet agents versus no prophylaxis | 1 RCT (1 comp) | No | OR 0.13 (0.01 to 2.09) | NA
Nonfatal PE | Injectable low molecular weight heparin versus no prophylaxis | 3 RCTs + 1 comp | Yes | One trial and 1 comparison from one trial had no events; the remaining trials showed OR 0.53 (0.05 to 5.09) | NA
Nonfatal PE | Injectable or oral factor Xa inhibitors versus no prophylaxis | 1 RCT (1 comp) | No | No events in the groups compared | NA
Nonfatal PE | Injectable or oral direct thrombin inhibitors versus no prophylaxis | 1 RCT | No | No events in the groups compared | NA
Nonfatal PE | Oral vitamin K antagonists versus no prophylaxis | 1 RCT (1 comp) | No | OR 0.13 (0.01 to 2.09) | NA
Nonfatal PE | Mechanical prophylaxis versus no prophylaxis | 1 RCT | No | No events in the groups compared | NA
Nonfatal PE | Venous foot pumps versus no prophylaxis | 1 RCT | No | No events in the groups compared | NA
PTS | Pharmacologic versus no prophylaxis | 0 | --- | --- | ---
PTS | Mechanical versus no prophylaxis | 0 | --- | --- | ---
Mortality | Pharmacologic versus no prophylaxis | 10 RCTs 3 OBS | Yes (RCTs) | Four trials had no events; the remaining trials showed OR: 1.23 (0.54 to 2.78). Two observational studies suggested no difference while 1 study suggested decrease number of deaths with prophylaxis. | 0
Mortality | - Comparing to truly no prophylaxis | 5 RCTs | Yes | 1 trial had no events; the remaining trials showed OR: 1.26 (0.52 to 3.11) | 0
Mortality | - 2001-present | 2 RCT 3 OBS | No | No events in the groups compared. Two observational studies suggested no difference while 1 study suggested decrease number of deaths with prophylaxis. | NA
Mortality | - THR | 6 RCTs 1 OBS | Yes | Two trials had no events; the remaining showed OR: 1.02 (0.21 to 5.10). Observational study was inconclusive. | 0
Mortality | - TKR | 2 RCTs 2 OBS | No | No events in either arm. Observational studies showed no difference. | NA
Mortality | - HFS | 2 RCTs | Yes | RR: 1.27 (0.50 to 3.26) | 0
Mortality | Oral antiplatelet agents versus no prophylaxis | 2 RCTs 1 OBS | No | One trial had no events; the remaining trial showed OR: 1.62 (0.39 to 6.72). The observational study was inconclusive. | 0
Mortality | Injectable low molecular weight heparin versus no prophylaxis | 8 RCTs 1 OBS | Yes (RCT) | Three trials showed no events; the remaining showed OR: 0.98 (0.32 to 3.01); observational data suggested decreased deaths with prophylaxis | 0
Mortality | Injectable or oral factor Xa inhibitors versus no prophylaxis | 1 RCT (1 comp) 1 OBS | No | No events in the groups compared; observational data suggested decreased deaths with prophylaxis | NA
Mortality | Injectable or oral direct thrombin inhibitors versus no prophylaxis | 1 RCT | No | No events in the groups compared | NA
Mortality | Oral vitamin K antagonists versus no prophylaxis | 1 RCT (1 comp) 1 OBS | No | OR: 1.64 (0.39 to 6.84). The observational study showed no difference. | NA
Mortality | Mechanical versus no prophylaxis | 0 | --- | --- | ---
Mortality due to bleeding | Pharmacologic versus no prophylaxis | 9 RCTs 1 OBS | No | Eight trials had no events; the remaining trial showed OR 0.14 (0.003 to 6.82); Observational data are supportive | NA
Mortality due to bleeding | - Comparing to truly no prophylaxis | 5 RCTs | No | Four trials had no events; the remaining trial showed OR 0.14 (0.003 to 6.82) | NA
Mortality due to bleeding | - 2001-present | 2 RCTs 1 OBS | No | No events in the groups compared; Observational data suggested no difference | NA
Mortality due to bleeding | - THR | 5 RCTs | No | Four trials had no events; the remaining trial showed OR 0.14 (0.003 to 6.82) | NA
Mortality due to bleeding | - TKR | 2 RCTs | No | No events in the groups compared | NA
Mortality due to bleeding | - HFS | 2 RCTs | No | No events in the groups compared | NA
Mortality due to bleeding | Oral antiplatelet agents versus no prophylaxis | 2 RCTs | No | No events in the groups compared | NA
Mortality due to bleeding | Injectable low molecular weight heparin versus no prophylaxis | 6 RCTs 1 OBS | No | Five trials had no events; the remaining trial showed OR 0.14 (0.003 to 6.82); Observational data were supportive | NA
Mortality due to bleeding | Injectable or oral factor Xa inhibitors versus no prophylaxis | 1 RCT (1 comp) 1 OBS | No | No events in the groups compared; Observational data suggested no significant difference | NA
Mortality due to bleeding | Injectable or oral direct thrombin inhibitors versus no prophylaxis | 1 RCT | No | No events in the groups compared | NA
Mortality due to bleeding | Oral vitamin K antagonists versus no prophylaxis | 1 RCT | No | No events in the groups compared | NA
Mortality due to bleeding | Mechanical prophylaxis versus no prophylaxis | 0 | --- | --- | --
HRQOL | Pharmacologic versus no prophylaxis | 0 | --- | --- | ---
HRQOL | Mechanical versus no prophylaxis | 0 | --- | --- | ---
DVT | Pharmacologic versus no prophylaxis | 17 RCTs | Yes | RR: 0.56 (0.47 to 0.68)^†^ | 52.8
DVT | - Comparing to truly no prophylaxis | 9 RCTs | Yes | RR: 0.44 (0.27 to 0.72)^†^ | 69
DVT | - 2001-present | 5 RCTs | Yes | RR: 0.54 (0.45 to 0.64)^†^ | 10.4
DVT | - THR | 12 RCTs | Yes | RR: 0.59 (0.45 to 0.77)^†^ | 52.9
DVT | - TKR | 4 RCTs | Yes | RR: 0.54 (0.40 to 0.73)^†^ | 61.4
DVT | - HFS | 1 RCT | No | RR: 0.35 (0.15 to 0.78)^†^ | ---
DVT | - Age | 2 RCTs | No | Age did not impact the effect of pharmacologic versus no prophylaxis on the risk of deep vein thrombosis. | NA
DVT | - Gender | 2 RCTs | No | 1 RCT showed no impact of gender although the other RCT showed decreased risk of DVT in male patients when comparing pharmacologic versus no prophylaxis | NA
DVT | Oral antiplatelet agents versus no prophylaxis | 3 RCTs | Yes | RR: 0.41 (0.12 to 1.32) | 76
DVT | Injectable low molecular weight heparin versus no prophylaxis | 12 RCTs | Yes | RR: 0.54 (0.44 to 0.67)^†^ | 50.2
DVT | Injectable unfractionated heparin versus no prophylaxis | 1 RCT | No | RR: 1.60 (0.66 to 4.05) | NA
DVT | Injectable or oral factor Xa inhibitors versus no prophylaxis | 1 RCT (1 comp) | No | RR: 0.99 (0.35 to 2.80) | NA
DVT | Injectable or oral direct thrombin inhibitors versus no prophylaxis | 1 RCT (2 comp) | Yes | RR 0.51 (0.37 to 0.69)^†^ | NA
DVT | Mechanical prophylaxis versus no prophylaxis | 1 RCT | No | RR 0.26 (0.10 to 0.65)^†^ | NA
DVT | Venous foot pumps versus no prophylaxis | 1 RCT | No | RR 0.26 (0.10 to 0.65)^†^ | NA
Asymptomatic DVT | Pharmacologic versus no prophylaxis | 3 RCTs | Yes | RR 0.52 (0.40 to 0.69)^†^ | 32.7
Asymptomatic DVT | - 2001-present | 1 RCT ( 2 comp) | Yes | RR 0.50 (0.37 to 0.67)^†^ | NA
Asymptomatic DVT | - THR | 2 RCTs | Yes | RR 0.52 (0.27 to 1.00) | NA
Asymptomatic DVT | - TKR | 1 RCT (2 comp) | Yes | RR 0.50 (0.37 to 0.67)^†^ | NA
Asymptomatic DVT | Injectable low molecular weight heparin versus no prophylaxis | 2 RCTs | Yes | RR 0.52 (0.27 to 1.00) | NA
Asymptomatic DVT | Injectable or oral direct thrombin inhibitors versus no prophylaxis | 1 RCT (2 comp) | Yes | RR 0.50 (0.37 to 0.67)^†^ | NA
Asymptomatic DVT | Mechanical prophylaxis versus no prophylaxis | 0 | --- | --- | ---
Symptomatic DVT | Pharmacologic versus no prophylaxis | 4 RCTs 1 OBS | Yes (RCT) | One trial and 1 comparison from one trial had no events; the remaining trials showed OR 1.07 (0.25 to 4.52); observational data suggest no significant difference | 0
Symptomatic DVT | - 2001-present | 2 RCTs | Yes | 1 comparison from one trial had no events; the remaining trials showed RR 1.02 (0.21 to 4.89) | 0
Symptomatic DVT | - THR | 3 RCTs | Yes | One trial and 1 comparison from one trial had no events; the remaining trials showed OR 1.90 (0.20 to 18.32) | NA
Symptomatic DVT | - TKR | 1 RCT (2 comp) | Yes | RR 0.72 (0.12 to 4.39) | NA
Symptomatic DVT | Injectable low molecular weight heparin versus no prophylaxis | 3 RCTs | No | Two trials had no events; the remaining trial showed OR 0.96 (0.06 to 15.52) | NA
Symptomatic DVT | Injectable or oral factor Xa inhibitors versus no prophylaxis | 1 RCT (1 comp) | No | OR: 7.30 (0.14 to 368.00) | NA
Symptomatic DVT | Injectable or oral direct thrombin inhibitors versus no prophylaxis | 1 RCT (2 comp) | Yes | RR 0.72 (0.12 to 4.39) | NA
Symptomatic DVT | Mechanical prophylaxis versus no prophylaxis | 0 | --- | --- | ---
Proximal DVT | Pharmacologic versus no prophylaxis | 12 RCTs | Yes | RR 0.53 (0.39 to 0.74)^†^ | 9.7
Proximal DVT | - Comparing to truly no prophylaxis | 5 RCTs | Yes | RR 0.46 (0.27 to 0.79)^†^ | 0
Proximal DVT | - 2001-present | 5 RCTs | Yes | RR 0.42 (0.22 to 0.79)^†^ | 0
Proximal DVT | - THR | 8 RCTs | Yes | One comparison from one trial had no events; the remaining trials showed RR 0.56 (0.38 to 0.81)^†^ | 20.9
Proximal DVT | - TKR | 4 RCTs | Yes | RR 0.43 (0.21 to 0.88)^†^ | 0
Proximal DVT | Oral antiplatelet agents versus no prophylaxis | 1 RCT | No | RR 0.80 (0.25 to 2.31) | NA
Proximal DVT | Injectable low molecular weight heparin versus no prophylaxis | 9 RCTs | Yes | 1 comparison from one trial had no events; the remaining trials showed RR 0.53 (0.38 to 0.75)^†^ | 14.3
Proximal DVT | Injectable or oral factor Xa inhibitors versus no prophylaxis | 1 RCT (1 comp) | No | OR 7.30 (0.14 to 368.00) | NA
Proximal DVT | Injectable or oral direct thrombin inhibitors versus no prophylaxis | 1 RCT (2 comp) | Yes | RR 0.21 (0.05 to 0.95)^†^ | NA
Proximal DVT | Mechanical prophylaxis versus no prophylaxis | 1 RCT | No | RR 0.41 (0.10 to 1.72) | NA
Proximal DVT | Venous foot pumps versus no prophylaxis | 1 RCT | No | RR 0.41 (0.10 to 1.72) | NA
Distal DVT | Pharmacologic versus no prophylaxis | 7 RCTs | Yes | RR 0.59 (0.42 to 0.82)^†^ | 0
Distal DVT | - Comparing to truly no prophylaxis | 3 RCTs | Yes | RR 0.57 (0.22 to 1.46) | 66.8
Distal DVT | - 2001-present | 2 RCT | Yes | RR 0.52 (0.20 to 1.38) | 48.9
Distal DVT | - THR | 5 RCTs | Yes | RR 0.62 (0.42 to 0.90)^†^ | 0
Distal DVT | - TKR | 2 RCTs | Yes | RR 0.55 (0.10 to 3.19) | NA
Distal DVT | Oral antiplatelet agents versus no prophylaxis | 1 RCT | No | RR 1.33 (0.45 to 3.84) | NA
Distal DVT | Injectable low molecular weight heparin versus no prophylaxis | 6 RCTs | Yes | RR 0.52 (0.37 to 0.75)^†^ | 0
Distal DVT | Injectable or oral factor Xa inhibitors versus no prophylaxis | 1 RCT (1 comp) | No | RR 0.99 (0.35 to 2.80) | NA
Distal DVT | Mechanical prophylaxis versus no prophylaxis | 1 RCT | No | RR 0.68 (0.14 to 3.26) | NA
Distal DVT | Venous foot pumps versus no prophylaxis | 1 RCT | No | RR 0.68 (0.14 to 3.26) | NA
Major bleeding | Pharmacologic versus no prophylaxis | 8 RCTs 1 OBS | Yes (RCT) | Two trials had no events; the remaining trials showed RR 0.74 (0.36 to 1.51): Observational data were supportive | 0
Major bleeding | - Comparing to truly no prophylaxis | 4 RCTs | Yes | 1 trial had no events; the remaining trials showed OR 0.53 (0.17 to 1.64) | 0
Major bleeding | - 2001-present | 4 RCTs 1 OBS | Yes (RCT) | One trial had no events; the remaining trials showed RR 0.87 (0.31 to 2.45); Observational data were supportive | 0
Major bleeding | - THR | 5 RCTs | Yes | 2 trials had no events; the remaining trials showed OR 1.61 (0.44 to 5.83) | 0
Major bleeding | - TKR | 2 RCTs | Yes | RR 0.59 (0.18 to 1.95) | 0
Major bleeding | - HFS | 1 RCT (2 comp) | Yes | RR 0.55 (0.12 to 2.51) | 0
Major bleeding | Oral antiplatelet agents versus no prophylaxis | 2 RCTs | No | One trial had no events; the remaining trial showed OR 0.24 (0.05 to 1.22) | NA
Major bleeding | Injectable low molecular weight heparin versus no prophylaxis | 5 RCTs 1 OBS | Yes | One trial had no events; the remaining trials showed RR 0.78 (0.29 to 2.08); Observational data were supportive | 0
Major bleeding | Injectable or oral direct thrombin inhibitors versus no prophylaxis | 1 RCT (2 comp) | Yes | RR 0.96 (0.09 to 10.73) | NA
Major bleeding | Injectable or oral factor Xa inhibitors versus no prophylaxis | 1 RCT (1 comp) 1 OBS | No | No events occurred in the groups compared; Observational data suggested no significant difference | NA
Major bleeding | Oral vitamin K antagonists versus no prophylaxis | 1 RCT | No | RR 0.97 (0.29 to 3.19) | NA
Major bleeding | Mechanical prophylaxis versus no prophylaxis | 0 | --- | --- | ---
Major bleeding leading to reoperation | Pharmacologic versus no prophylaxis | 2 RCTs | No | One trial and one comparison of one trial had no events; the remaining comparison of the second trial showed OR 7.11 (0.14 to 358.50) | NA
Major bleeding leading to reoperation | - 2001-present | 1 RCT (2 comp) | No | One comparison of the trial had no events; the remaining comparison showed OR 7.11 (0.14 to 358.50) | NA
Major bleeding leading to reoperation | - THR | 1 RCT | No | No events in the groups compared | NA
Major bleeding leading to reoperation | - TKR | 1 RCT (2 comp) | No | One arm of the trial had no events; the remaining arm showed OR 7.11 (0.14 to 358.50) | NA
Major bleeding leading to reoperation | Injectable low molecular weight heparin versus no prophylaxis | 1 RCT | No | No events in the groups compared | NA
Major bleeding leading to reoperation | Injectable or oral direct thrombin inhibitors versus no prophylaxis | 1 RCT (2 comp) | No | One arm of the trial had no events; the remaining arm showed OR 7.11 (0.14 to 358.50) | NA
Major bleeding leading to reoperation | Mechanical prophylaxis versus no prophylaxis | 0 | --- | --- | ---
Minor bleeding | Pharmacologic prophylaxis versus no prophylaxis | 6 RCTs | Yes | RR 1.67 (1.18 to 2.38)^†^ | 0
Minor bleeding | - Comparing to truly no prophylaxis | 1 RCT | No | OR 7.39 (0.15 to 372.38) | NA
Minor bleeding | - 2001-present | 4 RCTs | Yes | RR 2.04 (1.16 to 3.62)^†^ | 0
Minor bleeding | - THR | 4 RCTs | Yes | RR 1.65 (1.09 to 2.48)^†^ | 0
Minor bleeding | - TKR | 2 RCTs | Yes | RR 1.77 (0.89 to 3.49) | 0
Minor bleeding | Injectable low molecular weight heparin versus no prophylaxis | 5 RCTs | Yes | RR 1.66 (1.13 to 2.44)^†^ | 0
Minor bleeding | Injectable or oral factor Xa inhibitors versus no prophylaxis | 1 RCT (1 comp) | No | OR 3.21 (0.84 to 12.24) | NA
Minor bleeding | Injectable or oral direct thrombin inhibitors versus no prophylaxis | 1 RCT (2 comp) | Yes | OR 1.67 (0.73 to 3.84) | NA
Minor bleeding | Mechanical prophylaxis versus no prophylaxis | 0 | --- | --- | ---
Surgical site bleeding | Pharmacologic versus no prophylaxis | 0 | --- | --- | ---
Surgical site bleeding | Mechanical versus no prophylaxis | 0 | --- | --- | ---
Bleeding leading to infection | Pharmacologic versus no prophylaxis | 0 | --- | --- | ---
Bleeding leading to infection | Mechanical versus no prophylaxis | 0 | --- | --- | ---
Bleeding leading to transfusion | Pharmacologic versus no prophylaxis | 1 RCT (2 comp) 1 OBS | No | One arm of the trial had no events; the remaining arm showed OR 7.11 (0.14 to 358.50). The observational study was inconclusive. | NA
Bleeding leading to transfusion | - 2001-present | 1 RCT (2 comp) 1 OBS | No | One arm of the trial had no events; the remaining arm showed OR 7.11 (0.14 to 358.50). The observational study was inconclusive. | NA
Bleeding leading to transfusion | - TKR | 1 RCT (2 comp) 1 OBS | No | One arm of the trial had no events; the remaining arm showed OR 7.11 (0.14 to 358.50). The observational study was inconclusive. | NA
Bleeding leading to transfusion | Injectable or oral direct thrombin inhibitors versus no prophylaxis | 1 RCT (2 comp) | No | One comparison of the trial had no events; the remaining comparison showed OR 7.11 (0.14 to 358.50). | NA
Bleeding leading to transfusion | Oral vitamin K antagonists versus no prophylaxis | 1 OBS | No | The study was inconclusive | NA
Bleeding leading to transfusion | Mechanical prophylaxis versus no prophylaxis | 0 | --- | --- | ---
HIT | Pharmacologic versus no prophylaxis | 0 | --- | --- | ---
HIT | Mechanical versus no prophylaxis | 0 | --- | --- | ---
Discomfort | Pharmacologic versus no prophylaxis | 0 | --- | --- | ---
Discomfort | Mechanical versus no prophylaxis | 0 | --- | --- | ---
Readmission | Pharmacologic versus no prophylaxis | 1 OBS | No | No difference in the risk of readmission. | NA
Readmission | Oral vitamin K antagonists versus no prophylaxis | 1 OBS | No | No difference in the risk of readmission. | NA
Readmission | Mechanical versus no prophylaxis | 0 | --- | --- | ---
Reoperation | Pharmacologic versus no prophylaxis | 1 OBS | No | Significant increase in risk of reoperation in patients who received pharmacologic prophylaxis versus no prophylaxis. | NA
Reoperation | Oral vitamin K antagonists versus no prophylaxis | 1 OBS | No | Significant increase in risk of reoperation in patients who received pharmacologic prophylaxis versus no prophylaxis. | NA
Reoperation | Mechanical versus no prophylaxis | 0 | --- | --- | ---

comp = comparison(s); DVT = deep vein thrombosis; HIT = heparin induced thrombocytopenia; HRQOL = health related quality of life; NA = Not Applicable; OBS = observational; OR = Peto's Odds Ratio; PE = pulmonary embolism; RCT = Randomized Controlled Trial; RR = Relative Risk; VTE = venous thromboembolism

* All base case analyses are represented in this table. For subgroup analyses or class comparisons only analyses with trials or studies are represented.

† Statistically significant.

--- No data.

##### Symptomatic Objectively Confirmed Venous Thromboembolism

###### Pharmacologic Prophylaxis Versus no Prophylaxis

One randomized controlled trial by Yokote and colleagues in 2011 evaluated the impact of pharmacologic prophylaxis versus no prophylaxis on symptomatic objectively confirmed venous thromboembolism in patients who had major orthopedic surgery.135 This trial evaluated patients who had total hip replacement and included two separate comparisons: low molecular weight heparin (enoxaparin) versus placebo and injectable factor Xa inhibitor (fondaparinux) versus placebo. The use of concurrent elastic stockings and compression devices was allowed therefore this trial was not considered a trial comparing pharmacologic prophylaxis versus truly no prophylaxis. No patients in the enoxaparin or placebo groups had an event therefore the risk of symptomatic thromboembolism could not be calculated for this comparison. In patients who received fondaparinux versus placebo, the odds of symptomatic venous thromboembolism were not significantly different [OR 7.30 (0.14 to 368.00)]. Subgroup analyses were not possible because only one comparison was available. No randomized controlled trials evaluated the impact of prophylaxis with oral antiplatelet agents, unfractionated heparin, or vitamin K antagonists versus no prophylaxis in patients who had major orthopedic surgery on this outcome.

###### Mechanical Prophylaxis Versus no Prophylaxis

No randomized controlled trials or controlled observational studies evaluated the impact of mechanical prophylaxis versus no prophylaxis in patients who had major orthopedic surgery on this outcome.

##### Major Venous Thromboembolism

###### Pharmacologic Prophylaxis Versus no Prophylaxis

One randomized controlled trial by Fuji and colleagues in 2010 evaluated the impact of pharmacologic prophylaxis versus no prophylaxis on major venous thromboembolism in patients who had major orthopedic surgery.53 This trial evaluated patients who had total knee replacement and included two separate comparisons of an oral direct thrombin inhibitor; dabigatran 150mg (mg) daily and dabigatran 220mg daily versus placebo. The use of concurrent elastic stockings was allowed therefore this trial was not considered a trial comparing pharmacologic prophylaxis versus truly no prophylaxis. In patients who received pharmacologic prophylaxis versus no prophylaxis, the risk of major venous thromboembolism was significantly decreased [relative risk (RR) 0.21 (0.05 to 0.95), number needed to treat (NNT) 19 to 22] (Appendix G Figure 1). Statistical heterogeneity and publication bias could not be calculated because there were too few comparisons.

Subgroup analyses were not possible because only one trial was available. No randomized controlled trials evaluated the impact of prophylaxis with oral antiplatelet agents, injectable low molecular weight heparins, unfractionated heparin, injectable or oral factor Xa inhibitors, or vitamin K antagonists versus no prophylaxis in patients who had major orthopedic surgery on this outcome.

###### Mechanical Prophylaxis Versus no Prophylaxis

No randomized controlled trials or controlled observational studies evaluated the impact of mechanical prophylaxis versus no prophylaxis on this outcome.

##### Pulmonary Embolism

###### Pharmacologic Prophylaxis Versus no Prophylaxis

Twelve randomized controlled trials evaluated the impact of pharmacologic prophylaxis versus no prophylaxis on pulmonary embolism in patients who had major orthopedic surgery.35,36,38,42,44,49,50,52,53,132,135 The three trials by Fuji and colleagues each included two separate comparisons, as did the trials by Powers, Alfaro, and Yokote and colleagues.35,38,53,132,135 The trials by Fuji and colleagues in 2010, Samama and colleagues and Yokote and colleagues were excluded from the analysis because no events occurred in either group, as was one comparison from one of the trials by Fuji and colleagues in 2008. In patients who received pharmacologic prophylaxis versus no prophylaxis the odds of pulmonary embolism were not significantly different [OR 0.38 (0.13 to 1.07)] (Appendix G Figure 2). Statistical heterogeneity and publication bias were not detected (I^2^=0 percent, Egger's p-value=0.063).

When limiting the original analysis to trials that compared pharmacologic prophylaxis with truly no prophylaxis, five trials remained with the trials by Alfaro and Powers and colleagues each including two separate comparisons.35,36,49,50,132 In patients who received pharmacologic prophylaxis versus truly no prophylaxis the risk of pulmonary embolism was significantly decreased [RR 0.30 (0.09 to 0.99), NNT 20] (Appendix G Figure 3). Statistical heterogeneity was not detected (I^2^=0 percent). When limiting the original analysis to trials published from 2001 to present; five trials remained, with the three trials by Fuji and colleagues and the trial by Yokote and colleagues each including two separate comparisons.36,38,53,135 One trial by Fuji and colleagues, one comparison from a second trial by Fuji and colleagues, and the trial by Yokote and colleagues were excluded from the analysis because no events occurred in the groups compared.38,53,135 In patients who received pharmacologic prophylaxis versus no prophylaxis, the odds of pulmonary embolism were not significantly different [OR 0.40 (0.04 to 3.68)] (Appendix G Figure 4). A higher level of statistical heterogeneity was detected (I^2^=73.8 percent). When limiting the original analysis to total hip replacement surgery, eight trials remained, with the trials by Fuji, Alfaro, and Yokote and colleagues each including two separate comparisons.35,38,42,44,49,50,52,135 The trials by Samama and Yokote and colleagues and one comparison from the trial by Fuji and colleagues were excluded from the analysis because no events occurred in either groups compared.38,44,135 In patients who received pharmacologic prophylaxis versus no prophylaxis, the odds of pulmonary embolism were not significantly different [OR 0.48 (0.13 to 1.78)] (Appendix G Figure 5). Statistical heterogeneity was not detected (I^2^=0 percent). When limiting the original analysis to total knee replacement surgery, three trials remained, with the two trials by Fuji and colleagues each including two separate comparisons.36,38,53 One trial by Fuji and colleagues was excluded form the analysis because no events occurred in either group compared.53 In patients who received pharmacologic prophylaxis versus no prophylaxis the odds of pulmonary embolism were not significantly different [OR 0.31 (0.03 to 3.23)] (Appendix G Figure 6). No statistical heterogeneity was detected (I^2^=0 percent). When limiting the original analysis to hip fracture surgery, one trial by Powers and colleagues remained, with two separate comparisons.132 In patients who received pharmacologic prophylaxis versus no prophylaxis, the risk of pulmonary embolism was not significantly different [RR 0.30 (0.04 to 2.42)] (Appendix G Figure 7). Statistical heterogeneity could not be calculated because of too few studies.

Subgroup analyses based on age, gender and ethnicity were not possible because no randomized controlled trials reported data based on these subgroups.

###### Oral Antiplatelet Agents Versus no Prophylaxis

Two randomized controlled trials evaluated the impact of oral antiplatelet agents versus no prophylaxis on pulmonary embolism in patients who had major orthopedic surgery with the trial by Alfaro and colleagues including two separate comparisons.35,132 In patients who received oral antiplatelet agents versus no prophylaxis the risk of pulmonary embolism was not significantly different [RR 0.35 (0.07 to 1.87)] (Appendix G Figure 8). Statistical heterogeneity was not detected (I^2^=0 percent) and Egger's p-value could not be calculated due to the few number of studies.

###### Injectable low Molecular Weight Heparins Versus no Prophylaxis

Seven randomized controlled trials and one comparison from the trial by Yokote and colleagues evaluated the impact of injectable low molecular weight heparins versus no prophylaxis on pulmonary embolism in patients who had major orthopedic surgery with the two trials by Fuji and colleagues each contributing two separate comparisons.36,38,42,44,49,135 One trial by Samama and colleagues, the comparison from Yokote and colleagues, and one comparison from a trial by Fuji and colleagues were excluded from this analysis because no events occurred in either group compared.38,44,135 In patients who received injectable low molecular weight heparin versus no prophylaxis the odds of pulmonary embolism were not significantly different [OR 0.59 (0.17 to 2.08)] (Appendix G Figure 9). Statistical heterogeneity and publication bias were not detected (I^2^=0 percent, Egger's p-value=0.511).

###### Injectable Unfractionated Heparins Versus no Prophylaxis

One randomized controlled trial evaluated the impact of injectable unfractionated heparin versus no prophylaxis on pulmonary embolism in patients who had major orthopedic surgery.50 In this trial, patients who had total hip replacement surgery received either unfractionated heparin or no prophylaxis and the risk of pulmonary embolism was not significantly different [RR 0.33 (0.03 to 3.84)].

###### Injectable or Oral Factor Xa Inhibitors Versus no Prophylaxis

One comparison from the randomized controlled trial by Yokote and colleagues in 2011 evaluated the impact of injectable or oral factor Xa inhibitors versus no prophylaxis on pulmonary embolism although the risk could not be calculated because no events occurred.135

###### Injectable or Oral Direct Thrombin Inhibitors Versus no Prophylaxis

One randomized controlled trial evaluated the impact of oral direct thrombin inhibitors versus no prophylaxis on pulmonary embolism in patients who had major orthopedic surgery.53 This trial evaluated patients who had total knee replacement and included two separate comparisons; dabigatran 150mg daily and dabigatran 220mg daily each versus placebo. The risk of pulmonary embolism could not be calculated because no events occurred in the groups compared.

###### Oral Vitamin K Antagonists Versus no Prophylaxis

One comparison from the trial by Powers and colleagues evaluated the impact of vitamin K antagonists versus no prophylaxis in patients who had major orthopedic surgery.132 This trial evaluated patients who had hip fracture surgery and compared warfarin with no prophylaxis. In patients who received warfarin versus no prophylaxis the odds of pulmonary embolism were not significantly different [OR 0.13 (0.01 to 2.09)].

###### Mechanical Prophylaxis Versus no Prophylaxis

One randomized controlled trial evaluated the impact of mechanical prophylaxis versus no prophylaxis on pulmonary embolism in patients who had major orthopedic surgery.51 In this trial, a venous foot pump was compared with no prophylaxis in patients who had total knee replacement surgery. The risk of pulmonary embolism could not be calculated because no events occurred in either group compared.

Subgroup analyses were not possible because only one trial was available. No randomized controlled trials evaluated the impact of either graduated compression stockings or intermittent pneumatic compression devices versus no prophylaxis in patients who had major orthopedic surgery on this outcome.

##### Fatal Pulmonary Embolism

###### Pharmacologic Prophylaxis Versus no Prophylaxis

Six trials evaluated the impact of pharmacologic prophylaxis versus no prophylaxis on fatal pulmonary embolism in patients who had major orthopedic surgery with the trials by Yokote, Fuji, and Powers each including two separate comparisons.42,44,49,53,132,135 Five trials were excluded from the analysis because no events occurred in the groups compared, leaving one comparison from the trial by Powers and colleagues.132 In this comparison, in patients who received pharmacologic prophylaxis versus no prophylaxis the odds of fatal pulmonary embolism were not significantly different [OR 7.06 (0.14 to 356.21)].

When limiting the original analysis to trials comparing pharmacologic prophylaxis to truly no prophylaxis, two trials remained with the trial by Powers and colleagues including two separate comparisons.49,132 One trial and one comparison from Powers and colleagues were excluded because no events occurred in the groups compared, leaving the comparison of aspirin versus no prophylaxis from Powers and colleagues. In this comparison, in patients who received pharmacologic prophylaxis versus no prophylaxis the odds of fatal pulmonary embolism were not significantly different [OR 7.06 (0.14 to 356.21)]. Two trials were conducted from 2001- present, by Fuji and colleagues and Yokote and colleagues. Neither had events within the groups compared, therefore subgroup analysis was not possible.53,135 Subgroup analyses based on total hip replacement surgery42,44,49,135 and total knee replacement surgery53 were not possible because the included trials had no events in either groups compared. When limiting the original analysis to hip fracture surgery one trial by Powers and colleagues remained, with two separate comparisons included.132 However in the comparison of warfarin to no prophylaxis no events occurred, leaving the comparison of aspirin to no prophylaxis. In this comparison, in patients receiving pharmacologic prophylaxis versus no prophylaxis the odds of fatal pulmonary embolism were not significantly different [OR 7.06 (0.14 to 356.21)].

Subgroup analyses based on age, gender and ethnicity were not possible because no randomized controlled trials reported data based on these subgroups.

One controlled observational study evaluated the impact of pharmacologic prophylaxis versus no prophylaxis on fatal pulmonary embolism in patients who had major orthopedic surgery.144 This study was conducted in patients who had total hip or total knee replacement surgery and included two separate comparisons; warfarin versus no prophylaxis and aspirin versus no prophylaxis. Since no events occurred in either the warfarin or control groups, the risk of fatal pulmonary embolism could not be calculated in this comparison. In patients who received aspirin prophylaxis versus control, there was no significantly different in the occurrence of fatal pulmonary embolism (0.07 percent versus 0 percent, p=0.189).

###### Oral Antiplatelet Agents Versus no Prophylaxis

One comparison from the randomized controlled trial by Powers and colleagues evaluated the impact of oral antiplatelet agents versus no prophylaxis on fatal pulmonary embolism in patients who had major orthopedic surgery. In this trial patients who had hip fracture surgery received either aspirin or no prophylaxis and the odds of fatal pulmonary embolism were not significantly different [OR 7.06 (0.14 to 356.21)].132

One controlled observational study by Cusick and colleagues compared oral antiplatelet prophylaxis versus no prophylaxis and the results were previously described above.144

###### Injectable low Molecular Weight Heparins Versus no Prophylaxis

Three randomized controlled trials and one comparison from the trail by Yokote and colleagues evaluated the impact of injectable low molecular weight heparins versus no prophylaxis on fatal pulmonary embolism in patients who had major orthopedic surgery.42,44,49,135 The risk of fatal pulmonary embolism could not be calculated because no events occurred in the groups compared.

###### Injectable Unfractionated Heparin Versus no Prophylaxis

No randomized controlled trials evaluated the impact of injectable unfractionated heparin versus no prophylaxis on this outcome.

###### Injectable or Oral Factor Xa Inhibitors Versus no Prophylaxis

One comparison from the randomized controlled trial by Yokote and colleagues in 2011 evaluated the impact of injectable or oral factor Xa inhibitors versus no prophylaxis on fatal pulmonary embolism in patients who had major orthopedic surgery.135 However no events occurred and the risk of fatal pulmonary embolism could not be calculated.

###### Injectable or Oral Direct Thrombin Inhibitors Versus no Prophylaxis

One randomized controlled trial evaluated the impact of oral direct thrombin inhibitors versus no prophylaxis on fatal pulmonary embolism in patients who had major orthopedic surgery.53 This trial evaluated patients who had total knee replacement and included two separate comparisons; dabigatran 150mg daily and dabigatran 220mg daily each versus placebo. The risk of fatal pulmonary embolism could not be calculated because no events occurred in the groups compared.

###### Oral Vitamin K Antagonists Versus no Prophylaxis

One comparison from the randomized controlled trial by Powers and colleagues evaluated the impact of vitamin K antagonists versus no prophylaxis in patient who had major orthopedic surgery.132 This trial evaluated patients who had hip fracture surgery and received either warfarin or no prophylaxis. The risk of fatal pulmonary embolism could not be calculated because no events occurred in the groups compared.

One controlled observational study by Cusick and colleagues compared oral vitamin K antagonists versus no prophylaxis and the results were previously described above.144

###### Mechanical Prophylaxis Versus no Prophylaxis

One randomized controlled trial evaluated the impact of mechanical prophylaxis versus no prophylaxis on fatal pulmonary embolism in patients who had major orthopedic surgery.51 In this trial, a venous foot pump was compared with no prophylaxis in patients who had total knee replacement surgery. The risk of fatal pulmonary embolism could not be calculated because no events occurred in either group compared.

Subgroup analyses were not possible because only one trial was available. No randomized controlled trials evaluated the impact of either graduated compression stockings or intermittent pneumatic compression devices versus no prophylaxis in patients who had major orthopedic surgery on this outcome.

##### Nonfatal Pulmonary Embolism

###### Pharmacologic Prophylaxis Versus no Prophylaxis

Six randomized controlled trials evaluated the impact of pharmacologic prophylaxis versus no prophylaxis on nonfatal pulmonary embolism in patients who had major orthopedic surgery with the trials by Yokote, Fuji, and Powers and colleagues each including two separate comparisons.42,44,49,53,132,135 Three trials were excluded from the analysis because no events occurred in either of the groups compared.44,53,135 In patients who received pharmacologic prophylaxis versus no prophylaxis the odds of nonfatal pulmonary embolism were not significantly different [OR 0.21 (0.04 to 1.30)] (Appendix G Figure 10). Statistical heterogeneity was not detected (I^2^=0 percent) although publication bias was detected (Egger's p-value=0.009) The directionality of the publication bias was unclear.

When limiting the analysis to trials which compared pharmacologic prophylaxis with truly no prophylaxis, two trials remained, with the trial by Powers and colleagues including two separate comparisons.49,132 In patients who received pharmacologic prophylaxis versus no prophylaxis the risk of nonfatal pulmonary embolism was not significantly different [RR 0.21 (0.03 to 1.29)] (Appendix G Figure 11). Statistical heterogeneity was not detected (I^2^=0 percent). Subgroup analysis of trials published from 2001-present was not possible because two trials remained and no events occurred in either of the groups compared.53,135 When limiting the original analysis to total hip replacement, four trials remained although the trials by Yokote and Samama and colleagues were excluded because no events occurred.42,44,49,135 In patients who received pharmacologic prophylaxis versus no prophylaxis the odds of nonfatal pulmonary embolism were not significantly different [OR 0.53 (0.05 to 5.09)] (Appendix G Figure 12). Statistical heterogeneity could not be evaluated because of too few studies. Subgroup analysis of trials evaluating total knee replacement was not possible because only one trial remained and no events occurred in either of the groups compared.53 When limiting the original analysis to hip fracture surgery, one trial remained by Powers and colleagues which included two separate comparisons.132 In patients who received pharmacologic prophylaxis versus no prophylaxis the risk of nonfatal pulmonary embolism was not significantly different [RR 0.16 (0.02 to 1.53)] (Appendix G Figure 13). Statistical heterogeneity could not be evaluated because of too few studies.

Subgroup analyses based on age, gender and ethnicity were not possible because no randomized controlled trials reported data based on these subgroups.

One controlled observational study evaluated the impact of pharmacologic prophylaxis versus no prophylaxis on nonfatal pulmonary embolism in patients who had major orthopedic surgery.144 This study was conducted in patients who had total hip or total knee replacement surgery and included two separate comparisons; warfarin versus no prophylaxis and aspirin versus no prophylaxis. Since no events occurred in either the warfarin or control groups, the risk of nonfatal pulmonary embolism could not be calculated in this comparison. In patients who received aspirin prophylaxis versus control, there was no significant difference in the occurrence of nonfatal pulmonary embolism (0.67 percent versus 0 percent, p=0.683).

###### Oral Antiplatelet Agents Versus no Prophylaxis

One comparison from the randomized controlled trial by Powers and colleagues evaluated the impact of oral antiplatelet agents versus no prophylaxis on nonfatal pulmonary embolism in patients who had major orthopedic surgery. In this trial patients who had hip fracture surgery received either aspirin or no prophylaxis and the odds of nonfatal pulmonary embolism were not significantly different [OR 0.13 (0.01 to 2.09)].132 One controlled observational study by Cusik and colleagues also evaluated the impact of oral antiplatelet prophylaxis versus no prophylaxis on nonfatal pulmonary embolism in patients who had major orthopedic surgery and the results are presented above.144

###### Injectable low Molecular Weight Heparins Versus no Prophylaxis

Three randomized controlled trials and one comparison from the trial by Yokote and colleagues in 2011 evaluated the impact of injectable low molecular weight heparins versus no prophylaxis on nonfatal pulmonary embolism in patients who had major orthopedic surgery.42,44,49,135 One trial and the comparison from Yokote and colleagues were excluded from the analysis because no events occurred in either group compared.44,135 In patients who received pharmacologic prophylaxis versus no prophylaxis the odds of nonfatal pulmonary embolism were not significantly different [OR 0.53 (0.05 to 5.09)] (Appendix G Figure 14). Statistical heterogeneity and publication bias could not be evaluated because of too few studies.

###### Injectable Unfractionated Heparin Versus no Prophylaxis

No randomized controlled trials evaluated the impact of injectable unfractionated heparin versus no prophylaxis on this outcome.

###### Injectable or Oral Factor Xa inhibitors Versus no Prophylaxis

One comparison from the trial by Yokote and colleagues in 2011 evaluated the impact of injectable or oral factor Xa inhibitors versus no prophylaxis on nonfatal pulmonary embolism although the risk could not be calculated because no events occurred.135

###### Injectable or Oral Direct Thrombin Inhibitors Versus no Prophylaxis

One randomized controlled trial evaluated the impact of oral direct thrombin inhibitors versus no prophylaxis on nonfatal pulmonary embolism in patients who had major orthopedic surgery.53 This trial evaluated patients who had total knee replacement surgery and included two separate comparisons; dabigatran 150mg daily and dabigatran 220mg daily each versus placebo. The risk of nonfatal pulmonary embolism could not be calculated because no events occurred in the groups compared.

###### Oral Vitamin K Antagonists Versus no Prophylaxis

One comparison from the randomized controlled trial by Powers and colleagues evaluated the impact of oral vitamin K antagonists versus no prophylaxis in patient who had major orthopedic surgery.132 This trial evaluated patients who had hip fracture surgery and received either warfarin or no prophylaxis. In patients who received pharmacologic prophylaxis versus no prophylaxis the odds of nonfatal pulmonary embolism were not significantly different [OR 0.13 (0.01 to 2.09)]. One controlled observational study by Cusik and colleagues also evaluated the impact of oral vitamin K antagonist prophylaxis versus no prophylaxis on nonfatal pulmonary embolism in patients who had major orthopedic surgery and the results are presented above.144

###### Mechanical Prophylaxis Versus no Prophylaxis

One randomized controlled trial evaluated the impact of mechanical prophylaxis versus no prophylaxis on nonfatal pulmonary embolism in patients who had major orthopedic surgery.51 In this trial, a venous foot pump was compared with no prophylaxis in patients who had total knee replacement. The risk of nonfatal pulmonary embolism could not be calculated because no events occurred in either group compared.

Subgroup analyses were not possible because only one trial was available. No randomized controlled trials evaluated the impact of either graduated compression stockings or intermittent pneumatic compression devices versus no prophylaxis in patients who had major orthopedic surgery on this outcome.

##### Postthrombotic Syndrome

###### Pharmacologic Prophylaxis Versus no Prophylaxis

No randomized controlled trials or controlled observational studies evaluated the impact of pharmacologic prophylaxis versus no prophylaxis on this outcome.

###### Mechanical prophylaxis versus no prophylaxis

No randomized controlled trials or controlled observational studies evaluated the impact of mechanical prophylaxis versus no prophylaxis on this outcome.

##### Mortality

###### Pharmacologic Prophylaxis Versus no Prophylaxis

Ten randomized controlled trials evaluated the impact of pharmacologic prophylaxis versus no prophylaxis on mortality in patients who had major orthopedic surgery,40,42-45,47,49,53,132,135 of which the trials by Yokote, Fuji and Powers and colleagues each included two separate comparisons. Four trials were excluded from the analysis because no events occurred in the groups compared.43,44,53,135 In patients who received pharmacologic prophylaxis versus no prophylaxis the odds of mortality were not significantly different [OR 1.23 (0.54 to 2.78)] (Appendix G Figure 15). Statistical heterogeneity and publication bias were not detected (I^2^=0 percent, Egger's p-value=0.757).

When limiting the original pooled analysis to trials in which pharmacologic prophylaxis was compared with truly no prophylaxis, five trials remained, with the trial by Powers and colleagues including two separate comparisons.40,43,47,49,132 The trial by McKenna and colleagues was excluded from the analysis because no events occurred in either of the groups compared. In patients who received pharmacologic prophylaxis versus truly no prophylaxis the odds of mortality were not significantly different [OR 1.26 (0.52 to 3.11)] (Appendix G Figure 16). Statistical heterogeneity was not detected (I^2^=0 percent). Subgroup analysis of trials published from 2001-present was not possible because only two trials remained and no events occurred in the groups compared.53,135 When limiting original pooled analysis to trials conducted in patients who had total hip replacement surgery, six trials remained.42,44,45,47,49,135 of which the trial by Yokote and colleagues included two separate comparisons. The trial by Yokote and Samama were excluded from the analysis because no events occurred in either of the groups compared. In patients who received pharmacologic prophylaxis versus no prophylaxis the odds of mortality were not significantly different [OR 1.02 (0.21 to 5.10)] (Appendix G Figure 17). Statistical heterogeneity was not detected (I^2^=0 percent). When limiting original pooled analysis to trials conducted in patients who had total knee replacement surgery, two trials remained and the risk of mortality could not be calculated because no events occurred in the groups compared.43,53 When limiting the original pooled analysis to hip fracture surgery, two trials remained with the trial by Powers and colleagues including two separate comparisons.40,132 In patients who received pharmacologic prophylaxis versus no prophylaxis the risk of mortality was not significantly different [RR 1.27 (0.50 to 3.26)] (Appendix G Figure 18). Statistical heterogeneity was not detected (I^2^=0 percent).

Subgroup analyses based on age, gender or ethnicity were not possible because no randomized controlled trials reported data based on these subgroups.

Three controlled observational studies evaluated the impact of pharmacologic prophylaxis versus no prophylaxis in patients who had major orthopedic surgery.144,146,150 The first study by Cusick and colleagues evaluated patients who had either total hip or total knee replacement surgery and included two comparisons; warfarin versus no prophylaxis and aspirin versus no prophylaxis. Since no events occurred in either the warfarin or control groups, the risk of mortality could not be calculated in this comparison. In patients who received aspirin prophylaxis versus control, there was no significant difference in the risk of mortality (0.32 percent versus 0 percent, p=0.902). The second study by Sachs and colleagues evaluated patients who had total knee replacement surgery and compared warfarin versus no prophylaxis.146 No statistically significant difference in mortality was observed in this study when comparing patients who received warfarin versus no prophylaxis (0.1 percent versus 0.3 percent, p=0.863). The third study by Gerkens and colleagues evaluated patients who had total hip or knee replacement or hip fracture surgery and included two comparisons; enoxparin versus no prophylaxis and fondaparinux versus no prophylaxis.150 There was a significant lower number of deaths in patients who received enoxaparin versus no prophylaxis (2.2 percent versus 11.2 percent, p<0.001) and in patients who received fondaparinux versus no prophylaxis (0.8 percent versus 11.3 percent, p=0.002).

###### Oral Antiplatelet Agents Versus no Prophylaxis

Two randomized controlled trials evaluated the impact of oral antiplatelet agents versus no prophylaxis on mortality in patients who had major orthopedic surgery.43,132 The trial by McKenna and colleagues was excluded from the analysis because no events occurred in the groups compared, leaving one comparison from the trial by Powers and colleagues. The comparison within the randomized controlled trial by Powers and colleagues evaluated the impact of aspirin versus placebo on mortality in patients who had major orthopedic surgery. In this comparison, the odds of mortality were not significantly different in patients receiving oral antiplatelet agents versus no prophylaxis [OR 1.62 (0.39 to 6.72)].

One controlled observational study by Cusick and colleagues evaluated the impact of oral antiplatelet agents versus no prophylaxis and the results have been previously described above.144

###### Injectable low Molecular Weight Heparins Versus no Prophylaxis

Eight randomized controlled trials evaluated the impact of injectable low molecular weight heparins versus no prophylaxis on mortality in patients who had major orthopedic surgery.36,40,42,44,46,47,49,135 Three trials were excluded from the pooled analysis because no events occurred in either group.36,44,135 In patients who received injectable low molecular weight heparin versus no prophylaxis, the odds of mortality were not significantly different [OR 0.98 (0.32 to 3.01)] (Appendix G Figure 19). Statistical heterogeneity and publication bias were not detected (I^2^=0 percent, Egger's p-value=0.962).

One controlled observational study evaluated the impact of low molecular weight heparin versus no prophylaxis and the results have been previously described above.150

###### Injectable Unfractionated Heparins Versus no Prophylaxis

No randomized controlled trials evaluated the impact of injectable unfractionated heparin versus no prophylaxis on this outcome.

###### Injectable or Oral Factor Xa Inhibitors Versus no Prophylaxis

One comparison from the randomized controlled trial by Yokote and colleagues in 2011 evaluated the impact of injectable or oral factor Xa inhibitors versus no prophylaxis on mortality in patients who had major orthopedic surgery. No events occurred therefore the risk of mortality could not be calculated.135

One controlled observational study evaluated the impact of injectable or oral factor Xa inhibitors versus no prophylaxis and the results have been previously described above.150

###### Injectable or Oral Direct Thrombin Inhibitors Versus no Prophylaxis

One randomized controlled trial evaluated the impact of oral direct thrombin inhibitors versus no prophylaxis on mortality in patients who had major orthopedic surgery.53 In this trial, patients who had total knee replacement were randomized to either dabigatran 150mg daily, dabigatran 220mg daily or placebo. The risk of mortality could not be calculated because no events occurred in the groups compared.

###### Oral Vitamin K Antagonists Versus no Prophylaxis

One comparison within the randomized controlled trial by Powers and colleagues evaluated the impact of warfarin versus no prophylaxis on mortality in patients who had major orthopedic surgery.132 In this comparison, the odds of mortality in patients receiving warfarin compared with no prophylaxis were not significantly different [OR 1.64 (0.39 to 6.84)].

Two controlled observational studies evaluated the impact of oral vitamin K antagonists versus no prophylaxis and the results have been previously described above.144,146

###### Mechanical Prophylaxis Versus no Prophylaxis

No randomized controlled trials or controlled observational studies evaluated the impact of mechanical prophylaxis versus no prophylaxis on this outcome.

##### Mortality Due to Bleeding

###### Pharmacologic Prophylaxis Versus no Prophylaxis

Nine randomized controlled trials evaluated the impact of pharmacologic prophylaxis versus no prophylaxis on mortality due to bleeding in patients who had major orthopedic surgery with the trials by Yokote, Fuji and Powers and colleagues each included two separate comparisons.40,43-45,47,49,53,132,135 Eight trials were excluded from the analysis because no events occurred in the groups compared,40,43-45,47,53,132 leaving the trial by Turpie and colleagues which compared enoxaparin with placebo.49 In this trial, in patients who received enoxaparin versus placebo the odds of mortality due to bleeding were not significantly different [OR 0.14 (0.003 to 6.82)].

When limiting the original pooled analysis to trials in which pharmacologic prophylaxis was compared with truly no prophylaxis, five trials remained, with the trial by Powers and colleagues including two separate comparisons.40,43,47,49,132 Four trials were excluded from the analysis because no events occurred in the groups compared,40,43,47,132 leaving the trial by Turpie and colleagues which compared enoxaparin to placebo.49 In this trial, in patients who received enoxaparin versus placebo, the odds of mortality due to bleeding were not significantly different [OR 0.14 (0.003 to 6.82)]. Subgroup analysis based on trials published from 2001-present was not possible because only two trials remained and no events occurred in the groups compared.53,135 When limiting original pooled analysis to trials conducted in patients who had total hip replacement surgery, five trials remained.44,45,47,49,135 Four trials were excluded because no events occurred in the groups compared,44,45,47 leaving the trial by Turpie and colleagues which compared enoxaparin to placebo.49 In this trial, in patients who received pharmacologic prophylaxis versus no prophylaxis the odds of mortality due to bleeding were not significantly different [OR 0.14 (0.003 to 6.82)]. When limiting the original pooled analysis to trials conducted in patients who had total knee replacement surgery, two trials remained and the trial by Fuji and colleagues included two separate comparisons.43,53 The risk of mortality due to bleeding could not be calculated because no event occurred in the groups compared. When limiting the original pooled analysis to trials conducted in patients who had hip fracture surgery, two trials remained with the trial by Powers and colleagues contributing two separate comparisons of aspirin to placebo and warfarin to placebo.40,132 No events occurred in either trial group therefore the risk of mortality due to bleeding could not be calculated.

Subgroup analyses based on age, gender and ethnicity were not possible because no randomized controlled trials reported data based on these subgroups

One controlled observational study evaluated the impact of pharmacologic prophylaxis versus no prophylaxis on mortality due to bleeding.150 This study evaluated patients who had total hip or knee replacement or hip fracture surgery and included two comparisons; enoxparin versus no prophylaxis and fondaparinux versus no prophylaxis.150 There was no significant difference in mortality due to bleeding in patients who received enoxaparin versus no prophylaxis (0.3 percent versus 0.7 percent, p=0.749) and in patients who received fondaparinux versus no prophylaxis (0.0 percent versus 0.7 percent, p=0.976).

###### Oral Antiplatelet Agents Versus no Prophylaxis

One randomized controlled trial by McKenna and colleagues as well as one comparison from the randomized controlled trial by Powers and colleagues evaluated the impact of oral antiplatelet agents versus no prophylaxis on mortality due to bleeding in patients who had major orthopedic surgery.43,132 No events occurred in either trial therefore the risk of mortality due to bleeding could not be calculated.

###### Injectable low Molecular Weight Heparins Versus no Prophylaxis

Six randomized controlled trials evaluated the impact of injectable low molecular weight heparins versus no prophylaxis on mortality due to bleeding in patients who had major orthopedic surgery.40,44,45,47,49,135 Five trials were excluded from the pooled analysis because no events occurred in either group,40,44,45,47,135 leaving the trial by Turpie and colleagues which compared enoxaparin to placebo.49 In this trial, the odds of mortality due to bleeding in patients receiving enoxaparin versus placebo were not significantly different [OR 0.14 (0.003 to 6.82)].

One controlled observational study evaluated the impact of low molecular weight heparin versus no prophylaxis and the results have been previously described above.150

###### Injectable Unfractionated Heparins Versus no Prophylaxis

No randomized controlled trials evaluated the impact of injectable unfractionated heparin versus no prophylaxis on the outcome.

###### Injectable or Oral Factor Xa Inhibitors Versus no Prophylaxis

One comparison from the randomized controlled trial by Yokote and colleagues in 2011 evaluated the impact of injectable or oral factor Xa inhibitors versus no prophylaxis on mortality due to bleeding. No events occurred in the groups compared therefore the risk of mortality due to bleeding could not be calculated.135

One controlled observational study evaluated the impact of injectable or oral factor Xa inhibitors versus no prophylaxis and the results have been previously described above.150

###### Injectable or Oral Direct Thrombin Inhibitors Versus no Prophylaxis

One randomized controlled trial evaluated the impact of oral direct thrombin inhibitors versus no prophylaxis on mortality due to bleeding in patients who had major orthopedic surgery.53 In this trial, patients who had total knee replacement were randomized to either dabigatran 150mg daily, dabigatran 220mg daily or placebo. The risk of mortality due to bleeding could not be calculated because no events occurred in the groups compared.

###### Oral Vitamin K Antagonists Versus no Prophylaxis

One comparison within the randomized controlled trial by Powers and colleagues evaluated the impact of warfarin versus placebo on mortality due to bleeding in patients who had major orthopedic surgery.132 No events occurred in either arm therefore the risk of mortality due to bleeding could not be calculated.

###### Mechanical Prophylaxis Versus no Prophylaxis

No randomized controlled trials or controlled observational studies evaluated the impact of mechanical prophylaxis versus no prophylaxis on this outcome.

##### Health-Related Quality of Life

###### Pharmacologic Prophylaxis Versus no Prophylaxis

No randomized controlled trials or controlled observational studies evaluated the impact of pharmacologic prophylaxis versus no prophylaxis on this outcome.

###### Mechanical Prophylaxis Versus no Prophylaxis

No randomized controlled trials or controlled observational studies evaluated the impact of mechanical prophylaxis versus no prophylaxis on this outcome.

##### Deep Vein Thrombosis

###### Pharmacologic Prophylaxis Versus no Prophylaxis

Seventeen randomized controlled trials evaluated the impact of pharmacologic prophylaxis versus no prophylaxis on deep vein thrombosis in patients who had major orthopedic surgery, with the three trial by trials by Yokote, Fuji, Alfaro and colleagues each including two separate comparisons.35,36,38,40-45,47,49,50,52,53,133,135 In patients who received pharmacologic prophylaxis versus no prophylaxis, the risk of deep vein thrombosis was significantly decreased [RR 0.56 (0.47 to 0.68), NNT 3 to 33 ] (Appendix G Figure 20). A higher level of statistical heterogeneity was detected but publication bias was not detected (I^2^=52.8 percent, Egger's p-value=0.199). Higher statistical heterogenity may reflect the different pharmacologic agents evaluated across trials, the inclusion of all major orthopedic surgeries, and the changes in clinical practice over the years which trials were conducted.

When limiting the original pooled analysis to trials in which pharmacologic prophylaxis was compared with truly no prophylaxis, nine trials remained, with the trial by Alfaro and colleagues including two separate comparisons.35,36,40,41,43,47,49,50,133 In patients who received pharmacologic prophylaxis versus truly no prophylaxis, the risk of deep vein thrombosis was significantly decreased [RR 0.44 (0.27 to 0.72), NNT 2 to 9] (Appendix G Figure 21). A higher level of statistical heterogeneity was detected (I^2^=69 percent). When limiting the original pooled analysis to trials published from 2001-present, five trials remained, with the trials by Yokote and by Fuji and colleagues each including two separate comparisons.36,38,53,135 In patients who received pharmacologic prophylaxis versus no prophylaxis the risk of deep vein thrombosis was significantly decreased [RR 0.54 (0.45 to 0.64), NNT 4 to 31] (Appendix G Figure 22). A lower level of statistical heterogeneity was detected (I^2^=10.4 percent). When limiting the original pooled analysis to total hip replacement surgery, twelve trials remained,35,38,41,42,44,45,47,49,50,52,133,135 of which the trials by Yokote, Fuji and Alfaro and colleagues each included two separate comparisons. In patients who received pharmacologic prophylaxis versus no prophylaxis, the risk of deep vein thrombosis was significantly decreased [RR 0.59 (0.45 to 0.77), NNT 3 to 35] (Appendix G Figure 23). A higher level of statistical heterogeneity was detected (I^2^=52.9 percent). When limiting original pooled analysis to total knee replacement, four trials remained,36,38,43,53 of which the two trials by Fuji and colleagues each included two separate comparisons. In patients who received pharmacologic prophylaxis versus no prophylaxis, the risk of deep vein thrombosis was significantly decreased [RR 0.54 (0.40 to 0.73), NNT 3 to 10] (Appendix G Figure 24). A higher level of statistical heterogeneity was detected (I^2^=61.4 percent). When limiting the original pooled analysis to hip fracture surgery, one trial remained.40 In this trial, the risk of developing deep vein thrombosis in patients who received pharmacologic prophylaxis versus no prophylaxis was significantly decreased [RR 0.35 (0.15 to 0.78), NNT 4].

Two randomized controlled trial evaluated the impact of age on the incidence of deep vein thrombosis in patients who had major orthopedic surgery.41,43 The first trial by Kim and colleagues randomized patients to aspirin or no prophylaxis and performed subgroup analysis on the incidence of deep vein thrombosis based on patients with an age below 60 years versus age above 60 years. The incidence of deep vein thrombosis was not significantly different in the patients who received aspirin versus no prophylaxis in the subgroup aged below 60 years (p=0.426) or in the subgroup aged above 60 years (p=0.232).41 The second trial by McKenna and colleagues randomized patients to aspirin or no prophylaxis. When adjusting for age, the odds of deep vein thrombosis were not significantly different in patients who received aspirin versus no prophylaxis [AOR 1.30 (-2.16 to 4.76)].43

The trial by Kim and colleagues also evaluated the impact of gender on the incidence of deep vein thrombosis in patients who received aspirin versus no prophylaxis.41 There were no significant differences in the incidence of deep vein thrombosis in male patients (p=0.322) or in female patients (p=0.117) who received aspirin prophylaxis versus no prophylaxis. A second trial by Alfaro and colleagues found a significantly lower incidence of deep vein thrombosis in male patients who received aspirin prophylaxis versus no prophylaxis (0 percent versus 26 percent, p<0.04).

Subgroup analysis based on ethnicity was not possible because no randomized controlled trials reported data based on these subgroups.

###### Oral Antiplatelet Agents Versus no Prophylaxis

Three randomized controlled trials evaluated the impact of oral antiplatelet agents versus no prophylaxis on deep vein thrombosis in patients who had major orthopedic surgery,35,41,43 of which the trial by Alfaro and colleagues included two separate comparisons; aspirin 250mg per day versus no prophylaxis and aspirin 1 gram per day versus no prophylaxis. In patients who received oral antiplatelet agents versus no prophylaxis, the risk of deep vein thrombosis was not significantly different [RR 0.41 (0.12 to 1.32)] (Appendix G Figure 25). A higher level of statistical heterogeneity was detected as was the presence of publication bias although the directionality of the publication bias was unclear (I^2^=76 percent, Egger's p-value=0.002).

###### Injectable Low Molecular Weight Heparins Versus no Prophylaxis

Twelve randomized controlled trials evaluated the impact of injectable low molecular weight heparins versus no prophylaxis on deep vein thrombosis in patients who had major orthopedic surgery.36,38,40,42,44,45,47,49,52,133,135 The two trials by Fuji and colleagues included 2 separate comparisons of pharmacologic prophylaxis versus no prophylaxis. In patients who received low molecular weight heparin versus no prophylaxis, the risk of deep vein thrombosis was significantly decreased [RR 0.54 (0.44 to 0.67), NNT 4 to 31] (Appendix G Figure 26). A higher level of statistical heterogeneity was detected although publication bias was not detected (I^2^=50.2 percent, Egger's p-value=0.088).

###### Injectable Unfractionated Heparins Versus no Prophylaxis

One randomized controlled trial evaluated the impact of injectable unfractionated heparin versus no prophylaxis on deep vein thrombosis in patients who had major orthopedic surgery.50 In this trial, the risk of deep vein thrombosis in patients receiving injectable unfractionated heparin compared with no prophylaxis was not significantly different [RR 1.60 (0.66 to 4.05)].

###### Injectable or Oral Factor Xa Inhibitors Versus no Prophylaxis

One comparison from the randomized controlled trial by Yokote and colleagues in 2011 evaluated the impact of injectable or oral factor Xa inhibitors versus no prophylaxis on deep vein thrombosis in patients who had major orthopedic surgery.135 In this trial patients who had total hip replacement surgery received either fondaparinux 2.5 mg daily or placebo. The use of concurrent elastic stockings and compression devices was allowed therefore this trial was not considered a trial comparing pharmacologic prophylaxis versus truly no prophylaxis. In patients who received fondaparinux versus no prophylaxis the risk of deep vein thrombosis was not significantly different [RR 0.99 (0.35 to 2.80)]. Statistical heterogeneity and publication bias could not be calculated because of there was only one trial available.

###### Injectable or Oral Direct Thrombin Inhibitors Versus no Prophylaxis

One randomized controlled trial evaluated the impact of oral direct thrombin inhibitors versus no prophylaxis on deep vein thrombosis in patients who had major orthopedic surgery.53 In this trial patients who had total knee replacement were randomized to dabigatran 150mg daily, dabigatran 220mg daily or placebo. All patients were allowed to also receive elastic compression stockings. In patients who received oral direct thrombin inhibitors versus no prophylaxis the risk of deep vein thrombosis was significantly decreased [RR 0.51 (0.37 to 0.69), NNT 4] (Appendix G Figure 27). Statistical heterogeneity and publication bias could not be calculated because of too few studies. Because both experimental arms of the trial shared one control group, a range could not be calculated for the number needed to treat.

###### Oral Vitamin K Antagonists Versus no Prophylaxis

No randomized controlled trials evaluated the impact of oral vitamin K antagonists versus no prophylaxis on this outcome.

###### Mechanical Prophylaxis Versus no Prophylaxis

One randomized controlled trial by Fordyce and colleagues in 1992 evaluated the impact of mechanical prophylaxis versus no prophylaxis on deep vein thrombosis in patients who had major orthopedic surgery.37 In this trial, patients who had total hip replacement received either prophylaxis with a venous foot pump or no prophylaxis, although patients in both groups also wore graduated compression stockings. In patients who received mechanical prophylaxis versus no prophylaxis, the risk of deep vein thrombosis was significantly decreased [RR 0.26 (0.10 to 0.65), NNT 4].

Subgroup analyses were not possible because only one trial was available. No randomized controlled trials evaluated the impact of either graduated compression stockings or intermittent pneumatic compression devices versus no prophylaxis in patients who had major orthopedic surgery.

##### Asymptomatic Deep Vein Thrombosis

###### Pharmacologic Prophylaxis Versus no Prophylaxis

Three randomized controlled trials evaluated the impact of pharmacologic prophylaxis versus no prophylaxis on asymptomatic deep vein thrombosis in patients who had major orthopedic surgery and the trial by Fuji and colleagues included two separate comparisons.42,44,53 In patients who received pharmacologic prophylaxis versus no prophylaxis the risk of asymptomatic deep vein thrombosis was significantly decreased [RR 0.52 (0.40 to 0.69), NNT 4 to 6] (Appendix G Figure 28). A lower level of statistical heterogeneity was detected although publication bias was not detected (I^2^=32.7 percent, Egger's p-value=0.168).

Subgroup analysis limited to trials which compared pharmacologic prophylaxis to truly no prophylaxis was not possible because all three trials allowed concurrent use of graduated compression stockings along with the intervention patients were randomized to.42,44,53 When limiting the original analysis to trials published from 2001-present, one trial remained by Fuji and colleagues which included two separate comparisons; dabigatran 150mg daily or dabigatran 220mg daily versus no prophylaxis.53 In patients who received pharmacologic prophylaxis versus no prophylaxis the risk of asymptomatic deep vein thrombosis was significantly decreased [RR 0.50 (0.37 to 0.67), NNT 4] (Appendix G Figure 29). Because both experimental arms of the trial shared one control group, a range could not be calculated for the number needed to treat. Statistical heterogeneity could not be calculated because there were too few studies. This is also the same result that is obtained when limiting the original analysis to total knee replacement surgery since the trial by Fuji and colleagues was the only trial which fit this subgroup.53 When limiting the original analysis to total hip replacement, two trials remained.42,44 In patients who received pharmacologic prophylaxis versus no prophylaxis the risk of asymptomatic deep vein thrombosis was not significantly different [RR 0.52 (0.27 to 1.00)] (Appendix G Figure 30). Statistical heterogeneity could not be calculated because there were too few studies. Subgroup analysis limited to hip fracture surgery was not possible because none of the trials were conducted in this surgical population.

Subgroup analysis based on age, gender or ethnicity was not possible because no randomized controlled trials reported data based on these subgroups.

###### Oral Antiplatelet Agents Versus no Prophylaxis

No randomized controlled trials evaluated the impact of oral antiplatelet agents versus no prophylaxis in patients undergoing major orthopedic surgery on this outcome.

###### Injectable low Molecular Weight Heparins Versus no Prophylaxis

Two trials evaluated the impact of injectable low molecular weight heparins versus no prophylaxis on asymptomatic deep vein thrombosis in patients who had major orthopedic surgery.42,44 Both of these trials were conducted in patients who had total hip replacement surgery. In patients who received injectable low molecular weight heparins versus no prophylaxis the risk of asymptomatic deep vein thrombosis was not significantly different [RR 0.52 (0.27 to 1.00)] (Appendix G Figure 30). Statistical heterogeneity and publication bias could not be evaluated because of too few studies.

###### Injectable Unfractionated Heparins Versus no Prophylaxis

No randomized controlled trials evaluated the impact of injectable unfractionated heparins versus no prophylaxis in patients undergoing major orthopedic surgery on this outcome.

###### Injectable or Oral Factor Xa Inhibitors Versus no Prophylaxis

No randomized controlled trials evaluated the impact of injectable or oral factor Xa inhibitors versus no prophylaxis on this outcome.

###### Injectable or Oral Direct Thrombin Inhibitors Versus no Prophylaxis

One randomized controlled trial evaluated the impact of oral direct thrombin inhibitors versus no prophylaxis on asymptomatic deep vein thrombosis in patients who had major orthopedic surgery.53 In this trial patients who had total knee replacement were randomized to dabigatran 150mg daily, dabigatran 220mg daily or placebo. All patients were allowed to also receive elastic compression stockings. In patients who received oral direct thrombin inhibitors versus no prophylaxis the risk of asymptomatic deep vein thrombosis was significantly decreased [RR 0.50 (0.37 to 0.67), NNT 4] (Appendix G Figure 29). Statistical heterogeneity and publication bias could not be calculated because of too few studies. Because both experimental arms of the trial shared one control group, a range could not be calculated for the number needed to treat.

###### Oral Vitamin K Antagonists Versus no Prophylaxis

No randomized controlled trials evaluated the impact of injectable or oral direct thrombin inhibitors versus no prophylaxis on this outcome.

###### Mechanical Prophylaxis Versus no Prophylaxis

No randomized controlled trials or controlled observational studies evaluated the impact of mechanical prophylaxis versus no prophylaxis on asymptomatic deep vein thrombosis in patients who had major orthopedic surgery.

##### Symptomatic Deep Vein Thrombosis

###### Pharmacologic Prophylaxis Versus no Prophylaxis

Four randomized controlled trials evaluated the impact of pharmacologic prophylaxis versus no prophylaxis on symptomatic deep vein thrombosis in patients who had major orthopedic surgery and the trial by Yokote, Fuji and colleagues included two separate comparisons.42,44,53 One trial and one comparison from the trial by Yokote and colleagues was excluded from the analysis because no events occurred in either of the groups compared.42,135 In patients who received pharmacologic prophylaxis versus no prophylaxis the odds of symptomatic deep vein thrombosis were not significantly different [OR 1.07 (0.25 to 4.52)] (Appendix G Figure 31). Statistical heterogeneity and publication bias were not detected (I^2^=0 percent, Egger's p-value=0.316).

Subgroup analysis limited to trials which compared pharmacologic prophylaxis to truly no prophylaxis was not possible because all three trials allowed concurrent use of graduated compression stockings along with the intervention patients were randomized to.42,44,53 When limiting the original analysis to trials published from 2001- present, two trials by Yokote and Fuji and colleagues remained, both of which included two separate comparisons‥53,135 One of the two comparisons by Yokote and colleagues was excluded because no events occurred in either of the arms. In patients who received pharmacologic prophylaxis versus no prophylaxis the odds of symptomatic deep vein thrombosis were not significantly different [OR 1.11 (0.20 to 6.01)] (Appendix G Figure 32). No statistical heterogeneity was detected (I^2^=0 percent). When limiting the original analysis to total hip replacement, three trials remained with the trial by Yokote and colleagues including two separate comparisons.42,44,135 One of the two comparisons and the trial by Lassen and colleagues were excluded from the analysis because no events occurred in the groups compared, leaving one comparison from the trial by Yokote and the trial by Samama and colleagues.42,44,135 (Appendix G Figure 33) In patients who received pharmacologic prophylaxis versus no prophylaxis the odds of symptomatic deep vein thrombosis were not significantly different [OR 1.90 (0.20 to 18.32)]. Statistical heterogeneity could not be calculated because there were too few studies. When limiting the original analysis to total knee replacement surgery, two comparisons from the trial by Fuji and colleagues remained. In patients who received pharmacologic prophylaxis versus no prophylaxis, the risk of symptomatic deep vein thrombosis was not significantly different [RR 0.72 (0.12 to 4.39)] (Appendix G Figure 34). Statistical heterogeneity could not be calculated because only one trial was available. Subgroup analysis limited to hip fracture surgery was not possible because none of the trials were conducted in this surgical population.

Subgroup analysis based on age, gender or ethnicity was not possible because no randomized controlled trials reported data based on these subgroups.

One controlled observational study evaluated the impact of pharmacologic prophylaxis versus no prophylaxis on symptomatic deep vein thrombosis in patients who had major orthopedic surgery.146 This trial evaluated patients who had total knee replacement surgery and compared warfarin versus no prophylaxis. No statistically significant difference in symptomatic deep vein thrombosis was observed in this study when comparing patients who received warfarin versus no prophylaxis (0.2 percent versus 0 percent, p=0.568).

###### Oral Antiplatelet Agents Versus no Prophylaxis

No randomized controlled trials evaluated the impact of oral antiplatelet agents versus no prophylaxis in patients undergoing major orthopedic surgery on this outcome.

###### Injectable low Molecular Weight Heparins Versus no Prophylaxis

Three trials evaluated the impact of injectable low molecular weight heparins versus no prophylaxis on symptomatic deep vein thrombosis in patients who had major orthopedic surgery.42,44,135 All of these trials were conducted in patients who had total hip replacement surgery. The trial by Yokote and Lassen and colleagues were excluded from the analysis because no events occurred in the groups compared, leaving the trial by Samama and colleagues. In this trial, in patients who received injectable low molecular weight heparins versus no prophylaxis the odds of symptomatic deep vein thrombosis were not significantly different [OR 0.96 (0.06 to 15.52)]. Statistical heterogeneity and publication bias could not be evaluated because of too few studies.

###### Injectable Unfractionated Heparins Versus no Prophylaxis

No randomized controlled trials evaluated the impact of injectable unfractionated heparins versus no prophylaxis in patients undergoing major orthopedic surgery on this outcome.

###### Injectable or Oral Factor Xa Inhibitors Versus no Prophylaxis

One comparison from the randomized controlled trial by Yokote and colleagues in 2011 evaluated the impact of injectable or oral factor Xa inhibitors versus no prophylaxis on symptomatic deep vein thrombosis.135 In this trail, patients were randomized to receive either fondaparinux 2.5mg daily or placebo. The use of concurrent elastic stockings and compression devices was allowed therefore this trial was not considered a trial comparing pharmacologic prophylaxis versus truly no prophylaxis. In patients who received injectable or oral factor Xa inhibitors versus no prophylaxis the odds of symptomatic deep vein thrombosis were not significantly different [OR 7.30 (0.14 to 368.00)]. Statistical heterogeneity and publication bias could not be calculated because of too few studies.

###### Injectable or Oral Direct Thrombin Inhibitors Versus no Prophylaxis

One randomized controlled trial evaluated the impact of oral direct thrombin inhibitors versus no prophylaxis on symptomatic deep vein thrombosis in patients who had major orthopedic surgery.53 In this trial patients who had total knee replacement were randomized to dabigatran 150mg daily, dabigatran 220mg daily or placebo. All patients were allowed to also receive elastic compression stockings. In patients who received oral direct thrombin inhibitors versus no prophylaxis the risk of symptomatic deep vein thrombosis was not significantly different [RR 0.72 (0.12 to 4.39)] (Appendix G Figure 34). Statistical heterogeneity and publication bias could not be calculated because of too few studies.

###### Oral Vitamin K Antagonists Versus no Prophylaxis

No randomized controlled trials evaluated the impact of oral vitamin K antagonists versus no prophylaxis on this outcome.

###### Mechanical Prophylaxis Versus no Prophylaxis

No randomized controlled trials or controlled observational studies evaluated the impact of mechanical prophylaxis versus no prophylaxis on symptomatic deep vein thrombosis in patients who had major orthopedic surgery.

##### Proximal Deep Vein Thrombosis

###### Pharmacologic Prophylaxis Versus no Prophylaxis

Twelve randomized controlled trials evaluated the impact of pharmacologic prophylaxis versus no prophylaxis on proximal deep vein thrombosis in patients who had major orthopedic surgery with one trial by Yokote and three trials by Fuji and colleagues each including two separate comparisons.36,38,42-44,47,49,52,53,133,135 In patients who received pharmacologic prophylaxis versus no prophylaxis the risk of proximal deep vein thrombosis was significantly decreased [RR 0.53 (0.39 to 0.74), NNT 4 to 213] (Figure 4). A lower level of statistical heterogeneity was detected as was the presence of publication bias for studies in which the risk of proximal deep vein thrombosis was increased (I^2^=9.7 percent, Egger's p-value 0.012).

Figure 4 Impact of pharmacologic prophylaxis versus no prophylaxis on proximal deep vein thrombosis in patients who had major orthopedic surgery

I^2^: 9.7 percent

Egger's p-value: 0.012

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of pharmacologic prophylaxis versus no prophylaxis on deep vein thrombosis in patients who had major orthopedic surgery. Twelve trials were included in the analysis with four trials contributing to two separate comparisons presented individually here. The first trial by Yokote and colleagues in 2011 provided two separate comparisons. The first comparison was excluded from the analysis because no events occurred in the groups compared. The second comparison provided a relative risk of 2.96 with a 95 percent confidence interval of 0.25 to 35.86. The second trial by Fuji and colleagues in 2010 provided two separate comparisons. The first comparison provided a relative risk of 0.31 with a 95 percent confidence interval of 0.06 to 1.50. The second comparison provided a relative risk of 0.07 with a 95 percent confidence interval of 0.01 to 0.77. The third trial by Chin and colleagues in 2009 provided a relative risk of 0.33 with a 95 percent confidence interval of 0.05 to 2.29. The fourth trial by Fuji and colleagues in 2008 provided two separate comparisons. The first comparison provided a relative risk of 0.72 with a 95 percent confidence interval of 0.24 to 2.19. The second provided a relative risk of 0.32 with a 95 percent confidence interval of 0.09 to 1.20. The fifth trial by Fuji and colleagues in 2008 provided two separate comparisons. The first comparison provided a relative risk of 0.53 with a 95 percent confidence interval of 0.13 to 2.24. The second comparison provided a relative risk of 0.07 with a 95 percent confidence interval of 0.01 to 0.71. The sixth trial by Samama and colleagues in 1997 provided a relative risk of 0.16 with a 95 percent confidence interval of 0.04 to 0.61. The seventh trial by Kalodiki and colleagues in 1996 provided a relative risk of 0.49 with a 95 percent confidence interval of 0.24 to 1.03. The eighth trial by Warwick and colleagues in 1995 provided a relative risk of 0.86 with a 95 percent confidence interval of 0.43 to 1.71. The ninth trial by Lassen and colleagues in 1991 provided a relative risk of 0.72 with a 95 percent confidence interval of 0.46 to 1.10. The tenth trial by Torholm and colleagues in 1991 provided a relative risk of 0.10 with a 95 percent confidence interval of 0.01 to 1.04. The eleventh trial by Turpie and colleagues in 1986 provided a relative risk of 0.23 with a 95 percent confidence interval of 0.06 to 0.88. The twelfth trial by McKenna and colleagues in 1980 provided a relative risk of 0.80 with a 95 percent confidence interval of 0.25 to 2.31. The combined effect of these twelve trials showed a relative risk of 0.54 with a 95 percent confidence interval of 0.40 to 0.74. The I-squared value was 9.7 percent and the Egger's p-value was 0.012.

When limiting the original analysis to trials which compared pharmacologic prophylaxis to truly no prophylaxis, five trials remained.36,43,47,49,133 In patients who received pharmacologic prophylaxis versus truly no prophylaxis the risk of proximal deep vein thrombosis was significantly decreased [RR 0.46 (0.27 to 0.79), NNT 4 to 68] (Appendix G Figure 35). Statistical heterogeneity was not detected (I^2^=0 percent). When limiting the original analysis to trials published from 2001-present, five trials remained; one trial by Yokote and the three trials by Fuji and colleagues each included two separate comparisons.36,38,53,135 In patients who received pharmacologic prophylaxis versus no prophylaxis the risk of proximal deep vein thrombosis was significantly decreased [RR 0.42 (0.22 to 0.79), NNT 18 to 173] (Appendix G Figure 36). Statistical heterogeneity was not detected (I^2^=0 percent).

When limiting the original analysis to total hip replacement surgery, eight trials remained with the trial by Yokote and the trial by Fuji and colleagues including two separate comparisons.38,42,44,47,49,52,133,135 One comparison from the trial by Yokote and colleagues was excluded because no events occurred in the groups compared. In patients who received pharmacologic prophylaxis versus no prophylaxis the risk of proximal deep vein thrombosis was significantly decreased [RR 0.56 (0.38 to 0.81), NNT 4] (Appendix G Figure 37). A range for the NNT could not be calculated because the lower limit of the control event rate was zero. A lower level of statistical heterogeneity was detected (I^2^=20.9 percent). When limiting the original analysis to total knee replacement surgery four trials remained and the two trials by Fuji and colleagues each included two separate comparisons.36,38,43,53 In patients who received pharmacologic prophylaxis versus no prophylaxis the risk of proximal deep vein thrombosis was significantly decreased [RR 0.43 (0.21 to 0.88), NNT 5 to 65] (Appendix G Figure 38). Statistical heterogeneity was not detected (I^2^=0 percent). Subgroup analysis limited to hip fracture surgery was not possible because none of the trials were conducted in this surgical population.

Subgroup analysis based on age, gender or ethnicity was not possible because none of the randomized controlled trials reported data based on these subgroups.

###### Oral Antiplatelet Agents Versus no Prophylaxis

One randomized controlled trial evaluated the impact of oral antiplatelet agents versus no prophylaxis on proximal deep vein thrombosis in patients who had major orthopedic surgery.43 In this trial, patients who had total knee replacement were randomized to either aspirin or no prophylaxis. In patients who received oral antiplatelet agents versus no prophylaxis the risk of proximal deep vein thrombosis was not significantly different [RR 0.80 (0.25 to 2.31)].

###### Injectable Low Molecular Weight Heparins Versus no Prophylaxis

Nine trials plus one comparison from trial by Yokote and colleagues evaluated the impact of injectable low molecular weight heparins versus no prophylaxis on proximal deep vein thrombosis in patients who had major orthopedic surgery.36,38,42,44,47,49,52,133,135 The two trials by Fuji and colleagues each included two separate comparisons and the comparison by Yokote and colleagues was excluded from the analysis because no events occurred in the groups compared. In patients who received injectable low molecular weight heparins versus no prophylaxis the risk of proximal deep vein thrombosis was significantly decreased [RR 0.53 (0.38 to 0.75), NNT 4] (Appendix G Figure 39). A range for the NNT could not be calculated because the lower limit of the control event rate was zero. A lower level of statistical heterogeneity was detected as was the presence of publication bias (I^2^=14.3 percent, Egger's p-value=0.003). The directionality of the publication bias was unclear.

###### Injectable Unfractionated Heparins Versus no Prophylaxis

No randomized controlled trials evaluated the impact of injectable unfractionated heparins versus no prophylaxis in patients undergoing major orthopedic surgery on this outcome.

###### Injectable or Oral Factor Xa Inhibitors Versus no Prophylaxis

One comparison from the randomized controlled trial by Yokote and colleagues in 2011 evaluated the impact of injectable or oral factor Xa inhibitors versus no prophylaxis on proximal deep vein thrombosis.135 In this trial, patients who had total hip replacement surgery were randomized to fondaparinux 2.5mg daily or placebo. The use of concurrent elastic stockings and compression devices was allowed therefore this trial was not considered a trial comparing pharmacologic prophylaxis versus truly no prophylaxis. In patients who received injectable or oral factor Xa inhibitors versus no prophylaxis the odds of proximal deep vein thrombosis were not significantly different [OR 7.30 (0.14 to 368.00)]. Statistical heterogeneity and publication bias could not be evaluated because there was only one trial available.

###### Injectable or Oral Direct Thrombin Inhibitors Versus no Prophylaxis

One randomized controlled trial evaluated the impact of oral direct thrombin inhibitors versus no prophylaxis on proximal deep vein thrombosis in patients who had major orthopedic surgery.53 In this trial patients who had total knee replacement were randomized to dabigatran 150mg daily, dabigatran 220mg daily or placebo. All patients were allowed to also receive elastic compression stockings. In patients who received oral direct thrombin inhibitors versus no prophylaxis the risk of proximal deep vein thrombosis was significantly decreased [RR 0.21 (0.05 to 0.95), NNT 21] (Appendix G Figure 40). Because both experimental arms of the trial shared one control group, a range could not be calculated for the number needed to treat. Statistical heterogeneity could not be evaluated because of too few studies.

###### Oral Vitamin K Antagonists Versus no Prophylaxis

No randomized controlled trials evaluated the impact of oral vitamin K antagonists versus no prophylaxis on this outcome.

###### Mechanical Prophylaxis Versus no Prophylaxis

One randomized controlled trial by Fordyce and colleagues in 1992 evaluated the impact of mechanical prophylaxis versus no prophylaxis on deep vein thrombosis in patients who had major orthopedic surgery.37 In this trial, patients who had total hip replacement surgery received either prophylaxis with a venous foot pump or no prophylaxis, although patients in both groups also received graduated compression stockings. In patients who received mechanical prophylaxis versus no prophylaxis, the risk of proximal deep vein thrombosis was not significantly different [RR 0.41 (0.10 to 1.72)].

Subgroup analyses were not possible because only one trial was available. No randomized controlled trials evaluated the impact of either graduated compression stockings or intermittent pneumatic compression devices versus no prophylaxis in patients who had major orthopedic surgery.

##### Distal Deep Vein Thrombosis

###### Pharmacologic Prophylaxis Versus no Prophylaxis

Seven randomized controlled trials evaluated the impact of pharmacologic prophylaxis versus no prophylaxis on distal deep vein thrombosis in patients who had major orthopedic surgery with the trial by Yokote and colleagues including two separate comparisons.36,42-44,47,52,135 In patients who received pharmacologic prophylaxis versus no prophylaxis the risk of distal deep vein thrombosis was significantly decreased [RR 0.59 (0.42 to 0.82), NNT 8 to 35] (Figure 5). Statistical heterogeneity and publication bias were not detected. (I^2^=0 percent, Egger's p-value=0.305).

Figure 5 Impact of pharmacologic prophylaxis versus no prophylaxis on distal deep vein thrombosis in patients who had major orthopedic surgery

I^2^: 0 percent

Egger's p-value: 0.305

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of pharmacologic prophylaxis versus no prophylaxis on distal deep vein thrombosis in patients who had major orthopedic surgery. Seven trials were included in the analysis. The first trial by Yokote and colleagues in 2011 provided two separate comparisons. The first comparison provided a relative risk of 0.83 with 95 percent confidence interval of 0.23 to 3.07. The second comparison provided a relative risk of 0.99 with 95 percent confidence interval of 0.29 to 3.50. The second trial by Chin and colleagues in 2009 provided a relative risk of 0.24 with a 95 percent confidence interval of 0.10 to 0.58. The third trial by Samama and colleagues in 1997 provided a relative risk of 0.59 with a 95 percent confidence interval of 0.26 to 1.31. The fourth trial by Warwick and colleagues in 1995 provided a relative risk of 0.53 with a 95 percent confidence interval of 0.26 to 1.04. The fifth trial by Lassen and colleagues in 1991 provided a relative risk of 0.58 with a 95 percent confidence interval of 0.21 to 1.59. The sixth trial by Torholm and colleagues in 1991 provided a relative risk of 0.62 with a 95 percent confidence interval of 0.28 to 1.37. The seventh trial by McKenna and colleagues in 1980 provided a relative risk of 1.33 with a 95 percent confidence interval of 0.45 to 3.85. The combined effect of these seven trials showed a relative risk of 0.59 with a 95 percent confidence interval of 0.42 to 0.82. The I-squared value was 0 percent and the Egger's p-value was 0.305

When limiting the original analysis to trials in which pharmacologic prophylaxis was compared with truly no prophylaxis, three trials remained.36,43,47 In patients who received pharmacologic prophylaxis versus no prophylaxis the risk of distal deep vein thrombosis was not significantly different [RR 0.57 (0.22 to 1.46) (Appendix G Figure 41). A higher level of statistical heterogeneity was detected (I^2^=66.8 percent). When limiting the original analysis to trials published from 2001-present, two trials remained with the trial by Yokote and colleagues including two separate comparisons.36,135 In patients who received pharmacologic prophylaxis versus no prophylaxis the risk of distal deep vein thrombosis was not significantly different [RR 0.52 (0.20 to 1.38),] (Appendix G Figure 42). A lower level of statistical heterogeneity was detected (I^2^=48.9 percent). When limiting the original analysis to total hip replacement surgery, five trials remained with the trial by Yokote and colleagues including two separate comparisons.42,44,47,52,135 In patients who received pharmacologic prophylaxis versus no prophylaxis the risk of distal deep vein thrombosis was significantly decreased [RR 0.62 (0.42 to 0.90), NNT 12 to 38] (Appendix G Figure 43). Statistical heterogeneity was not detected (I^2^=0 percent). When limiting the original analysis to total knee replacement surgery, two trials remained.36,43 In patients who received pharmacologic prophylaxis versus no prophylaxis the risk if distal deep vein thrombosis was not significantly different [RR 0.55 (0.10 to 3.19)] (Appendix G Figure 44). Statistical heterogeneity could not be calculated because of too few studies. Subgroup analysis limited to hip fracture surgery was not possible because none of the trials were conducted in this surgical population.

Subgroup analysis based on age, gender or ethnicity was not possible because none of the randomized controlled trials reported data based on these subgroups.

###### Oral Antiplatelet Agents Versus no Prophylaxis

One randomized controlled trial evaluated the impact of oral antiplatelet agents versus no prophylaxis on distal deep vein thrombosis in patients who had major orthopedic surgery.43 In this trial, patients who had total knee replacement were randomized to either aspirin or no prophylaxis. In patients who received oral antiplatelet agents versus no prophylaxis the risk of distal deep vein thrombosis was not significantly different [RR 1.33 (0.45 to 3.84)].

###### Injectable Low Molecular Weight Heparins Versus no Prophylaxis

Six trials evaluated the impact of injectable low molecular weight heparins versus no prophylaxis on distal deep vein thrombosis in patients who had major orthopedic surgery.36,42,44,47,52,135 In patients who received injectable low molecular weight heparins versus no prophylaxis the risk of distal deep vein thrombosis was significantly decreased [RR 0.52 (0.37 to 0.75), NNT 9 to 30] (Appendix G Figure 45). Statistical heterogeneity and publication bias were not detected (I^2^=0 percent, Egger's p-value=0.892).

###### Injectable Unfractionated Heparins Versus no Prophylaxis

No randomized controlled trials evaluated the impact of injectable unfractionated heparins versus no prophylaxis in patients undergoing major orthopedic surgery on this outcome.

###### Injectable or Oral Factor Xa Inhibitors Versus no Prophylaxis

One comparison from the randomized controlled trial by Yokote and colleagues in 2011 evaluated the impact of injectable or oral factor Xa inhibitors versus no prophylaxis in patients who had major orthopedic surgery on distal deep vein thrombosis. In this trial, patients who had total hip replacement received either fondaparinux 2.5mg daily or placebo. The use of concurrent elastic stockings and compression devices was allowed therefore this trial was not considered a trial comparing pharmacologic prophylaxis versus truly no prophylaxis. In patients who received injectable or oral factor Xa inhibitors versus no prophylaxis, the risk of distal deep vein thrombosis were not significantly different [RR 0.99 (0.35 to 2.80)]. Statistical heterogeneity could not be evaluated because there was only one trial available.

###### Injectable or Oral Direct Thrombin Inhibitors Versus no Prophylaxis

No randomized controlled trials evaluated the impact of injectable or oral direct thrombin inhibitors versus no prophylaxis in patients who had major orthopedic on this outcome.

###### Oral Vitamin K Antagonists Versus no Prophylaxis

No randomized controlled trials evaluated the impact of oral vitamin K antagonists versus no prophylaxis in patients who had major orthopedic on this outcome.

###### Mechanical Prophylaxis Versus no Prophylaxis

One randomized controlled trial by Fordyce and colleagues in 1992 evaluated the impact of mechanical prophylaxis versus no prophylaxis on distal deep vein thrombosis in patients who had major orthopedic surgery.37 In this trial, patients who had total hip replacement surgery received either prophylaxis with a venous foot pump or no prophylaxis, although patients in both groups also received graduated compression stockings. In patients who received mechanical prophylaxis versus no prophylaxis, the risk of distal deep vein thrombosis was not significantly different [RR 0.68 (0.14 to 3.26)].

Subgroup analyses were not possible because only one trial was available. No randomized controlled trials evaluated the impact of either graduated compression stockings or intermittent pneumatic compression devices versus no prophylaxis in patients who had major orthopedic surgery.

##### Major Bleeding

###### Pharmacologic Prophylaxis Versus no Prophylaxis

Eight randomized controlled trials evaluated the impact of pharmacologic prophylaxis versus no prophylaxis on major bleeding in patients who had major orthopedic surgery.38,41,44,49,53,132,135 One trial by Yokote, one trial by Powers and three trials by Fuji and colleagues each included two separate comparisons.38,53,132,135 The trials by Yokote and Kim were excluded from the analysis because no events occurred in either group.41,135 In patients who received pharmacologic prophylaxis versus no prophylaxis the risk of major bleeding was not significantly different [RR 0.74 (0.36 to 1.51)] (Appendix G Figure 46). Statistical heterogeneity and publication bias were not detected (I^2^=0 percent, Egger's p-value=0.707).

When limiting to trials that compared pharmacologic prophylaxis to truly no prophylaxis, four trials remained.41,49,132 The trial by Powers and colleagues included two separate comparisons.132 The trial by Kim and colleagues was excluded from the analysis because no events occurred in either group.41 In patients who received pharmacologic prophylaxis versus truly no prophylaxis the odds of major bleeding were not significantly different [OR 0.53 (0.17 to 1.64)] (Appendix G Figure 47). Statistical heterogeneity was not detected (I^2^=0 percent). When limiting the original analysis to trials published from 2001-present; four trials remained with the trial by Yokote and three trials by Fuji and colleagues including two separate comparisons.38,53,135 The trial by Yokote was excluded from the analysis because no events occurred in the groups compared. In patients who received pharmacologic prophylaxis versus no prophylaxis, the risk of major bleeding was not significantly different [RR 0.87 (0.31 to 2.45)] (Appendix G Figure 48). Statistical heterogeneity was not detected (I^2^=0 percent).

When limiting the original analysis to total hip replacement surgery, five trials remained, with the trials by Yokote and by Fuji and colleagues providing two separate comparisons.38,41,44,49,135 The trials by Yokote and Kim and colleagues were excluded from the analysis because no events occurred in either group. In patients who received pharmacologic prophylaxis versus no prophylaxis, the odds of major bleeding were not significantly different [OR 1.61 (0.44 to 5.83)] (Appendix G Figure 49). Statistical heterogeneity was not detected (I^2^=0 percent). When limiting the original analysis to total knee replacement surgery, two trials remained by Fuji and colleagues and both trials provided two separate comparisons.38,53 In patients who received pharmacologic prophylaxis versus no prophylaxis, the risk of major bleeding was not significantly different [RR 0.59 (0.18 to 1.95)] (Appendix G Figure 50). Statistical heterogeneity was not detected (I^2^=0 percent). When limiting the original analysis to hip fracture surgery, one trial by Powers and colleagues remained and provided two separate comparisons.132 In patients who received pharmacologic prophylaxis versus no prophylaxis, the risk of major bleeding were not significantly different [RR 0.55 (0.12 to 2.51)] (Appendix G Figure 51). Statistical heterogeneity was not detected (I^2^=0 percent).

Subgroup analysis based on age, gender and ethnicity were not possible because no randomized controlled trials reported data based on these subgroups.

One controlled observational study evaluated the impact of pharmacologic prophylaxis versus no prophylaxis on major bleeding.150 This study evaluated patients who had total hip or knee replacement or hip fracture surgery and included two comparisons; enoxparin versus no prophylaxis and fondaparinux versus no prophylaxis.150 There was no significant difference in major bleeding in patients who received enoxaparin versus no prophylaxis (1.1 percent versus 0.9 percent, p=0.793) and in patients who received fondaparinux versus no prophylaxis (0.0 percent versus 0.9 percent, p=0.976).

###### Oral Antiplatelet Agents Versus no Prophylaxis

Two randomized controlled trials evaluated the impact of oral antiplatelet agents versus no prophylaxis on major bleeding in patients undergoing major orthopedic surgery.41,132 The trial by Kim and colleagues was excluded from the analysis because no events occurred in either group, leaving the trial by Powers and colleagues. In this trial, in patients who received pharmacologic prophylaxis versus no prophylaxis, the odds of major bleeding were not significantly different [OR 0.24 (0.05 to 1.22)].

###### Injectable Low Molecular Weight Heparins Versus no Prophylaxis

Five randomized controlled trials evaluated the impact of injectable low molecular weight heparins versus no prophylaxis on major bleeding in patients who had major orthopedic surgery with the trials by Fuji and colleagues including two separate comparisons.38,44,49,53,135 One trial by Yokote and colleagues was excluded from the analysis because no events occurred in either group. In patients who received pharmacologic prophylaxis versus no prophylaxis, the risk of major bleeding was not significantly different [RR 0.78 (0.29 to 2.08)] (Appendix G Figure 52). Statistical heterogeneity and publication bias were not detected (I^2^=0 percent, Egger's p-value=0.275).

One controlled observational study evaluated the impact of injectable low molecular weight heparin versus no prophylaxis and the results have been previously described above.150

###### Injectable Unfractionated Heparins Versus no Prophylaxis

No randomized controlled trials evaluated the impact of injectable unfractionated heparins versus no prophylaxis in patients undergoing major orthopedic surgery on this outcome.

###### Injectable or Oral Factor Xa Inhibitors Versus no Prophylaxis

One comparison from the randomized controlled trial by Yokote and colleagues in 2011 evaluated the impact of injectable or oral factor Xa inhibitors versus no prophylaxis in patients who had major orthopedic surgery on major bleeding. However the risk of major bleeding could not be calculated because no events occurred in the groups compared.135

One controlled observational study evaluated the impact of injectable or oral factor Xa inhibitors versus no prophylaxis and the results have been previously described above.150

###### Injectable or Oral Direct Thrombin Inhibitors Versus no Prophylaxis

One randomized controlled trial evaluated the impact of oral direct thrombin inhibitors versus no prophylaxis on major bleeding in patients who had major orthopedic surgery and included two separate comparisons.53 In patients who received oral direct thrombin inhibitors versus no prophylaxis the risk of major bleeding was not significantly different [RR 0.96 (0.09 to 10.73)] (Appendix G Figure 53). Statistical heterogeneity and publication bias could not be calculated because of too few studies.

###### Oral Vitamin K Antagonists Versus no Prophylaxis

One randomized controlled trial evaluated the impact of oral vitamin K antagonists versus no prophylaxis on major bleeding in patients undergoing major orthopedic surgery.132 In patients who received oral vitamin K antagonist prophylaxis versus no prophylaxis the risk of major bleeding was not significantly different [RR 0.97 (0.29 to 3.19)].

###### Mechanical Prophylaxis Versus no Prophylaxis

No randomized controlled trials or controlled observational studies evaluated the impact of mechanical prophylaxis versus no prophylaxis in patients who had major orthopedic surgery on this outcome.

##### Major Bleeding Leading to Reoperation

###### Pharmacologic Prophylaxis Versus no Prophylaxis

Two randomized controlled trials evaluated the impact of pharmacologic prophylaxis versus no prophylaxis on major bleeding leading to reoperation in patients who had major orthopedic surgery on this outcome and the trial by Fuji and colleagues included two separate comparisons.44,53 The trial by Samama and colleagues and the comparison of dabigatran 150mg versus placebo from the trial by Fuji and colleagues were excluded from the analysis because no events occurred in the groups compared. The comparison of dabigatran 220mg versus placebo from the trial by Fuji and colleagues which evaluated patients who had total knee replacement surgery remained. In this trial, patients were also allowed to receive elastic compression stockings. In this comparison, in patients who received pharmacologic prophylaxis versus no prophylaxis the odds of major bleeding leading to reoperation were not significantly different [OR 7.11 (0.14 to 358.50)].

Subgroup analysis limited to trials which compared pharmacologic prophylaxis to truly no prophylaxis was not possible since both trials allowed the use of elastic stockings.44,53 When limiting the original analysis to trials published from 2001- present one trial remained and included two separate comparisons.53 One comparison was excluded from the analysis because no events occurred leaving the second comparison of dabigatran 220mg versus no prophylaxis. In this comparison, in patients who received pharmacologic prophylaxis versus no prophylaxis the odds of major bleeding leading to reoperation were not significantly different [OR 7.11 (0.14 to 358.50)]. This is also the same result that is obtained when limiting the original analysis to total knee replacement surgery. Subgroup analysis based on total hip replacement was not possible because one trial remained and no events occurred in the groups compared.44 Subgroup analysis limited to hip fracture surgery was not possible because none of the studies were conducted in this surgical population.

Subgroup analysis based on age, gender or ethnicity was not possible because none of the randomized controlled trials reported data based on these subgroups.

###### Oral Antiplatelet Agents Versus no Prophylaxis

No randomized controlled trials evaluated the impact of oral antiplatelet agents versus no prophylaxis in patients undergoing major orthopedic surgery on this outcome.

###### Injectable low Molecular Weight Heparins Versus no Prophylaxis

One randomized controlled trial evaluated the impact of injectable low molecular weight heparins versus no prophylaxis on major bleeding leading to reoperation in patients who had major orthopedic surgery.44 However the risk of major bleeding leading to reoperation could not be calculated because no events occurred in the groups compared.

###### Injectable Unfractionated Heparins Versus no Prophylaxis

No randomized controlled trials evaluated the impact of injectable unfractionated heparins versus no prophylaxis in patients undergoing major orthopedic surgery on this outcome.

###### Injectable or Oral Factor Xa Inhibitors Versus no Prophylaxis

No randomized controlled trials evaluated the impact of injectable or oral factor Xa inhibitors versus no prophylaxis on this outcome.

###### Injectable or Oral Direct Thrombin Inhibitors Versus no Prophylaxis

One randomized controlled trial evaluated the impact of injectable or oral direct thrombin inhibitors versus no prophylaxis on major bleeding leading to reoperation in patients who had major orthopedic surgery and included two separate comparisons.53 One comparison was excluded from the analysis because no events occurred leaving the second comparison of dabigatran 220mg versus no prophylaxis. In this comparison, in patients who received oral direct thrombin inhibitors versus no prophylaxis the risk of major bleeding leading to reoperation was not significantly different [OR 7.11 (0.14 to 358.50)].

###### Oral Vitamin K Antagonists Versus no Prophylaxis

No randomized controlled trials or controlled observational studies evaluated the impact of oral vitamin K antagonists versus no prophylaxis on this outcome.

###### Mechanical Prophylaxis Versus no Prophylaxis

No randomized controlled trials or controlled observational studies evaluated the impact of mechanical prophylaxis versus no prophylaxis in patients who had major orthopedic surgery on this outcome.

##### Minor Bleeding

###### Pharmacologic Prophylaxis Versus no Prophylaxis

Six randomized controlled trials evaluated the impact of pharmacologic prophylaxis versus no prophylaxis on minor bleeding in patients who had major orthopedic surgery, with one trial by Yokote and three trials by Fuji and colleagues each contributing two separate comparisons.38,44,49,53,135 In patients who received pharmacologic prophylaxis versus no prophylaxis the risk of minor bleeding was significantly increased [RR 1.67 (1.18 to 2.38), NNH 30 to 75] (Figure 6). Statistical heterogeneity was not detected, but publication was detected for studies in which the risk of bleeding was decreased (I^2^=0 percent, Egger's p-value=0.005).

Figure 6 Impact of pharmacologic prophylaxis versus no prophylaxis on minor bleeding in patients who had major orthopedic surgery

I^2^: 0 percent

Egger's p-value: 0.005

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of pharmacologic prophylaxis versus no prophylaxis on minor bleeding in patients who had major orthopedic surgery. Six trials were included in the analysis with one trial by Yokote in 2011 and three trials by Fuji and colleagues each contributing to two separate comparisons presented individually here. The first trial by Yokote and colleagues in 2011 inlcuded two separate comparisons. The first comparison provided a relative risk of 2.93 with 95 percent confidence interval of 0.49 to 18.32. Thes econd comparison provided a relative risk of 3.42 with 95 percent confidence interval of 0.58 to 21.06. The second trial by Fuji and colleagues in 2010 provided two separate comparisons. The first comparison provided a relative risk of 1.97 with a 95 percent confidence interval of 0.63 to 6.37. The second comparison provided a relative risk of 1.44 with a 95 percent confidence interval of 0.44 to 4.83. The third trial by Fuji and colleagues in 2008 provided two separate comparisons. The first comparison provided a relative risk of 3.47 with a 95 percent confidence interval of 0.59 to 21.39. The second comparison provided a relative risk of 1.94 with a 95 percent confidence interval of 0.30 to 12.80. The fourth trial by Fuji and colleagues in 2008 provided two separate comparisons. The first comparison provided a relative risk of 1.47 with a 95 percent confidence interval of 0.36 to 6.23. The second comparison provided a relative risk of 2.34 with a 95 percent confidence interval of 0.62 to 9.33. The fifth trial by Samama and colleagues in 1997 provided a relative risk of 1.47 with a 95 percent confidence interval of 0.94 to 2.31. The sixth trial by Turpie and colleagues in 1996 provided a relative risk of 3.00 with a 95 percent confidence interval of 0.25 to 36.16. The combined effect of these six trials showed a relative risk of 1.68 with a 95 percent confidence interval of 1.18 to 2.38. The I-squared value was 0 percent and the Egger's p-value was 0.005.

When limiting the original analysis to trials that compared pharmacologic prophylaxis to truly no prophylaxis, one trial remained.49 In patients who received pharmacologic prophylaxis versus truly no prophylaxis the odds of minor bleeding were not significantly different [OR 7.39 (0.15 to 372.38)]. When limiting the original analysis to trials published from 2001-present; one trial by Yokote and three trials by Fuji and colleagues remained and all four trials provided two separate comparisons.38,53,135 In patients who received pharmacologic prophylaxis versus no prophylaxis the risk of minor bleeding was significantly increased [RR 2.04 (1.16 to 3.62), NNH 20 to 49] (Appendix G Figure 54). Statistical heterogeneity was not detected (I^2^=0 percent). When limiting the original analysis to trials that compared pharmacologic prophylaxis to no prophylaxis in patients undergoing total hip replacement surgery, four trials remained, with the trial by Fuji and colleagues providing two separate comparisons.38,44,49 In patients who received pharmacologic prophylaxis versus no prophylaxis the risk of minor bleeding was significantly increased [RR 1.65 (1.09 to 2.48), NNH 6 to 154] (Appendix G Figure 55). Statistical heterogeneity was not detected (I^2^=0 percent). When limiting the original analysis to trials that compared pharmacologic prophylaxis to no prophylaxis in patients undergoing total knee replacement surgery, two trials remained, with both the trials by Fuji and colleagues providing two separate comparisons.38,53 In patients who received pharmacologic prophylaxis versus no prophylaxis the risk of minor bleeding was not significantly different [RR 1.77 (0.89 to 3.49)] (Appendix G Figure 56). Statistical heterogeneity was not detected (I^2^=0 percent). Subgroup analysis based on hip fracture surgery was not possible because no trials evaluated this surgical population.

Subgroup analysis based on age, gender and ethnicity were not possible because no randomized controlled trials reported data based on these subgroups.

###### Oral Antiplatelet Agents Versus no Prophylaxis

No randomized controlled trials evaluated the impact of oral antiplatelet agents versus no prophylaxis in patients undergoing major orthopedic surgery on this outcome.

###### Injectable Low Molecular Weight Heparins Versus no Prophylaxis

Five randomized controlled trials evaluated the impact of injectable low molecular weight heparins versus no prophylaxis on minor bleeding in patients who had major orthopedic surgery.38,44,49,135 The two trials by Fuji and colleagues provided two separate comparisons. In patients who received pharmacologic prophylaxis versus no prophylaxis the risk of minor bleeding was significantly increased [RR 1.66 (1.13 to 2.44) NNH 6 to 152] (Appendix G Figure 57). Statistical heterogeneity was not detected, but publication bias was detected for studies in which the risk of minor bleeding was decreased (I^2^=0 percent, Egger's p-value=0.029).

###### Injectable Unfractionated Heparins Versus no Prophylaxis

No randomized controlled trials evaluated the impact of injectable unfractionated heparins versus no prophylaxis in patients undergoing major orthopedic surgery on this outcome.

###### Injectable or Oral Factor Xa Inhibitors Versus no Prophylaxis

One comparison from the randomized controlled trial by Yokote and colleagues in 2011 evaluated the impact of injectable or oral factor Xa inhibitors versus no prophylaxis in patients who had major orthopedic surgery on minor bleeding. In this trial, patients who had total hip replacement surgery received either fondaparinux 2.5mg daily or placebo. The use of concurrent elastic stockings and compression devices was allowed therefore this trial was not considered a trial comparing pharmacologic prophylaxis versus truly no prophylaxis. In patients who received injectable or oral factor Xa inhibitors versus no prophylaxis, the odds of minor bleeding were not significantly different [OR 3.21 (0.84 to 12.24)]. Statistical heterogeneity and publication bias could not be evaluated because only one trial was available.

###### Injectable or Oral Direct Thrombin Inhibitors Versus no Prophylaxis

One randomized controlled trial evaluated the impact of oral direct thrombin inhibitors versus no prophylaxis on minor bleeding in patients who had major orthopedic surgery and included two separate comparisons.53 In patients who received oral direct thrombin inhibitors versus no prophylaxis the odds of minor bleeding were not significantly different [OR 1.67 (0.73 to 3.84)] (Appendix G Figure 58). Statistical heterogeneity and publication bias could not be calculated because of too few studies.

###### Oral Vitamin K Antagonists Versus no Prophylaxis

No randomized controlled trials evaluated the impact of oral vitamin K antagonists versus no prophylaxis in patients who had major orthopedic surgery on this outcome.

###### Mechanical Prophylaxis Versus no Prophylaxis

No randomized controlled trials or controlled observational studies evaluated the impact of mechanical prophylaxis versus no prophylaxis in patients who had major orthopedic surgery on this outcome.

##### Surgical Site Bleeding

###### Pharmacologic Prophylaxis Versus no Prophylaxis

No randomized controlled trials or controlled observational studies evaluated the impact of pharmacologic prophylaxis versus no prophylaxis in patients who had major orthopedic surgery on this outcome.

###### Mechanical Prophylaxis Versus no Prophylaxis

No randomized controlled trials or controlled observational studies evaluated the impact of mechanical prophylaxis versus no prophylaxis in patients who had major orthopedic surgery on this outcome.

##### Bleeding Leading to Infection

###### Pharmacologic Prophylaxis Versus no Prophylaxis

No randomized controlled trials or controlled observational studies evaluated the impact of pharmacologic prophylaxis versus no prophylaxis in patients who had major orthopedic surgery on this outcome.

###### Mechanical Prophylaxis Versus no Prophylaxis

No randomized controlled trials or controlled observational studies evaluated the impact of mechanical prophylaxis versus no prophylaxis in patients who had major orthopedic surgery on this outcome.

##### Bleeding Leading to Transfusion

###### Pharmacologic Prophylaxis Versus no Prophylaxis

One randomized controlled trial evaluated the impact of pharmacologic prophylaxis versus no prophylaxis on bleeding leading to transfusion in patients who had major orthopedic surgery and included two comparisons.53 This trial evaluated patients who had total knee replacement and randomized patients to one of three groups; dabigatran 150mg daily, dabigatran 220mg daily or placebo. Patients were also allowed to receive elastic compression stockings. The comparison of dabigatran 150mg versus no prophylaxis was excluded from the analysis because no events occurred in the groups compared, leaving the dabigatran 220mg versus no prophylaxis comparison. In this comparison, in patients who received pharmacologic prophylaxis versus no prophylaxis the odds of bleeding leading to transfusion were not significantly different [OR 7.11 (0.14 to 358.50)]. Statistical heterogeneity and publication bias could not be calculated because of too few studies.

Subgroup analyses were not possible because only one trial was available. No randomized controlled trials evaluated the impact of prophylaxis with oral antiplatelet agents, injectable low molecular weight heparins, unfractionated heparin, injectable or oral factor Xa inhibitors, or vitamin K antagonists versus no prophylaxis in patients who had major orthopedic surgery on this outcome.

One controlled observational study evaluated the impact of pharmacologic prophylaxis versus no prophylaxis on bleeding leading to transfusion in patients who had major orthopedic surgery.146 This study evaluated patients who had total knee replacement surgery and compared warfarin versus no prophylaxis. In patients who received warfarin versus no prophylaxis the risk of bleeding leading to transfusion was not significantly different (0.1 percent versus 0 percent, p=0.921).

###### Mechanical Prophylaxis Versus no Prophylaxis

No randomized controlled trials or controlled observational studies evaluated the impact of mechanical prophylaxis versus no prophylaxis in patients who had major orthopedic surgery on this outcome.

##### Heparin-Induced Thrombocytopenia

###### Pharmacologic Prophylaxis Versus no Prophylaxis

No randomized controlled trials or controlled observational studies evaluated the impact of pharmacologic prophylaxis versus no prophylaxis in patients who had major orthopedic surgery on this outcome.

###### Mechanical Prophylaxis Versus no Prophylaxis

No randomized controlled trials or controlled observational studies evaluated the impact of mechanical prophylaxis versus no prophylaxis in patients who had major orthopedic surgery on this outcome.

##### Discomfort

###### Pharmacologic Prophylaxis Versus no Prophylaxis

No randomized controlled trials or controlled observational studies evaluated the impact of pharmacologic prophylaxis versus no prophylaxis in patients who had major orthopedic surgery on this outcome.

###### Mechanical Prophylaxis Versus no Prophylaxis

No randomized controlled trials or controlled observational studies evaluated the impact of mechanical prophylaxis versus no prophylaxis in patients who had major orthopedic surgery on this outcome.

##### Readmission

###### Pharmacologic Prophylaxis Versus no Prophylaxis

No randomized controlled trials evaluated the impact of pharmacologic prophylaxis versus no prophylaxis in patients who had major orthopedic surgery on this outcome.

One controlled observational study evaluated the impact of pharmacologic prophylaxis versus no prophylaxis on readmission in patients who had major orthopedic surgery.146 This study evaluated patients who had total knee replacement surgery and compared warfarin versus no prophylaxis. No statistically significant difference in readmission rate was observed when comparing patients who received warfarin to those who received control (1.8 percent versus 0.9 percent, p=0.171). The reasons reported for readmission in the control group included nonfatal pulmonary embolism, superficial wound infection, and deep wound infection and those reported for the warfarin group included superficial wound infection, deep wound infection, swelling without signs of infection, myocardial infarction, and angina.

###### Mechanical Prophylaxis Versus no Prophylaxis

No randomized controlled trials or controlled observational studies evaluated the impact of mechanical prophylaxis versus no prophylaxis in patients who had major orthopedic surgery on this outcome.

##### Reoperation

###### Pharmacologic Prophylaxis Versus no Prophylaxis

No randomized controlled trials evaluated the impact of pharmacologic prophylaxis versus no prophylaxis in patients who had major orthopedic surgery on this outcome.

One controlled observational study evaluated the impact of pharmacologic prophylaxis versus no prophylaxis on reoperation in patients who had major orthopedic surgery.146 This study evaluated patients who had total knee replacement surgery and compared warfarin versus no prophylaxis. Patients who received warfarin prophylaxis had a significantly higher rate of reoperation compared with patients who received no prophylaxis (1.1 percent versus 0.3 percent, p < 0.01).

###### Mechanical Prophylaxis Versus no Prophylaxis

No randomized controlled trials or controlled observational studies evaluated the impact of mechanical prophylaxis versus no prophylaxis in patients who had major orthopedic surgery on this outcome.

#### Strength of Evidence and Applicability of the Body of Evidence

When comparing pharmacologic prophylaxis to no prophylaxis in Key Question 4, there was high strength of evidence that pharmacologic prophylaxis decreased the risk of proximal or of distal deep vein thrombosis and that there was a signficant increase in the risk of minor bleeding. There was moderate strength of evidence that the risk of deep vein thrombosis and asymptomatic deep ven thrombosis were decreased, and that the risk of symptomatic deep vein thrombosis, mortality, or major bleeding were no different. Strength of evidence was low that there was no difference in the risk of pulmonary embolism or nonfatal pulmonary embolism and that there was a decrease in the risk of major venous thromboembolism and insufficient for all other outcomes. When comparing mechanical prophylaxis to no prophylaxis, all outcomes were rated as insufficient due to the paucity of data for this comparison.

For Key Question 4 the overall applicability was often limited because one or two of the major orthopedic surgeries were not evaluated, duration of followup was inadequate to evaluate the given outcome, and many trials were conducted outside of the United States and sometimes represented a majority of the available data.

## Key Question 5

In patients undergoing major orthopedic surgery (total hip or knee replacement, hip fracture surgery), what is the comparative efficacy between classes of agents on outcomes: symptomatic objectively confirmed venous thromboembolism, major venous thromboembolism, pulmonary embolism, fatal pulmonary embolism, nonfatal pulmonary embolism, post thrombotic syndrome, mortality, mortality due to bleeding, deep vein thrombosis (asymptomatic or symptomatic, proximal or distal deep vein thrombosis), asymptomatic deep vein thrombosis, symptomatic deep vein thrombosis, proximal deep thrombosis, distal deep vein thrombosis, major bleeding, major bleeding leading to reoperation, minor bleeding, surgical site bleeding, bleeding leading to infection, bleeding leading to transfusion, heparin induced thrombocytopenia, discomfort, readmission, and reoperation? Classes include oral antiplatelet agents, injectable low molecular weight heparins, injectable unfractionated heparin, injectable or oral factor Xa inhibitors, injectable or oral direct thrombin inhibitors, oral vitamin K antagonists, and mechanical interventions.

### Key Points

- Although no difference was found in the base case analysis, when patients with total hip replacement were evaluated separately, injectable low molecular weight heparin agents had significantly fewer objectively confirmed symptomatic venous thromboembolism events versus injectable or oral factor Xa inhibitors.
- Injectable low molecular weight heparin agents had significantly fewer pulmonary embolism events versus injectable unfractionated heparin [OR 0.48 (0.24 to 0.95)].
  ○ Injectable low molecular weight heparin agents had significantly fewer pulmonary embolism events versus injectable unfractionated heparin in total hip replacement surgery while in hip fracture surgery; injectable low molecular weight heparins had significantly higher pulmonary embolism events versus injectable unfractionated heparin.
- In a controlled observational study, oral vitamin K antagonists had significantly fewer fatal pulmonary embolism events versus oral antiplatelet agents.
  ○ In the only available randomized controlled trial, the same direction of effect was found but this was not significant.
- Although there was no significant difference between groups at preventing nonfatal pulmonary embolism, injectable low molecular weight heparin was statistically superior versus injectable unfractionated heparin in total hip replacement surgery but statistically inferior in hip fracture surgery.
  ○ The higher level of statistical heterogeneity in the base case analysis was likely due to the type of surgery.
- Although there was no significant difference between groups at preventing nonfatal pulmonary embolism, injectable low molecular weight heparin was statistically superior to injectable or oral factor Xa inhibitors in total hip replacement surgery.
- While no differences in mortality occurred in the available trials, several observational studies found significant differences.
  ○ In a controlled observational study, oral antiplatelet agents had significantly higher mortality versus oral vitamin K antagonists in total hip or total knee replacement surgeries in one study but another study limited to total knee replacement found no significant differences.
  ○ In a controlled observational study, injectable low molecular weight heparin agents had significantly higher mortality versus injectable or oral factor Xa inhibitors in total hip, knee replacement and hip fracture surgeries. A second study did not find a significant difference between the two groups, also evaluating all three surgery populations.
  ○ In a controlled observational study, the use of an injectable factor Xa inhibitor was associated with a lower mortality than injectable unfractionated heparin.
- Oral antiplatelet agents had significantly more deep venous thrombosis events versus mechanical prophylaxis [RR 1.63 (1.11 to 2.39)].
  ○ Oral antiplatelet agents had significantly more deep venous thrombosis events versus mechanical prophylaxis in total knee replacement surgery.
- Injectable low molecular weight heparin agents had significantly fewer deep venous thrombosis events versus unfractionated heparin [RR 0.80 (0.65 to 0.99)].
  ○ Injectable low molecular weight heparin agents had significantly fewer deep venous thrombosis events versus injectable unfractionated heparin in total hip and total knee replacement surgeries.
  ○ Injectable low molecular weight heparin agents had significantly more deep venous thrombosis events versus injectable unfractionated heparin in hip fracture surgery.
  ○ No differences in efficacy between injectable low molecular weight or injectable unfractionated heparin was seen based on age, gender, or African American race but enoxaparin 30mg, but not 40mg, was superior to unfractionated heparin in preventing deep venous thrombosis in Caucasians.
- Injectable low molecular weight heparins had significantly more deep venous thrombosis events versus injectable or oral factor Xa inhibitors [RR 1.99 (1.57 to 2.51)].
  ○ In studies conducted from 2001-present, the same results occurred.
  ○ Injectable low molecular weight heparins had significantly more deep venous thrombosis events versus injectable or oral factor Xa inhibitors in total hip replacement, total knee replacement, and hip fracture surgeries.
- Injectable low molecular weight heparin agents had significantly more deep venous thrombosis events versus injectable or oral direct thrombin inhibitors [RR 1.39 (1.15 to 1.68)].
- Injectable low molecular weight heparins had significantly fewer deep venous thrombosis events versus oral vitamin K antagonists [RR 0.66 (0.55 to 0.79)].
  ○ There were higher levels of statistical heterogeneity but the direction of effect was similar in all trials.
  ○ Injectable low molecular weight heparins had significantly fewer deep venous thrombosis events versus oral vitamin K antagonists in trials conducted from 2001-present, total hip replacement and total knee replacement surgeries.
- Injectable unfractionated heparin had significantly more deep venous thrombosis events versus injectable or oral direct thrombin inhibitors [RR 2.31 (1.34 to 4.00)].
  ○ Injectable unfractionated heparin had significantly more deep venous thrombosis events versus injectable or oral direct thrombin inhibitors in total hip replacement.
- Injectable unfractionated heparin had significantly more deep venous thrombosis events versus mechanical prophylaxis.
- Injectable low molecular weight heparin agents had significantly fewer asymptomatic deep vein thrombosis events versus oral vitamin K antagonists.
  ○ The same results occurred in trials published from 2001-present and in total knee replacement.
- While no significant differences were seen in the base case analysis, injectable low molecular weight heparin agents had significantly fewer symptomatic deep venous thrombosis events versus injectable or oral factor Xa inhibitors in total hip replacement surgery.
- Injectable low molecular weight heparin agents had significantly fewer proximal deep venous thrombosis events versus injectable unfractionated heparin [RR 0.60 (0.38 to 0.93)].
  ○ Injectable low molecular weight heparin agents had significantly fewer proximal deep venous thrombosis events versus injectable unfractionated heparin in total hip replacement surgery and total knee replacement surgery.
- Injectable low molecular weight heparin agents had significantly more proximal deep venous thrombosis events versus injectable or oral factor Xa inhibitors [OR 2.19 (1.52 to 3.16)].
  ○ The same results occurred when limited to studies from 2001-present.
  ○ There was a higher level of statistical heterogeneity but three of four trials had the same direction of effect. Heterogeneity could not be readily explained by the year of publication or type of surgery.
  ○ Injectable low molecular weight heparin agents had significantly more proximal deep venous thrombosis events versus injectable or oral factor Xa inhibitors in total knee replacement surgery and hip fracture surgery with a trend in the same direction with total hip replacement surgery.
- While no significant differences occurred in the base case analysis, injectable low molecular weight heparin agents had significantly more proximal deep venous thrombosis events versus injectable or oral direct thrombin inhibitors in total hip replacement surgery.
- Injectable low molecular weight heparin agents did not significantly impact the risk of proximal deep venous thrombosis versus oral vitamin K antagonists with borderline significance [RR 0.63 (0.37 to 1.00)].
- Injectable unfractionated heparin had significantly more proximal deep venous thrombosis events versus injectable or oral direct thrombin inhibitors [OR 4.74 (2.99 to 7.49)].
  ○ Injectable unfractionated heparin had significantly more proximal deep venous thrombosis events versus injectable or oral direct thrombin inhibitors in total hip replacement surgery.
- Oral vitamin K antagonists had significantly fewer proximal deep venous thrombosis events versus mechanical prophylaxis [RR 0.34 (0.16 to 0.73)].
  ○ Oral vitamin K antagonists had significantly fewer proximal deep venous thrombosis events versus mechanical prophylaxis in total hip replacement surgery.
- Oral antiplatelet agents had significantly more distal deep venous thrombosis events versus mechanical prophylaxis.
  ○ Oral antiplatelet agents had significantly more distal deep venous thrombosis events versus mechanical prophylaxis in total knee replacement surgery.
- Injectable low molecular weight heparin agents had significantly more distal deep venous thrombosis events versus injectable or oral factor Xa inhibitors [RR 2.02 (1.65 to 2.48)].
  ○ The same result occurred when limiting to studies from 2001-present.
  ○ Injectable low molecular weight heparin agents had significantly more distal deep venous thrombosis events versus injectable or oral factor Xa inhibitors in total hip replacement, total knee replacement, and hip fracture surgeries.
- Injectable low molecular weight heparins had significantly fewer distal deep venous thrombosis events versus injectable or oral direct thrombin inhibitors.
  ○ The same result occurred when limiting to studies from 2001-present.
  ○ Injectable low molecular weight heparin agents had significantly fewer distal deep venous thrombosis events versus injectable or oral direct thrombin inhibitors in total knee replacement.
- Injectable low molecular weight heparin agents had significantly fewer distal deep venous thrombosis events versus oral vitamin K antagonists [RR 0.56 (0.43 to 0.73)].
  ○ The same result occurred when limiting to studies from 2001-present.
  ○ Injectable low molecular weight heparin agents had significantly fewer distal deep venous thrombosis events versus oral vitamin K antagonists in total hip replacement and total knee replacement surgeries.
- Injectable low molecular weight heparin agents had significantly less major bleeding than injectable unfractionated heparin [OR 0.57 (0.37 to 0.88)].
  ○ Injectable low molecular weight heparin agents had significantly less major bleeding than injectable unfractionated heparin in total hip replacement surgery.
- Injectable low molecular weight heparin agents had significantly less major bleeding than injectable or oral factor Xa inhibitors [OR 0.65 (0.48 to 0.89)].
  ○ The results were the same when limited to trials from 2001-present.
  ○ Injectable low molecular weight heparin agents had significantly less major bleeding than injectable or oral factor Xa inhibitors in total hip replacement surgery and total knee replacement surgery.
    – The different direction of effect between the total hip and knee replacement surgery trials versus the hip fracture surgery trials likely explains the higher level of statistical heterogeneity in the base case analysis.
- Injectable low molecular weight heparin agents had significantly more major bleeding than oral vitamin K antagonists [OR 1.92 (1.27 to 2.91)].
  ○ Injectable low molecular weight heparin agents had significantly more major bleeding than oral vitamin K antagonists in total hip replacement surgery and total knee replacement surgery.
- In the only evaluation available (a controlled observational study), major bleeding events were significantly increased in the group receiving injectable unfractionated heparin versus injectable or oral factor Xa inhibitors.
- Injectable low molecular weight heparin agents had significantly less minor bleeding than injectable or oral factor Xa inhibitors [OR 0.57 (0.35 to 0.94)].
  ○ The results were the same when limited to trials from 2001-present.
    – Injectable low molecular weight heparin agents had significantly less minor bleeding than injectable or oral factor Xa inhibitors in hip fracture surgery.
- Injectable low molecular weight heparin agents had significantly more minor bleeding than oral vitamin K antagonists [RR 1.23 (1.06 to 1.43)].
- Injectable low molecular weight heparin agents had significantly more surgical site bleeding than injectable or oral direct thrombin inhibitors.
  ○ The same results occurred when trials were limited to 2001-present.
  ○ Injectable low molecular weight heparin agents had significantly more surgical site bleeding than injectable or oral direct thrombin inhibitors in total knee replacement surgery.
- Injectable low molecular weight heparin agents had significantly more surgical site bleeding than oral vitamin K antagonists [OR 2.63 (1.31 to 5.28)].
  ○ Injectable low molecular weight heparin agents had significantly more surgical site bleeding than oral vitamin K antagonists in total hip replacement surgery.
  ○ When major surgical site bleeding was evaluated for separately, injectable low molecular weight heparin agents had significantly more major surgical site bleeding than oral vitamin K antagonists.
- Injectable low molecular weight heparin agents had significantly less heparin induced thrombocytopenia than injectable unfractionated heparin [OR 0.12 (0.03 to 0.43)].
  ○ Injectable low molecular weight heparin agents had significantly less heparin induced thrombocytopenia than injectable unfractionated heparin in total hip replacement surgery.
- Injectable low molecular weight heparin agents had significantly less discomfort than mechanical prophylaxis.
  ○ Injectable low molecular weight heparin agents had significantly less discomfort than mechanical prophylaxis in total hip replacement surgery.

### Detailed Analysis

#### Study Design and Characteristics

Forty-five randomized controlled trials (N=36,152) and three controlled observational studies (N=144,806) evaluated the comparative efficacy between classes of pharmacologic prophylaxis and mechanical methods of prophylaxis on final health, intermediate and adverse outcomes.55-58,60-69,71,73-77,79-86,88-90,93-99,101,102,104-106,132,135 All forty-five randomized controlled trials were published as full text manuscripts. Two randomized controlled trials compared oral antiplatelet agents to oral vitamin K antagonists88,132 and two trials compared oral antiplatelet agents to mechanical methods of prophylaxis.79,82 Fourteen trials compared injectable low molecular weight heparins to injectable unfractionated heparin,55,57,61-63,71,74,86,89,93,96,97,104,105 six trials compared injectable low molecular weight heparin to injectable or oral factor Xa inhibitors,58,64,83,99,106,135 five trials compared injectable low molecular weight heparins to injectable or oral direct thrombin inhibitors,65-67,73,94 seven trials compared injectable low molecular weight heparins to oral vitamin K antagonist60,75,77,80,81,84,85 and three trials compared injectable low molecular weight heparin to mechanical prophylaxis .98,101,102 Two trials compared injectable unfractionated heparin to injectable or oral direct thrombin inhibitors68,69 and one trial compared injectable unfractionated heparin to mechanical prophylaxis.95 Three trials compared oral vitamin K antagonists to mechanical prophylaxis.56,76,90

Twenty-six trials enrolled exclusively patients who had total hip replacement surgery (N=20,261),55-57,60,61,63,67-69,71,73,76,77,81,83,86,89,90,93,95-99,101,135 eleven trials enrolled patients who had total knee replacement surgery (N=8,185),58,62,66,74,75,79,84,85,94,101,106 four trials enrolled patients who had hip fracture surgery (N=2,155).64,82,105,132 and four trials enrolled patients who had either total hip replacement surgery or total knee replacement surgery (N=4,043).65,80,88,104 The earliest trial was published in 1987 while the most recent published in 2011.^57,90,135^ The duration of followup ranged from the postoperative period to 180 days. Seven randomized controlled trials reported outcomes of interest during the postdischarge period.61,69,74,80,94,97 Seventeen trials received funding from industry,56,60,61,64-67,73-75,83,85,89,94,97,99,106 six trials received funding from government and foundation,71,76,80,86,88,101 one trial received funding from industry and government,132 one trial received funding from academia and industry,81 two trials received funding from industry, government and foundation90,132 and in nineteen trials the funding source was not reported.55,57,58,62,63,68,69,77,79,82,84,93,95,96,98,102,104,105,135

The mean age of enrolled patients ranged from 52.4 years to 78.3 years. Females represented between 36.05 and 84.09 percent of the enrolled populations. The mean weight ranged from 64.2 to 89 kilograms and obesity ranged from 5.4 to 59.09 percent. Few patients enrolled had a history of venous thromboembolism ranging from 0 to 14.49 percent. Presence of varicosity ranged from no varicosity to 55 percent. The percent of patients with a history of malignancy ranged from 0 to 12.4 percent. The percent of patients who had previously undergone orthopedic surgery ranged from 4 to 52.24 percent.

Fifty-four to 100 percent of patients underwent primary surgery and the percent of patients who had cemented fixation during surgery ranged from 21.2 to 100 percent. Mean duration of surgery ranged from 59 to 172 minutes and the mean duration of anesthesia was reported by four trials with a range of 127 to 205 minutes. Use of general versus regional anesthesia varied, with general anesthesia use ranging from 0 to 100 percent of patients and regional anesthesia use also ranging from 0 to 100 percent of patients. The mean length of hospital stay was infrequently reported, and when it was ranged from 9 to 17.2 days.

Of the three observational studies, two studies compared oral antiplatelet agents to oral vitamin K antagonists144,148 and one study reported comparison between injectable low molecular weight heparin, injectable unfractionated heparin and injectable or oral factor Xa inhibitors.147 One study enrolled only patients who had total knee replacement surgery (N=93,840)148 and another evaluated two surgical procedures and reported the outcomes separately for each; total hip replacement (N=2,203) and total knee replacement surgery (N=2,050).144 The third study enrolled patients who had total hip replacement, total knee replacement, or hip fracture surgery (N=144,806).147 The most recent study was published in 2010 while the earliest study was published in 2007. The duration of followup for the studies ranged from 30 to 90 days. One study was funded by government and foundation148 while the other two did not disclose the funding source.144,147

The mean age of patients ranged from 66.4 to 71 years. Females represented between 63.0 to 65.17 percent of the enrolled populations. Other baseline characteristics were not reported. Two studies enrolled exclusively patients who had primary surgery.144,148 One study reported the surgical approach and for those who had total hip replacement, the posterior approach was used while for those who had total knee replacement the medial parapatellar approach was used.144 Median hospital length of stay was reported in one study as 3 days.148 Other procedural characteristics were not reported in these three studies.

#### Outcome Evaluations

Outcomes reported during the postdischarge period are analyzed and reported separately within the corresponding class comparison section under the respective outcome. A summary of significant differences between comparative groups for outcomes in base case and subgroup analyses is presented in Table 11 and an overall summary of results presented in Table 12.

Table 11 Significant differences between comparative groups for outcomes in base case and subgroup analyses in Key Question 5

| | ATP vs. VKA | ATP vs. Mech | LMWH vs. UFH | LMWH vs. FXA | LMWH vs. DTI | LMWH vs. VKA | LMWH vs. Mech | UFH vs. DTI | UFH vs. FXA | UFH vs. Mech | VKA vs. Mech
Final health outcomes | Base Case | ↑ Death^*^ ↑ fPE^*^ | | ↓ PE | ↑ Death^*^ | | | | | ↑ Death^*^
Final health outcomes | 2001-Present | ↑ Death^*^ ↑ fPE^*^ | | | ↑ Death^*^ | | | | | ↑ Death^*^
Final health outcomes | THR | | | ↓ PE ↓ nfPE | ↓ sVTE ↓ nfPE
Final health outcomes | TKR
Final health outcomes | HFS | | | ↑ PE ↑ nfPE
Intermediate health outcomes | Base Case | | ↑ DVT ↑ dDVT | ↓ DVT ↓ pDVT | ↑ DVT ↑ pDVT ↑ dDVT | ↑ DVT ↓ dDVT | ↓ DVT ↓ asDVT ↓ pDVT ↓ dDVT | | ↑ DVT ↑p DVT | | ↑ DVT | ↓ pDVT
Intermediate health outcomes | 2001-Present | | | | ↑ DVT ↑ pDVT ↑ dDVT | ↓ dDVT | ↓ DVT ↓ asDVT ↓ dDVT
Intermediate health outcomes | THR | | | ↓ DVT ↓ pDVT | ↑ DVT ↑ dDVT ↓ sDVT | ↑ pDVT | ↓ DVT ↓ dDVT | | ↑ DVT ↑ pDVT | | | ↓ pDVT
Intermediate health outcomes | TKR | | ↑ DVT ↑ dDVT | ↓ DVT ↓ pDVT | ↑ DVT ↑ pDVT ↑ dDVT | ↓ dDVT | ↓ DVT ↓ asDVT ↓ dDVT
Intermediate health outcomes | HFS | | | ↑ DVT | ↑ DVT ↑ pDVT ↑ dDVT
Adverse outcomes | Base Case | | | ↓ MJB ↓ HIT | ↓ MJB ↓ MNB | ↑ SSB | ↑ MJB ↑ MNB ↑ SSB | ↓ DC | | ↑ MJB^*^
Adverse outcomes | 2001-Present | | | | ↓ MJB ↓ MNB | ↑ SSB | | | | ↑ MJB^*^
Adverse outcomes | THR | | | ↓ MJB ↓ HIT | ↓ MJB | | ↑ MJB ↑ SSB | ↓ DC
Adverse outcomes | TKR | | | | ↓ MJB | ↑ SSB | ↑ MJB
Adverse outcomes | HFS | | | | ↓ MNB

asDVT = asymptomatic deep vein thrombosis; ATP = antiplatelet; DC = discomfort; dDVT = distal deep vein thrombosis; DTI = direct thrombin inhibitor; DVT = deep venous thrombosis ; fPE = fatal pulmonary embolism; FXA = factor Xa inhibitors; HFS = hip fracture surgery; HIT = heparin induced thrombocytopenia; LMWH = low molecular weight heparin; Mech = mechanical prophylaxis; MJB = major bleeding; MNB = minor bleeding; nf PE = nonfatal pulmonary embolism; OBS = data derived from a controlled observational study; pDVT = proximal deep vein thrombosis; PE = pulmonary embolism; sDVT = symptomatic deep vein thrombosis; SSB = surgical site bleeding; THR = total hip replacement; TKR = total knee replacement; UFH = unfractionated heparin; VKA = vitamin K antagonist; vs = versus

* Based on observational data.

↓ Denotes significantly fewer occurrences in group A vs. group B.

↑ Denotes significantly more occurrences in group A than group B.

Table 12 Summary of results for Key Question 5: what is the comparative efficacy and safety between classes of pharmacologic and mechanical prophylaxis methods in major orthopedic surgery?^*^

| Endpoint/Comparison | Type and Number of Studies | Pooled | Result | Statistical Heterogeneity: I^2^ (%)
Symptomatic objectively confirmed VTE | Antiplatelet versus oral VKA | 0 | --- | --- | ---
Symptomatic objectively confirmed VTE | Antiplatelet versus mechanical | 0 | --- | --- | ---
Symptomatic objectively confirmed VTE | LMWH versus UFH | 1 RCT | No | OR 0.13 (0.01 to 2.15) | NA
Symptomatic objectively confirmed VTE | LMWH versus UFH | 1 RCT | No | One RCT evaluated this outcome during the postdischarge period and showed an OR 7.54 (0.47 to 122.28) | NA
Symptomatic objectively confirmed VTE | LMWH versus factor Xa inhibitors | 5 RCTs | Yes | OR 0.70 (0.48 to 1.02) | 38.5
Symptomatic objectively confirmed VTE | - Limited to 2001-present | 5 RCTs | Yes | OR 0.70 (0.48 to 1.02) | 38.5
Symptomatic objectively confirmed VTE | - Limited to THR | 3 RCTs | Yes | OR 0.53 (0.32 to 0.87)^†^ | 0
Symptomatic objectively confirmed VTE | - Limited to TKR | 1 RCT | No | OR 1.97 (0.71 to 5.45) | NA
Symptomatic objectively confirmed VTE | - Limited to HFS | 1 RCT | No | OR 0.75 (0.37 to 1.55) | NA
Symptomatic objectively confirmed VTE | LMWH versus DTI | 0 | --- | --- | ---
Symptomatic objectively confirmed VTE | LMWH versus VKA | 2 RCTs | Yes | OR 1.00 (0.69 to 1.46) | NA
Symptomatic objectively confirmed VTE | LMWH versus VKA | 1 RCT | No | 1 trial evaluated this outcome during the postdischarge period and showed an OR 2.24 (0.65 to 7.79) | NA
Symptomatic objectively confirmed VTE | - Limited to THR | 1 RCT | No | OR 0.97 (0.66 to 1.41) | NA
Symptomatic objectively confirmed VTE | - Limited to TKR | 1 RCT | No | OR 2.71 (0.38 to 19.35) | NA
Symptomatic objectively confirmed VTE | LMWH versus mechanical | 0 | --- | --- | ---
Symptomatic objectively confirmed VTE | UFH versus DTI | 0 | --- | --- | ---
Symptomatic objectively confirmed VTE | UFH versus factor Xa inhibitor | 0 | --- | --- | ---
Symptomatic objectively confirmed VTE | UFH versus mechanical | 0 | --- | --- | ---
Symptomatic objectively confirmed VTE | VKA versus mechanical | 0 | --- | --- | ---
Major venous thromboembolism | Antiplatelet versus VKA | 0 | --- | --- | ---
Major venous thromboembolism | Antiplatelet versus mechanical | 0 | --- | --- | ---
Major venous thromboembolism | LMWH versus UFH | 0 | --- | --- | ---
Major venous thromboembolism | LMWH versus factor Xa inhibitors | 0 | --- | --- | ---
Major venous thromboembolism | LMWH versus DTI | 3 RCTs | Yes | RR 1.26 (0.98 to 1.62) | 0
Major venous thromboembolism | - Limited to 2001-present | 2 RCTs | Yes | RR 1.08 (0.78 to 1.50) | 0
Major venous thromboembolism | - Limited to THR | 2 RCTs | Yes | RR 1.28 (0.94 to 1.76) | 18.6
Major venous thromboembolism | - Limited to TKR | 1 RCT | No | RR 1.11 (0.63 to 1.96) | NA
Major venous thromboembolism | LMWH versus VKA | 0 | --- | --- | ---
Major venous thromboembolism | LMWH versus mechanical | 0 | --- | --- | ---
Major venous thromboembolism | UFH versus DTI | 0 | --- | --- | ---
Major venous thromboembolism | UFH versus factor Xa inhibitor | 0 | --- | --- | ---
Major venous thromboembolism | UFH versus mechanical | 0 | --- | --- | ---
Major venous thromboembolism | VKA versus mechanical | 0 | --- | --- | ---
Pulmonary embolism | Antiplatelet versus VKA | 1 RCT | No | OR 7.28 (0.14 to 366.83) | NA
Pulmonary embolism | Antiplatelet versus mechanical | 1 RCT | No | OR 7.09 (0.14 to 357.70) | NA
Pulmonary embolism | LMWH versus UFH | 10 RCTs | Yes | OR 0.48 (0.24 to 0.95)^†^ | 59.7
Pulmonary embolism | LMWH versus UFH | 1 RCT | No | 1 trial evaluated this outcome at the postdischarge period and showed a RR 0.13 (0.01 to 1.17) | NA
Pulmonary embolism | - Limited to 2001-present | 1 RCT | No | No events occurred in the groups compared | NA
Pulmonary embolism | - Limited to THR | 7 RCTs | Yes | OR 0.28 (0.13 to 0.62)^†^ | 0
Pulmonary embolism | - Limited to TKR | 2 RCTs | No | 1 trial had no events in the groups compared, the remaining trial showed OR 0.13 (0.01 to 2.13) | NA
Pulmonary embolism | - Limited to HFS | 1 RCT | No | OR 7.95 (1.53 to 41.29)^†^ | NA
Pulmonary embolism | LMWH versus factor Xa inhibitor | 2 RCTs | No | 1 trial had no events in the groups compared, the remaining trial showed OR 3.34 (0.58 to 19.32) | NA
Pulmonary embolism | - Limited to 2001-present | 2 RCTs | No | 1 trial had no events in the groups compared, the remaining trial showed OR 3.34 (0.58 to 19.32) | NA
Pulmonary embolism | - Limited to THR | 1 RCT | No | 1 trial had no events in the groups compared | NA
Pulmonary embolism | - Limited to TKR | 1 RCT | No | OR 3.34 (0.58 to 19.32) | NA
Pulmonary embolism | LMWH versus DTI | 3 RCTs | Yes | RR 1.18 (0.41 to 3.39) | 0
Pulmonary embolism | LMWH versus DTI | 1 RCT | No | 1 trial evaluated this outcome during the postdischarge period and showed an OR 3.89 (0.78 to 19.34) | NA
Pulmonary embolism | - Limited to 2001-present | 2 RCTs | Yes | RR 1.25 (0.35 to 4.39) | 0
Pulmonary embolism | - Limited to THR | 2 RCTs | Yes | RR 1.03 (0.32 to 3.36) | 0
Pulmonary embolism | - Limited to TKR | 1 RCT (2 comp) | Yes | RR 2.00 (0.18 to 22.02) | NA
Pulmonary embolism | LMWH versus VKA | 5 RCTs | Yes | OR 1.11 (0.57 to 2.19) | 28.7
Pulmonary embolism | LMWH versus VKA | 1 RCT | No | 1 trial evaluated this outcome during the postdischarge period and showed an OR 1.01 (0.06 to 16.14) | NA
Pulmonary embolism | - Limited to 2001-present | 2 RCTs | Yes | OR 1.96 (0.20 to 18.94) | NA
Pulmonary embolism | - Limited to THR | 2 RCTs | No | One trial had no events in the groups compared, the remaining trial showed OR 1.23 (0.58 to 2.63) | NA
Pulmonary embolism | - Limited to TKR | 3 RCTs | Yes | OR 0.75 (0.17 to 3.31) | 48.2
Pulmonary embolism | LMWH versus mechanical | 1 RCT | No | OR 0.13 (0.003 to 6.72) | NA
Pulmonary embolism | UFH versus DTI | 2 RCTs | Yes | OR 3.23 (0.56 to 18.98) | NA
Pulmonary embolism | - Limited to THR | 2 RCTs | Yes | OR 3.23 (0.56 to 18.98) | NA
Pulmonary embolism | UFH versus factor Xa inhibitor | 0 | --- | --- | ---
Pulmonary embolism | UFH versus mechanical | 0 | --- | --- | ---
Pulmonary embolism | VKA versus mechanical | 1 RCT | No | No events occurred in the groups compared | NA
Fatal pulmonary embolism | Antiplatelet versus VKA | 1 RCT, 1 OBS | No | RCT: OR 7.28 (0.14 to 366.83); observational data suggested a significantly higher percent of patients who received aspirin had a fatal pulmonary embolism than those who received warfarin | NA
Fatal pulmonary embolism | Antiplatelet versus mechanical | 0 | --- | --- | ---
Fatal pulmonary embolism | LMWH versus UFH | 10 RCTs | No | Nine trials had no events; the remaining trial showed OR 0.13 (0.003 to 6.73) | NA
Fatal pulmonary embolism | - Limited to 2001-present | 1 RCT | No | No events occurred in the groups compared | NA
Fatal pulmonary embolism | - Limited to THR | 7 RCTs | No | No events occurred in the groups compared | NA
Fatal pulmonary embolism | - Limited to TKR | 1 RCT | No | OR 0.13 (0.003 to 6.73) | NA
Fatal pulmonary embolism | - Limited to HFS | 1 RCT | No | No events occurred in the groups compared | NA
Fatal pulmonary embolism | LMWH versus factor Xa inhibitor | 5 RCTs | Yes | One trial had no events in the groups compared, the remaining trials showed OR 0.90 (0.38 to 2.13) | 0
Fatal pulmonary embolism | - Limited to 2001-present | 5 RCTs | Yes | One trial had no events in the groups compared, the remaining trials showed OR 0.90 (0.38 to 2.13) | 0
Fatal pulmonary embolism | - Limited to THR | 3 RCTs | Yes | One trial had no events in the groups compared, the remaining trial showed OR 1.00 (0.14 to 7.10) | NA
Fatal pulmonary embolism | - Limited to TKR | 1 RCT | No | OR 1.00 (0.06 to 16.01) | NA
Fatal pulmonary embolism | - Limited to HFS | 1 RCT | No | OR 0.86 (0.31 to 2.39) | NA
Fatal pulmonary embolism | LMWH versus DTI | 2 RCTs | Yes | OR 1.43 (0.08 to 24.82) | 31.7
Fatal pulmonary embolism | LMWH versus DTI | 1 RCT | No | 1 trial evaluated this outcome during the postdischarge period and showed an OR 0.14 (0.003 to 6.97) | NA
Fatal pulmonary embolism | - Limited to 2001-present | 2 RCTs | Yes | OR 1.43 (0.08 to 24.82) | 31.7
Fatal pulmonary embolism | - Limited to THR | 1 RCT (2 comp) | No | One arm of the trial had no events; the reaming arm showed OR 0.14 (0.003 to 6.91) | NA
Fatal pulmonary embolism | - Limited to TKR | 1 RCT (2 comp) | Yes | RR 4.00 (0.36 to 44.03) | NA
Fatal pulmonary embolism | LMWH versus VKA | 4 RCTs | No | Three trials had no events and 1 trial showed OR 7.29 (0.14 to 367.30) | NA
Fatal pulmonary embolism | LMWH versus VKA | 1 RCT | No | 1 trial evaluated this outcome during the postdischarge period although no events occurred | NA
Fatal pulmonary embolism | - Limited to 2001-present | 1 RCT | No | No events occurred in the groups compared | NA
Fatal pulmonary embolism | - Limited to THR | 2 RCTs | No | One trials had no events; the remaining trial showed OR 7.29 (0.14 to 367.30) | NA
Fatal pulmonary embolism | - Limited to TKR | 2 RCTs | No | No events occurred in the groups compared | NA
Fatal pulmonary embolism | LMWH versus mechanical | 2 RCTs | Yes | One trial had no events; the remaining trial showed OR 0.14 (0.01 to 2.25) | NA
Fatal pulmonary embolism | - Limited to 2001-present | 1 RCT | No | OR 0.14 (0.01 to 2.25) | NA
Fatal pulmonary embolism | - Limited to THR | 1 RCT | No | No events occurred in the groups compared | NA
Fatal pulmonary embolism | - Limited to TKR | 1 RCT | No | OR 0.14 (0.01 to 2.25) | NA
Fatal pulmonary embolism | UFH versus DTI | 2 RCTs | No | No events occurred in the groups compared | NA
Fatal pulmonary embolism | - Limited to THR | 2 RCTs | No | No events occurred in the groups compared | NA
Fatal pulmonary embolism | UFH versus factor Xa inhibitor | 0 | --- | --- | ---
Fatal pulmonary embolism | UFH versus mechanical | 0 | --- | --- | ---
Fatal pulmonary embolism | VKA versus mechanical | 1 RCT | No | No events occurred in the groups compared | NA
Nonfatal pulmonary embolism | Antiplatelet versus VKA | 1 RCT, 1 OBS | No | RCT: No events occurred in the groups compared; observational data suggest no significant difference | NA
Nonfatal pulmonary embolism | Antiplatelet versus mechanical | 0 | --- | --- | ---
Nonfatal pulmonary embolism | LMWH versus UFH | 10 RCTs | Yes | OR 0.50 (0.25 to 1.00) | 58.8
Nonfatal pulmonary embolism | LMWH versus UFH | 1 RCT | No | 1 trial evaluated this outcome during the postdischarge period and showed a RR 0.13 (0.01 to 1.17) | NA
Nonfatal pulmonary embolism | - Limited to 2001-present | 1 RCT | No | No events occurred in the groups compared | NA
Nonfatal pulmonary embolism | - Limited to THR | 7 RCTs | Yes | OR 0.28 (0.13 to 0.62)^†^ | 0
Nonfatal pulmonary embolism | - Limited to TKR | 2 RCTs | No | One trial had no events; the remaining trial showed OR 0.13 (0.003 to 6.73) | NA
Nonfatal pulmonary embolism | - Limited to HFS | 1 RCT | No | OR 7.95 (1.53 to 41.29) | NA
Nonfatal pulmonary embolism | LMWH versus factor Xa inhibitor | 5 RCTs | Yes | One trial had no events in the groups compared; the remaining trials showed OR 0.68 (0.34 to 1.37) | 49.5
Nonfatal pulmonary embolism | - Limited to 2001-present | 5 RCTs | Yes | One trial had no events in the groups compared; the remaining trials showed OR 0.68 (0.34 to 1.37) | 49.5
Nonfatal pulmonary embolism | - Limited to THR | 3 RCTs | Yes | One trial had no events in the groups compared; the remaining trials showed OR 0.39 (0.16 to 0.95)^†^ | NA
Nonfatal pulmonary embolism | - Limited to TKR | 1 RCT | No | OR 1.95 (0.39 to 9.72) | NA
Nonfatal pulmonary embolism | - Limited to HFS | 1 RCT | No | OR 1.32 (0.30 to 5.81) | NA
Nonfatal pulmonary embolism | LMWH versus DTI | 2 RCTs | Yes | OR 0.93 (0.23 to 3.66) | 53.7
Nonfatal pulmonary embolism | - Limited to 2001-present | 2 RCTs | Yes | OR 0.93 (0.23 to 3.66) | 53.7
Nonfatal pulmonary embolism | - Limited to THR | 1 RCT (2 comp) | Yes | RR 1.61 (0.13 to 19.37) | NA
Nonfatal pulmonary embolism | - Limited to TKR | 1 RCT (2 comp) | No | One arm had no events; the remaining arm showed OR 0.14 (0.003 to 6.93) | NA
Nonfatal pulmonary embolism | LMWH versus VKA | 3 RCTs 1 RCT | Yes No | OR 1.00 (0.20 to 4.95) 1 trial evaluated this outcome during the postdischarge period and showed an OR 1.01 (0.06 to 16.14) | NA NA
Nonfatal pulmonary embolism | - Limited to 2001-present | 1 RCT | No | OR 7.46 (0.46 to 120.00) | NA
Nonfatal pulmonary embolism | - Limited to THR | 1 RCT (2 comp) | No | No events occurred in the groups compared | NA
Nonfatal pulmonary embolism | - Limited to TKR | 2 RCTs | Yes | OR 1.00 (0.20 to 4.95) | NA
Nonfatal pulmonary embolism | LMWH versus mechanical | 1 RCT | No | OR 0.13 (0.003 to 6.72) | NA
Nonfatal pulmonary embolism | UFH versus factor Xa inhibitor | 0 | --- | --- | ---
Nonfatal pulmonary embolism | UFH versus DTI | 2 RCTs | Yes | OR 3.27 (0.56 to 18.98) | NA
Nonfatal pulmonary embolism | - Limited to THR | 2 RCTs | Yes | OR 3.27 (0.56 to 18.98) | NA
Nonfatal pulmonary embolism | UFH versus mechanical | 0 | --- | --- | ---
Nonfatal pulmonary embolism | VKA versus mechanical | 1 RCT | No | No events occurred in the groups compared | NA
Post thrombotic Syndrome | | 0 | --- | --- | ---
Mortality | Antiplatelet versus VKA | 1 RCT, 2 OBS | No | RR 0.98 (0.32 to 3.05); observational data conflict with one study suggesting no significant difference and a second suggesting significantly higher percent of deaths in patients who received aspirin versus warfarin | NA
Mortality | Antiplatelet versus mechanical | 0 | --- | --- | ---
Mortality | LMWH versus UFH | 8 RCTs | Yes | OR 0.39 (0.10 to 1.49) | 0
Mortality | - Limited to 2001-present | 1 RCT | No | No events occurred in the groups compared | NA
Mortality | - Limited to THR | 7 RCTs | Yes | OR 0.21 (0.03 to 1.59) | 0
Mortality | - Limited to HFS | 1 RCT | No | RR 0.64 (0.13 to 3.06) | NA
Mortality | LMWH versus factor Xa inhibitor | 5 RCTs 2 OBS | Yes (RCTs) | One trial had no events in the groups compared, the remaining trials showed OR 1.08 (0.72 to 1.60); one observational study suggests significantly higher percent of deaths in patients who received LMWH versus factor Xa inhibitors while the other study suggests no difference | 0
Mortality | - Limited to 2001-present | 5 RCTs 1 OBS | Yes (RCT) | One trial had no events in the groups compared, the remaining trials showed OR 1.08 (0.72 to 1.60); Observational study is supportive | 0
Mortality | - Limited to THR | 3 RCTs | Yes | One trial had no events in the groups compared, the remaining trials showed OR 0.88 (0.32 to 2.42) | NA
Mortality | - Limited to TKR | 1 RCT | No | OR 1.49 (0.26 to 8.65) | NA
Mortality | - Limited to HFS | 1 RCT | No | OR 1.10 (0.70 to 1.72) | NA
Mortality | LMWH versus DTI | 4 RCTs | Yes | RR 0.45 (0.15 to 1.36) | 0
Mortality | - Limited to 2001-present | 3 RCTs | Yes | RR 0.54 (0.15 to 1.98) | 0
Mortality | - Limited to THR | 2 RCTs | Yes | RR 0.27 (0.06 to 1.23) | 0
Mortality | - Limited to TKR | 2 RCTs | Yes | RR 0.80 (0.16 to 4.17) | 0
Mortality | LMWH versus VKA | 6 RCTs | Yes | OR 0.79 (0.42 to 1.50) | 0
Mortality | - Limited to 2001-present | 2 RCTs | No | One trial had no events in the groups compared, the remaining trial showed OR 0.37 (0.05 to 2.66) | NA
Mortality | - Limited to THR | 2 RCTs | Yes | RR 0.81 (0.36 to 1.82) | 0
Mortality | - Limited to TKR | 3 RCTs | Yes | OR 0.52 (0.10 to 2.57) | NA
Mortality | LMWH versus mechanical | 2 RCTs | Yes | OR 0.31 (0.05 to 1.80) | NA
Mortality | - Limited to 2001-present | 1 RCT | No | OR 0.38 (0.05 to 2.73) | NA
Mortality | - Limited to THR | 1 RCT | No | OR 0.14 (0.003 to 7.01) | NA
Mortality | - Limited to TKR | 1 RCT | No | OR 0.38 (0.05 to 2.73) | NA
Mortality | UFH versus DTI | 2 RCTs | Yes | OR 7.13 (0.74 to 68.80) | NA
Mortality | - Limited to THR | 2 RCTs | Yes | OR 7.13 (0.74 to 68.80) | NA
Mortality | UFH versus factor Xa inhibitor | 1 OBS | No | Observational data suggested significantly higher percent of deaths in patients who received UFH versus factor Xa inhibitor | NA
Mortality | UFH versus mechanical | 1 RCT | No | OR 7.62 (0.15 to 384.19) | NA
Mortality | VKA versus mechanical | 2 RCTs | No | One trial had no events in the groups compared, the remaining trial showed OR 0.95 (0.06 to 15.33) | NA
Mortality | - Limited to THR | 1 RCT | No | OR 0.95 (0.06 to 15.33)
Mortality due to bleeding | Antiplatelet versus VKA | 1 RCT | No | No events occurred in the groups compared | NA
Mortality due to bleeding | Antiplatelet versus mechanical | 0 | --- | --- | ---
Mortality due to bleeding | LMWH versus UFH | 7 RCTs | No | Six trials had no events in the groups compared, the remaining trial showed OR 0.13 (0.003 to 6.52) | NA
Mortality due to bleeding | - Limited to 2001-present | 1 RCT | No | No events occurred in the groups compared | NA
Mortality due to bleeding | - Limited to THR | 6 RCTs | No | No events occurred in the groups compared | NA
Mortality due to bleeding | - Limited to HFS | 1 RCT | No | OR 0.13 (0.003 to 6.52) | NA
Mortality due to bleeding | LMWH versus factor Xa inhibitor | 5 RCTs 1 OBS | No | Four trials had no events in the groups compared, the remaining trial showed OR 7.29 (0.14 to 367.58); Observational data suggest no difference | NA
Mortality due to bleeding | - Limited to 2001-present | 2 RCTs 1 OBS | No | One trial had no events in the groups compared, the remaining trial showed OR 7.29 (0.14 to 367.58); Observational data suggest no difference | NA
Mortality due to bleeding | - Limited to THR | 3 RCTs | No | No events occurred in the groups compared | NA
Mortality due to bleeding | - Limited to TKR | 1 RCT | No | No events occurred in the groups compared | NA
Mortality due to bleeding | - Limited to HFS | 1 RCT | No | OR 7.29 (0.14 to 367.58) | NA
Mortality due to bleeding | LMWH versus DTI | 3 RCTs | Yes | Two trials had no events in the groups compared, the remaining trial included two comparisons pooled to show RR 0.67 (0.07 to 6.40) | NA
Mortality due to bleeding | - Limited to 2001-present | 3 RCTs | Yes | Two trials had no events in the groups compared, the remaining trial included two comparisons pooled to show RR 0.67 (0.07 to 6.40) | NA
Mortality due to bleeding | - Limited to THR | 1 RCT (2 comp) | Yes | RR 0.67 (0.07 to 6.40) | NA
Mortality due to bleeding | - Limited to TKR | 2 RCTs | No | No events occurred in the groups compared | NA
Mortality due to bleeding | LMWH versus VKA | 4 RCTs | No | Three trials had no events in the groups compared, the remaining trial showed OR 0.14 (0.003 to 6.94) | NA
Mortality due to bleeding | - Limited to 2001-present | 1 RCT | No | OR 0.14 (0.003 to 6.94) | NA
Mortality due to bleeding | - Limited to THR | 2 RCTs | No | No events occurred in the groups compared | NA
Mortality due to bleeding | - Limited to TKR | 3 RCTs | No | Two trials had no events in the groups compared, the remaining trial showed OR 0.14 (0.003 to 6.94) | NA
Mortality due to bleeding | LMWH versus mechanical | 2 RCTs | No | One trial had no events in the groups compared, the remaining trial showed OR 0.14 (0.003 to 7.01) | NA
Mortality due to bleeding | - Limited to 2001-present | 1 RCT | No | No events occurred in the groups compared | NA
Mortality due to bleeding | - Limited to THR | 1 RCT | No | OR 0.14 (0.003 to 7.01) | NA
Mortality due to bleeding | - Limited to TKR | 1 RCT | No | No events occurred in the groups compared | NA
Mortality due to bleeding | UFH versus DTI | 2 RCTs | No | No events occurred in the groups compared | NA
Mortality due to bleeding | - Limited to THR | 2 RCTs | No | No events occurred in the groups compared | NA
Mortality due to bleeding | UFH versus factor Xa inhibitor | 0 | --- | --- | ---
Mortality due to bleeding | UFH versus mechanical | 1 RCT | No | No events occurred in the groups compared | NA
Mortality due to bleeding | VKA versus mechanical | 2 RCTs | No | No events occurred in the groups compared | NA
Mortality due to bleeding | - Limited to THR | 2 RCTs | No | No events occurred in the groups compared | NA
Health related quality of life | | 0 | --- | --- | ---
Deep vein thrombosis | Antiplatelet versus VKA | 1 RCT | No | RR 1.06 (0.87 to 1.30) | NA
Deep vein thrombosis | - Gender | 1 RCT | No | No significant difference | NA
Deep vein thrombosis | Antiplatelet versus mechanical | 2 RCTs | Yes | RR 1.63 (1.11 to 2.39)^†^ | 0
Deep vein thrombosis | - Limited to TKR | 1 RCT (2 comp) | Yes | RR 1.63 (1.08 to 2.44)^†^ | NA
Deep vein thrombosis | - Limited to HFS | 1 RCT | No | RR 1.68 (0.55 to 5.19) | NA
Deep vein thrombosis | LMWH versus UFH | 13 RCTs | Yes | RR 0.80 (0.65 to 0.99)^†^ | 34.3
Deep vein thrombosis | LMWH versus UFH | 1 RCT (2 comp) | Yes | 1 trial ineligible for original pooled analysis showed RR 3.37 (0.70 to 16.17) | NA
Deep vein thrombosis | - Limited to 2001-present | 1 RCT | No | OR 0.13 (0.01 to 2.15) | NA
Deep vein thrombosis | - Limited to THR | 10 RCTs | Yes | RR 0.75 (0.58 to 0.97)^†^ | 26.4
Deep vein thrombosis | - Limited to THR | 1 RCT | No | 1 trial ineligible for pooling showed RR 1.60 (0.21 to 12.06) | NA
Deep vein thrombosis | - Limited to TKR | 2 RCTs | Yes | RR 0.75 (0.58 to 0.96)^†^ | NA
Deep vein thrombosis | - Limited to TKR | 1 RCT | No | 1 trial ineligible for pooling showed RR 6.00 (0.99 to 37.43) | NA
Deep vein thrombosis | - Limited to HFS | 1 RCT | No | RR 2.19 (1.01 to 4.98)^†^ | NA
Deep vein thrombosis | - Age | 1 RCT | No | Age did not impact the risk of DVT when comparing LMWH vs. UFH | NA
Deep vein thrombosis | - Gender | 2 RCTs | No | Gender did not impact risk of DVT when comparing LMWH vs. UFH | NA
Deep vein thrombosis | - Ethnicity | 1RCT | No | In white patients, enoxaparin was significantly better at reducing the risk of DVT although this effect was not seen in blacks. Oriental patients and a category called “other” did not have any events therefore the impact could not be evaluated. | NA
Deep vein thrombosis | LMWH versus factor Xa inhibitor | 5 RCTs | Yes | RR 1.99 (1.57 to 2.51)^†^ | 42.5
Deep vein thrombosis | - Limited to 2001-present | 5 RCTs | Yes | RR 1.99 (1.57 to 2.51)^†^ | 42.5
Deep vein thrombosis | - Limited to THR | 3 RCTs | Yes | OR 1.80 (1.38 to 2.34)^†^ | 51.4
Deep vein thrombosis | - Limited to TKR | 1 RCT | No | RR 2.18 (1.59 to 3.01)^†^ | NA
Deep vein thrombosis | - Limited to HFS | 1 RCT | No | RR 2.39 (1.75 to 3.28)^†^ | NA
Deep vein thrombosis | LMWH versus DTI | 1 RCT | No | RR 1.39 (1.15 to 1.68)^†^ | NA
Deep vein thrombosis | LMWH versus VKA | 5 RCTs | Yes | RR 0.66 (0.55 to 0.79)^†^ | 60.9
Deep vein thrombosis | - Limited to 2001-present | 1 RCT | No | RR 0.57 (0.42 to 0.76)^†^ | NA
Deep vein thrombosis | - Limited to THR | 3 RCTs | Yes | RR 0.61 (0.44 to 0.84)^†^ | 67.6
Deep vein thrombosis | - Limited to TKR | 3 RCTs | Yes | RR 0.71 (0.57 to 0.87)^†^ | 57.2
Deep vein thrombosis | LMWH versus mechanical | 3 RCTs | Yes | RR 0.90 (0.71 to 1.14) | 0
Deep vein thrombosis | - Limited to 2001-present | 1 RCT | No | RR 0.94 (0.72 to 1.21) | NA
Deep vein thrombosis | - Limited to THR | 2 RCTs | Yes | RR 0.75 (0.43 to 1.30) | NA
Deep vein thrombosis | - Limited to TKR | 1 RCT | No | RR 0.94 (0.72 to 1.21) | NA
Deep vein thrombosis | UFH versus DTI | 2 RCTs | Yes | RR 2.31 (1.34 to 4.00)^†^ | NA
Deep vein thrombosis | - Limited to THR | 2 RCTs | Yes | RR 2.31 (1.34 to 4.00)^†^ | NA
Deep vein thrombosis | UFH versus factor Xa inhibitor | 0 | --- | --- | ---
Deep vein thrombosis | UFH versus mechanical | 1 RCT | No | RR 2.63 (1.36 to 5.25)^†^ | NA
Deep vein thrombosis | VKA versus mechanical | 3 RCTs | Yes | RR 1.45 (0.75 to 2.82) | 58.5
Deep vein thrombosis | - Limited to THR | 3 RCTs | Yes | RR 1.45 (0.75 to 2.82) | 58.5
Asymptomatic DVT | Antiplatelet versus VKA | 0 | --- | --- | ---
Asymptomatic DVT | Antiplatelet versus mechanical | 1 RCT | No | OR 1.45 (0.24 to 8.56) | NA
Asymptomatic DVT | LMWH versus UFH | 2 RCTs | Yes | RR 0.70 (0.43 to 1.16) | NA
Asymptomatic DVT | - Limited to THR | 2 RCTs | Yes | RR 0.70 (0.43 to 1.16) | NA
Asymptomatic DVT | LMWH versus factor Xa inhibitor | 0 | --- | --- | ---
Asymptomatic DVT | LMWH versus DTI | 2 RCTs | Yes | RR 0.97 (0.85 to 1.10) | 0
Asymptomatic DVT | - Limited to 2001-present | 2 RCTs | Yes | RR 0.97 (0.85 to 1.10) | 0
Asymptomatic DVT | - Limited to THR | 1 RCT (2 comp) | Yes | RR 1.08 (0.69 to 1.69) | NA
Asymptomatic DVT | - Limited to TKR | 1 RCT (2 comp) | Yes | RR 0.95 (0.83 to 1.09) | NA
Asymptomatic DVT | LMWH versus VKA | 1 RCT | No | RR 0.50 (0.28 to 0.88)^†^ | NA
Asymptomatic DVT | LMWH versus mechanical | 1 RCT | No | OR 1.00 (0.06 to 16.45) | NA
Asymptomatic DVT | UFH versus DTI | 0 | --- | --- | ---
Asymptomatic DVT | UFH versus factor Xa inhibitor | 0 | --- | --- | ---
Asymptomatic DVT | UFH versus mechanical | 0 | --- | --- | ---
Asymptomatic DVT | VKA versus mechanical | 0 | --- | --- | ---
Symptomatic DVT | Antiplatelet versus VKA | 0 | --- | --- | ---
Symptomatic DVT | Antiplatelet versus mechanical | 1 RCT | No | OR 1.91 (0.37 to 9.75) | NA
Symptomatic DVT | LMWH versus UFH | 3 RCTs | Yes | OR 0.62 (0.22 to 1.75) | 0
Symptomatic DVT | LMWH versus UFH | 2 RCT | Yes | 2 trials evaluated this outcome during the post discharge period and showed OR 1.96 (0.20 to 19.02) | NA
Symptomatic DVT | - Limited to THR | 3 RCTs | Yes | OR 0.62 (0.22 to 1.75) | 0
Symptomatic DVT | LMWH versus factor Xa inhibitor | 6 RCTs | Yes | OR 0.48 (0.21 to 1.12) | 0
Symptomatic DVT | - Limited to 2001-present | 6 RCTs | Yes | OR 0.48 (0.21 to 1.12) | 0
Symptomatic DVT | - Limited to THR | 3 RCTs | Yes | OR 0.20 (0.06 to 0.70)^†^ | 0
Symptomatic DVT | - Limited to TKR | 2 RCTs | Yes | OR 1.01 (0.29 to 3.49) | NA
Symptomatic DVT | - Limited to HFS | 1 RCT | No | OR 0.99 (0.06 to 15.83) | NA
Symptomatic DVT | LMWH versus DTI | 3 RCTs | Yes | RR 0.98 (0.34 to 2.87) | 47.5
Symptomatic DVT | LMWH versus DTI | 1 RCT | No | 1 trial evaluated this outcome during the postdischarge period and showed OR 0.51 (0.14 to 1.91) | NA
Symptomatic DVT | - Limited to 2001-present | 3 RCTs | Yes | RR 0.98 (0.34 to 2.87) | 47.5
Symptomatic DVT | - Limited to THR | 1 RCT (2 comp) | Yes | RR 0.14 (0.02 to 1.03) | NA
Symptomatic DVT | - Limited to TKR | 2 RCTs | Yes | RR 1.55 (0.58 to 4.20) | 35
Symptomatic DVT | LMWH versus VKA | 3 RCTs | Yes | OR 0.87 (0.61 to 1.24) | 28.4
Symptomatic DVT | - Limited to 2001-present | 1 RCT | No | OR 1.00 (0.06 to 16.09) | NA
Symptomatic DVT | - Limited to THR | 2 RCTs | Yes | OR 0.87 (0.60 to 1.24) | 52.5
Symptomatic DVT | - Limited to TKR | 1 RCT | No | OR 1.00 (0.06 to16.09) | NA
Symptomatic DVT | LMWH versus mechanical | 2 RCTs | No | One trial had no events; the remaining trials showed OR 7.28 (0.14 to 367.07) | NA
Symptomatic DVT | - Limited to THR | 2 RCTs | No | One trial had no events; the remaining trials showed OR 7.28 (0.14 to 367.07) | NA
Symptomatic DVT | UFH versus DTI | 1 RCT | No | This trial evaluated this outcome during the postdischarge period and showed OR 1.50 (0.26 to 8.74) | NA
Symptomatic DVT | UFH versus factor Xa inhibitor | 0 | --- | --- | ---
Symptomatic DVT | UFH versus mechanical | 0 | --- | --- | ---
Symptomatic DVT | VKA versus mechanical | 0 | --- | --- | ---
Proximal deep vein thrombosis | Antiplatelet versus VKA | 1 RCT | No | RR 0.78 (0.42 to 1.46) | NA
Proximal deep vein thrombosis | Antiplatelet versus mechanical | 1 RCT | No | OR 0.57 (0.06 to 5.77) | NA
Proximal deep vein thrombosis | LMWH versus UFH | 9 RCTs | Yes | RR 0.60 (0.38 to 0.93)^†^ | 37
Proximal deep vein thrombosis | - Limited to THR | 6 RCTs | Yes | RR 0.58 (0.39 to 0.86)^†^ | 0
Proximal deep vein thrombosis | - Limited to TKR | 2 RCTs | Yes | RR 0.32 (0.13 to 0.82)^†^ | NA
Proximal deep vein thrombosis | - Limited to HFS | 1 RCT | No | RR 2.25 (0.95 to 5.61) | NA
Proximal deep vein thrombosis | LMWH versus factor Xa inhibitor | 5 RCTs | Yes | OR 2.19 (1.52 to 3.16)^†^ | 69.9
Proximal deep vein thrombosis | - Limited to 2001-present | 5 RCTs | Yes | OR 2.19 (1.52 to 3.16)^†^ | 69.9
Proximal deep vein thrombosis | - Limited to THR | 3 RCTs | Yes | OR 1.55 (0.91 to 2.66) | 78.2
Proximal deep vein thrombosis | - Limited to TKR | 1 RCT | No | OR 2.18 (1.04 to 4.57)^†^ | NA
Proximal deep vein thrombosis | - Limited to HFS | 1 RCT | No | OR 3.80 (1.92 to 7.50)^†^ | NA
Proximal deep vein thrombosis | LMWH versus DTI | 2 RCTs | Yes | RR 0.91 (0.40 to 2.11) | NA
Proximal deep vein thrombosis | - Limited to 2001-present | 1 RCT (2 comp) | Yes | RR 0.58 (0.29 to 1.17) | NA
Proximal deep vein thrombosis | - Limited to THR | 1 RCT | No | OR 1.71 (1.13 to 2.59)^†^ | NA
Proximal deep vein thrombosis | - Limited to TKR | 1 RCT (2 comp) | Yes | RR 0.58 (0.29 to 1.17) | NA
Proximal deep vein thrombosis | LMWH versus VKA | 6 RCTs | Yes | RR 0.63 (0.39 to 1.00) | 55.3
Proximal deep vein thrombosis | - Limited to 2001-present | 2 RCTs | Yes | RR 0.43 (0.05 to 4.11) | NA
Proximal deep vein thrombosis | - Limited to THR | 3 RCTs | Yes | OR 0.67 (0.42 to 1.08) | NA
Proximal deep vein thrombosis | - Limited to TKR | 4 RCTs | Yes | RR 0.63 (0.30 to 1.34) | 68.9
Proximal deep vein thrombosis | LMWH versus mechanical | 3 RCTs | Yes | RR 0.65 (0.34 to 1.26) | 0
Proximal deep vein thrombosis | - Limited to 2001-present | 1 RCT | No | OR 0.15 (0.02 to 1.05) | NA
Proximal deep vein thrombosis | - Limited to THR | 2 RCTs | Yes | RR 0.71 (0.36 to 1.40) | NA
Proximal deep vein thrombosis | - Limited to TKR | 1 RCT | No | OR 0.15 (0.02 to 1.05) | NA
Proximal deep vein thrombosis | UFH versus DTI | 2 RCTs | Yes | OR 4.74 (2.99 to 7.49)^†^; | NA
Proximal deep vein thrombosis | - Limited to THR | 2 RCTs | Yes | OR 4.74 (2.99 to 7.49)^†^ | NA
Proximal deep vein thrombosis | UFH versus factor Xa inhibitor | 0 | --- | --- | ---
Proximal deep vein thrombosis | UFH versus mechanical | 0 | --- | --- | ---
Proximal deep vein thrombosis | VKA versus mechanical | 3 RCTs | Yes | RR 0.34 (0.16 to 0.73)^†^ | 0
Proximal deep vein thrombosis | - Limited to THR | 3 RCTs | Yes | RR 0.34 (0.16 to 0.73)^†^ | 0
Distal deep vein thrombosis | Antiplatelet versus VKA | 0 | --- | --- | ---
Distal deep vein thrombosis | Antiplatelet versus mechanical | 1 RCT | No | RR 1.79 (1.15 to 2.79)^†^ | NA
Distal deep vein thrombosis | LMWH versus UFH | 8 RCTs | Yes | RR 0.95 (0.74 to 1.23) | 0
Distal deep vein thrombosis | - Limited to THR | 5 RCTs | Yes | RR 1.03 (0.58 to 1.83) | 0
Distal deep vein thrombosis | - Limited to TKR | 2 RCTs | Yes | RR 0.93 (0.69 to 1.24) | NA
Distal deep vein thrombosis | - Limited to HFS | 1 RCT | No | OR 1.86 (0.19 to 18.65) | NA
Distal deep vein thrombosis | LMWH versus factor Xa inhibitor | 5 RCTs | Yes | RR 2.02 (1.65 to 2.48)^†^ | 10
Distal deep vein thrombosis | - Limited to 2001-present | 5 RCTs | Yes | RR 2.02 (1.65 to 2.48)^†^ | 10
Distal deep vein thrombosis | - Limited to THR | 3 RCTs | Yes | OR 1.82 (1.36 to 2.42)^†^ | 28.1
Distal deep vein thrombosis | - Limited to TKR | 1 RCT | No | RR 2.27 (1.57 to 3.28)^†^ | NA
Distal deep vein thrombosis | - Limited to HFS | 1 RCT | No | RR 2.24 (1.59 to 3.17)^†^ | NA
Distal deep vein thrombosis | LMWH versus DTI | 1 RCT | No | RR 0.79 (0.67 to 0.93)^†^ | NA
Distal deep vein thrombosis | LMWH versus VKA | 2 RCTs | Yes | RR 0.56 (0.43 to 0.73)^†^ | NA
Distal deep vein thrombosis | - Limited to 2001-present | 1 RCT | No | RR 0.60 (0.44 to 0.81)^†^ | NA
Distal deep vein thrombosis | - Limited to THR | 1 RCT | No | RR 0.48 (0.30 to 0.78)^†^ | NA
Distal deep vein thrombosis | - Limited to TKR | 1 RCT | No | RR 0.60 (0.44 to 0.81)^†^ | NA
Distal deep vein thrombosis | LMWH versus mechanical | 3 RCTs | Yes | RR 1.00 (0.77 to 1.29) | NA
Distal deep vein thrombosis | - Limited to 2001-present | 1 RCT | No | RR 1.01 (0.77 to 1.31) | NA
Distal deep vein thrombosis | - Limited to THR | 2 RCTs | No | One trial had no events in the groups compared, the other showed OR 0.84 (0.28 to 2.55) | NA
Distal deep vein thrombosis | - Limited to TKR | 1 RCT | No | RR 1.01 (0.77 to 1.31) | NA
Distal deep vein thrombosis | UFH versus DTI | 0 | --- | --- | ---
Distal deep vein thrombosis | UFH versus factor Xa inhibitor | 0 | --- | --- | ---
Distal deep vein thrombosis | UFH versus mechanical | 0 | --- | --- | ---
Distal deep vein thrombosis | VKA versus mechanical | 1 RCT | No | OR 3.30 (0.91 to 11.91) | NA
Major Bleeding | Antiplatelet versus VKA | 1 RCT | No | RR 0.20 (0.03 to 1.23) | NA
Major Bleeding | Antiplatelet versus mechanical | 0 | --- | --- | ---
Major Bleeding | LMWH versus UFH | 7 RCTs | Yes | OR 0.57 (0.37 to 0.88)^†^ | 37.1
Major Bleeding | - Limited to 2001-present | 1 RCT | No | OR 7.54 (0.47 to 122.28) | NA
Major Bleeding | - Limited to THR | 6 RCTs | Yes | OR 0.54 (0.34 to 0.85)^†^ | 43.5
Major Bleeding | - Limited to TKR | 1 RCT | No | OR 0.99 (0.20 to 4.93) | NA
Major Bleeding | LMWH versus factor Xa inhibitor | 5 RCTs 2 OBS | Yes (RCT) | One trial had no events in the groups compared; the remaining trials showed OR 0.65 (0.48 to 0.89)^†^; observational data suggested no significant difference | 56.6
Major Bleeding | - Limited to 2001-present | 5 RCTs 1 OBS | Yes (RCT) | One trial had no events in the groups compared; the remaining trials showed OR 0.65 (0.48 to 0.89)^†^; Observational data suggest no significant difference | 56.6
Major Bleeding | - Limited to THR | 3 RCTs | Yes | One trial had no events in the groups compared; the remaining trials showed OR 0.64 (0.44 to 0.94)^†^ | NA
Major Bleeding | - Limited to TKR | 1 RCT | No | OR 0.19 (0.06 to 0.58)^†^ | NA
Major Bleeding | - Limited to HFS | 1 RCT | No | OR 1.04 (0.54 to 2.00) | NA
Major Bleeding | LMWH versus DTI | 4 RCTs 1 RCT | Yes No | RR 1.12 (0.80 to 1.57) 1 trial evaluated this outcome during the postdischarge period and showed RR 0.51 (0.06 to 4.58) | 0 NA
Major Bleeding | - Limited to 2001-present | 3 RCTs | Yes | RR 1.17 (0.79 to 1.75) | 0
Major Bleeding | - Limited to THR | 2 RCTs | Yes | RR 0.97 (0.64 to 1.48) | 0
Major Bleeding | - Limited to TKR | 2 RCTs | Yes | RR 1.46 (0.82 to 2.59) | 0
Major Bleeding | LMWH versus VKA | 7 RCTs | Yes | OR 1.92 (1.27 to 2.91)^†^ | 0
Major Bleeding | LMWH versus VKA | 1 RCT (2 comp) | Yes | 1 trial ineligible for pooling showed a RR 1.51 (0.92 to 2.48) for major bleeding days 0-1 and a RR 3.41 (0.77 to 15.18) for major bleeding on days 2-8 | NA
Major Bleeding | - Limited to 2001-present | 2 RCTs | Yes | One trial had no events; the remaining trial showed OR 2.26 (0.75 to 6.83) | NA
Major Bleeding | - Limited to THR | 3 RCTs | Yes | OR 1.91 (1.11 to 3.29)^†^ | 0
Major Bleeding | - Limited to THR | 1 RCT (2 comp) | Yes | 1 trial ineligible for pooling showed a RR 1.51 (0.92 to 2.48) for major bleeding days 0-1 and a RR 3.41 (0.77 to 15.18) for major bleeding on days 2-8 | NA
Major Bleeding | - Limited to TKR | 4 RCTs | Yes | OR 1.93 (1.01 to 3.67)^†^ | 0
Major Bleeding | LMWH versus mechanical | 0 | --- | --- | ---
Major Bleeding | UFH versus DTI | 0 | --- | --- | ---
Major Bleeding | UFH versus factor Xa inhibitor | 1 OBS | No | Observational data suggest major bleeding was significantly increased in patients who received UFH versus injectable or oral factor Xa inhibitor | NA
Major Bleeding | UFH versus mechanical | 0 | --- | --- | ---
Major Bleeding | VKA versus mechanical | 1 RCT | No | No events occurred in the groups compared | NA
Major bleeding leading to reoperation | Antiplatelet versus VKA | 0 | --- | --- | ---
Major bleeding leading to reoperation | Antiplatelet versus mechanical | 0 | --- | --- | ---
Major bleeding leading to reoperation | LMWH versus UFH | 1 RCT | No | No events occurred in the groups compared | NA
Major bleeding leading to reoperation | LMWH versus factor Xa inhibitor | 4 RCTs | Yes | OR 0.67 (0.28 to 1.61) | 0
Major bleeding leading to reoperation | - Limited to 2001-present | 4 RCTs | Yes | OR 0.67 (0.28 to 1.61) | 0
Major bleeding leading to reoperation | - Limited to THR | 2 RCTs | Yes | OR 0.72 (0.23 to 2.23) | 0
Major bleeding leading to reoperation | - Limited to TKR | 1 RCT | No | OR 0.51 (0.05 to 4.94) | NA
Major bleeding leading to reoperation | - Limited to HFS | 1 RCT | No | OR 0.66 (0.11 to 3.82) | NA
Major bleeding leading to reoperation | LMWH versus DTI | 3 RCTs | Yes | RR 1.27 (0.43 to 3.75) | 0
Major bleeding leading to reoperation | - Limited to 2001-present | 3 RCTs | Yes | RR 1.27 (0.43 to 3.75) | 0
Major bleeding leading to reoperation | - Limited to THR | 1 RCT (2 comp) | Yes | RR 1.21 (0.29 to 5.08) | NA
Major bleeding leading to reoperation | - Limited to TKR | 2 RCTs | Yes | RR 1.36 (0.27 to 7.03) | 0
Major bleeding leading to reoperation | LMWH versus VKA | 2 RCTs | No | One trial had no events; the remaining trial showed OR 7.61 (0.15 to 383.70) | NA
Major bleeding leading to reoperation | - Limited to 2001-present | 1 RCT | No | No events occurred in the groups compared | NA
Major bleeding leading to reoperation | - Limited to THR | 1 RCT | No | OR 7.61 (0.15 to 383.70) | NA
Major bleeding leading to reoperation | - Limited to TKR | 1 RCT | No | No events occurred in the groups compared | NA
Major bleeding leading to reoperation | LMWH versus mechanical | 0 | --- | --- | ---
Major bleeding leading to reoperation | UFH versus DTI | 2 RCTs | No | One trial had no events; the remaining trial showed OR 0.51 (0.10 to 2.55) | NA
Major bleeding leading to reoperation | - Limited to THR | 2 RCTs | No | One trial had no events; the remaining trial showed OR 0.51 (0.10 to 2.55) | NA
Major bleeding leading to reoperation | UFH versus factor Xa inhibitor | 0 | --- | --- | ---
Major bleeding leading to reoperation | UFH versus mechanical | 0 | --- | --- | ---
Major bleeding leading to reoperation | VKA versus mechanical | 1 RCT | No | No events occurred in the groups compared | NA
Minor Bleeding | Antiplatelet versus VKA | 0 | --- | --- | ---
Minor Bleeding | Antiplatelet versus mechanical | 0 | --- | --- | ---
Minor Bleeding | LMWH versus UFH | 5 RCTs | Yes | RR 0.90 (0.63 to 1.28) | 9.9
Minor Bleeding | - Limited to 2001-present | 1 RCT | No | RR 0.25 (0.03 to 2.16) | NA
Minor Bleeding | - Limited to THR | 4 RCTs | Yes | OR 0.92 (0.57 to 1.51) | 31.4
Minor Bleeding | - Limited to TKR | 1 RCT | No | RR 0.87 (0.60 to 1.25) | NA
Minor Bleeding | LMWH versus factor Xa inhibitor | 2 RCTs | Yes | OR 0.57 (0.35 to 0.94)^†^ | NA
Minor Bleeding | - Limited to 2001-present | 2 RCTs | Yes | OR 0.57 (0.35 to 0.94)^†^ | NA
Minor Bleeding | - Limited to THR | 1 RCT | No | OR 0.85 (0.27 to 2.62) | NA
Minor Bleeding | - Limited to HFS | 1 RCT | No | OR 0.52 (0.30 to 0.91)^†^ | NA
Minor Bleeding | LMWH versus DTI | 3 RCTs | Yes | RR: 1.07 (0.89 to 1.29) | 0
Minor Bleeding | LMWH versus DTI | 1 RCT | No | 1 trial evaluated this outcome during the postdischarge period and showed a RR 0.54 (0.15 to 1.94) | NA
Minor Bleeding | - Limited to 2001-present | 3 RCTs | Yes | RR 1.07 (0.89 to 1.29) | 0
Minor Bleeding | - Limited to THR | 1 RCT (2 comp) | Yes | RR 1.04 (0.79 to 1.37) | NA
Minor Bleeding | - Limited to TKR | 2 RCTs | Yes | RR 1.10 (0.86 to 1.40) | 0
Minor Bleeding | LMWH versus VKA | 7 RCTs | Yes | RR 1.23 (1.06 to 1.43)^†^ | 0
Minor Bleeding | LMWH versus VKA | 1 RCT (2 comp) | Yes | 1 trial ineligible for the original pooled analysis showed a RR 1.49 (0.30 to 7.37) on days 0-1 and a RR 0.87 (0.37 to 2.06) on days 2-8 | NA
Minor Bleeding | - Limited to 2001-present | 2 RCTs | Yes | RR 1.25 (0.85 to 1.83) | NA
Minor Bleeding | - Limited to THR | 3 RCTs | Yes | RR 1.26 (0.85 to 1.86) | 27.8
Minor Bleeding | - Limited to THR | 1 RCT (2 comp) | Yes | 1 trial ineligible for the original pooled analysis showed a RR 1.49 (0.30 to 7.37)] on days 0-1 and a RR 0.87 (0.37 to 2.06) on days 2-8 | NA
Minor Bleeding | - Limited to TKR | 4 RCTs | Yes | RR 1.17 (0.95 to 1.43) | 0
Minor Bleeding | LMWH versus mechanical | 0 | --- | --- | ---
Minor Bleeding | UFH versus DTI | 0 | --- | --- | ---
Minor Bleeding | UFH versus factor Xa inhibitor | 0 | --- | --- | ---
Minor Bleeding | UFH versus mechanical | 0 | --- | --- | ---
Minor Bleeding | VKA versus mechanical | 2 RCTs | Yes | OR 0.80 (0.26 to 2.41) | NA
Minor Bleeding | - Limited to THR | 2 RCTs | Yes | OR 0.80 (0.26 to 2.41) | NA
Surgical site bleeding | Antiplatelet versus VKA | 1 OBS | No | Observational data suggest no significant difference | ---
Surgical site bleeding | Antiplatelet versus mechanical | 0 | --- | --- | ---
Surgical site bleeding | LMWH versus UFH | 3 RCTs | Yes | OR 0.92 (0.46 to 1.82) | 41.1
Surgical site bleeding | - Limited to 2001-present | 1 RCT | No | RR 0.75 (0.20 to 2.86) | NA
Surgical site bleeding | - Limited to THR | 2 RCTs | Yes | RR 0.63 (0.26 to 1.55) | 3.1
Surgical site bleeding | - Limited to TKR | 1 RCT | No | OR 1.78 (0.61 to 5.14) | NA
Surgical site bleeding | LMWH versus factor Xa inhibitor | 1 RCT | No | OR 0.72 (0.45 to 1.17) | NA
Surgical site bleeding | LMWH versus DTI | 1 RCT | No | RR 4.35 (1.51 to 12.54)^†^ | NA
Surgical site bleeding | LMWH versus VKA | 2 RCT | Yes | OR 2.63 (1.31 to 5.28)^†^ | NA
Surgical site bleeding | - Limited to 2001-present | 1 RCT | No | OR 2.05 (0.80 to 5.29) | NA
Surgical site bleeding | - Limited to THR | 1 RCT | No | OR 3.35 (1.27 to 9.84)^†^ | NA
Surgical site bleeding | - Limited to TKR | 1 RCT | No | OR 2.05 (0.80 to 5.29) | NA
Surgical site bleeding | - Major surgical site bleeding | 2 RCTs | Yes | OR 2.51 (1.38 to 4.54)^†^ | NA
Surgical site bleeding | - Major surgical site bleeding | 1 RCT (2 comp) | Yes | 1 trial ineligible for original pooled analysis showed a RR 1.72 (1.02 to 2.92)^†^ on days 0-1 and a RR 2.72 (0.59 to 12.44) on days 2-8 | NA
Surgical site bleeding | - Minor surgical site bleeding | 2 RCTs | Yes | OR 1.34 (0.91 to 1.97) | NA
Surgical site bleeding | - Minor surgical site bleeding | 1 RCT (2 comp) | Yes | 1 trial ineligible for pooling showed an OR 7.42 (0.15 to 373.92) on days 0-1 and an OR 7.43 (0.46 to 119.03) on days 2-8 | NA
Surgical site bleeding | LMWH versus mechanical | 0 | --- | --- | ---
Surgical site bleeding | UFH versus DTI | 1 RCT | No | OR 0.87 (0.31 to 2.43) | NA
Surgical site bleeding | UFH versus factor Xa inhibitor | 0 | --- | --- | ---
Surgical site bleeding | UFH versus mechanical | 0 | --- | --- | ---
Surgical site bleeding | VKA versus mechanical | 0 | --- | --- | ---
Bleeding leading to infection | | 0 | --- | --- | ---
Bleeding leading to transfusion | Antiplatelet versus VKA | 0 | --- | --- | ---
Bleeding leading to transfusion | Antiplatelet versus mechanical | 0 | --- | --- | ---
Bleeding leading to transfusion | LMWH versus UFH | 0 | --- | --- | ---
Bleeding leading to transfusion | LMWH versus factor Xa inhibitor | 0 | --- | --- | ---
Bleeding leading to transfusion | LMWH versus DTI | 2 RCTs | Yes | RR 1.00 (0.59 to 1.69) | 0
Bleeding leading to transfusion | - Limited to 2001-present | 2 RCTs | Yes | RR 1.00 (0.59 to 1.69) | 0
Bleeding leading to transfusion | - Limited to THR | 1 RCT (2 comp) | Yes | RR 1.19 (0.46 to 3.10) | NA
Bleeding leading to transfusion | - Limited to TKR | 1 RCT (2 comp) | Yes | RR 0.71 (0.26 to 1.98) | NA
Bleeding leading to transfusion | LMWH versus VKA | 1 RCT | No | OR 1.71 (0.42 to 6.90) | NA
Bleeding leading to transfusion | LMWH versus mechanical | 0 | --- | --- | ---
Bleeding leading to transfusion | UFH versus DTI | 0 | --- | --- | ---
Bleeding leading to transfusion | UFH versus factor Xa inhibitor | 0 | --- | --- | ---
Bleeding leading to transfusion | UFH versus mechanical | 0 | --- | --- | ---
Bleeding leading to transfusion | VKA versus mechanical | 1 RCT | No | No events occurred in the groups compared | NA
Heparin induced thrombocytopenia | Antiplatelet versus VKA | 0 | --- | --- | ---
Heparin induced thrombocytopenia | Antiplatelet versus mechanical | 0 | --- | --- | ---
Heparin induced thrombocytopenia | LMWH versus UFH | 3 RCTs | Yes | OR 0.13 (0.03 to 0.43)^†^ | 0
Heparin induced thrombocytopenia | - Limited to 2001-present | 1 RCT | No | No events occurred in the groups compared | NA
Heparin induced thrombocytopenia | - Limited to THR | 3 RCTs | Yes | OR 0.13 (0.03 to 0.43)^†^ | 0
Heparin induced thrombocytopenia | LMWH versus factor Xa inhibitor | 0 | --- | --- | ---
Heparin induced thrombocytopenia | LMWH versus DTI | 0 | --- | --- | ---
Heparin induced thrombocytopenia | LMWH versus VKA | 1 RCT | No | No events occurred in the groups compared | NA
Heparin induced thrombocytopenia | LMWH versus mechanical | 0 | --- | --- | ---
Heparin induced thrombocytopenia | UFH versus DTI | 0 | --- | --- | ---
Heparin induced thrombocytopenia | UFH versus factor Xa inhibitor | 0 | --- | --- | ---
Heparin induced thrombocytopenia | UFH versus mechanical | 0 | --- | --- | ---
Heparin induced thrombocytopenia | VKA versus mechanical | 0 | --- | --- | ---
Discomfort | Antiplatelet versus VKA | 0 | --- | --- | --
Discomfort | Antiplatelet versus mechanical | 0 | --- | --- | ---
Discomfort | LMWH versus UFH | 0 | --- | --- | --
Discomfort | LMWH versus factor Xa inhibitor | 0 | --- | --- | --
Discomfort | LMWH versus DTI | 0 | --- | --- | --
Discomfort | LMWH versus VKA | 0 | --- | --- | --
Discomfort | LMWH versus mechanical | 1 RCT | No | RR 0.49 (0.29 to 0.82)^†^ | NA
Discomfort | UFH versus DTI | 0 | --- | --- | --
Discomfort | UFH versus factor Xa inhibitor | 0 | --- | --- | --
Discomfort | UFH versus mechanical | 0 | --- | --- | --
Discomfort | VKA versus mechanical | 0 | --- | --- | --
Readmission | Antiplatelet versus VKA | 0 | --- | --- | --
Readmission | Antiplatelet versus mechanical | 0 | --- | --- | ---
Readmission | LMWH versus UFH | 2 RCT | Yes | RR 0.82 (0.20 to 3.38) | 14.2
Readmission | - Limited to 2001-present | 1 RCT | No | OR 7.54 (0.47 to 122.23) | NA
Readmission | - Limited to THR | 2 RCT | Yes | RR 0.82 (0.20 to 3.38) | 14.2
Readmission | LMWH versus factor Xa inhibitor | 0 | --- | --- | ---
Readmission | LMWH versus DTI | 0 | --- | --- | ---
Readmission | LMWH versus VKA | 0 | --- | --- | ---
Readmission | LMWH versus mechanical | 2 RCT | Yes | OR 0.83 (0.22 to 3.11) | NA
Readmission | - Limited to 2001-present | 1 RCT | No | OR 0.78 (0.17 to 3.50) | NA
Readmission | - Limited to THR | 1 RCT | No | OR 0.78 (0.17 to 3.50) | NA
Readmission | - Limited to TKR | 1 RCT | No | OR 1.03 (0.06 to 16.52) | NA
Readmission | UFH versus DTI | 0 | --- | --- | ---
Readmission | UFH versus factor Xa inhibitor | 0 | --- | --- | ---
Readmission | UFH versus mechanical | 0 | --- | --- | ---
Readmission | VKA versus mechanical | 1 RCT | No | OR 0.15 (0.003 to 7.58) | NA
Reoperation | Antiplatelet versus VKA | 0 | --- | --- | ---
Reoperation | Antiplatelet versus mechanical | 0 | --- | --- | ---
Reoperation | LMWH versus UFH | 0 | --- | --- | ---
Reoperation | LMWH versus factor Xa inhibitor | 1 RCT | No | RR 0.25 (0.04 to 1.63) | NA
Reoperation | LMWH versus DTI | 0 | --- | --- | ---
Reoperation | LMWH versus VKA | 2 RCT | No | One trial had no events in the groups compared, the remaining trial showed RR 0.85 (0.59 to 1.22) | NA
Reoperation | - Limited to 2001-present | 1 RCT | No | No events occurred in the groups compared | NA
Reoperation | - Limited to THR | 1 RCT | No | RR 0.85 (0.59 to 1.22) | NA
Reoperation | - Limited to TKR | 1 RCT | No | No events occurred in the groups compared | NA
Reoperation | LMWH versus mechanical | 0 | --- | --- | ---
Reoperation | UFH versus DTI | 0 | --- | --- | ---
Reoperation | UFH versus factor Xa inhibitor | 0 | --- | --- | ---
Reoperation | UFH versus mechanical | 0 | --- | --- | ---
Reoperation | VKA versus mechanical | 0 | --- | --- | ---

comp = comparison(s); DTI = direct thrombin inhibitor; HFS = hip fracture surgery; LMWH = low molecular weight heparin; NA = Not Applicable; OBS = observational; OR = Peto's Odds Ratio; RCT = Randomized Controlled Trial; RR = Relative Risk; THR = total hip replacement; TKR = total knee replacement; UFH = unfractionated heparin; VKA = vitamin K antagonist

* All base case analyses are represented in the table without a bullet, bulleted analyses are subgroup analyses. When only 1 trial or study was available subgroup analyses were not run. Subgroup analyses with no available data are not represented in this table.

† Statistically significant.

--- No data.

One trial by Eriksson and colleagues in 2005 was a dose finding study that evaluated the impact of four dabigatran doses (50mg twice daily, 150mg twice daily, 300mg daily or 225mg twice daily) versus enoxaparin on various outcomes of interest in patients who had either total hip or total knee replacement surgery.65 When pooling trials that evaluated dabigatran in this report, the doses that have been evaluated in phase 3 trials were analyzed since dabigatran did not yet have Food and Drug Administration approval for venous thromboembolism. In this dose finding study, none of the regimens were those studied in phase 3 trials, and given the paucity of data comparing dabigatran to injectable low molecular weight heparin agents, the outcomes evaluated in this trial were discussed qualitatively.

##### Symptomatic Objectively Confirmed Venous Thromboembolism

###### Oral Antiplatelet Agents Versus Oral Vitamin K Antagonists

No randomized controlled trials or controlled observational studies evaluated the impact of oral antiplatelet prophylaxis versus oral vitamin K antagonist prophylaxis in patients who had major orthopedic surgery on this outcome.

###### Oral Antiplatelet Agents Versus Mechanical Prophylaxis

No randomized controlled trials or controlled observational studies evaluated the impact of oral antiplatelet prophylaxis versus mechanical prophylaxis in patients who had major orthopedic surgery on this outcome.

###### Injectable low Molecular Weight Heparin Agents Versus Injectable Unfractionated Heparin

One randomized controlled trial evaluated the impact of injectable low molecular weight heparin prophylaxis versus injectable unfractionated heparin prophylaxis on symptomatic objectively confirmed venous thromboembolism in patients who had major orthopedic surgery.97 In this trial by Senaran and colleagues in 2006, patients who had total hip replacement surgery were randomized to receive either enoxaparin or unfractionated heparin prophylaxis. In patients who received injectable low molecular weight heparin prophylaxis versus injectable unfractionated heparin prophylaxis the odds of symptomatic objectively confirmed venous thromboembolism was not significantly different [OR 0.13 (0.01 to 2.15)]. Subgroup analyses were not possible because only one trial was available.

One randomized controlled trial evaluated the impact of injectable low molecular weight heparin prophylaxis versus injectable unfractionated heparin prophylaxis on symptomatic objectively confirmed venous thromboembolism during the postdischarge period in patients who had total hip replacement surgery.97 In patients who received injectable low molecular weight heparin versus injectable unfractionated heparin the odds of symptomatic objectively confirmed venous thromboembolism during the postdischarge period were not significantly different [OR 7.54 (0.47 to 122.28)].

###### Injectable Low Molecular Weight Heparin Agents Versus Injectable or Oral Factor Xa Inhibitors

Five randomized controlled trials evaluated the impact of injectable low molecular weight heparin prophylaxis versus injectable or oral factor Xa inhibitor prophylaxis on symptomatic objectively confirmed venous thromboembolism in patients who had major orthopedic surgery.64,83,99,106,135 In patients who received injectable low molecular weight heparin prophylaxis versus injectable or oral factor Xa inhibitor prophylaxis the odds of symptomatic objectively confirmed venous thromboembolism were not significantly different [OR 0.70 (0.48 to 1.02)] (Appendix G Figure 59). A lower level of statistical heterogeneity was detected and publication bias was not detected (I^2^=38.5 percent, Egger's p-value=0.895). This is the same result obtained when limiting the analysis to trials published from 2001-present since all five trials fit this criterion. When limiting the original analysis to total hip replacement surgery three trials remained.83,99,135 In patients with total hip replacement surgery who received injectable low molecular weight heparin prophylaxis versus injectable or oral factor Xa inhibitor prophylaxis, the odds of symptomatic objectively confirmed venous thromboembolism were significantly decreased [OR 0.53 (0.32 to 0.87), NNT 50 to 100] (Appendix G Figure 60). Statistical heterogeneity was not detected (I^2^=0 percent). When limiting the original analysis to total knee replacement surgery one trial remained.106 In this trial, in patients who received injectable low molecular weight heparin prophylaxis versus injectable or oral factor Xa inhibitor prophylaxis the odds of symptomatic objectively confirmed venous thromboembolism were not significantly different [OR 1.97 (0.71 to 5.45)]. When limiting the original analysis to hip fracture surgery one trial remained.64 In this trial, in patients who received injectable low molecular weight heparin prophylaxis versus injectable or oral factor Xa inhibitor prophylaxis the odds of symptomatic objectively confirmed venous thromboembolism were not significantly different [OR 0.75 (0.37 to 1.55)].

###### Injectable Low Molecular Weight Heparin Agents Versus Injectable or Oral Direct Thrombin Inhibitors

No randomized controlled trials or controlled observational studies evaluated the impact of injectable low molecular weight heparin prophylaxis versus injectable or oral direct thrombin inhibitor prophylaxis in patients who had major orthopedic surgery on this outcome.

###### Injectable Low Molecular Weight Heparin Agents Versus Oral Vitamin K Antagonists

Two randomized controlled trials evaluated the impact of injectable low molecular weight heparin prophylaxis versus oral vitamin K antagonist prophylaxis on symptomatic objectively confirmed venous thromboembolism in patients who had major orthopedic surgery.60,85 In patients who received injectable low molecular weight heparin prophylaxis versus oral vitamin K antagonist prophylaxis the odds of symptomatic objectively confirmed venous thromboembolism were not significantly different [OR 1.00 (0.69 to 1.46)] (Appendix G Figure 61). Statistical heterogeneity and publication bias could not be evaluated because of too few studies.

Subgroup analysis based on trials published from 2001-present was not possible since both trials were published prior to 2001. When limiting the original analysis to total hip replacement surgery one trial remained.60 In this trial, in patients who received injectable low molecular weight heparin prophylaxis versus oral vitamin K antagonist prophylaxis, the odds of symptomatic objectively confirmed venous thromboembolism was not significantly different [OR 0.97 (0.66 to 1.41)]. When limiting the original analysis to total knee replacement surgery one trial remained.85 In this trial, in patients who received injectable low molecular weight heparin prophylaxis versus oral vitamin K antagonist prophylaxis the odds of symptomatic objectively confirmed venous thromboembolism was not significantly different [OR 2.71 (0.38 to 19.35)]. Subgroup analysis based on hip fracture surgery was not possible because no trials evaluated this surgical population.

Subgroup analyses based on age, gender and ethnicity were not possible because no randomized controlled trials reported data based on these subgroups.

One randomized controlled trial evaluated the impact of injectable low molecular weight heparin versus oral vitamin K antagonist prophylaxis on symptomatic objectively confirmed venous thromboembolism during the postdischarge period in patients who had major orthopedic surgery.80 This trial evaluated patients who had total hip or total knee replacement surgery and reported results separately. In patients who received injectable low molecular weight heparin versus oral vitamin K antagonist prophylaxis the odds of symptomatic objectively confirmed venous thromboembolism during the postdischarge period were not significantly different [OR 2.24 (0.65 to 7.79)] (Appendix G Figure 62). Similar results were seen when evaluating total hip replacement surgery [OR 2.74 (0.68 to 11.01)] or total knee replacement surgery [OR 1.02 (0.06 to 16.38)] separately.

###### Injectable Low Molecular Weight Heparin Agents Versus Mechanical Prophylaxis

No randomized controlled trials or controlled observational studies evaluated the impact of injectable low molecular weight heparin prophylaxis versus mechanical prophylaxis in patients who had major orthopedic surgery on this outcome.

###### Injectable Unfractionated Heparin Versus Injectable or Oral Direct Thrombin Inhibitors

No randomized controlled trials or controlled observational studies evaluated the impact of injectable unfractionated heparin prophylaxis versus injectable or oral direct thrombin inhibitor prophylaxis in patients who had major orthopedic surgery on this outcome.

###### Injectable Unfractionated Heparin Versus Injectable or Oral Factor Xa Inhibitors

No randomized controlled trials or controlled observational studies evaluated the impact of injectable unfractionated heparin prophylaxis versus injectable or oral factor Xa inhibitor prophylaxis in patients who had major orthopedic surgery on this outcome.

###### Injectable Unfractionated Heparin Versus Mechanical Prophylaxis

No randomized controlled trials or controlled observational studies evaluated the impact injectable unfractionated heparin prophylaxis versus mechanical prophylaxis in patients who had major orthopedic surgery on this outcome.

###### Oral Vitamin K Antagonists Versus Mechanical Prophylaxis

No randomized controlled trials or controlled observational studies evaluated the impact of oral vitamin K antagonist prophylaxis versus mechanical prophylaxis in patients who had major orthopedic surgery on this outcome.

##### Major Venous Thromboembolism

###### Oral Antiplatelet Agents Versus Oral Vitamin K Antagonists

No randomized controlled trials or controlled observational studies evaluated the impact of oral antiplatelet prophylaxis versus oral vitamin K antagonist prophylaxis in patients who had major orthopedic surgery on this outcome.

###### Oral Antiplatelet Agents Versus Mechanical Prophylaxis

No randomized controlled trials or controlled observational studies evaluated the impact of oral antiplatelet prophylaxis versus mechanical prophylaxis in patients who had major orthopedic surgery on this outcome.

###### Injectable Low Molecular Weight Heparin Agents Versus Injectable Unfractionated Heparin

No randomized controlled trials or controlled observational studies evaluated the impact of injectable low molecular weight heparin prophylaxis versus injectable unfractionated heparin prophylaxis in patients who had major orthopedic surgery on this outcome.

###### Injectable Low Molecular Weight Heparin Agents Versus Injectable or Oral Factor Xa Inhibitors

No randomized controlled trials or controlled observational studies evaluated the impact of injectable low molecular weight heparin prophylaxis versus injectable or oral factor Xa inhibitor prophylaxis in patients who had major orthopedic surgery on this outcome.

###### Injectable Low Molecular Weight Heparin Agents Versus Injectable or Oral Direct Thrombin Inhibitors

Three randomized controlled trials evaluated the impact of injectable low molecular weight heparin prophylaxis versus injectable or oral direct thrombin inhibitor prophylaxis on major venous thromboembolism in patients who had major orthopedic surgery.66,67 Two trials by Eriksson and colleagues each provided two separate comparisons. In patients who received injectable low molecular weight heparin prophylaxis versus injectable or oral direct thrombin inhibitor prophylaxis the risk of major venous thromboembolism was not significantly different [RR 1.26 (0.98 to 1.62)] (Appendix G Figure 63). Statistical heterogeneity and publication bias were not detected (I^2^=0 percent, Egger's p-value=0.326).

When limiting the original analysis to trials published from 2001-present, two trials remained each including two separate comparisons.66,67 In patients who received injectable low molecular weight heparin prophylaxis versus injectable or oral direct thrombin inhibitor prophylaxis the risk of major venous thromboembolism was not significantly different [RR 1.08 (0.78 to 1.50)] (Appendix G Figure 64). Statistical heterogeneity was not detected (I^2^=0 percent). When limiting the original analysis to total hip replacement surgery two trials remained with one including two separate comparisons.67,69 In patients who received injectable low molecular weight heparin prophylaxis versus injectable or oral direct thrombin inhibitor prophylaxis the risk of major venous thromboembolism was not significantly different [RR 1.28 (0.94 to 1.76)] (Appendix G Figure 65). A lower level of statistical heterogeneity was detected (I^2^=18.6 percent). When limiting the original analysis to total knee replacement surgery one trial which included two separate comparisons remained.66 In patients who received injectable low molecular weight heparin prophylaxis versus injectable or oral direct thrombin inhibitor prophylaxis the risk of major venous thromboembolism was not significantly different [RR 1.11 (0.63 to 1.96)] (Appendix G Figure 66). Statistical heterogeneity could not be evaluated because of too few studies. Subgroup analysis based on hip fracture surgery was not possible because no trials evaluated this surgical population.

Subgroup analyses based on age, gender and ethnicity were not possible because no randomized controlled trials reported data based on these subgroups.

###### Injectable Low Molecular Weight Heparin Agents Versus Oral Vitamin K Antagonists

No randomized controlled trials or controlled observational studies evaluated the impact of injectable low molecular weight prophylaxis versus oral vitamin K antagonist prophylaxis in patients who had major orthopedic surgery on this outcome.

###### Injectable Low Molecular Weight Heparin Agents Versus Mechanical Prophylaxis

No randomized controlled trials or controlled observational studies evaluated the impact of injectable low molecular weight heparin prophylaxis versus mechanical prophylaxis in patients who had major orthopedic surgery on this outcome.

###### Injectable Unfractionated Heparin Versus Injectable or Oral Direct Thrombin Inhibitors

No randomized controlled trials or controlled observational studies evaluated the impact of injectable unfractionated heparin prophylaxis versus injectable or oral direct thrombin inhibitor prophylaxis in patients who had major orthopedic surgery on this outcome.

###### Injectable Unfractionated Heparin Versus Injectable or Oral Factor Xa Inhibitors

No randomized controlled trials or controlled observational studies evaluated the impact of injectable unfractionated heparin prophylaxis versus injectable or oral factor Xa inhibitor prophylaxis in patients who had major orthopedic surgery on this outcome.

###### Injectable Unfractionated Heparin Versus Mechanical Prophylaxis

No randomized controlled trials or controlled observational studies evaluated the impact injectable unfractionated heparin prophylaxis versus mechanical prophylaxis in patients who had major orthopedic surgery on this outcome.

###### Oral Vitamin K Antagonists Versus Mechanical Prophylaxis

No randomized controlled trials or controlled observational studies evaluated the impact of oral vitamin K antagonist prophylaxis versus mechanical prophylaxis in patients who had major orthopedic surgery on this outcome.

##### Pulmonary Embolism

###### Oral Antiplatelet Agents Versus Oral Vitamin K Antagonists

One randomized controlled trial evaluated the impact of oral antiplatelet prophylaxis versus oral vitamin K antagonist prophylaxis on pulmonary embolism in patients who had major orthopedic surgery.132 In this trial by Powers and colleagues in 1989, patients who had hip fracture surgery were randomized to receive either aspirin or warfarin prophylaxis. In patients who received oral antiplatelet prophylaxis versus oral vitamin K antagonist prophylaxis the odds of pulmonary embolism were not significantly different [OR 7.28 (0.14 to 366.83)]. Subgroup analyses were not possible since this was the only trial available.

###### Oral Antiplatelet Agents Versus Mechanical Prophylaxis

One randomized controlled trial evaluated the impact of oral antiplatelet prophylaxis versus mechanical prophylaxis on pulmonary embolism in patients who had major orthopedic surgery.82 In this trial by Kennedy and colleagues in 2000, patients who had hip fracture surgery were randomized to receive either aspirin or venous foot pump prophylaxis. In patients who received oral antiplatelet prophylaxis versus mechanical prophylaxis the odds of pulmonary embolism were not significantly different [OR 7.09 (0.14 to 357.70)]. Subgroup analyses were not possible since this was the only trial available.

###### Injectable Low Molecular Weight Heparin Agents Versus Injectable Unfractionated Heparin

Ten randomized controlled trials evaluated the impact of injectable low molecular weight heparin prophylaxis versus injectable unfractionated heparin prophylaxis on pulmonary embolism in patients who had major orthopedic surgery and one trial included two separate comparisons.55,57,61,62,71,74,86,96,97,105 Four trials were excluded from the analysis because no events occurred in the groups compared.57,74,96,97 In patients who received injectable low molecular weight heparin prophylaxis versus injectable unfractionated heparin prophylaxis the odds of pulmonary embolism were significantly decreased [OR 0.48 (0.24 to 0.95), NNT 8] (Appendix G Figure 67). A range could not be calculated for the NNT because the lowest control event rate was zero. A higher level of statistical heterogeneity was detected although publication bias was not detected (I^2^=59.7 percent, Egger's p-value=0.623). The direction of effect was similar in all trials and showed nonsignificant difference except for one trial. Heterogeneity, then, is likely due to differences in the magnitude of benefit.

When limiting the original analysis to trials published from 2001-present one trial remained although no events occurred therefore the risk of pulmonary embolism could not be calculated.97 When limiting the original analysis to total hip replacement surgery seven trials remained with one trial including two separate comparisons.55,57,61,71,86,96,97 In patients who received injectable low molecular weight heparin prophylaxis versus injectable unfractionated heparin prophylaxis the odds of pulmonary embolism were significantly decreased [OR 0.28 (0.13 to 0.62), NNT 8] (Appendix G Figure 68). A range could not be calculated for the NNT because the lowest control event rate was zero. Statistical heterogeneity was not detected (I^2^=0 percent). When limiting the original analysis to total knee replacement surgery two trials remained.62,74 One trial was excluded because no events occurred.74 In the remaining trial, in patients who received injectable low molecular weight heparin prophylaxis versus injectable unfractionated heparin prophylaxis the odds of pulmonary embolism were not significantly different [OR 0.13 (0.01 to 2.13)]. When limiting the original analysis to hip fracture surgery one trial remained.105 In this trial, in patients who received injectable low molecular weight heparin prophylaxis versus injectable unfractionated heparin prophylaxis the odds of pulmonary embolism were significantly increased [OR 7.95 (1.53 to 41.29)]. The NNT could not be calculated because the control event rate was zero. Statistical heterogeneity could not be evaluated because of too few studies.

Subgroup analyses based on age, gender and ethnicity were not possible because no randomized controlled trials reported data based on these subgroups.

One randomized controlled trial evaluated the impact of injectable low molecular weight heparin prophylaxis versus injectable unfractionated heparin prophylaxis on pulmonary embolism during the postdischarge period in patients who had total hip replacement surgery.61 This trial included two comparisons; enoxaparin 30mg every 12 hours or enoxaparin 40mg daily versus unfractionated heparin. In patients who received injectable low molecular weight heparin versus injectable unfractionated heparin the risk of pulmonary embolism during the postdischarge period was not significantly different [RR 0.13 (0.01 to 1.17)] (Appendix G Figure 69).

###### Injectable Low Molecular Weight Heparin Agents Versus Injectable or Oral Factor Xa Inhibitors

Two randomized controlled trials evaluated the impact of injectable low molecular weight heparin prophylaxis versus injectable or oral factor Xa inhibitor prophylaxis on pulmonary embolism in patients who had major orthopedic surgery.106,135 One trial by Yokote and colleagues was excluded because no events occurred in either of the treatment arms leaving only one trial by Bauer and colleagues in 2001. In this trial by Bauer and colleagues, patients who had total knee replacement surgery were randomized to receive enoxaparin or fondaparinux prophylaxis. In patients who received injectable low molecular weight heparin prophylaxis versus injectable or oral factor Xa inhibitor prophylaxis the odds of pulmonary embolism were not significantly different [OR 3.34 (0.58 to 19.32)]. Subgroup analyses were not possible because only one trial with events was available.

###### Injectable Low Molecular Weight Heparin Agents Versus Injectable or Oral Direct Thrombin Inhibitors

Three randomized controlled trials evaluated the impact of injectable low molecular weight heparin prophylaxis versus injectable or oral direct thrombin inhibitor prophylaxis on pulmonary embolism in patients who had major orthopedic surgery.66,67 69 Two trials by Eriksson and colleagues each provided two separate comparisons. In patients who received injectable low molecular weight heparin prophylaxis versus injectable or oral direct thrombin inhibitor prophylaxis the risk of pulmonary embolism was not significantly different [RR 1.18 (0.41 to 3.39)] (Appendix G Figure 70). Statistical heterogeneity and publication bias were not detected (I^2^=0 percent, Egger's p-value=0.208).

When limiting the original analysis to trials published from 2001-present, two trials remained with each including two separate comparisons.66,67 In patients who received injectable low molecular weight heparin prophylaxis versus injectable or oral direct thrombin inhibitor prophylaxis, the risk of pulmonary embolism was not significantly different [RR 1.25 (0.35 to 4.39)] (Appendix G Figure 71). Statistical heterogeneity was not detected (I^2^=0 percent). When limiting the original analysis to total hip replacement surgery two trials remained with one including two separate comparisons.67,69 In patients who received injectable low molecular weight heparin prophylaxis versus injectable or oral direct thrombin inhibitor prophylaxis the risk of pulmonary embolism was not significantly different [RR 1.03 (0.32 to 3.36)] (Appendix G Figure 72). Statistical heterogeneity was not detected (I^2^=0 percent). When limiting the original analysis to total knee replacement surgery one trial which included two separate comparisons remained.66 In patients who received injectable low molecular weight heparin prophylaxis versus injectable or oral direct thrombin inhibitor prophylaxis the risk of pulmonary embolism was not significantly different [RR 2.00 (0.18 to 22.02)] (Appendix G Figure 73). Statistical heterogeneity could not be evaluated because of too few studies. Subgroup analysis based on hip fracture surgery was not possible because no trials evaluated this surgical population.

Subgroup analyses based on age, gender and ethnicity were not possible because no randomized controlled trials reported data based on these subgroups.

One randomized controlled trial evaluated the impact of injectable low molecular weight heparin prophylaxis versus injectable or oral direct thrombin inhibitor prophylaxis on pulmonary embolism during the post discharge period in patients who had total hip replacement surgery.73 In patients who received injectable low molecular weight heparin versus injectable or oral direct thrombin inhibitor prophylaxis the odds of pulmonary embolism during the post discharge period were not significantly different [OR 3.89 (0.78 to 19.34)].

###### Injectable Low Molecular Weight Heparin Agents Versus Oral Vitamin K Antagonists

Five randomized controlled trials evaluated the impact of injectable low molecular weight prophylaxis versus oral vitamin K antagonist prophylaxis on pulmonary embolism in patients who had major orthopedic surgery.60,75,81,84,85 One trial included two separate comparisons although it was excluded from the analysis because no events occurred in the groups compared.81 In patients who received injectable low molecular weight heparin prophylaxis versus oral vitamin K antagonist prophylaxis the odds of pulmonary embolism were not significantly different [OR 1.11 (0.57 to 2.19)] (Appendix G Figure 74). A lower level of statistical heterogeneity was detected although the presence of publication bias was not detected (I^2^=28.7 percent, Egger's p-value=0.762).

When limiting the original analysis to trials published from 2001-present two trials remained.75,84 In patients who received injectable low molecular weight heparin prophylaxis versus oral vitamin K antagonist prophylaxis the odds of pulmonary embolism were not significantly different [OR 1.96 (0.20 to 18.94)] (Appendix G Figure 75). Statistical heterogeneity could not be evaluated because of too few studies. When limiting the original analysis to total hip replacement surgery two trials remained with one trial including two separate comparisons, although this latter trial was excluded because no events occurred in the groups compared.60,81 In the remaining trial, in patients who received injectable low molecular weight heparin prophylaxis versus oral vitamin K antagonist prophylaxis the odds of pulmonary embolism were not significantly different [OR 1.23 (0.58 to 2.63)]. When limiting the original analysis to total knee replacement surgery three trials remained.75,84,85 In patients who received injectable low molecular weight heparin prophylaxis versus oral vitamin K antagonist prophylaxis the odds of pulmonary embolism were not significantly different [OR 0.75 (0.17 to 3.31)] (Appendix G Figure 76). A lower level of statistical heterogeneity was detected (I^2^=48.2 percent). Subgroup analysis based on hip fracture surgery was not possible as no trials evaluated this surgical population.

Subgroup analyses based on age, gender and ethnicity were not possible because no randomized controlled trials reported data based on these subgroups.

One randomized controlled trial evaluated the impact of injectable low molecular weight heparin versus oral vitamin K antagonist prophylaxis on pulmonary embolism during the postdischarge period in patients who had major orthopedic surgery.80 This trial evaluated patients who had total hip or total knee replacement surgery and reported results separately. In patients who received injectable low molecular weight heparin versus oral vitamin K antagonist prophylaxis the odds of pulmonary embolism during the postdischarge period were not significantly different [OR 1.01 (0.06 to 16.14)] (Appendix G Figure 77). Similar results were seen when evaluating total hip replacement surgery [OR 7.37 (0.15 to 371.45)] or total knee replacement surgery [OR 0.14 (0.003 to 6.97)] separately.

###### Injectable Low Molecular Weight Heparin Agents Versus Mechanical Prophylaxis

One randomized controlled trial evaluated the impact of injectable low molecular weight heparin prophylaxis versus mechanical prophylaxis on pulmonary embolism in patients who had major orthopedic surgery.101 In this trial by Warwick and colleagues in 1998, patients who had total hip replacement surgery were randomized to receive enoxaparin or venous foot pump prophylaxis. In patients who received injectable low molecular weight heparin prophylaxis versus mechanical prophylaxis the odds of pulmonary embolism were not significantly different [OR 0.13 (0.003 to 6.72)]. Subgroup analyses were not possible because this was the only trial available.

###### Injectable Unfractionated Heparin Versus Injectable or Oral Direct Thrombin Inhibitors

Two randomized controlled trials evaluated the impact of injectable unfractionated heparin versus injectable or oral direct thrombin inhibitors on pulmonary embolism in patients who had major orthopedic surgery.68,69 In patients who received injectable unfractionated heparin versus injectable or oral direct thrombin inhibitors the odds of pulmonary embolism were not significantly different [OR 3.27 (0.56 to 18.98)] (Appendix G Figure 78). Statistical heterogeneity and publication bias could not be evaluated because of too few studies. This is the same result obtained when limiting the analysis to total hip replacement surgery as both trials evaluated this surgical population. Subgroup analysis based on trials published from 2001-present was not possible as both trials were published prior to 2001. Subgroup analyses based on total knee replacement or hip fracture surgery were not possible as no trials evaluated these surgical populations.

Subgroup analyses based on age, gender and ethnicity were not possible because no randomized controlled trials reported data based on these subgroups.

###### Injectable Unfractionated Heparin Versus Injectable or Oral Factor Xa Inhibitors

No randomized controlled trials or controlled observational studies evaluated the impact of injectable unfractionated heparin prophylaxis versus injectable or oral factor Xa inhibitor prophylaxis in patients who had major orthopedic surgery on this outcome.

###### Injectable Unfractionated Heparin Versus Mechanical Prophylaxis

No randomized controlled trials or controlled observational studies evaluated the impact of injectable unfractionated heparin prophylaxis versus mechanical prophylaxis in patients who had major orthopedic surgery on this outcome.

###### Oral Vitamin K Antagonists Versus Mechanical Prophylaxis

One randomized controlled trial evaluated the impact of oral vitamin K antagonist prophylaxis versus mechanical prophylaxis on pulmonary embolism in patients who had major orthopedic surgery although no events occurred therefore the risk of pulmonary embolism could not be calculated.90

##### Fatal Pulmonary Embolism

###### Oral Antiplatelet Agents Versus Oral Vitamin K Antagonists

One randomized controlled trial evaluated the impact of oral antiplatelet prophylaxis versus oral vitamin K antagonist prophylaxis on fatal pulmonary embolism in patients who had major orthopedic surgery.132 This trial by Powers and colleagues in 1989 evaluated patients who had hip fracture surgery. In patients who received oral antiplatelet prophylaxis versus oral vitamin K antagonist prophylaxis the odds of fatal pulmonary embolism were not significantly different [OR 7.28 (0.14 to 366.83)]. Subgroup analyses were not possible as only one trial was available.

One controlled observational study evaluated the impact of oral antiplatelet prophylaxis versus oral vitamin K antagonist prophylaxis on fatal pulmonary embolism in patients who had major orthopedic surgery.144 This study evaluated patients who had total hip replacement or total knee replacement surgery and who received aspirin or warfarin prophylaxis. A significantly higher percent of patients who received aspirin prophylaxis had a fatal pulmonary embolism compared with those who received warfarin prophylaxis (0.07 percent versus 0 percent, p<0.05).

###### Oral Antiplatelet Agents Versus Mechanical Prophylaxis

No randomized controlled trials or controlled observational studies evaluated the impact of oral antiplatelet prophylaxis versus mechanical prophylaxis in patients who had major orthopedic surgery on this outcome.

###### Injectable Low Molecular Weight Heparin Agents Versus Injectable Unfractionated Heparin

Ten randomized controlled trials evaluated the impact of injectable low molecular weight heparin prophylaxis versus injectable unfractionated heparin prophylaxis on fatal pulmonary embolism in patients who had major orthopedic surgery.57,61,62,71,74,86,93,96,97,105 Nine trials were excluded from the analysis because no events occurred in the groups compared.57,61,71,74,86,93,96,97,105 The remaining trial by Colwell and colleagues in 1995 evaluated patients who had total knee replacement surgery. In this trial, in patients who received injectable low molecular weight heparin prophylaxis versus injectable unfractionated heparin prophylaxis the odds of fatal pulmonary embolism were not significantly different [OR 0.13 (0.003 to 6.73)]. Subgroup analyses were not possible because only one trial with events was available.

###### Injectable Low Molecular Weight Heparin Agents Versus Injectable or Oral Factor Xa Inhibitors

Five randomized controlled trials evaluated the impact of injectable low molecular weight heparin prophylaxis versus injectable or oral factor Xa inhibitor prophylaxis on fatal pulmonary embolism in patients who had major orthopedic surgery.64,83,99,106,135 One trial by Yokote and colleagues was excluded from the analysis because no events occurred in either of the treatment arms; therefore four trials were included in the meta-analysis. In patients who received injectable low molecular weight heparin prophylaxis versus injectable or oral factor Xa inhibitor prophylaxis the odds of fatal pulmonary embolism were not significantly different [OR 0.90 (0.38 to 2.13)] (Appendix G Figure 79). Statistical heterogeneity and publication bias were not detected (I^2^=0 percent, Egger's p-value=0.744). This is the same result obtained when limiting the analysis to trials published from 2001-present.

When limiting the original analysis to total hip replacement surgery three trials remained.83,99,135 One trial by Yokote and colleagues was excluded from the analysis because no events occurred in either of the treatment arms, therefore only two trials were included in this meta-analysis. In patients who received injectable low molecular weight heparin prophylaxis versus injectable or oral factor Xa inhibitor prophylaxis the odds of fatal pulmonary embolism were not significantly different [OR 1.00 (0.14 to 7.10)] (Appendix G Figure 80). Statistical heterogeneity could not be evaluated because of too few studies. When limiting the original analysis to total knee replacement surgery, one trial remained.106 In this trial, in patients who received injectable low molecular weight heparin prophylaxis versus injectable or oral factor Xa inhibitor prophylaxis the odds of fatal pulmonary embolism were not significantly different [OR 1.00 (0.06 to 16.01)]. When limiting the original analysis to hip fracture surgery one trial remained.64 In this trial, in patients who received injectable low molecular weight heparin prophylaxis versus injectable or oral factor Xa inhibitor prophylaxis the odds of fatal pulmonary embolism were not significantly different [OR 0.87 (0.31 to 2.39)].

Subgroup analyses based on age, gender and ethnicity were not possible because no randomized controlled trials reported data based on these subgroups.

###### Injectable Low Molecular Weight Heparin Agents Versus Injectable or Oral Direct Thrombin Inhibitors

Two randomized controlled trials evaluated the impact of injectable low molecular weight heparin prophylaxis versus injectable or oral direct thrombin inhibitor prophylaxis on fatal pulmonary embolism in patients who had major orthopedic surgery.66,67 The trials by Eriksson and colleagues in 2007 both provided two separate comparisons.66,67 One arm of the trial by Eriksson and colleagues in 2007 comparing 220mg of dabigatran to injectable low molecular weight heparin in patients undergoing total hip replacement was excluded from the analysis because no events occurred in either group.67 In patients who received injectable low molecular weight heparin prophylaxis versus injectable or oral direct thrombin inhibitor prophylaxis the odds of fatal pulmonary embolism were not significantly different [OR 1.43 (0.08 to 24.82) (Appendix G Figure 81). A lower level of statistical heterogeneity was detected (I^2^=31.7 percent), but publication bias could not be evaluated because of too few studies. This is the same result obtained when limiting the analysis to trials published from 2001-present.

When limiting the original analysis to total hip replacement surgery one trial remained that provided two separate comparisons, one comparison was excluded from the analysis because no events occurred in either group.67 In the remaining comparison, in patients who received injectable low molecular weight heparin prophylaxis versus injectable or oral direct thrombin inhibitor prophylaxis the odds of fatal pulmonary embolism were not significantly different [OR 0.14 (0.003 to 6.91)]. When limiting the original analysis to total knee replacement surgery one trial that included two separate comparisons remained.66 In patients who received injectable low molecular weight heparin prophylaxis versus injectable or oral direct thrombin inhibitor prophylaxis the risk of fatal pulmonary embolism was not significantly different [RR 4.00 (0.36 to 44.03)] (Appendix G Figure 82). Statistical heterogeneity could not be evaluated because of too few studies. Subgroup analysis based on hip fracture surgery was not possible because no trials evaluated this surgical population.

Subgroup analyses based on age, gender and ethnicity were not possible because no randomized controlled trials reported data based on these subgroups.

One randomized controlled trial evaluated the impact of injectable low molecular weight heparin prophylaxis versus injectable or oral direct thrombin inhibitor prophylaxis on fatal pulmonary embolism during the postdischarge period in patients who had total hip replacement surgery.73 In patients who received injectable low molecular weight heparin versus injectable or oral direct thrombin inhibitor prophylaxis the odds of fatal pulmonary embolism during the postdischarge period were not significantly different [OR 0.14 (0.003 to 6.97)].

###### Injectable Low Molecular Weight Heparin Agents Versus Oral Vitamin K Antagonists

Four randomized controlled trials evaluated the impact of injectable low molecular weight heparin prophylaxis versus oral vitamin K antagonist prophylaxis on fatal pulmonary embolism in patients who had major orthopedic surgery.60,80,84,85 Three trials were excluded from the analysis because no events occurred in either group.80,84,85 The remaining trial by Colwell and colleagues in 1994 evaluated patients who had total hip replacement surgery. In this trial, in patients who received injectable low molecular weight heparin prophylaxis versus oral vitamin K antagonist prophylaxis the odds of fatal pulmonary embolism were not significantly different [OR 7.29 (0.14 to 367.30)]. Subgroup analyses were not possible as only one trial with events was available.

One randomized controlled trial evaluated the impact of injectable low molecular weight heparin versus oral vitamin K antagonist prophylaxis on fatal pulmonary embolism during the postdischarge period in patients who had major orthopedic surgery although no events occurred in the groups compared therefore the risk of fatal pulmonary embolism could not be calculated.80

###### Injectable Low Molecular Weight Heparin Agents Versus Mechanical Prophylaxis

Two randomized controlled trials evaluated the impact of injectable low molecular weight heparin prophylaxis versus mechanical prophylaxis on fatal pulmonary embolism in patients who had major orthopedic surgery.101,102 One trial was excluded from the analysis because no events occurred in either group compared.101 The remaining trial by Warwick and colleagues in 2002 evaluated patients who had total knee replacement surgery. In this trial, in patients who received injectable low molecular weight heparin prophylaxis versus mechanical prophylaxis the odds of fatal pulmonary embolism were not significantly different [OR 0.14 (0.01 to 2.25)]. Subgroup analyses were not possible as only one trial with events was available.

###### Injectable Unfractionated Heparin Versus Injectable or Oral Direct Thrombin Inhibitors

Two randomized controlled trials evaluated the impact of injectable unfractionated heparin prophylaxis versus oral direct thrombin inhibitor prophylaxis on fatal pulmonary embolism in patients who had major orthopedic surgery although no events occurred in either trial so the risk of fatal pulmonary embolism could not be evaluated.68 69

###### Injectable Unfractionated Heparin Versus Injectable or Oral Factor Xa Inhibitors

No randomized controlled trials or controlled observational studies evaluated the impact of injectable unfractionated heparin prophylaxis versus injectable or oral factor Xa inhibitor prophylaxis in patients who had major orthopedic surgery on this outcome.

###### Injectable Unfractionated Heparin Versus Mechanical Prophylaxis

No randomized controlled trials or controlled observational studies evaluated the impact injectable unfractionated heparin prophylaxis versus mechanical prophylaxis in patients who had major orthopedic surgery on this outcome.

###### Oral Vitamin K Antagonists Versus Mechanical Prophylaxis

One randomized controlled trial evaluated the impact of oral vitamin K antagonist prophylaxis versus mechanical prophylaxis in patients who had major orthopedic surgery although no events occurred in either group so the risk of fatal pulmonary embolism could not be evaluated.90

##### Nonfatal Pulmonary Embolism

###### Oral Antiplatelet Agents Versus Oral Vitamin K Antagonists

One randomized controlled trial evaluated the impact of oral antiplatelet agent prophylaxis versus oral vitamin K antagonist prophylaxis on nonfatal pulmonary embolism in patients who had major orthopedic surgery. However, no events occurred in either group and the risk of nonfatal pulmonary embolism could not be evaluated.132

One controlled observational study evaluated the impact of oral antiplatelet prophylaxis versus oral vitamin K antagonist prophylaxis on nonfatal pulmonary embolism in patients who had major orthopedic surgery.144 This study evaluated patients who had total hip replacement or total knee replacement surgery and who received aspirin or warfarin prophylaxis. There was no significant difference in the percent of patients who had a nonfatal pulmonary embolism comparing aspirin to warfarin prophylaxis (0.67 percent versus 0 percent, p=0.112).

###### Oral Antiplatelet Agents Versus Mechanical Prophylaxis

No randomized controlled trials or controlled observational studies evaluated the impact of oral antiplatelet prophylaxis versus mechanical prophylaxis in patients who had major orthopedic surgery on this outcome.

###### Injectable Low Molecular Weight Heparin Agents Versus Injectable Unfractionated Heparin

Ten randomized controlled trials evaluated the impact of injectable low molecular weight heparin prophylaxis versus injectable unfractionated heparin prophylaxis on nonfatal pulmonary embolism in patients who had major orthopedic surgery.57,61,62,71,74,86,93,96,97,105 Four trials were excluded from the analysis because no events occurred in the groups compared.57,74,96,97 In patients who received injectable low molecular weight heparin prophylaxis versus injectable unfractionated heparin prophylaxis the odds of nonfatal pulmonary embolism were not significantly different [OR 0.50 (0.25 to 1.00)] (Appendix G Figure 83). A higher level of statistical heterogeneity was detected but the presence of publication bias was not detected (I^2^=58.8 percent, Egger's p-value=0.634). The direction of effect was similar in all trials and showed nonsignificant difference except for one trial. Heterogeneity, then, is likely due to differences in the magnitude of benefit. When limiting the original analysis to trials published from 2001-present, one trial remained although no events occurred in the groups compared therefore the risk of nonfatal pulmonary embolism could not be evaluated.97 When limiting the original analysis to total hip replacement surgery seven trials remained.57,61,71,86,93,96,97 Three trials were excluded from the analysis because no events occurred in the groups compared.57,96,97 In patients who received injectable low molecular weight heparin prophylaxis versus injectable unfractionated heparin prophylaxis the odds of nonfatal pulmonary embolism were significantly decreased [OR 0.28 (0.13 to 0.62), NNT 6] (Appendix G Figure 84). A range for the number needed to treat could not be calculated because the lowest control event rate was zero. Statistical heterogeneity was not detected (I^2^=0 percent). When limiting the original analysis to total knee replacement surgery two trials remained.62,74 One trial was excluded from the analysis because no events occurred in either group compared.74 In the remaining trial, in patients who received injectable low molecular weight heparin prophylaxis versus injectable unfractionated heparin prophylaxis the odds of nonfatal pulmonary embolism were not significantly different [OR 0.13 (0.003 to 6.73)]. When limiting the original analysis to hip fracture surgery one trial remained.105 In this trial, in patients who received injectable low molecular weight heparin prophylaxis versus injectable unfractionated heparin prophylaxis the odds of nonfatal pulmonary embolism were significantly increased [OR 7.95 (1.53 to 41.29)]. The number needed to harm could not be calculated because the control event rate was zero.

Subgroup analyses based on age, gender and ethnicity were not possible because no randomized controlled trials reported data based on these subgroups.

One randomized controlled trial including two separate comparisons evaluated the impact of injectable low molecular weight heparin prophylaxis versus injectable unfractionated heparin prophylaxis on nonfatal pulmonary embolism during the postdischarge period in patients who had total hip replacement surgery.61 In this trial, patients who had total hip replacement surgery were randomized to receive either enoxaparin 30mg every 12 hours, enoxaparin 40mg daily or unfractionated heparin prophylaxis. In patients who received injectable low molecular weight heparin versus injectable unfractionated heparin the risk of nonfatal pulmonary embolism during the postdischarge period was not significantly different [RR 0.13 (0.01 to 1.17)] (Appendix G Figure 69).

###### Injectable Low Molecular Weight Heparin Agents Versus Injectable or Oral Factor Xa Inhibitors

Five randomized controlled trials evaluated the impact of injectable low molecular weight heparin prophylaxis versus injectable or oral factor Xa inhibitor prophylaxis on nonfatal pulmonary embolism in patients who had major orthopedic surgery.64,83,99,106,135 One trial by Yokote and colleagues was excluded from the analysis because no events occurred in either of the treatment groups, therefore four trials were included in the meta-analysis. In patients who received injectable low molecular weight heparin prophylaxis versus injectable or oral factor Xa inhibitor prophylaxis the odds of nonfatal pulmonary embolism were not significantly different [OR 0.68 (0.34 to 1.37)] (Appendix G Figure 85). A lower level of statistical heterogeneity was detected as was the presence of publication bias for studies in which the odds of nonfatal pulmonary embolism were decreased with low molecular weight heparin compared with Xa inhibitors (I^2^=49.5 percent, Egger's p-value=0.040). This is the same result obtained when limiting the analysis to trials published from 2001-present.

When limiting the original analysis to total hip replacement surgery three trials remained.83,99,135 of which one trial by Yokote and colleagues in 2011 was excluded from the analysis because no events occurred in either of the treatment groups. In patients who received injectable low molecular weight heparin prophylaxis versus injectable or oral factor Xa inhibitor prophylaxis the odds of nonfatal pulmonary embolism were significantly decreased [OR 0.39 (0.16 to 0.95), NNT 166] (Appendix G Figure 86). A range for the NNT could not be calculated since the lower bound of the control event rate was zero. Statistical heterogeneity could not be evaluated because of too few studies. When limiting the original analysis to total knee replacement surgery one trial remained.106 In this trial, in patients who received injectable low molecular weight heparin prophylaxis versus injectable or oral factor Xa inhibitor prophylaxis the odds of nonfatal pulmonary embolism were not significantly different [OR 1.95 (0.39 to 9.72)]. When limiting the original analysis to hip fracture surgery one trial remained.64 In patients who received injectable low molecular weight heparin prophylaxis versus injectable or oral factor Xa inhibitor prophylaxis the odds of nonfatal pulmonary embolism were not significantly different [OR 1.32 (0.30 to 5.81)].

Subgroup analyses based on age, gender and ethnicity were not possible because no randomized controlled trials reported data based on these subgroups.

###### Injectable Low Molecular Weight Heparin Agents Versus Injectable or Oral Direct Thrombin Inhibitors

Two randomized controlled trials evaluated the impact of injectable low molecular weight heparin prophylaxis versus injectable or oral direct thrombin inhibitor prophylaxis on nonfatal pulmonary embolism in patients who had major orthopedic surgery, and both trials included two separate comparisons.66,67 One arm of the trial by Eriksson and colleagues in 2007 comparing 220mg of dabigatran to injectable low molecular weight heparin in patients undergoing total knee replacement was excluded from the analysis because no events occurred in either group.66 In patients who received injectable low molecular weight heparin prophylaxis versus injectable or oral direct thrombin inhibitor prophylaxis the odds of nonfatal pulmonary embolism were not significantly different [OR 0.92 (0.23 to 3.66)] (Appendix G Figure 87). A higher level of statistical heterogeneity was detected (I^2^=53.7 percent), but publication bias could not be evaluated because of too few studies. This is the same result obtained when limiting the analysis to trials published from 2001-present.

When limiting the original analysis to total hip replacement surgery one trial remained that included two separate comparisons.67 In patients who received injectable low molecular weight heparin prophylaxis versus injectable or oral direct thrombin inhibitor prophylaxis the risk of nonfatal pulmonary embolism was not significantly different [RR 1.61 (0.13 to 19.37)] (Appendix G Figure 88). Statistical heterogeneity could not be evaluated because of too few studies. When limiting the original analysis to total knee replacement surgery one trial that included two separate comparisons remained. 66 One arm of the trial by Eriksson and colleagues in 2007 comparing 220mg of dabigatran to injectable low molecular weight heparin in patients undergoing total knee replacement was excluded from the analysis because no events occurred in either group.66 In the remaining comparison, in patients who received injectable low molecular weight heparin prophylaxis versus injectable or oral direct thrombin inhibitor prophylaxis the odds of nonfatal pulmonary embolism were not significantly different [OR 0.14 (0.003 to 6.93)]. Subgroup analysis based on hip fracture surgery was not possible because no trials evaluated this surgical population.

Subgroup analyses based on age, gender and ethnicity were not possible because no randomized controlled trials reported data based on these subgroups.

###### Injectable Low Molecular Weight Heparin Agents Versus Oral Vitamin K Antagonists

Three randomized controlled trials evaluated the impact of injectable low molecular weight prophylaxis versus oral vitamin K antagonist prophylaxis on nonfatal pulmonary embolism in patients who had major orthopedic surgery.80,84,85 The trial by Hull and colleagues in 1993 provided two separate comparisons, however the trial was excluded from the analysis because no events occurred in either comparison.80 In patients who received injectable low molecular weight heparin prophylaxis versus oral vitamin K antagonist prophylaxis the odds of nonfatal pulmonary embolism were not significantly different [OR 1.00 (0.20 to 4.95)] (Appendix G Figure 89). Statistical heterogeneity and publication bias could not be evaluated because of too few studies.

When limiting the original analysis to trials published from 2001-present one trial remained.84 In this trial, in patients who received injectable low molecular weight heparin prophylaxis versus oral vitamin K antagonist prophylaxis the odds of nonfatal pulmonary embolism were not significantly different [OR 7.46 (0.46 to 120.00)]. When limiting the original analysis to total hip replacement surgery one trial, contributing two separate comparisons remained, however no events occurred in any of the groups compared therefore the risk of nonfatal pulmonary embolism could not be calculated.80 When limiting the original analysis to total knee replacement, two trials remained.84,85 In patients who received injectable low molecular weight heparin prophylaxis versus oral vitamin K antagonist prophylaxis the odds of nonfatal pulmonary embolism were not significantly different [OR 1.00 (0.20 to 4.95)] (Appendix G Figure 90). Statistical heterogeneity and publication bias could not be evaluated because of too few studies. Subgroup analysis based on hip fracture surgery was not possible because no trials evaluated this surgical population.

Subgroup analyses based on age, gender and ethnicity were not possible because no randomized controlled trials reported data based on these subgroups.

One randomized controlled trial evaluated the impact of injectable low molecular weight heparin versus oral vitamin K antagonist prophylaxis on nonfatal pulmonary embolism during the postdischarge period in patients who had major orthopedic surgery.80 This trial evaluated patients who had total hip or total knee replacement surgery and reported results separately. In patients who received injectable low molecular weight heparin versus oral vitamin K antagonist prophylaxis the odds of nonfatal pulmonary embolism during the postdischarge period were not significantly different [OR 1.01 (0.06 to 16.14)] (Appendix G Figure 91). Similar results were seen when evaluating total hip replacement surgery [OR 7.37 (0.15 to 371.45)] or total knee replacement surgery [OR 0.14 (0.003 to 6.97)] separately.

###### Injectable Low Molecular Weight Heparin Agents Versus Mechanical Prophylaxis

One randomized controlled trials evaluated the impact of injectable low molecular weight heparin prophylaxis versus mechanical prophylaxis on nonfatal pulmonary embolism in patients who had major orthopedic surgery.101 In this trial by Warwick and colleagues in 1998, patients who had total hip replacement surgery were evaluated. In patients who received injectable low molecular weight heparin prophylaxis versus mechanical prophylaxis the odds of nonfatal pulmonary embolism were not significantly different [OR 0.13 (0.003 to 6.72)]. Subgroup analyses were not possible as only one trial was available.

###### Injectable Unfractionated Heparin Versus Injectable or Oral Direct Thrombin Inhibitors

Two randomized controlled trials evaluated the impact of injectable unfractionated heparin prophylaxis versus oral direct thrombin inhibitor prophylaxis on nonfatal pulmonary embolism in patients who had major orthopedic surgery.68,69 In patients who received injectable unfractionated heparin prophylaxis versus injectable or oral direct thrombin inhibitor prophylaxis the odds of nonfatal pulmonary embolism were not significantly different [OR 3.27 (0.56 to 18.98)] (Appendix G Figure 92). Statistical heterogeneity and publication bias could not be evaluated because of too few studies. This is the same result for trials limited to total hip replacement surgery. Subgroup analysis based on trials published from 2001-present, total knee replacement surgery or hip fracture surgery was not possible because no trials fit these criteria.

Subgroup analyses based on age, gender and ethnicity were not possible because no randomized controlled trials reported data based on these subgroups.

###### Injectable Unfractionated Heparin Versus Injectable or Oral Factor Xa Inhibitors

No randomized controlled trials or controlled observational studies evaluated the impact of injectable unfractionated heparin prophylaxis versus injectable or oral factor Xa inhibitor prophylaxis in patients who had major orthopedic surgery on this outcome.

###### Injectable Unfractionated Heparin Versus Mechanical Prophylaxis

No randomized controlled trials or controlled observational studies evaluated the impact injectable unfractionated heparin prophylaxis versus mechanical prophylaxis in patients who had major orthopedic surgery on this outcome.

###### Oral Vitamin K Antagonists Versus Mechanical Prophylaxis

One randomized controlled trial evaluated the impact of oral vitamin K antagonist prophylaxis versus mechanical prophylaxis on nonfatal pulmonary embolism in patients who had major orthopedic surgery although no events occurred in either group so the risk of nonfatal pulmonary embolism could not be evaluated.90

##### Post Thrombotic Syndrome

No randomized controlled trials or controlled observational studies compared between pharmacological and/or mechanical classes of prophylaxis to evaluate this outcome.

##### Mortality

###### Oral Antiplatelet Agents Versus Oral Vitamin K Antagonists

One randomized controlled trial evaluated the impact of oral antiplatelet agents versus oral vitamin K antagonists on mortality in patients who had major orthopedic surgery.132 In this trial by Powers and colleagues in 1989, patients who had hip fracture surgery were randomized to receive either aspirin or warfarin prophylaxis. In patients who received oral antiplatelet prophylaxis versus oral vitamin K antagonist prophylaxis, the risk of mortality was not significantly different [RR 0.98 (0.32 to 3.05)]. Subgroup analyses were not possible as this was the only trial available.

Two controlled observational studies evaluated the impact of oral antiplatelet prophylaxis versus oral vitamin K antagonist prophylaxis on mortality in patients who had major orthopedic surgery.144,148 The first study evaluated patients who had total hip replacement or total knee replacement surgery and who received aspirin or warfarin prophylaxis.144 A significantly higher percent of patients who received aspirin prophylaxis died compared with those who received warfarin prophylaxis (0.3 percent versus 0 percent, p=0.013). The second study evaluated patients who had total knee replacement surgery and who received either aspirin or warfarin prophylaxis.148 The odds of mortality for patients who received warfarin versus aspirin prophylaxis were not significantly different [AOR 0.54 (0.25 to 1.15)].

###### Oral Antiplatelet Agents Versus Mechanical Prophylaxis

No randomized controlled trials or controlled observational studies evaluated the impact of oral antiplatelet agents versus mechanical prophylaxis in patients who had major orthopedic surgery on this outcome.

###### Injectable Low Molecular Weight Heparin Agents Versus Injectable Unfractionated Heparin

Eight randomized controlled trials evaluated the impact of injectable low molecular weight heparins versus injectable unfractionated heparin on mortality in patients who had major orthopedic surgery with one trial by Colwell and colleagues including two separate comparisons.57,61,71,86,93,96,97,105 Five trials were excluded from the analysis because no events occurred in the groups compared.57,86,93,96,97 In patients who received injectable low molecular weight heparins versus injectable unfractionated heparin the odds of mortality were not significantly different [OR 0.39 (0.10 to 1.49)] (Appendix G Figure 93). Statistical heterogeneity and publication bias were not detected (I^2^=0 percent, Egger's p-value=0.102).

When limiting the original analysis to trials published from 2001-present, one trial remained although no events occurred in the groups compared therefore risk of mortality could not be calculated.97 When limiting the original analysis to total hip replacement surgery, seven trials remained, with the trial by Colwell and colleagues including two separate comparisons. Five trials were excluded from the analysis because no events occurred in the groups compared. In patients who received injectable low molecular weight heparin versus injectable unfractionated heparin, the odds of mortality in the two remaining trials were not significantly different [OR 0.21 (0.03 to 1.59)] (Appendix G Figure 94). Statistical heterogeneity was not detected (I^2^=0 percent). Subgroup analysis based on total knee replacement was not possible because no trials evaluated this surgical population. When limiting the original analysis to hip fracture surgery, one trial remained.105 In this trial, in patients who received injectable low molecular weight heparin agents versus injectable unfractionated heparin the risk of mortality was not significantly different [RR 0.64 (0.13 to 3.06)].

Subgroup analyses based on age, gender and ethnicity were not possible because no randomized controlled trials reported data based on these subgroups.

###### Injectable Low Molecular Weight Heparin Agents Versus Injectable or Oral Factor Xa Inhibitors

Five randomized controlled trials evaluated the impact of injectable low molecular weight heparin agents versus injectable or oral factor Xa inhibitors on mortality in patients who had major orthopedic surgery.64,83,99,106,135 One trial by Yokote and colleagues was excluded from the analysis because no events occurred in either of the treatment arms. In patients who received injectable low molecular weight heparin agents versus injectable or oral factor Xa inhibitors the odds of mortality were not significantly different [OR 1.08 (0.72 to 1.60)] (Appendix G Figure 95). Statistical heterogeneity and publication bias were not detected (I^2^=0 percent, Egger's p-value=0.952). This is the same result obtained when limiting the analysis to trials published from 2001-present since all four trials fit this criterion.

When limiting the original analysis to total hip replacement surgery, three trials remained.83,99,135 One trial by Yokote and colleagues was excluded from the analysis because no events occurred in either of the treatment arms. In patients who received injectable low molecular weight heparin agents versus injectable or oral factor Xa inhibitors the odds of mortality were not significantly different [OR 0.88 (0.32 to 2.42)] (Appendix G Figure 96). Statistical heterogeneity was not evaluated because of too few studies. When limiting the original analysis to total knee replacement surgery, one trial remained.106 In patients who received injectable low molecular weight heparin agents versus injectable or oral factor Xa inhibitors the odds of mortality were not significantly different [OR 1.49 (0.26 to 8.65)]. When limiting the original analysis to hip fracture surgery, one trial remained.64 In patients who received injectable low molecular weight heparin agents versus injectable or oral factor Xa inhibitors the odds of mortality were not significantly different [OR 1.10 (0.70 to 1.72)].

Subgroup analyses based on age, gender and ethnicity were not possible because no randomized controlled trials reported data based on these subgroups.

Two controlled observational studies evaluated the impact of injectable low molecular weight heparin prophylaxis versus injectable or oral factor Xa inhibitor prophylaxis on mortality in patients who had major orthopedic surgery.147,150 The first study by Shorr and colleagues in 2007 evaluated patients who had total hip replacement, total knee replacement, or hip fracture surgery and received either an injectable low molecular weight heparin (enoxaparin or dalteparin) or fondaparinux. Mortality was significantly decreased in patients who received fondaparinux (0.6 percent) versus injectable low molecular weight heparin (1.1 percent) (p< 0.001). The second study by Gerkens and colleagues in 2010 also evaluated patients who had total hip replacement, total knee replacement, or hip fracture surgery and received either enoxaparin or fondaparinux prophylaxis. Mortality was not significantly different between the two groups (2.2 percent versus 0.8 percent, respectively, p=0.461).

###### Injectable Low Molecular Weight Heparin Agents Versus Injectable or Oral Direct Thrombin Inhibitors

Four randomized controlled trials evaluated the impact of injectable low molecular weight heparin agents versus injectable or oral direct thrombin inhibitors on mortality in patients who had major orthopedic surgery with one trial by Ginsberg and two trials by Eriksson and colleagues including two separate comparisons.66,94 In patients who received injectable low molecular weight heparin agents versus injectable or oral direct thrombin inhibitors the risk of mortality was not significantly different [RR 0.45 (0.15 to 1.36)] (Appendix G Figure 97). Statistical heterogeneity was not detected (I^2^=0 percent). The presence of publication bias was detected (Egger's p-value=0.023) although the directionality of the publication bias was unclear.

When limiting the original analysis to trials published from 2001-present, three trials remained with all three trials including two separate comparisons.66,67,94 In patients who received injectable low molecular weight heparin agents versus injectable or oral direct thrombin inhibitors the risk of mortality was not significantly different [RR 0.54 (0.15 to 1.98)] (Appendix G Figure 98). Statistical heterogeneity was not detected (I^2^=0 percent). When limiting the original analysis to total hip replacement surgery, two trials remained with one trial by Eriksson and colleagues in 2007 including two separate comparisons.67,73 In patients who received injectable low molecular weight heparin agents versus injectable or oral direct thrombin inhibitors the risk of mortality was not significantly different [RR 0.27 (0.06 to 1.23)] (Appendix G Figure 99). Statistical heterogeneity was not detected (I^2^=0 percent). When limiting the original analysis to total knee replacement surgery, two trials remained with both trials including two separate comparisons.66,94 In patients who received injectable low molecular weight heparin agents versus injectable or oral direct thrombin inhibitors the risk of mortality was not significantly different [RR 0.80 (0.16 to 4.17)] (Appendix G Figure 100). Statistical heterogeneity was not detected (I^2^=0 percent). Subgroup analysis based on hip fracture surgery was not possible because no trials evaluated this surgical population.

Subgroup analyses based on age, gender and ethnicity were not possible because no randomized controlled trials reported data based on these subgroups.

In the dose finding trial by Eriksson and colleagues in 2005 four doses of dabigatran were compared with enoxaparin in patients who had total hip or total knee replacement surgery.65 During the treatment period, no deaths occurred in any of the groups however during the post treatment period, one death occurred in each of the dabigatran 50mg twice daily and dabigatran 225mg twice daily groups.

###### Injectable Low Molecular Weight Heparin Agents Versus Oral Vitamin K Antagonists

Six randomized controlled trials evaluated the impact of injectable low molecular weight heparin agents versus oral vitamin K antagonists on mortality in patients who had major orthopedic surgery with one trial by Hull and colleagues including two separate comparisons.60,75,80,81,84,85 One trial was excluded from the analysis because no events occurred in the groups compared.84 In patients who received injectable low molecular weight heparin agents versus oral vitamin K antagonists the odds of mortality were not significantly different [OR 0.79 (0.42 to 1.50)] (Appendix G Figure 101). Statistical heterogeneity and publication bias were not detected (I^2^=0 percent, Egger's p-value=0.188)

When limiting the original analysis to trials published from 2001-present, two trials remained.75,84 One trial was excluded from the analysis because no events occurred in the groups compared84 leaving one trial for the analysis. In this trial, in patients who received injectable low molecular weight heparin agents versus oral vitamin K antagonists the odds of mortality were not significantly different [OR 0.37 (0.05 to 2.66)]. When limiting the original analysis to total hip replacement surgery, two trials remained with one trial by Hull and colleagues including two separate comparisons.60,81 In patients who received injectable low molecular weight heparin agents versus oral vitamin K antagonists the risk of mortality was not significantly different [RR 0.81 (0.36 to 1.82)] (Appendix G Figure 102). Statistical heterogeneity was not detected (I^2^=0 percent). When limiting the original analysis to total knee replacement surgery, three trials remained.75,84,85 One trial was excluded from the analysis because no events occurred in the groups compared.84 In patients who received injectable low molecular weight heparin agents versus oral vitamin K antagonists the odds of mortality were not significantly different [OR 0.52 (0.10 to 2.57)] (Appendix G Figure 103). Statistical heterogeneity was not evaluated because of too few studies. Subgroup analysis based on hip fracture surgery was not possible because no trials evaluated this surgical population.

Subgroup analyses based on age, gender and ethnicity were not possible because no randomized controlled trials reported data based on these subgroups.

###### Injectable Low Molecular Weight Heparin Agents Versus Mechanical Prophylaxis

Two randomized controlled trials evaluated the impact of injectable low molecular weight heparin versus mechanical prophylaxis on mortality in patients who had major orthopedic surgery.101,102 In patients who received injectable low molecular weight heparin agents versus mechanical prophylaxis the odds of mortality were not significantly different [OR 0.31 (0.05 to 1.81)] (Appendix G Figure 104). Statistical heterogeneity and publication bias were not evaluated because of too few studies.

When limiting the original analysis to trials published from 2001-present, one trial remained.102 In this trial, in patients who received injectable low molecular weight heparin agents versus mechanical prophylaxis the odds of mortality were not significantly different [OR 0.38 (0.05 to 2.73)]. This is the same result obtained when limiting the analysis to total knee replacement surgery. When limiting the original analysis to total hip replacement surgery, one trial remained.101 In this trial, in patients who received injectable low molecular weight heparin agents versus mechanical prophylaxis the odds of mortality were not significantly different [OR 0.14 (0.003 to 7.01)]. Subgroup analysis based on hip fracture surgery was not possible because no trials evaluated this surgical population.

Subgroup analyses based on age, gender and ethnicity were not possible because no randomized controlled trials reported data based on these subgroups.

###### Injectable Unfractionated Heparin Versus Injectable or Oral Direct Thrombin Inhibitors

Two randomized controlled trials evaluated the impact of injectable unfractionated heparin versus injectable or oral direct thrombin inhibitors on mortality in patients who had major orthopedic surgery.68,69 In patients who received injectable unfractionated heparin versus injectable or oral direct thrombin inhibitors the odds of mortality were not significantly different [OR 7.13 (0.74 to 68.80)] (Appendix G Figure 105). Statistical heterogeneity and publication bias were not evaluated because of too few studies. This is the same result obtained when limiting the analysis to total hip replacement surgery. Subgroup analyses based on trials published from 2001-present, total knee replacement surgery and hip fracture surgery were not possible because no trials fit these criteria.

Subgroup analyses based on age, gender and ethnicity were not possible because no randomized controlled trials reported data based on these subgroups.

###### Injectable Unfractionated Heparin Versus Injectable or Oral Factor Xa Inhibitors

One controlled observational study evaluated the impact of injectable unfractionated heparin prophylaxis versus injectable or oral factor Xa inhibitor prophylaxis on mortality in patients who had major orthopedic surgery.147This study evaluated patients who had total hip replacement, total knee replacement, or hip fracture surgery and received either fondaparinux or injectable unfractionated heparin. Mortality was significantly decreased in patients who received fondaparinux (0.6 percent) versus injectable unfractionated heparin (2.2 percent) (p< 0.001 for both comparisons).

###### Injectable Unfractionated Heparin Versus Mechanical Prophylaxis

One randomized controlled trial evaluated the impact of injectable unfractionated heparin versus mechanical prophylaxis on mortality in patients who had major orthopedic surgery.95 In this trial by Santori and colleagues in 1994, patients who had total hip replacement surgery were randomized to receive either unfractionated heparin or venous foot pump prophylaxis. In patients who received injectable unfractionated heparin versus mechanical prophylaxis, the odds of mortality were not significantly different [OR 7.62 (0.15 to 384.19)]. Subgroup analyses were not possible as this was the only trial available.

###### Oral Vitamin K Antagonists Versus Mechanical Prophylaxis

Two randomized controlled trials evaluated the impact of oral vitamin K antagonists versus mechanical prophylaxis on mortality in patients who had major orthopedic surgery.56,76 One trial was excluded from the analysis because no events occurred in the groups compared,56 leaving the trial by Francis and colleagues in 1992.^76^ In this trial, patients who had total hip replacement surgery were randomized to receive either warfarin or intermittent pneumatic compression prophylaxis. In patients who received oral vitamin K antagonist prophylaxis versus mechanical prophylaxis, the odds of mortality were not significantly different [OR 0.95 (0.06 to 15.33)]. Subgroup analyses were not possible as this was the only trial available.

##### Mortality Due to Bleeding

###### Oral Antiplatelet Agents Versus Oral Vitamin K Antagonists

One randomized controlled trial evaluated the impact of oral antiplatelet prophylaxis versus oral vitamin K antagonist prophylaxis on mortality due to bleeding in patients who had major orthopedic surgery, however no events occurred and therefore the risk of mortality due to bleeding could not be calculated.132

###### Oral Antiplatelet Agents Versus Mechanical Prophylaxis

No randomized controlled trials or controlled observational studies evaluated the impact of oral antiplatelet prophylaxis versus mechanical prophylaxis in patients who had major orthopedic surgery on this outcome.

###### Injectable Low Molecular Weight Heparin Agents Versus Injectable Unfractionated Heparin

Seven randomized controlled trials evaluated the impact of injectable low molecular weight heparin prophylaxis versus injectable unfractionated heparin prophylaxis on mortality due to bleeding in patients who had major orthopedic surgery.57,71,86,93,96,97,105 Six trials were excluded from the pooled analysis because no events occurred in the groups compared.57,71,86,93,96,97 The remaining trial by Monreal and colleagues in 1989 evaluated patients who had hip fracture surgery.105 In this trial, in patients who received injectable low molecular weight heparin prophylaxis versus injectable unfractionated heparin prophylaxis, the odds of mortality due to bleeding were not significantly different [OR 0.13 (0.003 to 6.52)]. Subgroup analyses were not possible because only one trial with events was available.

###### Injectable Low Molecular Weight Heparin Agents Versus Injectable or Oral Factor Xa Inhibitors

Five randomized controlled trials evaluated the impact of injectable low molecular weight heparin prophylaxis versus injectable or oral factor Xa inhibitor prophylaxis on mortality due to bleeding in patients who had major orthopedic surgery.64,83,99,106,135 Four trials were excluded from the pooled analysis because no events occurred in the groups compared.83,99,106,135 The remaining trial by Eriksson and colleagues in 2001 evaluated patients who had hip fracture surgery.64 In this trial, in patients who received injectable low molecular weight heparin prophylaxis versus injectable or oral factor Xa inhibitor prophylaxis, the odds of mortality due to bleeding were not significantly different [OR 7.29 (0.14 to 367.58)]. Subgroup analyses were not possible because only one trial with events was available.

One controlled observational study evaluated the impact of injectable low molecular weight heparin versus oral or injectable factor Xa inhibitors in major orthopedic surgery.150 In this study patients who had total hip or knee replacement or hip fracture surgery received either enoxaparin or fondaparinux prophylaxis. Mortality due to bleeding was not significantly different between the groups (0.3 percent versus 0.0 percent, respectively, p=0.751).

###### Injectable Low Molecular Weight Heparin Agents Versus Injectable or Oral Direct Thrombin Inhibitors

Three randomized controlled trials evaluated the impact of injectable low molecular weight heparin prophylaxis versus injectable or oral direct thrombin inhibitor prophylaxis on mortality due to bleeding in patients who had major orthopedic surgery.66,67,94 Each trial included two separate comparisons, although two trials were excluded from the analysis because no events occurred in the groups compared.66,94 The remaining trial by Eriksson and colleagues in 2007 evaluated patients who had total hip replacement surgery and included two separate comparisons. In patients who received injectable low molecular weight heparin prophylaxis versus injectable or oral direct thrombin inhibitor prophylaxis, the risk of mortality due to bleeding was not significantly different [RR 0.67 (0.07 to 6.40)] (Appendix G Figure 106). Statistical heterogeneity and publication bias could not be evaluated because of too few studies. This is the same result obtained when limiting the original analysis to trials published from 2001-present as well as limiting the original analysis to total hip replacement surgery (Appendix G Figure 107). No events occurred in the two trials evaluating patients who had total knee replacement surgery,66,94 and no trials evaluated patients who had hip fracture surgery.

Subgroup analyses based on age, gender and ethnicity were not possible because no randomized controlled trials reported data based on these subgroups.

###### Injectable Low Molecular Weight Heparin Agents Versus Oral Vitamin K Antagonists

Four randomized controlled trials evaluated the impact of injectable low molecular weight heparin prophylaxis versus oral vitamin K antagonist prophylaxis on mortality due to bleeding in patients who had major orthopedic surgery.75,80,81,85 One trial included patients who had hip replacement or knee replacement surgery and presented outcomes separately for each surgery while another trial included two comparisons. However, both of these trials, along with a third, were excluded from the analysis because no events occurred in the groups compared.80,81,85 The remaining trial by Fitzgerald and colleagues in 2001 evaluated patients who had total knee replacement surgery. In patients who received injectable low molecular weight heparin prophylaxis versus oral vitamin K antagonist prophylaxis, the odds of mortality due to bleeding were not significantly different [OR 0.14 (0.003 to 6.94)] in this trial. Subgroup analyses were not possible because only one trial with events was available.

###### Injectable Low Molecular Weight Heparin Agents Versus Mechanical Prophylaxis

Two randomized controlled trials evaluated the impact of injectable low molecular weight heparin prophylaxis versus mechanical prophylaxis in patients who had major orthopedic surgery.101,102 One trial was excluded from the analysis because no events occurred in the groups compared, leaving one trial by Warwick and colleagues in 1998 that evaluated patients who had total hip replacement surgery. In patients who received injectable low molecular weight heparin prophylaxis versus mechanical prophylaxis, the odds of mortality due to bleeding were not significantly different [OR 0.14 (0.003 to 7.01)]. Subgroup analyses were not possible because only one trial with events was available.

###### Injectable Unfractionated Heparin Versus Injectable or Oral Direct Thrombin Inhibitors

Two randomized controlled trials evaluated the impact of injectable unfractionated heparin versus injectable or oral direct thrombin inhibitors on mortality due to bleeding in patients who had major orthopedic surgery.68,69 The risk of mortality due to bleeding could not be calculated because no events occurred in the groups compared.

###### Injectable Unfractionated Heparin Versus Injectable or Oral Factor Xa Inhibitors

No randomized controlled trials or controlled observational studies evaluated the impact of injectable unfractionated heparin prophylaxis versus injectable or oral factor Xa inhibitor prophylaxis in patients who had major orthopedic surgery on this outcome.

###### Injectable Unfractionated Heparin Versus Mechanical Prophylaxis

One randomized controlled trial evaluated the impact of injectable unfractionated heparin prophylaxis versus mechanical prophylaxis on mortality due to bleeding. Since no events occurred in the groups compared, the risk of mortality due to bleeding could not be calculated.95

###### Oral Vitamin K Antagonists Versus Mechanical Prophylaxis

Two randomized controlled trials evaluated the impact of oral vitamin K antagonist prophylaxis versus mechanical prophylaxis on mortality due to bleeding in patients who had major orthopedic surgery.56,76 The risk of mortality due to bleeding could not be calculated because no events occurred in the groups compared.

##### Health-Related Quality of Life

No randomized controlled trials or controlled observational studies evaluated the comparative efficacy between classes of prophylaxis in patients who had major orthopedic surgery on this outcome.

##### Deep Vein Thrombosis

###### Oral Antiplatelet Agents Versus Oral Vitamin K Antagonists

One randomized controlled trial evaluated the impact of oral antiplatelet agents versus oral vitamin K antagonists on deep vein thrombosis in patients who had major orthopedic surgery.88 In this trial by Lotke and colleagues in 1996, patients who had total hip replacement or total knee replacement surgery were randomized to receive either aspirin or warfarin prophylaxis. In patients who received oral antiplatelet prophylaxis versus oral vitamin K antagonist prophylaxis, the risk of deep vein thrombosis was not significantly different [RR 1.06 (0.87 to 1.30)]. Subgroup analyses were not possible as this was the only trial available. This trial also evaluated the impact of gender on the development of deep vein thrombosis in patients treated with aspirin or warfarin prophylaxis and reported no significant differences between males and females.

###### Oral Antiplatelet Agents Versus Mechanical Prophylaxis

Two randomized controlled trials evaluated the impact of oral antiplatelet agents versus mechanical prophylaxis on deep vein thrombosis in patients who had major orthopedic surgery with one trial by Hass and colleagues including two surgical populations; unilateral or bilateral total knee replacement.79,82 In patients who received oral antiplatelet prophylaxis versus mechanical prophylaxis, the risk of deep vein thrombosis was significantly increased [RR 1.63 (1.11 to 2.39), NNH 4 to 27] (Appendix G Figure 108). Statistical heterogeneity was not detected (I^2^=0 percent) and publication bias could not be evaluated because of too few studies.

Subgroup analyses based on trials published from 2001-present or total hip replacement surgery were not possible because no trials fit either of these criteria. When limiting the original analysis to total knee replacement surgery, one trial by Haas and colleagues which reported unilateral and bilateral total knee replacement surgery separately remained.79 In patients who received oral antiplatelet prophylaxis versus mechanical prophylaxis, the risk of deep vein thrombosis was significantly increased [RR 1.63 (1.08 to 2.44), NNH 4 to 8] (Appendix G Figure 109). Statistical heterogeneity was not evaluated because of too few studies. When limiting the original analysis to hip fracture surgery, one trial remained.82 In patients who received oral antiplatelet prophylaxis versus mechanical prophylaxis, the risk of deep vein thrombosis was not significantly different [RR 1.68 (0.55 to 5.19)].

Subgroup analyses based on age, gender and ethnicity were not possible because no randomized controlled trials reported data based on these subgroups.

###### Injectable Low Molecular Weight Heparin Agents Versus Injectable Unfractionated Heparin

Fourteen randomized controlled trials evaluated the impact of injectable low molecular weight heparin agents versus injectable unfractionated heparin on deep vein thrombosis in patients who had major orthopedic surgery with three trials including two separate comparisons.55,57,61-63,71,74,86,89,93,96,97,104,105 The trial by Rader and colleagues was excluded from the pooled analysis because all patients received heparin prophylaxis pre- and postoperatively prior to being randomized to receive enoxaparin or unfractionated heparin.104 When pooling the remaining thirteen trials, in patients who received injectable low molecular weight heparin agents versus injectable unfractionated heparin, the risk of deep vein thrombosis was significantly decreased [RR 0.80 (0.65 to 0.99), NNT 12 to 100] (Appendix G Figure 110). A lower level of statistical heterogeneity was detected although publication bias was not detected (I^2^=34.3 percent, Egger's p-value=0.808).

The trial by Rader and colleagues in 1998 that was excluded from the pooled analysis was evaluated separately.104 This trial evaluated patients who had total hip or total knee replacement surgery and reported outcomes separately. In patients who received injectable low molecular weight prophylaxis versus injectable unfractionated heparin prophylaxis the risk of deep vein thrombosis was not significantly different [RR 3.37 (0.70 to 16.17)] (Appendix G Figure 111). Statistical heterogeneity and publication bias could not be evaluated because of too few studies. Results were similar when evaluating the two surgical populations separately; total hip replacement [RR 1.60 (0.21 to 12.06)] and total knee replacement [RR 6.00 (0.99 to 37.43)].

When limiting the original pooled analysis of 13 trials to trials published from 2001-present, 1 trial remained.97 In patients who received injectable low molecular weight heparin agents versus injectable unfractionated heparin, the odds of deep vein thrombosis were not significantly different [OR 0.13 (0.01 to 2.15)]. When limiting the original analysis to total hip replacement surgery, 10 trials remained, with 3 of the trials including two separate comparisons.55,57,61,63,71,86,89,93,96,97 In patients who received injectable low molecular weight heparin versus injectable unfractionated heparin, the risk of deep vein thrombosis was significantly decreased [RR 0.75 (0.58 to 0.97), NNT 12 to 100] (Appendix G Figure 112). A lower level of statistical heterogeneity was detected (I^2^=26.4 percent). When limiting the original analysis to total knee replacement surgery, two trials remained.62,74 In patients who received injectable low molecular weight heparin versus injectable unfractionated heparin, the risk of deep vein thrombosis was significantly decreased [RR 0.75 (0.58 to 0.96), NNT 12 to 16] (Appendix G Figure 113). Statistical heterogeneity could not be evaluated because of too few studies. When limiting the original analysis to hip fracture surgery, one trial remained.105 In this trial, in patients who received injectable low molecular weight heparin agents versus injectable unfractionated heparin the risk of deep vein thrombosis was significantly increased [RR 2.19 (1.01 to 4.98), NNH 5].

One trial that compared low molecular weight heparin to unfractionated heparin evaluated the impact of age, gender, and ethnicity on deep vein thrombosis.61 No significant difference in the risk of deep vein thrombosis were found in patients who received low molecular weight heparin versus unfractionated heparin when evaluating those with an age less than 65 years, greater than 65 years, female gender, male gender, or black race. In patients of white race and randomized to enoxaparin 30mg twice daily versus unfractionated heparin, the risk of deep vein thrombosis was significant decreased (5 percent vs. 14 percent, p=0.03) although this effect was not seen when comparing enoxaparin 40mg daily to unfractionated heparin. Although the race categories of “Oriental/Asian” and “other” were also evaluated, risk could not be calculated because no events occurred in the groups compared. A second trial evaluated the impact of gender on the effect of prophylaxis in patients who received low molecular weight heparin versus unfractionated heparin and concluded that gender did not significantly impact the antithrombotic effect of the prophylactic regimens when evaluating deep vein thrombosis (40 percent females vs. 30 percent males, p=0.30).71

###### Injectable Low Molecular Weight Heparin Agents Versus Injectable or Oral Factor Xa Inhibitors

Five randomized controlled trials evaluated the impact of injectable low molecular weight heparin agents versus injectable or oral factor Xa inhibitors on deep vein thrombosis in patients who had major orthopedic surgery.64,83,99,106,135 In patients who received injectable low molecular weight heparin agents versus injectable or oral factor Xa inhibitors, the risk of deep vein thrombosis was significantly increased [RR 1.99 (1.57 to 2.51), NNH 13 to 26 ] (Appendix G Figure 114). A lower level of statistical heterogeneity was detected although publication bias was not detected (I^2^=42.5 percent, Egger's p-value=0.225). This is the same result obtained when limiting the analysis to trials published from 2001-present since all five trials fit this criterion.

When limiting the original analysis to total hip replacement surgery, three trials remained.83,99,135 In patients who received injectable low molecular weight heparin versus injectable or oral factor Xa inhibitors, the odds of deep vein thrombosis were significantly increased [OR 1.80 (1.38 to 2.34), NNH 21 to 34 ] (Appendix G Figure 115). A higher level of statistical heterogeneity was detected (I^2^=51.4 percent). When limiting the original analysis to total knee replacement surgery, one trial remained.106 In this trial, in patients who received injectable low molecular weight heparin versus injectable or oral factor Xa inhibitors, the risk of deep vein thrombosis was significantly increased [RR 2.18 (1.59 to 3.01), NNH 8]. When limiting the original analysis to hip fracture surgery, one trial remained.64 In this trial, in patients who received injectable low molecular weight heparin agents versus injectable or oral factor Xa inhibitors the risk of deep vein thrombosis was significantly increased [RR 2.39 (1.75 to 3.28), NNH 9].

Subgroup analyses based on age, gender and ethnicity were not possible because no randomized controlled trials reported data based on these subgroups.

###### Injectable Low Molecular Weight Heparin Agents Versus Injectable or Oral Direct Thrombin Inhibitors

One randomized controlled trial evaluated the impact of injectable low molecular weight heparin versus injectable or oral direct thrombin inhibitors on deep vein thrombosis in patients who had major orthopedic surgery.73 In this trial by Eriksson and colleagues in 1997, patients who had total hip replacement surgery were randomized to receive enoxaparin or desirudin prophylaxis. In patients who received injectable low molecular weight heparin agents versus injectable or oral direct thrombin inhibitor prophylaxis, the risk of deep vein thrombosis was significantly increased [RR 1.39 (1.15 to 1.68), NNH 15]. Subgroup analyses were not possible as this was the only trial available.

###### Injectable Low Molecular Weight Heparin Agents Versus Oral Vitamin K Antagonists

Five randomized controlled trials evaluated the impact of injectable low molecular weight heparin agents versus oral vitamin K antagonists on deep vein thrombosis in patients who had major orthopedic surgery with one trial including two separate comparisons and another trial reporting two surgical populations separately.75,77,80,81,85 In patients who received injectable low molecular weight heparin agents versus oral vitamin K antagonists, the risk of deep vein thrombosis was significantly decreased [RR 0.66 (0.55 to 0.79), NNT 6 to 13] (Appendix G Figure 116). A higher level of statistical heterogeneity and the presence of publication bias for studies in which the risk of deep vein thrombosis was increased with low molecular weight heparin compared with vitamin K antagonists was detected (I^2^=60.9 percent, Egger's p-value=0.033). The direction of effect was similar in all trials and four of the five trials and one of two arms in another trial found significant superiority of injectable low molecular heparins versus oral vitamin K antagonists individually. Heterogeneity, then, is due to differences in the magnitude of benefit.

When limiting the original analysis to trials published from 2001-present, one trial remained.75 In patients who received injectable low molecular weight heparin agents versus oral vitamin K antagonists, the risk of deep vein thrombosis was significantly decreased [RR 0.57 (0.42 to 0.76), NNT 6]. When limiting the original analysis to total hip replacement surgery, three trials remained, with the one trial including two separate comparisons.77,80,81 In patients who received injectable low molecular weight heparin versus oral vitamin K antagonists, the risk of deep vein thrombosis was significantly decreased [RR 0.61 (0.44 to 0.84), NNT 10 to 12] (Appendix G Figure 117). A higher level of statistical heterogeneity was detected (I^2^=67.6 percent). When limiting the original analysis to total knee replacement surgery, three trials remained.75,80,85 In patients who received injectable low molecular weight heparin versus oral vitamin K antagonists, the risk of deep vein thrombosis was significantly decreased [RR 0.71 (0.57 to 0.87), NNT 7 to 11] (Appendix G Figure 118). A higher level of statistical heterogeneity was detected (I^2^=57.2 percent). Subgroup analysis based on hip fracture surgery was not possible because no trials evaluated this surgical population.

Subgroup analyses based on age, gender and ethnicity were not possible because no randomized controlled trials reported data based on these subgroups.

###### Injectable Low Molecular Weight Heparin Agents Versus Mechanical Prophylaxis

Three randomized controlled trials evaluated the impact of injectable low molecular weight heparin agents versus mechanical prophylaxis on deep vein thrombosis in patients who had major orthopedic surgery. 98,101,102 In patients who received injectable low molecular weight heparin agents versus mechanical prophylaxis, the risk of deep vein thrombosis was not significantly different [RR 0.90 (0.71 to 1.14)] (Appendix G Figure 119). Statistical heterogeneity was not detected (I^2^=0 percent) and publication bias could not be evaluated because of too few studies.

When limiting the original analysis to trials published from 2001-present, one trial remained.102 In this trial, in patients who received injectable low molecular weight heparin agents versus mechanical prophylaxis, the risk of deep vein thrombosis was not significantly different [RR 0.94 (0.72 to 1.21)]. This is the same result obtained when limiting the original analysis to total knee replacement surgery. When limiting the original analysis to total hip replacement surgery, two trials remained.98,101 In patients who received injectable low molecular weight heparin agents versus mechanical prophylaxis, the risk of deep vein thrombosis was not significantly different [RR 0.75 (0.43 to 1.30)] (Appendix G Figure 120). Statistical heterogeneity could not be evaluated because of too few studies. Subgroup analysis based on hip fracture surgery was not possible because no trials evaluated this surgical population.

Subgroup analyses based on age, gender and ethnicity were not possible because no randomized controlled trials reported data based on these subgroups.

###### Injectable Unfractionated Heparin Versus Injectable or Oral Direct Thrombin Inhibitors

Two randomized controlled trials evaluated the impact of injectable unfractionated heparin agents versus injectable or oral direct thrombin inhibitor prophylaxis on deep vein thrombosis in patients who had major orthopedic surgery.68,69 In patients who received injectable unfractionated heparin agents versus injectable or oral direct thrombin inhibitors, the risk of deep vein thrombosis was significantly increased [RR 2.31 (1.34 to 4.00) NNH 5 to 11] (Appendix G Figure 121). Statistical heterogeneity and publication bias could not be evaluated because of too few studies. This is the same result obtained when limiting the analysis to total hip replacement surgery. Subgroup analyses based on trials published from 2001-present, total knee replacement surgery or hip fracture surgery were not possible because no trials fit these criteria.

Subgroup analyses based on age, gender and ethnicity were not possible because no randomized controlled trials reported data based on these subgroups.

###### Injectable Unfractionated Heparin Versus Injectable or Oral Factor Xa Inhibitors

No randomized controlled trials or controlled observational studies evaluated the impact of injectable unfractionated heparin prophylaxis versus injectable or oral factor Xa inhibitor prophylaxis in patients who had major orthopedic surgery on this outcome.

###### Injectable Unfractionated Heparin Versus Mechanical Prophylaxis

One randomized controlled trial evaluated the impact of injectable unfractionated heparin versus mechanical prophylaxis on deep vein thrombosis in patients who had major orthopedic surgery.95 In this trial by Santori and colleagues in 1994, patients who had total hip replacement surgery were randomized to receive either unfractionated heparin or venous foot pump prophylaxis. In patients who received injectable unfractionated heparin versus mechanical prophylaxis, the risk of deep vein thrombosis was significantly increased [RR 2.63 (1.36 to 5.25) NNH 5]. Subgroup analyses were not possible as this was the only trial available.

###### Oral Vitamin K Antagonists Versus Mechanical Prophylaxis

Three randomized controlled trials evaluated the impact of oral vitamin K antagonists versus mechanical prophylaxis on deep vein thrombosis in patients who had major orthopedic surgery.56,76,90 In patients who received oral vitamin K antagonists versus mechanical prophylaxis, the risk of deep vein thrombosis was not significantly different [RR 1.45 (0.75 to 2.82)] (Appendix G Figure 122). A higher level of statistical heterogeneity was detected (I^2^=58.5 percent) although publication bias could not be evaluated because of too few studies. This is the same result obtained when limiting the analysis to total hip replacement surgery. Subgroup analyses based on trials published from 2001-present, total knee replacement surgery or hip fracture surgery were not possible because no trials fit these criteria.

Subgroup analyses based on age, gender and ethnicity were not possible because no randomized controlled trials reported data based on these subgroups.

##### Asymptomatic Deep Vein Thrombosis

###### Oral Antiplatelet Agents Versus Oral Vitamin K Antagonists

No randomized controlled trials or controlled observational studies evaluated the impact of pharmacologic prophylaxis versus no prophylaxis in patients who had major orthopedic surgery on this outcome.

###### Oral Antiplatelet Agents Versus Mechanical Prophylaxis

One randomized controlled trial evaluated the impact or oral antiplatelet agent prophylaxis versus mechanical prophylaxis on asymptomatic deep vein thrombosis in patients who had major orthopedic surgery.82 This trial by Kennedy and colleagues in 2000 evaluated patients who had hip fracture surgery. In patients who received oral antiplatelet agent prophylaxis versus mechanical prophylaxis the odds of asymptomatic deep vein thrombosis were not significantly different [OR 1.45 (0.24 to 8.56)]. Subgroup analyses were not possible as only one trial was available.

###### Injectable Low Molecular Weight Heparin Agents Versus Injectable Unfractionated Heparin

Two randomized controlled trials evaluated the impact of injectable low molecular weight heparin prophylaxis versus injectable unfractionated heparin prophylaxis on asymptomatic deep vein thrombosis in patients who had major orthopedic surgery.71,96 In patients who received injectable low molecular weight heparin prophylaxis versus injectable unfractionated heparin prophylaxis the risk of asymptomatic deep vein thrombosis was not significantly different [RR 0.70 (0.43 to 1.16)] (Appendix G Figure 123). Statistical heterogeneity and publication bias could not be evaluated because of too few studies. This result is the same when limiting the analysis to total hip replacement surgery. Subgroup analysis based on trials published 2001-present, hip fracture surgery and total knee replacement surgery were not possible because no trials fit these criteria.

Subgroup analyses based on age, gender and ethnicity were not possible because no randomized controlled trials reported data based on these subgroups.

###### Injectable Low Molecular Weight Heparin Agents Versus Injectable or Oral Factor Xa Inhibitors

No randomized controlled trials or controlled observational studies evaluated the impact of injectable low molecular weight heparin prophylaxis versus injectable or oral factor Xa inhibitor prophylaxis in patients who had major orthopedic surgery on this outcome.

###### Injectable Low Molecular Weight Heparin Agents Versus Injectable or Oral Direct Thrombin Inhibitors

Two randomized controlled trials evaluated the impact of injectable low molecular weight heparin prophylaxis versus injectable or oral direct thrombin inhibitor prophylaxis on asymptomatic deep vein thrombosis in patients who had major orthopedic surgery, and both contributed two separate comparisons.66,67 In patients who received injectable low molecular weight heparin prophylaxis versus injectable or oral direct thrombin inhibitor prophylaxis the risk of asymptomatic deep vein thrombosis was not significantly different [RR 0.97 (0.85 to 1.10)] (Appendix G Figure 124). Statistical heterogeneity and publication bias were not detected (I^2^=0 percent, Egger's p-value=0.536). This is the same result obtained when limiting the analysis to trials published from 2001-present.

When limiting the original analysis to total hip replacement surgery one trial remained and provided two separate comparisons.67 In patients who received injectable low molecular weight heparin prophylaxis versus injectable or oral direct thrombin inhibitor prophylaxis the risk of asymptomatic deep vein thrombosis was not significantly different [RR 1.08 (0.69 to 1.69)] (Appendix G Figure 125). Statistical heterogeneity could not be evaluated because of too few studies. When limiting the original analysis to total knee replacement surgery one trial that included two separate comparisons remained.66 In patients who received injectable low molecular weight heparin prophylaxis versus injectable or oral direct thrombin inhibitor prophylaxis the risk of asymptomatic deep vein thrombosis was not significantly different [RR 0.95 (0.83 to 1.09)] (Appendix G Figure 126). Statistical heterogeneity could not be evaluated because of too few studies. Subgroup analysis based on hip fracture surgery was not possible because no trials evaluated this surgical population.

Subgroup analyses based on age, gender and ethnicity were not possible because no randomized controlled trials reported data based on these subgroups.

###### Injectable Low Molecular Weight Heparin Agents Versus Oral Vitamin K Antagonists

One randomized controlled trial evaluated the impact of injectable low molecular weight prophylaxis versus oral vitamin K antagonist prophylaxis on asymptomatic deep vein thrombosis in patients who had major orthopedic surgery.84 This trial by Lassen and colleagues in 2007 evaluated patients who had total knee replacement surgery. In patients who received injectable low molecular weight heparin prophylaxis versus oral vitamin K antagonist prophylaxis the risk of asymptomatic deep vein thrombosis was significantly decreased [RR 0.50 (0.28 to 0.88), NNT 8]. Subgroup analyses were not possible as only one trial was available.

###### Injectable Low Molecular Weight Heparin Agents Versus Mechanical Prophylaxis

One randomized controlled trial evaluated the impact of injectable low molecular weight heparin prophylaxis versus mechanical prophylaxis on asymptomatic deep vein thrombosis in patients who had major orthopedic surgery.98 This trial by Stone and colleagues in 1996 evaluated patients who had total hip replacement surgery. In patients who received injectable low molecular weight heparin prophylaxis versus mechanical prophylaxis the odds of asymptomatic deep vein thrombosis were not significantly different [OR 1.00 (0.06 to 16.45)]. Subgroup analyses were not possible as only one trial was available.

###### Injectable Unfractionated Heparin Versus Injectable or Oral Direct Thrombin Inhibitors

No randomized controlled trials or controlled observational studies evaluated the impact of injectable unfractionated heparin prophylaxis versus injectable or oral direct thrombin inhibitor prophylaxis in patients who had major orthopedic surgery on this outcome.

###### Injectable Unfractionated Heparin Versus Injectable or Oral Factor Xa Inhibitors

No randomized controlled trials or controlled observational studies evaluated the impact of injectable unfractionated heparin prophylaxis versus injectable or oral factor Xa inhibitor prophylaxis in patients who had major orthopedic surgery on this outcome.

###### Injectable Unfractionated Heparin Versus Mechanical Prophylaxis

No randomized controlled trials or controlled observational studies evaluated the impact injectable unfractionated heparin prophylaxis versus mechanical prophylaxis in patients who had major orthopedic surgery on this outcome.

###### Oral Vitamin K Antagonists Versus Mechanical Prophylaxis

No randomized controlled trials or controlled observational studies evaluated the impact of oral vitamin K antagonist prophylaxis versus mechanical prophylaxis in patients who had major orthopedic surgery on this outcome.

##### Symptomatic Deep Vein Thrombosis

###### Oral Antiplatelet Agents Versus Oral Vitamin K Antagonists

No randomized controlled trials or controlled observational studies evaluated the impact of oral antiplatelet prophylaxis versus oral vitamin K antagonist prophylaxis in patients who had major orthopedic surgery on this outcome.

###### Oral Antiplatelet Agents Versus Mechanical Prophylaxis

One randomized controlled trial evaluated the impact or oral antiplatelet prophylaxis versus mechanical prophylaxis on symptomatic deep vein thrombosis in patients who had major orthopedic surgery.82 This trial by Kennedy and colleagues in 2000 evaluated patients who had hip fracture surgery. In patients who received oral antiplatelet agent prophylaxis versus mechanical prophylaxis the odds of symptomatic deep vein thrombosis were not significantly different [OR 1.91 (0.37 to 9.75)]. Subgroup analyses were not possible as only one trial was available.

###### Injectable Low Molecular Weight Heparin Agents Versus Injectable Unfractionated Heparin

Three randomized controlled trials evaluated the impact of injectable low molecular weight heparin prophylaxis versus injectable unfractionated heparin prophylaxis on symptomatic deep vein thrombosis in patients who had major orthopedic surgery.55,71,96 In patients who received injectable low molecular weight heparin prophylaxis versus injectable unfractionated heparin prophylaxis the odds of symptomatic deep vein thrombosis were not significantly different [OR 0.62 (0.22 to 1.75)] (Appendix G Figure 127). Statistical heterogeneity was not detected (I^2^=0 percent) but publication bias could not be evaluated because of too few studies. This result is the same when limiting the original analysis to total hip replacement surgery. Subgroup analysis based on trials published 2001-present, total knee replacement and hip fracture surgery were not possible because no trials fit these criteria.

Subgroup analyses based on age, gender and ethnicity were not possible because no randomized controlled trials reported data based on these subgroups.

Two randomized controlled trials evaluated the impact of injectable low molecular weight heparin prophylaxis versus injectable unfractionated heparin prophylaxis on symptomatic deep vein thrombosis during the postdischarge period in patients who had major orthopedic surgery.74,97 In patients who received injectable low molecular weight heparin versus injectable unfractionated heparin the odds of symptomatic deep vein thrombosis during the postdischarge period were not significantly different [OR 1.96 (0.20 to 19.02)] (Appendix G Figure 128). Similar results were seen when evaluating total hip replacement surgery [OR 7.54 (0.47 to 122.28)]97 or total knee replacement surgery [OR 0.14 (0.003 to 6.90)]74 separately.

###### Injectable Low Molecular Weight Heparin Agents Versus Injectable or Oral Factor Xa Inhibitors

Six randomized controlled trials evaluated the impact of injectable low molecular weight heparin prophylaxis versus injectable or oral factor Xa inhibitor prophylaxis on symptomatic deep vein thrombosis patients who had major orthopedic surgery.58,64,83,99,106,135 In patients who received injectable low molecular weight heparin prophylaxis versus injectable or oral factor Xa inhibitor prophylaxis the odds of symptomatic deep vein thrombosis were not significantly different [OR 0.48 (0.21 to 1.12)] (Appendix G Figure 129). Statistical heterogeneity and the presence of publication bias were not detected (I^2^=0 percent, Egger's p-value=0.583). This result is the same when limiting the original analysis trials published from 2001-present.

When limiting the original analysis to total hip replacement surgery three trials remained.83,99,135 In patients who received injectable low molecular weight heparin prophylaxis versus injectable or oral factor Xa inhibitor prophylaxis the odds of symptomatic deep vein thrombosis were significantly decreased [OR 0.20 (0.06 to 0.70), NNT 413 to 416] (Appendix G Figure 130). Statistical heterogeneity was not detected (I^2^=0 percent). When limiting the original analysis to total knee replacement surgery two trials remained.58,106 In patients who received injectable low molecular weight heparin prophylaxis versus injectable or oral factor Xa inhibitor prophylaxis the odds of symptomatic deep vein thrombosis were not significantly different [OR 1.01 (0.29 to 3.49)] (Appendix G Figure 131). Statistical heterogeneity could not be evaluated because of too few studies. When limiting the original analysis to hip fracture surgery one trial remained.64 In this trial, in patients who received injectable low molecular weight heparin prophylaxis versus injectable or oral factor Xa inhibitor prophylaxis the odds of symptomatic deep vein thrombosis were not significantly different [OR 0.99 (0.06 to 15.83)].

Subgroup analyses based on age, gender and ethnicity were not possible because no randomized controlled trials reported data based on these subgroups.

###### Injectable Low Molecular Weight Heparin Agents Versus Injectable or Oral Direct Thrombin Inhibitors

Three randomized controlled trials evaluated the impact of injectable low molecular weight heparin prophylaxis versus injectable or oral direct thrombin inhibitor prophylaxis on symptomatic deep vein thrombosis in patients who had major orthopedic surgery, and all three provided two separate comparisons.66,67,94 In patients who received injectable low molecular weight heparin prophylaxis versus injectable or oral direct thrombin inhibitor prophylaxis the risk of symptomatic deep vein thrombosis was not significantly different [RR 0.98 (0.34 to 2.87)] (Appendix G Figure 132). A lower level of statistical heterogeneity was detected but the presence of publication bias was not detected (I^2^=47.5 percent, Egger's p-value=0.476). This result is the same when limiting the original analysis to trials published from 2001-present.

When limiting the original analysis to total hip replacement surgery one trial remained and provided two separate comparisons.67 In patients who received injectable low molecular weight heparin prophylaxis versus injectable or oral direct thrombin inhibitor prophylaxis the risk of symptomatic deep vein thrombosis was not significantly different [RR 0.14 (0.02 to 1.03)] (Appendix G Figure 133). Statistical heterogeneity could not be evaluated because of too few studies. When limiting the original analysis to total knee replacement surgery two trials that included two separate comparisons remained.66,94 In patients who received injectable low molecular weight heparin prophylaxis versus injectable or oral direct thrombin inhibitor prophylaxis the risk of symptomatic deep vein thrombosis was not significantly different [RR 1.55 (0.58 to 4.20)] (Appendix G Figure 134). A lower level of statistical heterogeneity was detected (I^2^=35 percent). Subgroup analysis based on hip fracture surgery was not possible because no trials evaluated this surgical population.

Subgroup analyses based on age, gender and ethnicity were not possible because no randomized controlled trials reported data based on these subgroups.

One randomized controlled trial evaluated the impact of injectable low molecular weight heparin prophylaxis versus injectable or oral direct thrombin inhibitor prophylaxis on symptomatic deep vein thrombosis during the postdischarge period in patients who had total hip replacement surgery.73 In patients who received injectable low molecular weight heparin versus injectable or oral direct thrombin inhibitor prophylaxis the odds of symptomatic deep vein thrombosis during the postdischarge period were not significantly different [OR 0.51 (0.14 to 1.91)].

###### Injectable Low Molecular Weight Heparin Agents Versus Oral Vitamin K Antagonists

Three randomized controlled trials evaluated the impact of injectable low molecular weight prophylaxis versus oral vitamin K antagonist prophylaxis on symptomatic deep vein thrombosis in patients who had major orthopedic surgery.60,80,84 The trial by Hull and colleagues in 1993 provided two separate comparisons.80 In patients who received injectable low molecular weight heparin prophylaxis versus oral vitamin K antagonist prophylaxis the odds of symptomatic deep vein thrombosis were not significantly different [OR 0.87 (0.61 to 1.24)] (Appendix G Figure 135). A lower level of statistical heterogeneity was detected but the presence of publication bias was not detected (I^2^=28.4 percent, Egger's p-value=0.376).

When limiting the original analysis to trials published from 2001-present one trial remained.84 In this trial, in patients who received injectable low molecular weight heparin prophylaxis versus oral vitamin K antagonist prophylaxis the odds of symptomatic deep vein thrombosis were not significantly different [OR 1.00 (0.06 to 16.09)]. This is the same result obtained when limiting the original analysis to total knee replacement surgery. When limiting the original analysis to total hip replacement surgery two trials remained.60,80 The trial by Colwell and colleagues in 1999 contributed two separate comparisons.60 In patients who received injectable low molecular weight heparin prophylaxis versus oral vitamin K antagonist prophylaxis the odds of symptomatic deep vein thrombosis were not significantly different [OR 0.87 (0.60 to 1.24)] (Appendix G Figure 136). A higher level of statistical heterogeneity was detected (I^2^=52.5 percent). Subgroup analysis based on hip fracture surgery was not possible because no trials evaluated this surgical population.

Subgroup analyses based on age, gender and ethnicity were not possible because no randomized controlled trials reported data based on these subgroups.

###### Injectable Low Molecular Weight Heparin Agents Versus Mechanical Prophylaxis

Two randomized controlled trials evaluated the impact of injectable low molecular weight heparin prophylaxis versus mechanical prophylaxis on symptomatic deep vein thrombosis in patients who had major orthopedic surgery.98,101 The trial by Stone and colleagues was excluded from the analysis because no events occurred in either group.98 In remaining trial by Warwick and colleagues in 1998 patients who had total hip replacement surgery were evaluated. In this trial, in patients who received injectable low molecular weight heparin prophylaxis versus mechanical prophylaxis the odds of symptomatic deep vein thrombosis were not significantly different [OR 7.28 (0.14 to 367.07)]. Subgroup analyses were not possible because only one trial with events was available.

###### Injectable Unfractionated Heparin Versus Injectable or Oral Direct Thrombin Inhibitors

No randomized controlled trials or controlled observational studies evaluated the impact of injectable unfractionated heparin prophylaxis versus injectable or oral direct thrombin inhibitor prophylaxis in patients who had major orthopedic surgery on this outcome.

One randomized controlled trial evaluated the impact of injectable unfractionated heparin versus injectable or oral direct thrombin inhibitor prophylaxis on symptomatic deep vein thrombosis during the postdischarge period in patients who had total hip replacement surgery.69 In patients who received injectable unfractionated heparin versus injectable or oral direct thrombin inhibitor prophylaxis the odds of symptomatic deep vine thrombosis during the pos-discharge period were not significantly different [OR 1.50 (0.26 to 8.74)].

###### Injectable Unfractionated Heparin Versus Injectable or Oral Factor Xa Inhibitors

No randomized controlled trials or controlled observational studies evaluated the impact of injectable unfractionated heparin prophylaxis versus injectable or oral factor Xa inhibitor prophylaxis in patients who had major orthopedic surgery on this outcome.

###### Injectable Unfractionated Heparin Versus Mechanical Prophylaxis

No randomized controlled trials or controlled observational studies evaluated the impact injectable unfractionated heparin prophylaxis versus mechanical prophylaxis in patients who had major orthopedic surgery on this outcome.

###### Oral Vitamin K Antagonists Versus Mechanical Prophylaxis

No randomized controlled trials or controlled observational studies evaluated the impact of oral vitamin K antagonist prophylaxis versus mechanical prophylaxis in patients who had major orthopedic surgery on this outcome.

##### Proximal Deep Vein Thrombosis

###### Oral Antiplatelet Agents Versus Oral Vitamin K Antagonists

One randomized controlled trial evaluated the impact of oral antiplatelet agents versus oral vitamin K antagonists on proximal deep vein thrombosis in patients who had major orthopedic surgery.88 In this trial by Lotke and colleagues in 1996, patients who had either total hip replacement or total knee replacement surgery were randomized to receive either aspirin or warfarin prophylaxis. In patients who received oral antiplatelet prophylaxis versus oral vitamin K antagonist prophylaxis, the risk of proximal deep vein thrombosis was not significantly different [RR 0.78 (0.42 to 1.46)]. Subgroup analyses were not possible as this was the only trial available.

###### Oral Antiplatelet Agents Versus Mechanical Prophylaxis

One randomized controlled trial by Haas and colleagues in 1990 evaluated the impact of oral antiplatelet agents versus oral vitamin K antagonists on proximal deep vein thrombosis in patients who had major orthopedic surgery.79 In this trial, patients who had either unilateral or bilateral total knee replacement surgery were randomized to receive either aspirin or intermittent pneumatic compression prophylaxis. Results were reported separately for unilateral and bilateral surgery, however no events occurred in the unilateral surgery group therefore only the bilateral surgery group remained. In these patients who received oral antiplatelet prophylaxis versus mechanical prophylaxis, the odds of proximal deep vein thrombosis were not significantly different [OR 0.57 (0.06 to 5.77)]. Subgroup analyses were not possible as this was the only trial available.

###### Injectable Low Molecular Weight Heparin Agents Versus Injectable Unfractionated Heparin

Nine randomized controlled trials evaluated the impact of injectable low molecular weight heparin agents versus injectable unfractionated heparin on proximal deep vein thrombosis in patients who had major orthopedic surgery with two trials including two separate comparisons.55,61-63,74,86,93,96,105 In patients who received injectable low molecular weight heparin agents versus injectable unfractionated heparin the risk of proximal deep vein thrombosis was significantly decreased [RR 0.60 (0.38 to 0.93), NNT 14 to 50] (Appendix G Figure 137). A lower level of statistical heterogeneity was detected but the presence of publication bias was not detected (I^2^=37 percent, Egger's p-value=0.450).

Subgroup analysis based on trials published from 2001-present was not possible as all trials were published prior to 2001. When limiting the original analysis to total hip replacement surgery, six trials remained, with two trials including two separate comparisons.55,61,63,86,93,96 In patients who received injectable low molecular weight heparin versus injectable unfractionated heparin the risk of proximal deep vein thrombosis was significantly decreased [RR 0.58 (0.39 to 0.86), NNT 13 to 48] (Appendix G Figure 138). Statistical heterogeneity was not detected (I^2^=0 percent). When limiting the original analysis to total knee replacement surgery, two trials remained.62,74 In patients who received injectable low molecular weight heparin versus injectable unfractionated heparin the risk of proximal deep vein thrombosis was significantly decreased [RR 0.32 (0.13 to 0.82), NNT 15 to 30] (Appendix G Figure 139). Statistical heterogeneity could not be evaluated because of too few studies. When limiting the original analysis to hip fracture surgery, one trial remained.105 In this trial, in patients who received injectable low molecular weight heparin agents versus injectable unfractionated heparin the risk of proximal deep vein thrombosis was not significantly different [RR 2.25 (0.95 to 5.61)].

Subgroup analyses based on age, gender and ethnicity were not possible because no randomized controlled trials reported data based on these subgroups.

###### Injectable Low Molecular Weight Heparin Agents Versus Injectable or Oral Factor Xa Inhibitors

Five randomized controlled trials evaluated the impact of injectable low molecular weight heparin agents versus injectable or oral factor Xa inhibitors on proximal deep vein thrombosis in patients who had major orthopedic surgery.64,83,99,106,135 In patients who received injectable low molecular weight heparin agents versus injectable or oral factor Xa inhibitors the odds of proximal deep vein thrombosis were significantly increased [OR 2.19 (1.52 to 3.16), NNH 44 to 122] (Appendix G Figure 140). A higher level of statistical heterogeneity was detected but publication bias was not detected (I^2^=69.9 percent, Egger's p-value=0.388). The direction of effect was opposing in the trials overall, with three favoring oral factor Xa inhibitors and two favoring low molecular weight heparin. Additionally, two favoring factor Xa inhibitors showed statistically significant benefit. Heterogeneity, then, is likely due to differences in the effect and magnitude of benefit. This is the same result obtained when limiting the analysis to trials published from 2001-present.

When limiting the original analysis to total hip replacement surgery, three trials remained.83,99,135 In patients who received injectable low molecular weight heparin agents versus injectable or oral factor Xa inhibitors the odds of proximal deep vein thrombosis were not significantly different [OR 1.55 (0.91 to 2.66)] (Appendix G Figure 141). A high level of statistical heterogeneity was detected (I^2^=78.2). When limiting the original analysis to total knee replacement surgery, one trial remained.106 In this trial, in patients who received injectable low molecular weight heparin agents versus injectable or oral factor Xa inhibitors the odds of proximal deep vein thrombosis were significantly increased [OR 2.18 (1.04 to 4.57), NNH 45]. When limiting the original analysis to hip fracture surgery, one trial remained.64 In this trial, in patients who received injectable low molecular weight heparin agents versus injectable or oral factor Xa inhibitors the odds of proximal deep vein thrombosis were significantly increased [OR 3.80 (1.92 to 7.50), NNH 38].

Subgroup analyses based on age, gender and ethnicity were not possible because no randomized controlled trials reported data based on these subgroups.

###### Injectable Low Molecular Weight Heparin Agents Versus Injectable or Oral Direct Thrombin Inhibitors

Two randomized controlled trials evaluated the impact of injectable low molecular weight heparin agents versus injectable or oral direct thrombin inhibitors on proximal deep vein thrombosis in patients who had major orthopedic surgery with one trial including two separate comparisons.73,94 In patients who received injectable low molecular weight heparin agents versus injectable or oral direct thrombin inhibitors the risk of proximal deep vein thrombosis was not significantly different [RR 0.91 (0.40 to 2.11)] (Appendix G Figure 142). A higher statistical heterogeneity was detected (I^2^=70.8 percent) and publication bias was not evaluated because of too few studies.

When limiting the original analysis to trials published from 2001-present, one trial remained including two separate comparisons.94 In patients who received injectable low molecular weight heparin agents versus injectable or oral direct thrombin inhibitors the risk of proximal deep vein thrombosis was not significantly different [RR 0.58 (0.29 to 1.17)] (Appendix G Figure 143). Statistical heterogeneity could not be evaluated because of too few studies. This is the same result obtained when limiting the analysis to total knee replacement surgery. When limiting the original analysis to total hip replacement surgery, one trial remained.73 In this trial, in patients who received injectable low molecular weight heparin agents versus injectable or oral direct thrombin inhibitors the odds of proximal deep vein thrombosis were significantly increased [OR 1.71 (1.13 to 2.59), NNH 151]. Subgroup analysis based on hip fracture surgery was not possible as no trials evaluated this surgical population.

Subgroup analyses based on age, gender and ethnicity were not possible because no randomized controlled trials reported data based on these subgroups.

In the dose finding trial by Eriksson and colleagues in 2005 four doses of dabigatran were compared with enoxaparin in patients who had total hip or total knee replacement surgery.65 Investigators reported a significant dose dependent decrease in the frequency of proximal deep vein thrombosis with increasing doses of dabigatran in both surgical groups (p <0.0001) although direct comparison to enoxaparin was not made within this trial for this outcome.

###### Injectable Low Molecular Weight Heparin Agents Versus Oral Vitamin K Antagonists

Six randomized controlled trials evaluated the impact of injectable low molecular weight heparin agents versus injectable or oral vitamin K antagonists on proximal deep vein thrombosis in patients who had major orthopedic surgery with two trials including two separate comparisons.75,77,80,81,84,85 In patients who received injectable low molecular weight heparin agents versus oral vitamin K antagonists the risk of proximal deep vein thrombosis was not significantly different [RR 0.63 (0.39 to 1.00)] (Appendix G Figure 144). A higher level of statistical heterogeneity was detected but publication bias was not detected. (I^2^=55.3 percent, Egger's p-value=0.224).

When limiting the original analysis to trials published from 2001-present, two trials remained.75,84 In patients who received injectable low molecular weight heparin agents versus oral vitamin K antagonists the risk of proximal deep vein thrombosis was not significantly different [RR 0.43 (0.05 to 4.11)] (Appendix G Figure 145). Statistical heterogeneity could not be evaluated because of too few studies. When limiting the original analysis to total hip replacement surgery, three trials remained with one trial including two separate comparisons.77,80,81 In patients who received injectable low molecular weight heparin agents versus oral vitamin K antagonists the odds of proximal deep vein thrombosis were not significantly different [OR 0.67 (0.42 to 1.08)] (Appendix G Figure 146). A higher level of statistical heterogeneity was detected (I^2^=55.3 percent). When limiting the original analysis to total knee replacement surgery, four trials remained.75,80,84,85 In patients who received injectable low molecular weight heparin agents versus oral vitamin K antagonists the risk of proximal deep vein thrombosis was not significantly different [RR 0.63 (0.30 to 1.34)] (Appendix G Figure 147). A higher level of statistical heterogeneity was detected (I^2^=68.9 percent). Subgroup analysis based on hip fracture surgery was not possible as no trials evaluated this surgical population.

Subgroup analyses based on age, gender and ethnicity were not possible because no randomized controlled trials reported data based on these subgroups.

###### Injectable Low Molecular Weight Heparin Agents Versus Mechanical Prophylaxis

Three randomized controlled trials evaluated the impact of injectable low molecular weight heparin agents versus mechanical prophylaxis on proximal deep vein thrombosis in patients who had major orthopedic surgery.98,101,102 In patients who received injectable low molecular weight heparin agents versus mechanical prophylaxis, the risk of proximal deep vein thrombosis was not significantly different [RR 0.65 (0.34 to 1.26)] (Appendix G Figure 148). Statistical heterogeneity was not detected (I^2^=0 percent) and publication bias was not evaluated because of too few studies.

When limiting the original analysis to trials published from 2001-present, one trial remained.102 In this trial, in patients who received injectable low molecular weight heparin agents versus mechanical prophylaxis, the odds of proximal deep vein thrombosis were not significantly different [OR 0.15 (0.02 to 1.05)]. This is the same result obtained when limiting the analysis to total knee replacement surgery. When limiting the original analysis to total hip replacement surgery, two trials remained.98,101 In patients who received injectable low molecular weight heparin agents versus mechanical prophylaxis the risk of proximal deep vein thrombosis was not significantly different [RR 0.71 (0.36 to 1.40)] (Appendix G Figure 149). Statistical heterogeneity could not be evaluated because of too few studies. Subgroup analysis based on hip fracture surgery was not possible as no trials evaluated this surgical population.

Subgroup analyses based on age, gender and ethnicity were not possible because no randomized controlled trials reported data based on these subgroups.

###### Injectable Unfractionated Heparin Versus Injectable or Oral Direct Thrombin Inhibitors

Two randomized controlled trials evaluated the impact of injectable unfractionated heparin versus injectable or oral direct thrombin inhibitors on proximal deep vein thrombosis in patients who had major orthopedic surgery.68,69 In patients who received injectable unfractionated heparin versus injectable or oral direct thrombin inhibitors the odds of proximal deep vein thrombosis were significantly increased [OR 4.74 (2.99 to 7.49), NNH 11] (Appendix G Figure 150). A range for the NNH could not be calculated because the control event rate was the same in both groups. Statistical heterogeneity and publication bias were not evaluated because of too few studies. This is the same result obtained when limiting the analysis to total hip replacement surgery. Subgroup analyses based on trials published from 2001-present, total knee replacement surgery or hip fracture surgery could not be evaluated as no trials fit these criteria.

Subgroup analyses based on age, gender and ethnicity were not possible because no randomized controlled trials reported data based on these subgroups.

###### Injectable Unfractionated Heparin Versus Injectable or Oral Factor Xa Inhibitors

No randomized controlled trials or controlled observational studies evaluated the impact of injectable unfractionated heparin prophylaxis versus injectable or oral factor Xa inhibitor prophylaxis in patients who had major orthopedic surgery on this outcome.

###### Injectable Unfractionated Heparin Versus Mechanical Prophylaxis

No randomized controlled trials or controlled observational studies evaluated the impact of injectable unfractionated heparin versus mechanical prophylaxis in patients who had major orthopedic surgery on this outcome.

###### Oral Vitamin K Antagonists Versus Mechanical Prophylaxis

Three randomized controlled trials evaluated the impact of oral vitamin K antagonists versus mechanical prophylaxis on proximal deep vein thrombosis in patients who had major orthopedic surgery.56,76,90 In patients who received oral vitamin K antagonists versus mechanical prophylaxis the risk of proximal deep vein thrombosis was significantly decreased [RR 0.34 (0.16 to 0.73), NNT 11 to 31] (Appendix G Figure 151). Statistical heterogeneity was not detected (I^2^=0 percent) and publication bias was not evaluated because of too few studies. This is the same result obtained when limiting the analysis to total hip replacement surgery. Subgroup analyses based on trials published from 2001-present, total knee replacement surgery or hip fracture surgery could not be evaluated as no trials fit these criteria.

Subgroup analyses based on age, gender and ethnicity were not possible because no randomized controlled trials reported data based on these subgroups.

##### Distal Deep Vein Thrombosis

###### Oral Antiplatelet Agents Versus Oral Vitamin K Antagonists

No randomized controlled trials or controlled observational studies evaluated the impact of oral antiplatelet agents versus oral vitamin K antagonists on distal deep vein thrombosis in patients who had major orthopedic surgery.

###### Oral Antiplatelet Agents Versus Mechanical Prophylaxis

One randomized controlled trial by Haas and colleagues in 1990 evaluated the impact of oral antiplatelet agents versus mechanical prophylaxis on distal deep vein thrombosis in patients who had major orthopedic surgery.79 In this trial, patients who had total knee replacement surgery were randomized to receive either aspirin or intermittent pneumatic compression prophylaxis and results were reported separately for unilateral and bilateral surgery. In patients who received oral antiplatelet agents versus mechanical prophylaxis, the risk of distal deep vein thrombosis was significantly increased [RR 1.79 (1.15 to 2.79), NNH 4 to 6] (Appendix G Figure 152). Statistical heterogeneity and publication bias could not be evaluated because there were too few studies. Subgroup analyses were not possible as this was the only trial available.

###### Injectable Low Molecular Weight Heparin Agents Versus Injectable Unfractionated Heparin

Eight randomized controlled trials evaluated the impact of injectable low molecular weight heparin agents versus injectable unfractionated heparin on distal deep vein thrombosis in patients who had major orthopedic surgery with two trials including two separate comparisons.55,61-63,74,93,96,105 One trial was excluded from the analysis because no events occurred in the groups compared.55 In patients who received injectable low molecular weight heparins versus injectable unfractionated heparin the risk of distal deep vein thrombosis was not significantly different [RR 0.95 (0.74 to 1.23)] (Figure 7). Statistical heterogeneity and publication bias were not detected (I^2^=0 percent, Egger's p-value=0.544).

Figure 7 Impact of injectable low molecular weight heparin prophylaxis versus injectable unfractionated heparin prophylaxis on distal deep vein thrombosis in patients undergoing major orthopedic surgery

I^2^: 0 percent.

Egger's p-value: 0.544.

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of impact of injectable low molecular weight heparin prophylaxis versus injectable unfractionated heparin prophylaxis on distal deep vein thrombosis in patients undergoing major orthopedic surgery. Eight trials were included in the analysis with two trials contributing to two separate comparisons presented individually here. The first trial by Schwartsmann and colleagues in 1996 provided a relative risk of 2.71 with a 95 percent confidence interval of 0.23 to 32.73. The second trial by Avikainen and colleagues in 1995 was excluded because no events occurred in either of the groups compared. The third trial by Colwell and colleagues in 1995 provided a relative risk of 0.93 with a 95 percent confidence interval of 0.67 to 1.30. The fourth trial by Colwell and colleagues in 1994 included two separate comparisons. The first comparison provided a relative risk of 0.39 with a 95 percent confidence interval of 0.12 to 1.28. The second comparison provided a relative risk of 1.85 with a 95 percent confidence interval of 0.78 to 4.53. The fifth trial by Fauno and colleagues in 1994 provided a relative risk of 0.91 with a 95 percent confidence interval of 0.52 to 1.59. The sixth trial by Dechavanne and colleagues in 1989 included two separate comparisons. The first comparison provided a relative risk of 0.98 with a 95 percent confidence interval of 0.08 to 12.97. The second comparison provided a relative risk of 1.95 with a 95 percent confidence interval of 0.18 to 22.21. The seventh trial by Monreal and colleagues in 1989 provided a relative risk of 1.88 with a 95 percent confidence interval of 0.26 to 13.95. The eighth trial by Planes and colleagues in 1988 provided a relative risk of 0.77 with a 95 percent confidence interval of 0.28 to 2.13.The combined effect of the seven trials showed a relative risk of 0.95 with a 95 percent confidence interval of 0.74 to 1.23. The I-squared value was 0 percent and the Egger's p-value was 0.544.

Subgroup analysis based on trials published from 2001-present was not possible because no trials fit this criterion. When limiting the original analysis to total hip replacement surgery, five trials remained, with two trials including two separate comparisons.55,61,63,93,96 One trial was excluded from the analysis because no events occurred in the groups compared.55 In patients who received injectable low molecular weight heparin versus injectable unfractionated heparin, the risk of distal deep vein thrombosis was not significantly different [RR 1.03 (0.58 to 1.83)] (Appendix G Figure 153). Statistical heterogeneity was not detected (I^2^=0 percent).When limiting the original analysis to total knee replacement surgery, two trials remained.62,74 In patients who received injectable low molecular weight heparin versus injectable unfractionated heparin, the risk of distal deep vein thrombosis was not significantly different [RR 0.93 (0.69 to 1.24)] (Appendix G Figure 154). Statistical heterogeneity could not be evaluated because of too few studies. When limiting the original analysis to hip fracture surgery, one trial remained.105 In this trial, in patients who received injectable low molecular weight heparin versus injectable unfractionated heparin, the odds of distal deep vein thrombosis were not significantly different [OR 1.86 (0.19 to 18.65)].

Subgroup analyses based on age, gender and ethnicity were not possible because no randomized controlled trials reported data based on these subgroups.

###### Injectable Low Molecular Weight Heparin Agents Versus Injectable or Oral Factor Xa Inhibitors

Five randomized controlled trials evaluated the impact of injectable low molecular weight heparin agents versus injectable or oral factor Xa inhibitors on distal deep vein thrombosis in patients who had major orthopedic surgery.64,83,99,106,135 In patients who received injectable low molecular weight heparins versus injectable or oral factor Xa inhibitors, the risk of distal deep vein thrombosis was significantly increased [RR 2.02 (1.65 to 2.48), NNH 11 to 33] (Appendix G Figure 155). A lower level of statistical heterogeneity was detected (I^2^=10 percent) and publication bias was not detected (Egger's p-value=0.106). This is the same result obtained when limiting the analysis to trials published from 2001-present since all five trials fit this criterion.

When limiting the original analysis to total hip replacement surgery, three trials remained.83,99,135 In patients who received injectable low molecular weight heparin versus injectable or oral factor Xa inhibitors, the odds of distal deep vein thrombosis were significantly increased [OR 1.82 (1.36 to 2.42), NNH 20 to 44 ] (Appendix G Figure 156). A lower level of statistical heterogeneity was found (I^2^=28.1 percent). When limiting the original analysis to total knee replacement surgery, one trial remained.106 In this trial, in patients who received injectable low molecular weight heparin versus injectable or oral factor Xa inhibitors, the risk of distal deep vein thrombosis was significantly increased [RR 2.27 (1.57 to 3.28), NNH 8]. When limiting the original analysis to hip fracture surgery, one trial remained.64 In this trial in patients who received injectable low molecular weight heparin versus injectable or oral factor Xa inhibitors, the risk of distal deep vein thrombosis was significantly increased [RR 2.24 (1.59 to 3.17), NNH 12].

Subgroup analyses based on age, gender and ethnicity were not possible because no randomized controlled trials reported data based on these subgroups.

###### Injectable Low Molecular Weight Heparin Agents Versus Injectable or Oral Direct Thrombin Inhibitors

One randomized controlled trial by Ginsberg and colleagues in 1990, including two separate comparisons, evaluated the impact of injectable low molecular weight heparin agents versus injectable or oral direct thrombin inhibitors on distal deep vein thrombosis in patients who had major orthopedic surgery and included two separate comparisons.94 In this trial, patients who had total knee replacement surgery were randomized to receive either enoxaparin, dabigatran 150mg or dabigatran 220mg. In patients who received injectable low molecular weight heparin agents versus injectable or oral direct thrombin inhibitors, the risk of distal deep vein thrombosis was significantly decreased [RR 0.79 (0.67 to 0.93), NNT 16 to 18] (Appendix G Figure 157). Statistical heterogeneity and publication bias could not be evaluated because of too few studies. Subgroup analyses were not possible as this was the only trial available.

In the dose finding trial by Eriksson and colleagues in 2005 four doses of dabigatran were compared with enoxaparin in patients who had total hip or total knee replacement surgery.65 Investigators reported a significant dose dependent decrease in the frequency of distal deep vein thrombosis with increasing doses of dabigatran in both surgical groups (p <0.0001) although direct comparison to enoxaparin was not made within this trial for this outcome.

###### Injectable Low Molecular Weight Heparin Agents Versus Oral Vitamin K Antagonists

Two randomized controlled trials evaluated the impact of injectable low molecular weight heparin agents versus oral vitamin K antagonists on distal deep vein thrombosis in patients who had major orthopedic surgery.75,77 In patients who received injectable low molecular weight heparins versus oral vitamin K antagonists, the risk of distal deep vein thrombosis was significantly decreased [RR 0.56 (0.43 to 0.73), NNT 6 to 10] (Appendix G Figure 158). Statistical heterogeneity and publication bias could not be evaluated because of too few studies.

When limiting the original analysis to trials published from 2001-present, one trial remained.75 In this trial, in patients who received injectable low molecular weight heparin versus oral vitamin K antagonists, the risk of distal deep vein thrombosis was significantly decreased [RR 0.60 (0.44 to 0.81), NNT 6]. This is the same result obtained when limiting the analysis to total knee replacement surgery. When limiting the original analysis to total hip replacement surgery, one trial remained.77 In this trial, in patients who received injectable low molecular weight heparin versus oral vitamin K antagonists, the risk of distal deep vein thrombosis was significantly decreased [RR 0.48 (0.30 to 0.78), NNT 9]. Subgroup analysis based on hip fracture surgery was not possible because no trials evaluated this surgical population.

Subgroup analyses based on age, gender and ethnicity were not possible because no randomized controlled trials reported data based on these subgroups.

###### Injectable Low Molecular Weight Heparin Agents Versus Mechanical Prophylaxis

Three randomized controlled trials evaluated the impact of injectable low molecular weight heparin agents versus mechanical prophylaxis on distal deep vein thrombosis in patients who had major orthopedic surgery.98,101,102 One trial was excluded from the analysis because no events occurred in the groups compared.98 In patients who received injectable low molecular weight heparins versus mechanical prophylaxis, the risk of distal deep vein thrombosis was not significantly different [RR 1.00 (0.77 to 1.29)] (Appendix G Figure 159). Statistical heterogeneity and publication bias could not be evaluated because of too few studies.

When limiting the original analysis to trials published from 2001-present, one trial remained.102 In this trial, in patients who received injectable low molecular weight heparin versus mechanical prophylaxis, the risk of distal deep vein thrombosis was not significantly different [RR 1.01 (0.77 to 1.31)]. This is the same result obtained when limiting the original analysis to total knee replacement surgery. When limiting the original analysis to total hip replacement surgery, two trials remained.98,101 One trial was excluded from the analysis because no events occurred in the groups compared leaving one trial for the analysis.98 In the remaining trial, in patients who received injectable low molecular weight heparin versus mechanical prophylaxis, the odds of distal deep vein thrombosis were not significantly different [OR 0.84 (0.28 to 2.55)]. Subgroup analysis based on hip fracture surgery was not possible because no trials evaluated this surgical population.

Subgroup analyses based on age, gender and ethnicity were not possible because no randomized controlled trials reported data based on these subgroups.

###### Injectable Unfractionated Heparin Versus Injectable or Oral Direct Thrombin Inhibitors

No randomized controlled trials or controlled observational studies evaluated the impact of injectable unfractionated heparin versus injectable or oral direct thrombin inhibitors in patients who had major orthopedic surgery on this outcome.

###### Injectable Unfractionated Heparin Versus Injectable or Oral Factor Xa Inhibitors

No randomized controlled trials or controlled observational studies evaluated the impact of injectable unfractionated heparin prophylaxis versus injectable or oral factor Xa inhibitor prophylaxis in patients who had major orthopedic surgery on this outcome.

###### Injectable Unfractionated Heparin Versus Mechanical Prophylaxis

No randomized controlled trials or controlled observational studies evaluated the impact of injectable unfractionated heparin versus mechanical prophylaxis in patients who had major orthopedic surgery on this outcome.

###### Oral Vitamin K Antagonists Versus Mechanical Prophylaxis

One randomized controlled trial by Paiement and colleagues in 1987 evaluated the impact of oral vitamin K antagonists versus mechanical prophylaxis on distal deep vein thrombosis in patients who had major orthopedic surgery.90 In this trial, patients who had total hip replacement surgery were randomized to receive either warfarin or intermittent pneumatic compression prophylaxis. In patients who received oral vitamin K antagonists versus mechanical prophylaxis, the odds of distal deep vein thrombosis were not significantly different [OR 3.30 (0.91 to 11.91)]. Subgroup analyses were not possible as this was the only trial available.

##### Major Bleeding

###### Oral Antiplatelet Agents Versus Oral Vitamin K Antagonists

One randomized controlled trial evaluated the impact of oral antiplatelet agent prophylaxis versus oral vitamin K antagonist prophylaxis on major bleeding in patients who had major orthopedic surgery.132 This trial by Powers and colleagues in 1989 evaluated patients who had hip fracture surgery. In patients who received oral antiplatelet agent prophylaxis versus oral vitamin K antagonist prophylaxis the risk of major bleeding was not significantly different [RR 0.20 (0.03 to 1.23)]. Subgroup analyses were not possible as only one trial was available.

###### Oral Antiplatelet Agents Versus Mechanical Prophylaxis

No randomized controlled trials or controlled observational studies evaluated the impact of oral antiplatelet prophylaxis versus mechanical prophylaxis in patients who had major orthopedic surgery on this outcome.

###### Injectable Low Molecular Weight Heparin Agents Versus Injectable Unfractionated Heparin

Seven randomized controlled trials evaluated the impact of injectable low molecular weight heparin prophylaxis versus injectable unfractionated heparin prophylaxis on major bleeding in patients who had major orthopedic surgery.61,62,71,86,89,93,97 Two trials provided two separate comparisons.61,89 The trial by Eriksson in 1991 could not be pooled as no events occurred in either group.71 In patients who received injectable low molecular weight heparin prophylaxis versus injectable unfractionated heparin prophylaxis the odds of major bleeding were significantly decreased [OR 0.57 (0.37 to 0.88), NNT 41] (Figure 8). A range for the number needed to treat could not be calculated since the lowest control events rate was zero. A lower level of statistical heterogeneity was detected but the presence of publication bias was not detected (I^2^=37.1 percent, Egger's p-value=0.608).

Figure 8 Impact of injectable low molecular weight heparin versus injectableunfractionated heparin on major bleeding in patients undergoing major orthopedic surgery

I^2^: 37.1 percent.

Egger's p-value: 0.201.

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of injectable low molecular weight heparin prophylaxis versus injectable unfractionated heparin prophylaxis on major bleeding in patients undergoing major orthopedic surgery. Seven trials were included in the analysis with two trials contributing two separate comparisons presented individually here. The first trial by Seneran and colleagues in 2006 provided an odds ratio of 7.54 with a 95 percent confidence interval of 0.47 to 122.28. The second trial by Colwell and colleagues in 1995 provided an odds ratio of 0.99 with 95 confidence interval of 0.20 to 4.93. The third trial by Colwell and colleagues in 1994 provided two comparisons. The first comparison provided an odds ratio of 0.63 with a 95 percent confidence interval of 0.21 to 1.91. The second comparison provided an odds ratio of 0.21 with 95 percent confidence interval of 0.05 to 0.80. The fourth trial by Menzin and colleagues in 1994 provided two comparisons. The first comparison provided an odds ratio of 0.64 with a 95 percent confidence interval of 0.21 to 1.94. The second comparison provided an odds ratio of 0.21 with 95 percent confidence interval of 0.05 to 0.81. The fifth trial by Eriksson and colleagues in 1991 was excluded because no events occurred in the groups compared. The sixth trial by Levine and colleagues in 1991 provided an odds ratio of 0.57 with 95 percent confidence interval of 0.27 to 1.19. The seventh trial by Planes and colleagues in 1988 provided an odds ratio of 6.76 with a 95 confidence interval of 0.42 to 109.15. The combined effect of the six trials showed an odds ratio of 0.57 with a 95 percent confidence interval of 0.37 to 0.88. The I-squared value was 37.1 percent and the Egger's p-value was 0.201

When limiting the original analysis to trials published from 2001-present, one trial remained.97 In this trial, in patients who received injectable low molecular weight heparin prophylaxis versus injectable unfractionated heparin prophylaxis the odds of major bleeding were not significantly different [OR 7.54 (0.47 to 122.28)]. When limiting the original analysis to total hip replacement surgery six trials remained.61,71,86,89,93,97 In patients who received injectable low molecular weight heparin prophylaxis versus injectable unfractionated heparin prophylaxis the odds of major bleeding were significantly decreased [OR 0.54 (0.34 to 0.85), NNT 38] (Appendix G Figure 160). A range for the number needed to treat could not be calculated since the lowest control events rate was zero. A lower level of statistical heterogeneity was detected (I^2^=43.5 percent). When limiting the original analysis to total knee replacement surgery one trial remained.62 In this trial, in patients who received injectable low molecular weight heparin prophylaxis versus injectable unfractionated heparin prophylaxis the odds of major bleeding were not significantly different [OR 0.99 (0.20 to 4.93)]. Subgroup analysis based on hip fracture surgery was not possible as no trials evaluated this population.

Subgroup analyses based on age, gender and ethnicity were not possible because no randomized controlled trials reported data based on these subgroups.

###### Injectable Low Molecular Weight Heparin Agents Versus Injectable or Oral Factor Xa Inhibitors

Five randomized controlled trials evaluated the impact of injectable low molecular weight heparin prophylaxis versus injectable or oral factor Xa inhibitor prophylaxis on major bleeding in patients who had major orthopedic surgery.64,83,99,106,135 One trial by Yokote and colleagues was excluded from the analysis because no events occurred in either of the treatment groups. In patients who received injectable low molecular weight heparin prophylaxis versus injectable or oral factor Xa inhibitor prophylaxis the odds of major bleeding were significantly decreased [OR 0.65 (0.48 to 0.89), NNT 74 to 145] (Appendix G Figure 161). A higher level of statistical heterogeneity was detected but the presence of publication bias was not detected (I^2^=56.6 percent, Egger's p-value=0.347). The direction of effect was similar in three of the four trials, with one of the trials showing statistically significant benefit of low molecular weight heparin. Heterogeneity, then, is likely due to differences in direction and the magnitude of benefit. This is the same result obtained when limiting the analysis to trials published from 2001-present.

When limiting the original analysis to total hip replacement surgery three trials remained of which one trial by Yokote and colleagues was excluded from the analysis because no events occurred in either of the treatment groups.83,99,135 In patients who received injectable low molecular weight heparin prophylaxis versus injectable or oral factor Xa inhibitor prophylaxis the odds of major bleeding were significantly decreased [OR 0.64 (0.44 to 0.94), NNT 72] (Appendix G Figure 162). A range for the NNT could not be calculated since the lower bound of the control event rate was zero. Statistical heterogeneity could not be evaluated because of too few studies. When limiting the original analysis to total knee replacement surgery one trial remained.106 In this trial, in patients who received injectable low molecular weight heparin prophylaxis versus injectable or oral factor Xa inhibitor prophylaxis the odds of major bleeding were significantly decreased [OR 0.19 (0.06 to 0.58), NNT 62]. When limiting the original analysis to hip fracture surgery one trial remained.64 In this trial, in patients who received injectable low molecular weight heparin prophylaxis versus injectable or oral factor Xa inhibitor prophylaxis the odds of major bleeding were not significantly different [OR 1.04 (0.54 to 2.00)].

Subgroup analyses based on age, gender and ethnicity were not possible because no randomized controlled trials reported data based on these subgroups.

Two controlled observational studies evaluated the impact of injectable low molecular weight heparin prophylaxis versus injectable or oral factor Xa inhibitor prophylaxis on bleeding in patients who had major orthopedic surgery.147,150Although the first study by Shorr and colleagues in 2007 did not specifically report major bleeding, the definition used in this study is similar to those used in the trials evaluated above. This study evaluated patients who had total hip replacement, total knee replacement, or hip fracture surgery and received either an injectable low molecular weight heparin (enoxaparin or dalteparin) or fondaparinux prophylaxis. Bleeding was not significantly different in patients who received injectable low molecular weight heparin versus fondaparinux prophylaxis (1.5 percent versus 1.5 percent, p=0.970). In the second study by Gerkens and colleagues in 2010, patients who had total hip replacement, total knee replacement, or hip fracture surgery received either enoxaparin or fondaparinux. Major bleeding did not significantly differ between the two groups (1.1 percent versus 0.0 percent, respectively, p=0.488).

###### Injectable Low Molecular Weight Heparin Agents Versus Injectable or Oral Direct Thrombin Inhibitors

Four randomized controlled trials evaluated the impact of injectable low molecular weight heparin prophylaxis versus injectable or oral direct thrombin inhibitor prophylaxis on major bleeding in patients who had major orthopedic surgery.66,67,73,94 The trials by Erikson and colleagues in 2007 and the trial by Ginsberg and colleagues in 2009 provided two separate comparisons. In patients who received injectable low molecular weight heparin prophylaxis versus injectable or oral direct thrombin inhibitor prophylaxis the risk of major bleeding was not significantly different [RR 1.12 (0.80 to 1.57)] (Appendix G Figure 163). Statistical heterogeneity and publication bias were not detected (I^2^=0 percent, Egger's p-value=0.175).

When limiting the original analysis to trials published from 2001-present, three trials remained each including two separate comparisons.66,67,94 In patients who received injectable low molecular weight heparin prophylaxis versus injectable or oral direct thrombin inhibitor prophylaxis the risk of major bleeding was not significantly different [RR 1.17 (0.79 to 1.75)] (Appendix G Figure 164). Statistical heterogeneity was not detected (I^2^=0 percent). When limiting the original analysis to total hip replacement surgery two trials remained with the trial by Eriksson and colleagues in 2007 including two separate comparisons.67,73 In patients who received injectable low molecular weight heparin prophylaxis versus injectable or oral direct thrombin inhibitor prophylaxis the risk of major bleeding was not significantly different [RR 0.97 (0.64 to 1.48)] (Appendix G Figure 165). Statistical heterogeneity was not detected (I^2^=0 percent). When limiting the original analysis to total knee replacement surgery two trials that included two separate comparisons remained.66,94 In patients who received injectable low molecular weight heparin prophylaxis versus injectable or oral direct thrombin inhibitor prophylaxis the risk of major bleeding was not significantly different [RR 1.46 (0.82 to 2.59)] (Appendix G Figure 166). Statistical heterogeneity was not detected (I^2^=0 percent). Subgroup analysis based on hip fracture surgery was not possible because no trials evaluated this surgical population.

Subgroup analyses based on age, gender and ethnicity were not possible because no randomized controlled trials reported data based on these subgroups.

In the dose finding trial by Eriksson and colleagues in 2005 four doses of dabigatran were compared with enoxaparin in patients who had total hip or total knee replacement surgery.65 Investigators reported that major bleeding episodes were significantly higher in the dabigatran 150mg twice daily, dabigatran 225mg twice daily, and the dabigatran 300mg daily groups compared with the dabigatran 50mg twice daily group although results were not reported. When compared with enoxaparin, the dabigatran 50mg twice daily group had significantly less major bleeding episodes (0.3 percent versus 2.0 percent, p=0.047). However, the occurrence of major bleeding was not significantly different when comparing the other dabigatran groups to enoxaparin. Authors suggested a nonsignificant trend towards increased major bleeding with dabigatran 150mg twice daily, 225mg twice daily, and 300mg daily compared with enoxaparin.

One randomized controlled trial including two separate comparisons evaluated the impact of injectable low molecular weight heparin versus injectable or oral direct thrombin inhibitor prophylaxis on major bleeding during the postdischarge time period in patients who had total knee replacement surgery.94 In this trial patients who had total knee replacement surgery were randomized to receive either enoxaparin, dabigatran 150mg or dabigatran 220mg daily. In patients who received injectable low molecular weight heparin versus injectable or oral direct thrombin inhibitor prophylaxis the risk of major bleeding during the postdischarge period was not significantly different [RR 0.51 (0.06 to 4.58)] (Appendix G Figure 167).

###### Injectable Low Molecular Weight Heparin Agents Versus Oral Vitamin K Antagonists

Seven randomized controlled trials evaluated the impact of injectable low molecular weight heparin prophylaxis versus oral vitamin K antagonist prophylaxis on major bleeding in patients who had major orthopedic surgery.60,75,77,80,81,84,85 The trial by Hull and colleagues in 1993 provided two separate comparisons and the trial by Lassen and colleagues in 2007 was excluded from the analysis because no events occurred in either group compared. Another trial by Hull and colleagues in 2000 included two separate comparisons but was not included in the pooled analysis because major bleeding was reported at two postoperative time periods; days 0-1 and days 2-8.^81^ The six remaining trials were pooled, and in patients who received injectable low molecular weight heparin prophylaxis versus oral vitamin K antagonist prophylaxis the risk of major bleeding was significantly increased [OR 1.92 (1.27 to 2.91), NNH 57 to 220] (Figure 9). Statistical heterogeneity and publication bias were not detected (I^2^=0 percent, Egger's p-value=0.661).

Figure 9 Impact of injectable low molecular weight heparin versus oral vitamin K antagonists on major bleeding in patients undergoing major orthopedic surgery

I^2^: 0 percent.

Egger's p-value: 0.661.

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the Impact of injectable low molecular weight heparin prophylaxis versus oral vitamin K antagonist prophylaxis on major bleeding in patients undergoing major orthopedic surgery. Six trials were included in the analysis, with one trial providing two separate comparisons presented individually here. The first trial by Lassen and colleagues in 2007 was excluded because there were no events in the groups compared. The second trial by Fitzgerald and colleagues in 2001 provided an odds ratio of 2.26 with a 95 percent confidence interval of 0.75 to 6.83. The third trial by Colwell and colleagues in 1999 provided an odds ratio of 2.14 with a 95 percent confidence interval of 0.99 to 4.64. The fourth trial by Francis and colleagues in 1997 provided an odds ratio of 1.55 with a 95 percent confidence interval of 0.44 to 5.40. The fifth trial by Leclerc and colleagues in 1996 provided an odds ratio of 1.16 with a 95 percent confidence interval of 0.39 to 3.48. The sixth trial by Hull and colleagues in 1993 provided two comparisons. The first comparison provided an odds ratio of 1.82 with a 95 percent confidence interval of 0.70 to 4.75. The second comparison provided an odds ratio of 2.83 with a 95 percent confidence interval of 0.90 to 8.86. The combined effect of the five trials showed an odds ratio of 1.92 with a 95 percent confidence interval of 1.27 to 2.91. The I-squared value was zero percent and the Egger's p-value was 0.661.

The trial by Hull and colleagues in 2000 that was excluded from the pooled analysis was evaluated separately. In this trial, patients who had total hip replacement surgery were randomized to receive dalteparin initiated preoperatively, dalteparin initiated postoperatively or warfarin prophylaxis. In patients who received injectable low molecular weight heparin versus oral vitamin K antagonist prophylaxis the risk of major bleeding was not significantly different on days 0-1 [RR 1.51 (0.92 to 2.48)] (Appendix G Figure 168) or on days 2-8 [RR 3.41 (0.77 to 15.18)] (Appendix G Figure 169).

When limiting the original pooled analysis of six trials to trials published from 2001-present two trials remained.75,84 The trial by Lassen and colleagues in 2007 was excluded from the analysis because no events occurred in either group.84 In the remaining trial, in patients who received injectable low molecular weight heparin prophylaxis versus oral vitamin K antagonist prophylaxis the odds of major bleeding were not significantly different [OR 2.26 (0.75 to 6.83)]. When limiting the original analysis to total hip replacement surgery three trials remained.60,77,80 In patients who received injectable low molecular weight heparin prophylaxis versus oral vitamin K antagonist prophylaxis the odds of major bleeding were significantly increased [OR 1.91 (1.11 to 3.29), NNH 58 to 220] (Appendix G Figure 170). Statistical heterogeneity was not detected (I^2^=0 percent). When limiting the original analysis to total knee replacement surgery four trials remained.75,80,84,85 In patients who received injectable low molecular weight heparin prophylaxis versus oral vitamin K antagonist prophylaxis the odds of major bleeding were significantly increased [OR 1.93 (1.01 to 3.67), NNH 56] (Appendix G Figure 171). A range for the number needed to harm could not be calculated because the lowest control event rate was zero. Statistical heterogeneity was not detected (I^2^=0 percent). No trials evaluated patients with hip fracture surgery.

Subgroup analyses based on age, gender and ethnicity were not possible because no randomized controlled trials reported data based on these subgroups.

###### Injectable Low Molecular Weight Heparin Agents Versus Mechanical Prophylaxis

No randomized controlled trials or controlled observational studies evaluated the impact of injectable low molecular weight heparin prophylaxis versus mechanical prophylaxis in patients who had major orthopedic surgery on this outcome.

###### Injectable Unfractionated Heparin Versus Injectable or Oral Direct Thrombin Inhibitors

No randomized controlled trials or controlled observational studies evaluated the impact of injectable unfractionated heparin prophylaxis versus injectable or oral direct thrombin inhibitor prophylaxis in patients who had major orthopedic surgery on this outcome.

###### Injectable Unfractionated Heparin Versus Injectable or Oral Factor Xa Inhibitors

One controlled observational study evaluated the impact of injectable unfractionated heparin prophylaxis versus injectable or oral factor Xa inhibitor prophylaxis on bleeding in patients who had major orthopedic surgery.147 Although not reported as major bleeding, the definition used in this study is similar to those used in the trials evaluated above. This study evaluated patients who had total hip replacement, total knee replacement, or hip fracture surgery and received injectable unfractionated heparin or fondaparinux prophylaxis. Bleeding was significantly increased in patients who received unfractionated heparin versus fondaparinux prophylaxis [OR 1.27 (1.06 to 1.52), NNH 253].

###### Injectable Unfractionated Heparin Versus Mechanical Prophylaxis

No randomized controlled trials or controlled observational studies evaluated the impact injectable unfractionated heparin prophylaxis versus mechanical prophylaxis in patients who had major orthopedic surgery on this outcome.

###### Oral Vitamin K Antagonists Versus Mechanical Prophylaxis

One randomized controlled trial evaluated the impact of oral vitamin K antagonist prophylaxis versus mechanical prophylaxis on major bleeding in patients undergoing major orthopedic surgery although no events occurred therefore the risk of major bleeding could not be evaluated.90

##### Major Bleeding Leading to Reoperation

###### Oral Antiplatelet Agents Versus Oral Vitamin K Antagonists

No randomized controlled trials or controlled observational studies evaluated the impact of oral antiplatelet prophylaxis versus oral vitamin K antagonist prophylaxis in patients who had major orthopedic surgery on this outcome.

###### Oral Antiplatelet Agents Versus Mechanical Prophylaxis

No randomized controlled trials or controlled observational studies evaluated the impact of oral antiplatelet prophylaxis versus mechanical prophylaxis in patients who had major orthopedic surgery on this outcome.

###### Injectable Low Molecular Weight Heparin Agents Versus Injectable Unfractionated Heparin

One randomized controlled trial evaluated the impact of injectable low molecular weight heparin prophylaxis versus injectable unfractionated heparin prophylaxis on major bleeding leading to reoperation in patients who had major orthopedic surgery although no events occurred therefore the risk of major bleeding leading to reoperation could not be evaluated.71

###### Injectable Low Molecular Weight Heparin Agents Versus Injectable or Oral Factor Xa Inhibitors

Four randomized controlled trials evaluated the impact of injectable low molecular weight heparin prophylaxis versus injectable or oral factor Xa inhibitor prophylaxis on major bleeding leading to reoperation in patients who had major orthopedic surgery.64,83,99,106 In patients who received injectable low molecular weight heparin prophylaxis versus injectable or oral factor Xa inhibitor prophylaxis the odds of major bleeding leading to reoperation were not significantly different [OR 0.67 (0.28 to 1.61)] (Appendix G Figure 172). Statistical heterogeneity and publication bias were not detected (I^2^=0 percent, Egger's p-value=0.855). This is the same result as limiting the original analysis to trials published from 2001-present.

When limiting the original analysis to total hip replacement surgery two trials remained.83,99 In patients who received injectable low molecular weight heparin prophylaxis versus injectable or oral factor Xa inhibitor prophylaxis the odds of major bleeding leading to reoperation was not significantly different [OR 0.72 (0.23 to 2.23)] (Appendix G Figure 173). Statistical heterogeneity could not be evaluated because of too few studies. When limiting the original analysis to total knee replacement surgery one trial remained.106 In this trial, in patients who received injectable low molecular weight heparin prophylaxis versus injectable or oral factor Xa inhibitor prophylaxis the odds of major bleeding leading to reoperation were not significantly different [OR 0.51 (0.05 to 4.94)].When limiting the original analysis to hip fracture surgery one trial remained.64 In this trial, in patients who received injectable low molecular weight heparin prophylaxis versus injectable or oral factor Xa inhibitor prophylaxis the odds of major bleeding leading to reoperation were not significantly different [OR 0.66 (0.11 to 3.82)].

Subgroup analyses based on age, gender and ethnicity were not possible because no randomized controlled trials reported data based on these subgroups.

###### Injectable Low Molecular Weight Heparin Agents Versus Injectable or Oral Direct Thrombin Inhibitors

Three randomized controlled trials evaluated the impact of injectable low molecular weight heparin prophylaxis versus injectable or oral direct thrombin inhibitor prophylaxis on major bleeding leading to reoperation in patients who had major orthopedic surgery.66,67,94 All three trials provided two separate comparisons. In patients who received injectable low molecular weight heparin prophylaxis versus injectable or oral direct thrombin inhibitor prophylaxis the risk of major bleeding leading to reoperation was not significantly different [RR 1.27 (0.43 to 3.75)] (Appendix G Figure 174). Statistical heterogeneity and publication bias were not detected (I^2^=0 percent, Egger's p-value=0.614). This is the same result obtained when limiting the original analysis to trials published from 2001-present.

When limiting the original analysis to total hip replacement surgery one trial remained including two separate comparisons.67 In patients who received injectable low molecular weight heparin prophylaxis versus injectable or oral direct thrombin inhibitor prophylaxis the risk of major bleeding leading to reoperation was not significantly different [RR 1.21 (0.29 to 5.08)] (Appendix G Figure 175). Statistical heterogeneity could not be evaluated because of too few studies. When limiting the original analysis to total knee replacement surgery two trials that included two separate comparisons remained.66,94 In patients who received injectable low molecular weight heparin prophylaxis versus injectable or oral direct thrombin inhibitor prophylaxis the risk of major bleeding leading to reoperation was not significantly different [RR 1.36 (0.27 to 7.03)] (Appendix G Figure 176). Statistical heterogeneity was not detected (I^2^=0 percent). Subgroup analysis based on hip fracture surgery was not possible because no trials evaluated this surgical population.

Subgroup analyses based on age, gender and ethnicity were not possible because no randomized controlled trials reported data based on these subgroups.

###### Injectable Low Molecular Weight Heparin Agents Versus Oral Vitamin K Antagonists

Two randomized controlled trials evaluated the impact of injectable low molecular weight prophylaxis versus oral vitamin K antagonist prophylaxis on major bleeding leading to reoperation in patients who had major orthopedic surgery.75,77 One trial was excluded from the analysis because no events occurred in the groups compared.75 The remaining trial by Francis and colleagues in 1997 evaluated patients who had total hip replacement surgery. In patients who received injectable low molecular weight heparin prophylaxis versus oral vitamin K antagonist prophylaxis the odds of major bleeding leading to reoperation were not significantly different [OR 7.61 (0.15 to 383.70)]. Subgroup analyses were not possible as only one trial had events in the groups compared.

###### Injectable Low Molecular Weight Heparin Agents Versus Mechanical Prophylaxis

No randomized controlled trials or controlled observational studies evaluated the impact of injectable low molecular weight heparin prophylaxis verses mechanical prophylaxis in patients who had major orthopedic surgery on this outcome.

###### Injectable Unfractionated Heparin Versus Injectable or Oral Direct Thrombin Inhibitors

Two randomized controlled trials evaluated the impact of injectable unfractionated heparin versus injectable or oral direct thrombin inhibitors on major bleeding leading to reoperation in patients who had major orthopedic surgery.68,69 One trial was excluded from the analysis because no events occurred in the groups compared.69 In the remaining trial by Eriksson and colleagues in 1996, patients who had total hip replacement surgery were evaluated. In patients who received injectable unfractionated heparin versus injectable or oral direct thrombin inhibitors the odds of major bleeding leading to reoperation were not significantly different [OR 0.51 (0.10 to 2.55)]. Subgroup analyses were not possible since only one trial had events in the groups compared.

###### Injectable Unfractionated Heparin Versus Injectable or Oral Factor Xa Inhibitors

No randomized controlled trials or controlled observational studies evaluated the impact of injectable unfractionated heparin prophylaxis versus injectable or oral factor Xa inhibitor prophylaxis in patients who had major orthopedic surgery on this outcome.

###### Injectable Unfractionated Heparin Versus Mechanical Prophylaxis

No randomized controlled trials or controlled observational studies evaluated the impact injectable unfractionated heparin prophylaxis versus mechanical prophylaxis in patients who had major orthopedic surgery on this outcome.

###### Oral Vitamin K Antagonists Versus Mechanical Prophylaxis

One randomized controlled trial evaluated the impact of oral vitamin K antagonist prophylaxis versus mechanical prophylaxis on major bleeding leading to reoperation in patients who had major orthopedic surgery although no events occurred therefore the risk of major bleeding leading to reoperation could not be calculated.76

##### Minor Bleeding

###### Oral Antiplatelet Agents Versus Oral Vitamin K Antagonists

No randomized controlled trials or controlled observational studies evaluated the impact of oral antiplatelet prophylaxis versus oral vitamin K antagonist prophylaxis in patients who had major orthopedic surgery on this outcome.

###### Oral Antiplatelet Agents Versus Mechanical Prophylaxis

No randomized controlled trials or controlled observational studies evaluated the impact of oral antiplatelet prophylaxis versus mechanical prophylaxis in patients who had major orthopedic surgery on this outcome.

###### Injectable Low Molecular Weight Heparin Agents Versus Injectable Unfractionated Heparin

Five randomized controlled trials evaluated the impact of injectable low molecular weight heparin prophylaxis versus injectable unfractionated heparin prophylaxis on minor bleeding in patients who had major orthopedic surgery.61,62,86,93,97 The trial by Colwell and colleagues in 1994 provided two separate comparisons. In patients who received injectable low molecular weight heparin prophylaxis versus injectable unfractionated heparin prophylaxis the risk of minor bleeding was not significantly different [RR 0.90 (0.63 to 1.28)] (Appendix G Figure 177). A lower level of statistical heterogeneity was detected but the presence of publication bias was not detected (I^2^=9.9 percent, Egger's p-value=0.608).

When limiting the original analysis to trials published from 2001-present, one trial remained.97 In this trial, in patients who received injectable low molecular weight heparin prophylaxis versus injectable unfractionated heparin prophylaxis the risk of minor bleeding was not significantly different [OR 0.25 (0.03 to 2.16)]. When limiting the original analysis to total hip replacement surgery, four trials remained.61,86,93,97 The trial by Colwell and colleagues in 1994 provided two separate comparisons. In patients who received injectable low molecular weight heparin prophylaxis versus injectable unfractionated heparin prophylaxis the odds of minor bleeding were not significantly different [OR 0.92 (0.57 to 1.51)] (Appendix G Figure 178). A lower level of statistical heterogeneity was detected (I^2^=31.4 percent). When limiting the original analysis to total knee replacement surgery one trial remained.62 In this trial, in patients who received injectable low molecular weight heparin prophylaxis versus injectable unfractionated heparin prophylaxis the risk of major bleeding leading to reoperation was not significantly different [RR 0.87 (0.60 to 1.25)]. Subgroup analyses based on hip fracture surgery were not possible as no trials evaluated these surgical populations.

Subgroup analyses based on age, gender and ethnicity were not possible because no randomized controlled trials reported data based on these subgroups.

###### Injectable Low Molecular Weight Heparin Agents Versus Injectable or Oral Factor Xa Inhibitors

Two randomized controlled trials evaluated the impact of injectable low molecular weight heparin prophylaxis versus injectable or oral factor Xa inhibitor prophylaxis on minor bleeding in patients who had major orthopedic surgery.64,135 In patients who received injectable low molecular weight heparin prophylaxis versus injectable or oral factor Xa inhibitor prophylaxis the odds of minor bleeding were significantly decreased [OR 0.57 (0.35 to 0.94), NNT 31 to 60] (Appendix G Figure 179). Statistical heterogeneity and publication bias could not be evaluated because of too few studies. The same results occurred when trials were limited to the years 2001-present. When limiting the original analysis to total hip replacement surgery one trial by Yokote and colleagues in 2011 remained. In this trial in patients who received injectable low molecular weight heparin prophylaxis versus injectable or oral factor Xa inhibitor prophylaxis the odds of minor bleeding were not significantly different [OR 0.85 (0.27 to 2.62). Subgroup analysis based on total knee replacement surgery was not possible because no trials evaluated this population. When limiting the original analysis to hip fracture surgery one trial by Eriksson and colleagues in 2001 remained. In this trial in patients who received injectable low molecular weight heparin prophylaxis versus injectable or oral factor Xa inhibitor prophylaxis the odds of minor bleeding were significantly decreased [OR 0.52 (0.30 to 0.91), NNT 54].

###### Injectable Low Molecular Weight Heparin Agents Versus Injectable or Oral Direct Thrombin Inhibitors

Three randomized controlled trials evaluated the impact of injectable low molecular weight heparin prophylaxis versus injectable or oral direct thrombin inhibitor prophylaxis on minor bleeding in patients who had major orthopedic surgery.66,67,94 All three trials provided two separate comparisons. In patients who received injectable low molecular weight heparin prophylaxis versus injectable or oral direct thrombin inhibitor prophylaxis the risk of minor bleeding was not significantly different [RR 1.07 (0.89 to 1.29)] (Appendix G Figure 180). Statistical heterogeneity and publication bias were not detected (I^2^=0 percent, Egger's p-value=0.132). This is the same result obtained when limiting the original analysis to trials published from 2001-present.

When limiting the original analysis to total hip replacement surgery one trial remained including two separate comparisons.67 In patients who received injectable low molecular weight heparin prophylaxis versus injectable or oral direct thrombin inhibitor prophylaxis the risk of minor bleeding was not significantly different [RR 1.04 (0.79 to 1.37)] (Appendix G Figure 181). Statistical heterogeneity could not be evaluated because of too few studies. When limiting the original analysis to total knee replacement surgery two trials that included two separate comparisons remained.66,94 In patients who received injectable low molecular weight heparin prophylaxis versus injectable or oral direct thrombin inhibitor prophylaxis the risk of minor bleeding was not significantly different [RR 1.10 (0.86 to 1.40)] (Appendix G Figure 182). Statistical heterogeneity was not detected (I^2^=0 percent). Subgroup analysis based on hip fracture surgery was not possible because no trials evaluated this surgical population.

Subgroup analyses based on age, gender and ethnicity were not possible because no randomized controlled trials reported data based on these subgroups.

One randomized controlled trial including two separate comparisons evaluated the impact of injectable low molecular weight heparin versus injectable or oral direct thrombin inhibitor prophylaxis on minor bleeding during the postdischarge time period in patients who had total knee replacement surgery.94 In this trial patients who had total knee replacement surgery were randomized to receive either enoxaparin, dabigatran 150mg or dabigatran 220mg daily. In patients who received injectable low molecular weight heparin versus injectable or oral direct thrombin inhibitor prophylaxis the risk of minor bleeding during the postdischarge period was not significantly different [RR 0.54 (0.15 to 1.95)] (Appendix G Figure 183).

###### Injectable Low Molecular Weight Heparin Agents Versus Oral Vitamin K Antagonists

Eight randomized controlled trials evaluated the impact of injectable low molecular weight prophylaxis versus oral vitamin K antagonist prophylaxis on minor bleeding in patients who had major orthopedic surgery. 60,75,77,80,81,84,85 The trial by Hull and colleagues in 1993 provided two separate comparisons.80 The trial Hull and colleagues in 2000 including two separate comparisons but was excluded from the pooled analysis because minor bleeding was reported at two postoperative time periods; days 0-1 and days 2-8.^81^ The remaining seven trials were pooled and in patients who received injectable low molecular weight heparin prophylaxis versus oral vitamin K antagonist prophylaxis the risk of minor bleeding was significantly increased [RR 1.23 (1.06 to 1.43), NNH 18 to 218] (Appendix G Figure 184). Statistical heterogeneity and publication bias were not detected (I^2^=0 percent, Egger's p-value=0.311).

The trial by Hull and colleagues in 2000 that was excluded from the pooled analyses was evaluated separately.80 In this trial patients who had total hip replacement surgery were randomized to receive dalteparin initiated preoperatively, dalteparin initiated postoperatively or warfarin prophylaxis. In patients who received injectable low molecular weight heparin versus oral vitamin K antagonist prophylaxis the risk of minor bleeding was not significantly different on days 0-1 [RR 1.49 (0.30 to 7.37)] (Appendix G Figure 185) or on days 2-8 [RR 0.87 (0.37 to 2.06)] (Appendix G Figure 186).

When limiting the original pooled analysis of seven trials to trials published from 2001-present two trials remained.75,84 In patients who received injectable low molecular weight heparin prophylaxis versus oral vitamin K antagonist prophylaxis the risk of minor bleeding was not significantly different [RR 1.25 (0.85 to 1.83)] (Appendix G Figure 187). Statistical heterogeneity could not be evaluated because of too few studies. When limiting the original analysis to total hip replacement surgery three trials remained.60,77,80 In patients who received injectable low molecular weight heparin prophylaxis versus oral vitamin K antagonist prophylaxis the risk of minor bleeding was not significantly different [RR 1.26 (0.85 to 1.86)] (Appendix G Figure 188). A lower level of statistical heterogeneity was detected (I^2^=27.8 percent). When limiting the original analysis to total knee replacement surgery four trials remained.75,80,84,85 In patients who received injectable low molecular weight heparin prophylaxis versus oral vitamin K antagonist prophylaxis the risk of minor bleeding was not significantly different [RR 1.17 (0.95 to 1.43)] (Appendix G Figure 189). Statistical heterogeneity was not detected (I^2^=0 percent). No trials evaluated patients with hip fracture surgery.

Subgroup analyses based on age, gender and ethnicity were not possible because no randomized controlled trials reported data based on these subgroups.

###### Injectable Low Molecular Weight Heparin Agents Versus Mechanical Prophylaxis

No randomized controlled trials or controlled observational studies evaluated the impact of injectable low molecular weight heparin prophylaxis versus mechanical prophylaxis in patients who had major orthopedic surgery on this outcome.

###### Injectable Unfractionated Heparin Versus Injectable or Oral Direct Thrombin Inhibitors

No randomized controlled trials or controlled observational studies evaluated the impact of injectable unfractionated heparin prophylaxis versus injectable or oral direct thrombin inhibitor prophylaxis in patients who had major orthopedic surgery on this outcome.

###### Injectable Unfractionated Heparin Versus Injectable or Oral Factor Xa Inhibitors

No randomized controlled trials or controlled observational studies evaluated the impact of injectable unfractionated heparin prophylaxis versus injectable or oral factor Xa inhibitor prophylaxis in patients who had major orthopedic surgery on this outcome.

###### Injectable Unfractionated Heparin Versus Mechanical Prophylaxis

No randomized controlled trials or controlled observational studies evaluated the impact injectable unfractionated heparin prophylaxis versus mechanical prophylaxis in patients who had major orthopedic surgery on this outcome.

###### Oral Vitamin K Antagonists Versus Mechanical Prophylaxis

Two randomized controlled trials evaluated the impact of oral vitamin K antagonist prophylaxis versus mechanical prophylaxis on minor bleeding in patients who had major orthopedic surgery.76,90 In patients who received injectable low molecular weight heparin prophylaxis versus oral vitamin K antagonist prophylaxis the odds of minor bleeding were not significantly different [OR 0.80 (0.26 to 2.41)] (Appendix G Figure 190). Statistical heterogeneity and publication bias could not be evaluated because of too few studies. This is the same result obtained when limiting the analysis to trials limited to total hip replacement surgery. Subgroup analyses based on trials published 2001-present, total knee replacement and hip fracture surgery were not possible as no trials fit these criteria.

Subgroup analyses based on age, gender and ethnicity were not possible because no randomized controlled trials reported data based on these subgroups.

##### Surgical Site Bleeding

###### Oral Antiplatelet Agents Versus Oral Vitamin K Antagonists

One controlled observational study evaluated the impact of oral antiplatelet prophylaxis versus oral vitamin K antagonist prophylaxis on surgical site bleeding in patients who had major orthopedic surgery.148 This study evaluated patients who had total knee replacement surgery and who received either aspirin or warfarin prophylaxis.148 The odds of surgical site bleeding for patients who received warfarin versus aspirin prophylaxis were not significantly different [AOR 0.97 (0.65 to 1.47)].

###### Oral Antiplatelet Agents Versus Mechanical Prophylaxis

No randomized controlled trials or controlled observational studies evaluated the impact of oral antiplatelet agents versus mechanical prophylaxis in patients who had major orthopedic surgery on this outcome.

###### Injectable Low Molecular Weight Heparin Agents Versus Injectable Unfractionated Heparin

Three randomized controlled trials evaluated the impact of injectable low molecular weight heparin agents versus injectable unfractionated heparin on surgical site bleeding in patients who had major orthopedic surgery with one trial including two separate comparisons.61,62,97 In patients who received injectable low molecular weight heparin agents versus injectable unfractionated heparin, the odds of surgical site bleeding were not significantly different [OR 0.92 (0.46 to 1.82) ] (Appendix G Figure 191). A lower level of statistical heterogeneity and the presence of publication bias were detected (I^2^=41.4 percent, Egger's p-value=0.021) although the directionality of the publication bias was unclear.

When limiting the original analysis to trials published from 2001-present, one trial remained.97 In this trial, in patients who received injectable low molecular weight heparin agents versus injectable unfractionated heparin, the risk of surgical site bleeding was not significantly different [RR 0.75 (0.20 to 2.86)]. When limiting the original analysis to total hip replacement surgery, two trials remained with one trial including two separate comparisons.61,97 In patients who received injectable low molecular weight heparin agents versus injectable unfractionated heparin, the risk of surgical site bleeding was not significantly different [RR 0.63 (0.26 to 1.55)] (Appendix G Figure 192). A lower level of statistical heterogeneity was detected (I^2^=3.1 percent). When limiting the original analysis to total knee replacement surgery, one trial remained.62 In this trial, in patients who received injectable low molecular weight heparin agents versus injectable unfractionated heparin, the odds of surgical site bleeding were not significantly different [OR 1.78 (0.61 to 5.14)]. Subgroup analysis based on hip fracture surgery was not possible because no trials evaluated this surgical population.

Subgroup analyses based on age, gender and ethnicity were not possible because no randomized controlled trials reported data based on these subgroups.

###### Injectable Low Molecular Weight Heparin Agents Versus Injectable or Oral Factor Xa Inhibitors

One randomized controlled trial by Lassen and colleagues in 2002 evaluated the impact of injectable low molecular weight heparin agents versus injectable or oral factor Xa inhibitors on surgical site bleeding in patients who had major orthopedic surgery.83 In this trial, patients who had total hip replacement surgery were randomized to receive either enoxaparin or fondaparinux prophylaxis. In patients who received injectable low molecular weight heparin agents versus injectable or oral factor Xa inhibitors, the odds of surgical site bleeding were not significantly different [OR 0.72 (0.45 to 1.17)]. Subgroup analyses were not possible as this was the only trial available.

###### Injectable Low Molecular Weight Heparin Agents Versus Injectable or Oral Direct Thrombin Inhibitors

One randomized controlled trial by Ginsberg and colleagues in 2009 evaluated the impact of injectable low molecular weight heparin agents versus injectable or oral direct thrombin inhibitors on surgical site bleeding in patients who had major orthopedic surgery and included two separate comparisons.94 In this trial, patients who had total knee replacement surgery were randomized to receive either enoxaparin, dabigatran 150mg or dabigatran 220mg. In patients who received injectable low molecular weight heparin agents versus injectable or oral direct thrombin inhibitors, the risk of surgical site bleeding was significantly increased [RR 4.35 (1.51 to 12.54), NNH 100 to 105] (Appendix G Figure 193). Subgroup analyses were not possible as this was the only trial available.

###### Injectable Low Molecular Weight Heparin Agents Versus Oral Vitamin K Antagonists

Two randomized controlled trials evaluated the impact of injectable low molecular weight heparin agents versus oral vitamin K antagonists on surgical site bleeding in patients who had major orthopedic surgery.75,77 In patients who received injectable low molecular weight heparin agents versus oral vitamin K antagonists, the odds of surgical site bleeding were significantly increased [OR 2.63 (1.31 to 5.28), NNH 23 to 64] (Appendix G Figure 194). Statistical heterogeneity and publication bias could not be evaluated because of too few studies.

When limiting the original analysis to trials published from 2001-present, one trial remained.75 In this trial, in patients who received injectable low molecular weight heparin agents versus oral vitamin K antagonists, the odds of surgical site bleeding were not significantly different [OR 2.05 (0.80 to 5.29)]. This is the same result obtained when limiting the analysis to total knee replacement surgery. When limiting the original analysis to total hip replacement surgery, one trial remained.77 In this trial, in patients who received injectable low molecular weight heparin agents versus oral vitamin K antagonists, the odds of surgical site bleeding were significantly increased [OR 3.53 (1.27 to 9.84), NNH 42]. Subgroup analysis based on hip fracture surgery was not possible because no trials evaluated this surgical population.

Subgroup analyses based on age, gender and ethnicity were not possible because no randomized controlled trials reported data based on these subgroups.

Three randomized controlled trials evaluated the impact of injectable low molecular weight heparin agents versus oral vitamin K antagonists on major surgical site bleeding in patients who had major orthopedic surgery.60,80,81 The trial by Hull and colleagues in 2000 was excluded from the pooled analysis because major surgical site bleeding was reported at two postoperative time periods; days 0-1 and days 2-8.^81^ The remaining two trials were pooled and in patients who received injectable low molecular weight heparin agents versus oral vitamin K antagonists, the odds of major surgical site bleeding were significantly increased [OR 2.51 (1.38 to 4.54), NNH 70 to 224] (Appendix G Figure 195). Statistical heterogeneity and publication bias could not be evaluated because of too few studies.

The trial by Hull and colleagues in 2000 that was excluded from the pooled analysis was evaluated separately.81 In this trial patients who had total hip replacement surgery were randomized to receive dalteparin initiated preoperatively, dalteparin initiated postoperatively or warfarin prophylaxis. In patients who received injectable low molecular weight heparin versus oral vitamin K antagonist prophylaxis the risk of major surgical site bleeding was significantly increased on days 0 to 1 [RR 1.72 (1.02 to 2.92), NNH 47] (Appendix G Figure 196) but was not significantly different on days 2 to 8 [RR 2.72 (0.59 to 12.44)] (Appendix G Figure 197). A range for the number needed to harm for major surgical site bleeding on days 0-1 could not be calculated because the control events rate was the same in both groups.

When limiting the original pooled analysis of two trials to total hip replacement surgery, one trial remained.60 In this trial, in patients who received injectable low molecular weight heparin agents versus oral vitamin K antagonists, the odds of major surgical site bleeding were significantly increased [OR 2.56 (1.04 to 6.30), NNH 216]. Subgroup analyses based on trials published from 2001-present, total knee replacement or hip fracture surgery were not possible because no trials fit these criteria. The trial by Hull and colleagues in 1993 evaluated both total hip and knee replacement surgery although did not report results separately. Subgroup analyses based on age, gender and ethnicity were not possible because no randomized controlled trials reported data based on these subgroups.

Three randomized controlled trials evaluated the impact of injectable low molecular weight heparin agents versus oral vitamin K antagonists on minor surgical site bleeding in patients who had major orthopedic surgery.60,80,81 The trial by Hull and colleagues in 2000 was excluded from the pooled analysis because minor surgical site bleeding was reported at two postoperative time periods; days 0-1 and days 2-8.^81^ The two remaining trials were pooled and in patients who received injectable low molecular weight heparin agents versus oral vitamin K antagonists, the odds of minor surgical site bleeding were not significantly different [OR 1.34 (0.91 to 1.97)] (Appendix G Figure 198). Statistical heterogeneity and publication bias could not be evaluated because of too few studies.

The trial by Hull and colleagues in 2000 was excluded from the pooled analysis and was evaluated separately.81 In this trial patients who had total hip replacement surgery were randomized to receive dalteparin initiated preoperatively, dalteparin initiated postoperatively or warfarin prophylaxis. No events occurred in the comparison of dalteparin initiated preoperatively versus warfarin. In the remaining comparison, in patients who received injectable low molecular weight heparin versus oral vitamin K antagonist prophylaxis the odds of minor surgical site bleeding were not significantly different on days 0 to 1 [OR 7.42 (0.15 to 373.92)] or on days two to eight [OR 7.43 (0.46 to 119.03)].

When limiting the original pooled analysis of two trials to total hip replacement surgery, one trial remained.60 In this trial, in patients who received injectable low molecular weight heparin agents versus oral vitamin K antagonists, the odds of minor surgical site bleeding were not significantly different [OR 1.37 (0.93 to 2.02)]. Subgroup analyses based on trials published from 2001-present, total knee replacement or hip fracture surgery were not possible because no trials fit these criteria. Subgroup analyses based on age, gender and ethnicity were not possible because no randomized controlled trials reported data based on these subgroups.

###### Injectable Low Molecular Weight Heparin Agents Versus Mechanical Prophylaxis

No randomized controlled trials or controlled observational studies evaluated the impact of injectable low molecular weight heparin agents versus mechanical prophylaxis in patients who had major orthopedic surgery on this outcome.

###### Injectable Unfractionated Heparin Versus Injectable or Oral Direct Thrombin Inhibitors

One randomized controlled trial by Eriksson and colleagues in 1996 evaluated the impact of injectable unfractionated heparin versus injectable or oral direct thrombin inhibitors on surgical site bleeding in patients who had major orthopedic surgery.68 In this trial, patients who had total hip replacement surgery were randomized to receive either unfractionated heparin or desirudin. In patients who received injectable unfractionated heparin versus injectable or oral direct thrombin inhibitors, the odds of surgical site bleeding were not significantly different [OR 0.87 (0.31 to 2.43)]. Subgroup analyses were not possible as this was the only trial available.

###### Injectable Unfractionated Heparin Versus Injectable or Oral Factor Xa Inhibitors

No randomized controlled trials or controlled observational studies evaluated the impact of injectable unfractionated heparin prophylaxis versus injectable or oral factor Xa inhibitor prophylaxis in patients who had major orthopedic surgery on this outcome.

###### Injectable Unfractionated Heparin Versus Mechanical Prophylaxis

No randomized controlled trials or controlled observational studies evaluated the impact of injectable unfractionated heparin versus mechanical prophylaxis in patients who had major orthopedic surgery on this outcome.

###### Oral Vitamin K Antagonists Versus Mechanical Prophylaxis

No randomized controlled trials or controlled observational studies evaluated the impact of oral vitamin K antagonists versus mechanical prophylaxis in patients who had major orthopedic surgery on this outcome.

##### Bleeding Leading to Infection

No randomized controlled trials or controlled observational studies compared between pharmacological and/or mechanical classes of prophylaxis to evaluate this outcome.

##### Bleeding Leading to Transfusion

###### Oral Antiplatelet Agents Versus Oral Vitamin K Antagonists

No randomized controlled trials or controlled observational studies evaluated the impact of oral antiplatelet prophylaxis versus oral vitamin K antagonist prophylaxis in patients who had major orthopedic surgery on this outcome.

###### Oral Antiplatelet Agents Versus Mechanical Prophylaxis

No randomized controlled trials or controlled observational studies evaluated the impact of oral antiplatelet prophylaxis versus mechanical prophylaxis in patients who had major orthopedic surgery on this outcome.

###### Injectable Low Molecular Weight Heparin Agents Versus Injectable Unfractionated Heparin

No randomized controlled trials or controlled observational studies evaluated the impact of injectable low molecular weight heparin prophylaxis versus injectable unfractionated heparin prophylaxis in patients who had major orthopedic surgery on this outcome.

###### Injectable Low Molecular Weight Heparin Agents Versus Injectable or Oral Factor Xa Inhibitors

No randomized controlled trials or controlled observational studies evaluated the impact of injectable low molecular weight heparin prophylaxis versus injectable or oral factor Xa inhibitor prophylaxis in patients who had major orthopedic surgery on this outcome.

###### Injectable Low Molecular Weight Heparin Agents Versus Injectable or Oral Direct Thrombin Inhibitors

Two randomized controlled trials evaluated the impact of injectable low molecular weight heparin prophylaxis versus injectable or oral direct thrombin inhibitor prophylaxis on bleeding leading to transfusion in patients who had major orthopedic surgery and each trial included two separate comparisons.66,67 In patients who received injectable low molecular weight heparin prophylaxis versus injectable or oral direct thrombin inhibitor prophylaxis, the risk of bleeding leading to transfusion was not significantly different [RR 1.00 (0.59 to 1.69)] (Figure 10 ). Statistical heterogeneity and publication bias were not detected (I^2^=0 percent, Egger's p-value=0.827). This is the same result obtained when limiting the original analysis to trials published from 2001-present. When limiting the original analysis to total hip replacement surgery, one trial which included two separate comparisons remained.67 In patients who received injectable low molecular weight heparin prophylaxis versus injectable or oral direct thrombin inhibitor prophylaxis, the risk of bleeding leading to transfusion was not significantly different [RR 1.19 (0.46 to 3.10)] (Appendix G Figure 199). Statistical heterogeneity could not be evaluated because of too few studies. When limiting the original analysis to total knee replacement surgery, one trial which included two separate comparisons remained.66 In patients who received injectable low molecular weight heparin prophylaxis versus injectable or oral direct thrombin inhibitor prophylaxis, the risk of bleeding leading to transfusion was not statistically significant [RR 0.71 (0.26 to 1.98)] (Appendix G Figure 200). Statistical heterogeneity could not be evaluated because of too few studies. No trials evaluated patients who had hip fracture surgery.

Figure 10 Impact of injectable low molecular weight heparin prophylaxis versus injectable or oral direct thrombin inhibitor prophylaxis on bleeding leading to transfusion in patients who had major orthopedic surgery (same as analysis of 2001-present)

I^2^: 0 percent.

Egger's p-value: P=0.823.

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of injectable low molecular weight heparin prophylaxis versus injectable or oral direct thrombin inhibitor prophylaxis on bleeding leading to transfusion in patients who had major orthopedic surgery. This figure also depicts the analysis of the impact of injectable low molecular weight heparin prophylaxis versus injectable or oral direct thrombin inhibitor prophylaxis on bleeding leading to transfusion in patients who had major orthopedic surgery limited to trials published from 2001-present. Two trials were included with the two trials contributing two separate comparisons presented individually here. The first trial by Eriksson and colleagues in 2007 included two comparisons. The first comparison provided a relative risk of 2.02 with a 95 percent confidence interval of 0.79 to 5.16. The second comparison provided a relative risk of 0.76 with a 95 percent confidence interval of 0.34 to 1.66. The second trial by Eriksson and colleagues in 2007 included two comparisons. The first comparison provided a relative risk of 0.84 with a 95 percent confidence interval of 0.22 to 3.29. The second comparison provided a relative risk of 0.61 with a 95 percent confidence interval of 0.16 to 2.27. The combined effect of the two trials showed a relative risk of 1.00 with a 95 percent confidence interval of 0.59 to 1.69. The I-squared value was 0 percent and the Egger's p-value was 0.823.

Subgroup analyses based on age, gender and ethnicity were not possible because no randomized controlled trials reported data based on these subgroups.

###### Injectable Low Molecular Weight Heparin Agents Versus Oral Vitamin K Antagonists

One randomized controlled trial evaluated the impact of injectable low molecular weight prophylaxis versus oral vitamin K antagonist prophylaxis on bleeding leading to transfusion in patients who had major orthopedic surgery.77 This trial by Francis and colleagues in 1997, evaluated patients who had total hip replacement surgery. In this trial, in patients who received injectable low molecular weight heparin prophylaxis versus oral vitamin K antagonist prophylaxis the odds of bleeding leading to transfusion were not significantly different [OR 1.71 (0.42 to 6.90)]. Subgroup analyses were not possible because only one trial was available.

###### Injectable Low Molecular Weight Heparin Agents Versus Mechanical Prophylaxis

No randomized controlled trials or controlled observational studies evaluated the impact of injectable low molecular weight heparin prophylaxis versus mechanical prophylaxis on bleeding leading to transfusion in patients who had major orthopedic surgery.

###### Injectable Unfractionated Heparin Versus Injectable or Oral Direct Thrombin Inhibitors

No randomized controlled trials or controlled observational studies evaluated the impact of injectable unfractionated heparin versus injectable or oral direct thrombin inhibitors on bleeding leading to transfusion in patients who had major orthopedic surgery.

###### Injectable Unfractionated Heparin Versus Injectable or Oral Factor Xa Inhibitors

No randomized controlled trials or controlled observational studies evaluated the impact of injectable unfractionated heparin prophylaxis versus injectable or oral factor Xa inhibitor prophylaxis in patients who had major orthopedic surgery on this outcome.

###### Injectable Unfractionated Heparin Versus Mechanical Prophylaxis

No randomized controlled trials or controlled observational studies evaluated the impact injectable unfractionated heparin prophylaxis versus mechanical prophylaxis on bleeding leading to transfusion in patients who had major orthopedic surgery.

###### Oral Vitamin K Antagonists Versus Mechanical Prophylaxis

One randomized controlled trial evaluated the impact of oral vitamin K antagonist prophylaxis versus mechanical prophylaxis on bleeding leading to transfusion although no events occurred in the groups compared therefore the risk could not be calculated.76

##### Heparin Induced Thrombocytopenia

###### Oral Antiplatelet Agents Versus Oral Vitamin K Antagonists

No randomized controlled trials or controlled observational studies evaluated the impact of oral antiplatelet prophylaxis versus oral vitamin K antagonist prophylaxis in patients who had major orthopedic surgery on this outcome.

###### Oral Antiplatelet Agents Versus Mechanical Prophylaxis

No randomized controlled trials or controlled observational studies evaluated the impact of oral antiplatelet prophylaxis versus mechanical prophylaxis in patients who had major orthopedic surgery on this outcome.

###### Injectable Low Molecular Weight Heparin Agents Versus Injectable Unfractionated Heparin

Three randomized controlled trials evaluated the impact of injectable low molecular weight heparin prophylaxis versus injectable unfractionated heparin prophylaxis on heparin-induced thrombocytopenia in patients who had major orthopedic surgery.61,86,97 One trial by Colwell and colleagues included two separate comparisons.61 One trial was excluded from the analysis because no events occurred in the groups compared.97 In patients who received injectable low molecular weight heparin prophylaxis versus injectable unfractionated heparin prophylaxis, the odds of heparin induced thrombocytopenia was significantly decreased [OR 0.12 (0.03 to 0.43), NNT 34 to 202] (Appendix G Figure 201). Statistical heterogeneity was not detected (I^2^=0 percent) and publication bias could not be evaluated because of too few studies. This is the same result obtained when limiting the original analysis to total hip replacement as all three trials were conducted in this surgical population. No trials evaluated total knee replacement or hip fracture surgery. When limiting the original analysis to trials published from 2001-present, one trial remained although no events occurred in the groups compared.97

Subgroup analyses based on age, gender and ethnicity were not possible because no randomized controlled trials reported data based on these subgroups.

###### Injectable Low Molecular Weight Heparin Agents Versus Injectable or Oral Factor Xa Inhibitors

No randomized controlled trials or controlled observational studies evaluated the impact of injectable low molecular weight heparin prophylaxis versus injectable or oral factor Xa inhibitor prophylaxis in patients who had major orthopedic surgery on this outcome.

###### Injectable Low Molecular Weight Heparin Agents Versus Injectable or Oral Direct Thrombin Inhibitors

No randomized controlled trials or controlled observational studies evaluated the impact of injectable low molecular weight heparin prophylaxis versus injectable or oral direct thrombin inhibitor prophylaxis in patients who had major orthopedic surgery on this outcome.

###### Injectable Low Molecular Weight Heparin Agents Versus Oral Vitamin K Antagonists

One randomized controlled trial evaluated the impact of injectable low molecular weight prophylaxis versus oral vitamin K antagonist prophylaxis on heparin-induced thrombocytopenia in patients who had major orthopedic surgery although no events occurred in the groups compared therefore the risk of heparin-induced thrombocytopenia could not be calculated.60

###### Injectable Low Molecular Weight Heparin Agents Versus Mechanical Prophylaxis

No randomized controlled trials or controlled observational studies evaluated the impact of injectable low molecular weight heparin prophylaxis versus mechanical prophylaxis in patients who had major orthopedic surgery on this outcome.

###### Injectable Unfractionated Heparin Versus Injectable or Oral Direct Thrombin Inhibitors

No randomized controlled trials or controlled observational studies evaluated the impact of injectable unfractionated heparin versus injectable or oral direct thrombin inhibitors in patients who had major orthopedic surgery on this outcome.

###### Injectable Unfractionated Heparin Versus Injectable or Oral Factor Xa Inhibitors

No randomized controlled trials or controlled observational studies evaluated the impact of injectable unfractionated heparin prophylaxis versus injectable or oral factor Xa inhibitor prophylaxis in patients who had major orthopedic surgery on this outcome.

###### Injectable Unfractionated Heparin Versus Mechanical Prophylaxis

No randomized controlled trials or controlled observational studies evaluated the impact of injectable unfractionated heparin prophylaxis versus mechanical prophylaxis in patients who had major orthopedic surgery on this outcome.

###### Oral Vitamin K Antagonists Versus Mechanical Prophylaxis

No randomized controlled trials or controlled observational studies evaluated the impact of oral vitamin K antagonist prophylaxis versus mechanical prophylaxis in patients who had major orthopedic surgery on this outcome.

##### Discomfort

###### Oral Antiplatelet Agents Versus Oral Vitamin K Antagonists

No randomized controlled trials or controlled observational studies evaluated the impact of oral antiplatelet prophylaxis versus oral vitamin K antagonist prophylaxis in patients who had major orthopedic surgery on this outcome.

###### Oral Antiplatelet Agents Versus Mechanical Prophylaxis

No randomized controlled trials or controlled observational studies evaluated the impact of oral antiplatelet prophylaxis versus mechanical prophylaxis in patients who had major orthopedic surgery on this outcome.

###### Injectable Low Molecular Weight Heparin Agents Versus Injectable Unfractionated Heparin

No randomized controlled trials or controlled observational studies evaluated the impact of injectable low molecular weight heparin prophylaxis versus injectable unfractionated heparin prophylaxis in patients who had major orthopedic surgery on this outcome.

###### Injectable Low Molecular Weight Heparin Agents Versus Injectable or Oral Factor Xa Inhibitors

No randomized controlled trials or controlled observational studies evaluated the impact of injectable low molecular weight heparin prophylaxis versus injectable or oral factor Xa inhibitor prophylaxis in patients who had major orthopedic surgery on this outcome.

###### Injectable Low Molecular Weight Heparin Agents Versus Injectable or Oral Direct Thrombin Inhibitors

No randomized controlled trials or controlled observational studies evaluated the impact of injectable low molecular weight heparin prophylaxis versus injectable or oral direct thrombin inhibitor prophylaxis in patients who had major orthopedic surgery on this outcome.

###### Injectable Low Molecular Weight Heparin Agents Versus Oral Vitamin K Antagonists

No randomized controlled trial or controlled observational studies evaluated the impact of injectable low molecular weight prophylaxis versus oral vitamin K antagonist prophylaxis in patients who had major orthopedic surgery on this outcome.

###### Injectable Low Molecular Weight Heparin Agents Versus Mechanical Prophylaxis

One randomized controlled trial by Warwick and colleagues in 1998 evaluated the impact of injectable low molecular weight heparin versus mechanical prophylaxis on discomfort in patients who had major orthopedic surgery.101 In this trial, patients who had total hip replacement surgery were randomized to receive either enoxaparin or venous foot pump prophylaxis. Discomfort reported as “quite a bit of difficulty sleeping” or “quite uncomfortable” in patients who received mechanical prophylaxis and “quite painful” or “quite uncomfortable” in patients who received low molecular weight heparin was used. Although the discomfort was defined differently in each arm, in patients who received injectable low molecular weight heparin versus mechanical prophylaxis the risk of discomfort was significantly decreased [RR 0.49 (0.29 to 0.82), NNT 7].

###### Injectable Unfractionated Heparin Versus Injectable or Oral Direct Thrombin Inhibitors

No randomized controlled trials or controlled observational studies evaluated the impact of injectable unfractionated heparin versus injectable or oral direct thrombin inhibitors in patients who had major orthopedic surgery on this outcome.

###### Injectable Unfractionated Heparin Versus Injectable or Oral Factor Xa Inhibitors

No randomized controlled trials or controlled observational studies evaluated the impact of injectable unfractionated heparin prophylaxis versus injectable or oral factor Xa inhibitor prophylaxis in patients who had major orthopedic surgery on this outcome.

###### Injectable Unfractionated Heparin Versus Mechanical Prophylaxis

No randomized controlled trials or controlled observational studies evaluated the impact of injectable unfractionated heparin prophylaxis versus mechanical prophylaxis in patients who had major orthopedic surgery on this outcome.

###### Oral Vitamin K Antagonists Versus Mechanical Prophylaxis

No randomized controlled trials or controlled observational studies evaluated the impact of oral vitamin K antagonist prophylaxis versus mechanical prophylaxis in patients who had major orthopedic surgery on this outcome.

##### Readmission

###### Oral Antiplatelet Agents Versus Oral Vitamin K Antagonists

No randomized controlled trials or controlled observational studies evaluated the impact of oral antiplatelet prophylaxis versus oral vitamin K antagonist prophylaxis in patients who had major orthopedic surgery on this outcome.

###### Oral Antiplatelet Agents Versus Mechanical Prophylaxis

No randomized controlled trials or controlled observational studies evaluated the impact of oral antiplatelet prophylaxis versus mechanical prophylaxis in patients who had major orthopedic surgery on this outcome.

###### Injectable Low Molecular Weight Heparin Agents Versus Injectable Unfractionated Heparin

Two randomized controlled trials evaluated the impact of injectable low molecular weight heparin prophylaxis versus injectable unfractionated heparin prophylaxis on readmission in patients who had major orthopedic surgery.61,97 One trial by Colwell and colleagues included two separate comparisons.61 In patients who received injectable low molecular weight heparin prophylaxis versus injectable unfractionated heparin prophylaxis, the risk of readmission was not significantly different [RR 0.82 (0.20 to 3.38)] (Appendix G Figure 202). A lower level of statistical heterogeneity was detected (I^2^=14.1 percent) and publication bias could not be evaluated because of too few studies. The reasons reported for readmission in the low molecular weight heparin group included deep vein thrombosis while in the unfractionated heparin group included deep vein thrombosis and pulmonary embolism. This is the same results obtained when limiting the original analysis to total hip replacement as both trials were conducted in this surgical population. No trials evaluated total knee replacement or hip fracture surgery. When limiting the original analysis to trials published from 2001-present, one trial remained.97 In this trial, in patients who received injectable low molecular weight heparin versus injectable unfractionated heparin prophylaxis, the odds of readmission were not significantly different [OR 7.54 (0.47 to 122.23)]. The reported reason for readmission in the low molecular weight heparin group was venous thromboembolic disease, while no readmissions occurred in the unfractionated heparin group.

Subgroup analyses based on age, gender and ethnicity were not possible because no randomized controlled trials reported data based on these subgroups.

###### Injectable Low Molecular Weight Heparin Agents Versus Injectable or Oral Factor Xa Inhibitors

No randomized controlled trials or controlled observational studies evaluated the impact of injectable low molecular weight heparin prophylaxis versus injectable or oral factor Xa inhibitor prophylaxis in patients who had major orthopedic surgery on this outcome.

###### Injectable Low Molecular Weight Heparin Agents Versus Injectable or Oral Direct Thrombin Inhibitors

No randomized controlled trials or controlled observational studies evaluated the impact of injectable low molecular weight heparin prophylaxis versus injectable or oral direct thrombin inhibitor prophylaxis in patients who had major orthopedic surgery on this outcome.

###### Injectable Low Molecular Weight Heparin Agents Versus Oral Vitamin K Antagonists

No randomized controlled trials or controlled observational studies evaluated the impact of injectable low molecular weight heparin prophylaxis versus oral vitamin K antagonist prophylaxis in patients who had major orthopedic surgery on this outcome.

###### Injectable Low Molecular Weight Heparin Agents Versus Mechanical Prophylaxis

Two randomized controlled trials evaluated the impact of injectable low molecular weight heparin prophylaxis versus mechanical prophylaxis on readmission in patients who had major orthopedic surgery.101,102 In patients who received injectable low molecular weight heparin prophylaxis versus mechanical prophylaxis the odds of readmission were not significantly different [OR 0.83 (0.22 to 3.11)] (Appendix G Figure 203). Statistical heterogeneity and publication bias could not be evaluated because of too few studies.

When limiting the original analysis to trials published from 2001-present one trial by Warwick and colleagues remained.102 In this trial in patients who received injectable low molecular weight heparin prophylaxis versus mechanical prophylaxis the odds of readmission were not significantly different [OR 0.78 (0.17 to 3.50)]. This is the same result obtained when limiting the original analysis to total knee replacement surgery. When limiting the original analysis to total hip replacement, one trial remained.101 In this trial, in patients who received injectable low molecular weight heparin versus mechanical prophylaxis the odds of readmission were not significantly different [OR 1.03 (0.06 to 16.52)]. No trials evaluated hip fracture surgery.

Subgroup analyses based on age, gender and ethnicity were not possible because no randomized controlled trials reported data based on these subgroups.

###### Injectable Unfractionated Heparin Versus Injectable or Oral Direct Thrombin Inhibitors

No randomized controlled trials or controlled observational studies evaluated the impact of injectable unfractionated heparin versus injectable or oral direct thrombin inhibitors in patients who had major orthopedic surgery on this outcome.

###### Injectable Unfractionated Heparin Versus Injectable or Oral Factor Xa Inhibitors

No randomized controlled trials or controlled observational studies evaluated the impact of injectable unfractionated heparin prophylaxis versus injectable or oral factor Xa inhibitor prophylaxis in patients who had major orthopedic surgery on this outcome.

###### Injectable Unfractionated Heparin Versus Mechanical Prophylaxis

No randomized controlled trials or controlled observational studies evaluated the impact of injectable unfractionated heparin versus mechanical prophylaxis in patients who had major orthopedic surgery on this outcome.

###### Oral Vitamin K Antagonists Versus Mechanical Prophylaxis

One randomized controlled trials evaluated the impact of oral vitamin K antagonist prophylaxis versus mechanical prophylaxis on readmission in patients who had major orthopedic surgery.56 This trial evaluated patients who had total hip replacement surgery. In patients who received oral vitamin K antagonist prophylaxis versus mechanical prophylaxis, the odds of readmission were not significantly different [OR 0.15 (0.003 to 7.58)]. Subgroup analyses were not possible because only one trial was available.

##### Reoperation

###### Oral Antiplatelet Agents Versus Oral Vitamin K Antagonists

No randomized controlled trials or controlled observational studies evaluated the impact of oral antiplatelet prophylaxis versus oral vitamin K antagonist prophylaxis in patients who had major orthopedic surgery on this outcome.

###### Oral Antiplatelet Agents Versus Mechanical Prophylaxis

No randomized controlled trials or controlled observational studies evaluated the impact of oral antiplatelet prophylaxis versus mechanical prophylaxis in patients who had major orthopedic surgery on this outcome.

###### Injectable Low Molecular Weight Heparin Agents Versus Injectable Unfractionated Heparin

No randomized controlled trials or controlled observational studies evaluated the impact of injectable low molecular weight heparin prophylaxis versus injectable unfractionated heparin prophylaxis in patients who had major orthopedic surgery on this outcome.

###### Injectable Low Molecular Weight Heparin Agents Versus Injectable or Oral Factor Xa Inhibitors

One randomized controlled trials evaluated the impact of injectable low molecular weight heparin prophylaxis versus injectable or oral factor Xa inhibitor prophylaxis on reoperation in patients who had major orthopedic surgery.58 This trial by Bonneaux and colleagues in 2006 evaluated patients who had total knee replacement surgery. In patients who received injectable low molecular weight heparin prophylaxis versus injectable or oral factor Xa inhibitor prophylaxis, the risk of reoperation was not significantly different [RR 0.25 (0.04 to 1.63)]. Subgroup analyses were not possible since this was the only trial available.

###### Injectable Low Molecular Weight Heparin Agents Versus Injectable or Oral Direct Thrombin Inhibitors

No randomized controlled trials or controlled observational studies evaluated the impact of injectable low molecular weight heparin prophylaxis versus injectable or oral direct thrombin inhibitor prophylaxis in patients who had major orthopedic surgery on this outcome.

###### Injectable Low Molecular Weight Heparin Agents Versus Oral Vitamin K Antagonists

Two randomized controlled trials evaluated the impact of injectable low molecular weight heparin prophylaxis versus oral vitamin K antagonist prophylaxis on reoperation in patients who had major orthopedic surgery.75,77 One trial was excluded from the analysis because no events occurred, leaving the trial by Francis and colleagues in 1997.^77^ This trial evaluated patients who had total hip replacement surgery. In patients who received injectable low molecular weight heparin prophylaxis versus oral vitamin K antagonist prophylaxis, the risk of reoperation was not significantly different [RR 0.85 (0.59 to 1.22)]. Subgroup analyses were not possible because only one trial with events was available.

###### Injectable Low Molecular Weight Heparin Agents Versus Mechanical Prophylaxis

No randomized controlled trials or controlled observational studies evaluated the impact of injectable low molecular weight heparin prophylaxis versus mechanical prophylaxis in patients who had major orthopedic surgery on this outcome.

###### Injectable Unfractionated Heparin Versus Injectable or Oral Direct Thrombin Inhibitors

No randomized controlled trials or controlled observational studies evaluated the impact of injectable unfractionated heparin versus injectable or oral direct thrombin inhibitors in patients who had major orthopedic surgery on this outcome.

###### Injectable Unfractionated Heparin Versus Injectable or Oral Factor Xa Inhibitors

No randomized controlled trials or controlled observational studies evaluated the impact of injectable unfractionated heparin prophylaxis versus injectable or oral factor Xa inhibitor prophylaxis in patients who had major orthopedic surgery on this outcome.

###### Injectable Unfractionated Heparin Versus Mechanical Prophylaxis

No randomized controlled trials or controlled observational studies evaluated the impact of injectable unfractionated heparin versus mechanical prophylaxis in patients who had major orthopedic surgery on this outcome.

###### Oral Vitamin K Antagonists Versus Mechanical Prophylaxis

No randomized controlled trials or controlled observational studies evaluated the impact of oral vitamin K antagonist prophylaxis versus mechanical prophylaxis in patients who had major orthopedic surgery on this outcome.

#### Strength of Evidence and Applicability of the Body of Evidence

Key Question 5 compared between pharmacologic and mechanical device classes. Compared with injectable unfractionated heparin, there was a high strength of evidence that low molecular weight heparin decreased the risk of proximal deep vein thrombosis and the odds of major bleeding although did not impact the risk of distal deep vein thrombosis. There was moderate strength of evidence that low molecular weight heparin agents decreased the odds of pulmonary embolism, heparin induced thrombocytopenia and the risk of deep vein thrombosis, although did not impact the risk of mortality or minor bleeding. There was low strength of evidence that there was no difference in the risk of nonfatal pulmonary embolism, asymptomatic or symptomatic deep vein thrombosis, surgical site bleeding or readmission. Compared with factor Xa inhibitors, there was high strength of evidence that low molecular weight heparins increased the risk of distal deep vein thrombosis and moderate strength of evidence that low molecular weight heparins increased the risk of deep vein thrombosis and the odds of major bleeding. There was moderate strength of evidence that there was no difference in the odds of nonfatal pulmonary embolism, mortality, symptomatic deep vein thrombosis, or major bleeding leading to reoperation. There was low strength of evidence that there was no difference in the odds of symptomatic objectively confirmed venous thromboembolism or fatal pulmonary embolism and that there was an increased odds of proximal deep vein thrombosis and decreased odds of minor bleeding. All other outcomes were rated as insufficient evidence. Compared with vitamin K antagonists, there was high strength of evidence that low molecular weight heparins increased the odds of major bleeding and moderate strength of evidence they increased the odds of minor bleeding and low strength of evidence they increased the odds of surgical site bleeding. Strength of evidence was moderate that low molecular weight heparins decreased the risk of distal deep vein thrombosis and low that they decreased the risk of deep vein thrombosis compared with vitamin K antagonists. Strength of evidence was moderate that there was no difference in the odds of pulmonary embolism, mortality and symptomatic deep vein thrombosis and low that there was no difference in the risk of proximal deep vein thrombosis or the odds of symptomatic objectively confirmed venous thromboembolism or nonfatal pulmonary embolism. All other outcomes were rated as insufficient.

For both the comparisons of low molecular weight heparin with direct thrombin inhibitors and with mechanical prophylaxis, there were no significant differences between the two classes. Compared with injectable or oral direct thrombin inhibitors, there was high strength of evidence that there was no difference with the use of injectable low molecular weight heparin agents in the risk of bleeding leading to transfusion and there was moderate strength of evidence that there was no difference in the risk of major venous thromboembolism, pulmonary embolism, mortality, asymptomatic or symptomatic deep vein thrombosis, major bleeding, major bleeding leading to reoperation or minor bleeding. The strength of evidence was low that there was no difference in the odds of fatal or nonfatal pulmonary embolism or the risk of proximal deep vein thrombosis. Other outcomes were rated as insufficient. For the comparison of injectable low molecular weight heparin to mechanical prophylaxis, few studies were available and most outcomes were rated as insufficient. There was moderate strength of evidence that there was no significant difference in the risk of deep vein thrombosis, proximal or distal deep vein thrombosis and there was low strength of evidence that there was no difference in the odds of mortality and readmission.

For other class comparisons, there were relatively less data and more outcomes were rated with insufficient evidence. Compared with oral or injectable direct thrombin inhibitors, there was moderate strength of evidence that injectable unfractionated heparin increased the risk of deep vein thrombosis and the odds of proximal deep vein thrombosis while there was low strength of evidence that there was no difference in the risk of pulmonary embolism, fatal pulmonary embolism, mortality, or major bleeding leading to reoperation. Compared with mechanical prophylaxis, there was moderate strength of evidence that oral vitamin K antagonists decreased the risk of proximal deep vein thrombosis with a low strength of evidence that there was no difference in the risk of deep vein thrombosis or minor bleeding. Compared with mechanical prophylaxis there was moderate strength of evidence that oral antiplatelet prophylaxis increased the risk of deep vein thrombosis. All other outcomes were rated as insufficient for this comparison. All outcomes were rated as insufficient for the following comparisons: oral antiplatelet versus oral vitamin K antagonists, injectable unfractionated heparin versus factor Xa inhibitors, and injectable unfractionated heparin versus mechanical prophylaxis.

Overall applicability was often limited because one or two of the major orthopedic surgeries were not evaluated, duration of followup was inadequate to evaluate the given outcome, and many trials were conducted outside of the United States and sometimes represented a majority of the available data.

## Key Question 6

In patients undergoing major orthopedic surgery (total hip and knee replacement, hip fracture surgery), what is the comparative efficacy of individual agents within classes (injectable low molecular weight heparin or mechanical) on symptomatic objectively confirmed venous thromboembolism, major venous thromboembolism (proximal deep vein thrombosis, pulmonary embolism or venous thromboembolism related mortality), pulmonary embolism, fatal pulmonary embolism, nonfatal pulmonary embolism, post thrombotic syndrome, mortality, mortality due to bleeding, deep vein thrombosis (asymptomatic or symptomatic, proximal or distal deep vein thrombosis), asymptomatic deep vein thrombosis, symptomatic deep vein thrombosis, proximal deep thrombosis, distal deep vein thrombosis, major bleeding, major bleeding leading to reoperation, minor bleeding, surgical site bleeding, bleeding leading to infection, bleeding leading to transfusion, heparin induced thrombocytopenia, discomfort, readmission, and reoperation?

### Key Points

- The literature base for intraclass comparisons of therapy is not as extensive as the interclass comparisons in Key Question 5 and therefore for most outcomes was insufficient to determine comparative efficacy and safety.
- Venous thromboembolism (symptomatic, major), postthrombotic syndrome, health related quality of life, major bleeding leading to reoperation, bleeding leading to infection, bleeding leading to transfusion, discomfort, reoperation, or readmission outcomes could not be evaluated due to lack of trials or studies evaluating these endpoints.
- For pulmonary embolism, the single trial comparing low molecular weight heparins and two of the three trials comparing mechanical prophylaxis had no events in either group. In the one trial with events, no significant differences were found between the Venaflow and Kendall devices, although the confidence intervals were very large.
- For fatal pulmonary embolism, one of two trials comparing low molecular weight heparins and all three trials comparing mechanical prophylaxis had no events in either group. In the one trial with events, no significant differences were found between enoxaparin and tinzaparin although the confidence intervals were very large.
  ○ One observational trial comparing mechanical prophylactic devices also did not have any fatal pulmonary embolism events.
- For nonfatal pulmonary embolism, one of two trials comparing low molecular weight heparins and two of three trials comparing mechanical prophylaxis had no events in either group. In the one low molecular weight heparin trial with events, no significant differences were found between enoxaparin and tinzaparin although the confidence intervals were very large. In the one mechanical prophylaxis trial, no significant differences were found between the Venaflow and Kendall devices, although the confidence intervals were very large.
  ○ One observational study comparing the ActiveCare system versus the Flowtron pump mechanical devices found no significant differences between groups in the occurrence of nonfatal pulmonary embolism. Very low rates occurred in both groups (0 percent versus 0.7 percent, p=0.459).
- One trial found no difference in mortality between enoxaparin and tinzaparin while another trial found no difference between the Venaflow and Kendall devices. The confidence intervals for these evaluations were very large.
  ○ No events occurred in an observational study comparing mechanical prophylaxis devices.
- For mortality due to bleeding, one trial comparing low molecular weight heparins and one trial and one observational study evaluated the impact of mechanical prophylaxis strategies. No events occurred in either group in these evaluations.
- More data are available regarding the comparison of drugs within a class on the occurrence of deep venous thrombosis, proximal deep venous thrombosis, and distal deep venous thrombosis.
  ○ No difference in the occurrence of deep venous thrombosis occurred in the pooled analysis comparing enoxaparin versus either tinzaparin or dalteparin.
  ○ The Venaflow pneumatic compression device significantly reduced the occurrence of deep venous thrombosis versus the Kendall pneumatic compression device in the only trial.
    – The same results were found when trials were limited to the years 2001-present and to total knee replacement surgery.
  ○ Intermittent compression stockings significantly reduce the occurrence of deep venous thrombosis versus graduated compression stockings in the only trial.
    – The same results were found when trials were limited to the years 2001-present and to total hip replacement and total knee replacement surgery.
  ○ In the only observational study, two intermittent compression devices were compared (ActiveCare system versus Flowtron excel pump) and found to have a similar occurrence of deep venous thrombosis.
- For asymptomatic deep venous thrombosis, one trial compared low molecular weight heparins and found no significant differences between enoxaparin and dalteparin but no trials or observational studies compared mechanical devices.
- For symptomatic deep venous thrombosis, one trial compared low molecular weight heparins and found no significant differences between enoxaparin and tinzaparin but neither of the two trials comparing mechanical devices had events in either group.
- For proximal deep venous thrombosis, two trials compared low molecular weight heparins and found no significant difference between enoxaparin and either dalteparin or tinzaparin. In one trial comparing two different intermittent compression devices (Venoflow versus Kendall), no significant difference in the occurrence of proximal deep venous thrombosis occurred. Neither of the two trials comparing intermittent compressions stockings versus graduated compression stocking found a significant difference in the occurrence of proximal deep venous thrombosis.
- For distal deep venous thrombosis, one trial compared low molecular weight heparins and found no significant differences between enoxaparin and tinzaparin. In one trial, the occurrence of distal deep venous thrombosis was significantly lower with the Venaflow intermittent compression device than with the Kendall intermittent compression device. In a trial, the occurrence of distal deep venous thrombosis was lower with intermittent compression stockings versus graduated compression stockings. Both of the mechanical intervention trials were conducted from 2001-present and included patients with total hip and total knee replacement surgery.
- For major bleeding, two trials compared low molecular weight heparins and found no differences between enoxaparin and either dalteparin or tinzaparin. No trials or studies evaluated the impact of mechanical interventions on this endpoint.
- For minor bleeding, one trial found no significant difference between enoxaparin and tinzaparin for this outcome. No trials or studies evaluated mechanical interventions on this endpoint.
- For surgical site bleeding, two trials compared low molecular weight heparins and found no differences between enoxaparin and either dalteparin or tinzaparin. No trials or studies evaluated the impact of mechanical interventions on this endpoint.
- For heparin induced thrombocytopenia, one trial found no significant difference between enoxaparin and tinzaparin for this outcome. No trials or studies evaluated mechanical interventions on this endpoint.

### Detailed Analysis

#### Study Design and Characteristics

Five randomized controlled trials (N=1,285) and one controlled observational study (N=1,577) evaluated the comparative efficacy within the classes of injectable low molecular weight heparin agents and mechanical devices.27,108,110,113,141,149 All five trials were published as full text manuscripts. Two trials compared injectable low molecular weight heparin agents (N= 631),27,108 two trials compared mechanical prophylaxes (N=523)110,141 and one trial compared mechanical prophylaxes with all patients receiving enoxaparin prophylaxis also (N=131).113 The observational study compared mechanical prophylaxes (N=1,577).149 Two trials enrolled patients who had total hip replacement surgery (N= 599),27,112 one trial enrolled patients who had total knee replacement surgery (N= 423),110 one trial enrolled patients who had hip fracture surgery (N=132),108 and one trial enrolled patients who had either total hip replacement or total knee replacement surgery (N=131).113 The observational study also enrolled patients who had total hip replacement or total knee replacement surgery (N=1,577).149 The earliest study was published in 1998^141^ and the most recent study was published in 2009.^149^ The duration of followup ranged from postoperative period to 180 days. Four trials received funding from the industry,27,110,113,141 one trial received funding from government and foundation108 and the observational study was unfunded.149

The mean age of enrolled patients ranged from 63.0 years to 77 years. Females represented between 55.24 and 78.79 percent of the enrolled populations. The mean weight ranged from 71.0 to 87.7 kilograms. Few patients enrolled had a history of venous thromboembolism ranging from 3.1 to 9.0 percent. One study reported presence of varicosity ranging from 61.9 to 66.18 percent. The percent of patients with a history of malignancy ranged from 3.1 to 6.1 percent.

Seventy-seven to 100 percent of patients underwent primary surgery and one trial reported the percent of patients who had cemented fixation during surgery ranging from 42.65 to 46.03 percent. Mean duration of surgery ranged from 69.0 to 93.0 minutes and the mean duration of anesthesia ranged from 133 to 161 minutes. Use of general anesthesia ranged from 11.98 to 27.94 percent and use of regional anesthesia ranged from 72.0 to 100.0 percent of patients. The mean length of hospital stay was reported by the observational study ranging from 4.2 to 5 days.

#### Outcome Evaluations

A summary of the results is presented in Table 13.

Table 13 Summary of results of Key Question 6: what is the comparative efficacy and safety within class of low-molecular weight heparin agents and mechanical prophylaxis methods in major orthopedic surgery?^*^

| Endpoint/Comparison | Type and Number of Studies | Pooled | Result | Statistical Heterogeneity I^2^ (%)
Symptomatic objectively confirmed VTE | Enoxaparin versus LMWH | 0 | --- | --- | ---
Symptomatic objectively confirmed VTE | IPC versus IPC | 0 | --- | --- | ---
Symptomatic objectively confirmed VTE | IPC versus GCS | 0 | --- | --- | ---
Major VTE | Enoxaparin versus other LMWH | 0 | --- | --- | ---
Major VTE | IPC versus IPC | 0 | --- | --- | ---
Major VTE | IPC versus GCS | 0 | --- | --- | ---
PE | Enoxaparin versus other LMWH | 1 RCT | No | No events occurred in the groups compared | NA
PE | IPC versus IPC | 1 RCT | No | OR 0.14 (0.003 to 7.18) | NA
PE | IPC versus GCS | 2 RCTs | No | No events occurred in the groups compared | NA
PE | - Limited to 2001-present | 1 RCT | No | No events occurred in the groups compared | NA
PE | - Limited to THR | 2 RCTs | No | No events occurred in the groups compared | NA
PE | - Limited to TKR | 1 RCT | No | No events occurred in the groups compared | NA
Fatal PE | Enoxaparin versus other LMWH | 2 RCTs | No | One trial had no events; remaining one trial showed OR 7.48 (0.15 to 376.94) | NA
Fatal PE | - Limited to THR | 1 RCT | No | OR 7.48 (0.15 to 376.94) | NA
Fatal PE | - Limited to HFS | 1 RCT | No | No events occurred in the groups compared | NA
Fatal PE | IPC versus IPC | 1 RCT, 1 OBS | No | No events occurred in the groups compared | NA
Fatal PE | IPC versus GCS | 2 RCTs | No | No events occurred in the groups compared | NA
Fatal PE | - Limited to 2001-present | 1 RCT | No | No events occurred in the groups compared | NA
Fatal PE | - Limited to THR | 1 RCT | No | No events occurred in the groups compared | NA
Fatal PE | - Limited to TKR | 1 RCT | No | No events occurred in the groups compared | NA
Nonfatal PE | Enoxaparin versus other LMWH | 2 RCTs | No | One trial had no events; remaining one trial showed OR 1.01 (0.06 to 16.23) | NA
Nonfatal PE | - Limited to THR | 1 RCT | No | OR 1.01 (0.06 to 16.23) | NA
Nonfatal PE | - Limited to HFS | 1 RCT | No | No events occurred in the groups compared | NA
Nonfatal PE | IPC versus IPC | 1 RCT, 1 OBS | No | OR 0.14 (0.003 to 7.18); observational data suggest no significant difference in the percent of patients that developed a nonfatal PE in the ActiveCare group versus the Flowtron group | NA
Nonfatal PE | IPC versus GCS | 2 RCTs | No | No events occurred in the groups compared | NA
Nonfatal PE | - Limited to 2001-present | 1 RCT | No | No events occurred in the groups compared | NA
Nonfatal PE | - Limited to THR | 2 RCTs | No | No events occurred in the groups compared | NA
Nonfatal PE | - Limited to TKR | 1 RCT | No | No events occurred in the groups compared | NA
PTS | Enoxaparin versus other LMWH | 0 | --- | --- | ---
PTS | IPC versus IPC | 0 | --- | --- | ---
PTS | IPC versus GCS | 0 | --- | --- | ---
Mortality | Enoxaparin versus other LMWH | 1 RCT | No | OR 7.48 (0.15 to 376.94) | NA
Mortality | IPC versus IPC | 1 RCT, 1 OBS | No | OR 0.14 (0.003 to 7.18); In the observational study, no events occurred in the groups compared | NA
Mortality | IPC versus GCS | 0 | --- | --- | ---
Mortality due to bleeding | Enoxaparin versus other LMWH | 1 RCT | No | No events occurred in the groups compared | NA
Mortality due to bleeding | IPC versus IPC | 1 RCT, 1 OBS | No | No events occurred in the groups compared | NA
Mortality due to bleeding | IPC versus GCS | 0 | --- | --- | ---
HRQOL | Enoxaparin versus other LMWH | 0 | --- | --- | ---
HRQOL | IPC versus IPC | 0 | --- | --- | ---
HRQOL | IPC versus GCS | 0 | --- | --- | ---
DVT | Enoxaparin versus other LMWH | 2 RCTs | Yes | RR 1.05 (0.64 to 1.71) | NA
DVT | - Limited to THR | 1 RCT | No | RR 1.75 (0.64 to 4.84) | NA
DVT | - Limited to HFS | 1 RCT | No | RR 0.93 (0.64 to 1.33) | NA
DVT | IPC versus IPC | 1 RCT, 1 OBS | No | 1 trial evaluated this outcome in total knees operated and showed RR 0.46 (0.26 to 0.79); observational data suggest no significant difference in the risk of DVT in patients who received ActiveCare device versus Flowtron | NA
DVT | IPC versus GCS | 1 RCT (2 comp) | Yes | RR 0.06 (0.01 to 0.42) | NA
DVT | - Limited to 2001-present | 1 RCT (2 comp) | Yes | RR 0.06 (0.01 to 0.42) | NA
DVT | - Limited to THR | 1 RCT (1 comp) | No | RR 0.09 (0.01 to 0.92) | NA
DVT | - Limited to TKR | 1 RCT (1 comp) | No | RR 0.03 (0.004 to 0.31) | NA
DVT | - Limited to HFS | 0 | --- | --- | ---
Asymptomatic DVT | Enoxaparin versus other LMWH | 1 RCT | No | RR 1.75 (0.64 to 4.84) | NA
Asymptomatic DVT | IPC versus IPC | 0 | --- | --- | ---
Asymptomatic DVT | IPC versus GCS | 0 | --- | --- | ---
Symptomatic DVT | Enoxaparin versus other LMWH | 2 RCTs | No | 1 trial had no events; remaining trial showed OR 1.51 (0.26 to 8.79) | NA
Symptomatic DVT | - Limited to THR | 1 RCT | No | OR 1.51 (0.26 to 8.79) | NA
Symptomatic DVT | - Limited to HFS | 1 RCT | No | No events occurred in the groups compared | NA
Symptomatic DVT | IPC versus IPC | 0 | --- | --- | ---
Symptomatic DVT | IPC versus GCS | 1 RCT | No | No events occurred in the groups compared | NA
Proximal DVT | Enoxaparin versus other LMWH | 2 RCTs | Yes | RR 1.06 (0.62 to 1.81) | NA
Proximal DVT | - Limited to THR | 1 RCT | No | OR 0.73 (0.12 to 4.34) | NA
Proximal DVT | - Limited to HFS | 1 RCT | No | OR 1.12 (0.60 to 2.08) | NA
Proximal DVT | IPC versus IPC | 1 RCT | No | 1 trial evaluated this outcome in total knees operated and showed OR 0.24 (0.05 to 1.08) | NA
Proximal DVT | IPC versus GCS | 2 RCTs | No | 1 trial showed RR 0.36 (0.13 to 1.00) while the second trial which compared enoxaparin plus IPC versus enoxaparin plus GCS showed OR 0.12 (0.01 to 1.99)
Proximal DVT | - Limited to 2001-present | 1 RCT (2 comp) | Yes | OR 0.12 (0.01 to 1.99) | NA
Proximal DVT | - Limited to THR | 2 RCTs | No | 1 trial showed RR 0.36 (0.13 to 1.00) while the second trial which compared enoxaparin plus IPC versus enoxaparin plus GCS showed OR 0.11 (0.002 to 5.78) | NA
Proximal DVT | - Limited to TKR | 1 RCT | No | OR 0.14 (0.003 to 6.82) | NA
Distal DVT | Enoxaparin versus other LMWH | 1 RCT | No | RR 0.78 (0.46 to 1.34) | NA
Distal DVT | IPC versus IPC | 1 RCT | No | 1 trial evaluated this outcome in total knees operated and showed RR 0.52 (0.29 to 0.93) | NA
Distal DVT | IPC versus GCS | 1 RCT (2 comp) | Yes | RR 0.07 (0.01 to 0.54) | NA
Distal DVT | - Limited to 2001-present | 1 RCT (2 comp) | Yes | RR 0.07 (0.01 to 0.54) | NA
Distal DVT | - Limited to THR | 1 RCT (1 comp) | No | RR 0.15 (0.01 to 1.53) | NA
Distal DVT | - Limited to TKR | 1 RCT (1 comp) | No | RR 0.04 (0.004 to 0.33) | NA
Major bleeding | Enoxaparin versus other LMWH | 2 RCT | Yes | RR 1.98 (0.53 to 7.37) | NA
Major bleeding | - Limited to THR | 1 RCT | No | OR 1.97 (0.20 to 19.25) | NA
Major bleeding | - Limited to HFS | 1 RCT | No | OR 1.98 (0.40 to 9.91) | NA
Major bleeding | IPC versus IPC | 0 | --- | --- | ---
Major bleeding | IPC versus GCS | 0 | --- | --- | ---
Major bleeding leading to reoperation | Enoxaparin versus other LMWH | 0 | --- | --- | ---
Major bleeding leading to reoperation | IPC versus IPC | 0 | --- | --- | ---
Major bleeding leading to reoperation | IPC versus GCS | 0 | --- | --- | ---
Minor bleeding | Enoxaparin versus other LMWH | 1 RCT | No | OR 1.67 (0.84 to 3.36) | NA
Minor bleeding | IPC versus IPC | 0 | --- | --- | ---
Minor bleeding | IPC versus GCS | 0 | --- | --- | ---
Surgical site bleeding | Enoxaparin versus other LMWH | 2 RCT | Yes | RR 1.35 (0.30 to 5.97) | NA
Surgical site bleeding | - Limited to THR | 1 RCT | No | OR 0.14 (0.003 to 6.82) | NA
Surgical site bleeding | - Limited to HFS | 1 RCT | No | OR 1.98 (0.40 to 9.91) | NA
Surgical site bleeding | IPC versus IPC | 0 | --- | --- | ---
Surgical site bleeding | IPC versus GCS | 0 | --- | --- | ---
Bleeding leading to infection | Enoxaparin versus other LMWH | 0 | --- | --- | ---
Bleeding leading to infection | IPC versus IPC | 0 | --- | --- | ---
Bleeding leading to infection | IPC versus GCS | 0 | --- | --- | ---
Bleeding leading to transfusion | Enoxaparin versus other LMWH | 0 | --- | --- | ---
Bleeding leading to transfusion | IPC versus IPC | 0 | --- | --- | ---
Bleeding leading to transfusion | IPC versus GCS | 0 | --- | --- | ---
HIT | Enoxaparin versus other LMWH | 1 RCT | No | OR 7.48 (0.15 to 376.94) | NA
HIT | IPC versus IPC | 0 | --- | --- | ---
HIT | IPC versus GCS | 0 | --- | --- | ---
Discomfort | Enoxaparin versus other LMWH | 0 | --- | --- | ---
Discomfort | IPC versus IPC | 0 | --- | --- | ---
Discomfort | IPC versus GCS | 0 | --- | --- | ---
Readmission | Enoxaparin versus other LMWH | 0 | --- | --- | ---
Readmission | IPC versus IPC | 0 | --- | --- | ---
Readmission | IPC versus GCS | 0 | --- | --- | ---
Reoperation | Enoxaparin versus other LMWH | 0 | --- | --- | ---
Reoperation | IPC versus IPC | 0 | --- | --- | ---
Reoperation | IPC versus GCS | 0 | --- | --- | ---

comp = comparison(s); DVT = deep vein thrombosis; GCS = graduated compression stockings; HIT = heparin induced thrombocytopenia; HFS = hip fracture surgery; HRQOL = health related quality of life; IPC = intermittent pneumatic compression; LMWH = low molecular weight heparin; NA = Not Applicable; OBS = observational; OR = Peto's Odds Ratio; PE = pulmonary embolism; PTS = post thrombotic syndrome; RCT = Randomized Controlled Trial; RR = Relative Risk; THR = total hip replacement; TKR = total knee replacement; UFH = unfractionated heparin; VKA = vitamin K antagonist; VTE = venous thromboembolism

* All base case analyses are represented in this table. If only 1 trial was available subgroup analyses were not run. Only subgroup analyses with available data are represented in this table.

--- No data.

##### Symptomatic Objectively Confirmed Venous Thromboembolism

###### Low Molecular Weight Heparin Agents

No randomized controlled trials or controlled observational studies evaluated the comparative efficacy between individual low molecular weight heparin agents in patients who had major orthopedic surgery on this outcome.

###### Mechanical Prophylaxis

No randomized controlled trials or controlled observational studies evaluated the comparative efficacy between individual mechanical prophylaxis devices in patients who had major orthopedic surgery on this outcome.

##### Major Venous Thromboembolism

###### Low Molecular Weight Heparin Agents

No randomized controlled trials or controlled observational studies evaluated the comparative efficacy between individual low molecular weight heparin agents in patients who had major orthopedic surgery on this outcome.

###### Mechanical Prophylaxis

No randomized controlled trials or controlled observational studies evaluated the comparative efficacy between individual mechanical prophylaxis devices in patients who had major orthopedic surgery on this outcome.

##### Pulmonary Embolism

###### Low Molecular Weight Heparin Agents

One randomized controlled trial evaluated the comparative efficacy between enoxaparin and dalteparin on pulmonary embolism in patients who had hip fracture surgery although no events occurred therefore the risk of pulmonary embolism could not be calculated.108

###### Mechanical Prophylaxis

Three randomized controlled trials evaluated the comparative efficacy between individual mechanical prophylaxis devices on pulmonary embolism in patients who had major orthopedic surgery.110,113,141 Two trials that evaluated intermittent pneumatic compression versus graduated compression stockings did not have events occur in the groups compared therefore the risk of pulmonary embolism could not be evaluated.113,141 One trial by Lachiewicz and colleagues in 2004 compared the Venaflow intermittent pneumatic compression device to the intermittent pneumatic compression device by Kendall in patients who had total knee replacement surgery.110 In this trial, the odds of pulmonary embolism were not significantly different [OR 0.14 (0.003 to 7.18)] in patients who received the Venaflow device versus the Kendall device.

##### Fatal Pulmonary Embolism

###### Low Molecular Weight Heparin Agents

Two randomized controlled trials evaluated the comparative efficacy between individual low molecular weight heparin agents on fatal pulmonary embolism in patients who had major orthopedic surgery.27,108 One trial was excluded from the analysis because no events occurred.108 The remaining trial by Planes and colleagues in 1999 evaluated the comparative efficacy of enoxaparin to tinzaparin in patients who had total hip replacement surgery.27 In this trial, the odds of fatal pulmonary embolism were not significantly different [OR 7.48 (0.15 to 376.94)] in patients who received enoxaparin versus tinzaparin.

###### Mechanical Prophylaxis

Three randomized controlled trials evaluated the comparative efficacy between individual mechanical prophylaxis devices on pulmonary embolism in patients who had major orthopedic surgery although no events occurred in the groups compared therefore the risk of fatal pulmonary embolism could not be calculated.110,113,141

One controlled observational study evaluated the comparative efficacy between individual mechanical prophylaxis devices on fatal pulmonary embolism in patients who had major orthopedic surgery however no events occurred in the groups compared therefore the risk of fatal pulmonary embolism could not be calculated.149

##### Nonfatal Pulmonary Embolism

###### Low Molecular Weight Heparin Agents

Two randomized controlled trials evaluated the comparative efficacy between individual low molecular weight heparin agents on nonfatal pulmonary embolism in patients who had major orthopedic surgery.27,108 One trial was excluded from the analysis because no events occurred.108 The remaining trial by Planes and colleagues in 1999 evaluated the comparative efficacy of enoxaparin to tinzaparin in patients who had total hip replacement surgery.27 In this trial, the odds of nonfatal pulmonary embolism were not significantly different [OR 1.01 (0.06 to 16.23)] in patients who received enoxaparin versus tinzaparin.

###### Mechanical Prophylaxis

Three randomized controlled trials evaluated the comparative efficacy between individual mechanical prophylaxis devices on nonfatal pulmonary embolism in patients who had major orthopedic surgery.110,113,141 Two trials that evaluated intermittent pneumatic compression versus graduated compression stockings did not have events occur in the groups compared therefore the risk of pulmonary embolism could not be evaluated.113,141 One trial by Lachiewicz and colleagues in 2004 compared the Venaflow intermittent pneumatic compression device to the intermittent pneumatic compression device by Kendall in patients who had total knee replacement surgery.110 In this trial, in patients who received the Venaflow device versus the Kendall device, the odds of nonfatal pulmonary embolism were not significantly different [OR 0.14 (0.003 to 7.18)].

One controlled observational study evaluated comparative efficacy between individual mechanical prophylaxis devices on nonfatal pulmonary embolism in patients who had major orthopedic surgery.149 Two intermittent pneumatic compression devices were compared in patients who had either total hip or knee replacement surgery; ActiveCare continuous enhanced circulatory system versus Flowtron excel pump. Patients also received enoxaparin (30mg twice daily for knee and 40mg daily for hip surgery) starting 12-24 hours postoperatively at the discretion of the clinical team however the percent of patients that did receive enoxaparin in each group was not reported. There was no significant difference in the percent of patients that developed a nonfatal pulmonary embolism in the ActiveCare group versus the Flowtron group (0 percent versus 0.7 percent, p=0.459).

##### Postthrombotic Syndrome

###### Low Molecular Weight Heparin Agents

No randomized controlled trials or controlled observational studies evaluated the comparative efficacy between individual low molecular weight heparin agents in patients who had major orthopedic surgery on this outcome.

###### Mechanical Prophylaxis

No randomized controlled trials or controlled observational studies evaluated the comparative efficacy between individual mechanical prophylaxis devices in patients who had major orthopedic surgery on this outcome.

##### Mortality

###### Low Molecular Weight Heparin Agents

One randomized controlled trial evaluated the comparative efficacy between individual low molecular weight heparin agents on mortality in patients who had major orthopedic surgery.27 This trial by Planes and colleagues evaluated enoxaparin versus tinzaparin in patients who had total hip replacement surgery. In this trial, in patients who received enoxaparin versus tinzaparin the odds of mortality were not significantly different [OR 7.48 (0.15 to 376.94)].

###### Mechanical Prophylaxis

One randomized controlled trial evaluated the comparative efficacy between individual mechanical prophylaxis devices in patients who had major orthopedic surgery on this outcome.110 This trial by Lachiewicz and colleagues in 2004 compared the Venaflow intermittent pneumatic compression device to the intermittent pneumatic compression device by Kendall in patients who had total knee replacement surgery. In patients who received the Venaflow device versus the Kendall device, the odds of mortality were not significantly different [OR 0.14 (0.003 to 7.18)].

One controlled observational study evaluated the comparative efficacy between individual mechanical prophylaxis devices on mortality in patients who had major orthopedic surgery however no events occurred in the groups compared therefore the risk of mortality could not be calculated.149

##### Mortality Due to Bleeding

###### Low Molecular Weight Heparin Agents

One randomized controlled evaluated the comparative efficacy between individual low molecular weight heparin agents on mortality due to bleeding in patients who had major orthopedic surgery although no events occurred therefore the risk of mortality due to bleeding could not be calculated.27

###### Mechanical Prophylaxis

One randomized controlled trial evaluated the comparative efficacy between individual mechanical prophylaxis devices on mortality due to bleeding in patients who had major orthopedic surgery although no events occurred therefore the risk of mortality due to bleeding could not be calculated.110

One controlled observational study evaluated comparative efficacy between individual mechanical prophylaxis devices on mortality due to bleeding in patients who had major orthopedic surgery however no events occurred in the groups compared therefore the risk of mortality due to bleeding could not be calculated.149

##### Health-Related Quality of Life

###### Low Molecular Weight Heparin Agents

No randomized controlled trials or controlled observational studies evaluated the comparative efficacy between individual low molecular weight heparin agents in patients who had major orthopedic surgery on this outcome.

###### Mechanical Prophylaxis

No randomized controlled trials or controlled observational studies evaluated the comparative efficacy between individual mechanical prophylaxis devices in patients who had major orthopedic surgery on this outcome.

##### Deep Vein Thrombosis

###### Low Molecular Weight Heparin Agents

Two randomized controlled trials evaluated the comparative efficacy between individual low molecular weight heparin agents on deep vein thrombosis in patients who had major orthopedic surgery.27,108 The first trial by Planes and colleagues in 1999 compared enoxaparin versus dalteparin in patients who had hip fracture surgery. In this trial, in patients who received enoxaparin versus dalteparin, the risk of deep vein thrombosis was not significantly different [RR 0.93 (0.64 to 1.33)]. The second trial by the TIFDED study group compared enoxaparin versus tinzaparin in patients who had total hip replacement surgery. In this trial, in patients who received enoxaparin versus tinzaparin the risk of deep vein thrombosis was not significantly different [RR 1.75 (0.64 to 4.84)]. When pooling these two trials to evaluate the comparative efficacy on enoxaparin versus other low molecular weight heparin agents in patients who had major orthopedic surgery, the risk of deep vein thrombosis was not significantly different [RR 1.05 (0.64 to 1.71)] (Appendix G Figure 204). Statistical heterogeneity and publication bias could not be evaluated because of too few studies. Subgroup analysis based on trial published from 2001-present was not possible since both trial were published prior to 2001. Subgroup analyses based on age, gender or ethnicity were not possible because the trials did no report data based on these subgroups.

###### Mechanical Prophylaxis

Two randomized controlled trials evaluated the comparative efficacy between individual mechanical prophylaxis devices on deep vein thrombosis in patients who had major orthopedic surgery.110,113 The first trial by Lachiewicz and colleagues in 2004 compared two intermittent pneumatic compression devices to each other; the Venaflow intermittent pneumatic compression device and the intermittent pneumatic compression device by Kendall, in patients who had total knee replacement surgery. Outcomes were reported in terms of number of knees with deep vein thrombosis out of the total number of knees operated on. In the knees operated on in which patients received the Venaflow device versus the Kendall device for prophylaxis, the risk of deep vein thrombosis was significantly decreased [RR 0.46 (0.26 to 0.79), NNT 13].

The second trial by Silbersack and colleagues in 2004 compared enoxaparin plus intermittent pneumatic compression to enoxaparin plus graduated compression stockings in patients who had total hip or total knee replacement surgery, and outcomes were reported separately for each surgical population.113 In the patients who had total hip replacement surgery and received intermittent pneumatic compression versus graduated compression stockings; both in combination with enoxaparin, the risk of deep vein thrombosis was significantly decreased [RR 0.09 (0.01 to 0.92), NNT 7]. In the patients who had total knee replacement surgery and received intermittent pneumatic compression versus graduated compression stockings; both in combination with enoxaparin, the risk of deep vein thrombosis was significantly decreased [RR 0.03 (0.004 to 0.31), NNT 3]. When pooling these two surgical populations to compare intermittent pneumatic compression versus graduated compression stockings; both in combination with enoxaparin, in patients who had major orthopedic surgery, the risk of deep vein thrombosis was significantly decreased [RR 0.06 (0.01 to 0.42), NNT 3 to 7] (Appendix G Figure 205). Statistical heterogeneity and publication bias could not be evaluated because of too few studies. Subgroup analyses based on age, gender or ethnicity were not possible because the trials did no report data based on these subgroups.

One controlled observational study evaluated the comparative efficacy between individual mechanical prophylaxis devices on deep vein thrombosis in patients who had major orthopedic surgery.149 Two intermittent pneumatic compression devices were compared in patients who had either total hip or knee replacement surgery; ActiveCare continuous enhanced circulatory system versus Flowtron excel pump. Patients also received enoxaparin (30mg twice daily for knee and 40mg daily for hip surgery) starting 12-24 hours postoperatively at the discretion of the clinical team however the percent of patients that did receive enoxaparin in each group was not reported. In patients who received the ActiveCare device versus the Flowtron device, there was no significant difference in the risk of deep vein thrombosis (1.35 percent versus 3.62 percent, p=0.119).

##### Asymptomatic Deep Vein Thrombosis

###### Low Molecular Weight Heparin Agents

One randomized controlled trial evaluated the comparative efficacy between individual low molecular weight heparin agents on asymptomatic deep vein thrombosis in patients who had major orthopedic surgery.108 This trial by the TIFDED study group in 1999 compared enoxaparin to dalteparin in patients who had hip fracture surgery. In this trial, the risk of asymptomatic deep vein thrombosis was not significantly different [RR 1.75 (0.64 to 4.84)] in patients who received enoxaparin versus dalteparin.

###### Mechanical Prophylaxis

No randomized controlled trials or controlled observational studies evaluated the comparative efficacy between individual mechanical prophylaxis devices in patients who had major orthopedic surgery on this outcome.

##### Symptomatic Deep Vein Thrombosis

###### Low Molecular Weight Heparin Agents

Two randomized controlled trials evaluated the comparative efficacy between individual low molecular weight heparin agents on symptomatic deep vein thrombosis in patients who had major orthopedic surgery.27,108 One trial was excluded from the analysis because no events occurred.108 The remaining trial by Planes and colleagues in 1999 evaluated the comparative efficacy of enoxaparin to tinzaparin in patients who had total hip replacement surgery.27 In this trial, the odds of symptomatic deep vein thrombosis were not significantly different [OR 1.51 (0.26 to 8.79)] in patients who received enoxaparin versus tinzaparin.

###### Mechanical Prophylaxis

Two randomized controlled trials evaluated the comparative efficacy between individual mechanical prophylaxis devices on symptomatic deep vein thrombosis in patients who had major orthopedic surgery.110,141 One trial evaluated this outcome during the post discharge period.110 However, in both trials, no events occurred in the groups compared therefore the risk of symptomatic deep vein thrombosis could not be calculated.110,141

##### Proximal Deep Vein Thrombosis

###### Low Molecular Weight Heparin Agents

Two randomized controlled trials evaluated the comparative efficacy between individual low molecular weight heparin agents on proximal deep vein thrombosis in patients who had major orthopedic surgery.27,108 The first trial by Planes and colleagues in 1999 compared enoxaparin versus dalteparin in patients who had hip fracture surgery. In this trial, the odds of proximal deep vein thrombosis were not significantly different [OR 1.12 (0.60 to 2.08)] in patients who received enoxaparin versus dalteparin. The second trial by the TIFDED study group compared enoxaparin versus tinzaparin in patients who had total hip replacement surgery. In this trial, the odds of proximal deep vein thrombosis were not significantly different [OR 0.73 (0.12 to 4.34)] in patients who received enoxaparin versus tinzaparin. When pooling these two trials to evaluate the comparative efficacy on enoxaparin versus other low molecular weight heparin agents in patients who had major orthopedic surgery, the risk of proximal deep vein thrombosis was not significantly different [RR 1.06 (0.62 to 1.81)] (Appendix G Figure 206). Statistical heterogeneity and publication bias could not be evaluated because of too few studies. Subgroup analysis based on trial published from 2001-present was not possible since both trial were published prior to 2001. Subgroup analyses based on age, gender or ethnicity were not possible because the trials did no report data based on these subgroups.

###### Mechanical Prophylaxis

Three randomized controlled trials evaluated the comparative efficacy between individual mechanical prophylaxis devices on proximal deep vein thrombosis in patients who had major orthopedic surgery.110,113,141 The first trial by Lachiewicz and colleagues in 2004 compared two intermittent pneumatic compression devices to each other; the Venaflow intermittent pneumatic compression device and the intermittent pneumatic compression device by Kendall, in patients who had total knee replacement surgery. Outcomes were reported in terms of number of knees with deep vein thrombosis out of the total number of knees operated on. In the knees operated on, in which patients received the Venaflow device versus the Kendall device for prophylaxis, the odds of proximal deep vein thrombosis were not significantly different [OR 0.24 (0.05 to 1.08)].

The second trial by Ryan and colleagues in 1998 compared intermittent pneumatic compression versus graduated compression stockings in patients who had total hip replacement surgery. 141 In this trial, in patients who received intermittent pneumatic compression versus graduated compression stockings the risk of proximal deep vein thrombosis was not significantly different [RR 0.36 (0.13 to 1.00)].

The third trial by Silbersack and colleagues in 2004 compared enoxaparin plus intermittent pneumatic compression to enoxaparin plus graduated compression stockings in patients who had total hip or total knee replacement surgery, and outcomes were reported separately for each surgical population.113 In the patients who had total hip replacement surgery and received intermittent pneumatic compression versus graduated compression stockings; both in combination with enoxaparin, the odds of proximal deep vein thrombosis were not significantly different [OR 0.11 (0.002 to 5.78)]. In the patients who had total knee replacement surgery and received intermittent pneumatic compression versus graduated compression stockings; both in combination with enoxaparin, the odds of proximal deep vein thrombosis were not significantly different [OR 0.14 (0.003 to 6.82)]. When pooling these two surgical populations to evaluate the comparison of intermittent pneumatic compression versus graduated compression stockings; both in combination with enoxaparin, in patients who had major orthopedic surgery, the odds of proximal deep vein thrombosis were not significantly different [OR 0.12 (0.01 to 1.99)] (Appendix G Figure 207). Statistical heterogeneity and publication bias could not be evaluated because of too few studies. Subgroup analyses based on age, gender or ethnicity were not possible because the trials did no report data based on these subgroups.

##### Distal Deep Vein Thrombosis

###### Low Molecular Weight Heparin Agents

One randomized controlled trial evaluated the comparative efficacy between individual low molecular weight heparin agents on distal deep vein thrombosis in patients who had major orthopedic surgery.27 This trial by Planes and colleagues evaluated enoxaparin versus tinzaparin in patients who had total hip replacement surgery. In this trial, in patients who received enoxaparin versus tinzaparin the risk of distal deep vein thrombosis was not significantly different [RR 0.78 (0.46 to 1.34)].

###### Mechanical Prophylaxis

Two randomized controlled trials evaluated the comparative efficacy between individual mechanical prophylaxis devices on distal deep vein thrombosis in patients who had major orthopedic surgery.110,113 The first trial by Lachiewicz and colleagues in 2004 compared two intermittent pneumatic compression devices to each other; the Venaflow intermittent pneumatic compression device and the intermittent pneumatic compression device by Kendall, in patients who had total knee replacement surgery. Outcomes were reported in terms of number of knees with deep vein thrombosis out of the total number of knees operated on. In the knees operated on in which patients received the Venaflow device versus the Kendall device for prophylaxis, the risk of distal deep vein thrombosis was significantly decreased [RR 0.52 (0.29 to 0.93), NNT 35].

The second trial by Silbersack and colleagues in 2004 compared enoxaparin plus intermittent pneumatic compression to enoxaparin plus graduated compression stockings in patients who had total hip or total knee replacement surgery, and outcomes were reported separately for each surgical population.113 In the patients who had total hip replacement surgery and received intermittent pneumatic compression versus graduated compression stockings; both in combination with enoxaparin, the risk of distal deep vein thrombosis was not significantly different [RR 0.15 (0.01 to 1.53)]. In the patients who had total knee replacement surgery and received intermittent pneumatic compression versus graduated compression stockings; both in combination with enoxaparin, the risk of distal deep vein thrombosis was significantly decreased [RR 0.04 (0.004 to 0.33), NNT 3]. When pooling these two surgical populations to compare intermittent pneumatic compression versus graduated compression stockings, both in combination with enoxaparin in patients who had major orthopedic surgery, the risk of distal deep vein thrombosis was significantly decreased [RR 0.07 (0.01 to 0.54), NNT 3 to 11] (Appendix G Figure 208). Statistical heterogeneity and publication bias could not be evaluated because of too few studies. Subgroup analyses based on age, gender or ethnicity were not possible because the trials did no report data based on these subgroups.

##### Major Bleeding

###### Low Molecular Weight Heparin Agents

Two randomized controlled trials evaluated the comparative efficacy between individual low molecular weight heparin agents on major bleeding in patients who had major orthopedic surgery.27,108 The first trial by Planes and colleagues in 1999 compared enoxaparin versus dalteparin in patients who had hip fracture surgery. In this trial, in patients who received enoxaparin versus dalteparin, the odds of major bleeding were not significantly different [OR 1.98 (0.40 to 9.91)]. The second trial by the TIFDED study group compared enoxaparin versus tinzaparin in patients who had total hip replacement surgery. In this trial, in patients who received enoxaparin versus tinzaparin the odds of major bleeding were not significantly different [OR 1.97 (0.20 to 19.25)]. When pooling these two trials to evaluate the comparative efficacy on enoxaparin versus other low molecular weight heparin agents in patients who had major orthopedic surgery, the odds of major bleeding were not significantly different [RR 1.98 (0.53 to 7.37)] (Appendix G Figure 210). Statistical heterogeneity and publication bias could not be evaluated because of too few studies. Subgroup analysis based on trial published from 2001-present was not possible since both trial were published prior to 2001. Subgroup analyses based on age, gender or ethnicity were not possible because the trials did no report data based on these subgroups.

###### Mechanical Prophylaxis

No randomized controlled trials or controlled observational studies evaluated the comparative efficacy between individual mechanical prophylaxis devices in patients who had major orthopedic surgery on this outcome.

##### Major Bleeding Leading to Reoperation

###### Low Molecular Weight Heparin Agents

No randomized controlled trials or controlled observational studies evaluated the comparative efficacy between individual low molecular weight heparin agents in patients who had major orthopedic surgery on this outcome.

###### Mechanical Prophylaxis

No randomized controlled trials or controlled observational studies evaluated the comparative efficacy between individual mechanical prophylaxis devices in patients who had major orthopedic surgery on this outcome.

##### Minor Bleeding

###### Low Molecular Weight Heparin Agents

One randomized controlled trial evaluated the comparative efficacy between individual low molecular weight heparin agents on minor bleeding in patients who had major orthopedic surgery.27 This trial by Planes and colleagues evaluated enoxaparin versus tinzaparin in patients who had total hip replacement surgery. In this trial, in patients who received enoxaparin versus tinzaparin the odds of minor bleeding were not significantly different [OR 1.67 (0.84 to 3.36)].

###### Mechanical Prophylaxis

No randomized controlled trials or controlled observational studies evaluated the comparative efficacy between individual mechanical prophylaxis devices in patients who had major orthopedic surgery on this outcome.

##### Surgical Site Bleeding

###### Low Molecular Weight Heparin Agents

Two randomized controlled trials evaluated the comparative efficacy between individual low molecular weight heparin agents on surgical site bleeding in patients who had major orthopedic surgery.27,108 The first trial by Planes and colleagues in 1999 compared enoxaparin versus dalteparin in patients who had hip fracture surgery. In this trial, in patients who received enoxaparin versus dalteparin, the odds of surgical site bleeding were not significantly different [OR 1.98 (0.40 to 9.91)]. The second trial by the TIFDED study group compared enoxaparin versus tinzaparin in patients who had total hip replacement surgery. In this trial, in patients who received enoxaparin versus tinzaparin the odds of surgical site bleeding were not significantly different [OR 0.14 (0.003 to 6.82)]. When pooling these two trials to evaluate the comparative efficacy on enoxaparin versus other low molecular weight heparin agents in patients who had major orthopedic surgery, the odds of surgical site bleeding were not significantly different [RR 1.35 (0.30 to 5.97)] (Appendix G Figure 211). Statistical heterogeneity and publication bias could not be evaluated because of too few studies. Subgroup analysis based on trial published from 2001-present was not possible since both trial were published prior to 2001. Subgroup analyses based on age, gender or ethnicity were not possible because the trials did not report data based on these subgroups.

###### Mechanical Prophylaxis

No randomized controlled trials or controlled observational studies evaluated the comparative efficacy between individual mechanical prophylaxis devices in patients who had major orthopedic surgery on this outcome.

##### Bleeding Leading to Infection

###### Low Molecular Weight Heparin Agents

No randomized controlled trials or controlled observational studies evaluated the comparative efficacy between individual low molecular weight heparin agents in patients who had major orthopedic surgery on this outcome.

###### Mechanical Prophylaxis

No randomized controlled trials or controlled observational studies evaluated the comparative efficacy between individual mechanical prophylaxis devices in patients who had major orthopedic surgery on this outcome.

##### Bleeding Leading to Transfusion

###### Low Molecular Weight Heparin Agents

No randomized controlled trials or controlled observational studies evaluated the comparative efficacy between individual low molecular weight heparin agents in patients who had major orthopedic surgery on this outcome.

###### Mechanical Prophylaxis

No randomized controlled trials or controlled observational studies evaluated the comparative efficacy between individual mechanical prophylaxis devices in patients who had major orthopedic surgery on this outcome.

##### Heparin-Induced Thrombocytopenia

###### Low Molecular Weight Heparin Agents

One randomized controlled trial evaluated the comparative efficacy between individual low molecular weight heparin agents on heparin induced thrombocytopenia in patients who had major orthopedic surgery.27 This trial by Planes and colleagues evaluated enoxaparin versus tinzaparin in patients who had total hip replacement surgery. In this trial, in patients who received enoxaparin versus tinzaparin the odds of heparin induced thrombocytopenia were not significantly different [OR 7.48 (0.15 to 376.94)].

###### Mechanical Prophylaxis

No randomized controlled trials or controlled observational studies evaluated the comparative efficacy between individual mechanical prophylaxis devices in patients who had major orthopedic surgery on this outcome.

##### Discomfort

###### Low Molecular Weight Heparin Agents

No randomized controlled trials or controlled observational studies evaluated the comparative efficacy between individual low molecular weight heparin agents in patients who had major orthopedic surgery on this outcome.

###### Mechanical Prophylaxis

No randomized controlled trials or controlled observational studies evaluated the comparative efficacy between individual mechanical prophylaxis devices in patients who had major orthopedic surgery on this outcome.

##### Readmission

###### Low Molecular Weight Heparin Agents

No randomized controlled trials or controlled observational studies evaluated the comparative efficacy between individual low molecular weight heparin agents in patients who had major orthopedic surgery on this outcome.

###### Mechanical Prophylaxis

No randomized controlled trials or controlled observational studies evaluated the comparative efficacy between individual mechanical prophylaxis devices in patients who had major orthopedic surgery on this outcome.

##### Reoperation

###### Low Molecular Weight Heparin Agents

No randomized controlled trials or controlled observational studies evaluated the comparative efficacy between individual low molecular weight heparin agents in patients who had major orthopedic surgery on this outcome.

###### Mechanical Prophylaxis

No randomized controlled trials or controlled observational studies evaluated the comparative efficacy between individual mechanical prophylaxis devices in patients who had major orthopedic surgery on this outcome.

#### Strength of Evidence and Applicability of the Body of Evidence

Key Question 6 compared agents within the low molecular weight heparin class as well as within mechanical devices. Overall there were very few comparative studies and those evaluated had very low event rates. Therefore the majority of outcomes were rated with insufficient strength of evidence. There was insufficient evidence for all outcomes when comparing specific mechanical devices, as although two studies compared specific mechanical devices, they each compared different devices. When compared with graduated compression devices, intermittent pneumatic compression devices decreased the risk of overall and distal deep vein thrombosis, while there was no difference in the risk of proximal deep vein thrombosis, each with a low strength of evidence. When comparing enoxaparin to other low molecular weight heparins (dalteparin or tinzaparin), there was no difference in the risk of overall or proximal deep vein thrombosis, or in the odds of surgical site bleeding, all with low strength of evidence. When comparing enoxaparin to other low molecular weight heparins (dalteparin or tinzaparin), there was moderate strength of evidence that there as no difference in the risk of major bleeding, while all other outcomes were rated insufficient.

Overall applicability was often limited because one or two of the major orthopedic surgeries were not evaluated, duration of followup was inadequate to evaluate the given outcome, and many trials were conducted outside of the United States and sometimes represented a majority of the available data. The specificity of the comparisons within the given studies applicability was rated low for the great majority of outcomes and comparisons. Data were often highly applicable to a specific device comparison within one or two of the major orthopedic surgeries. Hip fracture surgery was general not evaluated. In comparison of low molecular weight heparins, the majority of trials were conducted outside of the United States and for a given outcome, usually either tinzaparin or dalteparin were compared with enoxaparin (not both) in one major orthopedic surgery.

## Key Question 7

In patients undergoing major orthopedic surgery (total hip or knee replacement, hip fracture surgery), what are the effect estimates of combined pharmacologic and mechanical modalities vs. single modality on symptomatic objectively confirmed venous thromboembolism, major venous thromboembolism (proximal deep vein thrombosis, pulmonary embolism or venous thromboembolism related mortality), pulmonary embolism, fatal pulmonary embolism, nonfatal pulmonary embolism, post thrombotic syndrome, mortality, mortality due to bleeding, deep vein thrombosis (asymptomatic or symptomatic, proximal or distal deep vein thrombosis), asymptomatic deep vein thrombosis, symptomatic deep vein thrombosis, proximal deep thrombosis, distal deep vein thrombosis, major bleeding, major bleeding leading to reoperation, minor bleeding, surgical site bleeding, bleeding leading to infection, bleeding leading to transfusion, heparin induced thrombocytopenia, discomfort, readmission, and reoperation?

### Key Points

- There was insufficient evidence for all outcomes when comparing two prophylactic strategies (pharmacologic plus mechanical) mechanical prophylaxis with the exception of proximal deep vein thrombosis. There was low strength of evidence that the combination has no signficant impact on proximal deep vein thrombosis compared to mechanical prpophyalxia alone [RR0.78 (0.35 to 1.74)].
- There is moderate evidence that the use of pharmacologic plus mechanical prophylaxis significantly decreases the occurrence of deep venous thrombosis versus pharmacologic prophylaxis alone in patients with major orthopedic surgery [RR 0.48 (0.32 to 0.72)].
  ○ The impact of pharmacological plus mechanical prophylaxis versus mechanical prophylaxis cannot be discerned due to a lack of events in experimental groups.
- The use of two prophylactic strategies (pharmacologic plus mechanical) versus either pharmacologic or mechanical does not significantly impact subclasses of deep venous thromboses (asymptomatic, proximal, or distal deep) in patients with major orthopedic surgery
- The use of two prophylactic strategies (pharmacologic plus mechanical) versus either pharmacologic or mechanical does not significantly impact nonfatal pulmonary embolism, mortality, asymptomatic deep venous thrombosis, symptomatic deep venous thrombosis, proximal deep venous thrombosis, or distal deep venous thrombosis in patients with major orthopedic surgery
- The comparative impact of pharmacologic plus mechanical prophylaxis versus pharmacologic prophylaxis on major bleeding or minor bleeding could not be determined since no events occurred in the two comparative groups in the available trials.
  ○ No data are available to evaluate the comparative impact of pharmacologic plus mechanical prophylaxis versus mechanical prophylaxis on major bleeding or minor bleeding.
- No data are available to evaluate the comparative impact of two prophylactic strategies (pharmacologic plus mechanical) versus either pharmacologic or mechanical on symptomatically confirmed or major venous thromboembolism, postthrombotic syndrome, health related quality of life, major bleeding leading to reoperation, surgical site bleeding, bleeding leading to infection, bleeding leading to transfusion, heparin induced thrombocytopenia, discomfort, reoperation, or readmission in patients with major orthopedic surgery.
- The comparative impact of dual prophylactic modalities versus a single modality on fatal pulmonary embolism, or mortality due to bleeding could not be determined since no events occurred in the two comparative groups in the available trials.

### Detailed Analysis

#### Study Design and Characteristics

Six randomized controlled trials (N=995) and no controlled observation studies evaluated the impact of combined pharmacologic and mechanical modalities versus single modality on final health, intermediate and adverse outcomes.114-117,133,134 All six trials were published as full text manuscripts. Four of the randomized controlled trials (N=708) compared pharmacologic prophylaxis in combination with a mechanical prophylaxis versus pharmacologic prophylaxis alone,114-116,133 one of the randomized controlled trials (N=212) compared pharmacologic prophylaxis in combination with a mechanical prophylaxis versus mechanical prophylaxis alone,117 and one randomized controlled trial (N=75) included both comparisons.134 Four trials enrolled exclusively patients who had total hip replacement surgery (N= 596),115,117,133,134 one trial enrolled exclusively patients who had total knee replacement surgery (N=122),116 and one trial enrolled both patient populations although reported results separately (N=277).114 No trials enrolled patients who had hip fracture surgery. The earliest trial was published in 1991 while the most recent published in 2008.^114,117^ The duration of followup ranged from the postoperative period to 90 days. Two trials received funding from industry,114,133 three trials were unfunded,115-117 and one trial funding source was not reported.134

The mean age of enrolled patients ranged from 64 to years to 69.7 years. Females represented between 55.4 to 67.12 percent of the enrolled populations. The mean weight ranged from 71 to 88 kilograms with only one trial reporting obesity which ranged from 21.43 to 34.38 percent. Few patients enrolled had a history of venous thromboembolism, with the majority of trials reporting 0 to 14 percent. Presence of varicosity was reported as 7 to 46.88 percent. The percent of patients with a history of malignancy ranged from 3.12 to 18.6 percent. None of the trials reported the percent of patients who had previously undergone orthopedic surgery.

Sixty-eight to 100 percent of patients underwent primary surgery and the number of patients who had cemented fixation during surgery ranged from 0 to 100 percent. Mean duration of surgery ranged from 86 to 125 minutes while the mean duration of anesthesia was not reported by any trial. Use of general versus regional anesthesia varied, with general anesthesia use ranging from 12 to 100 percent of patients and regional anesthesia use ranging from 80 to 100 percent of patients. One trial specifically reported use of hypotensive regional anesthesia in all patients.115 The mean length of hospital stay was infrequently reported, and when it was ranged from 3 to 10 days.

#### Outcome Evaluations

A summary of the results is presented in Table 14.

Table 14 Summary of results for Key Question 7: what are the effect estimates of combined pharmacologic and mechanical modalities versus single modality in patients undergoing major orthopedic surgery?^*^

| Endpoint/Comparison | Type and Number of Studies | Pooled | Result | Statistical Heterogeneity I^2^ (%)
Symptomatic objectively confirmed VTE | Pharmacologic + mechanical prophylaxis versus single modality | 0 | --- | --- | ---
Major VTE | Pharmacologic + mechanical prophylaxis versus single modality | 0 | --- | --- | ---
PE | Pharmacologic + mechanical prophylaxis versus pharmacologic prophylaxis | 2 RCTs | Yes | OR 1.03 (0.14 to 7.34) | NA
PE | - Anticoagulant + mechanical prophylaxis versus anticoagulant prophylaxis | 1 RCT | No | OR 1.01 (0.06 to 16.35) | NA
PE | - Antiplatelet + mechanical prophylaxis versus antiplatelet prophylaxis | 1 RCT | No | OR 1.04 (0.06 to 16.82) | NA
PE | - 2001-present | 1 RCT | No | OR 1.01 (0.06 to 16.35) | NA
PE | - THR | 2 RCTs | No | 1 RCT had no events; the other showed an OR 1.04 (0.06 to 16.82) | NA
PE | - TKR | 1 RCT | No | OR 1.01 (0.06 to 16.35) | NA
PE | Pharmacologic + mechanical prophylaxis versus mechanical prophylaxis | 1 RCT (2 comp) | No | 1 comparison had no events; the other showed a RR 1.57 (0.13 to 19.02) | NA
PE | - Anticoagulant + mechanical prophylaxis versus anticoagulant prophylaxis | 1 RCT (1comp) | No | No events occurred in the groups compared | NA
PE | - Antiplatelet + mechanical prophylaxis versus antiplatelet prophylaxis | 1 RCT (1 comp) | No | RR 1.57 (0.13 to 19.02) | NA
PE | - THR | 1 RCT (2 comp) | No | 1 comparison had no events; the other showed a RR 1.57 (0.13 to 19.02)
Fatal PE | Pharmacologic + mechanical prophylaxis versus pharmacologic prophylaxis | 2 RCTs | No | No events occurred in the groups compared | NA
Fatal PE | Pharmacologic + mechanical prophylaxis versus mechanical prophylaxis | 0 | --- | --- | ---
Nonfatal PE | Pharmacologic + mechanical prophylaxis versus pharmacologic prophylaxis | 2 RCTs | Yes | OR 1.03 (0.14 to 7.34) | NA
Nonfatal PE | - Anticoagulant + mechanical prophylaxis versus anticoagulant prophylaxis | 1 RCT | No | OR 1.01 (0.06 to 16.35) | NA
Nonfatal PE | - Antiplatelet + mechanical prophylaxis versus antiplatelet prophylaxis | 1 RCT | No | OR 1.04 (0.06 to 16.82) | NA
Nonfatal PE | - 2001-present | 1 RCT | No | OR 1.01 (0.06 to 16.35) | NA
Nonfatal PE | - THR | 1 RCT | No | OR 1.04 (0.06 to 16.82) | NA
Nonfatal PE | - TKR | 1 RCT | No | OR 1.01 (0.06 to 16.35) | NA
Nonfatal PE | Pharmacologic + mechanical prophylaxis versus mechanical prophylaxis | 0 | --- | --- | ---
PTS | Pharmacologic + mechanical prophylaxis versus single modality | 0 | --- | --- | ---
Mortality | Pharmacologic + mechanical prophylaxis versus pharmacologic prophylaxis | 3 RCTs | No | 2 RCTs had no events in the groups compared; the third showed an OR of 7.72 (0.15 to 389.50) | NA
Mortality | - Anticoagulant + mechanical prophylaxis versus anticoagulant prophylaxis | 2 RCTs | No | No events occurred in the groups compared | NA
Mortality | - Antiplatelet + mechanical prophylaxis versus antiplatelet prophylaxis | 1 RCT | No | OR 7.72 (0.15 to 389.50) | NA
Mortality | - 2001-present | 1 RCT | No | No events in the groups compared | NA
Mortality | - THR | 2 RCTs | No | 1 RCT had no events; the third showed an OR 7.72 (0.15 to 389.50) | NA
Mortality | - TKR | 1 RCT | No | No events in the groups compared | NA
Mortality | Pharmacologic + mechanical prophylaxis versus mechanical prophylaxis | 1 RCT | No | No events occurred in the groups compared | NA
Mortality due to bleeding | Pharmacologic + mechanical prophylaxis versus pharmacologic prophylaxis | 3 RCTs | No | No events occurred in the groups compared | NA
Mortality due to bleeding | Pharmacologic + mechanical prophylaxis versus mechanical prophylaxis | 1 RCT | No | No events occurred in the groups compared | NA
HRQOL | Pharmacologic + mechanical prophylaxis versus single modality | 0 | --- | --- | ---
DVT | Pharmacologic + mechanical prophylaxis versus pharmacologic prophylaxis | 4 RCTs | Yes | RR 0.48 (0.32 to 0.72) | 0
DVT | - Anticoagulant + mechanical prophylaxis versus anticoagulant prophylaxis | 2 RCTs | Yes | RR 0.58 (0.32 to 1.06) | 0
DVT | - Antiplatelet + mechanical prophylaxis versus antiplatelet prophylaxis | 1 RCT | No | RR 0.40 (0.23 to 0.68) | NA
DVT | - 2001-present | 1 RCT (2 comp) | Yes | RR 0.45 (0.16 to 1.26) | NA
DVT | - THR | 2 RCTs | Yes | RR 0.64 (0.32 to 1.31) | NA
DVT | - TKR | 2 RCTs | Yes | RR 0.41 (0.25 to 0.68) | NA
DVT | Pharmacologic + mechanical prophylaxis versus mechanical prophylaxis | 1 RCT | No | No events occurred in the groups compared | NA
Asymptomatic DVT | Pharmacologic + mechanical prophylaxis versus pharmacologic prophylaxis | 1 RCT | No | RR 0.20 (0.02 to 2.09) | NA
Asymptomatic DVT | Pharmacologic + mechanical prophylaxis versus mechanical prophylaxis | 1 RCT | No | No events occurred in the groups compared | NA
Symptomatic DVT | Pharmacologic + mechanical prophylaxis versus pharmacologic prophylaxis | 1 RCT | No | RR 0.14 (0.01 to 1.42) | NA
Symptomatic DVT | Pharmacologic + mechanical prophylaxis versus mechanical prophylaxis | 1 RCT | No | No events occurred in the groups compared | NA
Proximal DVT | Pharmacologic + mechanical prophylaxis versus pharmacologic prophylaxis | 3 RCTs | Yes | RR 0.33 (0.09 to 1.22) | NA
Proximal DVT | Pharmacologic + mechanical prophylaxis versus pharmacologic prophylaxis | 2 RCTs | No | Two trials ineligible for pooling were evaluated separately and showed OR 0.14 (0.003 to 6.93) in 1 trial and RR 0.09 (0.01 to 0.85) in the other trial | NA
Proximal DVT | Anticoagulant + mechanical prophylaxis versus anticoagulant prophylaxis | 2 RCTs | No | 1 RCT had no events; 1 RCT showed RR 0.44 (0.15 to 1.30) | NA
Proximal DVT | Antiplatelet + mechanical prophylaxis versus antiplatelet prophylaxis | 1 RCT | No | RR 0.09 (0.01 to 0.84) | NA
Proximal DVT | - 2001-present | 1 RCT (2 comp) | No | No events occurred in the groups compared | NA
Proximal DVT | - THR | 2 RCTs | No | 1 RCT had no events; 1 RCT showed RR 0.44 (0.15 to 1.30) | NA
Proximal DVT | - TKR | 2 RCTs | No | 1 RCT had no events; 1 RCT showed RR 0.09 (0.01 to 1.51) | NA
Proximal DVT | Pharmacologic + mechanical prophylaxis versus mechanical prophylaxis | 2 RCTs | Yes | RR 0.78 (0.35 to 1.74) | NA
Proximal DVT | - Anticoagulant + mechanical prophylaxis versus anticoagulant prophylaxis | 1 RCT (1 comp) | No | RR 0.73 (0.28 to 1.88) | NA
Proximal DVT | - Antiplatelet + mechanical prophylaxis versus antiplatelet prophylaxis | 1 RCT (1 comp) | No | RR 0.82 (0.33 to 2.02) | NA
Proximal DVT | - THR | 2 RCTs | Yes | 1 RCT was ineligible for pooling; the remaining RCT had 2 comparisons pooled to show a RR 0.78 (0.35 to 1.74) | NA
Distal DVT | Pharmacologic + mechanical prophylaxis versus pharmacologic prophylaxis | 2 RCTs | Yes | No significant difference, one trial had no events and the remaining trial had two comparisons which were pooled to show RR 0.45 (0.16 to 1.26) | NA
Distal DVT | Pharmacologic + mechanical prophylaxis versus pharmacologic prophylaxis | 1 RCT | No | One trial ineligible for pooling showed RR 0.89 (0.34 to 2.29) | NA
Distal DVT | - Anticoagulant + mechanical prophylaxis versus anticoagulant prophylaxis | 1 RCT (2 comp) | Yes | RR 0.60 (0.23 to 1.59) | NA
Distal DVT | - Antiplatelet + mechanical prophylaxis versus antiplatelet prophylaxis | 1 RCT | No | RR 0.89 (0.34 to 2.29) | NA
Distal DVT | - 2001-present | 1 RCT (2 comp) | Yes | RR 0.60 (0.23 to 1.59) | NA
Distal DVT | - THR | 3 RCTs | Yes | 2 RCTs were ineligible for pooling; the remaining RCT had 2 comparisons when pooled showed a RR 0.60 (0.23 to 1.59) | NA
Distal DVT | - TKR | 1 RCT | No | RR 0.45 (0.15 to 1.32) | NA
Distal DVT | Pharmacologic + mechanical prophylaxis versus mechanical prophylaxis | 1 RCT | No | No events occurred in the groups compared | NA
Major Bleeding | Pharmacologic + mechanical prophylaxis versus pharmacologic prophylaxis | 1 RCT | No | No events occurred in the groups compared | NA
Major Bleeding | Pharmacologic + mechanical prophylaxis versus mechanical prophylaxis | 0 | --- | --- | ---
Major Bleeding Leading to Reoperation | Pharmacologic + mechanical prophylaxis versus single modality | 0 | --- | --- | ---
Minor Bleeding | Pharmacologic + mechanical prophylaxis versus pharmacologic prophylaxis | 1 RCT | No | No events occurred in the groups compared | NA
Minor Bleeding | Pharmacologic + mechanical prophylaxis versus mechanical prophylaxis | 0 | --- | --- | ---
Surgical Site Bleeding | Pharmacologic + mechanical prophylaxis versus single modality | 0 | --- | --- | ---
Bleeding Leading to Infection | Pharmacologic + mechanical prophylaxis versus single modality | 0 | --- | --- | ---
Bleeding Leading to Transfusion | Pharmacologic + mechanical prophylaxis versus single modality | 0 | --- | --- | ---
HIT | Pharmacologic + mechanical prophylaxis versus single modality | 0 | --- | --- | ---
Discomfort | Pharmacologic + mechanical prophylaxis versus single modality | 0 | --- | --- | ---
Readmission | Pharmacologic + mechanical prophylaxis versus single modality | 0 | --- | --- | ---
Reoperation | Pharmacologic + mechanical prophylaxis versus single modality | 0 | --- | --- | ---

DVT = deep vein thrombosis; HRQOL = health related quality of life; NA = not applicable; OR = Peto's Odds Ratio; PE = pulmonary embolism; PTS = post thrombotic syndrome; RCT = randomized controlled trial; RR = relative risk; VTE = venous thromboembolism

* All base case analyses are represented in this table. If only one trial was available in a base case analysis no subgroups analyses were performed and therefore are not represented in this table. Only subgroup analyses with trials or studies are represented in this table.

--- No data.

##### Symptomatic Objectively Confirmed Venous Thromboembolism

No randomized controlled trials or controlled observational studies evaluated the impact of combined pharmacologic and mechanical prophylaxis versus single modality prophylaxis on this outcome in patients who had major orthopedic surgery.

##### Major Venous Thromboembolism

No randomized controlled trials or controlled observational studies evaluated the impact of combined pharmacologic and mechanical prophylaxis versus single modality prophylaxis on this outcome in patients who had major orthopedic surgery.

##### Pulmonary Embolism

###### Pharmacologic Plus Mechanical Versus Pharmacologic Prophylaxis

Two randomized controlled trials evaluated the impact of combined pharmacologic and mechanical prophylaxis versus pharmacologic prophylaxis alone on pulmonary embolism in patients who had major orthopedic surgery.114,115 In the trial by Edwards and colleagues in 2008, patients who underwent total hip replacement or total knee replacement were enrolled and the outcomes are included separately for these two populations. All patients were randomized to receive either the combination of enoxaparin plus intermittent pneumatic compression or enoxaparin alone. No events occurred in the patients who had total hip replacement surgery and this analysis was not pooled with the others. The patients who had total knee replacement surgery in this study did provide data that could be pooled. In the second trial by Lieberman and colleagues in 1994, patients who had total hip replacement were randomized to receive aspirin plus intermittent pneumatic compression or aspirin alone. All patients also received elastic stockings. In the pooled analysis, in patients who received a combination of pharmacologic and mechanical prophylaxis versus pharmacologic prophylaxis alone the odds of pulmonary embolism were not significantly different [OR 1.03 (0.14 to 7.34)] (Appendix G Figure 211). Statistical heterogeneity and publication bias could not be evaluated because there were too few studies.

Subgroup analyses were not possible in most instances. Limiting the analysis to trials comparing anticoagulant plus mechanical prophylaxis versus anticoagulant prophylaxis alone, the trial by Edwards demonstrated no events in either group in those with total hip replacement and the odds of pulmonary embolism were not significantly different [OR 1.01 (0.06 to 16.35)] in patients who had total knee replacement. This is the same result obtained when limiting the original pooled analysis to trials published from 2001-present. In the trial by Lieberman and colleagues, which compared antiplatelet therapy plus mechanical prophylaxis versus antiplatelet therapy alone, the odds of pulmonary embolism were not significantly different [OR 1.04 (0.06 to 16.82)]. Only the total knee replacement analysis in the Edwards study provided data in that surgery type. In total hip replacement surgery, the evaluation in total hip replacement surgery by Edwards and colleagues had no events, and the study by Lieberman and colleagues found no significant effect. Subgroup analyses based on gender, age and ethnicity were not possible because no data were available.

###### Pharmacologic Plus Mechanical Versus Mechanical Prophylaxis

One randomized controlled trial evaluated the impact of pharmacologic plus mechanical prophylaxis versus mechanical prophylaxis alone on pulmonary embolism in patients who had major orthopedic surgery.117 This trial by Woolson and colleagues enrolled patients who had total hip replacement and included two comparisons; aspirin plus intermittent pneumatic compression versus intermittent pneumatic compression alone and warfarin plus intermittent pneumatic compression versus intermittent pneumatic compression alone. No events occurred in either the experimental or control group in the warfarin comparison. In patients who received antiplatelet therapy plus intermittent pneumatic compression versus intermittent pneumatic compression alone, the risk of pulmonary embolism was not significantly different [RR 1.57 (0.13 to 19.02)]. Subgroup analyses were possible since this was the only comparison available and data were not available to evaluate the effects of age, gender or ethnicity.

##### Fatal Pulmonary Embolism

###### Pharmacologic Plus Mechanical Versus Pharmacologic Prophylaxis

Two randomized controlled trials evaluated the impact of combined pharmacologic and mechanical prophylaxis versus pharmacologic prophylaxis alone on fatal pulmonary embolism in patients who had major orthopedic surgery.114,115 The comparisons made in these trials included enoxaparin plus intermittent pneumatic compression or enoxaparin alone and aspirin plus intermittent pneumatic compression or aspirin alone. However, no events occurred in the groups compared and therefore the risk of fatal pulmonary embolism could not be calculated.

###### Pharmacologic Plus Mechanical Versus Mechanical Prophylaxis

No randomized controlled trials or controlled observational studies evaluated the impact of pharmacologic plus mechanical prophylaxis versus mechanical prophylaxis alone in patients who had major orthopedic surgery.

##### Nonfatal Pulmonary Embolism

###### Pharmacologic Plus Mechanical Versus Pharmacologic Prophylaxis

Two randomized controlled trials evaluated the impact of combined pharmacologic and mechanical prophylaxis versus pharmacologic prophylaxis alone on nonfatal pulmonary embolism in patients who had major orthopedic surgery.114,115 The results obtained for all analyses of nonfatal pulmonary embolism are the same as those results and subgroup analyses reported for pulmonary embolism above, as all pulmonary embolism events were nonfatal (Appendix G Figure 212).

###### Pharmacologic Plus Mechanical Versus Mechanical Prophylaxis

No randomized controlled trials or controlled observational studies evaluated the impact of pharmacologic plus mechanical prophylaxis versus mechanical prophylaxis alone in patients who had major orthopedic surgery.

##### Post Thrombotic Syndrome

No randomized controlled trials or controlled observational studies evaluated the impact of combined pharmacologic and mechanical prophylaxis versus single modality prophylaxis on this outcome in patients who had major orthopedic surgery.

##### Mortality

###### Pharmacologic Plus Mechanical Versus Pharmacologic Prophylaxis

Three randomized controlled trials evaluated the impact of combined pharmacologic and mechanical prophylaxis versus pharmacologic prophylaxis alone on mortality in patients who had major orthopedic surgery although pooling of results was not possible.114,115,134 The trial by Stannard and colleagues in 1996 enrolled patients who had total hip replacement surgery and randomized patients to receive sequential pharmacologic prophylaxis (unfractionated heparin for three days then aspirin) plus venous foot pump, sequential pharmacologic prophylaxis (unfractionated heparin for three days then aspirin) alone, or venous foot pump alone. This trial was not suitable for pooling because the pharmacologic therapy was sequential in nature; additionally no events occurred in this trial.134 In the trial by Edwards and colleagues in 2008, patients who underwent total hip replacement or total knee replacement were randomized to receive either the combination of enoxaparin plus intermittent pneumatic compression or enoxaparin alone; however no events occurred in the groups compared.114 The remaining trial by Lieberman and colleagues in 1994 enrolled patients who had total hip replacement and were randomized to receive aspirin plus intermittent pneumatic compression or aspirin alone. In this trial, the odds of mortality were not significantly different in patients who received combination versus single modality prophylaxis [OR 7.72 (0.15 to 389.59)].115 This is the same result obtained when evaluating the impact of pharmacologic plus mechanical prophylaxis versus pharmacologic prophylaxis on mortality limited to total hip replacement, since the total hip replacement group in the trial by Edwards had no deaths, leaving the trial by Lieberman and colleagues. The one trial by Edwards and colleagues which evaluated total knee replacement did not have any events,114 and no trials evaluated patients who had hip fracture surgery. Subgroup analyses based on gender, age and ethnicity were not possible because no data were available to evaluate the effects of age, gender or ethnicity.

###### Pharmacologic Plus Mechanical Versus Mechanical Prophylaxis

One randomized controlled trial evaluated the impact of combined pharmacologic plus mechanical prophylaxis versus mechanical prophylaxis alone (unfractionated heparin for three days then aspirin plus venous foot pump versus venous foot pump alone) on mortality in patients who had major orthopedic surgery.134 No deaths occurred in the groups compared therefore the risk of mortality could not be calculated.

##### Mortality Due to Bleeding

###### Pharmacologic Plus Mechanical Versus Pharmacologic Prophylaxis

Three randomized controlled trials evaluated the impact of combined pharmacologic and mechanical prophylaxis versus pharmacologic prophylaxis alone on mortality due to bleeding in patients who had major orthopedic surgery.114,115,134 The comparisons made in these trials included enoxaparin plus intermittent pneumatic compression or enoxaparin alone, aspirin plus intermittent pneumatic compression or aspirin alone, and unfractionated heparin for three days then aspirin plus venous foot pump versus unfractionated heparin plus aspirin alone. However, no events occurred in the groups compared and therefore the comparative risk of mortality due to bleeding could not be calculated.

###### Pharmacologic Plus Mechanical Versus Mechanical Prophylaxis

One randomized controlled trial evaluated the impact of combined pharmacologic plus mechanical prophylaxis versus mechanical prophylaxis alone (unfractionated heparin for three days then aspirin plus venous foot pump versus venous foot pump alone) on mortality due to bleeding in patients who had major orthopedic surgery.134 No deaths due to bleeding occurred in the groups therefore the comparative risk of mortality could not be calculated.

##### Health-Related Quality of Life

No randomized controlled trials or controlled observational trials evaluated the impact of combined pharmacologic and mechanical prophylaxis versus single modality prophylaxis on this outcome in patients who had major orthopedic surgery.

##### Deep Vein Thrombosis

Four randomized controlled trials evaluated the impact of combined pharmacologic and mechanical prophylaxis versus single modality prophylaxis on deep vein thrombosis in patients who had major orthopedic surgery.114,116,133,134 The trial by Stannard and colleagues enrolled patients who had total hip replacement surgery and randomized patients to receive sequential pharmacologic prophylaxis (unfractionated heparin for three days then aspirin) plus venous foot pump, sequential pharmacologic prophylaxis (unfractionated heparin for three days then aspirin) alone, or venous foot pump alone. This trial was not suitable for pooling with the others because the administration of pharmacologic therapy was sequential in nature. In the comparison of sequential pharmacologic prophylaxis (unfractionated heparin for three days then aspirin) plus venous foot pump versus sequential pharmacologic prophylaxis (unfractionated heparin for three days then aspirin), the risk of deep vein thrombosis was significantly decreased in patients who received combination prophylaxis versus single modality [RR 0.09 (0.01 to 0.85), NNT 5].

Of the trials amenable for pooling, the trial by Edwards and colleagues enrolled patients who underwent total hip replacement or total knee replacement and reported the results separately for these two populations. Patients were randomized to receive either the combination of enoxaparin plus intermittent pneumatic compression or enoxaparin alone. The trial by Kalodiki and colleagues enrolled patients who had total hip replacement surgery and randomized patients to receive either the combination of enoxaparin plus graduated compression stockings or enoxaparin alone. The fourth trial by Westrich and colleagues in 1996 enrolled patients who had total knee replacement surgery and randomized patients to receive either the combination of aspirin plus venous foot pump versus aspirin alone. In this trial, the number of deep vein thromboses was reported out of the number of operated knees because some patients had bilateral surgery while others had unilateral surgery. We only used the unilateral data in pooled analyses. In pooled analysis of the Edwards, Kalodiki, and Westrich trials, patients who received pharmacologic prophylaxis plus mechanical prophylaxis versus pharmacologic prophylaxis alone, the risk of deep vein thrombosis was significantly decreased [RR 0.48 (0.32 to 0.72), NNT 3 to 67] (Appendix G Figure 213).114,116,133 Statistical heterogeneity and publication bias were not detected (I^2^=0 percent, Egger's p-value=0.637).

When limiting this analysis to only anticoagulant agents combined with mechanical prophylaxis versus an anticoagulant agent alone, the trials by Edwards and Kalodiki and colleagues remained.114,133 In patients who received anticoagulant prophylaxis plus mechanical prophylaxis versus anticoagulant prophylaxis alone, the risk of deep vein thrombosis was not significantly different [RR 0.58 (0.32 to 1.06)] (Appendix G Figure 214). Statistical heterogeneity was not detected (I^2^=0 percent). In the single trial by Westrich and colleagues which compared antiplatelet plus mechanical prophylaxis versus antiplatelet prophylaxis alone, in patients who received the combination versus monotherapy, the risk of deep vein thrombosis was significantly decreased [RR 0.40 (0.23 to 0.68), NNT 3].116

When limiting the original analysis to trials published from 2001-present, the two surgery populations from the trial by Edwards and colleagues remained.114 In patients who received pharmacologic plus mechanical prophylaxis versus pharmacologic prophylaxis alone, the risk of deep vein thrombosis was not significantly different [RR 0.45 (0.16 to 1.26)] (Appendix G Figure 215). Statistical heterogeneity could not be evaluated because of too few studies. When limiting the original analysis to total hip replacement surgery, the trials by Edwards and Kalodiki remained.114,133 In patients who received pharmacologic plus mechanical prophylaxis versus pharmacologic prophylaxis alone the risk of deep vein thrombosis was not significantly different [RR 0.64 (0.32 to 1.31)] (Appendix G Figure 216). Statistical heterogeneity could not be evaluated because of too few studies. When limiting the original analysis to total knee replacement surgery the trials by Edwards and Westrich remained.114,116 In patients who received pharmacologic plus mechanical prophylaxis versus pharmacologic prophylaxis alone the risk of deep vein thrombosis was significantly decreased [RR 0.41 (0.25 to 0.68), NNT 3 to 18] (Appendix G Figure 217). Statistical heterogeneity could not be evaluated because of too few studies. No trials evaluated patients who had hip fracture surgery and no data were available to evaluate the effects of age, gender or ethnicity.

The trial by Stannard and colleagues also compared pharmacologic prophylaxis plus mechanical prophylaxis versus mechanical prophylaxis alone (unfractionated heparin for three days then aspirin plus venous foot pump versus venous foot pump).134 However no events occurred in the groups compared therefore the risk of deep vein thrombosis could not be calculated.

##### Asymptomatic Deep Vein Thrombosis

One randomized controlled trial by Stannard and colleagues in 1996 evaluated the impact of combination pharmacologic plus mechanical prophylaxis versus single modality prophylaxis on asymptomatic deep vein thrombosis in patients who had major orthopedic surgery.134 This trial enrolled patients who had total hip replacement surgery and randomized patients to receive sequential pharmacologic prophylaxis (unfractionated heparin for three days then aspirin) plus venous foot pump, sequential pharmacologic prophylaxis (unfractionated heparin for three days then aspirin) alone, or venous foot pump alone.

In the comparison of sequential pharmacologic prophylaxis (unfractionated heparin for three days then aspirin) plus venous foot pump versus sequential pharmacologic prophylaxis (unfractionated heparin for three days then aspirin) alone, the risk of asymptomatic deep vein thrombosis was not significantly different in patients who received combination prophylaxis versus single modality [RR 0.20 (0.02 to 2.09)].

In the comparison of sequential pharmacologic prophylaxis (unfractionated heparin for three days then aspirin) plus venous foot pump versus venous foot pump alone, the risk of asymptomatic deep vein thrombosis could not be calculated because no events occurred. Subgroup analyses were not possible since only one trial was available.

##### Symptomatic Deep Vein Thrombosis

One randomized controlled trial by Stannard and colleagues in 1996 evaluated the impact of combination pharmacologic plus mechanical prophylaxis versus single modality prophylaxis on symptomatic deep vein thrombosis in patients who had major orthopedic surgery.134 This trial enrolled patients who had total hip replacement surgery and randomized patients to sequential pharmacologic prophylaxis (unfractionated heparin for three days then aspirin) plus venous foot pump, sequential pharmacologic prophylaxis (unfractionated heparin for three days then aspirin) alone, or venous foot pump alone. In the comparison of sequential pharmacologic prophylaxis (unfractionated heparin for three days then aspirin) plus venous foot pump versus sequential pharmacologic prophylaxis (unfractionated heparin for three days then aspirin) alone, the risk of symptomatic deep vein thrombosis was not significantly different in patients who received combination prophylaxis versus single modality [RR 0.14 (0.01 to 1.42)]. In the comparison of sequential pharmacologic prophylaxis (unfractionated heparin for three days then aspirin) plus venous foot pump versus venous foot pump alone, the risk of symptomatic deep vein thrombosis could not be calculated because no events occurred. Subgroup analyses were not possible since only one trial was available.

##### Proximal Deep Vein Thrombosis

###### Pharmacologic Plus Mechanical Versus Pharmacologic Prophylaxis

Five randomized controlled trials evaluated the impact of combined pharmacologic and mechanical prophylaxis versus single modality prophylaxis on deep vein thrombosis in patients who had major orthopedic surgery.114-116,133,134 The first trial by Edwards and colleagues in 2008 enrolled patients who had total hip or total knee replacement and reported the results separately for each surgery.114 Patients were randomized to receive either the combination of enoxaparin plus intermittent pneumatic compression or enoxaparin alone. The second trial by Kalodiki and colleagues in 1996 enrolled patients who had total hip replacement surgery and randomized patients to receive either the combination of enoxaparin plus graduated compression stockings or enoxaparin alone; however no events occurred in the groups compared, therefore this trial was excluded from the pooled analysis.133 The third trial by Westrich and colleagues in 1996 enrolled patients who had total knee replacement surgery and randomized patients to receive either the combination of aspirin plus venous foot pump versus aspirin alone.116 The fourth trial by Stannard and colleagues in 1996 enrolled patients who had total hip replacement surgery and randomized patients to receive sequential pharmacologic prophylaxis (unfractionated heparin for three days then aspirin) plus venous foot pump, sequential pharmacologic prophylaxis (unfractionated heparin for three days then aspirin) alone, or venous foot pump alone.134 This trial was not suitable for pooling because the sequential nature of the pharmacologic prophylaxis. In this trial, in the comparison of sequential pharmacologic prophylaxis (unfractionated heparin for three days then aspirin) plus venous foot pump versus sequential pharmacologic prophylaxis (unfractionated heparin for three days then aspirin) alone, the risk of proximal deep vein thrombosis was significantly decreased in patients who received combination prophylaxis versus single modality [RR 0.09 (0.01 to 0.85), NNT 5]. The fifth trial by Lieberman and colleagues enrolled patients who had total hip replacement surgery and randomized patients to receive aspirin plus intermittent pneumatic compression or aspirin alone.115 All patients also received elastic stockings. This trial was not suitable for pooling because the number of proximal deep vein thromboses was reported out of the total number of hips rather than patients. In this trial, the odds of proximal deep vein thrombosis were not significantly different in hip surgeries in which patients received combination versus single modality prophylaxis [OR 0.14 (0.003 to 6.93)]. In pooled analysis of the two remaining trials, in patients who received pharmacologic prophylaxis plus mechanical prophylaxis versus pharmacologic prophylaxis alone, the risk of proximal deep vein thrombosis was not significantly different [RR 0.33 (0.09 to 1.22)] (Appendix G Figure 217).116,133 Statistical heterogeneity and publication bias could not be evaluated because of too few studies.

When limiting this analysis to only anticoagulant agents combined with mechanical prophylaxis versus an anticoagulant agent alone, two trials remained although the trial by Edwards and colleagues was excluded from the analysis because no events occurred in the groups compared, leaving the trial by Kalodiki and colleagues.114,133 In this trial, in patients who received anticoagulant prophylaxis plus mechanical prophylaxis versus anticoagulant prophylaxis alone, the risk of deep vein thrombosis was not significantly different [RR 0.44 (0.15 to 1.30)]. In the single trial by Westrich and colleagues which compared antiplatelet plus mechanical prophylaxis versus antiplatelet prophylaxis alone, in patients who received the combination versus monotherapy, the risk of proximal deep vein thrombosis was significantly decreased [RR 0.09 (0.01 to 0.84), NNT 8].

Subgroup analysis based on trials published from 2001-present was not possible because only the trial by Edwards and colleagues remained although no events occurred in either surgical population in the groups compared.114 When limiting the original analysis to total hip replacement surgery, two trials remained although the trial by Edwards and colleagues was excluded from the analysis because no events occurred, leaving the trial by Kalodiki and colleagues. In this trial, in patients who received pharmacologic plus mechanical prophylaxis versus pharmacologic prophylaxis alone, the risk of proximal deep vein thrombosis was not significantly different [RR 0.44 (0.15 to 1.30)].133 When limiting the original analysis to total knee replacement surgery, two trials remained although the trial by Edwards and colleagues was excluded because no events occurred in the groups compared, leaving the trial by Westrich and colleagues. In this trial, in patients who received pharmacologic plus mechanical prophylaxis versus pharmacologic prophylaxis alone, the risk of proximal deep vein thrombosis was not significantly different [RR 0.09 (0.01 to 1.51)].116 Subgroup analysis based on hip fracture surgery was not possible because no trials evaluated this patient population and data were not reported in a way to evaluate the effects of age, gender or ethnicity.

###### Pharmacologic Plus Mechanical Versus Mechanical Prophylaxis

Two randomized controlled trials evaluated the impact of combined pharmacologic and mechanical prophylaxis versus mechanical prophylaxis alone.117,134 The comparison of sequential pharmacologic prophylaxis (unfractionated heparin for three days then aspirin) plus venous foot pump versus venous foot pump alone from the trial by Stannard and colleagues described above was not suitable for pooling because of the sequential nature of the pharmacologic therapy, additionally no events occurred in the groups compared.134 The trial by Woolson and colleagues in 1991 enrolled patients who had total hip replacement surgery and randomized patients by hip (not patients since multiple surgeries in the same patient could have been randomized twice to different groups) to receive aspirin plus intermittent pneumatic compression, warfarin plus intermittent pneumatic compression, or intermittent pneumatic compression alone.117 All patients also received graduated compression stockings. In the pooled analysis of the two comparisons in this trial, in hip surgeries in which the patient received pharmacologic plus mechanical prophylaxis versus mechanical prophylaxis alone, the risk of proximal deep vein thrombosis was not significantly different [RR 0.78 (0.35 to 1.74)] (Appendix G Figure 218). Statistical heterogeneity and publication bias could not be calculated because of too few studies. This is the same result obtained when limiting the original analysis to total hip replacement because the trial by Stannard and colleagues was ineligible for pooling, leaving the patients from Edwards and colleagues. When evaluating the two comparisons in this trial separately, the risk of proximal deep vein thrombosis was not significantly different in patients who received anticoagulant plus mechanical prophylaxis versus mechanical prophylaxis alone [RR 0.73 (0.28 to 1.88)] or in those who received antiplatelet plus mechanical prophylaxis versus mechanical prophylaxis alone [RR 0.82 (0.33 to 2.02)]. Subgroup analysis based on trial published from 2001-present or limited to total knee replacement or hip fracture surgery was not possible because no trials evaluated this patient population and data were not reported in a way to evaluate the effects of age, gender or ethnicity.

##### Distal Deep Vein Thrombosis

###### Pharmacologic Plus Mechanical Versus Pharmacologic Prophylaxis

Three randomized controlled trials evaluated the impact of combined pharmacologic and mechanical prophylaxis versus pharmacologic prophylaxis alone on distal deep vein thrombosis in patients who had major orthopedic surgery.114,115,134 The first trial by Stannard and colleagues in 1994 enrolled patients who had total hip replacement surgery and randomized patients to receive sequential pharmacologic prophylaxis (unfractionated heparin for three days then aspirin) plus venous foot pump, sequential pharmacologic prophylaxis (unfractionated heparin for three days then aspirin) alone, or venous foot pump alone. This trial was not suitable for pooling because the sequential nature of the pharmacologic prophylaxis, additionally no events occurred in the groups compared. The second trial by Lieberman and colleagues in 1994 enrolled patients who had total hip replacement surgery and randomized patients to receive aspirin plus intermittent pneumatic compression or aspirin alone. All patients also received elastic stockings. This trial was not suitable for pooling because the number of distal deep vein thromboses was reported out of the total number of hips rather than patients.115 In this trial, the risk of distal deep vein thrombosis was not significantly different in hip surgeries in which patients received combination versus single modality prophylaxis [RR 0.89 (0.34 to 2.29)]. The third trial by Edwards and colleagues enrolled patients who underwent total hip replacement or total knee replacement and the outcomes are included separately for these two populations. All patients were randomized to receive either the combination of enoxaparin plus intermittent pneumatic compression or enoxaparin alone. In the pooled analysis of both groups in the trial by Edwards and colleagues, in patients who received pharmacologic plus mechanical prophylaxis versus pharmacologic prophylaxis alone, the risk of distal deep vein thrombosis was not significantly different [RR 0.45 (0.16 to 1.26)] (Appendix G Figure 219). This is the same result obtained when pooling trials published from 2001-present or when comparing anticoagulant plus mechanical prophylaxis versus anticoagulant prophylaxis alone. Statistical heterogeneity and publication bias could not be evaluated because of too few studies.

When limiting the pooled analysis to only patients who had total hip replacement surgery in this trial, in patients who received pharmacologic plus mechanical prophylaxis versus pharmacologic prophylaxis alone, the risk of distal deep vein thrombosis were not significantly different [RR 0.46 (0.05 to 4.51)].114 When limiting the analysis to only patients who had total knee replacement surgery in this trial, in patients who receive pharmacologic plus mechanical prophylaxis versus pharmacologic prophylaxis alone, the risk of distal deep vein thrombosis was not significantly different [RR 0.45 (0.15 to 1.32)].114 Only one trial compared antiplatelet plus mechanical prophylaxis versus mechanical prophylaxis alone.115 In this trial, the risk of distal deep vein thrombosis was not significantly different in hip surgeries in which patients received antiplatelet plus mechanical prophylaxis versus antiplatelet prophylaxis alone [RR 0.89 (0.34 to 2.29)]. Subgroup analysis based on hip fracture surgery was not possible because no trials evaluated this population no data were available to evaluate the effects of age, gender or ethnicity.

###### Pharmacologic Plus Mechanical Versus Mechanical Prophylaxis

The trial by Stannard and colleagues also compared pharmacologic prophylaxis plus mechanical prophylaxis versus mechanical prophylaxis alone (unfractionated heparin for three days then aspirin plus venous foot pump or venous foot pump alone).134 However no events occurred in the groups compared therefore the risk of distal deep vein thrombosis could not be calculated.

##### Major Bleeding

###### Pharmacologic Plus Mechanical Versus Pharmacologic Prophylaxis

One randomized controlled trials evaluated the impact of combined pharmacologic and mechanical prophylaxis versus pharmacologic prophylaxis alone (aspirin plus venous foot pump versus aspirin alone) on major bleeding in patients who had major orthopedic surgery however the risk of major bleeding could not be calculated because no events occurred in the groups compared.116 Subgroup analyses were not possible because there was only one trial which evaluated this outcome and no data were available to evaluate the effects of age, gender or ethnicity.

###### Pharmacologic Plus Mechanical Versus Mechanical Prophylaxis

No randomized controlled trials or observational controlled studies evaluated the impact of pharmacologic plus mechanical prophylaxis versus mechanical prophylaxis on this outcome in patients who had major orthopedic surgery.

##### Major Bleeding Leading to Reoperation

No randomized controlled trials or controlled observational studies evaluated the impact of combined pharmacologic and mechanical prophylaxis versus single modality prophylaxis on this outcome in patients who had major orthopedic surgery.

##### Minor Bleeding

###### Pharmacologic Plus Mechanical Versus Pharmacologic Prophylaxis

One randomized controlled trials evaluated the impact of combined pharmacologic and mechanical prophylaxis versus pharmacologic prophylaxis alone (aspirin plus venous foot pump versus aspirin alone) on minor bleeding in patients who had major orthopedic surgery however the risk of major bleeding could not be calculated because no events occurred in the groups compared.116 Subgroup analyses were not possible because there was only one trial which evaluated this outcome and no data were available to evaluate the effects of age, gender or ethnicity.

###### Pharmacologic Plus Mechanical Versus Mechanical Prophylaxis

No randomized controlled trials or observational controlled studies evaluated the impact of pharmacologic plus mechanical prophylaxis versus mechanical prophylaxis on this outcome in patients who had major orthopedic surgery.

##### Surgical Site Bleeding

No randomized controlled trials or controlled observational studies evaluated the impact of combined pharmacologic and mechanical prophylaxis versus single modality prophylaxis on this outcome in patients who had major orthopedic surgery.

##### Bleeding Leading to Infection

No randomized controlled trials or controlled observational studies evaluated the impact of combined pharmacologic and mechanical prophylaxis versus single modality prophylaxis on this outcome in patients who had major orthopedic surgery.

##### Bleeding Leading to Transfusion

No randomized controlled trials or controlled observational studies evaluated the impact of combined pharmacologic and mechanical prophylaxis versus single modality prophylaxis on this outcome in patients who had major orthopedic surgery.

##### Heparin-Induced Thrombocytopenia

No randomized controlled trials or controlled observational studies evaluated the impact of combined pharmacologic and mechanical prophylaxis versus single modality prophylaxis on this outcome in patients who had major orthopedic surgery.

##### Discomfort

No randomized controlled trials or controlled observational studies evaluated the impact of combined pharmacologic and mechanical prophylaxis versus single modality prophylaxis on this outcome in patients who had major orthopedic surgery.

##### Readmission

No randomized controlled trials or controlled observational studies evaluated the impact of combined pharmacologic and mechanical prophylaxis versus single modality prophylaxis on this outcome in patients who had major orthopedic surgery

##### Reoperation

No randomized controlled trials or controlled observational studies evaluated the impact of combined pharmacologic and mechanical prophylaxis versus single modality prophylaxis on this outcome in patients who had major orthopedic surgery.

#### Strength of Evidence and Applicability of the Body of Evidence

Very few trials compared combination pharmacologic and mechanical prophylaxis versus one of the methods alone, and therefore the majority of outcomes were rated with insufficient strength of evidence in Key Question 7. When comparing pharmacologic plus mechanical to pharmacologic prophylaxis alone, there was moderate strength of evidence that combination therapy decreased the risk of deep vein thrombosis and had no difference on the risk of distal deep vein thrombosis compared with single modality. There was low strength of evidence that there was no difference in the odds of pulmonary embolism, nonfatal pulmonary embolism, or proximal deep vein thrombosis. When comparing pharmacologic plus mechanical versus mechanical prophylaxis, there was low strength of evidence that there was no difference in the risk of proximal deep vein thrombosis. All other outcomes for both comparisons were rated insufficient.

Overall applicability was often limited because one or two of the major orthopedic surgeries were not evaluated, duration of followup was inadequate to evaluate the given outcome, and many trials were conducted outside of the United States and sometimes represented a majority of the available data. Due to the paucity of available literature, conclusions were sometimes based on a specific combination compared with a single modality in one of the major orthopedic surgeries and therefore the overall applicability of the evidence to combination versus single modality in major orthopedic surgery is limited. In comparing combination prophylaxis to mechanical prophylaxis alone, most comparisons were only in hip replacement surgery.

## Key Question 8

In patients undergoing major orthopedic surgery (total hip or knee replacement, hip fracture surgery), regardless of thromboprophylaxis method, what are the effects of prolonging thromboprophylaxis for 28 days or longer compared with thromboprophylaxis for 7–10 days on symptomatic objectively confirmed venous thromboembolism, major venous thromboembolism (proximal deep vein thrombosis, pulmonary embolism or venous thromboembolism related mortality), pulmonary embolism, fatal pulmonary embolism, nonfatal pulmonary embolism, post thrombotic syndrome, mortality, mortality due to bleeding, deep vein thrombosis (asymptomatic or symptomatic, proximal or distal deep vein thrombosis), asymptomatic deep vein thrombosis, symptomatic deep vein thrombosis, proximal deep thrombosis, distal deep vein thrombosis, major bleeding, major bleeding leading to reoperation, minor bleeding, surgical site bleeding, bleeding leading to infection, bleeding leading to transfusion, heparin-induced thrombocytopenia, discomfort, readmission, and reoperation?

### Key Points

- In this Key Question, the impact of prolonging prophylaxis for 28 days or longer on events was compared with prophylaxis for 7 to 10 days in patients who had major orthopedic surgery.
- Prolonged prophylaxis reduced the occurrence of symptomatic objectively confirmed venous thromboembolism versus shorter term prophylaxis [RR 0.38 (0.19 to 0.77)]. While high heterogeneity was found, the direction of effect was consistent between all of the trials.
  ○ In subgroup analyses of trials conducted from 2001-present or in patients undergoing total hip replacement or hip fracture surgery, prolonged prophylaxis reduced the occurrence of symptomatic objectively confirmed venous thromboembolism versus shorter term prophylaxis.
  ○ In the one trials that stratified results based on gender, women with total hip and total knee replacement surgery had fewer symptomatic venous thromboembolism events after prolonged prophylaxis as did men with total hip replacement.
- Prolonged prophylaxis reduced the occurrence of pulmonary embolism versus shorter term prophylaxis [OR 0.13 (0.04 to 0.47)].
  ○ In subgroup analyses of trials conducted from 2001-present or in patients undergoing total hip replacement surgery, prolonged prophylaxis reduced the occurrence of pulmonary embolism versus shorter term prophylaxis.
- Prolonged prophylaxis reduced the occurrence of nonfatal pulmonary embolism versus shorter term prophylaxis [OR 0.13 (0.03 to 0.54)].
  ○ In subgroup analyses of trials conducted from 2001-present or in patients undergoing total hip replacement surgery, prolonged prophylaxis reduced the occurrence of nonfatal pulmonary embolism versus shorter term prophylaxis.
- Prolonged prophylaxis reduced the occurrence of deep venous thrombosis versus shorter term prophylaxis [RR 0.37 (0.21 to 0.64)]. While higher heterogeneity was found, the direction of effect was consistent between all of the trials.
  ○ In subgroup analyses of trials conducted from 2001-present or in patients undergoing total hip replacement or hip fracture surgery, prolonged prophylaxis reduced the occurrence of deep venous thrombosis versus shorter term prophylaxis.
- Prolonged prophylaxis reduced the occurrence of asymptomatic deep venous thrombosis versus shorter term prophylaxis [RR 0.48 (0.31 to 0.75)].
  ○ In subgroup analyses of patients undergoing total hip replacement surgery, prolonged prophylaxis reduced the occurrence of deep venous thrombosis versus shorter term prophylaxis.
- Prolonged prophylaxis reduced the occurrence of symptomatic deep venous thrombosis versus shorter term prophylaxis [OR 0.36 (0.16 to 0.81)].
- Prolonged prophylaxis reduced the occurrence of proximal deep venous thrombosis versus shorter term prophylaxis [RR 0.29 (0.16 to 0.52)].
  ○ In subgroup analyses of trials conducted from 2001-present or in patients undergoing total hip replacement or hip fracture surgery, prolonged prophylaxis reduced the occurrence of proximal deep venous thrombosis versus shorter term prophylaxis.
- While no differences were seen in the base case analysis, prolonged prophylaxis reduced the occurrence of distal deep venous thrombosis versus shorter term prophylaxis in hip fracture surgery.
- Prolonged prophylaxis increases the occurrence of minor bleeding versus shorter term prophylaxis [OR 2.44 (1.44 to 4.20)].
  ○ In subgroup analyses patients undergoing total hip replacement prolonged prophylaxis increases the occurrence of minor bleeding versus shorter term prophylaxis.
- Prolonged prophylaxis increases the occurrence of surgical site bleeding versus shorter term prophylaxis although this was based on a single randomized controlled trial.
  ○ In subgroup analyses of trials conducted from 2001-present or patients undergoing hip fracture surgery, prolonged prophylaxis increases the occurrence of surgical site bleeding versus shorter term prophylaxis.
- While no significant difference was seen in the base case analysis, prolonged prophylaxis reduced the occurrence of hospital readmission versus shorter term prophylaxis in total hip replacement surgery.
- Subgroup analyses based on total knee replacement surgery were based on a single comparison from one randomized controlled trial and did not show any statistically significant difference for the outcomes evaluated. These include: symptomatic objectively confirmed venous thromboembolism, pulmonary embolism, nonfatal pulmonary embolism, mortality due to bleeding, overall, proximal, and distal deep vein thrombosis, and major bleeding.

### Detailed Analysis

#### Study Design and Characteristics

Eight randomized controlled trials (N=2,917) and no controlled observational studies evaluated the effect of prolonging prophylaxis for 28 days or longer compared with prophylaxis for 7 to 10 days on final, intermediate, or adverse outcomes 118,121,122,124,126,127,131,198 All trials were published as full text manuscripts. Six trials (N=1,388) enrolled exclusively patients who had total hip replacement surgery.118,122,126,127,131,198 One trial (N=873) enrolled patients who had either total hip replacement or total knee replacement surgery and reported the results separately for each surgical population.121 One trial (N=656) enrolled patients who had hip fracture surgery.124

One trial (N=656) evaluated the factor Xa inhibitor fondaparinux,124 one trial (N=360) evaluated the vitamin K antagonist warfarin,131 and five trials (N=1,636) evaluated injectable low molecular weight heparin agents including enoxparin and dalteparin.118,121,126,127,198 One trial (N=265) compared dalteparin prophylaxis for 7 days versus dalteparin prophylaxis for 35 days but patients also received dextran and graduated compression stockings as part of the randomized prophylaxis regimen therefore this trial was not pooled with other trials and is evaluated separately in this Key Question.122 The earliest trial was published in 1997 while the most recent was published in 2003. The duration of followup ranged from 32 to 90 days. Three trials were funded by industry,121,124,127 one trial was funded by government/foundation,118 and the remaining trials did not disclose the funding source.

The mean age of enrolled patients ranged from 63.4 years to 79 years. Females represented between 38.2 and 73.6 percent of the enrolled populations. The mean weight ranged from 65 to 89.2 kilograms and obesity ranged from 7.8 to 75.1percent. Few patients enrolled had a history of venous thromboembolism ranging from 1.12 to 9.0 percent. Presence of varicosity ranged from 7.6 to 24 percent. The percent of patients with a history of malignancy ranged from 1.7 to 9.4 percent. Few trials reported the percent of patients who had previously undergone orthopedic surgery ranging from 3.6 to 13.33 percent.

Seventy-two to 100 percent of patients underwent primary surgery and the percent of patients who had cemented fixation during surgery ranged from 23.9 to 84.1 percent. Mean duration of surgery ranged from 95 to 114 minutes and the mean duration of anesthesia was reported by two trials with a range of 125.83 to 165 minutes. Use of general versus regional anesthesia varied, with general anesthesia use ranging from 0.88 to 97.2 percent of patients and regional anesthesia use ranging from 25.0 to 99.12 percent of patients. The mean length of hospital stay was reported by one trial, and it was 9 days.

#### Outcome Evaluations

A summary of the results is presented in Table 15.

Table 15 Summary of results for Key Question 8: regardless of thromboprophylaxis method, what are the effects of prolonging thromboprophylaxis for 28 days or longer compared with thromboprophylaxis for 7-10 days in patients undergoing major orthopedic surgery^*^

| Endpoint/Comparison | Type and Number of Studies | Pooled | Result | Statistical Heterogeneity I^2^ (%)
Symptomatic objectively confirmed VTE | Prolonged prophylaxis versus standard duration prophylaxis | 4 RCTs | Yes | RR 0.38 (0.19 to 0.77) | 69.1
Symptomatic objectively confirmed VTE | - 2001-present | 3 RCTs | Yes | RR 0.43 (0.20 to 0.89) | 72.9
Symptomatic objectively confirmed VTE | - THR | 3 RCTs | Yes | RR 0.33 (0.21 to 0.51) | 0
Symptomatic objectively confirmed VTE | - TKR | 1 RCT (1 comp) | No | RR 0.84 (0.57 to 1.23) | NA
Symptomatic objectively confirmed VTE | - HFS | 1 RCT | No | RR 0.11 (0.02 to 0.68) | NA
Symptomatic objectively confirmed VTE | - Age, gender, ethnicity | 1 RCT | No | RCT showed that extended duration prophylaxis significantly reduced the percent of patients with symptomatic venous thromboembolism in males and in females undergoing THR and in females undergoing TKR. In males undergoing TKR, there was no significant difference in the percent of patients with symptomatic venous thromboembolism | NA
Major VTE | Prolonged prophylaxis versus standard duration prophylaxis | 1 RCT | No | OR 0.34 (0.11 to 1.07) | NA
PE | Prolonged prophylaxis versus standard duration prophylaxis | 6 RCTs | Yes | OR 0.14 (0.04 to 0.47) | 0
PE | Prolonged prophylaxis versus standard duration prophylaxis | 1 RCT | No | One trial ineligible for pooling showed OR 0.54 (0.16 to 1.80) | NA
PE | - 2001-present | 3 RCTs | Yes | OR 0.13 (0.03 to 0.59) | 0
PE | - THR | 5 RCTs | Yes | OR 0.13 (0.02 to 0.77) | 0
PE | - TKR | 1 RCT (1 comp) | No | OR 0.14 (0.01 to 2.20) | NA
PE | - HFS | 1 RCT | No | OR 0.14 (0.01 to 1.31) | NA
Fatal PE | Prolonged prophylaxis versus standard duration prophylaxis | 5 RCTs | Yes | Four trials had no events; remaining trial showed OR 0.14 (0.003 to 6.90) | NA
Fatal PE | Prolonged prophylaxis versus standard duration prophylaxis | 1 RCT | No | One trial ineligible for pooling showed OR 0.13 (0.003 to 6.51) | NA
Fatal PE | - 2001-present | 3 RCTs | No | Two trials had no events; remaining trial showed OR 0.14 (0.003 to 6.90) | NA
Fatal PE | - THR | 5 RCTs | No | Four trials had no events; one trial ineligible for pooling showed OR 0.13 (0.003 to 6.51) | NA
Fatal PE | - HFS | 1 RCT | No | OR 0.14 (0.003 to 6.90) | NA
Nonfatal PE | Prolonged prophylaxis versus standard duration prophylaxis | 5 RCTs | Yes | OR 0.13 (0.03 to 0.54) | 0
Nonfatal PE | Prolonged prophylaxis versus standard duration prophylaxis | 1 RCT | No | One trial ineligible for pooling showed OR 0.13 (0.01 to 2.06) | NA
Nonfatal PE | - 2001-present | 3 RCTs | Yes | OR 0.13 (0.03 to 0.66) | 0
Nonfatal PE | - THR | 4 RCTs | Yes | OR 0.13 (0.02 to 0.93) | 0
Nonfatal PE | - THR | 1 RCT | No | One trial ineligible for pooling showed OR 0.13 (0.01 to 2.06) | NA
Nonfatal PE | - TKR | 1 RCT (1 comp) | No | OR 0.14 (0.01 to 2.20) | NA
Nonfatal PE | - HFS | 1 RCT | No | OR 0.14 (0.01 to 2.19) | NA
PTS | Prolonged prophylaxis versus standard duration prophylaxis | 0 | --- | --- | ---
Mortality | Prolonged prophylaxis versus standard duration prophylaxis | 5 RCTs | No | Four trials had no events; remaining trial showed OR 0.75 (0.26 to 2.17) | NA
Mortality | Prolonged prophylaxis versus standard duration prophylaxis | 1 RCT | No | One trial ineligible for pooling showed RR 0.98 (0.10 to 9.31) | NA
Mortality | - 2001-present | 3 RCTs | No | 2 trials were excluded from the analysis because no events occurred in the groups compared; remaining trial showed OR 0.75 (0.26 to 2.17) | NA
Mortality | - THR | 4 RCTs | No | 3 trials were excluded from the analysis because no events occurred in the groups compared; one trial ineligible for pooling showed RR 0.98 (0.10 to 9.31) | NA
Mortality | - TKR | 1 RCT | No | No events occurred in the groups compared | NA
Mortality | - HFS | 1 RCT | No | OR 0.75 (0.26 to 2.17) | NA
Mortality due to bleeding | Prolonged prophylaxis versus standard duration prophylaxis | 5 RCTs | No | No events occurred in the groups compared | NA
Mortality due to bleeding | - 2001-present | 2 RCTs | No | No events occurred in the groups compared | NA
Mortality due to bleeding | - THR | 5 RCTs | No | No events occurred in the groups compared | NA
Mortality due to bleeding | - TKR | 1 RCT | No | No events occurred in the groups compared | NA
HRQOL | Prolonged prophylaxis versus standard duration prophylaxis | 0 | --- | --- | ---
DVT | Prolonged prophylaxis versus standard duration prophylaxis | 7 RCTs | Yes | RR 0.37 (0.21 to 0.64) | 78.3
DVT | Prolonged prophylaxis versus standard duration prophylaxis | 1 RCT | No | One trial ineligible for pooling showed RR 0.61 (0.38 to 0.97) | NA
DVT | - 2001-present | 3 RCTs | Yes | RR 0.28 (0.09 to 0.87) | 90.9
DVT | - THR | 6 RCTs | Yes | RR 0.41 (0.31 to 0.55) | 0
DVT | - THR | 1 RCT | No | One trial ineligible for pooling showed RR 0.61 (0.38 to 0.97) | NA
DVT | - TKR | 1 RCT | No | RR 0.84 (0.57 to 1.23) | NA
DVT | - HFS | 1 RCT | No | RR 0.04 (0.01 to 0.12) | NA
Asymptomatic DVT | Prolonged prophylaxis versus standard duration prophylaxis | 4 RCTs | Yes | RR 0.48 (0.31 to 0.75) | 0
Asymptomatic DVT | - 2001-present | 1 RCT | No | OR 0.25 (0.05 to 1.24) | NA
Asymptomatic DVT | - THR | 4 RCTs | Yes | RR 0.48 (0.31 to 0.75) | 0
Symptomatic DVT | Prolonged prophylaxis versus standard duration prophylaxis | 4 RCTs | Yes | OR 0.36 (0.16 to 0.81) | 0
Symptomatic DVT | Prolonged prophylaxis versus standard duration prophylaxis | 1 RCT | No | One trial ineligible for pooling showed OR 1.83 (0.57 to 5.87) | NA
Symptomatic DVT | - 2001-present | 2 RCTs | Yes | OR 0.36 (0.12 to 1.12) | NA
Symptomatic DVT | - THR | 4 RCTs | Yes | OR 0.43 (0.16 to 1.12) | 0
Symptomatic DVT | - THR | 1 RCT | No | One trial ineligible for pooling showed OR 1.83 (0.57 to 5.87) | NA
Symptomatic DVT | - HFS | 1 RCT | No | OR 0.24 (0.05 to 1.06) | NA
Proximal DVT | Prolonged prophylaxis versus standard duration prophylaxis | 6 RCTs | Yes | RR 0.29 (0.16 to 0.52) | 48.1
Proximal DVT | Prolonged prophylaxis versus standard duration prophylaxis | 1 RCT | | One trial ineligible for pooling showed RR 0.65 (0.31 to 1.38) | NA
Proximal DVT | - 2001-present | 3 RCTs | Yes | RR 0.23 (0.08 to 0.61) | 65.5
Proximal DVT | - THR | 5 RCTs | Yes | RR 0.30 (0.19 to 0.49) | 0
Proximal DVT | - THR | 1 RCT | No | One trial ineligible for pooling showed RR 0.65 (0.31 to 1.38) | NA
Proximal DVT | - TKR | 1 RCT (1 comp) | No | RR 0.54 (0.25 to 1.16) | NA
Proximal DVT | - HFS | 1 RCT | No | RR 0.06 (0.02 to 0.21) | NA
Distal DVT | Prolonged prophylaxis versus standard duration prophylaxis | 4 RCTs | Yes | RR 0.39 (0.15 to 1.04) | 83.6
Distal DVT | - 2001-present | 2 RCTs | Yes | RR 0.33 (0.07 to 1.51) | NA
Distal DVT | - THR | 3 RCTs | Yes | RR 0.53 (0.24 to 1.17) | 53.4
Distal DVT | - TKR | 1 RCT (1 comp) | No | RR 1.09 (0.67 to 1.78) | NA
Distal DVT | - HFS | 1 RCT | No | RR 0.02 (0.004 to 0.14) | NA
Major bleeding | Prolonged prophylaxis versus standard duration prophylaxis | 5 RCTs | Yes | OR 2.18 (0.73 to 6.51) | 35.6
Major bleeding | - 2001-present | 3 RCTs | Yes | OR 2.76 (0.88 to 8.61) | 22.3
Major bleeding | - THR | 2 RCTs | Yes | OR 0.98 (0.06 to 15.70) | NA
Major bleeding | - TKR | 1 RCT (1 comp) | No | OR 0.14 (0.003 to 6.95) | NA
Major bleeding | - HFS | 1 RCT | No | OR 3.40 (0.98 to 11.84) | NA
Major bleeding leading to reoperation | Prolonged prophylaxis versus standard duration prophylaxis | 1 RCT | No | OR 1.01 (0.14 to 7.18) | NA
Minor bleeding | Prolonged prophylaxis versus standard duration prophylaxis | 3 RCTs | Yes | OR 2.44 (1.41 to 4.20) | 0
Minor bleeding | - 2001-present | 1 RCT | No | OR 2.39 (0.54 to 10.59) | NA
Minor bleeding | - THR | 2 RCTs | Yes | OR 2.44 (1.36 to 4.39) | NA
Minor bleeding | - HFS | 1 RCT | No | OR 2.39 (0.54 to 10.59) | ---
Surgical site bleeding | Prolonged prophylaxis versus standard duration prophylaxis | 1 RCT | No | OR 7.55 (1.51 to 37.64) | NA
Bleeding leading to infection | Prolonged prophylaxis versus standard duration prophylaxis | 0 | --- | --- | ---
Bleeding leading to transfusion | Prolonged prophylaxis versus standard duration prophylaxis | 2 RCTs | No | 1 trial was excluded from the analysis because no events occurred in the groups compared; remaining trial showed RR 1.46 (0.85 to 2.51) | NA
Bleeding leading to transfusion | - 2001-present | 2 RCTs | No | 1 trial was excluded from the analysis because no events occurred in the groups compared; remaining trial showed RR 1.46 (0.85 to 2.51) | NA
Bleeding leading to transfusion | - THR | 1 RCT | No | No events occurred in the groups compared | NA
Bleeding leading to transfusion | - HFS | 1 RCT | No | RR 1.46 (0.85 to 2.51) | NA
HIT | Prolonged prophylaxis versus standard duration prophylaxis | 0 | --- | --- | ---
Discomfort | Prolonged prophylaxis versus standard duration prophylaxis | 0 | --- | --- | ---
Readmission | Prolonged prophylaxis versus standard duration prophylaxis | 1 RCT (2 comp) | Yes | RR 0.29 (0.96 to 1.34) | NA
Readmission | - 2001-present | 1 RCT (2 comp) | Yes | RR 0.29 (0.96 to 1.34) | NA
Readmission | - THR | 1 RCT (1 comp) | No | RR 0.13 (0.04 to 0.39) | NA
Readmission | - TKR | 1 RCT (1 comp) | No | RR 0.59 (0.24 to 1.44) | NA
Reoperation | Prolonged prophylaxis versus standard duration prophylaxis | 1 RCT | No | RR 0.21 (0.02 to 2.16) | NA

DVT = deep vein thrombosis; HFS = hip fracture surgery; HIT = heparin induced thrombocytopenia; LMWH = low molecular weight heparin; NA = not applicable; OR = Peto's Odds Ratio; PE = pulmonary embolism; PTS = post thrombotic syndrome; RCT = randomized controlled trial; RR = relative risk; THR = total hip replacement; TKR = total knee replacement; UFH = unfractionated heparin; VKA = vitamin K antagonist

* All base case analyses are represented in the table. Subgroup analyses without available data are not represented in this table. If only 1 trial was available subgroup analyses were not run.

--- No data.

##### Symptomatic Objectively Confirmed Venous Thromboembolism

Four randomized controlled trials evaluated the effect of prolonging prophylaxis for 28 days or longer compared with prophylaxis for 7 to 10 days on symptomatic objectively confirmed venous thromboembolism in patients who had major orthopedic surgery.121,124,126,131 The trial by Comp and colleagues included two separate comparisons based on the surgery type (total hip replacement and total knee replacement surgery).121 In patients who received prolonged prophylaxis versus standard duration prophylaxis the risk of symptomatic objectively confirmed venous thromboembolism was significantly decreased [RR 0.38 (0.19 to 0.77), NNT 8 to 54] (Appendix G Figure 220). A higher level of statistical heterogeneity was detected but the presence of publication bias was not detected (I^2^=69.1 percent, Egger's p-value=0.150). The direction of effect was the same in all of the trials and differed only in the magnitude of the effect. Some of the heterogeneity may be related to the type of surgery.

When limiting the original analysis to trials published from 2001-present three trials remained with the trial by Comp and colleagues including two separate comparisons based on surgery type.121,124,131 In patients who received prolonged prophylaxis versus standard duration prophylaxis the risk of symptomatic objectively confirmed venous thromboembolism was significantly decreased [RR 0.43 (0.20 to 0.89), NNT 8 to 59] (Appendix G Figure 221). A higher level of statistical heterogeneity was detected (I^2^=72.9 percent). When limiting the original analysis to total hip replacement surgery three trials remained.121,126,131 In patients who received prolonged prophylaxis versus standard duration prophylaxis the risk of symptomatic objectively confirmed venous thromboembolism was significantly decreased [RR 0.33 (0.21 to 0.51), NNT 7 to 30] (Appendix G Figure 222). Statistical heterogeneity was not detected (I^2^=0 percent). When limiting the original analysis to total knee replacement surgery one comparison from the trial by Comp and colleagues remained.121 In this comparison, in patients who received prolonged prophylaxis versus standard duration prophylaxis the risk of symptomatic objectively confirmed venous thromboembolism was not significantly different [RR 0.84 (0.57 to 1.23)]. When limiting the original analysis to hip fracture surgery one trial remained.124 In this trial, in patients who received prolonged prophylaxis versus standard duration prophylaxis the risk of symptomatic objectively confirmed venous thromboembolism was significantly decreased [RR 0.11 (0.02 to 0.68), NNT 38].

The trial by Comp and colleagues evaluated the impact of gender on the efficacy of extended duration prophylaxis versus standard duration prophylaxis on symptomatic venous thromboembolism in patients who had major orthopedic surgery.121 Two surgical populations were evaluated separately in this trial; total hip replacement and total knee replacement surgery. In males, extended duration prophylaxis significantly reduced the percent of patients who had symptomatic venous thromboembolism compared with standard duration prophylaxis in patients who had total hip replacement (6.3 percent versus 23.6, p < 0.001) but not in those who had total knee replacement (23.6 percent versus 15.3 percent, p=0.211). In females extended duration prophylaxis significantly reduced the percent of patients who had symptomatic venous thromboembolism compared with standard duration prophylaxis in patients who had total hip replacement (9.7 percent versus 22.9, p=0.014) and in those who had total knee replacement (13.3 percent versus 25.2 percent, p=0.025).

##### Major Venous Thromboembolism

One randomized controlled trial evaluated the effect of prolonging prophylaxis for 28 days or longer compared with prophylaxis for 7 to 10 days on major venous thromboembolism in patients who had major orthopedic surgery.131 This trial by Prandoni and colleagues in 2002 evaluated patients who had total hip replacement surgery and received warfarin prophylaxis for 28 days versus warfarin prophylaxis until hospital discharge, with a mean hospital length of stay of 9 days. In this trial, in patients who received prolonged prophylaxis versus standard duration prophylaxis the odds of major venous thromboembolism were not significantly different [OR 0.34 (0.11 to 1.07)]. Subgroup analyses were not possible as only one trial with events was available.

##### Pulmonary Embolism

Seven randomized controlled trials evaluated the effect of prolonging prophylaxis for 28 days or longer compared with prophylaxis for 7 to 10 days on pulmonary embolism in patients who had major orthopedic surgery.118,121,122,124,126,127,131 The trial by Comp and colleagues included two separate comparisons based on the surgery type; total hip replacement and total knee replacement surgery and the trial by Planes and colleagues was excluded from the analysis because no events occurred in the groups compared.121,127 The trial by Dahl and colleagues was evaluated separately from the pooled analysis because patients received triple prophylaxis.122 The remaining five trials were pooled and in patients who received prolonged prophylaxis versus standard duration prophylaxis the odds of pulmonary embolism were significantly decreased [OR 0.14 (0.04 to 0.47), NNT 24 to 232] (Figure 11). Statistical heterogeneity and publication bias were not detected (I^2^=0 percent, Egger's p-value=0.471).

Figure 11 Impact of prolonged prophylaxis versus standard duration of prophylaxis on pulmonary embolism in patients who had major orthopedic surgery

I^2^: 0 percent.

Egger's p-value: 0.471.

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of prolonged prophylaxis versus standard duration of prophylaxis on pulmonary embolism in patients who had major orthopedic surgery. Six trials were included in this analysis with the trial by Comp and colleagues contributing two comparisons presented individually here. The first trial by Eriksson and colleagues in 2003 provided a relative risk of 0.14 with a 95 percent confidence interval of 0.01 to 1.31. The second trial by Prandoni and colleagues in 2002 provided a relative risk of 0.13 with a 95 percent confidence interval of 0.003 to 6.52. The third trial by Comp and colleagues in 2001 provided two comparisons. The first comparison provided a relative risk of 0.13 with a 95 percent confidence interval of 0.003 to 6.42. The second comparison provided a relative risk of 0.14 with a 95 percent confidence interval of 0.01 to 2.20. The fourth trial by Andersen and colleagues in 1997 provided a relative risk of 0.14 with a 95 percent confidence interval of 0.003 to 7.16. The fifth trial by Nilsson and colleagues in 1997 provided relative risk of 0.13 and a 95 percent confidence interval of 0.01 to 2.16. The sixth trial by Planes and colleagues in 1997 was excluded because there were no evens in the groups compared. The combined effect of the five trials showed a relative risk of 0.14 with a 95 percent confidence interval of 0.04 to 0.47. The I-squared value was 0 percent and the Egger's p-value was 0.471.

The trial by Dahl and colleagues randomized patients who had total hip replacement surgery to continue dalteparin for a total of 35 days versus placebo until day 35 after seven days of prophylaxis with dalteparin, dextran, and graduated compression stockings.122 In this trial in patients who received prolonged prophylaxis versus standard duration prophylaxis the odds of pulmonary embolism were not significantly different [OR 0.54 (0.16 to 1.80)].

When limiting the original analysis to trials published from 2001-present three trials remained, with the trial by Comp and colleagues including two separate comparisons based on surgery type.121,124,131 In patients who received prolonged prophylaxis versus standard duration prophylaxis the odds of pulmonary embolism were significantly decreased [OR 0.13 (0.03 to 0.59), NNT 9 to 232] (Appendix G Figure 223). Statistical heterogeneity was not detected (I^2^=0 percent). When limiting the original analysis to total hip replacement surgery five trials remained although the trial by Planes and colleagues was excluded from the analysis because no events occurred in the groups compared.118,121,126,127,131 In patients who received prolonged prophylaxis versus standard duration prophylaxis the odds of pulmonary embolism were significantly decreased [OR 0.13 (0.02 to 0.77), NNT 24] (Appendix G Figure 224). A range for the number needed to treat could not be calculated because the lowest control event rate was zero. Statistical heterogeneity was not detected (I^2^=0 percent). When limiting the original analysis to total knee replacement surgery one comparison from the trial by Comp and colleagues remained.121 In this comparison, in patients who received prolonged prophylaxis versus standard duration prophylaxis the odds of pulmonary embolism were not significantly different [OR 0.14 (0.01 to 2.20)]. When limiting the original analysis to hip fracture surgery one trial remained.124 In this trial, in patients who received prolonged prophylaxis versus standard duration prophylaxis the odds of pulmonary embolism were not significantly different [OR 0.14 (0.01 to 1.31)].

##### Fatal Pulmonary Embolism

Six randomized controlled trials evaluated the effect of prolonging prophylaxis for 28 days or longer compared with prophylaxis for 7 to 10 days on fatal pulmonary embolism in patients who had major orthopedic surgery.121,122,124,126,127,131 Four trials were excluded from the analysis because no events occurred. The trial by Dahl and colleagues was evaluated separately because patients received triple prophylactic therapy.122 The remaining trial by Eriksson and colleagues in 2003 evaluated patients who had hip fracture surgery and who received fondaparinux prophylaxis for 25 to 31 days versus fondaparinux prophylaxis fro 6 to 8 days. In this trial, in patients who received prolonged prophylaxis versus standard duration prophylaxis the odds of fatal pulmonary embolism were not significantly different [OR 0.14 (0.003 to 6.90)]. Subgroup analyses were not possible as only one trial with events was available.

The trial by Dahl and colleagues randomized patients who had total hip replacement surgery to continue dalteparin for a total of 35 days versus placebo until day 35 after seven days of prophylaxis with dalteparin, dextran, and graduated compression stockings.122 In this trial the odds of fatal pulmonary embolism were not significantly different [OR 0.13 (0.003 to 6.51)] in patients who received prolonged prophylaxis versus shorter duration prophylaxis.

##### Nonfatal Pulmonary Embolism

Six randomized controlled trials evaluated the effect of prolonging prophylaxis for 28 days or longer compared with prophylaxis for 7 to 10 days on nonfatal pulmonary embolism in patients who had major orthopedic surgery.121,122,124,126,127,131 The trial by Comp and colleagues included two separate comparisons based on the surgery type (total hip replacement and total knee replacement surgery) and the trial by Planes and colleagues was excluded from the analysis because no events occurred in the groups compared.121,127 The trial by Dahl and colleagues was evaluated separately from the pooled analysis because patients received triple prophylactic therapy.122 The four remaining trials were pooled and in patients who received prolonged prophylaxis versus standard duration prophylaxis the odds of nonfatal pulmonary embolism were significantly decreased [OR 0.13 (0.03 to 0.54), NNT 58] (Appendix G Figure 225). A range for the number needed to treat could not be calculated because the lowest control event rate was zero. Statistical heterogeneity was not detected although the presence of publication bias was detected (I^2^=0 percent, Egger's p-value=0.016). The directionality of the publication bias, however, was unclear.

The trial by Dahl and colleagues randomized patients who had total hip replacement surgery to continue dalteparin for a total of 35 days versus placebo until day 35 after seven days of prophylaxis with dalteparin, dextran, and graduated compression stockings.122 In this trial the odds of nonfatal pulmonary embolism were not significantly different [OR 0.13 (0.01 to 2.06)] in patients who received prolonged prophylaxis versus shorter duration prophylaxis.

When limiting the original analysis to trials published from 2001-present, three trials remained with the trial by Comp and colleagues including two separate comparisons based on surgery type.121,124,131 In patients who received prolonged prophylaxis versus standard duration prophylaxis the odds of nonfatal pulmonary embolism were significantly decreased [OR 0.13 (0.03 to 0.66), NNT 9 to 232] (Appendix G Figure 226). Statistical heterogeneity was not detected (I^2^=0 percent). When limiting the original analysis to total hip replacement surgery four trials remained although the trial by Planes and colleagues was excluded from the analysis because no events occurred in the groups compared.121,126,127,131 In patients who received prolonged prophylaxis versus standard duration prophylaxis the odds of nonfatal pulmonary embolism were significantly decreased [OR 0.13 (0.02 to 0.93), NNT 58] (Appendix G Figure 227). A range for the number needed to treat could not be calculated because the lowest control event rate was zero. Statistical heterogeneity was not detected (I^2^=0 percent). When limiting the original analysis to total knee replacement surgery one comparison from the trial by Comp and colleagues remained.121 In this comparison, the odds of nonfatal pulmonary embolism were not significantly different [OR 0.14 (0.01 to 2.20)] in patients who received prolonged prophylaxis versus standard duration prophylaxis. When limiting the original analysis to hip fracture surgery one trial remained.124 In this trial, the odds of nonfatal pulmonary embolism were not significantly different [OR 0.14 (0.01 to 2.19)] in patients who received prolonged prophylaxis versus standard duration prophylaxis.

##### Post thrombotic Syndrome

No randomized controlled trials or controlled observational studies evaluated the effect of prolonging prophylaxis for 28 days or longer compared with prophylaxis for 7 to 10 days in patients who had major orthopedic surgery on this outcome.

##### Mortality

Six randomized controlled trials evaluated the effect of prolonging prophylaxis for 28 days or longer compared with prophylaxis for 7 to 10 days on mortality in patients who had major orthopedic surgery.121,122,124,126,127,131 The trial by Dahl and colleagues was evaluated separately because patients received triple prophylactic therapy.122 Four trials were excluded from the analysis because no events occurred, leaving the trial by Eriksson and colleagues in 2003. This trial evaluated patients who had hip fracture surgery and received fondaparinux prophylaxis for 25 to 31 days versus fondaparinux prophylaxis for 6 to 8 days. In this trial, in patients who received prolonged prophylaxis versus standard duration prophylaxis the odds of mortality were not significantly different [OR 0.75 (0.26 to 2.17)]. Subgroup analyses were not possible as only one trial with events was available.

The trial by Dahl and colleagues randomized patients who had total hip replacement surgery to continue dalteparin for a total of 35 days versus placebo until day 35 after seven days of prophylaxis with dalteparin, dextran, and graduated compression stockings.122 In this trial the risk of mortality was not significantly different [RR 0.98 (0.10 to 9.31)] in patients who received prolonged prophylaxis versus standard duration prophylaxis.

##### Mortality Due to Bleeding

Five randomized controlled trials evaluated the effect of prolonging prophylaxis for 28 days or longer compared with prophylaxis for 7 to 10 days on mortality due to bleeding in patients who had major orthopedic surgery however no events occurred in the groups compared therefore the risk of mortality due to bleeding could not be calculated.121,122,126,127,131

##### Health Related Quality of Life

No randomized controlled trials or controlled observational studies evaluated the effect of prolonging prophylaxis for 28 days or longer compared with prophylaxis for 7 to 10 days in patients who had major orthopedic surgery on this outcome.

##### Deep Vein Thrombosis

Eight randomized controlled trials evaluated the effect of prolonging prophylaxis for 28 days or longer compared with prophylaxis for 7 to 10 days on deep vein thrombosis in patients who had major orthopedic surgery.118,121,122,124,126,127,131,198 The trial by Comp and colleagues included two separate comparisons based on the surgery type (total hip replacement and total knee replacement).121 The trial by Dahl and colleagues was evaluated separately from the analysis because patients received triple prophylactic therapy.122 In patients who received prolonged prophylaxis versus standard duration prophylaxis the risk of deep vein thrombosis was significantly decreased [RR 0.37 (0.21 to 0.64), NNT 5 to 32] (Appendix G Figure 228). A higher level of statistical heterogeneity was detected but the presence of publication bias was not detected (I^2^=78.3 percent, Egger's p-value=0.164).

The trial by Dahl and colleagues randomized patients who had total hip replacement surgery to continue dalteparin for a total of 35 days versus placebo until day 35 after seven days of prophylaxis with dalteparin, dextran, and graduated compression stockings.122 In this trial in patients who received prolonged prophylaxis versus standard duration prophylaxis the risk of deep vein thrombosis was significantly decreased [RR 0.61 (0.38 to 0.97)].

When limiting the original analysis to trials published from 2001-present three trials remained with the trial by Comp and colleagues including two separate comparisons based on surgery type.121,124,131 In patients who received prolonged prophylaxis versus standard duration prophylaxis the risk of deep vein thrombosis was significantly decreased [RR 0.28 (0.09 to 0.87), NNT 5 to 28] (Appendix G Figure 229). A higher level of statistical heterogeneity was detected (I^2^=90.9 percent). When limiting the original analysis to total hip replacement surgery six trials remained.118,121,126,127,131,198 In patients who received prolonged prophylaxis versus standard duration prophylaxis the risk of deep vein thrombosis was significantly decreased [RR 0.41 (0.31 to 0.55), NNT 6 to 34] (Appendix G Figure 230). Statistical heterogeneity was not detected (I^2^=0 percent). When limiting the original analysis to total knee replacement surgery one comparison from the trial by Comp and colleagues remained.121 In this comparison, in patients who received prolonged prophylaxis versus standard duration prophylaxis the risk of deep vein thrombosis was not significantly different [RR 0.84 (0.57 to 1.23)]. When limiting the original analysis to hip fracture surgery one trial remained.124 In this trial, in patients who received prolonged prophylaxis versus standard duration prophylaxis the risk of deep vein thrombosis was significantly decreased [RR 0.04 (0.01 to 0.12), NNT 4].

##### Asymptomatic Deep Vein Thrombosis

Four randomized controlled trials evaluated the effect of prolonging prophylaxis for 28 days or longer compared with prophylaxis for 7 to 10 days on asymptomatic deep vein thrombosis in patients who had major orthopedic surgery.118,126,131,198 In patients who received prolonged prophylaxis versus standard duration prophylaxis the risk of asymptomatic deep venous thrombosis was significantly decreased [RR 0.48 (0.31 to 0.75), NNT 8 to 65] (Figure 12). Statistical heterogeneity and the presence of publication bias were not detected (I^2^=0 percent, Egger's p-value=0.252). This is the same result obtained when limiting the analysis to total hip replacement surgery since all four trials evaluated this surgical population. When limiting the original analysis to trials published from 2001-present, one trial remained.131 In this trial, the odds of asymptomatic deep vein thrombosis were not significantly different [OR 0.25 (0.05 to 1.24)] in patients who received prolonged prophylaxis versus standard duration prophylaxis. Subgroup analysis based on total knee replacement or hip fracture surgery were not possible since no trials evaluated these surgical populations.

Figure 12 Impact of prolonged prophylaxis versus standard duration of prophylaxis on asymptomatic deep vein thrombosis in patients who had major orthopedic surgery (same as limited to total hip replacement surgery)

I^2^: 0 percent.

Egger's p-value: 0.252.

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of prolonged prophylaxis versus standard duration of prophylaxis on asymptomatic deep vein thrombosis in patients who had major orthopedic surgery. This figure also depicts the meta-analysis of the impact of prolonged prophylaxis versus standard duration of prophylaxis on asymptomatic deep venous thrombosis in patients who had major orthopedic surgery limited to total hip replacement surgery. Four trials were included in this analysis. The first trial by Prandoni and colleagues in 2003 provided a relative risk of 0.19 with a 95 percent confidence interval of 0.03 to 1.22. The second trial by Lassen and colleagues in 1998 provided a relative risk of 0.30 with a 95 percent confidence interval of 0.09 to 1.00. The third trial by Andersen and colleagues in 1997 provided a relative risk of 0.53 with a 95 percent confidence interval of 0.07 to 3.74. The fourth trial by Nilsson and colleagues in 1997 provided a relative risk of 0.54 with a 95 percent confidence interval of 0.33 to 0.89. The combined effect of the four trials showed a relative risk of 0.48 with a 95 percent confidence interval of 0.31 to 0.75. The I-squared value was 0 percent and the Egger's p-value was 0.252.

##### Symptomatic Deep Vein Thrombosis

Five randomized controlled trials evaluated the effect of prolonging prophylaxis for 28 days or longer compared with prophylaxis for 7 to 10 days on symptomatic deep vein thrombosis in patients who had major orthopedic surgery.118,122,124,126,131 The trial by Dahl and colleagues was evaluated separately because patients received triple prophylactic therapy.122 In patients who received prolonged prophylaxis versus standard duration prophylaxis the odds of symptomatic deep vein thrombosis were significantly decreased [OR 0.36 (0.16 to 0.81), NNT 27 to 79] (Figure 13). Statistical heterogeneity and the presence of publication bias were not detected (I^2^=0 percent, Egger's p-value=0.155).

Figure 13 Impact of prolonged prophylaxis versus standard duration of prophylaxis on symptomatic deep vein thrombosis in patients who had major orthopedic surgery

I^2^: 0 percent.

Egger's p-value: 0.155.

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the iimpact of prolonged prophylaxis versus standard duration of prophylaxis on symptomatic deep vein thrombosis in patients who had major orthopedic surgery. Four trials were included in this analysis. The first trial by Eriksson and colleagues in 2003 provided an odds ratio of 0.24 with a 95 percent confidence interval of 0.05 to 1.06. The second trial by Prandoni and colleagues in 2002 provided an odds ratio of 0.64 with a 95 percent confidence interval of 0.11 to 3.72. The third trial by Andersen and colleagues in 1997 provided an odds ratio of 1.05 with a 95 percent confidence interval of 0.06 to 17.43. The fourth trial by Nilsson and colleagues in 1997 provided an odds ratio of 0.29 and a 95 percent confidence interval of 0.08 to 1.02. The combined effect of the four trials showed an odds ratio of 0.36 with a 95 percent confidence interval of 0.16 to 0.81. The I-squared value was 0 percent and the Egger's p-value was 0.155.

The trial by Dahl and colleagues randomized patients who had total hip replacement surgery to continue dalteparin for a total of 35 days versus placebo until day 35 after seven days of prophylaxis with dalteparin, dextran, and graduated compression stockings.122 In this trial in patients who received prolonged prophylaxis versus standard duration prophylaxis the odds of symptomatic deep vein thrombosis were not significantly different [OR 1.83 (0.57 to 5.87)].

When limiting the original analysis to trials published from 2001-present, two trials remained.124,131 In patients who received prolonged prophylaxis versus standard duration prophylaxis the odds of symptomatic deep vein thrombosis were not significantly different [OR 0.36 (0.12 to 1.12)] (Appendix G Figure 231). Statistical heterogeneity could not be evaluated because of too few studies. When limiting the original analysis to total hip replacement surgery three trials remained.118,126,131 In patients who received prolonged prophylaxis versus standard duration prophylaxis the odds of symptomatic deep vein thrombosis were not significantly different [OR 0.43 (0.16 to 1.12)] (Appendix G Figure 232). Statistical heterogeneity was not detected (I^2^=0 percent). When limiting the original analysis to hip fracture surgery one trial remained.124 In patients who received prolonged prophylaxis versus standard duration prophylaxis the odds of symptomatic deep vein thrombosis were not significantly different [OR 0.24 (0.05 to 1.06)]. Subgroup analysis based on total knee replacement surgery was not possible as no trials evaluated this surgical population.

##### Proximal Deep Vein Thrombosis

Seven randomized controlled trials evaluated the effect of prolonging prophylaxis for 28 days or longer compared with prophylaxis for 7 to 10 days on proximal deep vein thrombosis in patients who had major orthopedic surgery.121,122,124,126,127,131,198 The trial by Comp and colleagues included two separate comparisons based on the surgery type (total hip replacement and total knee replacement).121 The trial by Dahl and colleagues was evaluated separately from the analysis because patients received triple prophylactic therapy.122 In patients who received prolonged prophylaxis versus standard duration prophylaxis the risk of proximal deep vein thrombosis was significantly decreased [RR 0.29 (0.16 to 0.52), NNT 9 to 71] (Figure 14). A lower level of statistical heterogeneity was detected and the presence of publication bias was not detected (I^2^=48.1 percent, Egger's p-value=0.507).

Figure 14 Impact of prolonged prophylaxis versus standard duration of prophylaxis on proximal deep vein thrombosis in patients who had major orthopedic surgery

I^2^: 48.1 percent.

Egger's p-value: 0.507.

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of prolonged prophylaxis versus standard duration of prophylaxis on proximal deep vein thrombosis in patients who had major orthopedic surgery. Six trials were included in this analysis with the trial by Comp and colleagues including two separate comparisons presented individually here. The first trial by Eriksson and colleagues in 2003 provided a relative risk of 0.06 with a 95 percent confidence interval of 0.02 to 0.21. The second trial by Prandoni and colleagues in 2002 provided relative risk of 0.32 with a 95 percent confidence interval of 0.05 to 2.20. The third trial by Comp and colleagues in 2001 provided two separate comparisons. The first comparison provided a relative risk of 0.21 with a 95 percent confidence interval of 0.09 to 0.48. The second comparison provided a relative risk of 0.54 with a 95 percent confidence interval of 0.25 to 1.16. The fourth trial by Lassen and colleagues in 1998 provided a relative risk of 0.18 with a 95 percent confidence interval of 0.03 to 1.15. The fifth trial by Nilsson and colleagues in 1997 provided a relative risk of 0.29 with a 95 percent confidence interval of 0.14 to 0.59. The sixth trial by Planes and colleagues in 1997 provided a relative risk of 0.74 with a 95 percent confidence interval of 0.26 to 2.12. The combined effect of the six trials showed a relative risk of 0.29 with a 95 percent confidence interval of 0.16 to 0.52. The I-squared value was 48.1 percent and the Egger's p-value was 0.507

The trial by Dahl and colleagues randomized patients who had total hip replacement surgery to continue dalteparin for a total of 35 days versus placebo until day 35 after seven days of prophylaxis with dalteparin, dextran, and graduated compression stockings.122 In this trial the risk of proximal deep vein thrombosis was not significantly different [RR 0.65 (0.31 to 1.38)] in patients who received prolonged prophylaxis versus standard duration prophylaxis.

When limiting the original analysis to trials published from 2001-present, three trials remained.121,124,131 In patients who received prolonged prophylaxis versus standard duration prophylaxis the risk of proximal deep vein thrombosis was significantly decreased [RR 0.23 (0.08 to 0.61), NNT 8 to 57] (Appendix G Figure 233). A higher level of statistical heterogeneity was detected (I^2^=65.5 percent). When limiting the original analysis to total hip replacement surgery five trials remained.121,126,127,131,198 In patients who received prolonged prophylaxis versus standard duration prophylaxis the risk of proximal deep vein thrombosis was significantly decreased [RR 0.30 (0.19 to 0.49), NNT 7 to 72] (Appendix G Figure 234). Statistical heterogeneity was not detected (I^2^=0 percent). When limiting the original analysis to total knee replacement surgery one comparison from the trial by Comp and colleagues remained.121 In this comparison, in patients who received prolonged prophylaxis versus standard duration prophylaxis the risk of proximal deep vein thrombosis was not significantly different [RR 0.54 (0.25 to 1.16)]. When limiting the original analysis to hip fracture surgery one trial remained.124 In this trial, in patients who received prolonged prophylaxis versus standard duration prophylaxis the risk of proximal deep vein thrombosis was significantly decreased [RR 0.06 (0.02 to 0.21), NNT 7].

##### Distal Deep Vein Thrombosis

Four randomized controlled trials evaluated the effect of prolonging prophylaxis for 28 days or longer compared with prophylaxis for 7 to 10 days on distal deep vein thrombosis in patients who had major orthopedic surgery.121,124,126,127 The trial by Comp and colleagues included two separate comparisons based on the surgery type (total hip replacement and total knee replacement).121 In patients who received prolonged prophylaxis versus standard duration prophylaxis the risk of distal deep vein thrombosis was not significantly different [RR 0.39 (0.15 to 1.04)] (Appendix G Figure 235). A higher statistical heterogeneity was detected as was the presence of publication bias (I^2^ =83.6 percent, Egger's p-value=0.023). Publication bias suggests that larger trials with decreased risk and smaller trials with increased risk of distal deep vein thrombosis were omitted.

When limiting the original analysis to trials published from 2001-present, two trials remained with the trial by Comp and colleagues contributing two separate comparisons.121,124 In patients who received prolonged prophylaxis versus standard duration prophylaxis the risk of distal deep vein thrombosis was not significantly different [RR 0.33 (0.07 to 1.51)] (Appendix G Figure 236). Statistical heterogeneity could not be evaluated because of too few studies. When limiting the original analysis to total hip replacement surgery three trials remained.121,126,127 In patients who received prolonged prophylaxis versus standard duration prophylaxis the risk of distal deep vein thrombosis was not significantly different [RR 0.53 (0.24 to 1.17)] (Appendix G Figure 237). A higher level of statistical heterogeneity was detected (I^2^=53.4 percent). When limiting the original analysis to total knee replacement surgery one comparison from the trial by Comp and colleagues remained.121 In this comparison, in patients who received prolonged prophylaxis versus standard duration prophylaxis the risk of distal deep vein thrombosis was not significantly different [RR 1.09 (0.67 to 1.78)]. When limiting the original analysis to hip fracture surgery one trial remained.124 In this trial, in patients who received prolonged prophylaxis versus standard duration prophylaxis the risk of distal deep vein thrombosis was significantly decreased [RR 0.02 (0.004 to 0.14), NNT 6].

##### Major Bleeding

Five randomized controlled trials evaluated the effect of prolonging prophylaxis for 28 days or longer compared with prophylaxis for 7 to 10 days on major bleeding in patients who had major orthopedic surgery.121,124,127,131,198 The trial by Comp and colleagues included two separate comparisons based on the surgery type (total hip replacement and total knee replacement).121 One trial and one comparison in total hip replacement surgery by Comp and colleagues were excluded from the analysis because no events occurred in the groups compared.121,127 In patients who received prolonged prophylaxis versus standard duration prophylaxis the odds of major bleeding were not significantly different [OR 2.18 (0.73 to 6.51)] (Appendix G Figure 238). A lower statistical heterogeneity was detected and the presence of publication bias was not detected (I^2^=35.6 percent, Egger's p-value=0.334).

When limiting the original analysis to trials published from 2001-present, three trials remained with the trial by Comp and colleagues contributing two separate comparisons.121,124,131 The comparison in total hip replacement surgery by Comp and colleagues was excluded from the analysis because no events occurred in the groups compared. In patients who received prolonged prophylaxis versus standard duration prophylaxis the odds of major bleeding were not significantly different [OR 2.76 (0.88 to 8.61)] (Appendix G Figure 239). A lower level of statistical heterogeneity was detected (I^2^=22.3 percent). When limiting the original analysis to total hip replacement surgery four trials remained.121,127,131,198 Two trials were excluded from the analysis because no events occurred in the groups compared.121,127 In patients who received prolonged prophylaxis versus standard duration prophylaxis the odds of major bleeding were not significantly different [OR 0.98 (0.06 to 15.70)] (Appendix G Figure 240). Statistical heterogeneity could not be evaluated because of too few studies. When limiting the original analysis to total knee replacement surgery one comparison from the trial by Comp and colleagues remained.121 In this comparison, in patients who received prolonged prophylaxis versus standard duration prophylaxis the odds of major bleeding were not significantly different [OR 0.14 (0.003 to 6.95)]. When limiting the original analysis to hip fracture surgery one trial remained.124 In this trial, in patients who received prolonged prophylaxis versus standard duration prophylaxis the odds of major bleeding were not significantly different [OR 3.40 (0.98 to 11.84)].

##### Major Bleeding Leading to Reoperation

One randomized controlled trial evaluated the effect of prolonging prophylaxis for 28 days or longer compared with prophylaxis for 7 to 10 days on major bleeding leading to reoperation in patients who had major orthopedic surgery.124 In this trial by Eriksson and colleagues in 2003, patients who had hip fracture surgery were randomized to receive either fondaparinux prophylaxis for 25 to 31 days or fondaparinux prophylaxis for 6 to 8 days after surgery. In patients who received prolonged prophylaxis versus standard duration prophylaxis the odds of major bleeding leading to reoperation were not significantly different [OR 1.01 (0.14 to 7.18)]. Subgroup analysis was not possible because there was only one study available.

##### Minor Bleeding

Three randomized controlled trials evaluated the effect of prolonging prophylaxis for 28 days or longer compared with prophylaxis for 7 to 10 days on minor bleeding in patients who had major orthopedic surgery.124,127,198 In patients who received prolonged prophylaxis versus standard duration prophylaxis the odds of minor bleeding were significantly increased [OR 2.44 (1.41 to 4.20), NNH 11 to 118] (Figure 15). Statistical heterogeneity was not detected while publication bias not could be evaluated because of too few studies (I^2^=0 percent).

Figure 15 Impact of prolonged prophylaxis versus standard duration of prophylaxis on minor bleeding in patients who had major orthopedic surgery

I^2^: 0 percent.

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of prolonged prophylaxis versus standard duration of prophylaxis on minor bleeding in patients who had major orthopedic surgery. Three trials were included in this analysis. The first trial by Eriksson and colleagues in 2003 provided an odds ratio of 2.39 with a 95 percent confidence interval of 0.54 to 10.59. The second trial by Lassen and colleagues in 1998 provided an odds ratio of 1.72 with a 95 percent confidence interval of 0.80 to 3.71. The third trial by Planes and colleagues in 1997 provided an odds ratio of 3.98 with a 95 percent confidence interval of 1.61 to 9.88. The combined effect of the three trials showed an odds ratio of 2.44 with a 95 percent confidence interval of 1.41 to 4.20. The I-squared value was zero percent.

When limiting the original analysis to trials published from 2001-present, one trial remained.124 In patients who received prolonged prophylaxis versus standard duration prophylaxis the odds of minor bleeding were not significantly different [OR 2.39 (0.54 to 10.59)]. When limiting the original analysis to total hip replacement surgery two trials remained.127,198 In patients who received prolonged prophylaxis versus standard duration prophylaxis the odds of minor bleeding were significantly increased [OR 2.44 (1.36 to 4.39), NNH 11 to 20] (Appendix G Figure 241). Statistical heterogeneity could not be evaluated because of too few studies. Subgroup analysis based on total knee replacement surgery could not be evaluated because no trials evaluated this surgical population. When limiting the original analysis to hip fracture surgery one trial remained.124 In this trial, in patients who received prolonged prophylaxis versus standard duration prophylaxis the odds of minor bleeding were not significantly different [OR 2.39 (0.54 to 10.59)].

##### Surgical Site Bleeding

One randomized controlled trial evaluated the effect of prolonging prophylaxis for 28 days or longer compared with prophylaxis for 7 to 10 days on surgical site bleeding in patients who had major orthopedic surgery.124 In this trial by Eriksson and colleagues in 2003, patients who had hip fracture surgery were randomized to receive either fondaparinux prophylaxis for 25 to 31 days or fondaparinux prophylaxis for 6 to 8 days after surgery. In patients who received prolonged prophylaxis versus standard duration prophylaxis the odds of surgical site bleeding were significantly increased [OR 7.55 (1.51 to 37.64)]. The number needed to harm could not be calculated because the control event rate was zero. Subgroup analysis was not possible because there was only one study available.

##### Bleeding Leading to Infection

No randomized controlled trials or controlled observational studies evaluated the effect of prolonging prophylaxis for 28 days or longer compared with prophylaxis for 7 to 10 days in patients who had major orthopedic surgery on this outcome.

##### Bleeding Leading to Transfusion

Two randomized controlled trials evaluated the effect of prolonging prophylaxis for 28 days or longer compared with prophylaxis for 7 to 10 days on bleeding leading to transfusion in patients who had major orthopedic surgery.124,127 One trial by Planes and colleagues was excluded from the analysis because no events occurred in the groups compared, leaving one trial for the analysis. In this trial by Eriksson and colleagues in 2003, patients who had hip fracture surgery were randomized to receive either fondaparinux prophylaxis for 25 to 31 days or fondaparinux prophylaxis for 6 to 8 days after surgery. In this trial, the risk of bleeding leading to transfusion was not significantly different [RR 1.46 (0.85 to 2.51)] in patients who received prolonged prophylaxis versus standard duration prophylaxis. Subgroup analyses were not possible since only one trial with events was available.

##### Heparin-Induced Thrombocytopenia

No randomized controlled trials or controlled observational studies evaluated the effect of prolonging prophylaxis for 28 days or longer compared with prophylaxis for 7 to 10 days in patients who had major orthopedic surgery on this outcome.

##### Discomfort

No randomized controlled trials or controlled observational studies evaluated the effect of prolonging prophylaxis for 28 days or longer compared with prophylaxis for 7 to 10 days in patients who had major orthopedic surgery on this outcome.

##### Readmission

One randomized controlled trials evaluated the effect of prolonging prophylaxis for 28 days or longer compared with prophylaxis for 7 to 10 days on readmission in patients who had major orthopedic surgery.121 This trial by Comp and colleagues in 2001 included two separate comparisons based on the surgery type (total hip replacement and total knee replacement). When pooling these two comparisons, in patients who had major orthopedic surgery and received prolonged prophylaxis versus standard duration prophylaxis the risk of readmission was not significantly different [RR 0.29 (0.06 to 1.34)] (Appendix G Figure 242). Patients were randomized to receive enoxaparin prophylaxis for 7 to 10 days versus enoxaparin prophylaxis for 28 to 31 days. In patients who had total hip replacement surgery and received prolonged prophylaxis versus standard duration prophylaxis the risk of readmission was significantly decreased [RR 0.13 (0.04 to 0.39), NNT 12 to 23]. In patients who had total knee replacement surgery and received prolonged prophylaxis versus standard duration prophylaxis the risk of readmission was not significantly different [RR 0.59 (0.24 to 1.44)]. Subgroup analyses based on hip fracture surgery was not possible since no trials evaluated this surgical population.

##### Reoperation

One randomized controlled trials evaluated the effect of prolonging prophylaxis for 28 days or longer compared with prophylaxis for 7 to 10 days on reoperation in patients who had major orthopedic surgery.118 This trial by Andersen and colleagues in 1997 evaluated patients who had total hip replacement surgery and received dalteparin prophylaxis for 5 to 7 days versus dalteparin prophylaxis for 35 days. In patients who received prolonged prophylaxis versus standard duration prophylaxis the risk of reoperation was not significantly different [RR 0.21 (0.02 to 2.16)]. Subgroup analyses were not possible as only one trial was available.

#### Strength of Evidence and Applicability of the Body of Evidence

Relative to other Key Questions evaluating prophylaxis in major orthopedic surgery, Key Question 8 had the highest overall strength of evidence for outcomes evaluated. Overall there is a better comparative balance of benefits to harms for prolonging prophylaxis. There was high strength of evidence that prolonged prophylaxis decreased the risk of pulmonary embolism, asymptomatic or symptomatic or proximal deep vein thrombosis, moderate strength of evidence that prolonged prophylaxis decreased the risk of symptomatic objectively confirmed venous thromboembolism, deep vein thrombosis, and the odds of nonfatal pulmonary embolism. There was low strength of evidence that there was no difference in the risk of distal deep vein thrombosis, readmission or odds of major bleeding. The one harm which had high strength of evidence was the risk of minor bleeding, which was increased with prolonged prophylaxis. Other outcomes were rated as insufficient.

Overall applicability was often limited because one or two of the major orthopedic surgeries were not evaluated, duration of followup was inadequate to evaluate the given outcome, and many trials were conducted outside of the United States and sometimes represented a majority of the available data. The main limitation to the overall applicability was the lack of variety of pharmacologic classes evaluated. Almost all trials compared shorter versus longer term use of low molecular weight heparins and therefore, the applicability to other classes is limited. Often the majority of trials were conducted outside of the United States.

## Key Question 9

In patients undergoing major orthopedic surgery (total hip or knee replacement, hip fracture surgery) who have known contraindications to antithrombotic agents, what is the relative impact of prophylactic inferior vena cava filter placement compared with any external mechanical intervention on symptomatic objectively confirmed venous thromboembolism, major venous thromboembolism (proximal deep vein thrombosis, pulmonary embolism or venous thromboembolism related mortality), pulmonary embolism, fatal pulmonary embolism, nonfatal pulmonary embolism, post thrombotic syndrome, mortality, mortality due to bleeding, deep vein thrombosis (asymptomatic or symptomatic, proximal or distal deep vein thrombosis), asymptomatic deep vein thrombosis, symptomatic deep vein thrombosis, proximal deep thrombosis, distal deep vein thrombosis, major bleeding, major bleeding leading to reoperation, minor bleeding, surgical site bleeding, bleeding leading to infection, bleeding leading to transfusion, heparin induced thrombocytopenia, discomfort, readmission, reoperation, and inferior vena cava filter placement associated insertion site thrombosis?

No randomized controlled trials or controlled observational studies met our inclusion criteria for this Key Question and therefore all outcomes were rated as insufficient strength of evidence.

## Key Question 10

In patients requiring knee arthroscopy, surgical repair of a lower extremity injury distal to the hip, or elective spine surgery what is the relative impact of thromboprophylaxis (any agent, any mechanical intervention) compared with no thromboprophylaxis intervention on symptomatic objectively confirmed venous thromboembolism, major venous thromboembolism (proximal deep vein thrombosis, pulmonary embolism or venous thromboembolism related mortality), pulmonary embolism, fatal pulmonary embolism, nonfatal pulmonary embolism, post thrombotic syndrome, mortality, mortality due to bleeding, deep vein thrombosis (asymptomatic or symptomatic, proximal or distal deep vein thrombosis), asymptomatic deep vein thrombosis, symptomatic deep vein thrombosis, proximal deep thrombosis, distal deep vein thrombosis, major bleeding, major bleeding leading to reoperation, minor bleeding, surgical site bleeding, bleeding leading to infection, bleeding leading to transfusion, heparin induced thrombocytopenia, discomfort, readmission, and reoperation?

### Key Points

- There is a relative paucity of data comparing prophylactic strategies to no prophylaxis in patients undergoing knee arthroscopy, surgical repair of a lower extremity injury distal to the hip, or elective spine surgery.
  ○ No randomized controlled trial or controlled observational studies evaluating elective spine surgery met inclusion criteria.
  ○ One trial evaluated the injectable low molecular weight heparin dalteparin versus placebo for 6 weeks in patients who had Achilles tendon rupture surgery. There were no significant differences in the occurrence of deep vein thrombosis or proximal deep vein thrombosis at 6 weeks. No patients presented with clinical pulmonary emboli or had episodes of major bleeding.
  ○ One trial evaluated the injectable low molecular weight heparin dalteparin versus control for up to 30 days in patients who had arthroscopic knee surgery. Significantly fewer patients who received dalteparin developed a deep vein thrombosis or distal deep vein thrombosis. None of the deep vein thromboses were proximal. One patient in the dalteparin group developed a pulmonary embolism and also had a deep vein thrombosis. No patients had major bleeding and the occurrence of minor bleeding was not significantly different between the two groups.

### Detailed Analysis

#### Study Design and Characteristics

Two randomized controlled trials (N=235) and no controlled observational studies evaluated the impact of prophylaxis versus no prophylaxis on final, intermediate, or adverse health outcomes. 191,192 The first trial by Lapidus and colleagues in 2007 enrolled patients who had Achilles tendon rupture surgery and randomized patients to receive the injectable low molecular weight heparin dalteparin versus placebo injections for 6 weeks.192 This trial was published as a full text manuscript and was funded by industry and government/foundation. The mean age of enrolled patients ranged from 37 to 42 years and females represented 21 percent of the enrolled population. The mean weight ranged from 80 to 81 kilograms; obesity was not reported. None of the patients had a history of venous thromboembolism and 5.8 to 11.3 percent of patients had the presence of varicosity. The history of malignancy or prior orthopedic surgery was not reported. The mean duration of surgery ranged from 44 to 45 minutes and 100 percent of participants received regional anesthesia. Tourniquet use was reported in 11.3 to 11.5 percent of patients. As this was an outpatient procedure patients were not hospitalized.

The second trial by Michot and colleagues in 2002 enrolled patients who had diagnostic or therapeutic arthroscopic knee surgery and were randomized to receive the injectable low molecular weight heparin dalteparin versus control for 30 days.191 Diagnostic procedures were performed in 17 to 18 percent of patients while the majority of patients underwent therapeutic procedures (73 percent). Of the therapeutic procedures included, partial meniscectomy represented the majority of procedures (73.4 to 79.2 percent). The trial was published as a full text manuscript and the funding source was not disclosed. The mean age of enrolled patients ranged from 42.0 to 46.5 years and females represented 28.1 to 39.4 percent of the enrolled population. Mean body mass index was reported and ranged from 26.2 to 27.8 kilograms per meter squared. The presence of varicosity was reported in 12.1 to 14.1 percent of patients. The use of general anesthesia ranged from 29.7 to 33.3 percent, regional anesthesia ranged from 66.7 to 70.3 percent, and the use of both types of anesthesia ranged from 3.0 to 3.1 percent of the enrolled population. No other surgical characteristics were reported. As this was an outpatient procedure patients were not hospitalized.

#### Outcome Evaluations

##### Achilles Tendon Rupture Surgery

One trial by Lapidus and colleagues enrolled 105 patients who had Achilles tendon rupture surgery and randomized patients to receive dalteparin 5,000 units subcutaneously every day (n=52) or placebo saline injections daily (n=53) for six weeks.192 After surgery, a below-knee plaster cast was applied in all patients and was replaced by another plaster cast or orthosis at three weeks at which time full weight bearing was allowed. Followup visits were scheduled at three and six weeks at which time patients were screened clinically for signs and symptoms of deep vein thrombosis and pulmonary embolism and underwent unilateral color duplex sonography. Venography was used to confirm cases of deep vein thrombosis identified with sonography or when sonography was inconclusive.

In this trial, in patients who received dalteparin prophylaxis versus placebo, the risk of deep vein thrombosis (distal or proximal) was not significantly different at the sixth postoperative week (36.7 percent versus 40.4 percent, p=0.80). The same result was seen when evaluating proximal deep vein thrombosis (2.0 percent versus 6.4 percent, p=0.60). No patients presented with clinical signs or symptoms of pulmonary embolism during the followup period and no patients had major bleeding which was defined as bleeding requiring blood transfusion or into a critical organ (intraocular, intracranial, intraspinal or retroperitoneal).

##### Knee Arthroscopy

One trial by Michot and colleagues enrolled 130 patients who had diagnostic or therapeutic arthroscopic knee surgery and randomized patients to receive dalteparin subcutaneous injections daily (n=66) versus control (n=64) up to 30 days postoperatively.191 All patients received dalteparin 2,500 units 60 to 120 minutes prior to the start of surgery and subsequent dosing was weight based; 2500 units daily if weighing less than or equal to 70 kilograms and 5,000 units daily if weighting greater than 70 kilogram. Concomitant therapy with antiplatelet or anticoagulant therapy was not permitted. Patients were instructed to bear weight immediately after the surgery or as tolerated on crutches for 24 to 48 hours. Followup visits were scheduled on postoperative days 12 and 31 at which time patients were clinically examined for signs and symptoms of deep vein thrombosis, pulmonary embolism and adverse events. Bilateral compression ultrasonography was performed during these followup visits and venography was performed if ultrasonography was inconclusive. Patients were also instructed to report clinical signs earlier if they occurred, and physicians followed up by telephone every four days in patients who were randomized to dalteparin in between followup visits. Symptoms of deep vein thrombosis were confirmed with ultrasonography or venography and symptoms of pulmonary embolism were confirmed with ventilation-perfusion scans or angiography.

In this trial, the percent of patients with deep vein thrombosis was significantly decreased in those who received dalteparin prophylaxis versus control (1.5 percent versus 15.6 percent, p=0.004). All deep vein thromboses were distal and occurred in the operated leg while none were proximal or in the contralateral leg. Eight cases of deep vein thromboses were diagnosed at the first followup visit, 2 cases were diagnosed during the second followup visit, and 1 case was diagnosed on postoperative day 5 in the emergency room. Gender did not impact the effect of dalteparin versus placebo on the occurrence of deep vein thrombosis. One patient in the dalteparin group, who also had a distal deep vein thrombosis, developed a pulmonary embolism (1.5 percent) while none in the control group developed a pulmonary embolism (0 percent). No patients had major bleeding. There was no significant difference in the percent of patients who had minor bleeding in the dalteparin group versus control (12 percent versus 6 percent, p=0.365).

#### Strength of Evidence and Applicability of the Body of Evidence

In other orthopedic surgeries evaluated in this report, there were two trials which met inclusion criteria for Key Question 10; one trial in knee arthroscopy, one trial in Achilles tendon rupture repair, and no trials in elective spine surgery. Therefore the overall strength of evidence was insufficient for all outcomes evaluated in these patient populations. The applicability is limited because only two trials were identified and therefore applicability is specific to the surgeries and interventions of these trials.

## Key Question 11

In patients requiring knee arthroscopy, surgical repair of a lower extremity injury distal to the hip, or elective spine surgery what is the relative impact of injectable antithrombotic agents (injectable low molecular weight heparin versus unfractionated heparin versus factor Xa inhibitors versus direct thrombin inhibitors) compared with mechanical interventions on symptomatic objectively confirmed venous thromboembolism, major venous thromboembolism (proximal deep vein thrombosis, pulmonary embolism or venous thromboembolism related mortality), pulmonary embolism, fatal pulmonary embolism, nonfatal pulmonary embolism, post thrombotic syndrome, mortality, mortality due to bleeding, deep vein thrombosis (asymptomatic or symptomatic, proximal or distal deep vein thrombosis), asymptomatic deep vein thrombosis, symptomatic deep vein thrombosis, proximal deep thrombosis, distal deep vein thrombosis, major bleeding, major bleeding leading to reoperation, minor bleeding, surgical site bleeding, bleeding leading to infection, bleeding leading to transfusion, heparin induced thrombocytopenia, discomfort, readmission, and reoperation?

No randomized controlled trials or controlled observational studies met our inclusion criteria for this Key Question and therefore all outcomes were rated as insufficient strength of evidence.