# Peer Reviewers

Olivia J. Phung, Pharm.D.

Western University of Health Sciences

Pomona, CA

Sarah Spinler, Pharm.D., F.C.C.P., F.A.H.A., B.C.P.S. (AQ Cardiology)

University of the Sciences in Philadelphia

Philadelphia, PA

Paul Lotke, M.D.

Hospital of the University of Pennsylvania

Philadelphia, PA