# Methods

## Input From Stakeholders

The Evidence-based Practice Center drafted a topic refinement document with proposed Key Questions after consult with Key Informants. Our Key Informants included eight physicians: three provided the orthopedic surgeon's perspective one of which was a local expert, one provided a local pulmonologist's perspective, two provided expertise in methodology/guideline development, one provided a hematologist's perspective, and one provided expertise in health policy. There was equal representation from both the American College of Chest Physicians and the American Academy of Orthopedic Surgeons (three members each). Our Key Informants did not have financial or other declared conflicts. The public was invited to comment on the topic refinement document and Key Questions. After reviewing the public commentary, responses to public commentary, proposed revisions to the Key Questions, and a preliminary protocol was generated and reviewed with the Technical Expert Panel. The aforementioned Key Informants constituted our Technical Expert Panel and provided feedback on the feasibility and importance of our approach and provided their unique insight. Again, no conflict of interest was identified. The draft CER report underwent peer review and public commentary and revisions were made before finalizing the report.

## Searching for the Evidence

Two independent investigators conducted systematic literature searches in July 2010 of Medline, The Cochrane Central Register of Controlled Trials, and Scopus from 1980 to the July 2010. The restriction of 1980 was used to reflect contemporary practice. Language restrictions were not imposed and professional translation services were utilized when necessary. Two separate searches of these databases were conducted and the complete search strategies are included in Appendix A. The first search was used to identify studies which evaluated pharmacologic, mechanical, or inferior vena cava filter methods of thromboprophylaxis in patients undergoing major orthopedic surgery, described the association between patient, surgical, or postsurgical characteristics and venous thromboembolism or bleeding, or described the association between intermediate and final health outcomes to answer Key Questions 1 through 9. The second search was used to identify studies which evaluated pharmacologic or mechanical methods of thromboprophylaxis in patients undergoing knee arthroscopy, surgical repair of a lower extremity injury distal to the hip or elective spine surgery to answer Key Questions 10 and 11. A manual search of references of clinical trials, meta-analyses, and systematic reviews was conducted. A grey literature search of regulatory documents, abstracts, and ongoing clinical trials was conducted by the Scientific Resource Center and reviewed by two independent investigators for inclusion into our literature base by applying the same a priori defined inclusion criteria defined below. The literature search was updated in May 2011 using the same search strategy.

## Inclusion and Exclusion Criteria

Two independent investigators assessed studies for inclusion in a parallel manner based on a priori defined criteria. In evaluating all Key Questions, randomized controlled trials of any size or controlled observational trials (case-controlled or cohort studies) enrolling ≥ 750 patients were included if they explicitly reported the use of imagining studies to confirm venous thromboembolic events (Doppler ultrasound or venography for deep vein thrombosis and spiral computed tomography angiography or ventilation/perfusion scan with either Prospective Investigation of Pulmonary Embolism Diagnosis (PIOPED) criteria or high clinical suspicion based on symptoms for pulmonary embolism.11,12 Observational studies that enrolled <750 subjects were excluded because numerous RCTs in this literature base enroll over 500 participants, with the most contemporary trials enrolling over 1,000 participants. Therefore observational studies would need to be of larger size to provide additional valuable information on outcomes of interest and applicability. Studies were included if the pharmacologic thromboprophylaxis agent to which patients were randomized had Food and Drug Administration approval for any indication and mechanical thromboprophylactic devices to which patients were randomized were available for use in the United States.

Additional inclusion criteria for the evaluation of Key Question 1 were (1) studies which included only patients undergoing major orthopedic surgery (total hip or knee replacement or hip fracture surgery) or reported separate results for these major orthopedic surgeries; (2) studies which compared pharmacologic or mechanical methods of thromboprophylaxis with placebo or control without off protocol use of pharmacologic or mechanical methods of prophylaxis or studies included in other Key Questions which included a placebo or control arm without off protocol use of pharmacologic or mechanical methods of prophylaxis; and (3) reported data on at least one prespecified venous thromboembolic or bleeding outcome.

Additional inclusion criteria for the evaluation of Key Question 2 were (1) studies which included only patients undergoing major orthopedic surgery (total hip or knee replacement or hip fracture surgery) or reported separate results for these major orthopedic surgeries; and (2) described the association of patient, surgical or postsurgical characteristics and prespecified venous thromboembolic or bleeding outcomes. Studies were included only if adjustments were made for confounding factors (multivariable regression, randomization, or propensity score matching).

Additional inclusion criteria for the evaluation of Key Question 3 were (1) studies which included only patients undergoing major orthopedic surgery (total hip or knee replacement or hip fracture surgery) or reported separate results for these major orthopedic surgeries and (2) studies which reported data on both pulmonary embolism (asymptomatic or symptomatic) and deep vein thrombosis (asymptomatic or symptomatic). For this Key Question, due to the paucity of data, trials and studies were allowed that did not follow the strict diagnostic inclusion criteria previously identified. For transparency, diagnostic criteria were explained for each study included in the results of this Key Question.

For Key Questions 4 through 9, studies were included if the study reported data on at least one prespecified outcome of interest and included only patients undergoing major orthopedic surgery (total hip or knee replacement or hip fracture surgery) or reported separate results for these major orthopedic surgeries. Additionally, for Key Question 4 only studies which compared pharmacologic or mechanical prophylaxis with placebo or control without the use of off protocol prophylaxis (with the exception of elastic stockings) were included. For Key Question 5, only studies which randomized patients into one pharmacologic or mechanical intervention versus another single intervention were included. For Key Question 7, only studies which randomized patients to a combination of pharmacologic plus mechanical prophylaxis versus one of the interventions alone were included.

Additional inclusion criteria for the evaluation of Key Questions 10 and 11 were (1) studies which included only patients undergoing knee arthroscopy, surgical repair of a lower extremity injury distal to the hip (open reduction internal fixation of the femur, tibia, ankle or foot, intermedullary fixation, ankle fusion, osteotomy of the tibia or femur, open ligament reconstruction of the knee or ankle, and tendon repair) or elective spine surgery (anterior or posterior spinal fusion +/- decompression, laminectomy, or diskectomy all of the lumbar region) or reported separate results for these orthopedic surgeries; (2) compared pharmacologic or mechanical methods of thromboprophylaxis versus control or compared injectable antithrombotic agents (low molecular weight heparin, unfractionated heparin, factor Xa inhibitors, direct thrombin inhibitors) to mechanical interventions; (3) studies which reported data on at least one prespecified outcome of interest.

## Data Extraction and Data Management

Two reviewers used a standardized data extraction tool to independently extract study data with disagreements resolved through discussion. (Appendix B) The following data were collected from each trial when applicable: author identification, year of publication, funding source, study design characteristics and methodological quality criteria, study population (inclusion and exclusion criteria, geographic location, thromboprophylaxis intervention, length of study, duration of patient followup), patient baseline, surgical and postsurgical characteristics (including those which may modify risk of venous thromboembolism or bleeding), thromboprophylaxis regimen (name, strength, dose, frequency, route of administration and duration of therapy for pharmacologic interventions; name, frequency of use, and adherence for mechanical interventions), mobilization status of the patients, use of concurrent standard medical therapies, data needed to assess intermediate and final health outcomes and adverse events, outcome definition, diagnostic test used to confirm outcome of interest, and data reported for subgroups of interest (age, gender, ethnicity). Authors were contacted for clarification or to provide additional data when necessary. If a pharmacologic method of prophylaxis was included in this report on the premise of Food and Drug Administration approval for an indication other than venous thromboembolism prophylaxis, data were extracted for the regimen which most closely resembled that from phase 3 clinical trials.

## Assessment of Methodological Quality of Individual Studies

Validity assessment was performed using the recommendations in the Methods Guide for Comparative Effectiveness Review. Each study was assessed for the following individual criteria: comparable study groups at baseline, detailed description of study outcomes, blinding of outcome assessors, intent-to-treat analysis, description of participant withdrawals (percent followup) and potential conflict of interest. Additionally, randomized controlled trials were assessed for randomization technique and allocation concealment. Observational studies were assessed for sample size, participant selection method, exposure measurement method, potential design biases, and appropriate analyses to control for confounding. Studies were given an overall score of good, fair, or poor in Table 1.

Table 1 Summary of rating of quality of individual studies

Quality Rating | Definition
Good (low risk of bias) | These studies have the least bias and results are considered valid. A study that adheres mostly to the commonly held concepts of high quality include the following: a formal randomized, controlled study; clear description of the population, setting, interventions, and comparison groups; appropriate measurement of outcomes; appropriate statistical and analytic methods and reporting; no reporting errors; less than 20 percent dropout; and clear reporting of dropouts.
Fair | These studies are susceptible to some bias, but it is not sufficient to invalidate results. They do not meet all the criteria required for a rating of good quality because they have some deficiencies, but no flaw is likely to cause major bias. The study may be missing information, making it difficult to assess limitations and potential problems.
Poor (high risk of bias) | These studies have significant flaws that imply biases of various types that may invalidate the results. They have serious errors in design, analysis, or reporting; large amounts of missing information, or discrepancies in reporting.

## Data Synthesis

Key Questions 1 and 2 explore the baseline postoperative risk of venous thromboembolism and bleeding and the patient, surgical, or postsurgical characteristics that predict or differentiate the risk of venous thromboembolism or bleeding in major orthopedic surgery. These questions were answered with studies reflecting contemporary clinical practice (literature published in or after 1980). In Key Question 1, the baseline postoperative risk of venous thromboembolic outcomes was estimated for each of the major orthopedic surgeries separately. Incidences for each outcome were extracted from placebo or control arms of trials and pooled for each major orthopedic surgery. If only one arm was available, the raw incidence of the outcome from the trial was reported. The same was done for bleeding outcomes although arms which allowed the off protocol use of elastic stockings were also include. In Key Question 2, the patient, surgical, and postsurgical characteristics which were analyzed within trials or studies for their impact on venous thromboembolism or bleeding risk were reported and summarized qualitatively.

Key Question 3 explores the link between intermediate and final health outcomes and was qualitatively reported and summarized. From randomized controlled trials, the event rates of both asymptomatic and symptomatic pulmonary embolism and deep vein thrombosis from in patients undergoing major orthopedic surgery with use of the pharmacologic methods of venous thromboembolism prophylaxis were reported. Additionally, results of observational studies which reported predictors of pulmonary embolism were included qualitatively. We would have included any human trial or study that provided insight into the relationship between deep venous thrombosis and pulmonary embolism.

The remaining Key Questions 4 through 11 explore the impact of thromboprophylaxis on final health outcomes, intermediate outcomes, and adverse effects. We qualitatively examined data from all identified studies. The base case analysis for each Key Question was in major orthopedic surgery (total hip replacement, total knee replacement, and hip fracture surgery). For each outcome, we conducted separate analyses of studies comparing each individual thromboprophylactic intervention with placebo or control and studies in which different thromboprophylactic interventions were compared with each other. Key Questions 5 through 9 and 11 explore direct comparisons between or within specified classes and therefore only direct comparison trials were used in their quantitative analysis. In Key Question 6, within class comparisons are made for low molecular weight heparin agents and mechanical prophylaxis modalities. Data from trials will be pooled for like agents when possible and compared with other agents in the class (i.e. one low-molecular weight heparin agent versus others). In Key Questions 10 and 11, trials pertaining to each orthopedic surgery category (knee arthroscopy, surgical repair of lower extremity injuries distal to the hip, and elective spine surgery) were discussed separately due to the paucity of data that met inclusion criteria.

We conducted meta-analyses when two or more trials adequate for pooling were available for any outcome. Randomized controlled trials were pooled but data from observational studies were not. For dichotomous outcomes, weighted averages are reported as relative risks or Peto's odds ratio with associated 95 percent confidence intervals. Peto's odds ratio was chosen over relative risk when the control event rate was exceptionally low (less than 5 percent) and the number of subjects randomized in each group of a trial was similar in the majority of trials within the given analysis.13 As heterogeneity between included studies was expected, a DerSimonian and Laird random-effects model was used when pooling data and calculating relative risks and 95 percent confidence intervals.14 Trials with zero events in both arms were excluded from analyses as they do not provide information on the direction or magnitude of the effect.15 In the event that there was more than one method of thromboprophylaxis being compared with another method of thromboprophylaxis (i.e. low molecular weight heparin versus low molecular weight heparin plus compression stockings versus compression stockings), each method of thromboprophylaxis was compared individually against the other (as a separate trial) by dividing the control group equally between the comparisons.14 The number needed to treat (NNT) or number needed to harm (NNH) was calculated for statistically significant results of the base case analysis for Key Questions 4 through 11. To account for the variability in baseline risk that may be seen in clinical practice, the range of control event rates in the individual trials for a pooled analysis was considered when calculating the NNT and NNH. An equation which utilizes the control event rate and the relative effect estimate was applied to the lowest and highest control event rate in the range and then the NNT and NNH were reported as a range. When a trial with no events was included in the pooled analysis, a range could not be calculated for the NNT or NNH and instead a single value is presented.

Statistical heterogeneity was addressed using the I^2^ statistic (which assesses the degree of inconsistency not due to chance across studies and ranges from 0-100 percent with the higher percentage representing a higher likelihood of the existence of heterogeneity). While categorization of values for I^2^ may not be appropriate in all situations, I^2^ values of less than 50 percent and greater than 50 percent have been regarded as representative of lower and higher levels of statistical heterogeneity, respectively. Egger's weighted regression statistics was used to assess for the presence of publication bias. Statistical analyses were performs using StatsDirect statistical software, version 2.7.8 (StatsDirect Ltd, Cheshire, England). A p-value of <0.05 was considered statistically significant for all analyses.

Subgroup and sensitivity analyses were conducted to assess the effect of heterogeneity (both clinical and methodological) on our meta-analysis' conclusions. For Key Questions 1 through 9, in the events that the base case analysis for a Key Question was in major orthopedic surgery (total hip or knee replacement or hip fracture surgery) subgroup analyses in total hip replacement, total knee replacement and hip fracture surgery were conducted. Additional subgroup analyses included publication year (prior to 2001 versus 2001-present, with present defined as May 2011), gender, ethnicity and age. In Key Question 4, subgroup analysis was conducted on trials which compared an active intervention with placebo or control without off protocol use of elastic stockings, which is referred to as “true placebo” in this report.

## Grading the Strength of the Evidence

We used the Evidence-based Practice Center Grading of Recommendations Assessment, Development guide to assess the strength of evidence.16 This system uses four required domains; risk of bias, consistency, directness, and precision. Risk of bias is the degree to which the included studies for any given outcome or comparison has a high likelihood of adequate protection against bias. This can be assessed through the evaluation of both design and study limitations. For study design, whether the study was a randomized controlled trial or an observational study was recorded. Studies were ranked as having no limitations, serious limitations, or very serious limitations. Consistency refers to the degree of similarity in the direction of the effect sizes from included studies within an evidence base. We assessed whether or not the effect sizes were on the same side of unity, whether the range of effect sizes was narrow, and the degree of statistical heterogeneity in evaluating consistency. We ranked this domain as no inconsistency, serious inconsistency, and very serious inconsistency. When only a single study is included, consistency cannot be judged. Directness refers to whether the evidence links the compared interventions directly with health outcomes, and compares two or more interventions in head-to-head trials. Indirectness implies that more than one body of evidence is required to link interventions to the most important health outcomes. We ranked this domain as no indirectness, serious indirectness, and very serious indirectness. Precision refers to the degree of certainty surrounding an effect estimate with respect to a given outcome. For example, when a meta-analysis is performed, we evaluated the confidence interval around the summary effect size. A precise estimate is an estimate that would allow a clinically useful conclusion. An imprecise estimate is one for which the confidence interval is wide enough to include clinically distinct conclusions (e.g. both clinically important superiority and inferiority), a circumstance that will preclude a conclusion. Additional optional domains were not determined to be necessary and were not utilized.

All assessments were made by two investigators with disagreements resolved through discussion. The evidence pertaining to each Key Question was classified into four broad categories; high, moderate, low or insufficient. In Table 2 we describe in more detail the features that determined the strength of evidence for the different outcomes evaluated in this report.

Table 2 Definitions for grading the strength of evidence

Grade | Definition
High | There is high confidence that the evidence reflects the true effect. Further research is very unlikely to change our confidence in the estimate of effect.
Moderate | Moderate confidence that the evidence reflects the true effect. Further research may change our confidence in the estimate of effect and may change the estimate.
Low | Low confidence that the evidence reflects the true effect. Further research is likely to change our confidence in the estimate of effect and is likely to change the estimate.
Insufficient | Evidence either is unavailable or does not permit estimation of an effect.

## Evaluating the Applicability of the Evidence

Effectiveness studies met five of the following seven criteria: enrolled an orthopedic surgery population, used less stringent eligibility criteria, assessed final health outcomes, allowed for adequate study duration with clinically relevant treatment modalities, assessed adverse events, had an adequate sample size, and used intention to treat analysis.17 Studies which met less than five criteria were classified as efficacy trials and were deemed to have less applicability. In addition, factors identified in Table 3 were important when determining applicability and were extracted into evidence tables for every study. Given these inputs, the applicability of each study was determined as was the applicability for the body of evidence for the base case analysis of each comparison within a Key Question.

Table 3 Applicability considerations and data extracted

Feature | Condition That Limits Applicability | Features To Be Extracted Into Evidence Table
Population | Differences between patients in study and the community | Eligibility criteria, demographics
Population | Events rates markedly different than in community | Event rates in treatment and control groups
Intervention | Treatment not reflective of current practice | Complete regimen of thromboprophylactic intervention (pharmacologic, mechanical, or IVC filter)
Comparator | Use of substandard alternative therapy | Type of comparator
Outcomes | Surrogate endpoints, brief followup periods, improper definitions for outcomes, composite endpoints | Outcomes (benefits and harms) and how they were defined and diagnosed
Settings | Settings where standards of care differ markedly from setting of interest | Clinical Setting and geographic setting