# Future Research

## Limitations of Current Research

- In total hip replacement, total knee replacement, and hip fracture surgery there are numerous limitations to the current literature base that need to be appreciated.
  ○ While we found that there is a real risk of developing deep vein thrombosis, pulmonary embolism, and major bleeding after undergoing major orthopedic surgery, there are inadequate data to say whether or not deep vein thrombosis causes pulmonary embolism. We were not even able to determine that deep vein thrombosis is an independent predictor of pulmonary embolism. With prophylaxis to prevent deep vein thrombosis and pulmonary embolism and the use of active treatment of deep vein thrombosis to prevent pulmonary embolism, it is difficult to assess this linkage. In addition, we had no data to assess the linkage between deep vein thrombosis and other final health outcomes. This creates a dilemma for patients, healthcare decision makers, and clinicians when the endpoint most commonly evaluated in the prophylaxis trials is deep vein thrombosis.
  ○ In many studies a more specific duration of followup beyond “postoperative” was unclear and may be implied as a more immediate postoperative followup rather than a longer term followup. It is unclear whether the period of highest risk for outcomes is inclusive in “postoperative” followup. Few trials reported a longer term followup such as postdischarge.
  ○ Other than showing the superiority in the balance of benefits to harms for low molecular weight heparins versus unfractionated heparin, whether one class is superior to another class cannot be clearly determined. In a few cases, there are offsetting benefit and harms effects and in many cases, there just is not ample evidence to assess. While it seems that low molecular weight heparins (enoxaparin, dalteparin, tinzaparin) have similar effects, we cannot determine if an agent within any other class is superior to another agent within the same class.
  ○ The large variety and number of mechanical devices makes it hard to know how data can be extrapolated from one device to others in the same or different classes. Mechanical device trials are by and large devoid of harms evaluations.
  ○ We cannot discern the comparative benefits and harms of using both pharmacologic and mechanical prophylaxis versus either modality alone.
  ○ Further research is needed to determine independent predictors of intermediate, final health, and harms outcomes. Current literature is too scant to reliably determine the impact of surgical or patient characteristics on these outcomes.
  ○ We could not determine the comparative benefits and harms of using inferior vena cava filters with mechanical prophylaxis in major orthopedic surgery as no literature met our inclusion criteria.
- When we assess orthopedic surgeries other than total hip replacement, total knee replacement or hip fracture surgery, we do not have an adequate literature base to determine benefits or harms.

## Future Research Avenues

- In total hip replacement, total knee replacement, and hip fracture surgery there are several avenues for future research:
  ○ Since the linkage between deep vein thrombosis and venous thromboembolism, pulmonary embolism, postthrombotic syndrome, or mortality has not been shown, future comparative trials should focus on these final health outcomes or should explicitly show the linkage between deep vein thrombosis and these final health outcomes. It would not be sufficient just to show a correlation between these outcomes.
  ○ Future trials evaluating prophylaxis within major orthopedic surgery should more clearly define the period of followup and include a followup period beyond the hospital stay to include the period of highest risk for final health outcomes.
  ○ Future trials evaluating prophylaxis within major orthopedic surgery should include more outcomes assessing harms such as bleeding leading to infection, bleeding leading to transfusion, readmission and reoperation to provide more information for the comparative balance of benefits to harms. Additionally patient important outcomes such as health related quality of life and post thrombotic syndrome should be included.
  ○ Future observational studies should be designed to determine if there are surgical or patient factors that predict the occurrence of these outcomes. We have identified several promising predictors but need future evaluations to help determine their importance.
    – For regional versus general surgery, an adequately powered randomized controlled trial is needed to determine if anesthesia type impacts patient outcomes.
  ○ Future within class and between class comparative trials are needed. In several classes, both oral and intravenous methods of pharmacologic prophylaxis will be available and should be directly evaluated. More attention to assessing for final health outcomes and harms will be needed in these trials. Especially given the benefits of prolonged prophylaxis versus short term prophylaxis, the impact of oral therapy on patient perceived quality of life will be an important endpoint to consider. If a greater number of between class trials are conducted, mixed treatment comparison meta-analyses could be conducted to assess for indirect comparisons but presently, the literature base seems too sparse to conduct such an analysis.
  ○ Future trials comparing the benefits and harms of using both dual modality versus single modality prophylaxis alone are needed.
  ○ Further research is needed to determine independent predictors of intermediate, final health, and harms outcomes. Current literature is too scant to reliably determine the impact of surgical or patient characteristics on these outcomes
  ○ Future trials comparing the benefits and harms of using inferior vena cava filters versus mechanical prophylaxis are needed.
- Future trials in nonmajor orthopedic surgeries should determine whether or not prophylaxis is superior to control and the comparative effectiveness of different prophylactic options.