# Applicability Rating for Individual Trials and Studies and the Body of Evidence

Table 98 Evaluation of applicability for individual randomized controlled trials

Table 99 Evaluation of applicability for individual randomized controlled trials in nonmajor orthopedic surgery

Table 100 Evaluation of applicability for individual observational studies

Table 101 Strength of applicability for the body of evidence evaluating the link between deep vein thrombosis and pulmonary embolism in patients who had major orthopedic surgery

Table 102 Strength of applicability for the body of evidence evaluating symptomatic venous thromboembolism in patients who had major orthopedic surgery

Table 103 Strength of applicability for the body of evidence evaluating major venous thromboembolism in patients who had major orthopedic surgery

Table 104 Strength of applicability for the body of evidence evaluating pulmonary embolism in patients who had major orthopedic surgery

Table 105 Strength of applicability for the body of evidence evaluating fatal pulmonary embolism in patients who had major orthopedic surgery

Table 106 Strength of applicability for the body of evidence evaluating nonfatal pulmonary embolism in patients who had major orthopedic surgery

Table 107 Strength of applicability for the body of evidence evaluating post thrombotic syndrome in patients who had major orthopedic surgery

Table 108 Strength of applicability for the body of evidence evaluating mortality in patients who had major orthopedic surgery

Table 109 Strength of applicability for the body of evidence evaluating mortality due to bleeding in patients who had major orthopedic surgery

Table 110 Strength of applicability for the body of evidence evaluating health related quality of life in patients who had major orthopedic surgery

Table 111 Strength of applicability for the body of evidence evaluating deep vein thrombosis in patients who had major orthopedic surgery

Table 112 Strength of applicability for the body of evidence evaluating asymptomatic deep vein thrombosis in patients who had major orthopedic surgery

Table 113 Strength of applicability for the body of evidence evaluating symptomatic deep vein thrombosis in patients who had major orthopedic surgery

Table 114 Strength of applicability for the body of evidence evaluating proximal deep vein thrombosis in patients who had major orthopedic surgery

Table 115 Strength of applicability for the body of evidence evaluating distal deep vein thrombosis in patients who had major orthopedic surgery

Table 116 Strength of applicability for the body of evidence evaluating major bleeding in patients who had major orthopedic surgery

Table 117 Strength of applicability for the body of evidence evaluating major bleeding leading to reoperation in patients who had major orthopedic surgery

Table 118 Strength of applicability for the body of evidence evaluating minor bleeding in patients who had major orthopedic surgery

Table 119 Strength of applicability for the body of evidence evaluating surgical site bleeding in patients who had major orthopedic surgery

Table 120 Strength of applicability for the body of evidence evaluating bleeding leading to infection in patients who had major orthopedic surgery

Table 121 Strength of applicability for the body of evidence evaluating bleeding leading to transfusion in patients who had major orthopedic surgery

Table 122 Strength of applicability for the body of evidence evaluating heparin induced thrombocytopenia in patients who had major orthopedic surgery

Table 123 Strength of applicability for the body of evidence evaluating discomfort in patients who had major orthopedic surgery

Table 124 Strength of applicability for the body of evidence evaluating readmission in patients who had major orthopedic surgery

Table 125 Strength of applicability for the body of evidence evaluating reoperation in patients who had major orthopedic surgery