# Strength of Evidence Rating

Table 24 Strength of evidence for the incidence of final, intermediate and adverse outcomes in total hip replacement surgery

| | | Quality Assessment | | | | Summary of Findings
Outcome | Number of studies | Design | Risk of Bias | Consistency | Directness | Precision | Quality
Symptomatic objectively confirmed VTE | 0 | --- | --- | --- | --- | --- | Insufficient
Major venous thromboembolism | 0 | --- | --- | --- | --- | --- | Insufficient
Pulmonary Embolism | 5 | RCT | Very serious limitation | Very serious inconsistency | No indirectness | Serious imprecision | Low
Fatal pulmonary embolism | 1 | RCT | Serious limitation | NA | No indirectness | NA | Insufficient
Nonfatal pulmonary embolism | 1 | RCT | Serious limitation | NA | No indirectness | NA | Insufficient
Deep vein thrombosis | 8 | RCT | Very serious limitation | Very serious inconsistency | No indirectness | No imprecision | Low
Asymptomatic deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Symptomatic deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Proximal deep vein thrombosis | 4 | RCT | Serious limitation | Very serious inconsistency | No indirectness | Serious imprecision | Low
Distal deep vein thrombosis | 2 | RCT | Very serious limitation | Serious inconsistency | No indirectness | Very serious imprecision | Low
Major bleeding | 5 | RCT | Serious limitation | No inconsistency | No indirectness | No imprecision | Moderate
Major bleeding leading to reoperation | 2 | RCT | Serious limitation | NA | No indirectness | NA | Insufficient
Minor bleeding | 5 | RCT | Serious limitation | Very serious inconsistency | No indirectness | Serious imprecision | Low
Surgical site bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Bleeding leading to infection | 0 | --- | --- | --- | --- | --- | Insufficient
Bleeding leading to transfusion | 0 | --- | --- | --- | --- | --- | Insufficient

Abbreviations: NA=not applicable; RCT=randomized controlled trial; VTE=venous thromboembolism

Table 25 Strength of evidence for the incidence of final, intermediate and adverse outcomes in total knee replacement surgery

| | | Quality Assessment | | | | Summary of Findings
Outcome | Number of studies | Design | Risk of Bias | Consistency | Directness | Precision | Quality
Symptomatic objectively confirmed VTE | 0 | --- | --- | --- | --- | --- | Insufficient
Major VTE | 0 | --- | --- | --- | --- | --- | Insufficient
Pulmonary Embolism | 3 (2,1) | RCT, OBS | Very serious limitation | No inconsistency | No indirectness | No imprecision | Low
Fatal pulmonary embolism | 2 (1,1) | RCT, OBS | Very serious limitation | NA | No indirectness | NA | Insufficient
Nonfatal pulmonary embolism | 2 (1,1) | RCT, OBS | Very serious limitation | NA | No indirectness | NA | Insufficient
Deep vein thrombosis | 4 (2,1) | RCT, OBS | Very serious limitation | Serious inconsistency | No indirectness | Very serious imprecision | Low
Asymptomatic deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Symptomatic deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Proximal deep vein thrombosis | 2 | RCT | Very serious limitation | Serious inconsistency | No indirectness | Very serious imprecision | Low
Distal deep vein thrombosis | 2 | RCT | Very serious limitation | No inconsistency | No indirectness | No imprecision | Low
Major bleeding | 2 | RCT | Serious limitation | No inconsistency | No indirectness | Serious imprecision | Low
Major bleeding leading to reoperation | 1 | RCT | Serious limitation | NA | No indirectness | NA | Insufficient
Minor bleeding | 2 | RCT | Serious limitation | No inconsistency | No indirectness | No imprecision | Moderate
Surgical site bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Bleeding leading to infection | 0 | --- | --- | --- | --- | --- | Insufficient
Bleeding leading to transfusion | 0 | --- | --- | --- | --- | --- | Insufficient

Abbreviations: NA=not applicable; OBS=observational; RCT=randomized controlled trial; VTE=venous thromboembolism

Table 26 Strength of evidence for the incidence of final, intermediate and adverse outcomes in hip fracture surgery

| | | Quality Assessment | | | | Summary of Findings
Outcome | Number of studies | Design | Risk of Bias | Consistency | Directness | Precision | Quality
Symptomatic objectively confirmed VTE | 0 | --- | --- | --- | --- | --- | Insufficient
Major VTE | 0 | --- | --- | --- | --- | --- | Insufficient
Pulmonary Embolism | 1 | RCT | Serious limitation | NA | No indirectness | NA | Insufficient
Fatal pulmonary embolism | 1 | RCT | Serious limitation | NA | No indirectness | NA | Insufficient
Nonfatal pulmonary embolism | 1 | RCT | Serious limitation | NA | No indirectness | NA | Insufficient
Deep vein thrombosis | 1 | RCT | Very serious limitation | NA | No indirectness | NA | Insufficient
Asymptomatic deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Symptomatic deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Proximal deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Distal deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Major bleeding | 1 | RCT | Very serious limitation | NA | No indirectness | NA | Insufficient
Major bleeding leading to reoperation | 0 | --- | --- | --- | --- | --- | Insufficient
Minor bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Surgical site bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Bleeding leading to infection | 0 | --- | --- | --- | --- | --- | Insufficient
Bleeding leading to transfusion | 0 | --- | --- | --- | --- | --- | Insufficient

Abbreviations: NA=not applicable; RCT=randomized controlled trial; VTE=venous thromboembolism

Table 27 Strength of evidence for the impact of spinal versus epidural anesthesia on the risk of venous thromboembolic or bleeding outcomes

| | | Quality Assessment | | | | Summary of Findings
Outcome | Number of studies | Design | Risk of Bias | Consistency | Directness | Precision | Quality
Symptomatic objectively confirmed VTE | 0 | --- | --- | --- | --- | --- | Insufficient
Major VTE | 0 | --- | --- | --- | --- | --- | Insufficient
Pulmonary Embolism | 0 | --- | --- | --- | --- | --- | Insufficient
Fatal pulmonary embolism | 0 | --- | --- | --- | --- | --- | Insufficient
Nonfatal pulmonary embolism | 0 | --- | --- | --- | --- | --- | Insufficient
Deep vein thrombosis | 1 | RCT | Serious limitation | NA | No indirectness | NA | Insufficient
Asymptomatic deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Symptomatic deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Proximal deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Distal deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Major bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Major bleeding leading to reoperation | 0 | --- | --- | --- | --- | --- | Insufficient
Minor bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Surgical site bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Bleeding leading to infection | 0 | --- | --- | --- | --- | --- | Insufficient
Bleeding leading to transfusion | 0 | --- | --- | --- | --- | --- | Insufficient

Abbreviations: NA=not applicable; RCT=randomized controlled trial; VTE=venous thromboembolism

Table 28 Strength of evidence for the impact of general versus regional anesthesia on the risk of venous thromboembolic or bleeding outcomes

| | | Quality Assessment | | | | Summary of Findings
Outcome | Number of studies | Design | Risk of Bias | Consistency | Directness | Precision | Quality
Symptomatic objectively confirmed VTE | 0 | --- | --- | --- | --- | --- | Insufficient
Major VTE | 0 | --- | --- | --- | --- | --- | Insufficient
Pulmonary Embolism | 2 | RCT | Serious limitation | NA | No indirectness | NA | Insufficient
Fatal pulmonary embolism | 0 | --- | --- | --- | --- | --- | Insufficient
Nonfatal pulmonary embolism | 0 | --- | --- | --- | --- | --- | Insufficient
Deep vein thrombosis | 6(4,2) | RCT, OBS | Serious limitation | Serious inconsistency | No indirectness | NA | Low
Asymptomatic deep vein thrombosis | 2 | RCT | Serious limitation | Serious inconsistency | No indirectness | NA | Insufficient
Symptomatic deep vein thrombosis | 2 | RCT | Serious limitation | NA | No indirectness | NA | Low
Proximal deep vein thrombosis | 5 | RCT | Serious limitation | Serious inconsistency | No Indirectness | NA | Low
Distal deep vein thrombosis | 4 | RCT | Serious limitation | Serious inconsistency | No indirectness | NA | Insufficient
Major bleeding | 1 | RCT | Serious limitation | NA | No indirectness | NA | Insufficient
Major bleeding leading to reoperation | 0 | --- | --- | --- | --- | --- | Insufficient
Minor bleeding | 1 | RCT | Serious limitation | NA | No indirectness | NA | Insufficient
Surgical site bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Bleeding leading to infection | 0 | --- | --- | --- | --- | --- | Insufficient
Bleeding leading to transfusion | 0 | --- | --- | --- | --- | --- | Insufficient

Abbreviations: NA=not applicable; OBS=observational; RCT=randomized controlled trial; VTE=venous thromboembolism

Table 29 Strength of evidence for the impact of cemented versus noncemented arthroplasty on the risk of venous thromboembolic or bleeding outcomes

| | | Quality Assessment | | | | Summary of Findings
Outcome | Number of studies | Design | Risk of Bias | Consistency | Directness | Precision | Quality
Symptomatic objectively confirmed VTE | 0 | --- | --- | --- | --- | --- | Insufficient
Major VTE | 0 | --- | --- | --- | --- | --- | Insufficient
Pulmonary Embolism | 1 | RCT | Serious limitation | NA | No indirectness | NA | Insufficient
Fatal pulmonary embolism | 0 | --- | --- | --- | --- | --- | Insufficient
Nonfatal pulmonary embolism | 0 | --- | --- | --- | --- | --- | Insufficient
Deep vein thrombosis | 5 (2,3) | RCT, OBS | Serious limitation | Serious inconsistency | No indirectness | NA | Low
Asymptomatic deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Symptomatic deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Proximal deep vein thrombosis | 2 | RCT | Serious limitation | No inconsistency | No Indirectness | NA | Low
Distal deep vein thrombosis | 2 | RCT | Serious limitation | Serious inconsistency | No indirectness | NA | Insufficient
Major bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Major bleeding leading to reoperation | 0 | --- | --- | --- | --- | --- | Insufficient
Minor bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Surgical site bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Bleeding leading to infection | 0 | --- | --- | --- | --- | --- | Insufficient
Bleeding leading to transfusion | 0 | --- | --- | --- | --- | --- | Insufficient

Abbreviations: NA=not applicable; OBS=observational; RCT=randomized controlled trial; VTE=venous thromboembolism

Table 30 Strength of evidence for the impact of bone vacuum cement versus standard cement on the risk of venous thromboembolic or bleeding outcomes

| | | Quality Assessment | | | | Summary of Findings
Outcome | Number of studies | Design | Risk of Bias | Consistency | Directness | Precision | Quality
Symptomatic objectively confirmed VTE | 0 | --- | --- | --- | --- | --- | Insufficient
Major VTE | 0 | --- | --- | --- | --- | --- | Insufficient
Pulmonary Embolism | 1 | RCT | No limitations | NA | No indirectness | NA | Insufficient
Fatal pulmonary embolism | 0 | --- | --- | --- | --- | --- | Insufficient
Nonfatal pulmonary embolism | 0 | --- | --- | --- | --- | --- | Insufficient
Deep vein thrombosis | 1 | RCT | No limitations | NA | No indirectness | NA | Insufficient
Asymptomatic deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Symptomatic deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Proximal deep vein thrombosis | 1 | RCT | No limitations | NA | No indirectness | NA | Insufficient
Distal deep vein thrombosis | 1 | RCT | No limitations | NA | No indirectness | NA | Insufficient
Major bleeding | 1 | RCT | No limitations | NA | No indirectness | NA | Insufficient
Major bleeding leading to reoperation | 0 | --- | --- | --- | --- | --- | Insufficient
Minor bleeding | 1 | RCT | No limitations | NA | No indirectness | NA | Insufficient
Surgical site bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Bleeding leading to infection | 0 | --- | --- | --- | --- | --- | Insufficient
Bleeding leading to transfusion | 0 | --- | --- | --- | --- | --- | Insufficient

Abbreviations: NA=not applicable; RCT=randomized controlled trial; VTE=venous thromboembolism

Table 31 Strength of evidence for the impact of tourniquet versus no tourniquet on the risk of venous thromboembolic or bleeding outcomes

| | | Quality Assessment | | | | Summary of Findings
Outcome | Number of studies | Design | Risk of Bias | Consistency | Directness | Precision | Quality
Symptomatic objectively confirmed VTE | 0 | --- | --- | --- | --- | --- | Insufficient
Major VTE | 0 | --- | --- | --- | --- | --- | Insufficient
Pulmonary Embolism | 0 | --- | --- | --- | --- | --- | Insufficient
Fatal pulmonary embolism | 0 | --- | --- | --- | --- | --- | Insufficient
Nonfatal pulmonary embolism | 0 | --- | --- | --- | --- | --- | Insufficient
Deep vein thrombosis | 1 | RCT | Serious limitation | No inconsistency | No indirectness | NA | Insufficient
Asymptomatic deep vein thrombosis | 1 | RCT | Serious limitation | NA | No indirectness | NA | Insufficient
Symptomatic deep vein thrombosis | 1 | RCT | Serious limitation | NA | No indirectness | NA | Insufficient
Proximal deep vein thrombosis | 2 | RCT | Serious limitation | No inconsistency | No indirectness | NA | Insufficient
Distal deep vein thrombosis | 2 | RCT | Serious limitation | NA | No indirectness | NA | Insufficient
Major bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Major bleeding leading to reoperation | 0 | --- | --- | --- | --- | --- | Insufficient
Minor bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Surgical site bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Bleeding leading to infection | 0 | --- | --- | --- | --- | --- | Insufficient
Bleeding leading to transfusion | 0 | --- | --- | --- | --- | --- | Insufficient

Abbreviations: NA=not applicable; RCT=randomized controlled trial; VTE=venous thromboembolism

Table 32 Strength of evidence for the impact of tourniquet release prior to wound closure versus tourniquet release after wound closure on the risk of venous thromboembolic or bleeding outcomes

| | | Quality Assessment | | | | Summary of Findings
Outcome | Number of studies | Design | Risk of Bias | Consistency | Directness | Precision | Quality
Symptomatic objectively confirmed VTE | 0 | --- | --- | --- | --- | --- | Insufficient
Major VTE | 0 | --- | --- | --- | --- | --- | Insufficient
Pulmonary Embolism | 0 | --- | --- | --- | --- | --- | Insufficient
Fatal pulmonary embolism | 0 | --- | --- | --- | --- | --- | Insufficient
Nonfatal pulmonary embolism | 0 | --- | --- | --- | --- | --- | Insufficient
Deep vein thrombosis | 1 | RCT | Very serious limitation | NA | No indirectness | NA | Insufficient
Asymptomatic deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Symptomatic deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Proximal deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Distal deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Major bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Major bleeding leading to reoperation | 0 | --- | --- | --- | --- | --- | Insufficient
Minor bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Surgical site bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Bleeding leading to infection | 0 | --- | --- | --- | --- | --- | Insufficient
Bleeding leading to transfusion | 0 | --- | --- | --- | --- | --- | Insufficient

Abbreviations: NA=not applicable; RCT=randomized controlled trial; VTE=venous thromboembolism

Table 33 Strength of evidence for the impact of modified position to maintain femoral blood flow versus standard figure four position on the risk of venous thromboembolic or bleeding outcomes

| | | Quality Assessment | | | | Summary of Findings
Outcome | Number of studies | Design | Risk of Bias | Consistency | Directness | Precision | Quality
Symptomatic objectively confirmed VTE | 0 | --- | --- | --- | --- | --- | Insufficient
Major VTE | 0 | --- | --- | --- | --- | --- | Insufficient
Pulmonary Embolism | 1 | RCT | Serious limitation | NA | No indirectness | NA | Insufficient
Fatal pulmonary embolism | 1 | RCT | Serious limitation | NA | No indirectness | NA | Insufficient
Nonfatal pulmonary embolism | 1 | RCT | Serious limitation | NA | No indirectness | NA | Insufficient
Deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Asymptomatic deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Symptomatic deep vein thrombosis | 1 | RCT | Serious limitations | NA | No indirectness | NA | Insufficient
Proximal deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Distal deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Major bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Major bleeding leading to reoperation | 0 | --- | --- | --- | --- | --- | Insufficient
Minor bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Surgical site bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Bleeding leading to infection | 0 | --- | --- | --- | --- | --- | Insufficient
Bleeding leading to transfusion | 0 | --- | --- | --- | --- | --- | Insufficient

Abbreviations: NA=not applicable; RCT=randomized controlled trial; VTE=venous thromboembolism

Table 34 Strength of evidence for the impact of minimum hyperflexed knee versus standard hyperflexed knee on the risk of venous thromboembolic or bleeding outcomes

| | | Quality Assessment | | | | Summary of Findings
Outcome | Number of studies | Design | Risk of Bias | Consistency | Directness | Precision | Quality
Symptomatic objectively confirmed VTE | 0 | --- | --- | --- | --- | --- | Insufficient
Major VTE | 0 | --- | --- | --- | --- | --- | Insufficient
Pulmonary Embolism | 0 | --- | --- | --- | --- | --- | Insufficient
Fatal pulmonary embolism | 0 | --- | --- | --- | --- | --- | Insufficient
Nonfatal pulmonary embolism | 0 | --- | --- | --- | --- | --- | Insufficient
Deep vein thrombosis | 1 | RCT | Very serious limitation | NA | No indirectness | NA | Insufficient
Asymptomatic deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Symptomatic deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Proximal deep vein thrombosis | 1 | RCT | Very serious limitation | NA | No indirectness | NA | Insufficient
Distal deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Major bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Major bleeding leading to reoperation | 0 | --- | --- | --- | --- | --- | Insufficient
Minor bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Surgical site bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Bleeding leading to infection | 0 | --- | --- | --- | --- | --- | Insufficient
Bleeding leading to transfusion | 0 | --- | --- | --- | --- | --- | Insufficient

Abbreviations: NA=not applicable; RCT=randomized controlled trial; VTE=venous thromboembolism

Table 35 Strength of evidence for the impact of tissue fibrin adhesive versus no adhesive on the risk of venous thromboembolic or bleeding outcomes

| | | Quality Assessment | | | | Summary of Findings
Outcome | Number of studies | Design | Risk of Bias | Consistency | Directness | Precision | Quality
Symptomatic objectively confirmed VTE | 0 | --- | --- | --- | --- | --- | Insufficient
Major VTE | 0 | --- | --- | --- | --- | --- | Insufficient
Pulmonary Embolism | 0 | --- | --- | --- | --- | --- | Insufficient
Fatal pulmonary embolism | 1 | RCT | Serious limitation | NA | No indirectness | NA | Insufficient
Nonfatal pulmonary embolism | 0 | --- | --- | --- | --- | --- | Insufficient
Deep vein thrombosis | 1 | RCT | Serious limitation | NA | No indirectness | NA | Insufficient
Asymptomatic deep vein thrombosis | 1 | RCT | Serious limitation | NA | No indirectness | NA | Insufficient
Symptomatic deep vein thrombosis | 1 | RCT | Serious limitation | NA | No indirectness | NA | Insufficient
Proximal deep vein thrombosis | 1 | RCT | Serious limitation | NA | No indirectness | NA | Insufficient
Distal deep vein thrombosis | 1 | RCT | Serious limitation | NA | No indirectness | NA | Insufficient
Major bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Major bleeding leading to reoperation | 0 | --- | --- | --- | --- | --- | Insufficient
Minor bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Surgical site bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Bleeding leading to infection | 0 | --- | --- | --- | --- | --- | Insufficient
Bleeding leading to transfusion | 0 | --- | --- | --- | --- | --- | Insufficient

Abbreviations: NA=not applicable; RCT=randomized controlled trial; VTE=venous thromboembolism

Table 36 Strength of evidence for the impact of primary versus revision surgery on the risk of venous thromboembolic or bleeding outcomes

| | | Quality Assessment | | | | Summary of Findings
Outcome | Number of studies | Design | Risk of Bias | Consistency | Directness | Precision | Quality
Symptomatic objectively confirmed VTE | 0 | --- | --- | --- | --- | --- | Insufficient
Major VTE | 0 | --- | --- | --- | --- | --- | Insufficient
Pulmonary Embolism | 0 | --- | --- | --- | --- | --- | Insufficient
Fatal pulmonary embolism | 0 | --- | --- | --- | --- | --- | Insufficient
Nonfatal pulmonary embolism | 0 | --- | --- | --- | --- | --- | Insufficient
Deep vein thrombosis | 1 | OBS | Serious limitation | NA | No indirectness | NA | Insufficient
Asymptomatic deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Symptomatic deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Proximal deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Distal deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Major bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Major bleeding leading to reoperation | 0 | --- | --- | --- | --- | --- | Insufficient
Minor bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Surgical site bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Bleeding leading to infection | 0 | --- | --- | --- | --- | --- | Insufficient
Bleeding leading to transfusion | 0 | --- | --- | --- | --- | --- | Insufficient

Abbreviations: NA=not applicable; OBS=observational ; VTE=venous thromboembolism

Table 37 Strength of evidence for the impact of perioperative blood loss on the risk of venous thromboembolic or bleeding outcomes

| | | Quality Assessment | | | | Summary of Findings
Outcome | Number of studies | Design | Risk of Bias | Consistency | Directness | Precision | Quality
Symptomatic objectively confirmed VTE | 0 | --- | --- | --- | --- | --- | Insufficient
Major VTE | 0 | --- | --- | --- | --- | --- | Insufficient
Pulmonary Embolism | 0 | --- | --- | --- | --- | --- | Insufficient
Fatal pulmonary embolism | 0 | --- | --- | --- | --- | --- | Insufficient
Nonfatal pulmonary embolism | 0 | --- | --- | --- | --- | --- | Insufficient
Deep vein thrombosis | 1 | OBS | Serious limitation | NA | No indirectness | NA | Insufficient
Asymptomatic deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Symptomatic deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Proximal deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Distal deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Major bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Major bleeding leading to reoperation | 0 | --- | --- | --- | --- | --- | Insufficient
Minor bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Surgical site bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Bleeding leading to infection | 0 | --- | --- | --- | --- | --- | Insufficient
Bleeding leading to transfusion | 0 | --- | --- | --- | --- | --- | Insufficient

Abbreviations: NA=not applicable; OBS=observational ; VTE=venous thromboembolism

Table 38 Strength of evidence for the impact of operative time on the risk of venous thromboembolic or bleeding outcomes

| | | Quality Assessment | | | | Summary of Findings
Outcome | Number of studies | Design | Risk of Bias | Consistency | Directness | Precision | Quality
Symptomatic objectively confirmed VTE | 0 | --- | --- | --- | --- | --- | Insufficient
Major VTE | 0 | --- | --- | --- | --- | --- | Insufficient
Pulmonary Embolism | 0 | --- | --- | --- | --- | --- | Insufficient
Fatal pulmonary embolism | 0 | --- | --- | --- | --- | --- | Insufficient
Nonfatal pulmonary embolism | 0 | --- | --- | --- | --- | --- | Insufficient
Deep vein thrombosis | 1 | OBS | Serious limitation | NA | No indirectness | NA | Insufficient
Asymptomatic deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Symptomatic deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Proximal deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Distal deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Major bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Major bleeding leading to reoperation | 0 | --- | --- | --- | --- | --- | Insufficient
Minor bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Surgical site bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Bleeding leading to infection | 0 | --- | --- | --- | --- | --- | Insufficient
Bleeding leading to transfusion | 0 | --- | --- | --- | --- | --- | Insufficient

Abbreviations: NA=not applicable; OBS=observational; VTE=venous thromboembolism

Table 39 Strength of evidence for the impact of blood transfusions on the risk of venous thromboembolic or bleeding outcomes

| | | Quality Assessment | | | | Summary of Findings
Outcome | Number of studies | Design | Risk of Bias | Consistency | Directness | Precision | Quality
Symptomatic objectively confirmed VTE | 0 | --- | --- | --- | --- | --- | Insufficient
Major VTE | 0 | --- | --- | --- | --- | --- | Insufficient
Pulmonary Embolism | 0 | --- | --- | --- | --- | --- | Insufficient
Fatal pulmonary embolism | 0 | --- | --- | --- | --- | --- | Insufficient
Nonfatal pulmonary embolism | 0 | --- | --- | --- | --- | --- | Insufficient
Deep vein thrombosis | 1 | OBS | Serious limitation | NA | No indirectness | NA | Insufficient
Asymptomatic deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Symptomatic deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Proximal deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Distal deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Major bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Major bleeding leading to reoperation | 0 | --- | --- | --- | --- | --- | Insufficient
Minor bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Surgical site bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Bleeding leading to infection | 0 | --- | --- | --- | --- | --- | Insufficient
Bleeding leading to transfusion | 0 | --- | --- | --- | --- | --- | Insufficient

Abbreviations: NA=not applicable; OBS=observational ; VTE=venous thromboembolism

Table 40 Strength of evidence for the impact of congestive heart failure on the risk of venous thromboembolic or bleeding outcomes

| | | Quality Assessment | | | | Summary of Findings
Outcome | Number of studies | Design | Risk of Bias | Consistency | Directness | Precision | Quality
Symptomatic objectively confirmed VTE | 2 | OBS | No limitations | No inconsistency | No indirectness | NA | Moderate
Major VTE | 0 | --- | --- | --- | --- | --- | Insufficient
Pulmonary Embolism | 0 | --- | --- | --- | --- | --- | Insufficient
Fatal pulmonary embolism | 0 | --- | --- | --- | --- | --- | Insufficient
Nonfatal pulmonary embolism | 0 | --- | --- | --- | --- | --- | Insufficient
Deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Asymptomatic deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Symptomatic deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Proximal deep vein thrombosis | 1 | OBS | Serious limitation | NA | No indirectness | NA | Insufficient
Distal deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Major bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Major bleeding leading to reoperation | 0 | --- | --- | --- | --- | --- | Insufficient
Minor bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Surgical site bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Bleeding leading to infection | 0 | --- | --- | --- | --- | --- | Insufficient
Bleeding leading to transfusion | 0 | --- | --- | --- | --- | --- | Insufficient

Abbreviations: NA=not applicable; OBS=observational ; VTE=venous thromboembolism

Table 41 Strength of evidence for the impact of inactive malignancy on the risk of venous thromboembolic or bleeding outcomes

| | | Quality Assessment | | | | Summary of Findings
Outcome | Number of studies | Design | Risk of Bias | Consistency | Directness | Precision | Quality
Symptomatic objectively confirmed VTE | 1 | OBS | Serious limitation | NA | No indirectness | NA | Insufficient
Major VTE | 0 | --- | --- | --- | --- | --- | Insufficient
Pulmonary Embolism | 0 | --- | --- | --- | --- | --- | Insufficient
Fatal pulmonary embolism | 0 | --- | --- | --- | --- | --- | Insufficient
Nonfatal pulmonary embolism | 0 | --- | --- | --- | --- | --- | Insufficient
Deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Asymptomatic deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Symptomatic deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Proximal deep vein thrombosis | 1 | OBS | Serious limitation | NA | No indirectness | NA | Insufficient
Distal deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Major bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Major bleeding leading to reoperation | 0 | --- | --- | --- | --- | --- | Insufficient
Minor bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Surgical site bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Bleeding leading to infection | 0 | --- | --- | --- | --- | --- | Insufficient
Bleeding leading to transfusion | 0 | --- | --- | --- | --- | --- | Insufficient

Abbreviations: NA=not applicable; OBS=observational ; VTE=venous thromboembolism

Table 42 Strength of evidence for the impact of hormone replacement therapy on the risk of venous thromboembolic or bleeding outcomes

| | | Quality Assessment | | | | Summary of Findings
Outcome | Number of studies | Design | Risk of Bias | Consistency | Directness | Precision | Quality
Symptomatic objectively confirmed VTE | 1 | OBS | Serious limitation | NA | No indirectness | NA | Insufficient
Major VTE | 0 | --- | --- | --- | --- | --- | Insufficient
Pulmonary Embolism | 0 | --- | --- | --- | --- | --- | Insufficient
Fatal pulmonary embolism | 0 | --- | --- | --- | --- | --- | Insufficient
Nonfatal pulmonary embolism | 0 | --- | --- | --- | --- | --- | Insufficient
Deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Asymptomatic deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Symptomatic deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Proximal deep vein thrombosis | 1 | OBS | Serious limitation | NA | No indirectness | NA | Insufficient
Distal deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Major bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Major bleeding leading to reoperation | 0 | --- | --- | --- | --- | --- | Insufficient
Minor bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Surgical site bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Bleeding leading to infection | 0 | --- | --- | --- | --- | --- | Insufficient
Bleeding leading to transfusion | 0 | --- | --- | --- | --- | --- | Insufficient

Abbreviations: NA=not applicable; OBS=observational; VTE=venous thromboembolism

Table 43 Strength of evidence for the impact of age on the risk of venous thromboembolic or bleeding outcomes

| | | Quality Assessment | | | | Summary of Findings
Outcome | Number of studies | Design | Risk of Bias | Consistency | Directness | Precision | Quality
Symptomatic objectively confirmed VTE | 2 | OBS | Serious limitation | No inconsistency | No indirectness | NA | Low
Major VTE | 0 | --- | --- | --- | --- | --- | Insufficient
Pulmonary Embolism | 1 | OBS | Serious limitation | NA | No indirectness | NA | Insufficient
Fatal pulmonary embolism | 0 | --- | --- | --- | --- | --- | Insufficient
Nonfatal pulmonary embolism | 0 | --- | --- | --- | --- | --- | Insufficient
Deep vein thrombosis | 3 | OBS | Serious limitation | Serious inconsistency | No indirectness | NA | Low
Asymptomatic deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Symptomatic deep vein thrombosis | 1 | OBS | No limitations | NA | No indirectness | NA | Insufficient
Proximal deep vein thrombosis | 2 | OBS | Very serious limitation | No inconsistency | No indirectness | NA | Low
Distal deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Major bleeding | 1 | OBS | Very serious limitations | NA | No indirectness | NA | Insufficient
Major bleeding leading to reoperation | 0 | --- | --- | --- | --- | --- | Insufficient
Minor bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Surgical site bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Bleeding leading to infection | 0 | --- | --- | --- | --- | --- | Insufficient
Bleeding leading to transfusion | 0 | --- | --- | --- | --- | --- | Insufficient

Abbreviations: NA=not applicable; OBS=observational; VTE=venous thromboembolism

Table 44 Strength of evidence for the impact of living at home on the risk of venous thromboembolic or bleeding outcomes

| | | Quality Assessment | | | | Summary of Findings
Outcome | Number of studies | Design | Risk of Bias | Consistency | Directness | Precision | Quality
Symptomatic objectively confirmed VTE | 1 | OBS | No limitations | NA | No indirectness | NA | Insufficient
Major VTE | 0 | --- | --- | --- | --- | --- | Insufficient
Pulmonary Embolism | 0 | --- | --- | --- | --- | --- | Insufficient
Fatal pulmonary embolism | 0 | --- | --- | --- | --- | --- | Insufficient
Nonfatal pulmonary embolism | 0 | --- | --- | --- | --- | --- | Insufficient
Deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Asymptomatic deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Symptomatic deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Proximal deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Distal deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Major bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Major bleeding leading to reoperation | 0 | --- | --- | --- | --- | --- | Insufficient
Minor bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Surgical site bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Bleeding leading to infection | 0 | --- | --- | --- | --- | --- | Insufficient
Bleeding leading to transfusion | 0 | --- | --- | --- | --- | --- | Insufficient

Abbreviations: NA=not applicable; OBS=observational; VTE=venous thromboembolism

Table 45 Strength of evidence for the impact of intertrochanteric fractures on the risk of venous thromboembolic or bleeding outcomes

| | | Quality Assessment | | | | Summary of Findings
Outcome | Number of studies | Design | Risk of Bias | Consistency | Directness | Precision | Quality
Symptomatic objectively confirmed VTE | 1 | OBS | No limitations | NA | No indirectness | NA | Insufficient
Major VTE | 0 | --- | --- | --- | --- | --- | Insufficient
Pulmonary Embolism | 0 | --- | --- | --- | --- | --- | Insufficient
Fatal pulmonary embolism | 0 | --- | --- | --- | --- | --- | Insufficient
Nonfatal pulmonary embolism | 0 | --- | --- | --- | --- | --- | Insufficient
Deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Asymptomatic deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Symptomatic deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Proximal deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Distal deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Major bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Major bleeding leading to reoperation | 0 | --- | --- | --- | --- | --- | Insufficient
Minor bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Surgical site bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Bleeding leading to infection | 0 | --- | --- | --- | --- | --- | Insufficient
Bleeding leading to transfusion | 0 | --- | --- | --- | --- | --- | Insufficient

Abbreviations: NA=not applicable; OBS=observational; VTE=venous thromboembolism

Table 46 Strength of evidence for the impact of subtrochanteric fractures on the risk of venous thromboembolic or bleeding outcomes

| | | Quality Assessment | | | | Summary of Findings
Outcome | Number of studies | Design | Risk of Bias | Consistency | Directness | Precision | Quality
Symptomatic objectively confirmed VTE | 1 | OBS | No limitations | NA | No indirectness | NA | Insufficient
Major VTE | 0 | --- | --- | --- | --- | --- | Insufficient
Pulmonary Embolism | 0 | --- | --- | --- | --- | --- | Insufficient
Fatal pulmonary embolism | 0 | --- | --- | --- | --- | --- | Insufficient
Nonfatal pulmonary embolism | 0 | --- | --- | --- | --- | --- | Insufficient
Deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Asymptomatic deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Symptomatic deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Proximal deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Distal deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Major bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Major bleeding leading to reoperation | 0 | --- | --- | --- | --- | --- | Insufficient
Minor bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Surgical site bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Bleeding leading to infection | 0 | --- | --- | --- | --- | --- | Insufficient
Bleeding leading to transfusion | 0 | --- | --- | --- | --- | --- | Insufficient

Abbreviations: NA=not applicable; OBS=observational; VTE=venous thromboembolism

Table 47 Strength of evidence for the impact of increased hemoglobin on the risk of venous thromboembolic or bleeding outcomes

| | | Quality Assessment | | | | Summary of Findings
Outcome | Number of studies | Design | Risk of Bias | Consistency | Directness | Precision | Quality
Symptomatic objectively confirmed VTE | 1 | OBS | No limitations | NA | No indirectness | NA | Insufficient
Major VTE | 0 | --- | --- | --- | --- | --- | Insufficient
Pulmonary Embolism | 0 | --- | --- | --- | --- | --- | Insufficient
Fatal pulmonary embolism | 0 | --- | --- | --- | --- | --- | Insufficient
Nonfatal pulmonary embolism | 0 | --- | --- | --- | --- | --- | Insufficient
Deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Asymptomatic deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Symptomatic deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Proximal deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Distal deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Major bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Major bleeding leading to reoperation | 0 | --- | --- | --- | --- | --- | Insufficient
Minor bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Surgical site bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Bleeding leading to infection | 0 | --- | --- | --- | --- | --- | Insufficient
Bleeding leading to transfusion | 0 | --- | --- | --- | --- | --- | Insufficient

Abbreviations: NA=not applicable; OBS=observational; VTE=venous thromboembolism

Table 48 Strength of evidence for the impact of gender on the risk of venous thromboembolic or bleeding outcomes

| | | Quality Assessment | | | | Summary of Findings
Outcome | Number of studies | Design | Risk of Bias | Consistency | Directness | Precision | Quality
Symptomatic objectively confirmed VTE | 1 | OBS | No limitations | NA | No indirectness | NA | Insufficient
Major VTE | 0 | --- | --- | --- | --- | --- | Insufficient
Pulmonary Embolism | 0 | --- | --- | --- | --- | --- | Insufficient
Fatal pulmonary embolism | 0 | --- | --- | --- | --- | --- | Insufficient
Nonfatal pulmonary embolism | 0 | --- | --- | --- | --- | --- | Insufficient
Deep vein thrombosis | 2 | OBS | No limitations | Serious inconsistency | No indirectness | NA | Insufficient
Asymptomatic deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Symptomatic deep vein thrombosis | 1 | OBS | No limitations | NA | No indirectness | NA | Insufficient
Proximal deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Distal deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Major bleeding | 1 | OBS | Very serious limitations | NA | No indirectness | NA | Insufficient
Major bleeding leading to reoperation | 0 | --- | --- | --- | --- | --- | Insufficient
Minor bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Surgical site bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Bleeding leading to infection | 0 | --- | --- | --- | --- | --- | Insufficient
Bleeding leading to transfusion | 0 | --- | --- | --- | --- | --- | Insufficient

Abbreviations: NA=not applicable; OBS=observational; VTE=venous thromboembolism

Table 49 Strength of evidence for the impact of history of venous thromboembolism on the risk of venous thromboembolic or bleeding outcomes

| | | Quality Assessment | | | | Summary of Findings
Outcome | Number of studies | Design | Risk of Bias | Consistency | Directness | Precision | Quality
Symptomatic objectively confirmed VTE | 1 | OBS | No limitations | NA | No indirectness | NA | Insufficient
Major VTE | 0 | --- | --- | --- | --- | --- | Insufficient
Pulmonary Embolism | 1 | OBS | No limitations | NA | No indirectness | NA | Insufficient
Fatal pulmonary embolism | 0 | --- | --- | --- | --- | --- | Insufficient
Nonfatal pulmonary embolism | 0 | --- | --- | --- | --- | --- | Insufficient
Deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Asymptomatic deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Symptomatic deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Proximal deep vein thrombosis | 1 | OBS | No limitations | NA | No indirectness | NA | Insufficient
Distal deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Major bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Major bleeding leading to reoperation | 0 | --- | --- | --- | --- | --- | Insufficient
Minor bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Surgical site bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Bleeding leading to infection | 0 | --- | --- | --- | --- | --- | Insufficient
Bleeding leading to transfusion | 0 | --- | --- | --- | --- | --- | Insufficient

Abbreviations: NA=not applicable; OBS=observational; VTE=venous thromboembolism

Table 50 Strength of evidence for the impact of varicose veins on the risk of venous thromboembolic or bleeding outcomes

| | | Quality Assessment | | | | Summary of Findings
Outcome | Number of studies | Design | Risk of Bias | Consistency | Directness | Precision | Quality
Symptomatic objectively confirmed VTE | 1 | OBS | No limitations | NA | No indirectness | NA | Insufficient
Major VTE | 0 | --- | --- | --- | --- | --- | Insufficient
Pulmonary Embolism | 1 | OBS | No limitations | NA | No indirectness | NA | Insufficient
Fatal pulmonary embolism | 0 | --- | --- | --- | --- | --- | Insufficient
Nonfatal pulmonary embolism | 0 | --- | --- | --- | --- | --- | Insufficient
Deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Asymptomatic deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Symptomatic deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Proximal deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Distal deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Major bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Major bleeding leading to reoperation | 0 | --- | --- | --- | --- | --- | Insufficient
Minor bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Surgical site bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Bleeding leading to infection | 0 | --- | --- | --- | --- | --- | Insufficient
Bleeding leading to transfusion | 0 | --- | --- | --- | --- | --- | Insufficient

Abbreviations: NA=not applicable; OBS=observational; VTE=venous thromboembolism

Table 51 Strength of evidence for the impact of genitourinary infection on the risk of venous thromboembolic or bleeding outcomes

| | | Quality Assessment | | | | Summary of Findings
Outcome | Number of studies | Design | Risk of Bias | Consistency | Directness | Precision | Quality
Symptomatic objectively confirmed VTE | 0 | --- | --- | --- | --- | --- | Insufficient
Major VTE | 0 | --- | --- | --- | --- | --- | Insufficient
Pulmonary Embolism | 1 | OBS | Serious limitations | NA | No indirectness | NA | Insufficient
Fatal pulmonary embolism | 0 | --- | --- | --- | --- | --- | Insufficient
Nonfatal pulmonary embolism | 0 | --- | --- | --- | --- | --- | Insufficient
Deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Asymptomatic deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Symptomatic deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Proximal deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Distal deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Major bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Major bleeding leading to reoperation | 0 | --- | --- | --- | --- | --- | Insufficient
Minor bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Surgical site bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Bleeding leading to infection | 0 | --- | --- | --- | --- | --- | Insufficient
Bleeding leading to transfusion | 0 | --- | --- | --- | --- | --- | Insufficient

Abbreviations: NA=not applicable; OBS=observational; VTE=venous thromboembolism

Table 52 Strength of evidence for the impact of cardiovascular disease on the risk of venous thromboembolic or bleeding outcomes

| | | Quality Assessment | | | | Summary of Findings
Outcome | Number of studies | Design | Risk of Bias | Consistency | Directness | Precision | Quality
Symptomatic objectively confirmed VTE | 0 | --- | --- | --- | --- | --- | Insufficient
Major VTE | 0 | --- | --- | --- | --- | --- | Insufficient
Pulmonary Embolism | 1 | OBS | Serious limitations | NA | No indirectness | NA | Insufficient
Fatal pulmonary embolism | 0 | --- | --- | --- | --- | --- | Insufficient
Nonfatal pulmonary embolism | 0 | --- | --- | --- | --- | --- | Insufficient
Deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Asymptomatic deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Symptomatic deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Proximal deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Distal deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Major bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Major bleeding leading to reoperation | 0 | --- | --- | --- | --- | --- | Insufficient
Minor bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Surgical site bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Bleeding leading to infection | 0 | --- | --- | --- | --- | --- | Insufficient
Bleeding leading to transfusion | 0 | --- | --- | --- | --- | --- | Insufficient

Abbreviations: NA=not applicable; OBS=observational; VTE=venous thromboembolism

Table 53 Strength of evidence for the impact of thyroid hormone replacement on the risk of venous thromboembolic or bleeding outcomes

| | | Quality Assessment | | | | Summary of Findings
Outcome | Number of studies | Design | Risk of Bias | Consistency | Directness | Precision | Quality
Symptomatic objectively confirmed VTE | 0 | --- | --- | --- | --- | --- | Insufficient
Major VTE | 0 | --- | --- | --- | --- | --- | Insufficient
Pulmonary Embolism | 1 | OBS | Serious limitation | NA | No indirectness | NA | Insufficient
Fatal pulmonary embolism | 0 | --- | --- | --- | --- | --- | Insufficient
Nonfatal pulmonary embolism | 0 | --- | --- | --- | --- | --- | Insufficient
Deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Asymptomatic deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Symptomatic deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Proximal deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Distal deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Major bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Major bleeding leading to reoperation | 0 | --- | --- | --- | --- | --- | Insufficient
Minor bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Surgical site bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Bleeding leading to infection | 0 | --- | --- | --- | --- | --- | Insufficient
Bleeding leading to transfusion | 0 | --- | --- | --- | --- | --- | Insufficient

Abbreviations: NA=not applicable; OBS=observational; VTE=venous thromboembolism

Table 54 Strength of evidence for the impact of phlebitis on the risk of venous thromboembolic or bleeding outcomes

| | | Quality Assessment | | | | Summary of Findings
Outcome | Number of studies | Design | Risk of Bias | Consistency | Directness | Precision | Quality
Symptomatic objectively confirmed VTE | 0 | --- | --- | --- | --- | --- | Insufficient
Major VTE | 0 | --- | --- | --- | --- | --- | Insufficient
Pulmonary Embolism | 1 | OBS | Serious limitation | NA | No indirectness | NA | Insufficient
Fatal pulmonary embolism | 0 | --- | --- | --- | --- | --- | Insufficient
Nonfatal pulmonary embolism | 0 | --- | --- | --- | --- | --- | Insufficient
Deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Asymptomatic deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Symptomatic deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Proximal deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Distal deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Major bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Major bleeding leading to reoperation | 0 | --- | --- | --- | --- | --- | Insufficient
Minor bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Surgical site bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Bleeding leading to infection | 0 | --- | --- | --- | --- | --- | Insufficient
Bleeding leading to transfusion | 0 | --- | --- | --- | --- | --- | Insufficient

Abbreviations: NA=not applicable; OBS=observational; VTE=venous thromboembolism

Table 55 Strength of evidence for the impact of peripheral vascular disease on the risk of venous thromboembolic or bleeding outcomes

| | | Quality Assessment | | | | Summary of Findings
Outcome | Number of studies | Design | Risk of Bias | Consistency | Directness | Precision | Quality
Symptomatic objectively confirmed VTE | 0 | --- | --- | --- | --- | --- | Insufficient
Major VTE | 0 | --- | --- | --- | --- | --- | Insufficient
Pulmonary Embolism | 1 | OBS | Serious limitation | NA | No indirectness | NA | Insufficient
Fatal pulmonary embolism | 0 | --- | --- | --- | --- | --- | Insufficient
Nonfatal pulmonary embolism | 0 | --- | --- | --- | --- | --- | Insufficient
Deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Asymptomatic deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Symptomatic deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Proximal deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Distal deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Major bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Major bleeding leading to reoperation | 0 | --- | --- | --- | --- | --- | Insufficient
Minor bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Surgical site bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Bleeding leading to infection | 0 | --- | --- | --- | --- | --- | Insufficient
Bleeding leading to transfusion | 0 | --- | --- | --- | --- | --- | Insufficient

Abbreviations: NA=not applicable; OBS=observational; VTE=venous thromboembolism

Table 56 Strength of evidence for the impact of weight on the risk of venous thromboembolic or bleeding outcomes

| | | Quality Assessment | | | | Summary of Findings
Outcome | Number of studies | Design | Risk of Bias | Consistency | Directness | Precision | Quality
Symptomatic objectively confirmed VTE | 0 | --- | --- | --- | --- | --- | Insufficient
Major VTE | 0 | --- | --- | --- | --- | --- | Insufficient
Pulmonary Embolism | 0 | --- | --- | --- | --- | --- | Insufficient
Fatal pulmonary embolism | 0 | --- | --- | --- | --- | --- | Insufficient
Nonfatal pulmonary embolism | 0 | --- | --- | --- | --- | --- | Insufficient
Deep vein thrombosis | 3 | OBS | Very serious limitations | Serious inconsistency | No indirectness | NA | Insufficient
Asymptomatic deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Symptomatic deep vein thrombosis | 1 | OBS | No limitations | NA | No indirectness | NA | Insufficient
Proximal deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Distal deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Major bleeding | 1 | OBS | Very serious limitations | NA | No indirectness | NA | Insufficient
Major bleeding leading to reoperation | 0 | --- | --- | --- | --- | --- | Insufficient
Minor bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Surgical site bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Bleeding leading to infection | 0 | --- | --- | --- | --- | --- | Insufficient
Bleeding leading to transfusion | 0 | --- | --- | --- | --- | --- | Insufficient

Abbreviations: NA=not applicable; OBS=observational; VTE=venous thromboembolism

Table 57 Strength of evidence for the impact of smoking on the risk of venous thromboembolic or bleeding outcomes

| | | Quality Assessment | | | | Summary of Findings
Outcome | Number of studies | Design | Risk of Bias | Consistency | Directness | Precision | Quality
Symptomatic objectively confirmed VTE | 0 | --- | --- | --- | --- | --- | Insufficient
Major VTE | 0 | --- | --- | --- | --- | --- | Insufficient
Pulmonary Embolism | 0 | --- | --- | --- | --- | --- | Insufficient
Fatal pulmonary embolism | 0 | --- | --- | --- | --- | --- | Insufficient
Nonfatal pulmonary embolism | 0 | --- | --- | --- | --- | --- | Insufficient
Deep vein thrombosis | 1 | OBS | Serious limitations | NA | No indirectness | NA | Insufficient
Asymptomatic deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Symptomatic deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Proximal deep vein thrombosis | 1 | OBS | Serious limitations | NA | No indirectness | NA | Insufficient
Distal deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Major bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Major bleeding leading to reoperation | 0 | --- | --- | --- | --- | --- | Insufficient
Minor bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Surgical site bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Bleeding leading to infection | 0 | --- | --- | --- | --- | --- | Insufficient
Bleeding leading to transfusion | 0 | --- | --- | --- | --- | --- | Insufficient

Abbreviations: NA=not applicable; OBS=observational; VTE=venous thromboembolism

Table 58 Strength of evidence for the impact of height on the risk of venous thromboembolic or bleeding outcomes

| | | Quality Assessment | | | | Summary of Findings
Outcome | Number of studies | Design | Risk of Bias | Consistency | Directness | Precision | Quality
Symptomatic objectively confirmed VTE | 0 | --- | --- | --- | --- | --- | Insufficient
Major VTE | 0 | --- | --- | --- | --- | --- | Insufficient
Pulmonary Embolism | 0 | --- | --- | --- | --- | --- | Insufficient
Fatal pulmonary embolism | 0 | --- | --- | --- | --- | --- | Insufficient
Nonfatal pulmonary embolism | 0 | --- | --- | --- | --- | --- | Insufficient
Deep vein thrombosis | 1 | OBS | Serious limitations | NA | No indirectness | NA | Insufficient
Asymptomatic deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Symptomatic deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Proximal deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Distal deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Major bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Major bleeding leading to reoperation | 0 | --- | --- | --- | --- | --- | Insufficient
Minor bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Surgical site bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Bleeding leading to infection | 0 | --- | --- | --- | --- | --- | Insufficient
Bleeding leading to transfusion | 0 | --- | --- | --- | --- | --- | Insufficient

Abbreviations: NA=not applicable; OBS=observational; VTE=venous thromboembolism

Table 59 Strength of evidence for the impact of factor V Leiden mutation on the risk of venous thromboembolic or bleeding outcomes

| | | Quality Assessment | | | | Summary of Findings
Outcome | Number of studies | Design | Risk of Bias | Consistency | Directness | Precision | Quality
Symptomatic objectively confirmed VTE | 0 | --- | --- | --- | --- | --- | Insufficient
Major VTE | 0 | --- | --- | --- | --- | --- | Insufficient
Pulmonary Embolism | 0 | --- | --- | --- | --- | --- | Insufficient
Fatal pulmonary embolism | 0 | --- | --- | --- | --- | --- | Insufficient
Nonfatal pulmonary embolism | 0 | --- | --- | --- | --- | --- | Insufficient
Deep vein thrombosis | 1 | OBS | No limitations | NA | No indirectness | NA | Insufficient
Asymptomatic deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Symptomatic deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Proximal deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Distal deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Major bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Major bleeding leading to reoperation | 0 | --- | --- | --- | --- | --- | Insufficient
Minor bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Surgical site bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Bleeding leading to infection | 0 | --- | --- | --- | --- | --- | Insufficient
Bleeding leading to transfusion | 0 | --- | --- | --- | --- | --- | Insufficient

Abbreviations: NA=not applicable; OBS=observational; VTE=venous thromboembolism

Table 60 Strength of evidence for the impact of blood disorders on the risk of venous thromboembolic or bleeding outcomes

| | | Quality Assessment | | | | Summary of Findings
Outcome | Number of studies | Design | Risk of Bias | Consistency | Directness | Precision | Quality
Symptomatic objectively confirmed VTE | 0 | --- | --- | --- | --- | --- | Insufficient
Major VTE | 0 | --- | --- | --- | --- | --- | Insufficient
Pulmonary Embolism | 0 | --- | --- | --- | --- | --- | Insufficient
Fatal pulmonary embolism | 0 | --- | --- | --- | --- | --- | Insufficient
Nonfatal pulmonary embolism | 0 | --- | --- | --- | --- | --- | Insufficient
Deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Asymptomatic deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Symptomatic deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Proximal deep vein thrombosis | 1 | OBS | Serious limitations | NA | No indirectness | NA | Insufficient
Distal deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Major bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Major bleeding leading to reoperation | 0 | --- | --- | --- | --- | --- | Insufficient
Minor bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Surgical site bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Bleeding leading to infection | 0 | --- | --- | --- | --- | --- | Insufficient
Bleeding leading to transfusion | 0 | --- | --- | --- | --- | --- | Insufficient

Abbreviations: NA=not applicable; OBS=observational; VTE=venous thromboembolism

Table 61 Strength of evidence for the impact of metabolic syndrome on the risk of venous thromboembolic or bleeding outcomes

| | | Quality Assessment | | | | Summary of Findings
Outcome | Number of studies | Design | Risk of Bias | Consistency | Directness | Precision | Quality
Symptomatic objectively confirmed VTE | 0 | --- | --- | --- | --- | --- | Insufficient
Major VTE | 0 | --- | --- | --- | --- | --- | Insufficient
Pulmonary Embolism | 0 | --- | --- | --- | --- | --- | Insufficient
Fatal pulmonary embolism | 0 | --- | --- | --- | --- | --- | Insufficient
Nonfatal pulmonary embolism | 0 | --- | --- | --- | --- | --- | Insufficient
Deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Asymptomatic deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Symptomatic deep vein thrombosis | 1 | OBS | No limitations | NA | No indirectness | NA | Insufficient
Proximal deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Distal deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Major bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Major bleeding leading to reoperation | 0 | --- | --- | --- | --- | --- | Insufficient
Minor bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Surgical site bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Bleeding leading to infection | 0 | --- | --- | --- | --- | --- | Insufficient
Bleeding leading to transfusion | 0 | --- | --- | --- | --- | --- | Insufficient

Abbreviations: NA=not applicable; OBS=observational; VTE=venous thromboembolism

Table 62 Strength of evidence for the impact of education on the risk of venous thromboembolic or bleeding outcomes

| | | Quality Assessment | | | | Summary of Findings
Outcome | Number of studies | Design | Risk of Bias | Consistency | Directness | Precision | Quality
Symptomatic objectively confirmed VTE | 0 | --- | --- | --- | --- | --- | Insufficient
Major VTE | 0 | --- | --- | --- | --- | --- | Insufficient
Pulmonary Embolism | 0 | --- | --- | --- | --- | --- | Insufficient
Fatal pulmonary embolism | 0 | --- | --- | --- | --- | --- | Insufficient
Nonfatal pulmonary embolism | 0 | --- | --- | --- | --- | --- | Insufficient
Deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Asymptomatic deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Symptomatic deep vein thrombosis | 1 | OBS | No limitations | NA | No indirectness | NA | Insufficient
Proximal deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Distal deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Major bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Major bleeding leading to reoperation | 0 | --- | --- | --- | --- | --- | Insufficient
Minor bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Surgical site bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Bleeding leading to infection | 0 | --- | --- | --- | --- | --- | Insufficient
Bleeding leading to transfusion | 0 | --- | --- | --- | --- | --- | Insufficient

Abbreviations: NA=not applicable; OBS=observational; VTE=venous thromboembolism

Table 63 Strength of evidence for the impact of diabetes mellitus on the risk of venous thromboembolic or bleeding outcomes

| | | Quality Assessment | | | | Summary of Findings
Outcome | Number of studies | Design | Risk of Bias | Consistency | Directness | Precision | Quality
Symptomatic objectively confirmed VTE | 0 | --- | --- | --- | --- | --- | Insufficient
Major VTE | 0 | --- | --- | --- | --- | --- | Insufficient
Pulmonary Embolism | 0 | --- | --- | --- | --- | --- | Insufficient
Fatal pulmonary embolism | 0 | --- | --- | --- | --- | --- | Insufficient
Nonfatal pulmonary embolism | 0 | --- | --- | --- | --- | --- | Insufficient
Deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Asymptomatic deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Symptomatic deep vein thrombosis | 1 | OBS | No limitations | NA | No indirectness | NA | Insufficient
Proximal deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Distal deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Major bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Major bleeding leading to reoperation | 0 | --- | --- | --- | --- | --- | Insufficient
Minor bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Surgical site bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Bleeding leading to infection | 0 | --- | --- | --- | --- | --- | Insufficient
Bleeding leading to transfusion | 0 | --- | --- | --- | --- | --- | Insufficient

Abbreviations: NA=not applicable; OBS=observational; VTE=venous thromboembolism

Table 64 Strength of evidence for the impact of hypertension on the risk of venous thromboembolic or bleeding outcomes

| | | Quality Assessment | | | | Summary of Findings
Outcome | Number of studies | Design | Risk of Bias | Consistency | Directness | Precision | Quality
Symptomatic objectively confirmed VTE | 0 | --- | --- | --- | --- | --- | Insufficient
Major VTE | 0 | --- | --- | --- | --- | --- | Insufficient
Pulmonary Embolism | 0 | --- | --- | --- | --- | --- | Insufficient
Fatal pulmonary embolism | 0 | --- | --- | --- | --- | --- | Insufficient
Nonfatal pulmonary embolism | 0 | --- | --- | --- | --- | --- | Insufficient
Deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Asymptomatic deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Symptomatic deep vein thrombosis | 1 | OBS | No limitations | NA | No indirectness | NA | Insufficient
Proximal deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Distal deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Major bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Major bleeding leading to reoperation | 0 | --- | --- | --- | --- | --- | Insufficient
Minor bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Surgical site bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Bleeding leading to infection | 0 | --- | --- | --- | --- | --- | Insufficient
Bleeding leading to transfusion | 0 | --- | --- | --- | --- | --- | Insufficient

Abbreviations: NA=not applicable; OBS=observational; VTE=venous thromboembolism

Table 65 Strength of evidence for the impact of hyperlipidemia on the risk of venous thromboembolic or bleeding outcomes

| | | Quality Assessment | | | | Summary of Findings
Outcome | Number of studies | Design | Risk of Bias | Consistency | Directness | Precision | Quality
Symptomatic objectively confirmed VTE | 0 | --- | --- | --- | --- | --- | Insufficient
Major VTE | 0 | --- | --- | --- | --- | --- | Insufficient
Pulmonary Embolism | 0 | --- | --- | --- | --- | --- | Insufficient
Fatal pulmonary embolism | 0 | --- | --- | --- | --- | --- | Insufficient
Nonfatal pulmonary embolism | 0 | --- | --- | --- | --- | --- | Insufficient
Deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Asymptomatic deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Symptomatic deep vein thrombosis | 1 | OBS | No limitations | NA | No indirectness | NA | Insufficient
Proximal deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Distal deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Major bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Major bleeding leading to reoperation | 0 | --- | --- | --- | --- | --- | Insufficient
Minor bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Surgical site bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Bleeding leading to infection | 0 | --- | --- | --- | --- | --- | Insufficient
Bleeding leading to transfusion | 0 | --- | --- | --- | --- | --- | Insufficient

Abbreviations: NA=not applicable; OBS=observational; VTE=venous thromboembolism

Table 66 Strength of evidence for the impact of comorbidities on the risk of venous thromboembolic or bleeding outcomes

| | | Quality Assessment | | | | Summary of Findings
Outcome | Number of studies | Design | Risk of Bias | Consistency | Directness | Precision | Quality
Symptomatic objectively confirmed VTE | 0 | --- | --- | --- | --- | --- | Insufficient
Major VTE | 0 | --- | --- | --- | --- | --- | Insufficient
Pulmonary Embolism | 0 | --- | --- | --- | --- | --- | Insufficient
Fatal pulmonary embolism | 0 | --- | --- | --- | --- | --- | Insufficient
Nonfatal pulmonary embolism | 0 | --- | --- | --- | --- | --- | Insufficient
Deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Asymptomatic deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Symptomatic deep vein thrombosis | 1 | OBS | No limitations | NA | No indirectness | NA | Insufficient
Proximal deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Distal deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Major bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Major bleeding leading to reoperation | 0 | --- | --- | --- | --- | --- | Insufficient
Minor bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Surgical site bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Bleeding leading to infection | 0 | --- | --- | --- | --- | --- | Insufficient
Bleeding leading to transfusion | 0 | --- | --- | --- | --- | --- | Insufficient

Abbreviations: NA=not applicable; OBS=observational; VTE=venous thromboembolism

Table 67 Strength of evidence for the impact of risk of bleeding on the risk of venous thromboembolic or bleeding outcomes

| | | Quality Assessment | | | | Summary of Findings
Outcome | Number of studies | Design | Risk of Bias | Consistency | Directness | Precision | Quality
Symptomatic objectively confirmed VTE | 0 | --- | --- | --- | --- | --- | Insufficient
Major VTE | 0 | --- | --- | --- | --- | --- | Insufficient
Pulmonary Embolism | 0 | --- | --- | --- | --- | --- | Insufficient
Fatal pulmonary embolism | 0 | --- | --- | --- | --- | --- | Insufficient
Nonfatal pulmonary embolism | 0 | --- | --- | --- | --- | --- | Insufficient
Deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Asymptomatic deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Symptomatic deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Proximal deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Distal deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Major bleeding | 1 | OBS | Very serious limitations | NA | No indirectness | NA | Insufficient
Major bleeding leading to reoperation | 0 | --- | --- | --- | --- | --- | Insufficient
Minor bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Surgical site bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Bleeding leading to infection | 0 | --- | --- | --- | --- | --- | Insufficient
Bleeding leading to transfusion | 0 | --- | --- | --- | --- | --- | Insufficient

Abbreviations: NA=not applicable; OBS=observational; VTE=venous thromboembolism

Table 68 Strength of evidence for the impact of surgical procedure on the risk of venous thromboembolic or bleeding outcomes

| | | Quality Assessment | | | | Summary of Findings
Outcome | Number of studies | Design | Risk of Bias | Consistency | Directness | Precision | Quality
Symptomatic objectively confirmed VTE | 0 | --- | --- | --- | --- | --- | Insufficient
Major VTE | 0 | --- | --- | --- | --- | --- | Insufficient
Pulmonary Embolism | 0 | --- | --- | --- | --- | --- | Insufficient
Fatal pulmonary embolism | 0 | --- | --- | --- | --- | --- | Insufficient
Nonfatal pulmonary embolism | 0 | --- | --- | --- | --- | --- | Insufficient
Deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Asymptomatic deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Symptomatic deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Proximal deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Distal deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Major bleeding | 1 | OBS | Very serious limitations | NA | No indirectness | NA | Insufficient
Major bleeding leading to reoperation | 0 | --- | --- | --- | --- | --- | Insufficient
Minor bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Surgical site bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Bleeding leading to infection | 0 | --- | --- | --- | --- | --- | Insufficient
Bleeding leading to transfusion | 0 | --- | --- | --- | --- | --- | Insufficient

Abbreviations: NA=not applicable; OBS=observational; VTE=venous thromboembolism

Table 69 Strength of evidence for the impact of type of prophylaxis on the risk of venous thromboembolic or bleeding outcomes

| | | Quality Assessment | | | | Summary of Findings
Outcome | Number of studies | Design | Risk of Bias | Consistency | Directness | Precision | Quality
Symptomatic objectively confirmed VTE | 0 | --- | --- | --- | --- | --- | Insufficient
Major VTE | 0 | --- | --- | --- | --- | --- | Insufficient
Pulmonary Embolism | 0 | --- | --- | --- | --- | --- | Insufficient
Fatal pulmonary embolism | 0 | --- | --- | --- | --- | --- | Insufficient
Nonfatal pulmonary embolism | 0 | --- | --- | --- | --- | --- | Insufficient
Deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Asymptomatic deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Symptomatic deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Proximal deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Distal deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Major bleeding | 1 | OBS | Very serious limitations | NA | No indirectness | NA | Insufficient
Major bleeding leading to reoperation | 0 | --- | --- | --- | --- | --- | Insufficient
Minor bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Surgical site bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Bleeding leading to infection | 0 | --- | --- | --- | --- | --- | Insufficient
Bleeding leading to transfusion | 0 | --- | --- | --- | --- | --- | Insufficient

Abbreviations: NA=not applicable; OBS=observational; VTE=venous thromboembolism

Table 70 Strength of evidence for the causal link between deep vein thrombosis and pulmonary embolism in major orthopedic surgery

| | | Quality Assessment | | | | Summary of Findings
Outcome | Number of studies | Design | Risk of Bias | Consistency | Directness | Precision | Quality
Symptomatic objectively confirmed VTE | 11 (9,2) | RCT, OBS | Serious risk of bias | Serious inconsistency | Indirectness | NA | Insufficient

Abbreviations: RCT: randomized controlled trial; VTE=venous thromboembolism

Table 71 Strength of evidence for final, intermediate and adverse outcomes comparing pharmacologic prophylaxis to no prophylaxis in patients who had major orthopedic surgery

| | | Quality Assessment | | | | Summary of Findings
Outcome | Number of studies | Design | Risk of Bias | Consistency | Directness | Precision | Quality
Symptomatic objectively confirmed VTE | 1 | RCT | Serious limitation | NA | No indirectness | Very serious imprecision | Insufficient
Major VTE | 1 | RCT | No limitations | Serious limitation | No indirectness | Serious imprecision | Low
Pulmonary Embolism | 12 | RCT | No limitations | No inconsistency | No indirectness | Very serious imprecision | Low
Fatal pulmonary embolism | 7 (6,1) | RCT, OBS | No limitations | NA | No indirectness | Very serious imprecision | Insufficient
Nonfatal pulmonary embolism | 7 (6,1) | RCT, OBS | No limitations | No serious inconsistency | No indirectness | Very serious imprecision | Low
Post thrombotic syndrome | 0 | --- | --- | --- | --- | --- | Insufficient
Mortality | 13 (10, 3) | RCT , OBS | No limitations | No serious inconsistency | No indirectness | Serious imprecision | Moderate
Mortality due to bleeding | 10 (9,1) | RCT, OBS | No limitations | NA | No indirectness | Very serious imprecision | Insufficient
Health related quality of life | 0 | --- | --- | --- | --- | --- | Insufficient
Deep vein thrombosis | 17 | RCT | Serious limitations | Serious inconsistency | No indirectness | No imprecision | Moderate
Asymptomatic deep vein thrombosis | 3 | RCT | No limitations | No inconsistency | No indirectness | No imprecision | Moderate
Symptomatic deep vein thrombosis | 5 (4,1) | RCT, OBS | No limitations | No inconsistency | No indirectness | Serious imprecision | Moderate
Proximal deep vein thrombosis | 12 | RCT | No limitations | No inconsistency | No indirectness | No imprecision | High
Distal deep vein thrombosis | 7 | RCT | No limitations | No inconsistency | No indirectness | No imprecision | High
Major bleeding | 9 (8,1) | RCT, OBS | No limitations | No inconsistency | No indirectness | Serious imprecision | Moderate
Major bleeding leading to reoperation | 2 | RCT | No limitations | NA | No indirectness | Very serious imprecision | Insufficient
Minor bleeding | 6 | RCT | No limitations | No inconsistency | No indirectness | No imprecision | High
Surgical site bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Bleeding leading to infection | 0 | --- | --- | --- | --- | --- | Insufficient
Bleeding leading to transfusion | 1 | RCT | No limitations | NA | No indirectness | Very serious imprecision | Insufficient
Heparin-induced thrombocytopenia | 0 | --- | --- | --- | --- | --- | Insufficient
Discomfort | 0 | --- | --- | --- | --- | --- | Insufficient
Readmission | 1 | OBS | Serious risk of bias | NA | No indirectness | NA | Insufficient
Reoperation | 1 | OBS | Serious risk of bias | NA | No indirectness | NA | Insufficient

Abbreviations: NA=not applicable; RCT= randomized controlled trial; OBS=observational; VTE=venous thromboembolism

Table 72 Strength of evidence for final, intermediate and adverse outcomes comparing mechanical prophylaxis to no prophylaxis in patients who had major orthopedic surgery

| | | Quality Assessment | | | | Summary of Findings
Outcome | Number of studies | Design | Risk of Bias | Consistency | Directness | Precision | Quality
Symptomatic objectively confirmed VTE | 0 | --- | --- | --- | --- | --- | Insufficient
Major VTE | 0 | --- | --- | --- | --- | --- | Insufficient
Pulmonary Embolism | 1 | RCT | Serious limitation | NA | No indirectness | NA | Insufficient
Fatal pulmonary embolism | 1 | RCT | Serious limitation | NA | No indirectness | Serious imprecision | Insufficient
Nonfatal pulmonary embolism | 1 | RCT | Serious limitation | NA | No indirectness | Serious imprecision | Insufficient
Post thrombotic syndrome | 0 | --- | --- | --- | --- | --- | Insufficient
Mortality | 0 | --- | --- | --- | --- | --- | Insufficient
Mortality due to bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Health related quality of life | 0 | --- | --- | --- | --- | --- | Insufficient
Deep vein thrombosis | 1 | RCT | No limitation | NA | No indirectness | No imprecision | Insufficient
Asymptomatic deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Symptomatic deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Proximal deep vein thrombosis | 1 | RCT | No limitation | NA | No indirectness | Serious imprecision | Insufficient
Distal deep vein thrombosis | 1 | RCT | No limitation | NA | No indirectness | Serious imprecision | Insufficient
Major bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Major bleeding leading to reoperation | 0 | --- | --- | --- | --- | --- | Insufficient
Minor bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Surgical site bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Bleeding leading to infection | 0 | --- | --- | --- | --- | --- | Insufficient
Bleeding leading to transfusion | 0 | --- | --- | --- | --- | --- | Insufficient
Heparin-induced thrombocytopenia | 0 | --- | --- | --- | --- | --- | Insufficient
Discomfort | 0 | --- | --- | --- | --- | --- | Insufficient
Readmission | 0 | --- | --- | --- | --- | --- | Insufficient
Reoperation | 0 | --- | --- | --- | --- | --- | Insufficient

Abbreviations: NA=not applicable; RCT=randomized controlled trial; VTE=venous thromboembolism

Table 73 Strength of evidence for final, intermediate and adverse outcomes comparing oral antiplatelet agents prophylaxis to oral vitamin K antagonists prophylaxis in patients who had major orthopedic surgery

| | | Quality Assessment | | | | Summary of Findings
Outcome | Number of studies | Design | Risk of Bias | Consistency | Directness | Precision | Quality
Symptomatic objectively confirmed VTE | 0 | --- | --- | --- | --- | --- | Insufficient
Major VTE | 0 | --- | --- | --- | --- | --- | Insufficient
Pulmonary Embolism | 1 | RCT | No limitations | NA | No indirectness | Very serious imprecision | Insufficient
Fatal pulmonary embolism | 2 (1,1) | RCT, OBS | No limitations | NA | No indirectness | Very serious imprecision | Insufficient
Nonfatal pulmonary embolism | 2 (1,1) | RCT, OBS | No limitations | NA | No indirectness | NA | Insufficient
Post thrombotic syndrome | 0 | --- | --- | --- | --- | --- | Insufficient
Mortality | 3 (1, 2) | RCT, OBS | No limitations | NA | No indirectness | Very serious imprecision | Insufficient
Mortality due to bleeding | 1 | RCT | No limitations | NA | No indirectness | NA | Insufficient
Health related quality of life | 0 | --- | --- | --- | --- | --- | Insufficient
Deep vein thrombosis | 1 | RCT | Serious limitation | NA | No indirectness | Serious imprecision | Insufficient
Asymptomatic deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Symptomatic deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Proximal deep vein thrombosis | 1 | RCT | Serious limitation | NA | No indirectness | Serious imprecision | Insufficient
Distal deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Major bleeding | 1 | RCT | No limitations | NA | No indirectness | Serious imprecision | Insufficient
Major bleeding leading to reoperation | 0 | --- | --- | --- | --- | --- | Insufficient
Minor bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Surgical site bleeding | 1 | OBS | No limitations | NA | No indirectness | Serious imprecision | Insufficient
Bleeding leading to infection | 0 | --- | --- | --- | --- | --- | Insufficient
Bleeding leading to transfusion | 0 | --- | --- | --- | --- | --- | Insufficient
Heparin-induced thrombocytopenia | 0 | --- | --- | --- | --- | --- | Insufficient
Discomfort | 0 | --- | --- | --- | --- | --- | Insufficient
Readmission | 0 | --- | --- | --- | --- | --- | Insufficient
Reoperation | 0 | --- | --- | --- | --- | --- | Insufficient

Abbreviations: NA=not applicable; RCT: randomized controlled trial; OBS=observational; VTE=venous thromboembolism

Table 74 Strength of evidence for final, intermediate and adverse outcomes comparing oral antiplatelet agents prophylaxis to mechanical prophylaxis in patients who had major orthopedic surgery

| | | Quality Assessment | | | | Summary of Findings
Outcome | Number of studies | Design | Risk of Bias | Consistency | Directness | Precision | Quality
Symptomatic objectively confirmed VTE | 0 | --- | --- | --- | --- | --- | Insufficient
Major VTE | 0 | --- | --- | --- | --- | --- | Insufficient
Pulmonary Embolism | 1 | RCT | Serious limitation | NA | No indirectness | Very serious imprecision | Insufficient
Fatal pulmonary embolism | 0 | --- | --- | --- | --- | --- | Insufficient
Nonfatal pulmonary embolism | 0 | --- | --- | --- | --- | --- | Insufficient
Post thrombotic syndrome | 0 | --- | --- | --- | --- | --- | Insufficient
Mortality | 0 | --- | --- | --- | --- | --- | Insufficient
Mortality due to bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Health related quality of life | 0 | --- | --- | --- | --- | --- | Insufficient
Deep vein thrombosis | 2 | RCT | Serious limitation | No inconsistency | No indirectness | No imprecision | Moderate
Asymptomatic deep vein thrombosis | 1 | RCT | Serious limitation | NA | No indirectness | Very serious imprecision | Insufficient
Symptomatic deep vein thrombosis | 1 | RCT | Serious limitation | NA | No indirectness | Very serious imprecision | Insufficient
Proximal deep vein thrombosis | 1 | RCT | Serious limitation | NA | No indirectness | Very serious imprecision | Insufficient
Distal deep vein thrombosis | 1 | RCT | Serious limitation | No inconsistency | No indirectness | No imprecision | Insufficient
Major bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Major bleeding leading to reoperation | 0 | --- | --- | --- | --- | --- | Insufficient
Minor bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Surgical site bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Bleeding leading to infection | 0 | --- | --- | --- | --- | --- | Insufficient
Bleeding leading to transfusion | 0 | --- | --- | --- | --- | --- | Insufficient
Heparin-induced thrombocytopenia | 0 | --- | --- | --- | --- | --- | Insufficient
Discomfort | 0 | --- | --- | --- | --- | --- | Insufficient
Readmission | 0 | --- | --- | --- | --- | --- | Insufficient
Reoperation | 0 | --- | --- | --- | --- | --- | Insufficient

Abbreviations: NA=not applicable; RCT=randomized controlled trial; VTE=venous thromboembolism

Table 75 Strength of evidence for final, intermediate and adverse outcomes comparing injectable low molecular weight heparin prophylaxis to injectable unfractionated heparin prophylaxis in patients who had major orthopedic surgery

| | | Quality Assessment | | | | Summary of Findings
Outcome | Number of studies | Design | Risk of Bias | Consistency | Directness | Precision | Quality
Symptomatic objectively confirmed VTE | 1 | RCT | Serious limitation | NA | No indirectness | Very serious imprecision | Insufficient
Major VTE | 0 | --- | --- | --- | --- | --- | Insufficient
Pulmonary Embolism | 10 | RCT | No limitations | Serious inconsistency | No indirectness | No imprecision | Moderate
Fatal pulmonary embolism | 10 | RCT | Serious limitation | NA | No indirectness | Very serious imprecision | Insufficient
Nonfatal pulmonary embolism | 10 | RCT | No limitations | Serious inconsistency | No indirectness | Serious imprecision | Low
Post thrombotic syndrome | 0 | --- | --- | --- | --- | --- | Insufficient
Mortality | 8 | RCT | No limitations | No inconsistency | No indirectness | Serious imprecision | Moderate
Mortality due to bleeding | 7 | RCT | Serious limitation | NA | No indirectness | Very serious imprecision | Insufficient
Health related quality of life | 0 | --- | --- | --- | --- | --- | Insufficient
Deep vein thrombosis | 14 | RCT | No limitations | No inconsistency | No indirectness | Serious imprecision | Moderate
Asymptomatic deep vein thrombosis | 2 | RCT | Serious limitation | No inconsistency | No indirectness | No imprecision | Low
Symptomatic deep vein thrombosis | 3 | RCT | Serious limitation | No inconsistency | No indirectness | Serious imprecision | Low
Proximal deep vein thrombosis | 9 | RCT | No limitations | No inconsistency | No indirectness | No imprecision | High
Distal deep vein thrombosis | 8 | RCT | No limitations | No inconsistency | No indirectness | No imprecision | High
Major bleeding | 7 | RCT | No limitations | No inconsistency | No indirectness | No imprecision | High
Major bleeding leading to reoperation | 1 | RCT | Serious limitation | NA | No indirectness | NA | Insufficient
Minor bleeding | 5 | RCT | No limitations | No inconsistency | No indirectness | Serious imprecision | Moderate
Surgical site bleeding | 3 | RCT | Serious limitation | No inconsistency | No indirectness | Serious imprecision | Low
Bleeding leading to infection | 0 | --- | --- | --- | --- | --- | Insufficient
Bleeding leading to transfusion | 0 | --- | --- | --- | --- | --- | Insufficient
Heparin-induced thrombocytopenia | 3 | RCT | Serious limitation | No inconsistency | No indirectness | No imprecision | Moderate
Discomfort | 0 | --- | --- | --- | --- | --- | Insufficient
Readmission | 2 | RCT | Serious limitation | No inconsistency | No indirectness | Serious imprecision | Low
Reoperation | 0 | --- | --- | --- | --- | --- | Insufficient

Abbreviations: NA=not applicable; RCT= randomized controlled trial; VTE=venous thromboembolism

Table 76 Strength of evidence for final, intermediate and adverse outcomes comparing injectable low molecular weight heparin prophylaxis to injectable or oral factor Xa inhibitor prophylaxis in patients who had major orthopedic surgery

| | | Quality Assessment | | | | Summary of Findings
Outcome | Number of studies | Design | Risk of Bias | Consistency | Directness | Precision | Quality
Symptomatic objectively confirmed VTE | 5 | RCT | No limitations | No inconsistency | No indirectness | Serious imprecision | Low
Major VTE | 0 | --- | --- | --- | --- | --- | Insufficient
Pulmonary Embolism | 2 | RCT | No limitations | NA | No indirectness | Very serious imprecision | Insufficient
Fatal pulmonary embolism | 5 | RCT | No limitations | No inconsistency | No indirectness | Very serious imprecision | Low
Nonfatal pulmonary embolism | 5 | RCT | No limitations | No inconsistency | No indirectness | Serious imprecision | Moderate
Post thrombotic syndrome | 0 | --- | --- | --- | --- | --- | Insufficient
Mortality | 7 (5, 2) | RCT, OBS | No limitations | No inconsistency | No indirectness | Serious imprecision | Moderate
Mortality due to bleeding | 6 (5,1) | RCT, OBS | Serious limitation | NA | No indirectness | Very serious imprecision | Insufficient
Health related quality of life | 0 | --- | --- | --- | --- | --- | Insufficient
Deep vein thrombosis | 5 | RCT | No limitations | No inconsistency | No indirectness | Serious imprecision | Moderate
Asymptomatic deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Symptomatic deep vein thrombosis | 6 | RCT | No limitations | No inconsistency | No indirectness | Serious imprecision | Moderate
Proximal deep vein thrombosis | 5 | RCT | No limitations | Serious inconsistency | No indirectness | Serious imprecision | Low
Distal deep vein thrombosis | 5 | RCT | No limitations | No inconsistency | No indirectness | Serious imprecision | Moderate
Major bleeding | 7 (5,2) | RCT, OBS | No limitations | Serious inconsistency | No indirectness | No imprecision | Moderate
Major bleeding leading to reoperation | 4 | RCT | No limitation | No inconsistency | No indirectness | Serious imprecision | Moderate
Minor bleeding | 2 | RCT | Serious limitations | No inconsistency | No indirectness | Serious imprecision | Low
Surgical site bleeding | 1 | RCT | No limitations | NA | No indirectness | Serious imprecision | Insufficient
Bleeding leading to infection | 0 | --- | --- | --- | --- | --- | Insufficient
Bleeding leading to transfusion | 0 | --- | --- | --- | --- | --- | Insufficient
Heparin-induced thrombocytopenia | 0 | --- | --- | --- | --- | --- | Insufficient
Discomfort | 0 | --- | --- | --- | --- | --- | Insufficient
Readmission | 0 | --- | --- | --- | --- | --- | Insufficient
Reoperation | 1 | RCT | Serious limitation | NA | No indirectness | Serious imprecision | Insufficient

Abbreviations: NA=not applicable; RCT=randomized controlled trial; VTE=venous thromboembolism

Table 77 Strength of evidence for final, intermediate and adverse outcomes comparing injectable low molecular weight heparin prophylaxis to injectable or oral direct thrombin inhibitors prophylaxis in patients who had major orthopedic surgery

| | | Quality Assessment | | | | Summary of Findings
Outcome | Number of studies | Design | Risk of Bias | Consistency | Directness | Precision | Quality
Symptomatic objectively confirmed VTE | 0 | --- | --- | --- | --- | --- | Insufficient
Major VTE | 3 | RCT | No limitations | No inconsistency | No indirectness | Serious imprecision | Moderate
Pulmonary Embolism | 3 | RCT | No limitations | No inconsistency | No indirectness | Serious imprecision | Moderate
Fatal pulmonary embolism | 3 | RCT | No limitations | No inconsistency | No indirectness | Very serious imprecision | Low
Nonfatal pulmonary embolism | 2 | RCT | No limitations | Serious inconsistency | No indirectness | Serious imprecision | Low
Post thrombotic syndrome | 0 | --- | --- | --- | --- | --- | Insufficient
Mortality | 5 | RCT | No limitation | No inconsistency | No indirectness | Serious imprecision | Moderate
Mortality due to bleeding | 3 | RCT | No limitations | NA | No indirectness | Very serious imprecision | Insufficient
Health related quality of life | 0 | --- | --- | --- | --- | --- | Insufficient
Deep vein thrombosis | 1 | RCT | No limitations | NA | No indirectness | No imprecision | Insufficient
Asymptomatic deep vein thrombosis | 2 | RCT | No limitations | No inconsistency | No indirectness | Serious imprecision | Moderate
Symptomatic deep vein thrombosis | 4 | RCT | No limitations | No inconsistency | No indirectness | Serious imprecision | Moderate
Proximal deep vein thrombosis | 3 | RCT | No limitations | Serious inconsistency | No indirectness | Serious imprecision | Low
Distal deep vein thrombosis | 1 | RCT | No limitations | No inconsistency | No indirectness | No imprecision | Insufficient
Major bleeding | 4 | RCT | No limitations | No inconsistency | No indirectness | Serious imprecision | Moderate
Major bleeding leading to reoperation | 3 | RCT | No limitations | No inconsistency | No indirectness | Serious imprecision | Moderate
Minor bleeding | 3 | RCT | No limitations | No inconsistency | No indirectness | Serious imprecision | Moderate
Surgical site bleeding | 1 | RCT | No limitations | No inconsistency | No indirectness | Very serious imprecision | Insufficient
Bleeding leading to infection | 0 | --- | --- | --- | --- | --- | Insufficient
Bleeding leading to transfusion | 2 | RCT | No limitations | No inconsistency | No indirectness | No imprecision | High
Heparin-induced thrombocytopenia | 0 | --- | --- | --- | --- | --- | Insufficient
Discomfort | 0 | --- | --- | --- | --- | --- | Insufficient
Readmission | 0 | --- | --- | --- | --- | --- | Insufficient
Reoperation | 0 | --- | --- | --- | --- | --- | Insufficient

Abbreviations: NA=not applicable; RCT: randomized controlled trial; VTE=venous thromboembolism

Table 78 Strength of evidence for final, intermediate and adverse outcomes comparing injectable low molecular weight heparin prophylaxis to oral vitamin K antagonists prophylaxis in patients who had major orthopedic surgery

| | | Quality Assessment | | | | Summary of Findings
Outcome | Number of studies | Design | Risk of Bias | Consistency | Directness | Precision | Quality
Symptomatic objectively confirmed VTE | 2 | RCT | No limitations | Serious inconsistency | No indirectness | Serious imprecision | Low
Major VTE | 0 | --- | --- | --- | --- | --- | Insufficient
Pulmonary Embolism | 5 | RCT | No limitations | No inconsistency | No indirectness | Serious imprecision | Moderate
Fatal pulmonary embolism | 4 | RCT | Serious limitation | NA | No indirectness | Very serious imprecision | Insufficient
Nonfatal pulmonary embolism | 3 | RCT | No limitations | Serious inconsistency | No indirectness | Serious imprecision | Low
Post thrombotic syndrome | 0 | --- | --- | --- | --- | --- | Insufficient
Mortality | 6 | RCT | No limitations | No inconsistency | No indirectness | Serious imprecision | Moderate
Mortality due to bleeding | 4 | RCT | Serious limitation | NA | No indirectness | Very serious imprecision | Insufficient
Health related quality of life | 0 | --- | --- | --- | --- | --- | Insufficient
Deep vein thrombosis | 5 | RCT | Serious limitation | Serious inconsistency | No indirectness | No imprecision | Low
Asymptomatic deep vein thrombosis | 1 | RCT | No limitations | NA | No indirectness | No imprecision | Insufficient
Symptomatic deep vein thrombosis | 3 | RCT | No limitations | No inconsistency | No indirectness | Serious imprecision | Moderate
Proximal deep vein thrombosis | 6 | RCT | No limitations | Serious inconsistency | No indirectness | Serious imprecision | Low
Distal deep vein thrombosis | 2 | RCT | Serious limitation | No inconsistency | No indirectness | No imprecision | Moderate
Major bleeding | 7 | RCT | No limitations | No inconsistency | No indirectness | No imprecision | High
Major bleeding leading to reoperation | 2 | RCT | Serious limitation | NA | No indirectness | Very serious imprecision | Insufficient
Minor bleeding | 8 | RCT | No limitations | No inconsistency | No indirectness | Serious imprecision | Moderate
Surgical site bleeding | 2 | RCT | Serious limitation | No inconsistency | No indirectness | Serious imprecision | Low
Bleeding leading to infection | 0 | --- | --- | --- | --- | --- | Insufficient
Bleeding leading to transfusion | 1 | RCT | Serious limitation | NA | No indirectness | Serious imprecision | Insufficient
Heparin-induced thrombocytopenia | 1 | RCT | Serious limitation | NA | No indirectness | NA | Insufficient
Discomfort | 0 | --- | --- | --- | --- | --- | Insufficient
Readmission | 0 | --- | --- | --- | --- | --- | Insufficient
Reoperation | 2 | RCT | Serious limitation | NA | No indirectness | Serious imprecision | Insufficient

Abbreviations: NA=not applicable; RCT=randomized controlled trial; VTE=venous thromboembolism

Table 79 Strength of evidence for final, intermediate and adverse outcomes comparing injectable low molecular weight heparin prophylaxis to mechanical prophylaxis in patients who had major orthopedic surgery

| | | Quality Assessment | | | | Summary of Findings
Outcome | Number of studies | Design | Risk of Bias | Consistency | Directness | Precision | Quality
Symptomatic objectively confirmed VTE | 0 | --- | --- | --- | --- | --- | Insufficient
Major VTE | 0 | --- | --- | --- | --- | --- | Insufficient
Pulmonary Embolism | 1 | RCT | No limitations | NA | No indirectness | Very serious imprecision | Insufficient
Fatal pulmonary embolism | 2 | RCT | No limitations | NA | No indirectness | Serious imprecision | Insufficient
Nonfatal pulmonary embolism | 1 | RCT | No limitations | NA | No indirectness | Very serious imprecision | Insufficient
Post thrombotic syndrome | 0 | --- | --- | --- | --- | --- | Insufficient
Mortality | 2 | RCT | No limitations | No inconsistency | No indirectness | Very serious imprecision | Low
Mortality due to bleeding | 2 | RCT | No limitations | NA | No indirectness | Very serious imprecision | Insufficient
Health related quality of life | 0 | --- | --- | --- | --- | --- | Insufficient
Deep vein thrombosis | 3 | RCT | No limitations | No inconsistency | No indirectness | Serious imprecision | Moderate
Asymptomatic deep vein thrombosis | 1 | RCT | Serious limitation | NA | No indirectness | Very serious imprecision | Insufficient
Symptomatic deep vein thrombosis | 2 | RCT | No limitation | NA | No indirectness | Very serious imprecision | Insufficient
Proximal deep vein thrombosis | 3 | RCT | No limitations | No inconsistency | No indirectness | Serious imprecision | Moderate
Distal deep vein thrombosis | 3 | RCT | No limitations | No inconsistency | No indirectness | Serious imprecision | Moderate
Major bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Major bleeding leading to reoperation | 0 | --- | --- | --- | --- | --- | Insufficient
Minor bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Surgical site bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Bleeding leading to infection | 0 | --- | --- | --- | --- | --- | Insufficient
Bleeding leading to transfusion | 0 | --- | --- | --- | --- | --- | Insufficient
Heparin-induced thrombocytopenia | 0 | --- | --- | --- | --- | --- | Insufficient
Discomfort | 1 | RCT | No limitations | NA | No indirectness | No imprecision | Insufficient
Readmission | 2 | RCT | No limitations | No inconsistency | No indirectness | Serious imprecision | Low
Reoperation | 0 | --- | --- | --- | --- | --- | Insufficient

Abbreviations: NA=not applicable; RCT=randomized controlled trial; VTE=venous thromboembolism

Table 80 Strength of evidence for final, intermediate and adverse outcomes comparing injectable unfractionated heparin prophylaxis to injectable or oral direct thrombin inhibitors prophylaxis in patients who had major orthopedic surgery

| | | Quality Assessment | | | | Summary of Findings
Outcome | Number of studies | Design | Risk of Bias | Consistency | Directness | Precision | Quality
Symptomatic objectively confirmed VTE | 0 | --- | --- | --- | --- | --- | Insufficient
Major VTE | 0 | --- | --- | --- | --- | --- | Insufficient
Pulmonary Embolism | 2 | RCT | No limitations | Serious inconsistency | No indirectness | Very serious imprecision | Low
Fatal pulmonary embolism | 2 | RCT | No limitations | NA | No indirectness | NA | Insufficient
Nonfatal pulmonary embolism | 2 | RCT | No limitations | Serious inconsistency | No indirectness | Very serious imprecision | Low
Post thrombotic syndrome | 0 | --- | --- | --- | --- | --- | Insufficient
Mortality | 2 | RCT | No limitations | No inconsistency | No indirectness | Very serious imprecision | Low
Mortality due to bleeding | 2 | RCT | No limitations | NA | No indirectness | NA | Insufficient
Health related quality of life | 0 | --- | --- | --- | --- | --- | Insufficient
Deep vein thrombosis | 2 | RCT | No limitations | No inconsistency | No indirectness | Serious imprecision | Moderate
Asymptomatic deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Symptomatic deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Proximal deep vein thrombosis | 2 | RCT | No limitations | No inconsistency | No indirectness | Serious imprecision | Moderate
Distal deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Major bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Major bleeding leading to reoperation | 2 | RCT | Serious limitation | NA | No indirectness | Serious imprecision | Low
Minor bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Surgical site bleeding | 1 | RCT | Serious limitation | NA | No indirectness | Serious imprecision | Insufficient
Bleeding leading to infection | 0 | --- | --- | --- | --- | --- | Insufficient
Bleeding leading to transfusion | 0 | --- | --- | --- | --- | --- | Insufficient
Heparin-induced thrombocytopenia | 0 | --- | --- | --- | --- | --- | Insufficient
Discomfort | 0 | --- | --- | --- | --- | --- | Insufficient
Readmission | 0 | --- | --- | --- | --- | --- | Insufficient
Reoperation | 0 | --- | --- | --- | --- | --- | Insufficient

Abbreviations: NA=not applicable; RCT=randomized controlled trial; VTE=venous thromboembolism

Table 81 Strength of evidence for final, intermediate and adverse outcomes comparing injectable unfractionated heparin prophylaxis to injectable or oral factor Xa inhibitors prophylaxis in patients who had major orthopedic surgery

| | | Quality Assessment | | | | Summary of Findings
Outcome | Number of studies | Design | Risk of Bias | Consistency | Directness | Precision | Quality
Symptomatic objectively confirmed VTE | 0 | --- | --- | --- | --- | --- | Insufficient
Major VTE | 0 | --- | --- | --- | --- | --- | Insufficient
Pulmonary Embolism | 0 | --- | --- | --- | --- | --- | Insufficient
Fatal pulmonary embolism | 0 | --- | --- | --- | --- | --- | Insufficient
Nonfatal pulmonary embolism | 0 | --- | --- | --- | --- | --- | Insufficient
Post thrombotic syndrome | 0 | --- | --- | --- | --- | --- | Insufficient
Mortality | 1 | OBS | Serious limitation | NA | No indirectness | NA | Insufficient
Mortality due to bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Health related quality of life | 0 | --- | --- | --- | --- | --- | Insufficient
Deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Asymptomatic deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Symptomatic deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Proximal deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Distal deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Major bleeding | 1 | OBS | Serious limitation | NA | No indirectness | Serious imprecision | Insufficient
Major bleeding leading to reoperation | 0 | --- | --- | --- | --- | --- | Insufficient
Minor bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Surgical site bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Bleeding leading to infection | 0 | --- | --- | --- | --- | --- | Insufficient
Bleeding leading to transfusion | 0 | --- | --- | --- | --- | --- | Insufficient
Heparin-induced thrombocytopenia | 0 | --- | --- | --- | --- | --- | Insufficient
Discomfort | 0 | --- | --- | --- | --- | --- | Insufficient
Readmission | 0 | --- | --- | --- | --- | --- | Insufficient
Reoperation | 0 | --- | --- | --- | --- | --- | Insufficient

Abbreviations: NA=not applicable; OBS=observational; VTE=venous thromboembolism

Table 82 Strength of evidence for final, intermediate and adverse outcomes comparing injectable unfractionated heparin prophylaxis to mechanical prophylaxis in patients who had major orthopedic surgery

| | | Quality Assessment | | | | Summary of Findings
Outcome | Number of studies | Design | Risk of Bias | Consistency | Directness | Precision | Quality
Symptomatic objectively confirmed VTE | 0 | --- | --- | --- | --- | --- | Insufficient
Major VTE | 0 | --- | --- | --- | --- | --- | Insufficient
Pulmonary Embolism | 0 | --- | --- | --- | --- | --- | Insufficient
Fatal pulmonary embolism | 0 | --- | --- | --- | --- | --- | Insufficient
Nonfatal pulmonary embolism | 0 | --- | --- | --- | --- | --- | Insufficient
Post thrombotic syndrome | 0 | --- | --- | --- | --- | --- | Insufficient
Mortality | 1 | RCT | Serious limitation | NA | No indirectness | Very serious imprecision | Insufficient
Mortality due to bleeding | 1 | RCT | Serious limitation | NA | No indirectness | NA | Insufficient
Health related quality of life | 0 | --- | --- | --- | --- | --- | Insufficient
Deep vein thrombosis | 1 | RCT | Serious limitation | NA | No indirectness | No imprecision | Insufficient
Asymptomatic deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Symptomatic deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Proximal deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Distal deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Major bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Major bleeding leading to reoperation | 0 | --- | --- | --- | --- | --- | Insufficient
Minor bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Surgical site bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Bleeding leading to infection | 0 | --- | --- | --- | --- | --- | Insufficient
Bleeding leading to transfusion | 0 | --- | --- | --- | --- | --- | Insufficient
Heparin-induced thrombocytopenia | 0 | --- | --- | --- | --- | --- | Insufficient
Discomfort | 0 | --- | --- | --- | --- | --- | Insufficient
Readmission | 0 | --- | --- | --- | --- | --- | Insufficient
Reoperation | 0 | --- | --- | --- | --- | --- | Insufficient

Abbreviations: NA=not applicable; RCT=randomized controlled trial; VTE=venous thromboembolism

Table 83 Strength of evidence for final, intermediate and adverse outcomes comparing oral vitamin K antagonists prophylaxis to mechanical prophylaxis in patients who had major orthopedic surgery

| | | Quality Assessment | | | | Summary of Findings
Outcome | Number of studies | Design | Risk of Bias | Consistency | Directness | Precision | Quality
Symptomatic objectively confirmed VTE | 0 | --- | --- | --- | --- | --- | Insufficient
Major VTE | 0 | --- | --- | --- | --- | --- | Insufficient
Pulmonary Embolism | 1 | RCT | Serious limitation | NA | No indirectness | NA | Insufficient
Fatal pulmonary embolism | 1 | RCT | Serious limitation | NA | No indirectness | NA | Insufficient
Nonfatal pulmonary embolism | 1 | RCT | Serious limitation | NA | No indirectness | NA | Insufficient
Post thrombotic syndrome | 0 | --- | --- | --- | --- | --- | Insufficient
Mortality | 2 | RCT | Serious limitation | NA | No indirectness | Very serious imprecision | Insufficient
Mortality due to bleeding | 2 | RCT | Serious limitation | NA | No indirectness | NA | Insufficient
Health related quality of life | 0 | --- | --- | --- | --- | --- | Insufficient
Deep vein thrombosis | 3 | RCT | Serious limitation | Serious inconsistency | No indirectness | Serious imprecision | Low
Asymptomatic deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Symptomatic deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Proximal deep vein thrombosis | 3 | RCT | Serious limitation | No inconsistency | No indirectness | No imprecision | Moderate
Distal deep vein thrombosis | 1 | RCT | Serious limitation | NA | No indirectness | Very serious imprecision | Insufficient
Major bleeding | 1 | RCT | Serious limitation | NA | No indirectness | NA | Insufficient
Major bleeding leading to reoperation | 1 | RCT | Serious limitation | NA | No indirectness | NA | Insufficient
Minor bleeding | 2 | RCT | Serious limitation | No inconsistency | No indirectness | Serious imprecision | Low
Surgical site bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Bleeding leading to infection | 0 | --- | --- | --- | --- | --- | Insufficient
Bleeding leading to transfusion | 1 | RCT | Serious limitation | NA | No indirectness | NA | Insufficient
Heparin-induced thrombocytopenia | 0 | --- | --- | --- | --- | --- | Insufficient
Discomfort | 0 | --- | --- | --- | --- | --- | Insufficient
Readmission | 1 | RCT | No limitations | NA | No indirectness | Very serious imprecision | Insufficient
Reoperation | 0 | --- | --- | --- | --- | --- | Insufficient

Abbreviations: NA=not applicable; RCT: randomized controlled trial; VTE=venous thromboembolism

Table 84 Strength of evidence for final, intermediate and adverse outcomes comparing enoxaparin prophylaxis to other low molecular weight heparin agents in patients who had major orthopedic surgery

| | | Quality Assessment | | | | Summary of Findings
Outcome | Number of studies | Design | Risk of Bias | Consistency | Directness | Precision | Quality
Symptomatic objectively confirmed VTE | 0 | --- | --- | --- | --- | --- | Insufficient
Major VTE | 0 | --- | --- | --- | --- | --- | Insufficient
Pulmonary Embolism | 1 | RCT | Serious limitation | NA | No indirectness | NA | Insufficient
Fatal pulmonary embolism | 2 | RCT | No limitations | NA | No indirectness | Very serious imprecision | Insufficient
Nonfatal pulmonary embolism | 2 | RCT | No limitations | NA | No indirectness | Very serious imprecision | Insufficient
Post thrombotic syndrome | 0 | --- | --- | --- | --- | --- | Insufficient
Mortality | 1 | RCT | No limitations | NA | No indirectness | Very serious imprecision | Insufficient
Mortality due to bleeding | 1 | RCT | No limitations | NA | No indirectness | NA | Insufficient
Health related quality of life | 0 | --- | --- | --- | --- | --- | Insufficient
Deep vein thrombosis | 2 | RCT | No limitations | Serious inconsistency | No indirectness | Serious imprecision | Low
Asymptomatic deep vein thrombosis | 1 | RCT | Serious limitation | NA | No indirectness | Serious imprecision | Insufficient
Symptomatic deep vein thrombosis | 2 | RCT | No limitations | NA | No indirectness | Serious imprecision | Insufficient
Proximal deep vein thrombosis | 2 | RCT | No limitations | Serious inconsistency | No indirectness | Serious imprecision | Low
Distal deep vein thrombosis | 1 | RCT | No limitations | NA | No indirectness | No imprecision | Insufficient
Major bleeding | 2 | RCT | No limitations | No inconsistency | No indirectness | Serious imprecision | Moderate
Major bleeding leading to reoperation | 0 | --- | --- | --- | --- | --- | Insufficient
Minor bleeding | 1 | RCT | No limitations | NA | No indirectness | Serious imprecision | Insufficient
Surgical site bleeding | 2 | RCT | No limitations | No inconsistency | No indirectness | Very serious imprecision | Low
Bleeding leading to infection | 0 | --- | --- | --- | --- | --- | Insufficient
Bleeding leading to transfusion | 0 | RCT | No limitations | NA | No indirectness | Very serious imprecision | Insufficient
Heparin-induced thrombocytopenia | 1 | --- | --- | --- | --- | --- | Insufficient
Discomfort | 0 | --- | --- | --- | --- | --- | Insufficient
Readmission | 0 | --- | --- | --- | --- | --- | Insufficient
Reoperation | 0 | --- | --- | --- | --- | --- | Insufficient

Abbreviations: NA=not applicable; RCT=randomized controlled trial; VTE=venous thromboembolism

Table 85 Strength of evidence for final, intermediate and adverse outcomes comparing the intermittent pneumatic compression device by Kendall to the Venaflow intermittent pneumatic compression device in patients who had major orthopedic surgery

| | | Quality Assessment | | | | Summary of Findings
Outcome | Number of studies | Design | Risk of Bias | Consistency | Directness | Precision | Quality
Symptomatic objectively confirmed VTE | 0 | --- | --- | --- | --- | --- | Insufficient
Major VTE | 0 | --- | --- | --- | --- | --- | Insufficient
Pulmonary Embolism | 1 | RCT | No limitations | NA | No indirectness | Very serious imprecision | Insufficient
Fatal pulmonary embolism | 1 | RCT | No limitations | NA | No indirectness | Very serious imprecision | Insufficient
Nonfatal pulmonary embolism | 1 | RCT | No limitations | No inconsistency | No indirectness | Very serious imprecision | Insufficient
Post thrombotic syndrome | 0 | --- | --- | --- | --- | --- | Insufficient
Mortality | 1 | RCT | No limitations | NA | No indirectness | Very serious imprecision | Insufficient
Mortality due to bleeding | 1 | RCT | No limitations | NA | No indirectness | Very serious imprecision | Insufficient
Health related quality of life | 0 | --- | --- | --- | --- | --- | Insufficient
Deep vein thrombosis | 1 | RCT | No limitations | NA | No indirectness | Very serious imprecision | Insufficient
Asymptomatic deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Symptomatic deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Proximal deep vein thrombosis | 1 | RCT | No limitations | NA | No indirectness | Very serious imprecision | Insufficient
Distal deep vein thrombosis | 1 | RCT | No limitations | NA | No indirectness | Very serious imprecision | Insufficient
Major bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Major bleeding leading to reoperation | 0 | --- | --- | --- | --- | --- | Insufficient
Minor bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Surgical site bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Bleeding leading to infection | 0 | --- | --- | --- | --- | --- | Insufficient
Bleeding leading to transfusion | 0 | --- | --- | --- | --- | --- | Insufficient
Heparin-induced thrombocytopenia | 0 | --- | --- | --- | --- | --- | Insufficient
Discomfort | 0 | --- | --- | --- | --- | --- | Insufficient
Readmission | 0 | --- | --- | --- | --- | --- | Insufficient
Reoperation | 0 | --- | --- | --- | --- | --- | Insufficient

Abbreviations: NA=not applicable; RCT=randomized controlled trial; VTE=venous thromboembolism

Table 86 Strength of evidence for final, intermediate and adverse outcomes comparing the ActiveCare intermittent pneumatic compression device to the Flowtron intermittent pneumatic compression device in patients who had major orthopedic surgery

| | | Quality Assessment | | | | Summary of Findings
Outcome | Number of studies | Design | Risk of Bias | Consistency | Directness | Precision | Quality
Symptomatic objectively confirmed VTE | 0 | --- | --- | --- | --- | --- | Insufficient
Major VTE | 0 | --- | --- | --- | --- | --- | Insufficient
Pulmonary Embolism | 0 | --- | --- | --- | --- | --- | Insufficient
Fatal pulmonary embolism | 1 | OBS | Serious limitations | NA | No indirectness | NA | Insufficient
Nonfatal pulmonary embolism | 1 | OBS | Serious limitations | NA | No indirectness | NA | Insufficient
Post thrombotic syndrome | 0 | --- | --- | --- | --- | --- | Insufficient
Mortality | 1 | OBS | Serious limitations | NA | No indirectness | NA | Insufficient
Mortality due to bleeding | 1 | OBS | Serious limitations | NA | No indirectness | NA | Insufficient
Health related quality of life | 0 | --- | --- | --- | --- | --- | Insufficient
Deep vein thrombosis | 1 | OBS | Serious limitations | NA | No indirectness | NA | Insufficient
Asymptomatic deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Symptomatic deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Proximal deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Distal deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Major bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Major bleeding leading to reoperation | 0 | --- | --- | --- | --- | --- | Insufficient
Minor bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Surgical site bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Bleeding leading to infection | 0 | --- | --- | --- | --- | --- | Insufficient
Bleeding leading to transfusion | 0 | --- | --- | --- | --- | --- | Insufficient
Heparin-induced thrombocytopenia | 0 | --- | --- | --- | --- | --- | Insufficient
Discomfort | 0 | --- | --- | --- | --- | --- | Insufficient
Readmission | 0 | --- | --- | --- | --- | --- | Insufficient
Reoperation | 0 | --- | --- | --- | --- | --- | Insufficient

Abbreviations: NA=not applicable; OBS=observational; VTE=venous thromboembolism

Table 87 Strength of evidence for final, intermediate and adverse outcomes comparing intermittent pneumatic compression versus graduated compression stockings in patients who had major orthopedic surgery

| | | Quality Assessment | | | | Summary of Findings
Outcome | Number of studies | Design | Risk of Bias | Consistency | Directness | Precision | Quality
Symptomatic objectively confirmed VTE | 0 | --- | --- | --- | --- | --- | Insufficient
Major VTE | 0 | --- | --- | --- | --- | --- | Insufficient
Pulmonary Embolism | 2 | RCT | Serious limitation | NA | No indirectness | NA | Insufficient
Fatal pulmonary embolism | 2 | RCT | Serious limitation | NA | No indirectness | NA | Insufficient
Nonfatal pulmonary embolism | 2 | RCT | Serious limitation | NA | No indirectness | NA | Insufficient
Post thrombotic syndrome | 0 | --- | --- | --- | --- | --- | Insufficient
Mortality | 0 | --- | --- | --- | --- | --- | Insufficient
Mortality due to bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Health related quality of life | 0 | --- | --- | --- | --- | --- | Insufficient
Deep vein thrombosis | 1 | RCT | Serious limitation | NA | No indirectness | No imprecision | Low
Asymptomatic deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Symptomatic deep vein thrombosis | 1 | RCT | Serious limitation | NA | No indirectness | NA | Insufficient
Proximal deep vein thrombosis | 2 | RCT | Serious limitation | No inconsistency | No indirectness | Serious imprecision | Low
Distal deep vein thrombosis | 1 | RCT | No limitations | No inconsistency | No indirectness | No imprecision | Low
Major bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Major bleeding leading to reoperation | 0 | --- | --- | --- | --- | --- | Insufficient
Minor bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Surgical site bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Bleeding leading to infection | 0 | --- | --- | --- | --- | --- | Insufficient
Bleeding leading to transfusion | 0 | --- | --- | --- | --- | --- | Insufficient
Heparin-induced thrombocytopenia | 0 | --- | --- | --- | --- | --- | Insufficient
Discomfort | 0 | --- | --- | --- | --- | --- | Insufficient
Readmission | 0 | --- | --- | --- | --- | --- | Insufficient
Reoperation | 0 | --- | --- | --- | --- | --- | Insufficient

Abbreviations: NA=not applicable; RCT=randomized controlled trial; VTE=venous thromboembolism

Table 88 Strength of evidence for final, intermediate and adverse outcomes comparing pharmacologic plus mechanical prophylaxis versus pharmacologic prophylaxis alone in patients who had major orthopedic surgery

| | | Quality Assessment | | | | Summary of Findings
Outcome | Number of studies | Design | Risk of Bias | Consistency | Directness | Precision | Quality
Symptomatic objectively confirmed VTE | 0 | --- | --- | --- | --- | --- | Insufficient
Major VTE | 0 | --- | --- | --- | --- | --- | Insufficient
Pulmonary Embolism | 2 | RCT | No limitations | No serious inconsistency | No indirectness | Very serious imprecision | Low
Fatal pulmonary embolism | 2 | RCT | No limitations | NA | No indirectness | NA | Insufficient
Nonfatal pulmonary embolism | 2 | RCT | No limitations | No serious inconsistency | No indirectness | Very serious imprecision | Low
Post thrombotic syndrome | 0 | --- | --- | --- | --- | --- | Insufficient
Mortality | 3 | RCT | No limitations | NA | No indirectness | Very serious imprecision | Insufficient
Mortality due to bleeding | 3 | RCT | No limitations | NA | No indirectness | NA | Insufficient
Health related quality of life | 0 | --- | --- | --- | --- | --- | Insufficient
Deep vein thrombosis | 4 | RCT | No limitations | No serious inconsistency | No indirectness | No imprecision | Moderate
Asymptomatic deep vein thrombosis | 1 | RCT | No limitations | NA | No indirectness | Very serious imprecision | Insufficient
Symptomatic deep vein thrombosis | 1 | RCT | No limitations | NA | No indirectness | Very serious imprecision | Insufficient
Proximal deep vein thrombosis | 5 | RCT | No limitations | No serious inconsistency | No indirectness | Very serious imprecision | Low
Distal deep vein thrombosis | 3 | RCT | No limitations | No serious inconsistency | No indirectness | Serious imprecision | Moderate
Major bleeding | 1 | RCT | No limitations | NA | No indirectness | NA | Insufficient
Major bleeding leading to reoperation | 0 | --- | --- | --- | --- | --- | Insufficient
Minor bleeding | 1 | RCT | No limitations | NA | No indirectness | NA | Insufficient
Surgical site bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Bleeding leading to infection | 0 | --- | --- | --- | --- | --- | Insufficient
Bleeding leading to transfusion | 0 | --- | --- | --- | --- | --- | Insufficient
Heparin-induced thrombocytopenia | 0 | --- | --- | --- | --- | --- | Insufficient
Discomfort | 0 | --- | --- | --- | --- | --- | Insufficient
Reoperation | 0 | --- | --- | --- | --- | --- | Insufficient
Readmission | 0 | --- | --- | --- | --- | --- | Insufficient

Abbreviations: NA=not applicable; RCT=randomized controlled trial; VTE=venous thromboembolism

Table 89 Strength of evidence for final, intermediate and adverse outcomes comparing pharmacologic plus mechanical prophylaxis versus mechanical prophylaxis alone in patients who had major orthopedic surgery

| | | Quality Assessment | | | | Summary of Findings
Outcome | Number of studies | Design | Risk of Bias | Consistency | Directness | Precision | Quality
Symptomatic objectively confirmed VTE | 0 | --- | --- | --- | --- | --- | Insufficient
Major VTE | 0 | --- | --- | --- | --- | --- | Insufficient
Pulmonary Embolism | 1 | RCT | Serious limitations | NA | No indirectness | Very serious imprecision | Insufficient
Fatal pulmonary embolism | 0 | --- | --- | --- | --- | --- | Insufficient
Nonfatal pulmonary embolism | 0 | --- | --- | --- | --- | --- | Insufficient
Post thrombotic syndrome | 0 | --- | --- | --- | --- | --- | Insufficient
Mortality | 1 | RCT | No limitations | NA | No indirectness | Very serious imprecision | Insufficient
Mortality due to bleeding | 1 | RCT | No limitations | NA | No indirectness | NA | Insufficient
Health related quality of life | 0 | --- | --- | --- | --- | --- | Insufficient
Deep vein thrombosis | 1 | RCT | No limitations | NA | No indirectness | NA | Insufficient
Asymptomatic deep vein thrombosis | 1 | RCT | No limitations | NA | No indirectness | NA | Insufficient
Symptomatic deep vein thrombosis | 1 | RCT | No limitations | NA | No indirectness | NA | Insufficient
Proximal deep vein thrombosis | 2 | RCT | Serious limitation | No serious inconsistency | No indirectness | Serious imprecision | Low
Distal deep vein thrombosis | 1 | RCT | No limitations | NA | No indirectness | NA | Insufficient
Major bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Major bleeding leading to reoperation | 0 | --- | --- | --- | --- | --- | Insufficient
Minor bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Surgical site bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Bleeding leading to infection | 0 | --- | --- | --- | --- | --- | Insufficient
Bleeding leading to transfusion | 0 | --- | --- | --- | --- | --- | Insufficient
Heparin-induced thrombocytopenia | 0 | --- | --- | --- | --- | --- | Insufficient
Discomfort | 0 | --- | --- | --- | --- | --- | Insufficient
Reoperation | 0 | --- | --- | --- | --- | --- | Insufficient
Readmission | 0 | --- | --- | --- | --- | --- | Insufficient

Abbreviations: NA=not applicable; RCT=randomized controlled trial; VTE=venous thromboembolism

Table 90 Strength of evidence for final, intermediate and adverse outcomes comparing extended duration prophylaxis versus standard duration prophylaxis in patients who had major orthopedic surgery

| | | Quality Assessment | | | | Summary of Findings
Outcome | Number of studies | Design | Risk of Bias | Consistency | Directness | Precision | Quality
Symptomatic objectively confirmed VTE | 4 | RCT | No limitations | Serious inconsistency | No indirectness | No imprecision | Moderate
Major VTE | 1 | RCT | Serious limitation | NA | No indirectness | Serious imprecision | Insufficient
Pulmonary Embolism | 7 | RCT | No limitations | No inconsistency | No indirectness | No imprecision | High
Fatal pulmonary embolism | 6 | RCT | No limitations | NA | No indirectness | Serious imprecision | Insufficient
Nonfatal pulmonary embolism | 6 | RCT | Serious limitation | No inconsistency | No indirectness | No imprecision | Moderate
Post thrombotic syndrome | 0 | --- | --- | --- | --- | --- | Insufficient
Mortality | 6 | RCT | No limitations | NA | No indirectness | Serious imprecision | Insufficient
Mortality due to bleeding | 5 | RCT | No limitations | NA | No indirectness | NA | Insufficient
Health related quality of life | 0 | --- | --- | --- | --- | --- | Insufficient
Deep vein thrombosis | 8 | RCT | No limitations | Serious inconsistency | No indirectness | No imprecision | Moderate
Asymptomatic deep vein thrombosis | 4 | RCT | No limitations | No inconsistency | No indirectness | No imprecision | High
Symptomatic deep vein thrombosis | 5 | RCT | No limitations | No inconsistency | No indirectness | No imprecision | High
Proximal deep vein thrombosis | 7 | RCT | No limitations | No inconsistency | No indirectness | No imprecision | High
Distal deep vein thrombosis | 4 | RCT | Serious limitation | Serious inconsistency | No indirectness | Serious imprecision | Low
Major bleeding | 5 | RCT | No limitations | No inconsistency | No indirectness | Very serious imprecision | Low
Major bleeding leading to reoperation | 1 | RCT | No limitations | NA | No indirectness | Very serious imprecision | Insufficient
Minor bleeding | 3 | RCT | No limitations | No inconsistency | No indirectness | No imprecision | High
Surgical site bleeding | 1 | RCT | No limitations | NA | No indirectness | No imprecision | Insufficient
Bleeding leading to infection | 0 | --- | --- | --- | --- | --- | Insufficient
Bleeding leading to transfusion | 2 | RCT | No limitations | NA | No indirectness | Serious imprecision | Insufficient
Heparin-induced thrombocytopenia | 0 | --- | --- | --- | --- | --- | Insufficient
Discomfort | 0 | --- | --- | --- | --- | --- | Insufficient
Readmission | 1 | RCT | No limitations | No inconsistency | No indirectness | Serious imprecision | Low
Reoperation | 1 | RCT | Serious limitation | NA | No indirectness | Serious imprecision | Insufficient

Abbreviations: NA=not applicable; RCT=randomized controlled trial; VTE=venous thromboembolism

Table 91 Strength of evidence for final, intermediate and adverse outcomes comparing inferior vena cava filters to mechanical prophylaxis in patients who had major orthopedic surgery

| | | Quality Assessment | | | | Summary of Findings
Outcome | Number of studies | Design | Risk of Bias | Consistency | Directness | Precision | Quality
Symptomatic objectively confirmed VTE | 0 | --- | --- | --- | --- | --- | Insufficient
Major VTE | 0 | --- | --- | --- | --- | --- | Insufficient
Pulmonary Embolism | 0 | --- | --- | --- | --- | --- | Insufficient
Fatal pulmonary embolism | 0 | --- | --- | --- | --- | --- | Insufficient
Nonfatal pulmonary embolism | 0 | --- | --- | --- | --- | --- | Insufficient
Post thrombotic syndrome | 0 | --- | --- | --- | --- | --- | Insufficient
Mortality | 0 | --- | --- | --- | --- | --- | Insufficient
Mortality due to bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Health related quality of life | 0 | --- | --- | --- | --- | --- | Insufficient
Deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Asymptomatic deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Symptomatic deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Proximal deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Distal deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Major bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Major bleeding leading to reoperation | 0 | --- | --- | --- | --- | --- | Insufficient
Minor bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Surgical site bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Bleeding leading to infection | 0 | --- | --- | --- | --- | --- | Insufficient
Bleeding leading to transfusion | 0 | --- | --- | --- | --- | --- | Insufficient
Heparin-induced thrombocytopenia | 0 | --- | --- | --- | --- | --- | Insufficient
Discomfort | 0 | --- | --- | --- | --- | --- | Insufficient
Readmission | 0 | --- | --- | --- | --- | --- | Insufficient
Reoperation | 0 | --- | --- | --- | --- | --- | Insufficient

Abbreviations: VTE=venous thromboembolism

Table 92 Strength of evidence for final, intermediate and adverse outcomes comparing prophylaxis versus no prophylaxis in patients who had knee arthroscopy

| | | Quality Assessment | | | | Summary of Findings
Outcome | Number of studies | Design | Risk of Bias | Consistency | Directness | Precision | Quality
Symptomatic objectively confirmed VTE | 0 | --- | --- | --- | --- | --- | Insufficient
Major venous thromboembolism | 0 | --- | --- | --- | --- | --- | Insufficient
Pulmonary Embolism | 1 | RCT | Serious risk of bias | NA | No indirectness | NA | Insufficient
Fatal pulmonary embolism | 0 | --- | --- | --- | --- | --- | Insufficient
Non-fatal pulmonary embolism | 0 | --- | --- | --- | --- | --- | Insufficient
Post thrombotic syndrome | 0 | --- | --- | --- | --- | --- | Insufficient
Mortality | 0 | --- | --- | --- | --- | --- | Insufficient
Mortality due to bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Health related quality of life | 0 | --- | --- | --- | --- | --- | Insufficient
Deep vein thrombosis | 1 | RCT | Serious risk of bias | NA | No indirectness | NA | Insufficient
Asymptomatic deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Symptomatic deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Proximal deep vein thrombosis | 1 | RCT | Serious risk of bias | NA | No indirectness | NA | Insufficient
Distal deep vein thrombosis | 1 | RCT | Serious risk of bias | NA | No indirectness | NA | Insufficient
Major bleeding | 1 | RCT | Serious risk of bias | NA | No indirectness | NA | Insufficient
Major bleeding leading to reoperation | 0 | --- | --- | --- | --- | --- | Insufficient
Minor bleeding | 1 | RCT | Serious risk of bias | NA | No indirectness | NA | Insufficient
Surgical site bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Bleeding leading to infection | 0 | --- | --- | --- | --- | --- | Insufficient
Bleeding leading to transfusion | 0 | --- | --- | --- | --- | --- | Insufficient
Heparin-induced thrombocytopenia | 0 | --- | --- | --- | --- | --- | Insufficient
Discomfort | 0 | --- | --- | --- | --- | --- | Insufficient
Readmission | 0 | --- | --- | --- | --- | --- | Insufficient
Reoperation | 0 | --- | --- | --- | --- | --- | Insufficient

Abbreviations: RCT: randomized controlled trial; VTE=venous thromboembolism

Table 93 Strength of evidence for final, intermediate and adverse outcomes comparing prophylaxis versus no prophylaxis in patients who had surgical repair of a lower extremity injury distal to the hip

| | | Quality Assessment | | | | Summary of Findings
Outcome | Number of studies | Design | Risk of Bias | Consistency | Directness | Precision | Quality
Symptomatic objectively confirmed VTE | 0 | --- | --- | --- | --- | --- | Insufficient
Major venous thromboembolism | 0 | --- | --- | --- | --- | --- | Insufficient
Pulmonary Embolism | 1 | RCT | No risk of bias | NA | No indirectness | NA | Insufficient
Fatal pulmonary embolism | 0 | --- | --- | --- | --- | --- | Insufficient
Non-fatal pulmonary embolism | 0 | --- | --- | --- | --- | --- | Insufficient
Post thrombotic syndrome | 0 | --- | --- | --- | --- | --- | Insufficient
Mortality | 0 | --- | --- | --- | --- | --- | Insufficient
Mortality due to bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Health related quality of life | 0 | --- | --- | --- | --- | --- | Insufficient
Deep vein thrombosis | 1 | RCT | No risk of bias | NA | No indirectness | NA | Insufficient
Asymptomatic deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Symptomatic deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Proximal deep vein thrombosis | 1 | RCT | No risk of bias | NA | No indirectness | NA | Insufficient
Distal deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Major bleeding | 1 | RCT | No risk of bias | NA | No indirectness | NA | Insufficient
Major bleeding leading to reoperation | 0 | --- | --- | --- | --- | --- | Insufficient
Minor bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Surgical site bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Bleeding leading to infection | 0 | --- | --- | --- | --- | --- | Insufficient
Bleeding leading to transfusion | 0 | --- | --- | --- | --- | --- | Insufficient
Heparin-induced thrombocytopenia | 0 | --- | --- | --- | --- | --- | Insufficient
Discomfort | 0 | --- | --- | --- | --- | --- | Insufficient
Readmission | 0 | --- | --- | --- | --- | --- | Insufficient
Reoperation | 0 | --- | --- | --- | --- | --- | Insufficient

Abbreviations: RCT: randomized controlled trial; VTE=venous thromboembolism

Table 94 Strength of evidence for final, intermediate and adverse outcomes comparing prophylaxis versus no prophylaxis in patients who had elective spine surgery

| | | Quality Assessment | | | | Summary of Findings
Outcome | Number of studies | Design | Risk of Bias | Consistency | Directness | Precision | Quality
Symptomatic objectively confirmed VTE | 0 | --- | --- | --- | --- | --- | Insufficient
Major venous thromboembolism | 0 | --- | --- | --- | --- | --- | Insufficient
Pulmonary Embolism | 0 | --- | --- | --- | --- | --- | Insufficient
Fatal pulmonary embolism | 0 | --- | --- | --- | --- | --- | Insufficient
Non-fatal pulmonary embolism | 0 | --- | --- | --- | --- | --- | Insufficient
Post thrombotic syndrome | 0 | --- | --- | --- | --- | --- | Insufficient
Mortality | 0 | --- | --- | --- | --- | --- | Insufficient
Mortality due to bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Health related quality of life | 0 | --- | --- | --- | --- | --- | Insufficient
Deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Asymptomatic deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Symptomatic deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Proximal deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Distal deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Major bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Major bleeding leading to reoperation | 0 | --- | --- | --- | --- | --- | Insufficient
Minor bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Surgical site bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Bleeding leading to infection | 0 | --- | --- | --- | --- | --- | Insufficient
Bleeding leading to transfusion | 0 | --- | --- | --- | --- | --- | Insufficient
Heparin-induced thrombocytopenia | 0 | --- | --- | --- | --- | --- | Insufficient
Discomfort | 0 | --- | --- | --- | --- | --- | Insufficient
Readmission | 0 | --- | --- | --- | --- | --- | Insufficient
Reoperation | 0 | --- | --- | --- | --- | --- | Insufficient

Abbreviations: RCT: randomized controlled trial; VTE=venous thromboembolism

Table 95 Strength of evidence for final, intermediate and adverse outcomes comparing injectable pharmacologic prophylaxis versus mechanical prophylaxis in patients who had knee arthoscopy

| | | Quality Assessment | | | | Summary of Findings
Outcome | Number of studies | Design | Risk of Bias | Consistency | Directness | Precision | Quality
Symptomatic objectively confirmed VTE | 0 | --- | --- | --- | --- | --- | Insufficient
Major venous thromboembolism | 0 | --- | --- | --- | --- | --- | Insufficient
Pulmonary Embolism | 0 | --- | --- | --- | --- | --- | Insufficient
Fatal pulmonary embolism | 0 | --- | --- | --- | --- | --- | Insufficient
Non-fatal pulmonary embolism | 0 | --- | --- | --- | --- | --- | Insufficient
Post thrombotic syndrome | 0 | --- | --- | --- | --- | --- | Insufficient
Mortality | 0 | --- | --- | --- | --- | --- | Insufficient
Mortality due to bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Health related quality of life | 0 | --- | --- | --- | --- | --- | Insufficient
Deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Asymptomatic deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Symptomatic deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Proximal deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Distal deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Major bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Major bleeding leading to reoperation | 0 | --- | --- | --- | --- | --- | Insufficient
Minor bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Surgical site bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Bleeding leading to infection | 0 | --- | --- | --- | --- | --- | Insufficient
Bleeding leading to transfusion | 0 | --- | --- | --- | --- | --- | Insufficient
Heparin-induced thrombocytopenia | 0 | --- | --- | --- | --- | --- | Insufficient
Discomfort | 0 | --- | --- | --- | --- | --- | Insufficient
Readmission | 0 | --- | --- | --- | --- | --- | Insufficient
Reoperation | 0 | --- | --- | --- | --- | --- | Insufficient

Abbreviations: RCT: randomized controlled trial; VTE=venous thromboembolism

Table 96 Strength of evidence for final, intermediate and adverse outcomes comparing injectable pharmacologic prophylaxis versus mechanical prophylaxis in patients who had surgical repair of a lower extremity injury distal to the hip

| | | Quality Assessment | | | | Summary of Findings
Outcome | Number of studies | Design | Risk of Bias | Consistency | Directness | Precision | Quality
Symptomatic objectively confirmed VTE | 0 | --- | --- | --- | --- | --- | Insufficient
Major venous thromboembolism | 0 | --- | --- | --- | --- | --- | Insufficient
Pulmonary Embolism | 0 | --- | --- | --- | --- | --- | Insufficient
Fatal pulmonary embolism | 0 | --- | --- | --- | --- | --- | Insufficient
Non-fatal pulmonary embolism | 0 | --- | --- | --- | --- | --- | Insufficient
Post thrombotic syndrome | 0 | --- | --- | --- | --- | --- | Insufficient
Mortality | 0 | --- | --- | --- | --- | --- | Insufficient
Mortality due to bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Health related quality of life | 0 | --- | --- | --- | --- | --- | Insufficient
Deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Asymptomatic deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Symptomatic deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Proximal deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Distal deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Major bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Major bleeding leading to reoperation | 0 | --- | --- | --- | --- | --- | Insufficient
Minor bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Surgical site bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Bleeding leading to infection | 0 | --- | --- | --- | --- | --- | Insufficient
Bleeding leading to transfusion | 0 | --- | --- | --- | --- | --- | Insufficient
Heparin-induced thrombocytopenia | 0 | --- | --- | --- | --- | --- | Insufficient
Discomfort | 0 | --- | --- | --- | --- | --- | Insufficient
Readmission | 0 | --- | --- | --- | --- | --- | Insufficient
Reoperation | 0 | --- | --- | --- | --- | --- | Insufficient

Abbreviations: RCT: randomized controlled trial; VTE=venous thromboembolism

Table 97 Strength of evidence for final, intermediate and adverse outcomes comparing injectable pharmacologic prophylaxis versus mechanical prophylaxis in patients who had elective spine surgery

| | | Quality Assessment | | | | Summary of Findings
Outcome | Number of studies | Design | Risk of Bias | Consistency | Directness | Precision | Quality
Symptomatic objectively confirmed VTE | 0 | --- | --- | --- | --- | --- | Insufficient
Major venous thromboembolism | 0 | --- | --- | --- | --- | --- | Insufficient
Pulmonary Embolism | 0 | --- | --- | --- | --- | --- | Insufficient
Fatal pulmonary embolism | 0 | --- | --- | --- | --- | --- | Insufficient
Non-fatal pulmonary embolism | 0 | --- | --- | --- | --- | --- | Insufficient
Post thrombotic syndrome | 0 | --- | --- | --- | --- | --- | Insufficient
Mortality | 0 | --- | --- | --- | --- | --- | Insufficient
Mortality due to bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Health related quality of life | 0 | --- | --- | --- | --- | --- | Insufficient
Deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Asymptomatic deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Symptomatic deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Proximal deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Distal deep vein thrombosis | 0 | --- | --- | --- | --- | --- | Insufficient
Major bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Major bleeding leading to reoperation | 0 | --- | --- | --- | --- | --- | Insufficient
Minor bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Surgical site bleeding | 0 | --- | --- | --- | --- | --- | Insufficient
Bleeding leading to infection | 0 | --- | --- | --- | --- | --- | Insufficient
Bleeding leading to transfusion | 0 | --- | --- | --- | --- | --- | Insufficient
Heparin-induced thrombocytopenia | 0 | --- | --- | --- | --- | --- | Insufficient
Discomfort | 0 | --- | --- | --- | --- | --- | Insufficient
Readmission | 0 | --- | --- | --- | --- | --- | Insufficient
Reoperation | 0 | --- | --- | --- | --- | --- | Insufficient

Abbreviations: RCT: randomized controlled trial; VTE=venous thromboembolism