# Forest Plots

Figure 1 Impact of pharmacologic prophylaxis versus no prophylaxis on major venous thromboembolism in patients who had major orthopedic surgery

I^2^: Too few strata

Egger's p-value: Too few strata

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of pharmacologic prophylaxis versus no prophylaxis on major venous thromboembolism in patients who had major orthopedic surgery. One trial by Fuji and colleagues in 2010 was included in the analysis and this trial included two separate comparisons. The first comparison provided a relative risk of 0.31 with a 95 percent confidence interval of 0.06 to 1.50. The second comparison provided a relative risk of 0.07 with a 95 percent confidence interval of 0.01 to 0.77. The combined effect of these two comparisons showed a relative risk of 0.21 with a 95 percent confidence interval of 0.05 to 0.95. The I-squared value and Egger's p-value could not be calculated because of too few strata.

Figure 2 Impact of pharmacologic prophylaxis versus no prophylaxis on pulmonary embolism in patients who had major orthopedic surgery

I^2^: 0 percent

Egger's p-value: 0.063

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the analysis of the impact of pharmacologic prophylaxis versus no prophylaxis on the odds of pulmonary embolism in patients who had major orthopedic surgery. Twelve trials were included in this analysis with six trials providing two separate comparisons. The first and second trials by Yokote in 2011 and Fuji in 2010, each including two separate comparisons, were excluded from the analysis because no events occurred in the groups compared. The third trial by Chin and colleagues in 2009 provided an odds ratio of 0.14 with a 95 percent confidence interval of 0.003 to 6.82. The fourth trial by Fuji and colleagues in 2008 included two separate comparisons with the first comparison providing an odds ratio of 7.77 with a 95 percent confidence interval of 0.15 to 391.93 and the second comparison was excluded from the analysis because no events occurred in the groups compared. The fifth trial also by Fuji and colleagues in 2008 included two separate comparisons with the first providing an odds ratio of 1.07 with a 95 percent confidence interval of 0.04 to 30.94 and the second providing an odds ratio of 0.04 with a 95 percent confidence interval of 0.0001 to 16.72. The sixth trial by Samama and colleagues in 1997 was excluded because no events occurred in the groups compared. The seventh trial by Warwick and colleagues in 1995 provided an odds ratio of 0.51 with a 95 percent confidence interval of 0.05 to 4.97. The eighth trial by Lassen and colleagues in 1991 provided an odds ratio of 1.04 with a 95 percent confidence interval of 0.06 to 16.81. The ninth trial by Powers and colleagues in 1989 included two separate comparisons with the first comparison providing an odds ratio of 0.05 with a 95 percent confidence interval of 0.02 to 8.79 and the second providing an odds ratio of 0.05 with a 95 percent confidence interval of 0.001 to 3.05. The tenth trial by Alfaro and colleagues in 1986 included two separate comparisons and the first provided an odds ratio of 0.05 with a 95 percent confidence interval of 0.0001 to 17.82 and the second comparison providing an odds ratio of 0.05 with a 95 percent confidence interval of 0.0001 to 17.82. The eleventh trial by Turpie and colleagues in 1986 provided an odds ratio of 0.14 with a 95 percent confidence interval of 0.003 to 6.82. The twelfth trial by Welin-Berger and colleagues in 1982 provided an odds ratio of 0.14 with a 95 percent confidence interval of 0.003 to 6.82. The combined effect of the nine trials showed an odds ratio of 0.38 with a 95 percent confidence interval of 0.13 to 1.07. The I-squared value was 0 percent and the Egger's p-value was 0.063.

Figure 3 Impact of pharmacologic prophylaxis versus no prophylaxis on pulmonary embolism in patients who had major orthopedic surgery limited to truly no prophylaxis trials

I^2^: 0 percent

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of pharmacologic prophylaxis versus no prophylaxis on pulmonary embolism in patients who had major orthopedic surgery limited to truly no prophylaxis trials. Five trials were included in the analysis with two trials contributing to two separate comparisons presented individually here. The first trial by Chin and colleagues in 2009 provided a relative risk of 0.33 with a 95 percent confidence interval of 0.03 to 4.01. The second trial by Powers and colleagues in 1989 provided two separate comparisons. The first comparison provided a relative risk of 0.48 with a 95 percent confidence interval of 0.05 to 4.58. The second comparison provided a relative risk of 0.16 with a 95 percent confidence interval of 0.01 to 1.94. The Third trial by Alfaro and colleagues in 1986 provided two separate comparisons. The first comparison provided a relative risk of 0.25 with a 95 percent confidence interval of 0.02 to 3.32. The second comparison provided a relative risk of 0.25 with a 95 percent confidence interval of 0.02 to 3.32. The forth trial by Turpie and colleagues in 1986 provided a relative risk of 0.33 with a 95 percent confidence interval of 0.03 to 3.97. The fifth trial by Welin-Berger and colleagues in 1982 provided a relative risk of 0.33 with a 95 percent confidence interval of 0.03 to 3.84. The combined effect of these five trials showed a relative risk of 0.30 with a 95 percent confidence interval of 0.09 to 0.99 The I-squared value was 0 percent.

Figure 4 Impact of pharmacologic prophylaxis versus no prophylaxis on pulmonary embolism in patients who had major orthopedic surgery limited to trials published from 2001-present

I^2^: 73.8 percent

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the analysis of the impact of pharmacologic prophylaxis versus no prophylaxis on the odds of pulmonary embolism in patients who had major orthopedic surgery limited to trials published form 2001-present. Five trials were included in this analysis with four trials providing two separate comparisons. The first and second trials by Yokote in 2011 and Fuji in 2010 were excluded from the analysis because no events occurred in the groups compared. The third trial by Chin and colleagues in 2009 provided an odds ratio of 0.00002 with a 95 percent confidence interval of 0.00000002 to 0.02. The fourth trial by Fuji and colleagues in 2008 included two separate comparisons with the first comparison providing an odds ratio of 7.77 with a 95 percent confidence interval of 0.15 to 391.93 and the second comparison was excluded from the analysis because no events occurred in the groups compared. The fifth trial also by Fuji and colleagues in 2008 included two separate comparisons with the first providing an odds ratio of 1.07 with a 95 percent confidence interval of 0.04 to 30.94 and the second providing an odds ratio of 0.04 with a 95 percent confidence interval of 0.0001 to 16.72. The combined effect of the three trials showed an odds ratio of 0.40 with a 95 percent confidence interval of 0.04 to 3.68. The I-squared value was 73.8 percent.

Figure 5 Impact of pharmacologic prophylaxis versus no prophylaxis on pulmonary embolism in patients who had major orthopedic surgery limited total hip replacement surgery

I^2^: 0 percent

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of pharmacologic prophylaxis versus no prophylaxis on pulmonary embolism in patients who had major orthopedic surgery limited to total hip replacement surgery. Eight trials were included in the analysis with three trials contributing to two separate comparisons presented individually here. The first trial by Yokote and colleagues in 2011 was excluded from the analysis because no events occurred in the groups compared. The second trial by Fuji and colleagues in 2008 provided two separate comparisons. The first comparison provided an odds ratio of 7.77 with a 95 percent confidence interval of 0.15 to 391.93. The second comparison was excluded because no events occurred in the groups compared. The third trial by Samama and colleagues in 1997 was excluded because no events occurred in the groups compared. The fourth trial by Warwick and colleagues in 1995 provided a relative risk of 0.51 with a 95 percent confidence interval of 0.05 to 4.97. The fifth trial by Lassen and colleagues in 1991 provided an odds ratio of 1.04 with a 95 percent confidence interval of 0.06 to 16.81. The sixth trial by Alfaro and colleagues in 1986 provided two separate comparisons. The first comparison provided an odds ratio of 0.05 with a 95 percent confidence interval of 0.0001 to 6.82. The second comparison provided an odds ratio of 0.44 with a 95 percent confidence interval of 0.12 to 1.70. The seventh trial by Turpie and colleagues 1986 provided an odds ratio of 0.14 with a 95 percent confidence interval of 0.003 to 6.82. The eighth trial by Welin-Berger and colleagues in 1982 provided an odds ratio of 0.14 with a 95 percent confidence interval of 0.003 to 6.82. The combined effect of the six trials showed an odds ratio of 0.48 with a 95 percent confidence interval of 0.13 to 1.78. The I-squared value was 0 percent.

Figure 6 Impact of pharmacologic prophylaxis versus no prophylaxis on pulmonary embolism in patients who had major orthopedic surgery limited total knee replacement surgery

I^2^: 0 percent

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the analysis of the impact of pharmacologic prophylaxis versus no prophylaxis on the odds of pulmonary embolism in patients who had major orthopedic surgery limited to total knee replacement surgery. Three trials were included in this analysis with two trials providing two separate comparisons. The first trial by Fuji and colleagues in 2010 was excluded from the analysis because no events occurred in the groups compared. The second trial by Chin and colleagues in 2009 provided an odds ratio of 0.14 with a 95 percent confidence interval of 0.003 to 6.82. The third trial by Fuji and colleagues in 2008 included two separate comparisons with the first providing an odds ratio of 1.07 with a 95 percent confidence interval of 0.04 to 30.94 and the second providing an odds ratio of 0.04 with a 95 percent confidence interval of 0.0001 to 16.72. The combined effect of the two trials showed an odds ratio of 0.31 with a 95 percent confidence interval of 0.03 to 3.23. The I-squared value was 0 percent.

Figure 7 Impact of pharmacologic prophylaxis versus no prophylaxis on pulmonary embolism in patients who had major orthopedic surgery limited hip fracture surgery

I^2^: Too few strata

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of pharmacologic prophylaxis versus no prophylaxis on pulmonary embolism in patients who had major orthopedic surgery limited to hip fracture surgery. One trial by Powers and colleagues in 1989 was included in the analysis and this trial included two separate comparisons. The first comparison provided a relative risk of 0.48 with a 95 percent confidence interval of 0.05 to 4.58. The second comparison provided a relative risk of 0.16 with a 95 percent confidence interval of 0.01 to 1.94. The combined effect of these two comparisons showed a relative risk of 0.30 with a 95 percent confidence interval of 0.04 to 2.42. The I-squared value could not be calculated because of too few strata.

Figure 8 Impact of oral antiplatelet agents versus no prophylaxis on pulmonary embolism in patients who had major orthopedic surgery

I^2^: 0 percent

Egger's p-value: Too few strata

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of oral antiplatelet agents versus no prophylaxis on pulmonary embolism in patients who had major orthopedic surgery. Two trials were included in this analysis and one trial included two separate comparisons. The first trial by Powers and colleagues in 1989 provided a relative risk of 0.48 with a 95 percent confidence interval of 0.06 to 3.62. The second trial by Alfaro and colleagues included two separate comparisons. The first comparison provided a relative risk of 0.25 with a 95 percent confidence interval of 0.02 to 3.32. The second comparison provided a relative risk of 0.25 with a 95 percent confidence interval of 0.02 to 3.32. The combined effect of these two trials showed a relative risk of 0.35 with a 95 percent confidence interval of 0.07 to 1.87. The I-squared value was 0 percent and Egger's p-value could not be calculated because there were too few strata.

Figure 9 Impact of injectable low molecular weight heparins versus no prophylaxis on pulmonary embolism in patients who had major orthopedic surgery

I^2^: 0 percent

Egger's p-value: 0.511

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of injectable low molecular weight heparins versus no prophylaxis on pulmonary embolism in patients who had major orthopedic surgery. Eight trials were included in the analysis with two trials contributing to two separate comparisons presented individually here. The first trial by Yokote and colleagues in 2011 was excluded from the analysis because no events occurred in either groups. The second trial by Chin and colleagues in 2009 provided an odds ratio of 0.14 with a 95 percent confidence interval of 0.0003 to 6.82. The third trial by Fuji and colleagues in 2008 provided two separate comparisons. The first comparison provided an odds ratio of 7.96 with a 95 percent confidence interval of 0.16 to 402.42. The second comparison was excluded because no events occurred in the groups compared. The fourth trial by Fuji and Colleagues provided two separate comparisons. The first comparison provided an odds ratio of 1.07 with a 95 percent confidence interval of 0.04 to 30.94. The second comparison provided an odds ratio of 0.04 with a 95 percent confidence interval of 0.0001 to 16.72. The fifth trial by Samama and colleagues in 1997 was excluded because no events occurred in the groups compared. The sixth trial by Warwick and colleagues in 1995 provided an odds ratio of 0.51 with a 95 percent confidence interval of 0.05 to 4.97. The seventh trial by Lassen and colleagues in 1991 provided an odds ratio of 1.04 with a 95 percent confidence interval of 0.06 to 16.81. The eighth trial by Turpie and colleagues in 1986 provided an odds ratio of 0.14 with a 95 percent confidence interval of 0.003 to 6.82. The combined effect of these six trials showed an odds ratio of 0.59 with a 95 percent confidence interval of 0.17 to 2.08. The I-squared value was 0 percent and the Egger's p-value was 0.511.

Figure 10 Impact of pharmacologic prophylaxis versus no prophylaxis on nonfatal pulmonary embolism in patients who had major orthopedic surgery

I^2^: 0 percent

Egger's p-value: 0.009

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the analysis of the impact of pharmacological prophylaxis versus no prophylaxis on nonfatal pulmonary embolism in patients who had major orthopedic surgery. Six trials were included in this analysis and three trials included two separate comparisons. The first trial by Yokote in 2011 and second trial by Fuji in 2010 were excluded from the analysis because no events occurred in the groups compared. The third trial by Samama and colleagues in 1997 was also excluded from the analysis because no events occurred in the groups compared. The fourth trial by Lassen and colleagues in 1992 provided an odds ratio of 1.04 with a 95 percent confidence interval of 0.06 to 16.81. The fifth trial by Powers and colleagues in 1989 included two separate comparisons and the first provided an odds ratio of 0.05 with a 95 percent confidence interval of 0.001 to 3.05 and the second provided an odds ratio of 0.05 with a 95 percent confidence interval of 0.001 to 3.05. The sixth trial by Turpie and colleagues in 1986 provided an odds ratio of 0.14 with a 95 percent confidence interval of 0.003 to 6.82. The combined effect of the three trials showed an odds ratio of 0.21 with a 95 percent confidence interval of 0.04 to 1.30. The I-squared value was 0 percent and the Egger's p-value was 0.009.

Figure 11 Impact of pharmacologic prophylaxis versus no prophylaxis on nonfatal pulmonary embolism in patients who had major orthopedic surgery limited to truly no prophylaxis trials

I^2^: 0 percent

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of pharmacologic prophylaxis versus no prophylaxis on nonfatal pulmonary embolism in patients who had major orthopedic surgery limited to truly no prophylaxis trials. Two trials were included in this analysis with the trial by Powers and colleagues including two separate comparisons. The first trial by Powers and colleagues in 1989 included two separate comparisons. The first comparison provided a relative risk of 0.16 with a 95 percent confidence interval of 0.01 to 1.94. The second comparison provided a relative risk of 0.16 with a 95 percent confidence interval of 0.01 to 1.94. The second trial by Turpie and colleagues in 1986 provided a relative risk of 0.33 with a 95 percent confidence interval of 0.03 to 3.97. The combined effect of these two trials showed a relative risk of 0.21 with a 95 percent confidence interval of 0.03 to 1.29. The I-squared value was 0 percent.

Figure 12 Impact of pharmacologic prophylaxis versus no prophylaxis on nonfatal pulmonary embolism in patients who had major orthopedic surgery limited to total hip replacement

I^2^: Too few strata

Egger's p-value: Too few strata

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of pharmacologic prophylaxis versus no prophylaxis on nonfatal pulmonary embolism in patients who had major orthopedic surgery limited to total hip replacement. Four trials were included in this analysis. The first trial by Yokote and colleagues in 2011 and second trial by Samama and colleagues in 1997 were excluded from the analysis because no events occurred in either group compared. The third trial by Lassen and colleagues in 1991 provided an odds ratio of 1.04 with a 95 percent confidence interval of 0.07 to 16.81. The fourth trial by Turpie and colleagues in 1986 provided an odds ratio of 0.14 with a 95 percent confidence interval of 0.003 to 6.82. The combined effect of these two trials showed an odds ratio 0.53 with a 95 percent confidence interval of 0.06 to 5.09. The I-squared value and the Egger's p-value could not be calculated because of too few strata.

Figure 13 Impact of pharmacologic prophylaxis versus no prophylaxis on nonfatal pulmonary embolism in patients who had major orthopedic surgery limited to hip fracture surgery

I^2^: Too few strata

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of pharmacologic prophylaxis versus no prophylaxis on nonfatal pulmonary embolism in patients who had major orthopedic surgery limited to hip fracture surgery. One trial by Powers and colleagues in 1989 was included and this trial included two separate comparisons. The first comparison provided a relative risk of 0.16 with a 95 percent confidence interval of 0.01 to 1.94. The second comparison provided a relative risk of 0.16 with a 95 percent confidence interval of 0.01 to 1.94. The combined effect of these two comparisons showed a relative risk of 0.16 with a 95 percent confidence interval of 0.02 to 1.53. The I-squared value could not be calculated because of too few strata.

Figure 14 Impact of injectable low molecular weight heparins versus no prophylaxis on nonfatal pulmonary embolism in patients who had major orthopedic surgery

I^2^: Too few strata

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of injectable low molecular weight heparin versus no prophylaxis on nonfatal pulmonary embolism in patients who had major orthopedic surgery. Four trials were included in this analysis. The first trial by Yokote in 2011 and the second trial by Samama in 1997 were excluded from the analysis because no events occurred in either groups compared. The third trial by Lassen and colleagues in 1991 provided an odds ratio of 0.14 with a 95 percent confidence interval of 0.003 to 6.82. The fourth trial by Turpie and colleagues in 1996 provided an odds ratio of 0.13 with 95 percent confidence interval of 0.003 to 6.82. The combined effect of these two trials showed an odds ratio of 0.53 with a 95 percent confidence interval of 0.06 to 5.09. The I-squared value could not be calculated because of too few strata.

Figure 15 Impact of pharmacologic prophylaxis versus no prophylaxis on mortality in patients who had major orthopedic surgery

I^2^: 0 percent

Egger's p-value: 0.757

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of pharmacologic prophylaxis versus no prophylaxis on mortality in patients who had major orthopedic surgery. Ten trials were included in the analysis with the trials by Yokote, Fuji and Powers and colleagues each contributing to two separate comparisons that are listed individually here. The first trial by Yokote and colleagues in 2011 included two separate comparisons. Both comparisons were excluded because no events occurred in the grousp compared. The second trial by Fuji and colleagues in 2010 included two separate comparisons. Both comparisons were excluded because no events occurred in the groups compared. The third trial by Samama and colleagues in 1997 was excluded from the analysis because no events occurred in either group. The fourth trial by Jorgensen and colleagues in 1992 provided an odds ratio of 0.95 with a 95 percent confidence interval of 0.20 to 4.52. The fifth trial by Lassen and colleagues in 1991 provided an odds ratio of 1.04 with a 95 percent confidence interval of 0.07 to 16.81. The sixth trial by Torholm and colleagues in 1991 provided an odds ratio of 6.90 with a 95 percent confidence interval of 0.14 to 348.44. The seventh trial by Sorensen and colleagues in 1990 provided an odds ratio of 1.07 with a 95 percent confidence interval of 0.07 to 17.44. The eighth trial by Powers and colleagues in 1989 contributed two separate comparisons. The first comparison of aspirin versus no prophylaxis provided an odds ratio of 1.57 with a 95 percent confidence interval of 0.29 to 8.50. The second comparison of warfarin versus no prophyalxis provided an odds ratio of 1.59 with a 95 percent confidence interval of 0.29 to 8.59. The ninth trial by Turpie and colleagues in 1986 provided an odds ratio of 0.14 with a 95 percent confidence interval of 0.003 to 6.82. The tenth trial by McKenna and colleagues in 1980 was excluded from the analysis because no events occurred in either group. The combined effect of the seven trials showed an odds ratio of 1.23 with a 95 percent confidence interval of 0.54 to 2.78, an I-squared value of zero percent and Egger's p-value of 0.757.

Figure 16 Impact of pharmacologic prophylaxis versus no prophylaxis on mortality in patients who had major orthopedic surgery limited to truly no prophylaxis trials

I^2^: 0 percent

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of pharmacologic prophylaxis versus no prophylaxis on mortality in patients who had major orthopedic surgery limited to truly no prophylaxis trials. Five trials were included in the analysis, with the trial by Powers and colleagues contributing to two separate comparisons that are listed individually here. The first trial by Jorgensen and colleagues in 1992 provided an odds ratio of 0.95 with a 95 percent confidence interval of 0.20 to 4.52. The second trial by Torholm and colleagues in 1991 provided an odds ratio of 6.90 with a 95 percent confidence interval of 0.14 to 348.44. The third trial by Powers and colleagues in 1989 contributed two separate comparisons. The first comparison of aspirin versus no prophylaxis provided an odds ratio of 1.57 with a 95 percent confidence interval of 0.29 to 8.50. The second comparison of warfarin versus no prophylaxis provided an odds ratio of 1.59 with a 95 percent confidence interval of 0.29 to 8.59. The fourth trial by Turpie and colleagues in 1986 provided an odds ratio of 0.14 with a 95 percent confidence interval of 0.003 to 6.82. The fifth trial by McKenna and colleagues in 1980 was excluded from the analysis because no events occurred in either group. The combined effect of the four trials showed an odds ratio of 1.26 with a 95 percent confidence interval of 0.52 to 3.11 and an I-squared value of zero percent.

Figure 17 Impact of pharmacologic prophylaxis versus no prophylaxis on mortality in patients who had major orthopedic surgery limited to total hip replacement surgery

I^2^: 0 percent

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of pharmacologic prophylaxis versus no prophylaxis on mortality in patients who had major orthopedic surgery limited to total hip replacement surgery. Six trials were included in the analysis. The first trial by Yokote and colleagues in 2011 provided two separate comparisons. Both comparisons were excluded from the analysis because no events occurred in either group. The second trial by Samama and colleagues in 1997 was excluded from the analysis because no events occurred in either group. The third trial by Lassen and colleagues in 1991 provided an odds ratio of 1.04 with a 95 percent confidence interval of 0.07 to 16.81. The fourth trial by Torholm and colleagues in 1991 provided an odds ratio of 6.90 with a 95 percent confidence interval of 0.14 to 348.44. The fifth trial by Sorensen and colleagues in 1990 provided an odds ratio of 1.07 with a 95 percent confidence interval of 0.07 to 17.44. The sixth trial by Turpie and colleagues in 1986 provided an odds ratio of 0.14 with a 95 percent confidence interval of 0.003 to 6.82. The combined effect of the four trials showed an odds ratio of 1.02 with a 95 percent confidence interval of 0.21 to 5.10 and an I-squared value of zero percent.

Figure 18 Impact of pharmacologic prophylaxis versus no prophylaxis on mortality in patients who had major orthopedic surgery limited to hip fracture surgery

I^2^: 0 percent

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of pharmacologic prophylaxis versus no prophylaxis on mortality in patients who had major orthopedic surgery limited to hip fracture surgery. Two trials were included in the analysis, with the trial by Powers and colleagues contributing two separate comparisons that are listed individually here. The first trial by Jorgensen and colleagues in 1992 provided a relative risk of 0.95 with a 95 percent confidence interval of 0.25 to 3.53. The second trial by Powers and colleagues in 1989 contributed two separate comparisons. The first comparison of aspirin versus no prophylaxis provided a relative risk of 1.59 with a 95 percent confidence interval of 0.33 to 8.00. The second comparison of warfarin versus no prophylaxis provided a relative risk of 1.62 with a 95 percent confidence interval of 0.34 to 8.12. The combined effect of the two trials showed a relative risk of 1.27 with a 95 percent confidence interval of 0.50 to 3.26 and an I-squared value of zero percent.

Figure 19 Impact of injectable low molecular weight heparins versus no prophylaxis on mortality in patients who had major orthopedic surgery

I^2^: 0 percent

Egger's p-value: 0.962

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of injectable low molecular weight heparins versus no prophylaxis on mortality in patients who had major orthopedic surgery. Eight trials were included in the analysis. The first trial by Yokote and colleagues in 2011 was excluded because no events occurred in either group. The second trial by Chin and colleagues in 2009 was excluded from the analysis because no events occurred in either arm. The third trial by Samama and colleagues in 1997 was excluded from the analysis because no events occurred in either arm. The fourth trial by Jorgensen and colleagues in 1992 provided an odds ratio of 0.95 with a 95 percent confidence interval of 0.20 to 4.52. The fifth trial by Lassen and colleagues in 1991 provided an odds ratio of 1.04 with a 95 percent confidence interval of 0.07 to 16.81. The sixth trial by Torholm and colleagues in 1991 provided an odds ratio of 6.90 with a 95 percent confidence interval of 0.14 to 348.44. The seventh trial by Sorensen and colleagues in 1990 provided an odds ratio of 1.07 with a 95 percent confidence interval 0.07 to 17.44. The eighth trial by Turpie and colleagues in 1986 provided an odds ratio of 0.14 with a 95 percent confidence interval of 0.003 to 6.82. The combined effect of the five trials showed an odds ratio of 0.98 with a 95 percent confidence interval of 0.32 to 3.01, an I-squared value of zero percent and an Egger's p-value of 0.962.

Figure 20 Impact of pharmacologic prophylaxis versus no prophylaxis on deep vein thrombosis in patients who had major orthopedic surgery

I^2^: 52.8 percent

Egger's p-value: 0.199

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of pharmacologic prophylaxis versus no prophylaxis on deep vein thrombosis in patients who had major orthopedic surgery. Sventeen trials were included in the analysis with five trials contributing 2 separate comparisons presented individually here. The first trial by Yokote and colleagues included two separate comparisons, The first comparison provided a relative risk of 0.83 with a 95 percent confidence interval of 0.23 to 3.07. The second comparison provided a relative risk of 0.99 with a 95 percent confidence interval of 0.29 to 3.50. The second trial by Fuji and colleagues in 2010 included two separate comparisons. The first comparison provided a relative risk of 0.58 with a 95 percent confidence interval of 0.40 to 0.84. The second comparison provided a relative risk of 0.42 with a 95 percent confidence interval of 0.28 to 0.65. The third trial by Chin and colleagues in 2009 provided a relative risk of 0.25 with a 95 percent confidence interval of 0.11 to 0.57. The fourth by Fuji and colleagues in 2008, contributed two separate comparisons. The first comparison provided a relative risk of 0.81 with a 95 percent confidence interval of 0.51 to 1.30. The second comparison provided a relative risk of 0.48 with a 95 percent confidence interval of 0.28 to 0.83. The fifth trial also by Fuji and colleagues in 2008, contributed two separate comparisons. The first comparison provided a relative risk of 0.56 with a 95 percent confidence interval of 0.37 to 0.84. The second comparison provided a relative risk of 0.49 with a 95 percent confidence interval of 0.32 to 0.75. The sixth trial by Kim and colleagues in 1998 provided a relative risk of 0.60 with a 95 percent confidence interval of 0.24 to 1.47. The seventh trial by Samama and colleagues in 1997 provided a relative risk of 0.38 with a 95 percent confidence interval of 0.20 to 0.69. The eighth trial by Kalodiki and colleagues in 1996 provided a relative risk of 0.40 with a 95 percent confidence interval of 0.24 to 0.64. The ninth trial by Warwick and colleagues in 1995 provided a relative risk of 0.67 with a 95 percent confidence interval of 0.43 to 1.03. The tenth trial by Jorgensen and colleagues in 1992 provided a relative risk of 0.35 with a 95 percent confidence interval of 0.15 to 0.78. The eleventh trial by Lassen and colleagues in 1991 provided a relative risk of 0.69 with a 95 percent confidence interval of 0.47 to 0.99. The twelfth trial by Torholm and colleagues in 1991 provided a relative risk of 0.47 with a 95 percent confidence interval of 0.22 to 0.97. The thirteenth trial by Sorensen and colleagues in 1990 provided a relative risk of 1.13 with a 95 percent confidence interval of 0.70 to 1.84. The fourteenth trial by Alfaro and colleagues in 1986 provided two separate comparisons. The first comparison provided a relative risk of 0.11 with a 95 percent confidence interval of 0.02 to 0.66. The second comparison provided a relative risk of 0.11 with a 95 percent confidence interval of 0.02 to 0.66. The fifteenth trial by Turpie and colleagues in 1986 provided a relative risk of 0.21 with a 95 percent confidence interval of 0.08 to 0.52. The sixteenth trial by Welin-Berger and colleagues in 1982 provided a relative risk of 1.60 with a 95 percent confidence interval of 0.66 to 4.05. The seventeenth trial by McKenna and colleagues in 1980 provided a relative risk of 1.04 with a 95 percent confidence interval of 0.57 to 1.77. The combined effect of the seventeen trials showed a relative risk of 0.56 with a 95 percent confidence interval of 0.47 to 0.68, an I-squared value of 52.8 percent and an Egger's p value of 0.199.

Figure 21 Impact of pharmacologic prophylaxis versus no prophylaxis on deep vein thrombosis in patients who had major orthopedic surgery limited to truly no prophylaxis trials

I^2^: 69 percent

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of pharmacologic prophylaxis versus no prophylaxis on deep vein thrombosis in patients who had major orthopedic surgery limited to truly no prophylaxis trials. Nine trials were included in the analysis with the trial by Alfaro and colleagues contributing to two separate comparisons presented individually here. The first trial by Chin and colleagues in 2009 provided a relative risk of 0.25 with a 95 percent confidence interval of 0.11 to 0.57. The second trial by Kim and colleagues in 1998 provided a relative risk of 0.60 with a 95 percent confidence interval of 0.24 to 1.47. The third trial by Kalodiki and colleagues in 1996 provided a relative risk of 0.40 with a 95 percent confidence interval of 0.24 to 0.64. The fourth trial by Jorgensen and colleagues in 1992 provided a relative risk of 0.35 with a 95 percent confidence interval of 0.15 to 0.78. The fifth trial by Torholm and colleagues in 1991 provided a relative risk of 0.47 with a 95 percent confidence interval of 0.22 to 0.97. The sixth trial by Alfaro and colleagues in 1986 contributed two comparisons. The first comparison provided a relative risk of 0.11 with a 95 percent confidence interval of 0.02 to 0.66. The second comparison provided a relative risk of 0.11 with a 95 percent confidence interval of 0.02 to 0.66. The seventh trial by Turpie and colleagues in 1986 provided a relative risk of 0.21 with a 95 percent confidence interval of 0.08 to 0.52. The eight trial by Welin-Berger and colleagues in 1982 provided a relative risk of 1.60 with a 95 percent confidence interval of 0.66 to 4.05. The ninth trial by McKenna and colleagues in 1980 provided a relative risk of 1.04 with a 95 percent confidence interval of 0.57 to 1.77. The combined effect of the nine trials showed a relative risk of 0.44 with a 95 percent confidence interval of 0.27 to 0.72. The I-squared value was 69 percent.

Figure 22 Impact of pharmacologic prophylaxis versus no prophylaxis on deep vein thrombosis in patients who had major orthopedic surgery limited to trials published from 2001-present

I^2^: 10.4 percent

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of pharmacologic prophylaxis versus no prophylaxis on deep vein thrombosis in patients who had major orthopedic surgery limited to trials published from 2001 to present. Five trials were included in the analysis with four trials contributing to two separate comparisons presented individually here. The first trial by Yokote and colleagues in 2011 provided two separate comparisons. The first comparison provided a relative risk of 0.83 with a 95 percent confidence interval of 0.23 to 3.07. The second comparison provided a relative risk of 0.99 with a 95 percent confidence interval of 0.29 to 3.50. The second trial by Fuji and colleagues in 2010 provided two separate comparisons. The first comparison provided a relative risk of 0.58 with a 95 percent confidence interval of 0.40 to 0.84. The second comparison provided a relative risk of 0.42 with a 95 percent confidence interval of 0.28 to 0.65. The third trial by Chin and colleagues in 2009 provided a relative risk of 0.25 with a 95 percent confidence interval of 0.11 to 0.57. The fourth trial by Fuji and colleagues in 2008 provided two separate comparisons. The first comparison provided a relative risk of 0.81 with a 95 percent confidence interval of 0.51 to 1.30. The second provided a relative risk of 0.48 with a 95 percent confidence interval of 0.28 to 0.83. The fifth trial by Fuji and colleagues in 2008 provided two separate comparisons. The first comparison provided a relative risk of 0.56 with a 95 percent confidence interval of 0.37 to 0.84. The second comparison provided a relative risk of 0.49 with a 95 percent confidence interval of 0.32 to 0.75. The combined effect of these five trials showed a relative risk of 0.54 with a 95 percent confidence interval of 0.45 to 0.64. The I-squared value was 10.4 percent.

Figure 23 Impact of pharmacologic prophylaxis versus no prophylaxis on deep vein thrombosis in patients who had major orthopedic surgery limited to total hip replacement surgery

I^2^: 52.9 percent

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of pharmacologic prophylaxis versus no prophylaxis on deep vein thrombosis in patients who had total hip replacement surgery. Twelve trials were included in the analysis with three trials contributing to two separate comparisons each, presented individually here. The first trial by Yokotei and colleagues in 2011 contributed two separate comparisons. The first comparison provided a relative risk of 0.83 with a 95 percent confidence interval of 0.23 to 3.07. The second comparison provided a relative risk of 0.99 with a 95 percent confidence interval of 0.29 to 3.50. The second trial by Fuji and colleagues in 2008 contributed two separate comparisons. The first comparison provided a relative risk of 0.81 with a 95 percent confidence interval of 0.51 to 1.30. The second comparison provided a relative risk of 0.48 with a 95 percent confidence interval of 0.28 to 0.83. The third trial by Kim and colleagues in 1998 provided a relative risk of 0.60 with a 95 percent confidence interval of 0.24 to 1.47. The fourth trial by Samama and colleagues in 1997 provided a relative risk of 0.38 with a 95 percent confidence interval of 0.20 to 0.69. The fifth trial by Kalodiki and colleagues in 1996 provided a relative risk of 0.40 with a 95 percent confidence interval of 0.24 to 0.64. The sixth trial by Warwick and colleagues in 1995 provided a relative risk of 0.67 with a 95 percent confidence interval of 0.43 to 1.03. The seventh trial by Lassen and colleagues in 1991 provided a relative risk of 0.69 with a confidence interval of 0.47 to 0.99. The eighth trial by Torholm and colleagues in 1991 provided a relative risk of 0.47 with a 95 percent confidence interval of 0.22 to 0.97. The ninth trial by Sorensen and colleagues in 1990 provided a relative risk of 1.13 with a 95 percent confidence interval of 0.70 to 1.84. The tenth trial by Alfaro and colleagues provided two separate comparisons. The first comparison provided a relative risk of 0.11 with a 95 percent confidence interval of 0.02 to 0.66. The second comparison provided a relative risk of 0.11 with a 95 percent confidence interval of 0.02 to 0.66. The eleventh trial by Turpie and colleagues in 1986 provided a relative risk of 0.21 with a 95 percent confidence interval of 0.08 to 0.52. The twelfth trial by Welin-Berger and colleagues in 1982 provided a relative risk of 1.60 with a 95 percent confidence interval of 0.66 to 4.05. The combined effect of the twleve trials showed a relative risk of 0.59 with a 95 percent confidence interval of 0.45 to 0.77. The I-squared value of 52.9 percent.

Figure 24 Impact of pharmacologic prophylaxis versus no prophylaxis on deep vein thrombosis in patients who had major orthopedic surgery limited to total knee replacement surgery

I^2^: 61.4 percent

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of pharmacologic prophylaxis versus no prophylaxis on deep vein thrombosis in patients who had major orthopedic surgery limited to total knee replacement surgery. Four trials were included in the analysis with both trials by Fuji and colleagues each contributing to two separate comparisons, reported individually here. The first trial by Fuji and colleagues in 2010 included two separate comparisons. The first comparison provided a relative risk of 0.58 with a 95 percent confidence interval of 0.40 to 0.84. The second comparison provided a relative risk of 0.42 with a 95 percent confidence interval of 0.28 to 0.65. The second trial by Chin and colleagues in 2009 provided a relative risk of 0.25 with a 95 percent confidence interval of 0.11 to 0.57. The third trial by Fuji and colleagues in 2008 provided two separate comparisons. The first comparison provided a relative risk of 0.56 with a 95 percent confidence interval or 0.37 to 0.84. The second comparison provided a relative risk of 0.49 with a 95 percent confidence interval of 0.32 to 0.75. The fourth trial by McKenna and colleagues in 1980 provided a relative risk of 1.04 with a 95 percent confidence interval of 0.57 to 1.77. The combined effect of the four trials showed a relative risk of 0.54 with a 95 percent confidence interval of 0.40 to 0.73. The I- squared value was 61.4 percent.

Figure 25 Impact of oral antiplatelet agents versus no prophylaxis on deep vein thrombosis in patients who had major orthopedic surgery

I^2^: 76 percent

Egger's p-value: 0.002

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of oral antiplatelet agents versus no prophylaxis on deep vein thrombosis in patients who had major orthopedic surgery. Three trials are included in this analysis, with one trial by Alfaro and colleagues contributing two separate comparisons, presented individually here. The first trial by Kim and colleagues in 1998 provided a relative risk of 0.60 with a 95 percent confidence interval or 0.24 to 1.47. The second trial by Alfaro and colleagues in 1986 contributed two comparisons. The first comparison provided a relative risk of 0.11 with a 95 percent confidence interval of 0.02 to 0.66. The second comparison provided a relative risk of 0.11 with a 95 percent confidence interval of 0.02 to 0.66. The third trial by McKenna and colleagues in 1980 provided a relative risk of 1.04 with a 95 percent confidence interval of 0.57 to 1.77. The combined effect of the three trials showed a relative risk of 0.41 with a 95 percent confidence interval of 0.12 to 1.32. The I-squared value was 76 percent and Egger's p-value was 0.002.

Figure 26 Impact of injectable low molecular weight heparins versus no prophylaxis on deep vein thrombosis in patients who had major orthopedic surgery

I^2^: 50.2 percent

Egger's p-value: 0.088

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of injectable low molecular weight heparins versus no prophylaxis on deep vein thrombosis in patients who had major orthopedic surgery. Twelve trials are included with two trials by Fuji and colleagues in 2008 each contributing two separate comparisons, presented individually here. The first trial by Yokote and colleagues in 2011 provided a relative risk of 0.83 with a 95 percent confidence interval of 0.28 to 2.48. The second trial by Chin and colleagues in 2009 provided a relative risk of 0.25 with a 95 percent confidence interval of 0.11 to 0.57. The third trial by Fuji and colleagues in 2008 contributed two comparisons. The first comparison provided a relative risk of 0.81 with a 95 percent confidence interval of 0.51 to 1.30. The second comparison provided a relative risk of 0.48 with a 95 percent confidence interval of 0.28 to 0.83. The fourth trial, also by Fuji and colleagues in 2008, contributed two comparisons. The first comparison provided a relative risk of 0.56 with a 95 percent confidence interval of 0.37 to 0.84. The second comparison provided a relative risk of 0.49 with a 95 percent confidence interval of 0.32 to 0.75. The fifth trial by Samama and colleagues in 1997 provided a relative risk of 0.38 with a 95 percent confidence interval of 0.20 to 0.69. The sixth trial by Kalodiki and colleagues in 1996 provided a relative risk of 0.40 with a 95 percent confidence interval of 0.24 to 0.64. The seventh trial by Warwick and colleagues in 1995 provided a relative risk of 0.67 with a 95 percent confidence interval of 0.43 to 1.03. The eighth trial by Jorgensen and colleagues in 1992 provided a relative risk of 0.35 with a 95 percent confidence interval of 0.15 to 0.78. The ninth trial by Lassen and colleagues in 1991 provided a relative risk of 0.69 with a 95 percent confidence interval of 0.47 to 0.99. The tenth trial by Torholm and colleagues in 1991 provided a relative risk of 0.47 with a 95 percent confidence interval of 0.22 to 0.97. The eleventh trial by Sorensen and colleagues in 1990 provided a reltive risk of 1.13 with a 95 percent confidence interval of 0.70 to 1.84. The twelfth trial by Turpie and colleagues in 1986 provided a relative risk of 0.21 with a 95 percent confidence interval of 0.08 to 0.52. The combined effect of the twelve trials showed a relative risk of 0.54 with a 95 percent confidence interval of 0.47 to 0.67. The I-squared value was 50.2 percent and the Egger's p-value was 0.088.

Figure 27 Impact of injectable or oral direct thrombin inhibitors versus no prophylaxis on deep vein thrombosis in patients who had major orthopedic surgery

I^2^: Too few strata

Egger's p-value: Too few strata

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of injectable or oral direct thrombin inhibitors versus no prophylaxis on deep vein thrombosis in patients who had major orthopedic surgery. One trial by Fuji and colleagues in 2010 was included in the analysis and this trial included two separate comparisons. The first comparison provided a relative risk of 0.58 with a 95 percent confidence interval of 0.40 to 0.84. The second comparison provided a relative risk of 0.42 with a 95 percent confidence interval of 0.28 to 0.65. The combined effect of these two comparisons showed a relative risk of 0.51 with a 95 percent confidence interval of 0.37 to 0.69. The I-squared value and Egger's p-value could not be calculated because of too few strata.

Figure 28 Impact of pharmacologic prophylaxis versus no prophylaxis on asymptomatic deep vein thrombosis in patients who had major orthopedic surgery

I^2^: 32.7 percent

Egger's p-value: 0.168

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of pharmacologic prophylaxis versus no prophylaxis on asymptomatic deep vein thrombosis in patients who had major orthopedic surgery. Three trials were included in the analysis with one trial by Fuji and colleagues contributing to two separate comparisons. The first trial by Fuji and colleagues in 2010 included two separate comparisons. The first comparison provided a relative risk of 0.57 with a 95 percent confidence interval of 0.39 to 0.84. The second comparison provided a relative risk of 0.42 with a 95 percent confidence interval of 0.27 to 0.66. The second trial by Samama and colleagues in 1997 provided a relative risk of 0.36 with a 95 percent confidence interval of 0.19 to 0.67. The third trial by Lassen and colleagues in 1991 provided a relative risk of 0.69 with a 95 percent confidence interval or 0.47 to 0.99. The combined effect of these three trials showed a relative risk of 0.52 with a 95 percent confidence interval of 0.40 to 0.69. The I-squared value was 32.7 percent and the Egger's p-value was 0.168.

Figure 29 Impact of pharmacologic prophylaxis versus no prophylaxis on asymptomatic deep vein thrombosis in patients who had major orthopedic surgery limited to trials published from 2001-present (same analysis as limited to total knee replacement; same analysis as injectable or oral direct thrombin inhibitors versus no prophylaxis in major orthopedic surgery)

I^2^: Too few strata

Egger's p-value: Too few strata

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of pharmacologic prophylaxis versus no prophylaxis on asymptomatic deep vein thrombosis in patients who had major orthopedic surgery limited to trials published in 2001-present. This figure also represents the analysis of pharmacologic prophylaxis versus no prophylaxis on asymptomatic deep vein thrombosis in patients who had major orthopedic surgery limited to total knee replacement as well as the analysis of injectable or oral direct thrombin inhibitors versus no prophylaxis on asymptomatic deep vein thrombosis in patients who had major orthopedic surgery. One trial by Fuji and colleagues in 2010 was included in the analysis and this trial included two separate comparisons. The first comparison provided a relative risk of 0.57 with a 95 percent confidence interval of 0.39 to 0.84. The second comparison provided a relative risk of 0.42 with a 95 percent confidence interval of 0.27 to 0.66. The combined effect of these two comparisons showed a relative risk of 0.50 with a 95 percent confidence interval of 0.37 to 0.67. The I-squared value and Egger's p-value could not be calculated because of too few strata.

Figure 30 Impact of pharmacologic prophylaxis versus no prophylaxis on asymptomatic deep vein thrombosis in patients who had major orthopedic surgery limited to total hip replacement (same analysis as low molecular weight heparin versus no prophylaxis in major orthopedic surgery)

I^2^: Too few strata

Egger's p-value: Too few strata

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of pharmacologic prophylaxis versus no prophylaxis on asymptomatic deep vein thrombosis in patients who had major orthopedic surgery limited to total hip replacement. This figure also represents the analysis of pharmacologic prophylaxis versus no prophylaxis on asymptomatic deep vein thrombosis in patients who had major orthopedic surgery limited to total hip replacement as well as the analysis of low molecular weight heparin versus no prophylaxis in major orthopedic surgery. Two trials were included in this analysis. The first trial by Samama and colleagues in 1997 provided a relative risk of 0.36 with a 95 percent confidence interval of 0.19 to 0.67. The second trial by Lassen and colleagues in 1991 provided a relative risk of 0.69 with a 95 percent confidence interval of 0.47 to 0.99. The combined effect of these two trials showed a relative risk of 0.52 with a 95 percent confidence interval of 0.27 to 1.00. The I-squared and Egger's p-value could not be calculated because of too few strata.

Figure 31 Impact of pharmacologic prophylaxis versus no prophylaxis on symptomatic deep vein thrombosis in patients who had major orthopedic surgery

I^2^: 0 percent

Egger's p-value: 0.316

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of pharmacologic prophylaxis versus no prophylaxis on symptomatic deep vein thrombosis in patients who had major orthopedic surgery. Four trials were included in the analysis with the trials by Yokote in 2011 and Fuji in 2010 contributing two separate comparisons. The first trial by Yokote and colleagues in 2011 provided two separate comparisons. The first comparison was excluded from the analysis because no events occurred in the groups compared. The second comparison provided an odds ratio of 7.30 with a 95 percent confidence interval of 0.14 to 368.00. The second trial by Fuji and colleagues in 2010 provided two separate comparisons. The first comparison provided an odds ratio of 0.98 with a 95 percent confidence interval of 0.09 to 11.06. The second comparison provided an odds ratio of 0.45 with a 95 percent confidence interval of 0.02 to 8.70. The third trial by Samama and colleagues in 1997 provided an odds ratio of 0.96 with a 95 percent confidence interval of 0.06 to 15.52. The fourth trial by Lassen and colleagues in 1991 was excluded because no events occurred in the groups compared. The combined effect of these two trials showed an odds ratio of 1.07 with a 95 percent confidence interval of 0.25 to 4.52. The I-squared value was 0 percent and the Egger's p-value was 0.316.

Figure 32 Impact of pharmacologic prophylaxis versus no prophylaxis on symptomatic deep vein thrombosis in patients who had major orthopedic surgery limited to trials published in 2001-present

I^2^: 0 percent

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of pharmacologic prophylaxis versus no prophylaxis on symptomatic deep vein thrombosis in patients who had major orthopedic surgery limited to trials published in 2001 to the present. Two trials each including two separate comparisons were included in this analysis. The first trial by Yokote and colleagues in 2011 provided two separate comparisons. The first comparison by Yokote and colleagues in 2011 was excluded because no events occurred in the groups compared. The second comparison provided an odds ratio of 7.30 with 95 percent confidence interval of 0.14 to 368.00. The second trial by Fuji and colleagues in 2010 was included in the analysis and this trial included two separate comparisons. The first comparison provided an odds ratio of 0.98 with a 95 percent confidence interval of 0.09 to 11.06. The second comparison provided an odds ratio of 0.45 with a 95 percent confidence interval of 0.02 to 8.70. The combined effect of these trials showed an odds ratio of 1.11 with a 95 percent confidence interval of 0.20 to 6.01. The I-squared value was 0 percent.

Figure 33 Impact of pharmacologic prophylaxis versus no prophylaxis on symptomatic deep vein thrombosis in patients who had major orthopedic surgery limited to trials total hip replecament

I^2^: Too few strata

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of pharmacologic prophylaxis versus no prophylaxis on symptomatic deep vein thrombosis in patients who had major orthopedic surgery limited to total hip replacement. Three trials were included in the analysis including one trial providing two separate comparisons. The first trial by Yokote and colleagues in 2011 provided two separate comparisons. The first comparison by Yokote and colleagues in 2011 was excluded because no events occurred in the groups compared. The second comparison provided an odds ratio of 7.30 with 95 percent confidence interval of 0.14 to 368.00. The second trial by Samama and colleagues in 1997 provided provided an odds ratio of 0.96 with 95 percent confidence interval of 0.06 to 15.52. The third trial by Lassen and colleagues in 1991 was excluded from the analysis because no events occurred in the groups compared. The combined effect of the these trials showed an odds ratio of 1.90 with a 95 percent confidence interval of 0.20 to 18.32. The I-squared value could not be evaluated because of too few strata.

Figure 34 Impact of pharmacologic prophylaxis versus no prophylaxis on symptomatic deep vein thrombosis in patients who had major orthopedic surgery limited to trials total knee replecament

I^2^: Too few strata

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of pharmacologic prophylaxis versus no prophylaxis on symptomatic deep vein thrombosis in patients who had major orthopedic surgery limited to total knee replacement. One trial by Fuji and colleagues in 2010 was included in the analysis and this trial included two separate comparisons. The first comparison provided a relative risk of of 0.98 with a 95 percent confidence interval of 0.13 to 7.46. The second comparison provided a relative risk of 0.48 with a 95 percent confidence interval of 0.05 to 4.57. The combined effect of these trials showed a relative risk of 0.72 with a 95 percent confidence interval of 0.12 to 4.39. The I-squared value could not be evaluated because of too few strata

Figure 35 Impact of pharmacologic prophylaxis versus no prophylaxis on proximal deep vein thrombosis in patients who had major orthopedic surgery limited to truly no prophylaxis trials

I^2^: 0 percent

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of pharmacologic prophylaxis versus no prophylaxis on deep vein thrombosis in patients who had major orthopedic surgery limited to truly no prophylaxis trials. Five trials were included in the analysis. The first trial by Chin and colleagues in 2009 provided a relative risk of 0.33 with a 95 percent confidence interval of 0.05 to 2.29. The second trial by Kalodiki and colleagues in 1996 provided a relative risk of 0.49 with a 95 percent confidence interval of 0.24 to 1.03. The third trial by Torholm and colleagues in 1991 provided a relative risk of 0.10 with a 95 percent confidence interval of 0.01 to 1.04. The forth trial by Turpie and colleagues in 1986 provided a relative risk of 0.23 with a 95 percent confidence interval of 0.06 to 0.88. The fifth trial by McKenna and colleagues in 1980 provided a relative risk of 0.80 with a 95 percent confidence interval of 0.25 to 2.31. The combined effect of these five trials showed a relative risk of 0.46 with a 95 percent confidence interval of 0.27 to 0.79. The I-squared value was 0 percent.

Figure 36 Impact of pharmacologic prophylaxis versus no prophylaxis on proximal deep vein thrombosis in patients who had major orthopedic surgery limited to trials published from 2001-present

I^2^: 0 percent

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of pharmacologic prophylaxis versus no prophylaxis on proximal deep vein thrombosis in patients who had major orthopedic surgery limited to trials published from 2001 to present. Five trials were included in the analysis with four trials contributing to two separate comparisons presented individually here. The first trial by Yokote and colleagues in 2011 provided two separate comparisons. The first comparison was excluded from the analysis because no events occurred in the groups compared. The second comparison provided a relative risk of 2.96 with a 95 percent confidence interval of 0.25 to 35.86. The second trial by Fuji and colleagues in 2010 provided two separate comparisons. The first comparison provided a relative risk of 0.31 with a 95 percent confidence interval of 0.06 to 1.50. The second comparison provided a relative risk of 0.07 with a 95 percent confidence interval of 0.01 to 0.77. The third trial by Chin and colleagues in 2009 provided a relative risk of 0.33 with a 95 percent confidence interval of 0.05 to 2.29. The fourth trial by Fuji and colleagues in 2008 provided two separate comparisons. The first comparison provided a relative risk of 0.72 with a 95 percent confidence interval of 0.24 to 2.19. The second comparison provided a relative risk of 0.32 with a 95 percent confidence interval of 0.09 to 1.19. The fifth trial by Fuji and colleagues in 2008 provided two separate comparisons. The first comparison provided a relative risk of 0.53 with a 95 percent confidence interval of 0.13 to 2.24. The second comparison provided a relative risk of 0.07 with a 95 percent confidence interval of 0.01 to 0.71. The combined effect of these five trials showed a relative risk of 0.42 with a 95 percent confidence interval of 0.22 to 0.79. The I-squared value was 0 percent.

Figure 37 Impact of pharmacologic prophylaxis versus no prophylaxis on proximal deep vein thrombosis in patients who had major orthopedic surgery limited to total hip replacement

I^2^: 20.9 percent

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of pharmacologic prophylaxis versus no prophylaxis on proximal deep vein thrombosis in patients who had major orthopedic surgery limited to total hip replacement. Eigth trials were included in the analysis with the trial by Yokote in 2011 and Fuji in 2008 including two separate comparisons. The first trial by Yokote and colleagues in 2011 provided two separate comparisons. The first comparison was excluded from the analysis because no events occurred in the groups compared. The second comparison provided a relative risk of 2.96 with a 95 percent confidence interval of 0.25 to 35.86. The second trial by Fuji and colleagues in 2008 provided two separate comparisons. The first comparison provided a relative risk of 0.72 with a 95 percent confidence interval of 0.24 to 2.19. The second comparison provided a relative risk of 0.32 with a 95 percent confidence interval of 0.09 to 1.19. The third trial by Samama and colleagues in 1997 provided a relative risk of 0.16 with a 95 percent confidence interval of 0.04 to 0.61. The fourth trial by Kalodiki and colleagues in 1996 provided a relative risk of 0.49 with a 95 percent confidence interval of 0.24 to 1.03. The fifth trial by Warwik and colleagues in 1995 provided a relative risk of 0.86 with a 95 percent confidence interval of 0.43 to 1.71. The sixth trial by Lassen and colleagues in 1991 provided a relative risk of 0.72 with a 95 percent confidence interval of 0.46 to 1.10. The seventh trial by Torholm and colleagues in 1991 provided a relative risk of 0.10 with a 95 percent confidence interval of 0.01 to 1.04. The eighth trial by Turpie and colleagues in 1986 provided a relative risk of 0.23 with a 95 percent confidence interval of 0.06 to 0.88. The combined effect of these eight trials showed a relative risk of 0.56 with a 95 percent confidence interval of 0.38 to 0.81. The I-squared value was 20.9 percent.

Figure 38 Impact of pharmacologic prophylaxis versus no prophylaxis on proximal deep vein thrombosis in patients who had major orthopedic surgery limited to total knee replacement

I^2^: 0 percent

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of pharmacologic prophylaxis versus no prophylaxis on proximal deep vein thrombosis in patients who had major orthopedic surgery limited to total knee replacement. Four trials were included in the analysis with two trials by Fuji and colleagues each contributing to two separate comparisons presented individually here. The first trial by Fuji and colleagues in 2010 provided two separate comparisons. The first comparison provided a relative risk of 0.31 with a 95 percent confidence interval of 0.63 to 1.50. The second comparison provided a relative risk of 0.07 with a 95 percent confidence interval of 0.01 to 0.77. The second trial by Chin and colleagues in 2009 provided a relative risk of 0.33 with a 95 percent confidence interval of 0.05 to 2.29. The third trial by Fuji and colleagues in 2008 provided two separate comparisons. The first comparison provided a relative risk of 0.53 with a 95 percent confidence interval of 0.13 to 2.24. The second comparison provided a relative risk of 0.07 with a 95 percent confidence interval of 0.01 to 0.71. The forth trial by Mckenna and colleagues in 1980 provided a relative risk of 0.80 with a 95 percent confidence interval of 0.25 to 2.31. The combined effect of these four trials showed a relative risk of 0.43 with a 95 percent confidence interval of 0.21 to 0.88. The I-squared value was 0 percent.

Figure 39 Impact of injectable low molecular weight heparins versus no prophylaxis on proximal deep vein thrombosis in patients who had major orthopedic surgery

I^2^: 14.3 percent

Egger's p-value: 0.003

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of injectable low molecular weight heparins versus no prophylaxis on proximal deep vein thrombosis in patients who had major orthopedic surgery. Ten trials were included in the analysis with two trials by Fuji and colleagues contributing two separate comparisons presented individually here. The first trial by Yokote and colleagues in 2011 was excluded from the analysis because no events occurred in the groups compared. The second trial by Chin and colleagues in 2009 provided a relative risk of 0.33 with a 95 percent confidence interval of 0.05 to 2.29. The third trial by Fuji and colleagues in 2008 provided two separate comparisons. The first comparison provided a relative risk of 0.72 with a 95 percent confidence interval of 0.24 to 2.19. The second comparison provided a relative risk of 0.32 with a 95 percent confidence interval of 0.09 to 1.19. The fourth trial by Fuji and colleagues in 2008 provided two separate comparisons. The first comparison provided a relative risk of 0.53 with a 95 percent confidence interval of 0.13 to 2.24. The second comparison provided a relative risk of 0.07 with a 95 percent confidence interval of 0.01 to 0.71. The fifth trial by Samama and colleagues in 1997 provided a relative risk of 0.16 with a 95 percent confidence interval of 0.04 to 0.61. The sixth trial by Kalodiki and colleagues in 1996 provided a relative risk of 0.49 with a 95 percent confidence interval of 0.24 to 1.03. The seventh trial by Warwik and colleagues in 1995 provided a relative risk of 0.86 with a 95 percent confidence interval of 0.43 to 1.71. The eighth trial by Lassen and colleagues in 1991 provided a relative risk of 0.72 with a 95 percent confidence interval of 0.46 to 1.10. The ninth trial by Torholm and colleagues in 1991 provided a relative risk of 0.10 with a 95 percent confidence interval of 0.01 to 1.04. The tenth trial by Turpie and colleagues in 1986 provided a relative risk of 0.23 with a 95 percent confidence interval of 0.06 to 0.88. The combined effect of these nine trials showed a relative risk of 0.53 with a 95 percent confidence interval of 0.38 to 0.75. The I-squared value was 14.3 percent and the Egger's p-value was 0.003.

Figure 40 Impact of injectable or oral direct thrombin inhibitors versus no prophylaxis on proximal deep vein thrombosis in patients who had major orthopedic surgery

I^2^: Too few strata

Egger's p-value: Too few strata

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of injectable or oral direct thrombin inhibitors versus no prophylaxis on proximal deep vein thrombosis in patients who had major orthopedic surgery. One trial by Fuji and colleagues in 2010 was included in the analysis and this trial included two separate comparisons. The first comparison provided a relative risk of 0.31 with a 95 percent confidence interval of 0.06 to 1.50. The second comparison provided a relative risk of 0.07 with a 95 percent confidence interval of 0.01 to 0.77. The combined effect of these two comparisons showed a relative risk of 0.21 with a 95 percent confidence interval of 0.05 to 0.96. The I-squared value and Egger's p-value could not be calculated because of too few strata.

Figure 41 Impact of pharmacologic prophylaxis versus no prophylaxis on distal deep vein thrombosis in patients who had major orthopedic surgery limited to truly no prophylaxis trials

I^2^: 66.8 percent

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of pharmacologic prophylaxis versus no prophylaxis on distal deep vein thrombosis in patients who had major orthopedic surgery limited to truly no prophylaxis trials. Three trials were included in the analysis. The first trial by Chin and colleagues in 2009 provided a relative risk of 0.24 with a 95 percent confidence interval of 0.10 to 0.58. The second trial by Torholm and colleagues in 1991 provided a relative risk of 0.62 with a 95 percent confidence interval of 0.28 to 1.37. The third trial by McKenna and colleagues in 1980 provided a relative risk of 1.33 with a 95 percent confidence interval of 0.45 to 3.85. The combined effect of these three trials showed a relative risk of 0.57 with a 95 percent confidence interval of 0.22 to 1.46. The I-squared value was 66.8 percent.

Figure 42 Impact of pharmacologic prophylaxis versus no prophylaxis on distal deep vein thrombosis in patients who had major orthopedic surgery limited to trials published from 2001-present

I^2^: 48.9 percent

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of pharmacologic prophylaxis versus no prophylaxis on distal deep vein thrombosis in patients who had major orthopedic surgery limited to trials published from 2001 to present. Two trials were included in the analysis with one trial by Yokote and collegaues in 2011 including two separate comparisons. The first comparison provided a relative risk of 0.83 with a 95 percent confidence interval of 0.23 to 3.07. The second comparison provided a relative risk of 0.99 with a 95 percent confidence interval of 0.29 to 3.50. The second trial by Chin and colleagues in 2009 provided a relative risk of 0.24 with a 95 percent confidence interval of 0.10 to 0.58. The combined effect of these two trials showed a relative risk of 0.52 with a 95 percent confidence interval of 0.20 to 1.38. The I-squared value was 48.9 percent.

Figure 43 Impact of pharmacologic prophylaxis versus no prophylaxis on distal deep vein thrombosis in patients who had major orthopedic surgery limited to total hip replacement

I^2^: 0 percent

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of pharmacologic prophylaxis versus no prophylaxis on distal deep vein thrombosis in patients who had major orthopedic surgery limited to total hip replacement. Five trials were included in the analysis with the trial by Yokote and colleagues including two separate comparisons. The first trial by Yokote and colleagues in 2011 included two separate comparisons. The first comparison provided a relative risk of 0.83 with 95 percent confidence interval of 0.23 to 3.07. The second comparison provided a relative risk of 0.99 with 95 percent confidence interval of 0.29 to 3.50. The second trial by Samama and colleagues in 1997 provided a relative risk of 0.59 with a 95 percent confidence interval of 0.26 to 1.31. The third trial by Warwick and colleagues in 1995 provided a relative risk of 0.53 with a 95 percent confidence interval of 0.26 to 1.04. The fourth trial by Lassen and colleagues in 1991 provided a relative risk of 0.58 with a 95 percent confidence interval of 0.21 to 1.59. The fifth trial by Torholm and colleagues in 1991 provided a relative risk of 0.62 with a 95 percent confidence interval of 0.28 to 1.37. The combined effect of these five trials showed a relative risk of 0.62 with a 95 percent confidence interval of 0.42 to 0.90. The I-squared value was 0 percent.

Figure 44 Impact of pharmacologic prophylaxis versus no prophylaxis on distal deep vein thrombosis in patients who had major orthopedic surgery limited to total knee replacement

I^2^: Too few strata

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of pharmacologic prophylaxis versus no prophylaxis on distal deep vein thrombosis in patients who had major orthopedic surgery limited to total knee replacement. Two trials were included in the analysis. The first trial by Chin and colleagues in 2009 provided a relative risk of 0.24 with a 95 percent confidence interval of 0.10 to 0.58. The second trial by McKenna and colleagues in 1980 provided a relative risk of 1.33 with a 95 percent confidence interval of 0.45 to 3.85. The combined effect of these two trials showed a relative risk of 0.55 with a 95 percent confidence interval of 0.10 to 3.19. The I-squared value could not be calculated because of too few strata.

Figure 45 Impact of injectable low molecular weight heparins versus no prophylaxis on distal deep vein thrombosis in patients who had major orthopedic surgery

I^2^: 0 percent

Egger's p-value: 0.892

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of injectable low molecular weight heparins versus no prophylaxis on distal deep vein thrombosis in patients who had major orthopedic surgery. Six trials were included in the analysis. The first trial by Yokote and colleagues in 2011 provided a relative risk of 0.83 with a 95 percent confidence interval of 0.28 to 2.48. The second trial by Chin and colleagues in 2009 provided a relative risk of 0.24 with a 95 percent confidence interval of 0.10 to 0.58. The third trial by Samama and colleagues in 1997 provided a relative risk of 0.59 with a 95 percent confidence interval of 0.26 to 1.31. The fourth trial by Warwick and colleagues in 1995 provided a relative risk of 0.53 with a 95 percent confidence interval of 0.26 to 1.04. The fifth trial by Lassen and colleagues in 1991 provided a relative risk of 0.58 with a 95 percent confidence interval of 0.21 to 1.59. The sixth trial by Torholm and colleagues in 1991 provided a relative risk of 0.62 with a 95 percent confidence interval of 0.28 to 1.37. The combined effect of these six trials showed a relative risk of 0.52 with a 95 percent confidence interval of 0.37 to 0.75. The I-squared value was 0 percent and the Egger's p-value was 0.892.

Figure 46 Impact of pharmacologic prophylaxis versus no prophylaxis on major bleeding in patients who had major orthopedic surgery

I^2^: 0 percent

Egger's p-value: 0.707

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the analysis of the impact of pharmacological prophylaxis versus no prophylaxis on major bleeding in patients who had major orthopedic surgery. Eight trials are included in this analysis with five of the trials including two separate comparisons. The first trial by Yokote and colleagues in 2011 included two separate comparisons. Both the comparisons were excluded from the analysis because no events occurred in the groups compared. The second trial by Fuji and colleagues in 2010 included two comparisons. The first comparison provided a relative risk of 0.25 with a 95 percent confidence interval of 0.02 to 3.30. The second comparison provided a relative risk of 2.88 with a 95 percent confidence interval of 0.27 to 31.23. The third trial by Fuji and colleagues in 2008 included two separate comparisons. The first comparison provided a relative risk of 2.44 with a 95 percent confidence interval of 0.23 to 27.02. The second comparison provided a relative risk of 3.35 with a 95 percent confidence interval of 0.32 to 35.63. The fourth trial by Fuji and colleagues in 2008 included two separate comparisons. The first comparison provided a relative risk of 0.24 with a 95 percent confidence interval of 0.03 to 1.83. The second comparison provided a relative risk of 0.70 with a 95 percent confidence interval of 0.15 to 3.45. The fifth trial by Kim and colleagues in 1998 provided a relative risk of 1.00 with a 95 percent confidence interval of 0.06 to 17.16. The sixth trial by Samama and colleagues in 1997 provided a relative risk of 0.96 with a 95 percent confidence interval of 0.10 to 9.11. The seventh trial by Powers and colleagues in 1989 included two separate comparisons. The first comparison provided a relative risk of 0.19 with a 95 percent confidence interval of 0.03 to 1.34. The second comparison provided a relative risk of 0.97 with a 95 percent confidence interval of 0.26 to 3.81. The eighth trial by Turpie and colleagues in 1986 provided a relative risk of 0.50 with a 95 percent confidence interval of 0.07 to 3.71. The combined effect of the seven trials showed a relative risk of 0.74 with a 95 percent confidence interval of 0.36 to 1.51. The I-squared value was 0 percent and the Egger's p-value was 0.707.

Figure 47 Impact of pharmacologic prophylaxis versus no prophylaxis on major bleeding in patients who had major orthopedic surgery limited to truly no prophylaxis trials

I^2^: 0 percent

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of pharmacologic prophylaxis versus no prophylaxis on major bleeding in patients who had major orthopedic surgery limited to truly no prophylaxis trials. Three trials were included in the analysis with the trial by Powers and colleagues in 1989 contributing two separate comparisons. The first trial by Kim and colleagues in 1998 was excluded because no events occurred in the groups compared. The second trial by Powers and colleagues in 1989 provided two separate comparisons. The first comparison provided an odds ratio of 0.16 with a 95 percent confidence interval of 0.02 to 1.54. The second comparison provided an odds ratio of 0.97 with a 95 percent confidence interval of 0.20 to 4.70. The third trial by Turpie and colleagues in 1996 provided an odds ratio of 0.51 with a 95 percent confidence interval of 0.05 to 4.98. The combined effect of these two trials showed an odds ratio of 0.53 with a 95 percent confidence interval of 0.17 to 1.64. The I-squared value was 0 percent.

Figure 48 Impact of pharmacologic prophylaxis versus no prophylaxis on major bleeding in patients who had major orthopedic surgery limited to trials published from 2001-present

I^2^: 0 percent

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the analysis of the impact of pharmacological prophylaxis versus no prophylaxis on major bleeding in patients who had major orthopedic surgery limited to trials published from 2001-present. Four trials were included in this analysis with each trial including two separate comparisons. The first trial by Yokote and colleagues in 2011 included two separate comparisons. Both of these comparisons were excluded from the analysis because no events occurred in the groups compared. The second trial by Fuji and colleagues in 2010 included two comparisons. The first comparison provided a relative risk of 0.25 with a 95 percent confidence interval of 0.02 to 3.30. The second comparison provided a relative risk of 2.88 with a 95 percent confidence interval of 0.27 to 31.23. The third trial by Fuji and colleagues in 2008 included two separate comparisons. The first comparison provided a relative risk of 2.44 with a 95 percent confidence interval of 0.23 to 27.02. The second comparison provided a relative risk of 3.35 with a 95 percent confidence interval of 0.32 to 35.63. The fourth trial by Fuji and colleagues in 2008 included two separate comparisons. The first comparison provided a relative risk of 0.24 with a 95 percent confidence interval of 0.03 to 1.83. The second comparison provided a relative risk of 0.70 with a 95 percent confidence interval of 0.15 to 3.45. The combined effect of the four trials showed a relative risk of 0.87 with a 95 percent confidence interval of 0.31 to 2.45. The I-squared value was 0 percent.

Figure 49 Impact of pharmacologic prophylaxis versus no prophylaxis on major bleeding in patients who had major orthopedic surgery limited to total hip replacement

I^2^: 0 percent

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of pharmacologic prophylaxis versus no prophylaxis on major bleeding in patients who had major orthopedic surgery limited to total hip replacement. Five trials were included in the analysis with the trial by Yokote in 2011and Fuji in 2008 including two separate comparisons. The first trial by Yokote included two separate comparisons. Both the comparisons were excluded from the analysis because no events occurred in the groups compared. The second trial by Fuji and colleagues in 2008 provided two separate comparisons. The first comparison provided an odds ratio of 4.46 with a 95 percent confidence interval of 0.23 to 86.49. The second comparison provided an odds ratio of 4.46 with a 95 percent confidence interval of 0.39 to 51.03. The third trial by Kim and colleagues in 1998 was excluded because no events occurred in the groups compared. The fourth trial by Samma and colleagues in 1997 provided an odds ratio of 0.96 with a 95 percent confidence interval of 0.06 to 15.52. The fifth trial by Turpie and colleagues in 1996 provided an odds ratio of 0.51 with a 95 percent confidence interval of 0.05 to 4.98. The combined effect of these three trials showed an odds ratio of 1.61 with a 95 percent confidence interval of 0.44 to 5.83. The I-squared value was 0 percent.

Figure 50 Impact of pharmacologic prophylaxis versus no prophylaxis on major bleeding in patients who major orthopedic surgery limited to total knee replacement

I^2^: 0 percent

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the analysis of the impact of pharmacologic prophylaxis versus no prophylaxis on major bleeding in patients who had major orthopedic surgery limited to total knee replacement surgery. Two trials were included in this analysis and each trial included two separate comparisons. The first trial by Fuji and colleagues in 2010 included two separate comparisons. The first comparison provided a relative risk of 0.25 with a 95 percent confidence interval of 0.02 to 3.30. The second comparison provided a relative risk of 2.88 with a 95 percent confidence interval of 0.27 to 31.23. The second trial by Fuji and colleagues in 2008 included two separate comparisons. The first comparison provided a relative risk of 0.24 with a 95 percent confidence interval of 0.03 to 1.83. The second comparison provided a relative risk of 0.70 with a 95 percent confidence interval of 0.15 to 3.45. The combined effect of the two trials showed a relative risk of 0.59 wit a 95 percent confidence interval of 0.18 to 1.95. The I-squared value was 0 percent.

Figure 51 Impact of pharmacologic prophylaxis versus no prophylaxis on major bleeding in patients who had major orthopedic surgery limited to hip fracture surgery

I^2^: too few strata

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of pharmacologic prophylaxis versus no prophylaxis on major bleeding in patients who had major orthopedic surgery limited to hip fracture surgery. One trial by Powers and colleagues in 1989 was included in the analysis and this trial included two separate comparisons. The first comparison provided a relative risk of 0.19 with a 95 percent confidence interval of 0.03 to 1.34. The second comparison provided a relative risk of 0.97 with a 95 percent confidence interval of 0.26 to 3.81. The combined effect of this one trial showed a relative risk of 0.55 with a 95 percent confidence interval of 0.12 to 2.51. The I-squared value could not be calculated because of too few strata

Figure 52 Impact of injectable low molecular weight heparins versus no prophylaxis on major bleeding in patients who had major orthopedic surgery

I^2^: 0 percent

Egger's p-value: 0.275

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of injectable low molecular weight heparins versus no prophylaxis on major bleeding in patients who had major orthopedic surgery. Five trials were included in the analysis with two trials by Fuji and colleagues contributing to two separate comparisons presented individually here. The first trial by Yokote and colleagues in 2011 was excluded from the analysis because no events occurred in the groups compared. The second trial by Fuji and colleagues in 2008 provided two separate comparisons. The first comparison provided a relative risk of 2.44 with a 95 percent confidence interval of 0.23 to 27.02. The second comparison provided a relative risk of 3.35 with a 95 percent confidence interval of 0.32 to 35.63. The third trial by Fuji and colleagues in 2008 provided two separate comparisons. The first comparison provided a relative risk of 0.24 with a 95 percent confidence interval of 0.03 to 1.83. The second comparison provided a relative risk of 0.70 with a 95 percent confidence interval of 0.15 to 3.45. The fourth trial by Samma and colleagues in 1997 provided a relative risk of 0.96 with a 95 percent confidence interval of 0.10 to 9.11. The fifth trial by Turpie and colleagues in 1996 provided a relative risk of 0.50 with a 95 percent confidence interval of 0.07 to 3.71. The combined effect of these five trials showed a relative risk of 0.78 with a 95 percent confidence interval of 0.29 to 2.08. The I-squared value was 0 percent and the Egger's p-value was 0.275.

Figure 53 Impact of injectable or oral direct thrombin inhibitors versus no prophylaxis on major bleeding in patients who had major orthopedic surgery

I^2^: too few strata

Egger's p-value: too few strata

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the analysis of the impact of injectable or oral direct thrombin inhibitors versus no prophylaxis on major bleeding in patients who had major orthopedic surgery. One trial by Fuji and colleagues in 2010 was included in the analysis and included two separate comparisons. The first comparison provided a relative risk of 0.25 with a 95 percent confidence interval of 0.02 to 3.30. The second comparison provided a relative risk of 2.88 with a 95 percent confidence interval of 0.27 to 31.23. The combined effect of these two comparisons showed a relative risk of 0.96 with a 95 percent confidence interval of 0.09 to 10.73. The I-squared value and Egger's p-value could not be calculated because of too few strata.

Figure 54 Impact of pharmacologic prophylaxis versus no prophylaxis on minor bleeding in patients who had major orthopedic surgery limited to trials published from 2001-present

I^2^: 0 percent

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of pharmacologic prophylaxis versus no prophylaxis on minor bleeding in patients who had major orthopedic surgery limited to trials published from 2001 to present. Four trials including one by Yokote and collegues in 2011 and three trials by Fuji and colleagues were included in the analysis and all four contributed to two separate comparisons presented individually here. The first trial by Yokote and colleagues in 2011 included two separate comparisons. The first comparison provided a relative risk of 2.93 with 95 percent confidence interval of 0.49 to 18.32. The second comparison provided a relative risk of 3.42 with 95 percent confidence interval of 0.58 to 21.06. The second trial by Fuji and colleagues in 2010 provided two separate comparisons. The first comparison provided a relative risk of 1.89 with a 95 percent confidence interval of 0.62 to 5.78. The second comparison provided a relatie risk of 1.44 with a 95 percent confidence interval of 0.41 to 4.98. The third trial by Fuji and colleagues in 2008 provided two separate comparisons. The first comparison provided a relative risk of 2.65 with a 95 percent confidence interval of 0.59 to 11.98. The second comparison provided a relative risk of 1.81 with a 95 percent confidence interval of 0.27 to 12.01. The fourth trial by Fuji and colleagues in 2008 provided two separate comparisons. The first comparison provided a relative risk of 1.46 with a 95 percent confidence interval of 0.32 to 6.62. The second comparison provided a relative risk of 2.14 with a 95 percent confidence interval of 0.60 to 7.59. The combined effect of these four trials showed a relative risk of 2.04 with a 95 percent confidence interval of 1.16 to 3.62. The I-squared value was 0 percent.

Figure 55 Impact of pharmacologic prophylaxis versus no prophylaxis on minor bleeding in patients who had major orthopedic surgery limited to total hip replacement

I^2^: 0 percent

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of pharmacologic prophylaxis versus no prophylaxis on minor bleeding in patients who had major orthopedic surgery limited to total hip replacement. Four trials were included in the analysis with the trials by Yokote in 2011and Fuji and colleagues in 2008 including two separate comparisons. The first trial by Yokote and colleagues in 2011 provided two separate comparisons. The first comparison provided a relative risk of 2.93 with 95 percent confidence interval of 0.49 to 18.32. The second comparison provided a relatuive risk of 3.42 with 95 percent confidence interval of 0.58 to 21.06. The second trial by Fuji and colleagues in 2008 provided two separate comparisons. The first comparison provided a relative risk of 3.47 with a 95 percent confidence interval of 0.59 to 21.39. The second comparison provided a relative risk of 1.94 with a 95 percent confidence interval of 0.30 to 12.80. The third trial by Samama and colleagues in 1997 provided a relative risk of 1.47 with a 95 percent confidence interval of 0.94 to 2.31. The fourth trial by Turpie and colleagues in 1986 provided a relative risk of 3.00 with a 95 percent confidence interval of 0.25 to 36.16. The combined effect of these four trials showed a relative risk of 1.65 with a 95 percent confidence interval of 1.09 to 2.48. The I-squared value was 0 percent.

Figure 56 Impact of pharmacologic prophylaxis versus no prophylaxis on minor bleeding in patients who had major orthopedic surgery limited to total knee replacement

I^2^: 0 percent

Egger's p-value: 0.974

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the analysis of the impact of pharmacologic prophylaxis versus no prophylaxis on minor bleeding in patients who had major orthopedic surgery limited to total knee replacement surgery. Two trials are included in this analysis, each including two separate comparisons. The first trial by Fuji and colleagues in 2010 included two separate comparisons. The first comparison provided a relative risk of 1.97 with a 95 percent confidence interval of 0.63 to 6.37. The second comparison provided a relative risk of 1.44 with a 95 percent confidence interval of 0.44 to 4.83. The second trial by Fuji and colleagues in 2008 included two separate comparisons. The first comparison provided a relative risk of 1.47 with a 95 percent confidence interval of 0.36 to 6.23. The second comparison provided a relative risk of 2.34 with a 95 percent confidence interval of 0.62 to 9.33. The combined effect of these two trials showed a relative risk of 1.77 with a 95 percent confidence interval of 0.89 to 3.49. The I-squared value was 0 percent and Egger's p-value was 0.974.

Figure 57 Impact of injectable low molecular weight heparins versus no prophylaxis on minor bleeding in patients who had major orthopedic surgery

I^2^: 0 percent

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of low molecular weight heparins versus no prophylaxis on minor bleeding in patients who had major orthopedic surgery. Five trials were included in this analysis with two trials by Fuji and colleagues each contributing to two separate comparisons presented individually here. The first trial by Yokote and colleagues in 2011 provided a relative risk of 3.00 with 95 percent confidence interval of 0.72 to 12.77. The second trial by Fuji and colleagues in 2008 provided two separate comparisons. The first comparison provided a relative risk of 3.47 with a 95 percent confidence interval of 0.59 to 21.39. The second comparison provided a relative risk of 1.94 with a 95 percent confidence interval of 0.30 to 12.80. The third trial by Fuji and colleagues in 2008 provided two separate comparisons. The first comparison provided a relative risk of 1.47 with a 95 percent confidence interval of 0.36 to 6.23. The second comparison provided a relative risk of 2.34 with a 95 percent confidence interval of 0.62 to 9.33. The fourth trial by Samama and colleagues in 1997 provided a relative risk of 1.47 with a 95 percent confidence interval of 0.94 to 2.31. The fifth trial by Turpie and colleagues in 1996 provided a relative risk of 3.00 with a 95 percent confidence interval of 0.25 to 36.16. The combined effect of these five trials showed a relative risk of 1.66 with a 95 percent confidence interval of 1.13 to 2.44. The I-squared value was 0 percent.

Figure 58 Impact of injectable or oral direct thrombin inhibitors versus no prophylaxis on minor bleeding in patients who had major orthopedic surgery

I^2^: too few strata

Egger's p-value: too few strata

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of injectable or oral direct thrombin inhibitors versus no prophylaxis on minor bleeding in patients who had major orthopedic surgery. One trial by Fuji and colleagues in 2010 was included in the analysis and this trial included two separate comparisons. The first comparison provided an odds ratio of 1.89 with a 95 percent confidence interval of 0.62 to 5.78. The second comparison provided an odds ratio of 1.44 with a 95 percent confidence interval of 0.41 to 4.98. The combined effect of these two comparisons showed an odds ratio of 1.67 with a 95 percent confidence interval of 0.73 to 3.84. The I-squared value and Egger's p-value could not be calculated because of too few strata.

Figure 59 Impact of injectable low molecular weight heparin versus injectable or oral factor Xa inhibitors on symptomatic objectively confirmed venous thromboembolism in patients undergoing major orthopedic surgery (same as analysis limited to trials published from 2001 to the present)

I^2^: 38.5 percent

Egger's p-value: 0.895

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the analysis of the impact of injectable low molecular weight heparin prophylaxis versus injectable or oral factor Xa inhibitors on symptomatic objectively confirmed venous thromboembolism in patients who had major orthopedic surgery. This also represents the same analysis limited to trials published from 2001 to present. Five trials are included in this analysis. The first trial by Yokote and colleagues in 2011 provided an odds ratio of 0.14 with a 95 percent confidence interval of 0.003 to 6.90. The second trial by Lassen and colleagues in 2002 provided an odds ratio of 0.75 with a 95 percent confidence interval of 0.32 to 1.78. The third trial by Turpie and colleagues also in 2002 provided an odds ratio of 0.46 with a 95 percent confidence interval of 0.25 to 0.85. The fourth trial by Bauer and colleagues in 2001 provided an odds ratio of 1.97 with a 95 percent confidence interval of 0.71 to 5.45. The fifth trial by Eriksson and colleagues in 2001 provided an odds ratio of 0.75 with a 95 percent confidence interval of 0.37 to 1.55. The combined effect of the five trials showed an odds ratio of 0.70 with a 95 percent confidence interval of 0.48 to 1.02. The I-squared value was 38.5 percent and the Egger's p-value was 0.895.

Figure 60 Impact of injectable low molecular weight heparin versus injectable or oral factor Xa inhibitors on symptomatic objectively confirmed venous thromboembolism in patients undergoing major orthopedic surgery limited to total hip replacement surgery

I^2^: 0 percent

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the analysis of the impact of injectable low molecular weight heparin prophylaxis versus injectable or oral factor Xa inhibitors on symptomatic venous thromboembolism in patients who had major orthopedic surgery limited to total hip replacement surgery. Two trials are included in this analysis. The first trial by Lassen and colleagues in 2002 provided an odds ratio of 0.75 with a 95 percent confidence interval of 0.32 to 1.78. The second trial by Turpie and colleagues also in 2002 provided an odds ratio of 0.46 with a 95 percent confidence interval of 0.25 to 0.85. The combined effect of the two trials showed an odds ratio of 0.54 with a 95 percent confidence interval of 0.33 to 0.89. The I-squared value could not be calculated because of too few strata.

Figure 61 Impact of injectable low molecular weight heparin prophylaxis versus oral vitamin K antagonist prophylaxis on symptomatic objectively confirmed venous thromboembolism in patients undergoing major orthopedic surgery

I^2^: Too few strata

Egger's p-value: Too few strata

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the analysis of the impact of injectable low molecular weight heparin prophylaxis versus oral vitamin K antagonist prophylaxis on symptomatic venous thromboembolism in patients who had major orthopedic surgery. Two trials are included in this analysis. The first trial by Colwell and colleagues in 1999 provided an odds ratio of 0.97 with a 95 percent confidence interval of 0.66 to 1.41. The second trial by Leclerc and colleagues in 1996 provided an odds ratio of 2.71 with a 95 percent confidence interval of 0.38 to 19.35. The combined effect of the two trials showed an odds ratio of 1.00 with a 95 percent confidence interval of 0.69 to 1.46. The I-squared value and Egger's p-value could not be calculated because of too few strata.

Figure 62 Impact of injectable low molecular weight heparin versus oral vitamin K antagonists on symptomatic objectively confirmed venous thromboembolism during the postdischarge period in patients who had major orthopedic surgery

I^2^: Too few strata

Egger's p-value: Too few strata

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of injectable low molecular weight heparin versus oral vitamin K antagonists on symptomatic objectively confirmed venous thromboembolism during the post-discharge period in patients who had major orthopedic surgery. One trial by Hull and colleagues in 1993 was included in the analysis, with this trial contributing two separate comparisons presented individually here. The first comparison provided an odds ratio of 2.74 with a 95 percent confidence interval of 0.68 to 11.01. The second comparison provided an odds ratio of 1.02 with a 95 percent confidence interval of 0.06 to 16.38. The combined effect of the two analyses showed an odds ratio of 2.24 with a 95 percent confidence interval of 0.65 to 7.79. The I-squared value and the Egger's p-value could not be calculated because only one study was available.

Figure 63 Impact of injectable low molecular weight heparin versus oral or injectable direct thrombin inhibitors on major venous thromboembolism in patients undergoing major orthopedic surgery

I^2^: 0 percent

Egger's p-value: 0.326

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the analysis of the impact of injectable low molecular weight heparin prophylaxis versus injectable or oral direct thrombin inhibitor prophylaxis major venous thromboembolism in patients who had major orthopedic surgery. Three trials are included in this analysis with the two trials by Eriksson and colleagues in 2007 each including two separate comparisons. The first trial by Eriksson and colleagues in 2007 included two separate comparisons. The first comparison provided a relative risk of 0.92 with a 95 percent confidence intervals of 0.53 to 1.58. The second comparison provided a relative risk of 1.27 with a 95 percent confidence interval of 0.72 to 2.26. The second trial also by Eriksson and colleagues in 2007 included two separate comparisons. The first comparison provided a relative risk of 0.93 with a 95 percent confidence interval of 0.44 to 1.97. The second comparison provided a relative risk of 1.37 with a 95 percent confidence interval of 0.61 to 3.09. The third trial by Eriksson and colleagues in 1997 provided a relative risk of 1.57 with a 95 percent confidence interval of 1.07 to 2.32. The combined effect of these three trials showed a relative risk of 1.26 with a 95 percent confidence interval of 0.98 to 1.62. The I-squared value was 0 percent and the Egger's p-value was 0.326.

Figure 64 Impact of injectable low molecular weight heparin versus oral or injectable direct thrombin inhibitors on major venous thromboembolism in patients undergoing major orthopedic surgery limited to trials published from 2001 to the present

I^2^: 0 percent

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the analysis of the impact of injectable low molecular weight heparin prophylaxis versus injectable or oral direct thrombin inhibitor prophylaxis on major venous thromboembolism in patients who had major orthopedic surgery limited to trials published from 2001 to present. Two trials are included in this analysis with each trial including two separate comparisons. The first trial by Eriksson and colleagues in 2007 included two separate comparisons. The first comparison provided a relative risk of 0.92 with a 95 percent confidence interval of 0.53 to 1.58. The second comparison provided a relative risk of 1.27 with a 95 percent confidence interval of 0.72 to 2.26. The second trial also by Eriksson and colleagues in 2007 included two separate comparisons. The first comparison provided a relative risk of 0.93 with a 95 percent confidence interval of 0.44 to 1.97. The second comparison provided a relative risk of 1.37 with a 95 percent confidence interval of 0.61 to 3.09. The combined effect of these two trials showed a relative risk of 1.08 with a 95 percent confidence interval of 0.78 to 1.50. The I-squared value was 0 percent.

Figure 65 Impact of injectable low molecular weight heparin versus oral or injectable direct thrombin inhibitors on major venous thromboembolism in patients undergoing major orthopedic surgery limited to total hip replacement

I^2^: 18.6 percent

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the analysis of the impact of injectable low molecular weight heparin prophylaxis versus injectable or oral direct thrombin inhibitor prophylaxis major venous thromboembolism in patients who had major orthopedic surgery limited to total hip replacement surgery. Two trials are included in this analysis with the one trial by Eriksson and colleagues in 2007 including two separate comparisons. The first trial by Eriksson and colleagues in 2007 included two separate comparisons. The first comparison provided a relative risk of 0.92 with a 95 percent confidence interval of 0.53 to 1.58. The second comparison provided a relative risk of 1.27 with a 95 percent confidence interval of 0.72 to 2.26. The second trial by Eriksson and colleagues in 1997 provided a relative risk of 1.57 with a 95 percent confidence interval of 1.07 to 2.32. The combined effect of these two trials showed a relative risk of 1.28 with a 95 percent confidence interval of 0.94 to 1.76. The I-squared value was 18.6 percent.

Figure 66 Impact of injectable low molecular weight heparin versus oral or injectable direct thrombin inhibitors on major venous thromboembolism in patients undergoing major orthopedic surgery limited to total knee replacement

I^2^: Too few strata

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the analysis of the impact of injectable low molecular weight heparin prophylaxis versus injectable or oral direct thrombin inhibitor prophylaxis on major venous thromboembolism in patients who had major orthopedic surgery limited to total knee replacement surgery. One trial by Eriksson and colleagues in 2007 which includes two separate comparisons is included in this analysis. The first comparison provided a relative risk of 0.93 with a 95 percent confidence interval of 0.44 to 1.97. The second comparison provided a relative risk of 1.37 with a 95 percent confidence interval of 0.61 to 3.09. The combined effect of these two comparisons showed a relative risk of 1.11 with a 95 percent confidence interval of 0.63 to 1.96. The I-squared value could not be calculated because of too few strata.

Figure 67 Impact of injectable low molecular weight heparin versus injectable unfractionated heparin on pulmonary embolism in patients undergoing major orthopedic surgery

I^2^: 59.7

Egger's p-value: 0.629

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the analysis of the impact of injectable low molecular weight heparin versus injectable unfractionated heparin on pulmonary embolism in patients who had major orthopedic surgery. Ten trials are included in this analysis with one trial included two separate comparisons. The first trial by Senaran and colleagues in 2006 was excluded from the analysis because no events occurred in the groups compared. The second trial by Schwartsmann and colleagues in 1996 was also excluded because no events occurred in the groups compared. The third trial by Avikainen and colleagues in 1995 provided an odds ratio of 0.14 with a 95 percent confidence interval of 0.003 to 6.90. The fourth trial by Colewell and colleagues in 1995 provided an odds ratio 0.13 with a 95 percent confidence interval of 0.01 to 2.13. The fifth trial by Colewell and colleagues in 1994 included two separate comparisons. The first provided and odds ratio of 0.06 with a 95 percent confidence interval of 0.0002 to 19.09. The second comparison provided an odds ratio of 0.05 with a 95 percent confidence interval of 0.0002 to 18.35. The sixth trial by Fauno and colleagues in 1994 was excluded from the analysis because no events occurred in the groups compared. The seventh trial by Eriksson and colleagues in 1991 provided an odds ratio of 0.34 with a 95 percent confidence interval of 0.14 to 0.79. The eight trial by Levine and colleagues in 1991 provided an odds ratio of 0.13 with a 95 percent confidence interval of 0.01 to 2.16. The ninth trial by Monreal and colleagues in 1989 provided an odds ratio of 7.95 with a 95 percent confidence interval of 1.53 to 41.29. The tenth trial by Barre and colleagues and 1987 was excluded from the analysis because no events occurred in the groups compared. The combined effect of the six trials showed an odds ratio of 0.48 with a 95 percent confidence interval of 0.24 to 0.95. The I-squared value was 59.7 percent and the Egger's p-value was 0.629.

Figure 68 Impact of injectable low molecular weight heparin versus injectable unfractionated heparin on pulmonary embolism in patients undergoing major orthopedic surgery limited to total hip replacement

I^2^: 0 percent

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the analysis of the impact of injectable low molecular weight heparin versus injectable unfractionated heparin on pulmonary embolism in patients who had major orthopedic surgery limited total hip replacement. Seven trials are included in this analysis with one trial included two separate comparisons. The first trial by Senaran and colleagues in 2006 was excluded from the analysis because no events occurred in the groups compared. The second trial by Schwartsmann and colleagues in 1996 was also excluded because no events occurred in the groups compared. The third trial by Avikainen and colleagues in 1995 provided an odds ratio of 0.14 with a 95 percent confidence interval of 0.003 to 6.90. The fourth trial by Colewell and colleagues in 1994 included two separate comparisons. The first comparison provided and odds ratio of 0.06 with a 95 percent confidence interval of 0.0002 to 19.09. The second comparison provided an odds ratio of 0.05 with a 95 percent confidence interval of 0.0002 to 18.35. The fifth trial by Eriksson and colleagues in 1991 provided an odds ratio of 0.34 with a 95 percent confidence interval of 0.14 to 0.79. The sixth trial by Levine and colleagues in 1991 provided an odds ratio of 0.13 with a 95 percent confidence interval of 0.01 to 2.16. The seventh trial by Barre and colleagues and 1987 was excluded from the analysis because no events occurred in the groups compared. The combined effect of the four trials showed an odds ratio of 0.28 with a 95 percent confidence interval of 0.13 to 0.62. The I-squared value was 0 percent.

Figure 69 Impact of injectable low molecular weight heparin versus injectable unfractionated heparin on pulmonary embolism during the postdischarge period in patients who had total hip replacement surgery (same as analysis of nonfatal pulmonary embolism during the post discharge period)

I^2^: Too few strata

Egger's p-value: Too few strata

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of injectable low molecular weight heparin versus injectable unfractionated heparin on pulmonary embolism during the post-discharge period in patients who had total hip replacement surgery. This analysis also depicts the meta-analysis of the impact of of injectable low molecular weight heparin versus injectable or oral direct thrombin inhibitors on nonfatal pulmonary embolism during the post-discharge period in patients who had total hip replacement surgery. One trial by Colwell and colleagues in 1994 was included in the analysis, with this trial contributing two separate comparisons presented individually here. The first comparison provided a relative risk of 0.13 with a 95 percent confidence interval of 0.01 to 1.53. The second comparison provided a relative risk of 0.13 with a 95 percent confidence interval of 0.01 to 1.47. The combined effect of the two analyses showed a relative risk of 0.13 with a 95 percent confidence interval of 0.01 to 1.17. The I-squared value and the Egger's p-value could not be calculated because only one study was available.

Figure 70 Impact of injectable low molecular weight heparin versus oral or injectable direct thrombin inhibitors on pulmonary embolism in patients undergoing major orthopedic surgery

I^2^: 0 percent

Egger's p-value: 0.208

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the analysis of the impact of injectable low molecular weight heparin prophylaxis versus injectable or oral direct thrombin inhibitor prophylaxis on pulmonary embolism in patients who had major orthopedic surgery. Three trials are included in this analysis with two trials by Eriksson and colleagues each including two separate comparisons. The first trial by Eriksson and colleagues in 2007 included two separate comparisons. The first comparison provided a relative risk of 3.04 with a 95 percent confidence interval of 0.37 to 25.12. The second comparison provided a relative risk of 0.60 with a 95 percent confidence interval of 0.12 to 3.06. The second trial by Eriksson and colleagues also in 2007 included two separate comparisons. The first comparison provided a relative risk of 1.02 with a 95 percent confidence interval of 0.08 to 13.64. The second comparison provided a relative risk of 3.94 with a 95 percent confidence interval of 0.29 to 52.91. The third trial by Eriksson and colleagues in 1997 provided a relative risk of 1.18 with a 95 percent confidence interval of 0.41 to 3.39. The combined effect of these three trials showed a relative risk of 1.18 with a 95 percent confidence interval of 0.41 to 3.39. The I-squared value was 0 percent and the Egger's p-value was 0.208.

Figure 71 Impact of injectable low molecular weight heparin versus oral or injectable direct thrombin inhibitors on pulmonary embolism in patients undergoing major orthopedic surgery limited to trials published from 2001 to the present

I^2^: 0 percent

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the analysis of the impact of injectable low molecular weight heparin prophylaxis versus injectable or oral direct thrombin inhibitor prophylaxis on pulmonary embolism in patients who had major orthopedic surgery limited to trials published from 2001- present. Two trials are included in this analysis with each trial including two separate comparisons. The first trial by Eriksson and colleagues in 2007 included two separate comparisons. The first comparison provided a relative risk of 3.04 with a 95 percent confidence interval of 0.37 to 25.12. The second comparison provided a relative risk of 0.60 with a 95 percent confidence interval of 0.12 to 3.06. The second trial by Eriksson and colleagues also in 2007 included two separate comparisons. The first comparison provided a relative risk of 1.02 with a 95 percent confidence interval of 0.08 to 13.64. The second comparison provided a relative risk of 3.94 with a 95 percent confidence interval of 0.29 to 52.91. The combined effect of these two trials showed a relative risk of 1.25 with a 95 percent confidence interval of 0.35 to 4.39. The I-squared value was 0 percent.

Figure 72 Impact of injectable low molecular weight heparin versus oral or injectable direct thrombin inhibitors on pulmonary embolism in patients undergoing major orthopedic surgery limited to total hip replacement surgery

I^2^: 0 percent

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the analysis of the impact of injectable low molecular weight heparin prophylaxis versus injectable or oral direct thrombin inhibitor prophylaxis on pulmonary embolism in patients who had major orthopedic surgery limited to total hip replacement surgery. Two trials are included in this analysis with the trial by Eriksson and colleagues including two separate comparisons. The first trial by Eriksson and colleagues in 2007 included two separate comparisons. The first comparison provided a relative risk of 3.04 with a 95 percent confidence interval of 0.37 to 25.12. The second comparison provided a relative risk of 0.60 with a 95 percent confidence interval of 0.12 to 3.06. The second trial by Eriksson and colleagues in 1997 provided a relative risk of 1.02 with a 95 percent confidence interval of 0.18 to 5.78. The combined effect of these two trials showed a relative risk of 1.03 with a 95 percent confidence interval of 0.32 to 3.36. The I-squared value was 0 percent.

Figure 73 Impact of injectable low molecular weight heparin versus oral or injectable direct thrombin inhibitors on pulmonary embolism in patients undergoing major orthopedic surgery limited to total knee replacement surgery

I^2^: Too few strata

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the analysis of the impact of injectable low molecular weight heparin prophylaxis versus injectable or oral direct thrombin inhibitor prophylaxis on pulmonary embolism in patients who had major orthopedic surgery limited to total knee replacement surgery. One trial by Eriksson and colleagues in 2007 is included in this analysis with two separate comparisons. The first comparison provided a relative risk of 1.02 with a 95 percent confidence interval of 0.08 to 13.64. The second comparison provided a relative risk of 3.94 with a 95 percent confidence interval of 0.29 to 52.91. The combined effect of these two comparisons showed a relative risk of 2.00 with a 95 percent confidence interval of 0.18 to 22.02. The I-squared value could not be calculated because of too few strata.

Figure 74 Impact of injectable low molecular weight heparin versus oral vitamin k antagonists on pulmonary embolism in patients undergoing major orthopedic surgery

I^2^: 28.7 percent

Egger's p-value: 0.762

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the analysis of the impact of injectable low molecular weight heparin prophylaxis versus oral vitamin K antagonist prophylaxis on pulmonary embolism in patients who had major orthopedic surgery. Five trials were included in this analysis with the trial by Hull and colleagues in 2003 contributing two separate comparisons. The first trial by Lassen and colleagues in 2007 provided an odds ratio of 7.46 with a 95 percent confidence interval of 0.46 to 120.00. The second trial by Fitzgerald and colleagues in 2001 provided am odds ratio of 0.14 with a 95 percent confidence interval of 0.003 to 6.94. The third trial by Hull and colleagues in 2003 included two separate comparisons however both were excluded from this analysis because no events occurred in the groups compared. The fourth trial by Colwell and colleagues in 1999 provided an odds ratio of 1.23 with a 95 percent confidence interval of 0.58 to 2.63. The fifth trial by Leclerc and colleagues provided an odds ratio 0.36 with a 95 percent confidence interval of 0.05 to 2.60. The combined effect of the four trials provided an odds ratio of 1.11 with a 95 percent confidence interval of 0.57 to 2.19. The I-squared value was 28.7 percent and the Egger's p-value was 0.762.

Figure 75 Impact of injectable low molecular weight heparin versus oral vitamin K antagonists on pulmonary embolism in patients undergoing major orthopedic surgery limited to trials published from 2001 to the present

I^2^: Too few strata

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the analysis of the impact of injectable low molecular weight heparin prophylaxis versus oral vitamin K antagonist prophylaxis on pulmonary embolism in patients who had major orthopedic surgery limited to trials published from 2001 to present. Two trials were included in this analysis. The first trial by Lassen and colleagues in 2007 provided an odds ratio of 7.46 with a 95 percent confidence interval of 0.46 to 120.00. The second trial by Fitzgerald and colleagues in 2001 provided an odds ratio of 0.14 with a 95 percent confidence interval of 0.003 to 6.94. The combined effect of these two trials showed an odds ratio of 1.96 with a 95 percent confidence interval of 0.20 to 18.94. The I-squared value could not be calculated because of too few strata.

Figure 76 Impact of injectable low molecular weight heparin versus oral vitamin K antagonists on pulmonary embolism in patients undergoing major orthopedic surgery limited total knee replacement surgery

I^2^: 48.2 percent

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the analysis of the impact of injectable low molecular weight heparin prophylaxis versus oral vitamin K antagonists on pulmonary embolism in patients who had major orthopedic surgery limited to total knee replacement surgery. Three trials were included in this analysis. The first trial by Lassen and colleagues in 2007 provided an odds ratio of 7.46 with a 95 percent confidence interval of 0.46 to 120.00. The second trial by Fitzgerald and colleagues in 2001 provided an odds ratio of 0.14 with a 95 percent confidence interval of 0.003 to 6.94. The third trial by Leclerc and colleagues provided an odds ratio of 0.36 with a 95 percent confidence interval of 0.05 to 2.60. The combined effect of these three trials showed an odds ratio of 0.75 with a 95 percent confidence interval of 0.17 to 3.31. The I-squared value was 48.2 percent.

Figure 77 Impact of injectable low molecular weight heparin versus oral vitamin K antagonists on pulmonary embolism during the postdischarge period in patients who had major orthopedic surgery

I^2^: Too few strata

Egger's p-value: Too few strata

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of injectable low molecular weight heparin versus oral vitamin K antagonists on pulmonary embolism during the post-discharge period in patients who had major orthopedic surgery. One trial by Hull and colleagues in 1993 was included in the analysis, with this trial contributing two separate comparisons presented individually here. The first comparison provided an odds ratio of 7.37 with a 95 percent confidence interval of 0.15 to 371.45. The second comparison provided an odds ratio of 0.14 with a 95 percent confidence interval of 0.003 to 6.97. The combined effect of the two analyses showed an odds ratio of 1.01 with a 95 percent confidence interval of 0.06 to 16.14. The I-squared value and the Egger's p-value could not be calculated because only one study was available.

Figure 78 Impact of injectable unfractionated heparin versus oral or injectable direct thrombin inhibitors on pulmonary embolism in patients undergoing major orthopedic surgery (same as limited to total hip replacement surgery)

I^2^: Too few strata

Egger's p-value: Too few strata

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the analysis of the impact of injectable unfractionated heparin prophylaxis versus injectable or oral direct thrombin inhibitor prophylaxis in patients who had major orthopedic surgery. This also represents the analysis limited to total hip replacement surgery. Two trials were included in the analysis. The first trial by Eriksson and colleagues in 1997 provided an odds ratio of 7.52 with a 95 percent confidence interval of 1.05 to 53.79. The second trial by Eriksson and colleagues in 1996 provided an odds ratio of 0.12 with a 95 percent confidence interval of 0.002 to 6.01. The combined effect of these two trials showed an odds ratio of 3.27 with a 95 percent confidence interval of 0.56 to 18.98. The I-squared value and the Egger's p-value could not be calculated because of too few strata.

Figure 79 Impact of injectable low molecular weight heparin versus injectable or oral factor Xa inhibitors on fatal pulmonary embolism in patients undergoing major orthopedic surgery (Same as analysis limited to trials published from 2001-present)

I^2^: 0 percent

Egger's p-value: 0.744

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of injectable low molecular weight heparin prophylaxis versus injectable or oral factor Xa inhibitor prophylaxis on fatal pulmonary embolism in patients who had major orthopedic surgery. This figure also depicts the analysis of injectable low molecular weight heparin prophylaxis versus injectable or oral factor Xa inhibitor prophylaxis on fatal pulmonary embolism in patients who had major orthopedic surgery limited to trials published from 2001-present. Five trials were included in this analysis. The first trial by Yokote and colleagues in 2011 was excluded from the analysis because no events occurred in either of the treatment arms. The second trial by Lassen and colleagues in 2002 provided an odds ratio of 0.14 with a 95 percent confidence interval of 0.003 to 6.86. The third trial by Turpie and colleagues in 2002 provided an odds ratio of 1.95 with a 95 percent confidence interval of 0.20 to 18.72. The fourth trial by Bauer and colleagues in 2001 provided an odds ratio of 1.00 with a 95 percent confidence interval of 0.006 to 16.01. The fifth trial by Eriksson and colleagues in 2001 provided an odds ratio of 0.87 with a 95 percent confidence interval of 0.31 to 2.39. The combined effect of the four trials showed an odds ratio of 0.90 with a 95 percent confidence interval of 0.38 to 2.13, the I-squared value of 0 percent, and the Egger's p-value of 0.744.

Figure 80 Impact of injectable low molecular weight heparin versus injectable or oral factor Xa inhibitors on fatal pulmonary embolism in patients undergoing major orthopedic surgery limited to total hip replacement

I^2^: Too few strata

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of injectable low molecular weight heparin prophylaxis versus injectable or oral factor Xa inhibitor prophylaxis on fatal pulmonary embolism in patients who had major orthopedic surgery limited to total hip replacement surgery. Three trials were included in this analysis. The first trial by Yokote and colleagues in 2011 was excluded from the analysis because no events occurred in either of the treatment arms. The second trial by Lassen and colleagues in 2002 provided an odds ratio of 0.14 with a 95 percent confidence interval of 0.003 to 6.86. The third trial by Turpie and colleagues in 2002 provided an odds ratio of 1.95 with a 95 percent confidence interval of 0.20 to 18.72. The combined effect of the two trials showed an odds ratio of 1.00 with a 95 percent confidence interval of 0.14 to 7.10. The I-squared value could not be calculated because only two studies were available

Figure 81 Impact of injectable low molecular weight heparin versus injectable or oral direct thrombin inhibitors on fatal pulmonary embolism in patients undergoing major orthopedic surgery (Same as analysis limited to trials published from 2001-present)

I^2^: 31.7 percent

Egger's p-value: Too few strata

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of injectable low molecular weight heparin prophylaxis versus injectable or oral direct thrombin inhibitor prophylaxis on fatal pulmonary embolism in patients who had major orthopedic surgery. This figure also depicts the analysis of the impact of injectable low molecular weight heparin prophylaxis versus injectable or oral direct thrombin inhibitor prophylaxis on fatal pulmonary embolism in patients who had major orthopedic surgery limited to trials published from 2001-present. Two trials were included with the two trials contributing two separate comparisons presented individually here. The first trial by Eriksson and colleagues in 2007 included two comparisons. The first comparison provided an odds ratio of 0.14 with a 95 percent confidence interval of 0.003 to 6.90. The second comparison was excluded from the analysis because no events occurred in the groups compared. The second trial by Eriksson and colleagues in 2007 included two comparisons. The first comparison provided an odds ratio of 20.71 with a 95 percent confidence interval of 0.06 to 7517.03. The second comparison provided an odds ratio of 19.48 with a 95 percent confidence interval of 0.06 to 6860.53. The combined effect of the two trials showed a relative risk of 1.43 with a 95 percent confidence interval of 0.08 to 24.82. The I-squared value was 31.7 percent and the Egger's p-value could not be calculated because only two studies were available.

Figure 82 Impact of injectable low molecular weight heparin versus injectable or oral direct thrombin inhibitors on fatal pulmonary embolism in patients undergoing major orthopedic surgery limited to total knee replacement

I^2^: Too few strata

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of injectable low molecular weight heparin prophylaxis versus injectable or oral direct thrombin inhibitor prophylaxis on fatal pulmonary embolism in patients who had major orthopedic surgery limited to total knee replacement surgery. One trial by Eriksson and colleagues in 2007 was included in the analysis with this trial contributing two separate comparisons presented individually here. The first comparison provided a relative risk of 4.06 with a 95 percent confidence interval of 0.30 to 54.56. The second comparison provided a relative risk of 3.94 with a 95 percent confidence interval of 0.29 to 52.91. The combined effect of the two analyses showed a relative risk of 4.00 with a 95 percent confidence interval of 0.36 to 44.03. The I-squared value could not be calculated because only one study was available.

Figure 83 Impact of injectable low molecular weight heparin versus injectable unfractionated heparin on nonfatal pulmonary embolism in patients undergoing major orthopedic surgery

I^2^: 58.8 percent

Egger's p-value: 0.634

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of injectable low molecular weight heparin prophylaxis versus injectable unfractionated heparin prophylaxis on nonfatal pulmonary embolism in patients who had major orthopedic surgery. Ten trials were included in the analysis with one trial contributing two separate comparisons presented individually here. The first trial by Senaran and colleagues in 2006 was excluded because no events occurred in the groups compared. The second trial by Schwartsmann and colleagues in 1996 was excluded because no events occurred in the groups compared. The third trial by Colwell and colleagues in 1995 provided an odds ration of 0.13 with a 95 percent confidence interval of 0.003 to 6.73. The fourth trial by Colwell and colleagues in 1994 included two comparisons. The first comparison provided an odds ratio of 0.06 with a 95 percent confidence interval of 0.0002 to 19.09. The second comparison provided an odds ratio of 0.05 with a 95 percent confidence interval of 0.0002 to 18.35. The fifth trial by Fauno and colleagues in 1991 was excluded because no events occurred in the groups compared. The sixth trial by Eriksson and colleagues in 1991 provided an odds ratio of 0.34 with a 95 percent confidence interval of 0.14 to 0.79. The seventh trial by Levine and colleagues in 1991 provided an odds ratio of 0.13 with a 95 percent confidence interval of 0.008 to 2.16. The eighth trial by Monreal and colleagues in 1989 provided an odds ratio of 7.95 with a 95 percent confidence interval of 1.53 to 41.29. The ninth trial by Planes and colleagues in 1988 provided an odds ratio of 0.12 with a 95 percent confidence interval 0.002 to 6.14. The tenth trial by Barre and colleagues in 1987 was excluded because no events occurred in the groups compared. The combined effect of the six trials showed an odds ratio of 0.50 with a 95 percent confidence interval of 0.25 to 1.00. The I-squared value was 58.8 percent and the Egger's p-value was 0.634.

Figure 84 Impact of injectable low molecular weight heparin versus injectable unfractionated heparin on nonfatal pulmonary embolism in patients undergoing major orthopedic surgery limited to total hip replacement surgery

I^2^: 0 percent

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of injectable low molecular weight heparin prophylaxis versus injectable unfractionated heparin prophylaxis on nonfatal pulmonary embolism in patients who had major orthopedic surgery limited to total hip replacement surgery. Seven trials were included in the analysis with one trial contributing two separate comparisons presented individually here. The first trial by Senaran and colleagues in 2006 was excluded because no events occurred in the groups compared. The second trial by Schwartsmann and colleagues in 1996 was excluded because no events occurred in the groups compared. The third trial by Colwell and colleagues in 1994 included two comparisons. The first comparison provided an odds ratio of 0.06 with a 95 percent confidence interval of 0.0002 to 19.09. The second comparison provided an odds ratio of 0.05 with a 95 percent confidence interval of 0.0002 to 18.35. The fourth trial by Eriksson and colleagues in 1991 provided an odds ratio of 0.34 with a 95 percent confidence interval of 0.14 to 0.79. The fifth trial by Levine and colleagues in 1991 provided an odds ratio of 0.13 with a 95 percent confidence interval of 0.008 to 2.16. The sixth trial by Planes and colleagues in 1988 provided an odds ratio of 0.12 with a 95 percent confidence interval of 0.002 to 6.14. The seventh trial by Barre and colleagues in 1987 was excluded because no events occurred in the groups compared. The combined effect of the four trials showed an odds ratio of 0.28 with a 95 percent confidence interval of 0.13 to 0.62. The I- squared value was 0 percent.

Figure 85 Impact of injectable low molecular weight heparin versus injectable or oral factor Xa inhibitors on nonfatal pulmonary embolism in patients undergoing major orthopedic surgery (same as analysis limited to trials published from 2001-present)

I^2^: 49.5 percent

Egger's p-value: 0.040

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of injectable low molecular weight heparin prophylaxis versus injectable or oral factor Xa inhibitor prophylaxis on nonfatal pulmonary embolism in patients who had major orthopedic surgery. This figure also depicts the analysis of injectable low molecular weight heparin prophylaxis versus injectable or oral factor Xa inhibitor prophylaxis on nonfatal pulmonary embolism in patients who had major orthopedic surgery limited to trials published from 2001-present. Five trials were included in this analysis. The first trial by Yokote and colleagues in 2011 was excluded from the analysis because no events occurred in either of the treatment arms. The second trial by Lassen and colleagues in 2002 provided an odds ratio of 1.01 with a 95 percent confidence interval of 0.20 to 4.99. The third trial by Turpie and colleagues in 2002 provided an odds ratio of 0.25 with a 95 percent confidence interval of 0.08 to 0.74. The fourth trial by Bauer and colleagues in 2001 provided an odds ratio of 1.95 with a 95 percent confidence interval of 0.39 to 9.72. The fifth trial by Eriksson and colleagues in 2001 provided an odds ratio of 1.32 with a 95 percent confidence interval of 0.30 to 5.81. The combined effect of the four trials showed an odds ratio of 0.68 with a 95 percent confidence interval of 0.34 to 1.37. The I-squared value was 49.5 percent and the Egger's p-value was 0.040.

Figure 86 Impact of injectable low molecular weight heparin versus injectable or oral factor Xa inhibitors on nonfatal pulmonary embolism in patients undergoing major orthopedic surgery limited to total hip replacement surgery

I^2^: Too few strata

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of injectable low molecular weight heparin prophylaxis versus injectable or oral factor Xa inhibitor prophylaxis on nonfatal pulmonary embolism in patients who had major orthopedic surgery limited to total hip replacement surgery. Three trials were included in this analysis. The first trial by Yokote and colleagues in 2011 was excluded from the analysis because no events occurred in either of the treatment arms. The second trial by Lassen and colleagues in 2002 provided an odds ratio of 1.01 with a 95 percent confidence interval of 0.20 to 4.99. The third trial by Turpie and colleagues in 2002 provided an odds ratio of 0.25 with a 95 percent confidence interval of 0.08 to 0.74. The combined effect of the two trials showed an odds ratio of 0.39 with a 95 percent confidence interval of 0.16 to 0.95. The I-squared value could not be calculated because only two studies were available.

Figure 87 Impact of injectable low molecular weight heparin versus injectable or oral direct thrombin inhibitors on nonfatal pulmonary embolism in patients undergoing major orthopedic surgery (same as analysis limited to trials published from 2001 to the present)

I^2^: 53.7 percent

Egger's p-value: Too few strata

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of injectable low molecular weight heparin prophylaxis versus injectable or oral direct thrombin inhibitor prophylaxis on nonfatal pulmonary embolism in patients who had major orthopedic surgery. This figure also depicts the analysis of injectable low molecular weight heparin prophylaxis versus injectable or oral direct thrombin inhibitor prophylaxis on nonfatal pulmonary embolism in patients who had major orthopedic surgery limited to trials published from 2001-present. Two trials were included in the analysis with two trials contributing two separate comparisons presented individually here. The first trial by Eriksson and colleagues in 2007 included two separate comparisons. The first comparison provided a relative risk of 20.60 with a 95 percent confidence interval of 0.69 to 618.69. The second comparison provided a relative risk of 0.63 with a 95 percent confidence interval of 0.12 to 3.01. The second trial by Eriksson and colleagues in 2007 included two separate comparisons. The first comparison provided a relative risk of 0.14 with a 95 percent confidence interval of 0.003 to 6.93. The second comparison was excluded from the analysis because no events occurred in the groups compared. The combined effect of the two analyses showed a relative risk of 0.92 with a 95 percent confidence interval of 0.23 to 3.66. The I-squared value was 53.7 percent and the Egger's p-value could not be calculated because only two studies were available.

Figure 88 Impact of injectable low molecular weight heparin versus injectable or oral direct thrombin inhibitors on nonfatal pulmonary embolism in patients undergoing major orthopedic surgery limited to total hip replacement surgery

I^2^: Too few strata

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of injectable low molecular weight heparin prophylaxis versus injectable or oral direct thrombin inhibitor prophylaxis on nonfatal pulmonary embolism due to bleeding in patients who had major orthopedic surgery limited to total hip replacement surgery. One trial by Eriksson and colleagues in 2007 was included in the analysis with this trial contributing two separate comparisons presented individually here. The first comparison provided a relative risk of 8.09 with a 95 percent confidence interval of 0.70 to 93.15. The second comparison provided a relative risk of 0.60 with a 95 percent confidence interval of 0.12 to 3.06. The combined effect of the two analyses showed a relative risk of 1.61 with a 95 percent confidence interval of 0.13 to 19.37. The I-squared value could not be calculated because only one study was available.

Figure 89 Impact of injectable low molecular weight heparin versus oral vitamin k antagonists on nonfatal pulmonary embolism in patients undergoing major orthopedic surgery

I^2^: Too few strata

Egger's p-value: Too few strata

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of injectable low molecular weight heparin prophylaxis versus oral vitamin K antagonist prophylaxis on nonfatal pulmonary embolism in patients who had major orthopedic surgery. Three trials were included in the analysis with one trial contributing two separate comparisons presented individually here. The first trial by Lassen and colleagues in 2007 provided an odds ratio of 7.46 with a 95 percent confidence interval of 0.46 to 120.00. The second trial by Hull and colleagues in 2000 was excluded because no events occurred in the groups compared. The third trial by Leclerc and colleagues in 1996 provided a relative risk of 0.36 with a 95 percent confidence interval of 0.05 to 2.60. The combined effect of the two trials showed a relative risk of 1.00 with a 95 percent confidence interval of 0.20 to 4.95. The I-squared value and the Egger's p-value could not be calculated because only two studies were available.

Figure 90 Impact of injectable low molecular weight heparin versus oral vitamin k antagonists on nonfatal pulmonary embolism in patients undergoing major orthopedic surgery limited to total knee replacement surgery

I^2^: Too few strata

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of injectable low molecular weight heparin prophylaxis versus injectable or oral vitamin K antagonist prophylaxis on nonfatal pulmonary embolism in patients who had major orthopedic surgery limited to total knee replacement surgery. Two trials were included in this analysis. The first trial by Lassen and colleagues in 2007 provided an odds ratio of 7.46 with a 95 percent confidence interval of 0.46 to 120.00. The second trial by Leclerc and colleagues in 1996 provided an odds ratio of 0.36 with a 95 percent confidence interval of 0.05 to 2.60. The combined effect of the two trials showed an odds ratio of 1.00 with a 95 percent confidence interval of 0.20 to 4.95. The I-squared value could not be calculated because only two studies were available.

Figure 91 Impact of injectable low molecular weight heparin versus oral vitamin K antagonists on nonfatal pulmonary embolism during the postdischarge period in patients who had major orthopedic surgery

I^2^: Too few strata

Egger's p-value: Too few strata

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of injectable low molecular weight heparin versus oral vitamin K antagonists on nonfatal pulmonary embolism during the post-discharge period in patients who had major orthopedic surgery. One trial by Hull and colleagues in 1993 was included in the analysis, with this trial contributing two separate comparisons presented individually here. The first comparison provided an odds ratio of 7.37 with a 95 percent confidence interval of 0.15 to 371.45. The second comparison provided an odds ratio of 0.14 with a 95 percent confidence interval of 0.003 to 6.97. The combined effect of the two analyses showed an odds ratio of 1.01 with a 95 percent confidence interval of 0.06 to 16.14. The I-squared value and the Egger's p-value could not be calculated because only one study was available.

Figure 92 Impact of injectable unfractionated heparin versus injectable or oral direct thrombin inhibitors on nonfatal pulmonary embolism in patients undergoing major orthopedic surgery (same as analysis limited to total hip replacement)

I^2^: Too few strata

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of injectable unfractionated heparin prophylaxis versus injectable or oral direct thrombin inhibitor prophylaxis on nonfatal pulmonary embolism in patients who had major orthopedic surgery. This figure also depicts the analysis of injectable low molecular weight heparin prophylaxis versus injectable or oral direct thrombin inhibitor prophylaxis on nonfatal pulmonary embolism in patients who had major orthopedic surgery limited to total hip replacement surgery. One trial by Eriksson and colleagues in 1997 was included in the analysis with this trial contributing two separate comparisons presented individually here. The first comparison provided an odds ratio of 7.52 with a 95 percent confidence interval of 1.05 to 53.79. The second comparison provided an odds ratio of 0.12 with a 95 percent confidence interval of 0.002 to 6.01. The combined effect of the two analyses showed an odds ratio of 3.27 with a 95 percent confidence interval of 0.56 to 18.98. The I-squared value could not be calculated because only one study was available.

Figure 93 Impact of injectable low molecular weight heparin prophylaxis versus injectable unfractionated heparin prophylaxis on mortality in patients who had major orthopedic surgery

I^2^: 0 percent

Egger's p-value: 0.102

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the analysis of the impact of injectable low molecular weight heparin prophylaxis versus injectable unfractionated heparin prophylaxis on mortality in patients who had major orthopedic surgery. Eight trials are included, with one trial by Colwell and colleagues in 1994 contributing two separate comparisons. The first trial by Senaran and colleagues in 2006 was excluded from the analysis because no events occurred in the groups compared. The second trial by Schwartsmann and colleagues in 1996 was also excluded from the analysis because no events occurred in the groups compared. The third trial by Colwell and colleagues in 1994 included two separate comparisons. The first comparison provided an odds ratio of 0.51 with a 95 percent confidence interval of 0.03 to 9.44. The second comparison provided an odds ratio of 0.05 with a 95 percent confidence interval of 0.001 to 3.30. The fourth trial by Eriksson and colleagues in 1991 provided an odds ratio of 0.14 with a 95 percent confidence interval of 0.003 to 7.02. The fifth trial by Levin and colleagues in 1991 was excluded from the analysis because no events occurred in the groups compared. The sixth trial by Monreal and colleagues in 1989 provided an odds ratio of 0.63 with a 95 percent confidence interval of 0.10 to 3.78. The seventh trial by Planes and colleagues in 1988 was excluded from the analysis because no events occurred in the groups compared. The eighth trial by Barre and colleagues in 1987 was also excluded from the analysis because no events occurred in the groups compared. The combined effect of the three trials showed an odds ratio of 0.39 with a 95 percent confidence interval of 0.10 to 1.49. The I-squared value was 0 percent and the Egger's p-value was 0.102

Figure 94 Impact of injectable low molecular weight heparin prophylaxis versus injectable unfractionated heparin prophylaxis on mortality in patients who had major orthopedic surgery limited to total hip replacement surgery

I^2^: 0 percent

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of injectable low molecular weight heparin prophylaxis versus injectable unfractionated heparin prophylaxis on mortality in patients who had major orthopedic surgery limited to total hip replacement surgery. Seven trials are included with one trial contributing to two separate comparisons presented individually here. The first trial by Senaran and colleagues in 2006 was excluded from the analysis because no evens occurred in the groups compared. The second trial by Schwartsmann and colleagues in 1996 was excluded from the analysis because no events occurred in the groups compared. The third trial by Colwell and colleagues in 1994 included two separate comparisons. The first comparison provided an odds ratio of 0.51 with a 95 percent confidence interval of 0.03 to 9.44. The second comparison provided an odds ratio of 0.05 with a 95 percent confidence interval of 0.001 to 3.30. The fourth trial by Eriksson and colleagues in 1991 provided an odds ratio of 0.14 with a 95 percent confidence interval of 0.003 to 7.02. The fifth trial by Levin and colleagues in 1991 was excluded from the analysis because no events occurred in the groups compared. The sixth trial by Planes and colleagues in 1988 was excluded from the analysis because no events occurred in the groups compared. The seventh trial by Barre and colleagues in 1987 was excluded from the analysis because no events occurred in the groups compared. The combined effect of the two trials showed an odds ratio of 0.21 with a 95 percent confidence interval of 0.03 to 1.59. The I-squared value was 0 percent.

Figure 95 Impact of injectable low molecular weight heparin prophylaxis versus injectable or oral factor Xa inhibitor prophylaxis on mortality in patients who had major orthopedic surgery (same as analysis limited to 2001 to present)

I^2^: 0 percent

Egger's p-value: P = 0.952

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of injectable low molecular weight heparin prophylaxis versus injectable or oral factor Xa inhibitor prophylaxis on mortality in patients who had major orthopedic surgery. This figure also depicts the analysis of injectable low molecular weight heparin prophylaxis versus injectable or oral factor Xa inhibitor prophylaxis on mortality in patients who had major orthopedic surgery limited to trials published from 2001 to present. Five trials were included in this analysis. The first trial by Yokote and colleagues in 2011 was excluded from the analysis because no events occurred in either of the treatment arms. The sceond trial by Lassen and colleagues in 2002 provided an odds ratio of 1.96 with a 95 percent confidence interval of 0.40 to 9.74. The third trial by Turpie and colleagues in 2002 provided an odds ratio of 0.51 with a 95 percent confidence interval of 0.14 to 1.89. The fourth trial by Bauer and colleagues in 2001 provided an odds ratio of 1.49 with a 95 percent confidence interval of 0.26 to 8.65. The fifth trial by Eriksson and colleagues in 2001 provided an odds ratio of 1.10 with a 95 percent confidence interval of 0.70 to 1.72. The combined effect of the four trials showed an odds ratio of 1.08 with a 95 percent confidence interval of 0.72 to 1.60. The I-squared value was 0 percent and the Egger's p-value was 0.952.

Figure 96 Impact of injectable low molecular weight heparin prophylaxis versus injectable or oral factor Xa inhibitor prophylaxis on mortality in patients who had major orthopedic surgery limited to total hip replacement surgery

I^2^: Too few strata

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of injectable low molecular weight heparin prophylaxis versus injectable or oral factor Xa inhibitor prophylaxis on mortality in patients who had major orthopedic surgery limited to total hip replacement surgery. Three trials were included in this analysis. The first trial by Yokote and colleagues in 2011 because no events occurred in either of the treatment arms. The second trial by Lassen and colleagues in 2002 provided an odds ratio of 1.96 with a 95 percent confidence interval of 0.40 to 9.74. The third trial by Turpie and colleagues in 2002 provided an odds ratio of 0.51 with a 95 percent confidence interval of 0.14 to 1.89. The combined effect of the two trials showed an odds ratio of 0.88 with a 95 percent confidence interval of 0.32 to 2.42. The I-squared value could not be calculated because of too few strata.

Figure 97 Impact of injectable low molecular weight heparin prophylaxis versus injectable or oral direct thrombin inhibitor prophylaxis on mortality in patients who had major orthopedic surgery

I^2^: 0 percent

Egger's p-value: P = 0.023

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of injectable low molecular weight heparin prophylaxis versus injectable or oral direct thrombin inhibitor prophylaxis on mortality in patients who had major orthopedic surgery. Four trials were included in the analysis with three trials contributing two separate comparisons presented individually here. The first trial by Ginsberg and colleagues in 2009 included two comparisons. The first comparison provided a relative risk of 0.67 with a 95 percent confidence interval of 0.06 to 8.11. The second comparison provided a relative risk of 0.66 with a 95 percent confidence interval of 0.05 to 7.98. The second trial by Eriksson and colleagues in 2007 included two separate comparisons. The first comparison provided a relative risk of 0.29 with a 95 percent confidence interval of 0.03 to 3.08. The second comparison provided a relative risk of 0.28 with a 95 percent confidence interval of 0.03 to 3.03. The third trial by Eriksson and colleagues in 2007 included two separate comparisons. The first comparison provided a relative risk of 1.02 with a 95 percent confidence interval of 0.08 to 13.64. The second comparison provided a relative risk of 0.99 with a 95 percent confidence interval of 0.07 to 13.22. The fourth trial by Eriksson and colleagues in 1997 provided a relative risk of 0.26 with a 95 percent confidence interval of 0.04 to 1.69. The combined effect of the four trials provided a relative risk of 0.45 with a 95 percent confidence interval of 0.15 to 1.36. The I-squared value was 0 percent and the Egger's p-value was 0.023.

Figure 98 Impact of injectable low molecular weight heparin prophylaxis versus injectable or oral direct thrombin inhibitor prophylaxis on mortality in patients who had major orthopedic surgery limited to trials published from 2001 to present

I^2^: 0 percent

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of injectable low molecular weight heparin prophylaxis versus injectable or oral direct thrombin inhibitor prophylaxis on mortality in patients who had major orthopedic surgery limited to trials published from 2001 to present. Three trials were included in the analysis with three trials contributing two separate comparisons presented individually here. The first trial by Ginsberg and colleagues in 2009 included two comparisons. The first comparison provided a relative risk of 0.67 with a 95 percent confidence interval of 0.06 to 8.11. The second comparison provided a relative risk of 0.66 with a 95 percent confidence interval of 0.05 to 7.98. The second trial by Eriksson and colleagues in 2007 included two separate comparisons. The first comparison provided a relative risk of 0.29 with a 95 percent confidence interval of 0.03 to 3.08. The second comparison provided a relative risk of 0.28 with a 95 percent confidence interval of 0.03 to 3.03. The third trial by Eriksson and colleagues in 2007 included two separate comparisons. The first comparison provided a relative risk of 1.02 with a 95 percent confidence interval of 0.08 to 13.64. The second comparison provided a relative risk of 0.99 with a 95 percent confidence interval of 0.07 to 13.22. The combined effect of the three trials provided a relative risk of 0.54 with a 95 percent confidence interval of 0.15 to 1.98. The I-squared value was 0 percent.

Figure 99 Impact of injectable low molecular weight heparin prophylaxis versus injectable or oral direct thrombin inhibitor prophylaxis on mortality in patients who had major orthopedic surgery limited to total hip replacement surgery

I^2^: 0 percent

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of injectable low molecular weight heparin prophylaxis versus injectable or oral direct thrombin inhibitor prophylaxis on mortality in patients who had major orthopedic surgery limited to total hip replacement surgery. Two trials were included in the analysis with one trial contributing two separate comparisons presented individually here. The first trial by Eriksson and colleagues in 2007 included two separate comparisons. The first comparison provided a relative risk of 0.29 with a 95 percent confidence interval of 0.03 to 3.08. The second comparisons provided a relative risk of 0.28 with a 95 percent confidence interval of 0.03 to 3.03. The second trial by Eriksson and colleagues in 1997 provided a relative risk of 0.26 with a 95 percent confidence interval of 0.04 to 1.69. The combined effect of the two trials showed a relative risk of 0.27 with a 95 percent confidence interval of 0.06 to 1.23. The I-squared value was 0 percent.

Figure 100 Impact of injectable low molecular weight heparin prophylaxis versus injectable or oral direct thrombin inhibitor prophylaxis on mortality in patients who had major orthopedic surgery limited to total knee replacement surgery

I^2^: 0 percent

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of injectable low molecular weight heparin prophylaxis versus injectable or oral direct thrombin inhibitor prophylaxis on mortality in patients who had major orthopedic surgery limited to total knee replacement surgery. Two trials were included in the analysis with two trials contributing two separate comparisons presented individually here. The first trial by Ginsberg and colleagues in 2009 included two separate comparisons. The first comparison provided a relative risk of 0.67 with a 95 percent confidence interval of 0.06 to 8.11. The second comparisons provided a relative risk of 0.66 with a 95 percent confidence interval of 0.05 to 7.98. The second trial by Eriksson and colleagues in 2007 included two separate comparisons. The first comparison provided a relative risk of 1.02 with a 95 percent confidence interval of 0.08 to 13.64. The second comparison provided a relative risk of 0.99 with a 95 percent confidence interval of 0.07 to 13.22. The combined effect of the two trials showed a relative risk of 0.80 with a 95 percent confidence interval of 0.16 to 4.17. The I-squared value was 0 percent.

Figure 101 Impact of injectable low molecular weight heparin prophylaxis versus oral vitamin K antagonist prophylaxis on mortality in patients who had major orthopedic surgery

I^2^: 0 percent

Egger's p-value: P = 0.188

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of injectable low molecular weight heparin prophylaxis versus oral vitamin K antagonist prophylaxis on mortality in patients who had major orthopedic surgery. Six trials were included in the analysis with one trial contributing two separate comparisons presented individually here. The first trial by Lassen and colleagues in 2007 was because no events occurred in the groups compared. The second trial by Fitzgerald and colleagues in 2001 provided an odds ratio of 0.37 with a 95 percent confidence interval of 0.05 to 2.66. The third trial by Hull and colleagues in 2000 included two comparisons. The first comparison provided an odds ratio of 0.99 with a 95 percent confidence interval of 0.09 to 10.97. The second comparison provided an odds ratio of 0.05 with a 95 percent confidence interval of 0.001 to 3.20. The fourth trial by Colwell and colleagues by 1999 provided an odds ratio of 0.89 with a 95 percent confidence interval of 0.36 to 2.19. The fifth trial by Leclerc and colleagues in 1996 provided an odds ratio of 0.99 with a 95 percent confidence interval of 0.06 to 15.93. The sixth trial by Hull and colleagues by 1993 provided an odds ratio of 1.01 with a 95 percent confidence interval of 0.29 to 3.50. The combined effect of the five trials showed an odds ratio of 0.79 with a 95 percent confidence interval of 0.42 to 1.50. The I-squared value was 0 percent and the Egger's p-value was 0.188.

Figure 102 Impact of injectable low molecular weight heparin prophylaxis versus oral vitamin K antagonist prophylaxis on mortality in patients who had major orthopedic surgery limited to total hip replacement surgery

I^2^: 0 percent

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of injectable low molecular weight heparin prophylaxis versus oral vitamin K antagonist prophylaxis on mortality in patients who had major orthopedic surgery limited to total hip replacement surgery. Two trials were included in the analysis with one trial contributing two separate comparisons presented individually here. The first trial by Hull and colleagues in 2000 included two separate comparisons. The first comparison provided a relative risk of 0.99 with a 95 percent confidence interval of 0.13 to 7.51. The second comparisons provided a relative risk of 0.17 with a 95 percent confidence interval of 0.01 to 2.03. The second trial by Colwell and colleagues in 1999 provided a relative risk of 0.89 with a 95 percent confidence interval of 0.37 to 2.12. The combined effect of the two trials showed a relative risk of 0.81 with a 95 percent confidence interval of 0.36 to 1.82. The I-squared value was 0 percent.

Figure 103 Impact of injectable low molecular weight heparin prophylaxis versus oral vitamin K antagonist prophylaxis on mortality in patients who had major orthopedic surgery limited to total knee replacement surgery

I^2^: Too few strata

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of injectable low molecular weight heparin prophylaxis versus oral vitamin K antagonist prophylaxis on mortality in patients who had major orthopedic surgery limited to total knee replacement surgery. Three trials were included in the analysis. The first trial by Lassen and colleagues in 2007 was excluded because no events occurred in the groups compared. The second trial by Fitzgerald and colleagues in 2001 provided an odds ratio of 0.37 with a 95 percent confidence interval of 0.05 to 2.66. The third trial by Leclerc and colleagues in 1996 provided an odds ratio of 0.99 with a 95 percent confidence interval of 0.06 to 15.93. The combined effect of the two trials showed an odds ratio of 0.52 with a 95 percent confidence interval of 0.10 to 2.57. The I-squared value could not be calculated since only two studies were available.

Figure 104 Impact of injectable low molecular weight heparin prophylaxis versus mechanical prophylaxis on mortality in patients who had major orthopedic surgery

I^2^: Too few strata

Egger's p-value: Too few strata

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of injectable low molecular weight heparin prophylaxis versus mechanical prophylaxis on mortality in patients who had major orthopedic surgery. Two trials were included in the analysis. The first trial by Warwick and colleagues in 2002 provided an odds ratio of 0.38 with a 95 percent confidence interval of 0.053 to 2.73. The second trial by Warwick and colleagues in 1998 provided an odds ratio of 0.14 with a 95 percent confidence interval of 0.003 to 7.01. The combined effect of the two trials showed an odds ratio of 0.31 with a 95 percent confidence interval of 0.05 to 1.81. The I-squared value and Egger's p-value could not be calculated because only two studies were available.

Figure 105 Impact of injectable unfractionated heparin prophylaxis versus injectable or oral direct thrombin inhibitor prophylaxis on mortality in patients who had major orthopedic surgery (same as analysis limited to total hip replacement surgery)

I^2^: Too few strata

Egger's p-value: Too few strata

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of injectable unfractionated heparin prophylaxis versus injectable or oral direct thrombin inhibitor prophylaxis on mortality in patients who had major orthopedic surgery. This figure also depicts the analysis of the impact of injectable unfractionated heparin prophylaxis versus injectable or oral direct thrombin inhibitor prophylaxis on mortality in patients who had major orthopedic surgery limited to total hip replacement surgery. Two trials were included in the analysis. The first trial by Eriksson and colleagues in 1997 provided an odds ratio of 7.43 with a 95 percent confidence interval of 0.46 to 119.25. The second trial by Eriksson and colleagues in 1996 provided an odds ratio of 6.57 with a 95 percent confidence interval of 0.13 to 333.53. The combined effect of the two trials showed an odds ratio of 7.13 with a 95 percent confidence interval of 0.74 to 68.80. The I-squared value and Egger's p-value could not be calculated because only two studies were available.

Figure 106 Impact of injectable low molecular weight heparin prophylaxis versus injectable or oral direct thrombin inhibitor prophylaxis on mortality due to bleeding in patients who had major orthopedic surgery (same as analysis limited to 2001 to present)

I^2^: Too few strata

Egger's p-value: Too few strata

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of injectable low molecular weight heparin prophylaxis versus injectable or oral direct thrombin inhibitor prophylaxis on mortality due to bleeding in patients who had major orthopedic surgery. This figure also depicts the analysis of the impact of injectable low molecular weight heparin prophylaxis versus injectable or oral direct thrombin inhibitor prophylaxis on mortality due to bleeding in patients who had major orthopedic surgery limited to trials published from 2001 to present. Three trials were included in the analysis with three trials contributing two separate comparisons presented individually here. The first trial by Ginsberg and colleagues in 2009 was excluded because no events occurred in the groups compared. The second trial by Eriksson and colleagues in 2007 included two separate comparisons. The first comparison provided a relative risk of 0.67 with a 95 percent confidence interval of 0.06 to 8.15. The second comparison provided a relative risk of 0.66 with a 95 percent confidence interval of 0.05 to 8.03. The third trial by Eriksson and colleagues in 2007 was excluded because no events occurred in the groups compared. The combined effect of the two comparisons showed a relative risk of 0.67 with a 95 confidence interval of 0.07 to 6.40. The I-squared value and Egger's p-value could not be calculated because only of too few studies.

Figure 107 Impact of injectable low molecular weight heparin prophylaxis versus injectable or oral direct thrombin inhibitor prophylaxis on mortality due to bleeding in patients who had major orthopedic surgery limited to total hip replacement surgery

I^2^: Too few strata

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of injectable low molecular weight heparin prophylaxis versus injectable or oral direct thrombin inhibitor prophylaxis on mortality due to bleeding in patients who had major orthopedic surgery limited to total hip replacement surgery. One trial by Eriksson and colleagues in 2007 was included in the analysis with this trial contributing two separate comparisons presented individually here. The first comparison provided a relative risk of 0.67 with a 95 percent confidence interval of 0.06 to 8.15. The second comparison provided a relative risk of 0.66 with a 95 percent confidence interval of 0.05 to 8.03. The combined effect of the two comparisons showed a relative risk of 0.67 with a 95 percent confidence interval of 0.07 to 6.40. The I-squared value could not be calculated because only one study was available.

Figure 108 Impact of oral antiplatelet prophylaxis versus mechanical prophylaxis on deep vein thrombosis in patients undergoing major orthopedic surgery

I^2^: 0 percent

Egger's p-value: Too few strata

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the analysis of the impact of oral antiplatelet prophylaxis versus mechanical prophylaxis on deep vein thrombosis in patients undergoing major orthopedic surgery. Two trials were included in the analysis with one trial by Haas and colleagues in 1990 including two separate comparisons presented individually here. The first trial by Kennedy and colleagues in 2000 provided a relative risk of 1.68 with a 95 percent confidence interval of 0.55 to 5.19. The second trial by Haas and colleagues in 1990 included two separate comparisons. The first comparison provided a relative risk of 2.13 with a 95 percent confidence interval of 1.09 to 4.33. The second comparison provided a relative risk of 1.42 with a 95 percent confidence interval of 0.86 to 2.41. The combined effect of these two trials showed a relative risk of 1.63 with a 95 percent confidence interval of 1.11 to 2.39. The I-squared value was 0 percent and the Egger's p-value could not be calculated because of too few strata.

Figure 109 Impact of oral antiplatelet prophylaxis versus mechanical prophylaxis on deep vein thrombosis in patients undergoing major orthopedic surgery limited to total knee replacement surgery

I^2^: 0 percent

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the analysis of the impact of oral antiplatelet prophylaxis versus mechanical prophylaxis on deep vein thrombosis in patients undergoing major orthopedic surgery limited to total knee replacement surgery. One trial by Haas and colleagues in 1990 with two separate comparisons was included in this analysis. The first comparison provided a relative risk of 2.13 with a 95 percent confidence interval of 1.09 to 4.33. The second comparison provided a relative risk of 1.42 with a 95 percent confidence interval of 0.86 to 2.41. The combined effect of these two comparisons showed a relative risk of 1.63 with a 95 percent confidence interval of 1.08 to 2.44. The I-squared value was 0 percent.

Figure 110 Impact of injectable low molecular weight heparin prophylaxis versus injectable unfractionated heparin prophylaxis on deep vein thrombosis in patients undergoing major orthopedic surgery

I^2^: 34.4 percent

Egger's p-value: 0.808

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of Impact of injectable low molecular weight heparin prophylaxis versus injectable unfractionated heparin prophylaxis on deep vein thrombosis in patients undergoing major orthopedic surgery. Thirteen trials were included in the analysis with three trials contributing to two separate comparisons presented individually here. The first trial by Senaran and colleagues in 2006 provided a relative risk of 0.20 with a 95 percent confidence interval of 0.02 to 2.16. The second trial by Schwartsmann and colleagues in 1996 provided a relative risk of 0.90 with a 95 percent confidence interval of 0.30 to 2.77. The third trial by Avikainen and colleagues in 1995 provided a relative risk of 0.25 with a 95 percent confidence interval of 0.04 to 1.64. The fourth trial by Colwell and colleagues in 1995 provided a relative risk of 0.72 with a 95 percent confidence interval of 0.54 to 0.96. The fifth trial by Colwell and colleagues in 1994 included two separate comparisons. The first comparison provided a relative risk of 0.40 with a 95 percent confidence interval of 0.18 to 0.90. The second comparison provided a relative risk of 1.27 with a 95 percent confidence interval of 0.70 to 2.38. The sixth trial by Fauno and colleagues in 1994 provided a relative risk of 0.85 with a 95 percent confidence interval of 0.51 to 1.40. The seventh trial by Menzin and colleagues in 1994 included two separate comparisons. The first comparison provided a relative risk of 0.41 with a 95 percent confidence interval of 0.18 to 0.92. The second comparison provided a relative risk of 1.29 with a 95 percent confidence interval of 0.71 to 2.42. The eighth trial by Eriksson and colleagues in 1991 provided a relative risk of 0.71 with a 95 percent confidence interval of 0.44 to 1.14. The ninth trial by Levine and colleagues in 1991 provided a relative risk of 0.84 with a 95 percent confidence interval of 0.60 to 1.16. The tenth trial by Dechavanne and colleagues in 1989 included two separate comparisons. The first comparison provided a relative risk of 0.49 with a 95 percent confidence interval of 0.09 to 2.66. The second comparison provided a relative risk of 0.73 with a 95 percent confidence interval of 0.16 to 3.51. The eleventh trial by Monreal and colleagues in 1989 provided a relative risk of 2.19 with a 95 percent confidence interval of 1.01 to 4.98. The twelfth trial by Planes and colleagues in 1988 provided a relative risk of 0.50 with a 95 percent confidence interval of 0.28 to 0.88. The thirteenth trial by Barre and colleagues in 1987 provided a relative risk of 1.75 with a 95 percent confidence interval of 0.59 to 5.28. The combined effect of the thirteen trials showed a relative risk of 0.80 with a 95 percent confidence interval of 0.65 to 0.99. The I-squared value was 34.4 percent and the Egger's p-value was 0.808.

Figure 111 Impact of injectable low molecular weight heparin versus injectable unfractionated heparin on deep vein thrombosis in patients who all received unfractionated heparin before randomization and underwent major orthopedic surgery

I^2^: Too few strata

Egger's p-value: Too few strata

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of injectable low molecular weight heparin versus injectable unfractionated heparin on deep vein thrombosis in patients who all received unfractionated heparin before randomization and underwent major orthopedic surgery. One trial by Rader and colleagues in 1998 was included in the analysis with this trial contributing two separate comparisons presented individually here. The first comparison provided a relative risk of 6.00 with a 95 percent confidence interval of 0.99 to 37.43. The second comparison provided a relative risk of 1.60 with a 95 percent confidence interval of 0.21 to 12.06. The combined effect of the two analyses showed a relative risk of 3.37 with a 95 percent confidence interval of 0.70 to 16.17. The I-squared value and the Egger's p-value could not be calculated because only two studies were available.

Figure 112 Impact of injectable low molecular weight heparin prophylaxis versus injectable unfractionated heparin prophylaxis on deep vein thrombosis in patients undergoing major orthopedic surgery limited to total hip replacement surgery

I^2^: 26.4 percent

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of Impact of injectable low molecular weight heparin prophylaxis versus injectable unfractionated heparin prophylaxis on deep vein thrombosis in patients undergoing major orthopedic surgery limited to total hip replacement surgery. Ten trials were included in the analysis with three trials contributing to two separate comparisons presented individually here. The first trial by Senaran and colleagues in 2006 provided a relative risk of 0.20 with a 95 percent confidence interval of 0.02 to 2.16. The second trial by Schwartsmann and colleagues in 1996 provided a relative risk of 0.90 with a 95 percent confidence interval of 0.30 to 2.77. The third trial by Avikainen and colleagues in 1995 provided a relative risk of 0.25 with a 95 percent confidence interval of 0.04 to 1.64. The fourth trial by Colwell and colleagues in 1994 included two separate comparisons. The first comparison provided a relative risk of 0.40 with a 95 percent confidence interval of 0.18 to 0.90. The second comparison provided a relative risk of 1.27 with a 95 percent confidence interval of 0.70 to 2.38. The fifth trial by Menzin and colleagues in 1994 included two separate comparisons. The first comparison provided a relative risk of 0.41 with a 95 percent confidence interval of 0.18 to 0.92. The second comparison provided a relative risk of 1.29 with a 95 percent confidence interval of 0.71 to 2.42. The sixth trial by Eriksson and colleagues in 1991 provided a relative risk of 0.71 with a 95 percent confidence interval of 0.44 to 1.14. The seventh trial by Levine and colleagues in 1991 provided a relative risk of 0.84 with a 95 percent confidence interval of 0.60 to 1.16. The eighth trial by Dechavanne and colleagues in 1989 included two separate comparisons. The first comparison provided a relative risk of 0.49 with a 95 percent confidence interval of 0.09 to 2.66. The second comparison provided a relative risk of 0.73 with a 95 percent confidence interval of 0.16 to 3.51. The ninth trial by Planes and colleagues in 1988 provided a relative risk of 0.50 with a 95 percent confidence interval of 0.28 to 0.88. The tenth trial by Barre and colleagues in 1987 provided a relative risk of 1.75 with a 95 percent confidence interval of 0.59 to 5.28. The combined effect of the ten trials showed a relative risk of 0.75 with a 95 percent confidence interval of 0.58 to 0.97. The I-squared value was 26.4 percent.

Figure 113 Impact of injectable low molecular weight heparin prophylaxis versus injectable unfractionated heparin prophylaxis on deep vein thrombosis in patients undergoing major orthopedic surgery limited to total knee replacement surgery

I^2^: Too few strata

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of Impact of injectable low molecular weight heparin prophylaxis versus injectable unfractionated heparin prophylaxis on deep vein thrombosis in patients undergoing major orthopedic surgery limited to total knee replacement surgery. Two trials were included in the analysis. The first trial by Colwell and colleagues in 1995 provided a relative risk of 0.72 with a 95 percent confidence interval of 0.54 to 0.96. The second trial by Fauno and colleagues in 1994 provided a relative risk of 0.85 with a 95 percent confidence interval of 0.51 to 1.40. The combined effect of the two trials showed a relative risk of 0.75 with a 95 percent confidence interval of 0.58 to 0.96. The I-squared value could not be calculated because only two studies were available.

Figure 114 Impact of injectable low molecular weight heparin prophylaxis versus injectable or oral factor Xa inhibitor prophylaxis on deep vein thrombosis in patients undergoing major orthopedic surgery (same as limited from 2001 to present)

I^2^: 42.5 percent

Egger's p-value: 0.225

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of Impact of injectable low molecular weight heparin prophylaxis versus injectable or oral factor Xa inhibitor prophylaxis on deep vein thrombosis in patients undergoing major orthopedic surgery. This also represents the same analysis limited to trials published from 2001 to present. Five trials were included in the analysis. The first trial by Yokote and colleagues in 2011 prvided a relative risk of 0.84 with a 95 perecnt confidence interval of 0.28 to 2.51. The second trial by Lassen and colleagues in 2002 provided a relative risk of 2.28 with a 95 percent confidence interval of 1.56 to 3.33. The third trial by Turpie and colleagues in 2002 provided a relative risk of 1.46 with a 95 percent confidence interval of 1.01 to 2.10. The fourth trial by Bauer and colleagues in 2001 provided a relative risk of 2.18 with a 95 percent confidence interval of 1.59 to 3.01. The fifth trial by Eriksson and colleagues in 2001 provided a relative risk of 2.39 with a 95 percent confidence interval of 1.75 to 3.28. The combined effect of the five trials showed a relative risk of 1.99 with a 95 percent confidence interval of 1.57 to 2.51. The I-squared value was 42.5 percent and the Egger's p-value was 0.225.

Figure 115 Impact of injectable low molecular weight heparin prophylaxis versus injectable or oral factor Xa inhibitor prophylaxis on deep vein thrombosis in patients undergoing major orthopedic surgery limited to total hip replacement surgery

I^2^: 51.4 percent

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of Impact of injectable low molecular weight heparin prophylaxis versus injectable or oral factor Xa inhibitor prophylaxis on deep vein thrombosis in patients undergoing major orthopedic surgery limited to total hip replacement surgery. Three trials were included in the analysis. The first trial by Yokote and colleagues in 2011 provided an odds ratio of 0.83 with 95 percent confidence interval of 0.25 to 2.82. The second trial by Lassen and colleagues in 2002 provided an odds ratio of 2.30 with a 95 percent confidence interval of 1.59 to 3.33. The third trial by Turpie and colleagues in 2002 provided an odds ratio of 1.49 with a 95 percent confidence interval of 1.01 to 2.20. The combined effect of the three trials showed an odds ratio of 1.80 with a 95 percent confidence interval of 1.38 to 2.34. The I-squared value was 51.4 percent.

Figure 116 Impact of injectable low molecular weight heparin prophylaxis versus oral vitamin K antagonist prophylaxis on deep vein thrombosis in patients undergoing major orthopedic surgery

I^2^: 60.9 percent

Egger's p-value: 0.033

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of Impact of injectable low molecular weight heparin prophylaxis versus oral vitamin K antagonist prophylaxis on deep vein thrombosis in patients undergoing major orthopedic surgery. Five trials were included in the analysis with two trials contributing to two separate comparisons presented individually here. The first trial by Fitzgerald and colleagues in 2001 provided a relative risk of 0.57 with a 95 percent confidence interval of 0.42 to 0.76. The second trial by Hull and colleagues in 2000 included two separate comparisons. The first comparison provided a relative risk of 0.45 with a 95 percent confidence interval of 0.30 to 0.67. The second comparison provided a relative risk of 0.55 with a 95 percent confidence interval of 0.37 to 0.80. The third trial by Francis and colleagues in 1997 provided a relative risk of 0.57 with a 95 percent confidence interval of 0.37 to 0.85. The fourth trial by Leclerc and colleagues in 1996 provided a relative risk of 0.69 with a 95 percent confidence interval of 0.54 to 0.89. The fifth trial by Hull and colleagues in 1993 included two separate comparisons. The first comparison provided a relative risk of 0.89 with a 95 percent confidence interval of 0.67 to 1.19. The second comparison provided a relative risk of 0.82 with a 95 percent confidence interval of 0.69 to 0.97. The combined effect of the five trials showed a relative risk of 0.66 with a 95 percent confidence interval of 0.55 to 0.79. The I-squared value was 60.9 percent and the Egger's p-value was 0.033.

Figure 117 Impact of injectable low molecular weight heparin prophylaxis versus oral vitamin K antagonist prophylaxis on deep vein thrombosis in patients undergoing major orthopedic surgery limited to total hip replacement surgery

I^2^: 67.6 percent

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of Impact of injectable low molecular weight heparin prophylaxis versus oral vitamin K antagonist prophylaxis on deep vein thrombosis in patients undergoing major orthopedic surgery limited to total hip replacement surgery. Three trials were included in the analysis with one trial contributing to two separate comparisons presented individually here. The first trial by Hull and colleagues in 2000 included two separate comparisons. The first comparison provided a relative risk of 0.45 with a 95 percent confidence interval of 0.30 to 0.67. The second comparison provided a relative risk of 0.55 with a 95 percent confidence interval of 0.37 to 0.80. The second trial by Francis and colleagues in 1997 provided a relative risk of 0.57 with a 95 percent confidence interval of 0.37 to 0.85. The third trial by Hull and colleagues in provided a relative risk of 0.89 with a 95 percent confidence interval of 0.67 to 1.19. The combined effect of the three trials showed a relative risk of 0.61 with a 95 percent confidence interval of 0.44 to 0.84. The I-squared value was 67.6 percent.

Figure 118 Impact of injectable low molecular weight heparin prophylaxis versus oral vitamin K antagonist prophylaxis on deep vein thrombosis in patients undergoing major orthopedic surgery limited to total knee replacement surgery

I^2^: 57.2 percent

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of Impact of injectable low molecular weight heparin prophylaxis versus oral vitamin K antagonist prophylaxis on deep vein thrombosis in patients undergoing major orthopedic surgery limited to total knee replacement surgery. Three trials were included in the analysis. The first trial by Fitzgerald and colleagues in 2001 provided a relative risk of 0.57 with a 95 percent confidence interval of 0.42 to 0.76. The second trial by Leclerc and colleagues in 1996 provided a relative risk of 0.69 with a 95 percent confidence interval of 0.54 to 0.89. The third trial by Hull and colleagues in 1993 provided a relative risk of 0.82 with a 95 percent confidence interval of 0.69 to 0.97. The combined effect of the three trials showed a relative risk of 0.71 with a 95 percent confidence interval of 0.57 to 0.87. The I-squared value was 57.2 percent.

Figure 119 Impact of injectable low molecular weight heparin prophylaxis versus mechanical prophylaxis on deep vein thrombosis in patients undergoing major orthopedic surgery

I^2^: 0 percent

Egger's p-value: Too few strata

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of impact of injectable low molecular weight heparin prophylaxis versus mechanical prophylaxis on deep vein thrombosis in patients undergoing major orthopedic surgery. Three trials were included in the analysis. The first trial by Warwick and colleagues in 2002 provided a relative risk of 0.94 with a 95 percent confidence interval of 0.72 to 1.21. The second trial by Warwick and colleagues in 1998 provided a relative risk of 0.74 with a 95 percent confidence interval of 0.42 to 1.29. The third trial by Stone and colleagues in 1996 provided a relative risk of 1.00 with a 95 percent confidence interval of 0.11 to 9.28. The combined effect of the three trials showed a relative risk of 0.90 with a 95 percent confidence interval of 0.71 to 1.14. The I-squared value was 0 percent and the Egger's p-value could not be calculated because there were only three studies.

Figure 120 Impact of injectable low molecular weight heparin prophylaxis versus mechanical prophylaxis on deep vein thrombosis in patients undergoing major orthopedic surgery limited to total hip replacement surgery

I^2^: 0 percent

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of impact of injectable low molecular weight heparin prophylaxis versus mechanical prophylaxis on deep vein thrombosis in patients undergoing major orthopedic surgery limited to total hip replacement surgery. Two trials were included in the analysis. The first trial by Warwick and colleagues in 1998 provided a relative risk of 0.74 with a 95 percent confidence interval of 0.42 to 1.29. The second trial by Stone and colleagues in 1996 provided a relative risk of 1.00 with a 95 percent confidence interval of 0.11 to 9.28. The combined effect of the two trials showed a relative risk of 0.75 with a 95 percent confidence interval of 0.43 to 1.30. The I-squared value was 0 percent.

Figure 121 Impact of injectable unfractionated heparin prophylaxis versus injectable or oral direct thrombin inhibitor prophylaxis on deep vein thrombosis in patients undergoing major orthopedic surgery (same as total hip replacement therapy)

I^2^: 0 percent

Egger's p-value: Too few strata

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of impact of injectable unfractionated heparin prophylaxis versus injectable or oral direct thrombin inhibitor prophylaxis on deep vein thrombosis in patients undergoing major orthopedic surgery. This also represents the same analysis limited total hip replacement surgery. Two trials were included in the analysis. The first trial by Eriksson and colleagues in 1997 provided a relative risk of 3.23 with a 95 percent confidence interval of 1.82 to 5.79. The second trial by Eriksson and colleagues in 1996 provided a relative risk of 1.84 with a 95 percent confidence interval of 1.31 to 2.59. The combined effect of the two trials showed a relative risk of 2.31 with a 95 percent confidence interval of 1.34 to 4.00. The I-squared value was 0 percent and the Egger's p-value could not be calculated because there were only two studies available.

Figure 122 Impact of oral vitamin K antagonist prophylaxis versus mechanical prophylaxis on deep vein thrombosis in patients undergoing major orthopedic surgery (same as limited to total hip replacement surgery)

I^2^: 58.5 percent

Egger's p-value: Too few strata

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of impact of oral vitamin K antagonist prophylaxis versus mechanical prophylaxis on deep vein thrombosis in patients undergoing major orthopedic surgery. This also represents the same analysis limited total hip replacement surgery. Three trials were included in the analysis. The first trial by Francis and colleagues in 1992 provided a relative risk of 1.17 with a 95 percent confidence interval of 0.76 to 1.81. The second trial by Bailey and colleagues in 1991 provided a relative risk of 4.44 with a 95 percent confidence interval of 1.46 to 14.05. The third trial by Paiement and colleagues in 1987 provided a relative risk of 1.00 with a 95 percent confidence interval of 0.48 to 2.08. The combined effect of the three trials showed a relative risk of 1.45 with a 95 percent confidence interval of 0.75 to 2.82. The I-squared value was 58.5 percent and the Egger's p-value could not be calculated because there were only three studies available.

Figure 123 Impact of injectable low molecular weight heparin versus injectable unfractionated heparin on asymptomatic deep vein thrombosis in patients undergoing major orthopedic surgery (same as analysis limited to total hip replacement surgery)

I^2^: Too few strata

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of injectable low molecular weight heparin prophylaxis versus injectable unfractionated heparin prophylaxis on asymptomatic deep vein thrombosis in patients who had major orthopedic surgery. This figure also depicts the analysis of the impact of injectable low molecular weight heparin prophylaxis versus injectable unfractionated heparin prophylaxis on asymptomatic deep vein thrombosis in patients who had major orthopedic surgery limited to total hip replacement surgery. Two trials were included in the analysis, contributing two comparisons presented individually here. The first trial by Schwartsmann and colleagues in 1996 provided a relative risk of 0.90 with a 95 percent confidence interval of 0.16 to 4.98. The second trial by Eriksson and colleagues in 1991 provided a relative risk of 0.69 with a 95 percent confidence interval of 0.41 to 1.15. The combined effect of the two trials showed a relative risk of 0.70 with a 95 percent confidence interval of 0.43 to 1.16. The I-squared could not be calculated because only two studies were available.

Figure 124 Impact of injectable low molecular weight heparin versus injectable or oral direct thrombin inhibitors on asymptomatic deep vein thrombosis in patients undergoing major orthopedic surgery (same as analysis limited to trials published from 2001-present)

I^2^: 0 percent

Egger's p-value: 0.536

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of injectable low molecular weight heparin prophylaxis versus injectable or oral direct thrombin inhibitor prophylaxis on asymptomatic deep vein thrombosis in patients who had major orthopedic surgery. This figure also depicts the analysis of injectable low molecular weight heparin prophylaxis versus injectable or oral direct thrombin inhibitor prophylaxis on asymptomatic deep vein thrombosis in patients who had major orthopedic surgery limited to trials published from 2001-present. Two trials were included in the analysis with two trials contributing two separate comparisons presented individually here. The first trial by Eriksson and colleagues in 2007 included two separate comparisons. The first comparison provided a relative risk of 0.87 with a 95 percent confidence interval of 0.56 to 1.32. The second comparison provided a relative risk of 1.37 with a 95 percent confidence interval of 0.86 to 2.18. The second trial by Eriksson and colleagues in 2007 included two separate comparisons. The first comparison provided a relative risk of 0.91 with a 95 percent confidence interval of 0.74 to 1.10. The second comparison provided a relative risk of 1.00 with a 95 percent confidence interval of 0.82 to 1.22. The combined effect of the two trials showed a relative risk of 0.97 with a 95 percent confidence interval of 0.85 to 1.10. The I-squared value was 0 percent and the Egger's p-value was 0.536.

Figure 125 Impact of injectable low molecular weight heparin versus injectable or oral direct thrombin inhibitors on asymptomatic deep vein thrombosis in patients undergoing major orthopedic surgery limited to total hip replacement surgery

I^2^: Too few strata

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of injectable low molecular weight heparin prophylaxis versus injectable or oral direct thrombin inhibitor prophylaxis on asymptomatic deep vein thrombosis in patients who had major orthopedic surgery limited to total hip replacement surgery. One trial by Eriksson and colleagues in 2007 was included in the analysis contributing two separate comparisons presented individually here. The first comparison provided a relative risk of 0.87 with a 95 percent confidence interval of 0.56 to 1.32. The second comparison provided a relative risk of 1.37 with a 95 percent confidence interval of 0.86 to 2.18. The combined effect of the two analyses showed a relative risk of 1.08 with a 95 percent confidence interval of 0.69 to 1.69. The I-squared value could not be calculated because only one study was available.

Figure 126 Impact of injectable low molecular weight heparin versus injectable or oral direct thrombin inhibitors on asymptomatic deep vein thrombosis in patients undergoing major orthopedic surgery limited to total knee replacement

I^2^: Too few strata

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of injectable low molecular weight heparin prophylaxis versus injectable or oral direct thrombin inhibitor prophylaxis on asymptomatic deep vein thrombosis in patients who had major orthopedic surgery limited to total knee replacement surgery. One trial by Eriksson and colleagues in 2007 was included in the analysis, contributing two separate comparisons presented individually here. The first comparison provided a relative risk of 0.91 with a 95 percent confidence interval of 0.74 to 1.10. The second comparison provided a relative risk of 1.00 with a 95 percent confidence interval of 0.82 to 1.22. The combined effect of the two analyses showed a relative risk of 0.95 with a 95 percent confidence interval of 0.83 to 1.09. The I-squared value could not be calculated because only one study was available.

Figure 127 Impact of injectable low molecular weight heparin versus injectable unfractionated heparin on symptomatic deep vein thrombosis in patients undergoing major orthopedic surgery (same as analysis limited to total hip replacement)

I^2^: 0 percent

Egger's p-value: Too few strata

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of injectable low molecular weight heparin prophylaxis versus injectable unfractionated heparin prophylaxis on symptomatic deep vein thrombosis in patients who had major orthopedic surgery. This figure also depicts the analysis of the impact of injectable low molecular weight heparin prophylaxis versus injectable unfractionated heparin prophylaxis on symptomatic deep vein thrombosis in patients who had major orthopedic surgery limited to total hip replacement surgery. Three trials were included in the analysis. The first trial by Schwartsmann and colleagues in 1996 provided an odds ratio of 0.90 with a 95 percent confidence interval of 0.17 to 4.66. The second trial by Avikainen and colleagues in 1995 provided an odds ratio of 0.30 with a 95 percent confidence interval of 0.05 to 1.75. The third trial by Eriksson in 1991 provided an odds ratio of 0.93 with a 95 percent confidence interval of 0.13 to 6.81. The combined effect of the three trials showed a relative risk of 0.62 with a 95 percent confidence interval of 0.22 to 1.75. The I-squared value was 0 percent and the Egger's p-value could not be calculated because only three studies were available.

Figure 128 Impact of injectable low molecular weight heparin versus injectable unfractionated heparin on symptomatic deep vein thrombosis during the postdischarge period in patients who had major orthopedic surgery

I^2^: Too few strata

Egger's p-value: Too few strata

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of injectable low molecular weight heparin versus injectable unfractionated heparin on symptomatic deep vein thrombosis during the post-discharge period in patients who had major orthopedic surgery. Two trials were included in the analysis presented here. The first comparison by Seneran and colleagues in 2006 provided an odds ratio of 7.54 with a 95 percent confidence interval of 0.47 to 122.28. The second comparison by Fauno and colleagues in 1994 provided an odds ratio of 0.14 with a 95 percent confidence interval of 0.003 to 6.90. The combined effect of the two analyses showed an odds ratio of 1.96 with a 95 percent confidence interval of 0.20 to 19.02. The I-squared value and the Egger's p-value could not be calculated because only two studies were available.

Figure 129 Impact of injectable low molecular weight heparin versus injectable or oral factor Xa inhibitors on symptomatic deep vein thrombosis in patients undergoing major orthopedic surgery (same as analysis limited to trials published from 2001-present)

I^2^: 0 percent

Egger's p-value: 0.583

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of injectable low molecular weight heparin prophylaxis versus injectable or oral factor Xa inhibitor prophylaxis on symptomatic deep vein thrombosis in patients who had major orthopedic surgery. This figure also depicts the analysis of injectable low molecular weight heparin prophylaxis versus injectable or oral factor Xa inhibitor prophylaxis on symptomatic deep vein thrombosis in patients who had major orthopedic surgery limited to trials published from 2001-present. Six trials were included in this analysis. The first trial by Yokote and colleagues in 2011 provided an odds ratio of 0.14 with 95 percent confidence interval of 0.003 to 6.90. The second trial by Bonneux and colleagues in 2006 provided an odds ratio of 0.52 with a 95 percent confidence interval of 0.05 to 5.07. The third trial by Lassen and colleagues in 2002 provided an odds ratio of 0.37 with a 95 percent confidence interval of 0.05 to 2.63. The fourth trial by Turpie and colleagues in 2002 provided an odds ratio of 0.13 with a 95 percent confidence interval of 0.02 to 0.78. The fifth trial by Bauer and colleagues in 2001 provided an odds ratio of 1.33 with a 95 percent confidence interval of 0.30 to 5.89. The fourth trial by Eriksson and colleagues in 2001 provided an odds ratio of 0.99 with a 95 percent confidence interval of 0.06 to 15.83. The combined effect of the six trials showed an odds ratio of 0.48 with a 95 percent confidence interval of 0.21 to 1.12. The I-squared value was 0 percent and the Egger's p-value was 0.583.

Figure 130 Impact of injectable low molecular weight heparin versus injectable or oral factor Xa inhibitors on symptomatic deep vein thrombosis in patients undergoing major orthopedic surgery limited to total hip replacement surgery

I^2^: 0 percent

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of injectable low molecular weight heparin prophylaxis versus injectable or oral factor Xa inhibitor prophylaxis on symptomatic deep vein thrombosis in patients who had major orthopedic surgery limited to total hip replacement surgery. Three trials were included in this analysis. The first trial by Yokote and colleagues in 2011 provided an odds ration of 0.14 with 95 percent confidence interval of 0.003 to 6.90. The second trial by Lassen and colleagues in 2002 provided an odds ratio of 0.37 with a 95 percent confidence interval of 0.05 to 2.63. The third trial by Turpie and colleagues in 2002 provided an odds ratio of 0.13 with a 95 percent confidence interval of 0.02 to 0.78. The combined effect of the three trials showed an odds ratio of 0.20 with a 95 percent confidence interval of 0.06 to 0.70. The I-squared value was 0 percent.

Figure 131 Impact of injectable low molecular weight heparin versus injectable or oral factor Xa inhibitors on symptomatic deep vein thrombosis in patients undergoing major orthopedic surgery limited to total knee replacement surgery

I^2^: Too few strata

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of injectable low molecular weight heparin prophylaxis versus injectable or oral factor Xa inhibitor prophylaxis on symptomatic deep vein thrombosis in patients who had major orthopedic surgery limited to total knee replacement surgery. Two trials were included in this analysis. The first trial by Bonneux and colleagues in 2006 provided an odds ratio of 0.52 with a 95 percent confidence interval of 0.05 to 5.07. The second trial by Bauer and colleagues in 2001 provided an odds ratio of 1.33 with a 95 percent confidence interval of 0.30 to 5.89. The combined effect of the two trials showed an odds ratio of 1.01 with a 95 percent confidence interval of 0.29 to 3.48. The I-squared value could not be calculated because only two studies were available.

Figure 132 Impact of injectable low molecular weight heparin versus injectable or oral direct thrombin inhibitors on symptomatic deep vein thrombosis in patients undergoing major orthopedic surgery (same as analysis limited to trials published from 2001-present)

I^2^: 47.5 percent

Egger's p-value: 0.476

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of injectable low molecular weight heparin prophylaxis versus injectable or oral direct thrombin inhibitor prophylaxis on symptomatic deep vein thrombosis in patients who had major orthopedic surgery. This figure also depicts the meta-analysis of the impact of injectable low molecular weight heparin prophylaxis versus injectable or oral direct thrombin inhibitor prophylaxis on symptomatic deep vein thrombosis in patients who had major orthopedic surgery limited to trials published from 2001-present. Three trials were included in the analysis with all three trials contributing two separate comparisons presented individually here. The first trial by Ginsberg and colleagues in 2009 included two comparisons. The first comparison provided a relative risk of 0.84 with a 95 percent confidence interval of 0.22 to 3.27. The second comparison provided a relative risk of 0.67 with a 95 percent confidence interval of 0.18 to 2.54. The second trial by Eriksson and colleagues in 2007 included two separate comparisons. The first comparison provided a relative risk of 0.11 with a 95 percent confidence interval of 0.01 to 1.12. The second comparison provided a relative risk of 0.17 with a 95 percent confidence interval of 0.02 to 1.69. The third trial by Eriksson and colleagues in 2007 included two separate comparisons. The first comparison provided a relative risk of 2.71 with a 95 percent confidence interval of 0.68 to 10.76. The second comparison provided a relative risk of 7.88 with a 95 percent confidence interval of 1.19 to 52.32. The combined effect of the three trials provided a relative risk of 0.98 with a 95 percent confidence interval of 0.34 to 2.87. The I-squared value was 47.5 percent and the Egger's p-value was 0.476.

Figure 133 Impact of injectable low molecular weight heparin versus injectable or oral direct thrombin inhibitors on symptomatic deep vein thrombosis in patients undergoing major orthopedic surgery limited to total hip replacement surgery

I^2^: Too few strata

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of injectable low molecular weight heparin prophylaxis versus injectable or oral direct thrombin inhibitor prophylaxis on symptomatic deep vein thrombosis in patients who had major orthopedic surgery limited to total hip replacement surgery. One trial by Eriksson and colleagues in 2007 was included in the analysis with this trial contributing two separate comparisons presented individually here. The first comparison provided a relative risk of 0.11 with a 95 percent confidence interval of 0.01 to 1.12. The second comparison provided a relative risk of 0.17 with a 95 percent confidence interval of 0.02 to 1.69. The combined effect of the two analyses showed a relative risk of 0.14 with a 95 percent confidence interval of 0.02 to 1.03. The I-squared value could not be calculated because only one study was available.

Figure 134 Impact of injectable low molecular weight heparin versus injectable or oral direct thrombin inhibitors on symptomatic deep vein thrombosis in patients undergoing major orthopedic surgery limited to total knee replacement surgery

I^2^: 35 percent

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of injectable low molecular weight heparin prophylaxis versus injectable or oral direct thrombin inhibitor prophylaxis on symptomatic deep vein thrombosis in patients who had major orthopedic surgery limited to total knee replacement surgery. Two trials were included in the analysis with two trials contributing two separate comparisons presented individually here. The first trial by Ginsberg and colleagues in 2009 included two separate comparisons. The first comparison provided a relative risk of 0.84 with a 95 percent confidence interval of 0.22 to 3.27. The second comparisons provided a relative risk of 0.67 with a 95 percent confidence interval of 0.18 to 2.54. The second trial by Eriksson and colleagues in 2007 included two separate comparisons. The first comparison provided a relative risk of 2.71 with a 95 percent confidence interval of 0.68 to 10.76. The second comparison provided a relative risk of 7.88 with a 95 percent confidence interval of 1.19 to 52.32. The combined effect of the two trials showed a relative risk of 1.55 with a 95 percent confidence interval of 0.58 to 4.20. The I-squared value was 35 percent.

Figure 135 Impact of injectable low molecular weight heparin versus oral vitamin K antagonists on symptomatic deep vein thrombosis in patients undergoing major orthopedic surgery

I^2^: 28.4 percent

Egger's p-value: 0.376

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of injectable low molecular weight heparin prophylaxis versus oral vitamin K antagonist prophylaxis on symptomatic deep vein thrombosis in patients who had major orthopedic surgery. Three trials were included in the analysis with one trial contributing two separate comparisons presented individually here. The first trial by Lassen and colleagues in 2007 provided an odds ratio of 1.00 with a 95 percent confidence interval of 0.06 to 16.09. The second trial by Hull and colleagues in 2000 included two separate comparisons. The first comparison provided an odds ratio of 0.29 with a 95 percent confidence interval of 0.09 to 0.97. The second comparison provided an odds ratio of 0.65 with a 95 percent confidence interval of 0.24 to 1.77. The third trial by Colwell and colleagues in 1999 provided an odds ratio of 1.03 with a 95 percent confidence interval of 0.69 to 1.55. The combined effect of the two trials showed an odds ratio of 0.87 with a 95 percent confidence interval of 0.61 to 1.24. The I-squared value and the Egger's p-value could not be calculated because only two studies were available.

Figure 136 Impact of injectable low molecular weight heparin versus oral vitamin K antagonists on symptomatic deep vein thrombosis in patients undergoing major orthopedic surgery limited to total hip replacement surgery

I^2^: 52.2 percent

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of injectable low molecular weight heparin prophylaxis versus oral vitamin K antagonist prophylaxis on symptomatic deep vein thrombosis in patients undergoing major orthopedic surgery limited to total hip replacement surgery. Two trials were included in the analysis with one trial contributing two separate comparisons presented individually here. The first trial by Hull and colleagues in 2000 provided two comparisons. The first comparison provided an odds ratio of 0.29 with a 95 percent confidence interval of 0.09 to 0.97. The second comparison provided an odds ratio of 0.65 with a 95 percent confidence interval of 0.24 to 1.77. The second trial by Colwell and colleagues in 1999 provided an odds ratio of 1.03 with a 95 percent confidence interval of 0.69 to 1.55. The combined effect of the two trials showed an odds ratio of 0.87 with a 95 percent confidence interval of 0.60 to 1.24. The I-squared value was 52.2 percent.

Figure 137 Impact of injectable low molecular weight heparin prophylaxis versus injectable unfractionated heparin prophylaxis on proximal deep vein thrombosis in patients undergoing major orthopedic surgery

I^2^: 37 percent

Egger's p-value: 0.450

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of impact of injectable low molecular weight heparin prophylaxis versus injectable unfractionated heparin prophylaxis on proximal deep vein thrombosis in patients undergoing major orthopedic surgery. Nine trials were included in the analysis with two trials contributing to two separate comparisons presented individually here. The first trial by Schwartsmann and colleagues in 1996 provided a relative risk of 0.72 with a 95 percent confidence interval of 0.22 to 2.36. The second trial by Avikainen and colleagues in 1995 provided a relative risk of 0.25 with a 95 percent confidence interval of 0.04 to 1.64. The third trial by Colwell and colleagues in 1995 provided a relative risk of 0.22 with a 95 percent confidence interval of 0.09 to 0.56. The fourth trial by Colwell and colleagues in 1994 included two separate comparisons. The first comparison provided a relative risk of 0.43 with a 95 percent confidence interval of 0.13 to 1.44. The second comparison provided a relative risk of 0.82 with a 95 percent confidence interval of 0.29 to 2.33. The fifth trial by Fauno and colleagues in 1994 provided a relative risk of 0.61 with a 95 percent confidence interval of 0.16 to 2.23. The sixth trial by Levine and colleagues in 1991 provided a relative risk of 0.84 with a 95 percent confidence interval of 0.43 to 1.65. The seventh trial by Dechavanne and colleagues in 1989 included two separate comparisons. The first comparison provided a relative risk of 0.33 with a 95 percent confidence interval of 0.04 to 2.61. The second comparison provided a relative risk of 0.33 with a 95 percent confidence interval of 0.04 to 2.61. The eighth trial by Monreal and colleagues in 1989 provided a relative risk of 2.25 with a 95 percent confidence interval of 0.95 to 5.61. The ninth trial by Planes and colleagues in 1988 provided a relative risk of 0.41 with a 95 percent confidence interval of 0.19 to 0.83. The combined effect of the nine trials showed a relative risk of 0.60 with a 95 percent confidence interval of 0.38 to 0.93. The I-squared value was 37 percent and the Egger's p-value was 0.450.

Figure 138 Impact of injectable low molecular weight heparin prophylaxis versus injectable unfractionated heparin prophylaxis on proximal deep vein thrombosis in patients undergoing major orthopedic surgery limited to total hip replacement surgery

I^2^: 0 percent

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of impact of injectable low molecular weight heparin prophylaxis versus injectable unfractionated heparin prophylaxis on proximal deep vein thrombosis in patients undergoing major orthopedic surgery limited to total hip replacement surgery. Six trials were included in the analysis with two trials contributing to two separate comparisons presented individually here. The first trial by Schwartsmann and colleagues in 1996 provided a relative risk of 0.72 with a 95 percent confidence interval of 0.22 to 2.36. The second trial by Avikainen and colleagues in 1995 provided a relative risk of 0.25 with a 95 percent confidence interval of 0.04 to 1.64. The third trial by Colwell and colleagues in 1994 included two separate comparisons. The first comparison provided a relative risk of 0.43 with a 95 percent confidence interval of 0.13 to 1.44. The second comparison provided a relative risk of 0.82 with a 95 percent confidence interval of 0.29 to 2.33. The fourth trial by Levine and colleagues in 1991 provided a relative risk of 0.84 with a 95 percent confidence interval of 0.43 to 1.65. The fifth trial by Dechavanne and colleagues in 1989 included two separate comparisons. The first comparison provided a relative risk of 0.33 with a 95 percent confidence interval of 0.04 to 2.61. The second comparison provided a relative risk of 0.33 with a 95 percent confidence interval of 0.04 to 2.61. The sixth trial by Planes and colleagues in 1988 provided a relative risk of 0.41 with a 95 percent confidence interval of 0.19 to 0.83. The combined effect of the six trials showed a relative risk of 0.58 with a 95 percent confidence interval of 0.39 to 0.86. The I-squared value was 0 percent.

Figure 139 Impact of injectable low molecular weight heparin prophylaxis versus injectable unfractionated heparin prophylaxis on proximal deep vein thrombosis in patients undergoing major orthopedic surgery limited to total knee replacement surgery

I^2^: Too few strata

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of impact of injectable low molecular weight heparin prophylaxis versus injectable unfractionated heparin prophylaxis on proximal deep vein thrombosis in patients undergoing major orthopedic surgery limited to total knee replacement surgery. Two trials were included in the analysis. The first trial by Colwell and colleagues in 1995 provided a relative risk of 0.22 with a 95 percent confidence interval of 0.09 to 0.56. The second trial by Fauno and colleagues in 1994 provided a relative risk of 0.61 with a 95 percent confidence interval of 0.16 to 2.23. The combined effect of the two trials showed a relative risk of 0.32 with a 95 percent confidence interval of 0.13 to 0.82. The I-squared value could not be calculated because there were only two studies available.

Figure 140 Impact of injectable low molecular weight heparin prophylaxis versus injectable or oral factor Xa inhibitor prophylaxis on proximal deep vein thrombosis in patients undergoing major orthopedic surgery (same as 2001 to present)

I^2^: 69.9 percent

Egger's p-value: 0.388

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of impact of injectable low molecular weight heparin prophylaxis versus injectable or oral factor Xa inhibitor prophylaxis on proximal deep vein thrombosis in patients undergoing major orthopedic surgery. This also represents the analysis limited to trials published from 2001 to present. Five trials were included in the analysis. The first trial by Yokote and colleagues in 2011 provided an odds ratio of 0.14 with 95 percent confidence interval of 0.003 to 6.90. The second trial by Lassen and colleagues in 2002 provided an odds ratio of 3.27 with a 95 percent confidence interval of 1.57 to 6.81. The third trial by Turpie and colleagues in 2002 provided an odds ratio of 0.70 with a 95 percent confidence interval of 0.31 to 1.57. The fourth trial by Bauer and colleagues in 2001 provided an odds ratio of 2.18 with a 95 percent confidence interval of 1.04 to 4.57. The fifth trial by Eriksson and colleagues in 2001 provided an odds ratio of 3.80 with a 95 percent confidence interval of 1.92 to 7.50. The combined effect of the five trials showed an odds ratio of 2.19 with a 95 percent confidence interval of 1.52 to 3.16. The I-squared value was 69.9 percent and Egger's p-value was 0.388.

Figure 141 Impact of injectable low molecular weight heparin prophylaxis versus injectable or oral factor Xa inhibitor prophylaxis on proximal deep vein thrombosis in patients undergoing major orthopedic surgery limited to total hip replacement surgery

I^2^: 78.2 percent

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of impact of injectable low molecular weight heparin prophylaxis versus injectable or oral factor Xa inhibitor prophylaxis on proximal deep vein thrombosis in patients undergoing major orthopedic surgery limited to total hip replacement surgery. Three trials were included in the analysis. The first trial by Yokote and colleagues in 2011 provided an odds ratio of 0.14 with 95 percent confiedence interval of 0.003 to 6.90. The second trial by Lassen and colleagues in 2002 provided an odds ratio of 3.27 with a 95 percent confidence interval of 1.57 to 6.81. The third trial by Turpie and colleagues in 2002 provided an odds ratio of 0.70 with a 95 percent confidence interval of 0.31 to 1.57. The combined effect of the three trials showed an odds ratio of 1.55 with a 95 percent confidence interval of 0.91 to 2.66. The I-squared value was 78,2 percent.

Figure 142 Impact of injectable low molecular weight heparin prophylaxis versus injectable or oral direct thrombin inhibitor prophylaxis on proximal deep vein thrombosis in patients undergoing major orthopedic surgery

I^2^: 70.8 percent

Egger's p-value: Too few strata

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of impact of injectable low molecular weight heparin prophylaxis versus injectable or oral direct thrombin inhibitor prophylaxis on proximal deep vein thrombosis in patients undergoing major orthopedic surgery. Two trials were included in the analysis including one trial with two separate comparisons. The first trial by Ginsberg and colleagues in 2009 provided two separate comparisons. The first comparison provided a relative risk of 0.50 with a 95 percent confidence interval of 0.20 to 1.28. The second comparison provided a relative risk of 0.67 with a 95 percent confidence interval of 0.25 to 1.77. The second trial by Eriksson and colleagues in 1997 provided a relative risk of 1.67 with a 95 percent confidence interval of 1.12 to 2.50. The combined effect of the two trials showed a relative risk of 0.91 with a 95 percent confidence interval of 0.40 to 2.11. The I-squared value was 70.8 percent and Egger's p-value could not be calculated because there were only two studies available.

Figure 143 Impact of injectable low molecular weight heparin prophylaxis versus injectable or oral direct thrombin inhibitor prophylaxis on proximal deep vein thrombosis in patients undergoing major orthopedic surgery limited to trials published from 2001 to present (same as original analysis limited to total knee replacement surgery)

I^2^: Too few strata

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of impact of injectable low molecular weight heparin prophylaxis versus injectable or oral direct thrombin inhibitor prophylaxis on proximal deep vein thrombosis in patients undergoing major orthopedic surgery limited to trials published from 2001to present. This represents the same analysis limited to total knee replacement surgery. One trial by Ginsberg and colleagues in 2009 including two separate comparisons was included in the analysis. The first comparison provided a relative risk of 0.50 with a 95 percent confidence interval of 0.20 to 1.28. The second comparison provided a relative risk of 0.67 with a 95 percent confidence interval of 0.25 to 1.77. The combined effect of the two comparisons showed a relative risk of 0.58 with a 95 percent confidence interval of 0.29 to 1.17. The I-squared value could not be calculated because there was only one study available.

Figure 144 Impact of injectable low molecular weight heparin prophylaxis versus oral vitamin K antagonist prophylaxis on proximal deep vein thrombosis in patients undergoing major orthopedic surgery

I^2^: 55.3 percent

Egger's p-value: 0.224

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of impact of injectable low molecular weight heparin prophylaxis versus oral vitamin K antagonist prophylaxis on proximal deep vein thrombosis in patients undergoing major orthopedic surgery. Six trials were included in the analysis with two trials contributing to two separate comparisons presented individually here. The first trial by Lassen and colleagues in 2007 provided a relative risk of 1.50 with a 95 percent confidence interval of 0.31 to 7.41. The second trial by Fitzgerald and colleagues in 2001 provided a relative risk of 0.15 with a 95 percent confidence interval of 0.05 to 0.47. The third trial by Hull and colleagues in 2000 included two separate comparisons. The first comparison provided a relative risk of 0.28 with a 95 percent confidence interval of 0.08 to 1.03. The second comparison provided a relative risk of 0.28 with a 95 percent confidence interval of 0.08 to 1.01. The fourth trial by Francis and colleagues in 1997 provided a relative risk of 0.62 with a 95 percent confidence interval of 0.29 to 1.30. The fifth trial by Leclerc and colleagues in 1996 provided a relative risk of 1.08 with a 95 percent confidence interval of 0.62 to 1.88. The sixth trial by Hull and colleagues in 1993 included two separate comparisons. The first comparison provided a relative risk of 1.26 with a 95 percent confidence interval of 0.63 to 2.54. The second comparison provided a relative risk of 0.63 with a 95 percent confidence interval of 0.37 to 1.06. The combined effect of the six trials showed a relative risk of 0.63 with a 95 percent confidence interval of 0.39 to 1.00. The I-squared value was 55.3 percent and Egger's p-value was 0.224.

Figure 145 Impact of injectable low molecular weight heparin prophylaxis versus oral vitamin K antagonist prophylaxis on proximal deep vein thrombosis in patients undergoing major orthopedic surgery limited to trials published from 2001 to present

I^2^: Too few strata

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of impact of injectable low molecular weight heparin prophylaxis versus oral vitamin K antagonist prophylaxis on proximal deep vein thrombosis in patients undergoing major orthopedic surgery limited to trials published from 2001 to present. Two trials were included in the analysis. The first trial by Lassen and colleagues in 2007 provided a relative risk of 1.50 with a 95 percent confidence interval of 0.31 to 7.41. The second trial by Fitzgerald and colleagues in 2001 provided a relative risk of 0.15 with a 95 percent confidence interval of 0.05 to 0.47. The combined effect of the two trials showed a relative risk of 0.43 with a 95 percent confidence interval of 0.05 to 4.11. The I-squared value could not be calculated because there were only two studies available.

Figure 146 Impact of injectable low molecular weight heparin prophylaxis versus oral vitamin K antagonist prophylaxis on proximal deep vein thrombosis in patients undergoing major orthopedic surgery limited to total hip replacement surgery

I^2^: 55.3 percent

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of impact of injectable low molecular weight heparin prophylaxis versus oral vitamin K antagonist prophylaxis on proximal deep vein thrombosis in patients undergoing major orthopedic surgery limited to total hip replacement surgery. Three trials were included in the analysis with one trial contributing to two separate comparisons presented individually here. The first trial by Hull and colleagues in 2000 included two separate comparisons. The first comparison provided an odds ratio of 0.25 with a 95 percent confidence interval of 0.06 to 1.03. The second comparison provided an odds ratio of 0.24 with a 95 percent confidence interval of 0.06 to 1.02. The second trial by Francis and colleagues in 1997 provided an odds ratio of 0.60 with a 95 percent confidence interval of 0.27 to 1.34. The third trial by Hull and colleagues in 1993 provided an odds ratio of 1.27 with a 95 percent confidence interval of 0.60 to 2.68. The combined effect of the three trials showed an odds ratio of 0.67 with a 95 percent confidence interval of 0.42 to 1.08. The I-squared value was 55.3 percent.

Figure 147 Impact of injectable low molecular weight heparin prophylaxis versus oral vitamin K antagonist prophylaxis on proximal deep vein thrombosis in patients undergoing major orthopedic surgery limited to total knee replacement surgery

I^2^: 68.9 percent

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of injectable low molecular weight heparin prophylaxis versus oral vitamin K antagonist prophylaxis on proximal deep vein thrombosis in patients who had major orthopedic surgery limited to total knee replacement surgery. Four trials were included in the analysis. The first trial by Lassen and colleagues in 2007 provided a relative risk of 1.50 with a 95 percent confidence interval of 0.31 to 7.41. The second trial by Fitzgerald and colleagues in 2001 provided a relative risk of 0.15 with a 95 percent confidence interval of 0.05 to 0.47. The third trial by Leclerc and colleagues in 1996 provided a relative risk of 1.08 with a 95 percent confidence interval of 0.62 to 1.88. The fourth trial by Hull and colleagues in 1993 provided a relative risk of 0.63 with a 95 percent confidence interval of 0.37 to 1.06. The combine effect of four trials showed a relative risk of 0.63 with a 95 percent confidence interval of 0.30 to 1.34. The I-squared value was 68.9 percent.

Figure 148 Impact of injectable low molecular weight heparin prophylaxis versus mechanical prophylaxis on proximal deep vein thrombosis in patients undergoing major orthopedic surgery

I^2^: 0 percent

Egger's p-value: Too few strata

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of injectable low molecular weight heparin prophylaxis versus mechanical prophylaxis on proximal deep vein thrombosis in patients who had major orthopedic surgery. Three trials were included in the analysis. The first trial by Warwick and colleagues in 2002 provided a relative risk of 0.12 with a 95 percent confidence interval of 0.00 to 1.05. The second trial by Warwick and colleagues in 1998 provided a relative risk of 0.70 with a 95 percent confidence interval of 0.35 to 1.38. The third trial by Stone and colleagues in 1996 provided a relative risk of 1.00 with a 95 percent confidence interval of 0.11 to 9.28. The combined effect of three trials showed a relative risk of 0.65 with a 95 percent confidence interval of 0.34 to 1.26. The I-squared value was 0 percent. The Egger's p-value could not be calculated because only three studies were available.

Figure 149 Impact of injectable low molecular weight heparin prophylaxis versus mechanical prophylaxis on proximal deep vein thrombosis in patients undergoing major orthopedic surgery limited to total hip replacement surgery

I^2^: Too few strata

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of injectable low molecular weight heparin prophylaxis versus mechanical prophylaxis on proximal deep vein thrombosis in patients who had major orthopedic surgery limited to total hip replacement surgery. Two trials were included in the analysis. The first trial by Warwick and colleagues in 1998 provided a relative risk of 0.70 with a 95 percent confidence interval of 0.35 to 1.38. The second trial by Stone and colleagues in 1996 provided a relative risk of 1.00 with a 95 percent confidence interval of 0.11 to 9.28. The combined effect of the two trials showed a relative risk of 0.71 with a 95 percent confidence interval of 0.36 to 1.40. The I-squared value could not be calculated because only two studies were available.

Figure 150 Impact of injectable unfractionated heparin prophylaxis versus injectable or oral direct thrombin inhibitor prophylaxis on proximal deep vein thrombosis in patients undergoing major orthopedic surgery (same as limited to total hip replacement surgery)

I^2^: Too few strata

Egger's p-value: Too few strata

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of injectable unfractionated heparin prophylaxis versus injectable or oral direct thrombin inhibitor prophylaxis on proximal deep vein thrombosis in patients who had major orthopedic surgery. This also represents the same analysis limited to total hip replacement surgery. Two trials were included in the analysis. The first trial by Eriksson and colleagues in 1997 provided an odds ratio of 4.55 with a 95 percent confidence interval of 2.22 to 9.31. The second trial by Eriksson and colleagues in 1996 provided an odds ratio of 4.87 with a 95 percent confidence interval of 2.68 to 8.84. The combined effect of the two trials showed an odds ratio of 4.74 with a 95 percent confidence interval of 2.99 to 7.49. The I-squared value and the Egger's p-value could not be calculated because only two studies were available.

Figure 151 Impact of oral vitamin K antagonist prophylaxis versus mechanical prophylaxis on proximal deep vein thrombosis in patients undergoing major orthopedic surgery (same as limited to total hip replacement surgery)

I^2^: 0 percent

Egger's p-value: Too few strata

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of oral vitamin K antagonist prophylaxis versus mechanical prophylaxis on proximal deep vein thrombosis in patients who had major orthopedic surgery. This also represents the same analysis limited to total hip replacement surgery. Three trials were included in the analysis. The first trial by Francis and colleagues in 1992 provided a relative risk of 0.24 with a 95 percent confidence interval of 0.07 to 0.76. The second trial by Bailey and colleagues in 1991 provided a relative risk of 0.22 with a 95 percent confidence interval of 0.02 to 2.39. The third trial by Paiement and colleagues in 1987 provided a relative risk of 0.46 with a 95 percent confidence interval of 0.17 to 1.21. The combined effect of the three trials showed a relative risk of 0.34 with a 95 percent confidence interval of 0.16 to 0.73. The I-squared value was 0 percent. The Egger's p-value could not be calculated because only three studies were available.

Figure 152 Impact of oral antiplatelet prophylaxis versus mechanical prophylaxis on distal deep vein thrombosis in patients undergoing major orthopedic surgery

I^2^: Too few strata

Egger's p-value: Too few strata

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact oral antiplatelet prophylaxis versus mechanical prophylaxis on distal deep vein thrombosis in patients who had major orthopedic. One trial by Haas and colleagues in 1990 was included in the analysis with this trial contributing two separate comparisons presented individually here. The first comparison provided a relative risk of 2.13 with a 95 percent confidence interval of 1.09 to 4.33. The second comparison provided a relative risk of 1.59 with a 95 percent confidence interval of 0.91 to 2.90. The combined effect of the two comparisons showed a relative risk of 1.79 with a 95 percent confidence interval of 1.15 to 2.79. The I-squared value and the Egger's p-value could not be calculated because only one study was available.

Figure 153 Impact of injectable low molecular weight heparin prophylaxis versus injectable unfractionated heparin prophylaxis on distal deep vein thrombosis in patients undergoing major orthopedic surgery limited to total hip replacement surgery

I^2^: 0 percent

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of impact of injectable low molecular weight heparin prophylaxis versus injectable unfractionated heparin prophylaxis on distal deep vein thrombosis in patients undergoing major orthopedic surgery limited to total hip replacement surgery. Five trials were included in the analysis with two trials contributing to two separate comparisons presented individually here. The first trial by Schwartsmann and colleagues in 1996 provided a relative risk of 2.72 with a 95 percent confidence interval of 0.24 to infinity. The second trial by Avikainen and colleagues in 1995 was excluded because no events occurred in either of the groups compared. The third trial by Colwell and colleagues in 1994 included two separate comparisons. The first comparison provided a relative risk of 0.39 with a 95 percent confidence interval of 0.12 to 1.28. The second comparison provided a relative risk of 1.85 with a 95 percent confidence interval of 0.78 to 4.53. The fourth trial by Dechavanne and colleagues in 1989 included two separate comparisons. The first comparison provided a relative risk of 0.98 with a 95 percent confidence interval of 0.08 to 12.97. The second comparison provided a relative risk of 1.95 with a 95 percent confidence interval of 0.18 to 22.21. The fifth trial by Planes and colleagues in 1988 provided a relative risk of 0.77 with a 95 percent confidence interval of 0.28 to 2.13. The combined effect of the four trials showed a relative risk of 1.03 with a 95 percent confidence interval of 0.58 to 1.83. The I-squared value was 0 percent.

Figure 154 Impact of injectable low molecular weight heparin prophylaxis versus injectable unfractionated heparin prophylaxis on distal deep vein thrombosis in patients undergoing major orthopedic surgery limited to total knee replacement surgery

I^2^: Too few strata

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of impact of injectable low molecular weight heparin prophylaxis versus injectable unfractionated heparin prophylaxis on distal deep vein thrombosis in patients undergoing major orthopedic surgery limited to total knee replacement surgery. Two trials were included in the analysis. The first trial by Colwell and colleagues in 1995 provided a relative risk of 0.93 with a 95 percent confidence interval of 0.67 to 1.30. The second trial by Fauno and colleagues in 1994 provided a relative risk of 0.91 with a 95 percent confidence interval of 0.52 to 1.59. The combined effect of the two trials showed a relative risk of 0.93 with a 95 percent confidence interval of 0.69 to 1.24. The I-squared value could not be calculated because there were only two studies available.

Figure 155 Impact of injectable low molecular weight heparin prophylaxis versus injectable or oral factor Xa inhibitor prophylaxis on distal deep vein thrombosis in patients undergoing major orthopedic surgery (same as limited to 2001 to present)

I^2^: 10 percent

Egger's p-value: 0.106

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of impact of injectable low molecular weight heparin prophylaxis versus injectable or oral factor Xa inhibitor prophylaxis on distal deep vein thrombosis in patients undergoing major orthopedic surgery. This also represents the same analysis limited to trials published from 2001 to present. Five trials were included in the analysis. The first trial by Yokote and colleagues in 2011 provided a relative risk of 0.84 with 95 percent confidence interval of 0.28 to 2.51. The second trial by Lassen and colleagues in 2002 provided a relative risk of 2.21 with a 95 percent confidence interval of 1.46 to 3.36. The third trial by Turpie and colleagues in 2002 provided a relative risk of 1.58 with a 95 percent confidence interval of 1.04 to 2.39. The fourth trial by Bauer and colleagues in 2001 provided a relative risk of 2.27 with a 95 percent confidence interval of 1.57 to 3.28. The fifth trial by Eriksson and colleagues in 2001 provided a relative risk of 2.24 with a 95 percent confidence interval of 1.59 to 3.17. The combined effect of the five trials showed a relative risk of 2.02 with a 95 percent confidence interval of 1.65 to 2.48. The I-squared value was 10 percent and the Egger's p-value was 0.106.

Figure 156 Impact of injectable low molecular weight heparin prophylaxis versus injectable or oral factor Xa inhibitor prophylaxis on distal deep vein thrombosis in patients undergoing major orthopedic surgery limited to total hip replacement surgery

I^2^: 28.1 percent

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of impact of injectable low molecular weight heparin prophylaxis versus injectable or oral factor Xa inhibitor prophylaxis on distal deep vein thrombosis in patients undergoing major orthopedic surgery limited to total hip replacement surgery. Three trials were included in the analysis. The first trial by Yokote and colleagues in 2011 provided an odds ration of 0.83 with 95 percent confidence interval of 0.25 to 2.82. The second trial by Lassen and colleagues in 2002 provided an odds ratio of 2.22 with a 95 percent confidence interval of 1.47 to 3.34. The third trial by Turpie and colleagues in 2002 provided an odds ratio of 1.61 with a 95 percent confidence interval of 1.05 to 2.47. The combined effect of the three trials showed an odds ratio of 1.82 with a 95 percent confidence interval of 1.36 to 2.42. The I-squared value was 28.1 percent.

Figure 157 Impact of injectable low molecular weight heparin prophylaxis versus injectable or oral direct thrombin inhibitor prophylaxis on distal deep vein thrombosis in patients undergoing major orthopedic surgery (same as limited to 2001 to present, same as limited to total hip replacement surgery)

I^2^: Too few strata

Egger's p-value: Too few strata

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of impact of injectable low molecular weight heparin prophylaxis versus injectable or oral direct thrombin inhibitor prophylaxis on distal deep vein thrombosis in patients undergoing major orthopedic surgery. This also represents the same analysis limited to trials published from 2001 to present, and total hip replacement surgery. One trial by Ginsberg and colleagues in 2009 including two separate comparisons was included in the analysis. The first comparison provided a relative risk of 0.75 with a 95 percent confidence interval of 0.60 to 0.95. The second comparison provided a relative risk of 0.83 with a 95 percent confidence interval of 0.65 to 1.05. The combined effect of the two comparisons showed a relative risk of 0.79 with a 95 percent confidence interval of 0.67 to 0.93. The I-squared value and Egger's p-value could not be calculated because there was only one study available.

Figure 158 Impact of injectable low molecular weight heparin prophylaxis versus oral vitamin K antagonist prophylaxis on distal deep vein thrombosis in patients undergoing major orthopedic surgery

I^2^: Too few strata

Egger's p-value: Too few strata

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of impact of injectable low molecular weight heparin prophylaxis versus oral vitamin K antagonist prophylaxis on distal deep vein thrombosis in patients undergoing major orthopedic surgery. Two trials were included in the analysis. The first trial by Fitzgerald and colleagues in 2001 provided a relative risk of 0.60 with a 95 percent confidence interval of 0.44 to 0.81. The second trial by Francis and colleagues in 1997 provided a relative risk of 0.48 with a 95 percent confidence interval of 0.30 to 0.78. The combined effect of the two trials showed a relative risk of 0.56 with a 95 percent confidence interval of 0.43 to 0.73. The I-squared value and the Egger's p-value could not be calculated because there were only two studies available.

Figure 159 Impact of injectable low molecular weight heparin prophylaxis versus mechanical prophylaxis on distal deep vein thrombosis in patients undergoing major orthopedic surgery

I^2^: Too few strata

Egger's p-value: Too few strata

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of impact of injectable low molecular weight heparin prophylaxis versus mechanical prophylaxis on distal deep vein thrombosis in patients undergoing major orthopedic surgery. Three trials were included in the analysis. The first trial by Warwick and colleagues in 2002 provided a relative risk of 1.01 with a 95 percent confidence interval of 0.77 to 1.31. The second trial by Warwick and colleagues in 1998 provided a relative risk of 0.84 with a 95 percent confidence interval of 0.30 to 2.34. The third trial by Stone and colleagues in 1996 was excluded because no events occurred in either of the groups compared. The combined effect of the two trials showed a relative risk of 1.00 with a 95 percent confidence interval of 0.77 to 1.29. The I-squared value and the Egger's p-value could not be calculated because there were only three studies available.

Figure 160 Impact of injectable low molecular weight heparin versus injectable unfractionated heparin on major bleeding in patients undergoing major orthopedic surgery limited to total hip replacement surgery

I^2^: 43.5 percent

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of injectable low molecular weight heparin prophylaxis versus injectable unfractionated heparin prophylaxis on major bleeding in patients undergoing major orthopedic surgery limited to total hip replacement surgery. Six trials were included in the analysis with two trials contributing two separate comparisons presented individually here. The first trial by Seneran and colleagues in 2006 provided an odds ratio of 7.54 with a 95 percent confidence interval of 0.47 to 122.28. The second trial by Colwell and colleagues in 1994 provided two comparisons. The first comparison provided an odds ratio of 0.63 with a 95 percent confidence interval of 0.21 to 1.91. The second comparison provided an odds ratio of 0.21 with 95 percent confidence interval of 0.05 to 0.80. The third trial by Menzin and colleagues in 1994 provided two comparisons. The first comparison provided an odds ratio of 0.64 with a 95 percent confidence interval of 0.21 to 1.94. The second comparison provided an odds ratio of 0.21 with 95 percent confidence interval of 0.05 to 0.81. The fourth trial by Eriksson and colleagues in 1991 was excluded because there were no events in the groups compared. The fifth trial by Levine and colleagues in 1991 provided an odds ratio of 0.57 with 95 percent confidence interval of 0.27 to 1.19. The sixth trial by Planes and colleagues in 1988 provided an odds ratio of 6.76 with a 95 confidence interval of 0.42 to 109.15. The combined effect of the five trials showed an odds ratio of 0.54 with a 95 percent confidence interval of 0.34 to 0.85. The I-squared value was 43.5 percent

Figure 161 Impact of injectable low molecular weight heparin versus injectable or oral factor Xa inhibitors on major bleeding in patients undergoing major orthopedic surgery (same as analysis limited to trials published from 2001 to the present)

I^2^: 56.6 percent

Egger's p-value: 0.347

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of injectable low molecular weight heparin prophylaxis versus injectable or oral factor Xa inhibitor prophylaxis on major bleeding in patients undergoing major orthopedic surgery. The figure also depicts the analysis of the impact of injectable low molecular weight heparin versus injectable or oral factor Xa inhibitors on major bleeding in patients undergoing major orthopedic surgery limited to trials published from 2001 to the present. Five trials were included in the analysis. The first trial by Yokote and colleagues in 2011 was excluded from the analysis because no events occurred in either of the treatment arms. The second trial by Lassen and colleagues in 2002 provided an odds ratio of 0.68 with a 95 confidence interval of 0.43 to 1.06. The third trial by Turpie and colleagues in 2002 provided an odds ratio of 0.55 with a 95 confidence interval of 0.27 to 1.13. The fourth trial by Bauer and colleagues in 2001 provided an odds ratio of 0.19 with a 95 confidence interval of 0.06 to 0.58. The fifth trial by Eriksson and colleagues in 2001 provided an odds ratio of 1.04 with a 95 confidence interval of 0.54 to 2.00. The combined effect of the four trials showed an odds ratio of 0.65 with a 95 percent confidence interval of 0.48 to 0.89. The I-squared value was 56.6 percent and the Egger's p-value was 0.347

Figure 162 Impact of injectable low molecular weight heparin versus injectable or oral factor Xa inhibitors on major bleeding in patients undergoing major orthopedic surgery limited to total hip replacement surgery

I^2^: Too few strata

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of injectable low molecular weight heparin prophylaxis versus injectable or oral factor Xa inhibitor prophylaxis on major bleeding in patients undergoing major orthopedic surgery limited to total hip replacement surgery. Three trials were included in the analysis. The first trial by Yokote and colleagues in 2011 was excluded from the analysis because no events occurred in either of the treatment arms. The second trial by Lassen and colleagues in 2002 provided an odds ratio of 0.68 with 95 confidence interval of 0.43 to 1.06. The third trial by Turpie and colleagues in 2002 provided an odds ratio of 0.55 with 95 confidence interval of 0.27 to 1.13. The combined effect of the three trials showed an odds ratio of 0.64 with a 95 percent confidence interval of 0.44 to 0.94. The I-squared value could not be calculated because of too few strata.

Figure 163 Impact of injectable low molecular weight heparin versus injectable or oral direct thrombin inhibitors on major bleeding in patients undergoing major orthopedic surgery

I^2^: 0 percent

Egger's p-value: 0.175

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of injectable low molecular weight heparin prophylaxis versus injectable or oral direct thrombin inhibitor prophylaxis on major bleeding in patients undergoing major orthopedic surgery. Four trials were included in the analysis with three trials providing two separate comparisons presented individually here. The first trial by Ginsberg and colleagues in 2009 provided two comparisons. The first comparison provided a relative risk of 2.41 with a 95 percent confidence interval of 0.78 to 7.39. The second comparison provided a relative risk of 2.37 with a 95 percent confidence interval of 0.77 to 7.27. The second trial by Eriksson and colleagues in 2007 provided two comparisons. The first comparison provided a relative risk of 1.21 with a 95 percent confidence interval of 0.54 to 2.68. The second comparison provided a relative risk of 0.78 with a 95 percent confidence interval of 0.37 to 1.64. The third trial by Eriksson and colleagues in 2007 provided two comparisons. The first comparison provided a relative risk of 1.01 with a 95 percent confidence interval of 0.35 to 2.95. The second comparison provided a relative risk of 0.88 and a 95 percent confidence interval of 0.31 to 2.52. The fourth trial by Eriksson and colleagues in 1997 provided a relative risk of 1.00 with a 95 percent confidence interval of 0.55 to 1.84. The combined effect of the four trials showed a relative risk of 1.12 with a 95 percent confidence interval of 0.80 to 1.57. The I-squared value was 0 percent and the Egger's p-value was 0.175

Figure 164 Impact of injectable low molecular weight heparin versus injectable or oral direct thrombin inhibitors on major bleeding in patients undergoing major orthopedic surgery limited to trials published from 2001 to the present

I^2^: 0 percent

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of injectable low molecular weight heparin prophylaxis versus injectable or oral direct thrombin inhibitor prophylaxis on major bleeding in patients undergoing major orthopedic surgery limited to trials published from 2001 to the present. Three trials were included in the analysis all providing two separate comparisons presented individually here. The first trial by Ginsberg and colleagues in 2009 provided two comparisons. The first comparison provided a relative risk of 2.41 with a 95 percent confidence interval of 0.78 to 7.39. The second comparison provided a relative risk of 2.37 with a 95 percent confidence interval of 0.77 to 7.27. The second trial by Eriksson and colleagues in 2007 provided two comparisons. The first comparison provided a relative risk of 1.21 with a 95 percent confidence interval of 0.54 to 2.68. The second comparison provided a relative risk of 0.78 with a 95 percent confidence interval of 0.37 to 1.64. The third trial by Eriksson and colleagues in 2007 provided two comparisons. The first comparison provided a relative risk of 1.01 with a 95 percent confidence interval of 0.35 to 2.95. The second comparison provided a relative risk of 0.88 and a 95 percent confidence interval of 0.31 to 2.52. The combined effect of the three trials showed a relative risk of 1.17 with a 95 percent confidence interval of 0.79 to 1.75. The I-squared value was 0 percent

Figure 165 Impact of injectable low molecular weight heparin versus injectable or oral direct thrombin inhibitors on major bleeding in patients undergoing major orthopedic surgery limited to total hip replacement surgery

I^2^: 0 percent

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of injectable low molecular weight heparin prophylaxis versus injectable or oral direct thrombin inhibitor prophylaxis on major bleeding in patients undergoing major orthopedic surgery limited to total hip replacement surgery. Two trials were included in the analysis, with one trial providing two separate comparisons presented individually here. The first trial by Eriksson and colleagues in 2007 provided two comparisons. The first comparison provided an odds ratio of 1.22 with a 95 percent confidence interval of 0.52 to 2.87. The second comparison provided an odds ratio of 0.78 with a 95 percent confidence interval of 0.37 to 1.64. The second trial by Eriksson and colleagues in 1997 provided an odds ratio of 1.00 with a 95 percent confidence interval of 0.54 to 1.88. The combined effect of the two trials showed an odds ratio of 0.97 with a 95 percent confidence interval of 0.64 to 1.48. The I-squared value was 0 percent

Figure 166 Impact of injectable low molecular weight heparin versus injectable or oral direct thrombin inhibitors on major bleeding in patients undergoing major orthopedic surgery limited to total knee replacement surgery

I^2^: 0 percent

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the iimpact of injectable low molecular weight heparin prophylaxis versus injectable or oral direct thrombin inhibitor prophylaxis on major bleeding in patients undergoing major orthopedic surgery limited to total knee replacement surgery. Two trials were included in the analysis, with each trial providing two separate comparisons presented individually here. The first trial by Ginsberg and colleagues in 2009 provided two comparisons. The first comparison provided a relative risk of 2.41 with a 95 percent confidence interval of 0.78 to 7.39. The second comparison provided a relative risk of 2.37 with a 95 percent confidence interval of 0.77 to 7.27. The second trial by Eriksson and colleagues in 2007 provided two comparisons. The first comparison provided a relative risk of 1.01 with a 95 percent confidence interval of 0.35 to 2.95. The second comparison provided a relative risk of 0.88 with a 95 percent confidence interval of 0.31 to 2.52. The combined effect of the two trials showed a relative risk of 1.46 with a 95 percent confidence interval of 0.82 to 2.59. The I-squared value was 0 percent.

Figure 167 Impact of injectable low molecular weight heparin versus injectable or oral direct thrombin inhibitors on major bleeding during the postdischarge period in patients who had total knee replacement surgery

I^2^: Too few strata

Egger's p-value: Too few strata

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of injectable low molecular weight heparin versus injectable or oral direct thrombin inhibitors on major bleeding during the post-discharge period in patients who had total knee replacement surgery. One trial by Ginsberg and colleagues in 2009 was included in the analysis, with this trial contributing two separate comparisons presented individually here. The first comparison provided a relative risk of 0.40 with a 95 percent confidence interval of 0.04 to 4.45. The second comparison provided a relative risk of 0.66 with a 95 percent confidence interval of 0.05 to 7.98. The combined effect of the two analyses showed a relative risk of 0.51 with a 95 percent confidence interval of 0.06 to 4.58. The I-squared value and the Egger's p-value could not be calculated because only one study was available.

Figure 168 Impact of injectable low molecular weight heparin versus oral vitamin K antagonists on major bleeding during days 0 to 1 in patients who had total hip replacement surgery

I^2^: Too few strata

Egger's p-value: Too few strata

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of injectable low molecular weight heparin versus oral vitamin K antagonists on major bleeding during days 0 to 1 in patients who had total hip replacement surgery. One trial by Hull and colleagues in 2000 was included in the analysis, with this trial contributing two separate comparisons presented individually here. The first comparison provided a relative risk of 1.63 with a 95 percent confidence interval of 0.83 to 3.22. The second comparison provided a relative risk of 1.41 with a 95 percent confidence interval of 0.71 to 2.82. The combined effect of the two analyses showed a relative risk of 1.51 with a 95 percent confidence interval of 0.92 to 2.48. The I-squared value and the Egger's p-value could not be calculated because only one study was available.

Figure 169 Impact of injectable low molecular weight heparin versus oral vitamin K antagonists on major bleeding during days 2 to 8 in patients who had total hip replacement surgery

I^2^: Too few strata

Egger's p-value: Too few strata

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of injectable low molecular weight heparin versus oral vitamin K antagonists on major bleeding during days 2 to 8 in patients who had total hip replacement surgery. One trial by Hull and colleagues in 2000 was included in the analysis, with this trial contributing two separate comparisons presented individually here. The first comparison provided a relative risk of 5.42 with a 95 percent confidence interval of 0.91 to 32.61. The second comparison provided a relative risk of 2.01 with a 95 percent confidence interval of 0.30 to 13.33. The combined effect of the two analyses showed a relative risk of 3.41 with a 95 percent confidence interval of 0.77 to 15.18. The I-squared value and the Egger's p-value could not be calculated because only one study was available.

Figure 170 Impact of injectable low molecular weight heparin versus oral vitamin k antagonists on major bleeding in patients undergoing major orthopedic surgery limited to total hip replacement surgery

I^2^: 0 percent

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of injectable low molecular weight heparin prophylaxis versus oral vitamin k antagonist prophylaxis on major bleeding in patients undergoing major orthopedic surgery limited to total hip replacement surgery. Three trials were included in the analysis. The first trial by Colwell and colleagues in 1999 provided an odds ratio of 2.14 with a 95 percent confidence interval of 0.99 to 4.64. The second trial by Francis and colleagues in 1997 provided an odds ratio of 1.55 with a 95 percent confidence interval of 0.44 to 5.40. The third trial by Hull and colleagues in 1993 provided an odds ratio of 1.82 with a 95 percent confidence interval of 0.70 to 4.75. The combined effect of the three trials showed an odds ratio of 1.91 with a 95 percent confidence interval of 1.11 to 3.29. The I-squared value was 0 percent.

Figure 171 Impact of injectable low molecular weight heparin versus oral vitamin K antagonists on major bleeding in patients undergoing major orthopedic surgery limited to total knee replacement surgery

I^2^: 0 percent

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of injectable low molecular weight heparin prophylaxis versus oral vitamin k antagonist prophylaxis on major bleeding in patients undergoing major orthopedic surgery limited to total knee replacement. Four trials were included in the analysis. The first trial by Lassen and colleagues in 2007 was excluded because there were no events in the groups compared. The second trial by Fitzgerald and colleagues in 2001 provided an odds ratio of 2.26 with a 95 percent confidence interval of 0.75 to 6.83. The third trial by Leclerc and colleagues in 1996 provided an odds ratio of 1.16 with a 95 percent confidence interval of 0.39 to 3.48. The fourth trial by Hull and colleagues in 1993 provided an odds ratio of 2.83 with a 95 percent confidence interval of 0.90 to 8.86. The combined effect of the three trials showed an odds ratio of 1.93 with a 95 percent confidence interval of 1.01 to 3.67. The I-squared value was 0 percent

Figure 172 Impact of injectable low molecular weight heparin versus injectable or oral factor Xa antagonists on major bleeding leading to reoperation (same as analysis limited to trials published from 2001-present)

I^2^: 0 percent

Egger's p-value: 0.855

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of injectable low molecular weight heparin prophylaxis versus injectable or oral factor Xa antagonist prophylaxis on major bleeding leading to reoperation. This figure also depicts the analysis of the impact of injectable low molecular weight heparin versus injectable or oral factor Xa antagonists on major bleeding leading to reoperation limited to trials published from 2001-present. Four trials were included in the analysis with comparisons presented individually here. The first trial by Lassen and colleagues in 2002 provided an odds ratio of 0.61 with a 95 percent confidence interval of 0.15 to 2.44. The second trial by Turpie and colleagues in 2002 provided an odds ratio of 1.00 with a 95 percent confidence interval of 0.14 to 7.10. The third trial by Bauer and colleagues in 201 provided an odds ratio of 0.51with a 95 percent confidence interval of 0.05 to 4.94. The fourth trial by Eriksson and colleagues in 2001 provided an odds ratio of 0.66 with a 95 percent confidence interval of 0.11 to 3.82. The combined effect of the four trials showed an odds ratio of 0.67 with a 95 percent confidence interval of 0.28 to 1.61. The I-squared value was 0 percent and the Egger's p-value was 0.855.

Figure 173 Impact of injectable low molecular weight heparin versus injectable or oral factor Xa antagonists on major bleeding leading to reoperation in patients undergoing major orthopedic surgery limited to total hip replacement

I^2^: 0 percent

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of injectable low molecular weight heparin prophylaxis versus injectable or oral factor Xa antagonist prophylaxis on major bleeding leading to reoperation in patients undergoing major orthopedic surgery limited to total hip replacement. Two trials were included in the analysis, with comparisons presented individually here. The first trial by Lassen and colleagues in 2002 provided an odds ratio of 0.61 with a 95 percent confidence interval of 0.15 to 2.44. The second trial by Turpie and colleagues in 2002 provided an odds ratio of 1.00 with a 95 percent confidence interval of 0.14 to 7.10. The combined effect of the two trials showed an odds ratio of 0.72 with a 95 percent confidence interval of 0.23 to 2.23. The I-squared value was 0 percent

Figure 174 Impact of injectable low molecular weight heparin agents versus injectable or oral direct thrombin inhibitors on major bleeding leading to reoperation in patients who had major orthopedic surgery (same as analysis limited to trials published from 2001-present)

I^2^: 0 percent

Egger's p-value: 0.614

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of injectable low molecular weight heparin prophylaxis versus injectable or oral direct thrombin inhibitor prophylaxis on major bleeding leading to reoperation in patients who had major orthopedic surgery. This figure also depicts the meta-analysis of the impact of injectable low molecular weight heparin prophylaxis versus injectable or oral direct thrombin inhibitor prophylaxis on major bleeding leading to reoperation in patients who had major orthopedic surgery limited to trials published from 2001-present. Three trials were included in the analysis with all three trials contributing two separate comparisons presented individually here. The first trial by Ginsberg and colleagues in 2009 included two comparisons. The first comparison provided a relative risk of 4.01 with a 95 percent confidence interval of 0.30 to 53.90. The second comparison provided a relative risk of 3.95 with a 95 percent confidence interval of 0.29 to 53.04. The second trial by Eriksson and colleagues in 2007 included two separate comparisons. The first comparison provided a relative risk of 1.01 with a 95 percent confidence interval of 0.18 to 5.69. The second comparison provided a relative risk of 1.49 with a 95 percent confidence interval of 0. 24 to 9.40. The third trial by Eriksson and colleagues in 2007 included two separate comparisons. The first comparison provided a relative risk of 1.01 with a 95 percent confidence interval of 0.08 to 13.59. The second comparison provided a relative risk of 0.33 with a 95 percent confidence interval of 0.03 to 3.53. The combined effect of the three trials provided a relative risk of 1.27 with a 95 percent confidence interval of 0.43 to 3.75. The I-squared value was 0 percent and the Egger's p-value was 0.614.

Figure 175 Impact of injectable low molecular weight heparin agents versus injectable or oral direct thrombin inhibitors on major bleeding leading to reoperation in patients who had major orthopedic surgery limited to total hip replacement surgery

I^2^: 0 percent

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of injectable low molecular weight heparin prophylaxis versus injectable or oral direct thrombin inhibitor prophylaxis on major bleeding leading to reoperation in patients who had major orthopedic surgery limited to total hip replacement surgery. One trial by Eriksson and colleagues in 2007 was included in the analysis with this trial contributing two separate comparisons presented individually here. The first comparison provided a relative risk of 1.01 with a 95 percent confidence interval of 0.18 to 5.69. The second comparison provided a relative risk of 1.49 with a 95 percent confidence interval of 0.24 to 9.40. The combined effect of the two analyses showed a relative risk of 1.21 with a 95 percent confidence interval of 0.29 to 5.08. The I-squared value was 0 percent.

Figure 176 Impact of injectable low molecular weight heparin agents versus injectable or oral direct thrombin inhibitors on major bleeding leading to reoperation in patients who had major orthopedic surgery limited to total knee replacement surgery

I^2^: 0 percent

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of injectable low molecular weight heparin prophylaxis versus injectable or oral direct thrombin inhibitor prophylaxis on major bleeding leading to reoperation in patients who had major orthopedic surgery limited to total knee replacement surgery. Two trials were included in the analysis with two trials contributing two separate comparisons presented individually here. The first trial by Ginsberg and colleagues in 2009 included two separate comparisons. The first comparison provided a relative risk of 4.01 with a 95 percent confidence interval of 0.30 to 53.90. The second comparisons provided a relative risk of 3.95 with a 95 percent confidence interval of 0.29 to 53.04. The second trial by Eriksson and colleagues in 2007 included two separate comparisons. The first comparison provided a relative risk of 1.01 with a 95 percent confidence interval of 0.08 to 13.59. The second comparison provided a relative risk of 0.33 with a 95 percent confidence interval of 0.03 to 3.53. The combined effect of the two trials showed a relative risk of 1.36 with a 95 percent confidence interval of 0.27 to 7.03. The I-squared value was 0 percent.

Figure 177 Impact of injectable low molecular weight heparin versus injectable unfractionated heparin on minor bleeding in patients undergoing major orthopedic surgery

I^2^: 9.9 percent

Egger's p-value: 0.608

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of injectable low molecular weight heparin prophylaxis versus injectable unfractionated heparin prophylaxis on minor bleeding in patients undergoing major orthopedic surgery. Five trials were included in the analysis with one trial contributing two separate comparisons presented individually here. The first trial by Seneran and colleagues in 2006 provided an odds ratio of 0.25 with 95 percent confidence interval of 0.04 to 1.59. The second trial by Colwell and colleagues in 1995 provided an odds ratio of 0.87 with 95 percent confidence interval of 0.60 to 1.25. The third trial by Colwell and colleagues in 1994 provided two comparisons. The first comparison provided an odds ratio of 1.43 with 95 percent confidence interval of 0.60 to 3.47. The second comparison provided an odds ratio of 1.54 with 95 percent confidence interval of 0.66 to 3.70. The fourth trial by Levine and colleagues in 1991 provided an odds ratio of 0.50 with 95 percent confidence interval of 0.20 to 1.27. The fifth trial by Planes and colleagues in 1988 provided an odds ratio of 0.45 with 95 percent confidence interval of 0.06 to 3.41. The combined effect of the five trials provided an odds ratio of 0.90 with 95 percent confidence interval of 0.63 to 1.28. The I-squared value was 9.9 percent and the Egger's p-value was 0.608.

Figure 178 Impact of injectable low molecular weight heparin versus injectable unfrationated heparin on minor bleeding in patients undergoing major orthopedic surgery limited to total hip replacement surgery

I^2^: 0 percent

Egger's p-value: 0.132

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of injectable low molecular weight heparin prophylaxis versus injectable unfrationated heparin prophylaxis on minor bleeding in patients undergoing major orthopedic surgery limited to total hip replacement surgery. The analysis included four trials with one trial contributing two separate comparisons presented individually here. The first trial by Seneran and colleagues in 2006 provided an odds ratio of 0.29 with 95 percent confidence interval of 0.05 to 0.71. The second trial by Colwell and colleagues provided two comparisons. The first comparison provided an odds ratio of 1.43 with 95 percent confidence interval of 0.58 to 3.56. The second comparison provided an odds ratio of 1.54 with 95 percent confidence interval of 0.64 to 3.71. The third trial by Levine and colleagues in 1991 provided an odds ratio of 0.50 with 95 percent confidence interval of 0.20 to 1.28. The fourth trial by Planes and colleagues in 1988 provided an odds ratio of 0.46 with 95 percent confidence interval of 0.05 to 4.48. The combined effect of the four trials provided an odds ratio of 0.92 with 95 percent confidence interval of 0.57 to 1.51. The I-squared value was zero percent and the Egger's p-value was 0.132

Figure 179 Impact of injectable low molecular weight heparin versus injectable or factor Xa inhibitors on minor bleeding in patients undergoing major orthopedic surgery (same as analysis limited to trials published from 2001-present)

I^2^: Too few strata

Egger's p-value: Too few strata

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of injectable low molecular weight heparin prophylaxis versus injectable or oral factor Xa inhibitor prophylaxis on minor bleeding in patients undergoing major orthopedic surgery. This is the same analysis when limiting to trials published from 2001 to present. Two trials were included in the analysis. The first trial by Yokote and colleagues in 2011 provided an odds ration of 0.85 with 95 percent confidence interval of 0.27 to 2.62. The second trial by Eriksson and colleagues in 2001 provided an odds ratio of 0.52 with 95 confidence interval of 0.30 to 0.91. The combined effect of the two trials showed an odds ratio of 0.57 with a 95 percent confidence interval of 0.35 to 0.94. The I-squared value could not be calculated because of too few strata.

Figure 180 Impact of injectable low molecular weight heparin versus injectable or oral direct thrombin inhibitors on minor bleeding in patients undergoing major orthopedic surgery (same as analysis limited to trials published from 2001-present)

I^2^: 0 percent

Egger's p-value: 0.132

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of injectable low molecular weight heparin prophylaxis versus injectable or oral direct thrombin inhibitor prophylaxis on minor bleeding in patients undergoing major orthopedic surgery. This figure also depicts the analysis of the impact of injectable low molecular weight heparin versus injectable or oral direct thrombin inhibitors on minor bleeding in patients undergoing major orthopedic surgery limited to trials published from 2001 to present. Three trials were included in the analysis with all three trials contributing two separate comparisons presented individually here. The first trial by Ginsberg and colleagues in 2009 included two comparisons. The first comparison provided a relative risk of 0.96 with a 95 percent confidence interval of 0.47 to 1.95. The second comparison provided a relative risk of 0.90 with a 95 percent confidence interval of 0.44 to 1.82. The second trial by Eriksson and colleagues in 2007 included two separate comparisons. The first comparison provided a relative risk of 1.04 with a 95 percent confidence interval of 0.71 to 1.51. The second comparison provided a relative risk of 1.05 with a 95 percent confidence interval of 0.71 to 1.54. The third trial by Eriksson and colleagues in 2007 included two separate comparisons. The first comparison provided a relative risk of 1.18 with a 95 percent confidence interval of 0.79 to 1.76. The second comparison provided a relative risk of 1.33 with a 95 percent confidence interval of 0.76 to 1.67. The combined effect of the three trials provided a relative risk of 1.07 with a 95 percent confidence interval of 0.89 to 1.29. The I-squared value was0 percent and the Egger's p-value was 0.132.

Figure 181 Impact of injectable low molecular weight heparin versus injectable or oral direct thrombin inhibitors on minor bleeding in patients undergoing major orthopedic surgery limited to total hip replacement

I^2^: Too few strata

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of injectable low molecular weight heparin prophylaxis versus injectable or oral direct thrombin inhibitor prophylaxis on minor bleeding in patients undergoing major orthopedic surgery limited to total hip replacement. One trial by Eriksson and colleagues in 2007 was included in the analysis, contributing two separate comparisons presented individually here. The first comparison provided a relative risk of1.04 with 95 percent confidence interval of 0.71 to 1.51. The second comparison provided a relative risk of1.05 with 95 percent confidence interval of 0.71 to 1.54. The combined effect of the two comparisons showed a relative risk of 1.04 with a 95 percent confidence interval of 0.79 to 1.37. The I-squared value could not be calculated because only one study was available.

Figure 182 Impact of injectable low molecular weight heparin versus injectable or oral direct thrombin inhibitors on minor bleeding in patients undergoing major orthopedic surgery limited to total knee replacement

I^2^: 0 percent

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of injectable low molecular weight heparin prophylaxis versus injectable or oral direct thrombin inhibitor prophylaxis on minor bleeding in patients undergoing major orthopedic surgery limited to total knee replacement. Two trials were included in the analysis, each contributing two separate comparisons presented individually here. The first trial by Ginsberg and colleagues in 2009 provided two comparisons. The first comparison provided a relative risk of 0.96 with 95 percent confidence interval of 0.47 to 1.95. The second comparison provided a relative risk of 0.90 with 95 percent confidence interval of 0.44 to 1.82. The second trial by Eriksson and colleagues in 2007 provided two comparisons. The first comparison provided a relative risk of 1.18 with 95 percent confidence interval of 0.79 to 1.76. The second comparison provided a relative risk of 1.13 with 95 percent confidence interval of 0.76 to 1.67. The combined effect of the two trials showed a relative risk of 1.10 with a 95 percent confidence interval of 0.86 to 1.40. The I-squared value was 0 percent.

Figure 183 Impact of injectable low molecular weight heparin versus injectable or oral direct thrombin inhibitors on minor bleeding during the postdischarge period in patients who had total knee replacement surgery

I^2^: Too few strata

Egger's p-value: Too few strata

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of injectable low molecular weight heparin versus injectable or oral direct thrombin inhibitors on minor bleeding during the post-discharge period in patients who had total knee replacement surgery. One trial by Ginsberg and colleagues in 2009 was included in the analysis, with this trial contributing two separate comparisons presented individually here. The first comparison provided a relative risk of 0.60 with a 95 percent confidence interval of 0.12 to 3.08. The second comparison provided a relative risk of 0.49 with a 95 percent confidence interval of 0.10 to 2.46. The combined effect of the two analyses showed a relative risk of 0.54 with a 95 percent confidence interval of 0.15 to 1.95. The I-squared value and the Egger's p-value could not be calculated because only one study was available.

Figure 184 Impact of injectable low molecular weight heparin versus oral vitamin K antagonists on minor bleeding in patients undergoing major orthopedic surgery

I^2^: 0 percent

Egger's p-value: 0.311

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of injectable low molecular weight heparin prophylaxis versus oral vitamin K antagonist prophylaxis on minor bleeding in patients undergoing major orthopedic surgery. Six trials were included in the analysis, with one trial contributing two separate comparisons presented individually here. The first trial by Lassen and colleagues in 2007 provided a relative risk of 0.76 with a 95 percent confidence interval of 0.28 to 2.05. The second trial by Fitzgerald and colleagues in 2001 provided a relative risk of 1.35 with a 95 percent confidence interval of 0.93 to 1.95. The third trial by Colwell and colleagues in 1999 provided a relative risk of 1.33 with 95 percent confidence interval of 1.05 to 1.00. The fourth trial by Francis and colleagues in 1997 provided a relative risk of 1.65 with a 95 percent confidence interval of 0.78 to 3.51. The fifth trial by Leclerc and colleagues in 1996 provided a relative risk of 1.13 with 95 percent confidence interval of 0.87 to 1.45. The sixth trial by Hull and colleagues 1993 contributed two comparisons. The first comparison provided a relative risk of 0.55 with 95 percent confidence interval of 0.20 to 1.56. The second comparison provided a relative risk of 1.02 with 95 percent confidence interval of 0.32 to 3.27. The combined effect of the six trials showed a relative risk of 1.23 with a 95 percent confidence interval of 1.06 to 1.43. The I-squared value was 0 percent and the Egger's p – value was 0.311.

Figure 185 Impact of injectable low molecular weight heparin versus oral vitamin K antagonists on minor bleeding during days 0 to 1 in patients who had total hip replacement surgery

I^2^: Too few strata

Egger's p-value: Too few strata

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of injectable low molecular weight heparin versus oral vitamin K antagonists on minor bleeding during days 0 to 1 in patients who had total hip replacement surgery. One trial by Hull and colleagues in 2000 was included in the analysis, with this trial contributing two separate comparisons presented individually here. The first comparison provided a relative risk of 1.48 with a 95 percent confidence interval of 0.21 to 10.30. The second comparison provided a relative risk of 1.51 with a 95 percent confidence interval of 0.22 to 10.49. The combined effect of the two analyses showed a relative risk of 1.49 with a 95 percent confidence interval of 0.30 to 7.37. The I-squared value and the Egger's p-value could not be calculated because only one study was available.

Figure 186 Impact of injectable low molecular weight heparin versus oral vitamin K antagonists on minor bleeding during days 2 to 8 in patients who had total hip replacement surgery

I^2^: Too few strata

Egger's p-value: Too few strata

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of injectable low molecular weight heparin versus oral vitamin K antagonists on minor bleeding during days 2 to 8 in patients who had total hip replacement surgery. One trial by Hull and colleagues in 2000 was included in the analysis, with this trial contributing two separate comparisons presented individually here. The first comparison provided a relative risk of 0.74 with a 95 percent confidence interval of 0.23 to 2.42. The second comparison provided a relative risk of 1.00 with a 95 percent confidence interval of 0.33 to 3.11. The combined effect of the two analyses showed a relative risk of 0.87 with a 95 percent confidence interval of 0.37 to 2.06. The I-squared value and the Egger's p-value could not be calculated because only one trial was available.

Figure 187 Impact of injectable low molecular weight heparin versus oral vitamin K antagonists on minor bleeding in patients undergoing major orthopedic surgery limited to trials published from 2001-present

I^2^: Too few strata

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of injectable low molecular weight heparin prophylaxis versus oral vitamin K-antagonists prophylaxis on minor bleeding in patients undergoing major orthopedic surgery limited to trials published from 2001-present. Two trials were included in the analysis. The first trial by Lassen and colleagues in 2007 provided a relative risk of 0.76 with a 95 percent confidence interval of 0.28 to 2.05. The second trial by Fitzgerald and colleagues in 2001 provided a relative risk of 1.35 with a 95 percent confidence interval of 0.93 to 1.95. The combined effect of the two trials showed a relative risk of 1.25 with a 95 percent confidence interval of 0.85 to 1.83. The I-squared value could not be calculated because only two trials were available.

Figure 188 Impact of injectable low molecular weight heparin versus oral vitamin K antagonists on minor bleeding in patients undergoing major orthopedic surgery limited to total hip replacement surgery

I^2^: 27.8 percent

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the Impact of injectable low molecular weight heparin prophylaxis versus oral vitamin K antagonist prophylaxis on minor bleeding in patients undergoing major orthopedic surgery limited to total hip replacement surgery. Three trials were included in the analysis contributing three separate comparisons presented individually here. The first trial by Colwell and colleagues in 1999 provided a relative risk of 1.33 with a 95 percent confidence interval of 1.05 to 1.69. The second trial by Francis and colleagues in 1997 provided a relative risk of 1.65 with a 95 percent confidence interval of 0.78 to 3.51. The third trial by Hull and colleagues in 1993 provided a relative risk of 0.55 with a 95 percent confidence interval of 0.20 to 1.56. The combined effect of the three trials showed a relative risk of 1.26 with a 95 percent confidence interval of 0.85 to 1.86. The I-squared value was 27.8 percent.

Figure 189 Impact of injectable low molecular weight heparin versus oral vitamin K antagonists on minor bleeding in patients undergoing major orthopedic surgery limited to total knee replacement

I^2^: 0 percent

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of injectable low molecular weight heparin prophylaxis versus oral vitamin K antagonist prophylaxis on minor bleeding in patients undergoing major orthopedic surgery limited to total knee replacement. Four trials were included in the analysis contributing four separate comparisons presented individually here. The first trial by Lassen and colleagues in 2007 provided a relative risk of 0.76 with a 95 percent confidence interval of 0.28 to 2.05. The second trial by Fitzgerald and colleagues in 2001 provided a relative risk of 1.35 with a 95 percent confidence interval of 0.93 to 1.95. The third trial by Leclerc and colleagues in 1996 provided a relative risk of 1.13 with a 95 percent confidence interval of 0.87 to 1.45. The fourth trial by Hull and colleagues in 1993 provided a relative risk of 1.02 with a 95 percent confidence interval of 0.32 to 3.27. The combined effect of the four trials showed a relative risk of 1.17 with a 95 percent confidence interval of 0.95 to 1.43. The I-squared value was 0 percent.

Figure 190 Impact of oral vitamin K antagonists versus mechanical prophylaxis on minor bleeding in patients undergoing major orthopedic surgery (same as analysis limited to total hip replacement)

I^2^: Too few strata

Egger's p-value: Too few strata

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of oral vitamin K antagonist prophylaxis versus mechanical prophylaxis on minor bleeding in patients undergoing major orthopedic surgery. This figure also depicts the meta-analysis of the impact of oral vitamin K antagonists versus mechanical prophylaxis on minor bleeding in patients who had major orthopedic surgery limited to total hip replacement. Two trials were included in the analysis contributing two separate comparisons presented individually here. The first trial by Francis and colleagues in 1992 provided an odds ratio of 0.71 with a 95 percent confidence interval of 0.16 to 6.19. The second trial by Paiement and colleagues in 1987 provided an odds ratio of 0.91 with a 95 percent confidence interval of 0.18 to 4.67. The combined effect of the two trials showed a relative risk of 0.80 with a 95 percent confidence interval of 0.26 to 2.41. The I-squared value and the Egger's p-value could not be calculated because only two trials were available.

Figure 191 Impact of injectable low molecular weight heparin prophylaxis versus injectable unfractionated heparin prophylaxis on surgical site bleeding in patients undergoing major orthopedic surgery

I^2^: 41.4 percent

Egger's p-value: 0.021

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of injectable low molecular weight heparin prophylaxis versus injectable unfractionated heparin prophylaxis on surgical site bleeding in patients who had major orthopedic surgery. Three trials were included in this analysis with one trial contributing two separate comparisons presented individually here. The first trial by Senaran and colleagues in 2006 provided an odds ratio of 0.74 with a 95 percent confidence interval of 0.16 to 3.40. The second trial by Colwell and colleagues in 1995 provided an odds ratio of 1.78 with a 95 percent confidence interval of 0.61 to 5.14. The third trial by Colwell and colleagues in 1994 included two comparisons. The first comparison provided an odds ratio of 0.92 with a 95 percent confidence interval of 0.24 to 3.54. The second comparison provided an odds ratio of 0.14 with a 95 percent confidence interval of 0.02 to 0.99. The combined effect of three trials showed an odds ratio of 0.92 with a 95 percent confidence interval of 0.46 to 1.82. The I-squared value was 41.4 percent and the Egger's p-value was 0.021.

Figure 192 Impact of injectable low molecular weight heparin prophylaxis versus injectable unfractionated heparin prophylaxis on surgical site bleeding in patients undergoing major orthopedic surgery limited to total hip replacement surgery

I^2^: 3.1 percent

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of injectable low molecular weight heparin prophylaxis versus injectable unfractionated heparin prophylaxis on surgical site bleeding in patients who had major orthopedic surgery limited to total hip replacement surgery. Two trials were included in this analysis with one trial contributing two separate comparisons presented individually here. The first trial by Senaran and colleagues in 2006 provided a relative risk of 0.75 with a 95 percent confidence interval of 0.20 to 2.86. The second trial by Colwell and colleagues in 1994 included two comparisons. The first comparison provided a relative risk of 0.92 with a 95 percent confidence interval of 0.27 to 3.13. The second comparison provided a relative risk of 0.15 with a 95 percent confidence interval of 0.02 to 0.99. The combined effect of the two trials showed a relative risk of 0.63 with a 95 percent confidence interval of 0.26 to 1.55. The I-squared value was 3.1 percent.

Figure 193 Impact of injectable low molecular weight heparin prophylaxis versus injectable or oral direct thrombin inhibitor prophylaxis on surgical site bleeding in patients undergoing major orthopedic surgery (same as 2001-present, same as limited to total knee replacement

I^2^: Too few strata

Egger's p-value: Too few strata

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of injectable low molecular weight heparin prophylaxis versus injectable or oral direct thrombin inhibitor prophylaxis on surgical site bleeding in patients who had major orthopedic surgery. This also represents the same analysis limited to trials published from 2001-present and total knee replacement surgery. One trial by Ginsberg and colleagues in 2009 contributing two separate comparisons is included in this analysis. The first comparison provided a relative risk of 3.68 with a 95 percent confidence interval of 1.00 to 13.59. The second comparison provided a relative risk of 5.43 with a 95 percent confidence interval of 1.24 to 23.78. The combined effect of the two comparisons showed a relative risk of 4.35 with a 95 percent confidence interval of 1.51 to 12.54. The I-squared value and Egger's p-value could not be calculated because only one study was available.

Figure 194 Impact of injectable low molecular weight heparin prophylaxis versus oral vitamin K antagonist prophylaxis on surgical site bleeding in patients undergoing major orthopedic surgery

I^2^: Too few strata

Egger's p-value: Too few strata

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of injectable low molecular weight heparin prophylaxis versus oral vitamin K antagonist prophylaxis on surgical site bleeding in patients who had major orthopedic surgery. Two trials were included in this analysis. The first trial by Fitzgerald and colleagues in 2001 provided an odds ratio of 2.05 with a 95 percent confidence interval of 0.80 to 5.29. The second trial by Francis and colleagues in 1997 provided an odds ratio of 3.53 with a 95 percent confidence interval of 1.27 to 9.84. The combined effect of the two trials showed an odds ratio of 2.63 with a 95 percent confidence interval of 1.31 to 5.28. The I-squared value and Egger's p-value could not be calculated because only two studies were available.

Figure 195 Impact of injectable low molecular weight heparin prophylaxis versus oral vitamin K antagonist prophylaxis on major surgical site bleeding in patients undergoing major orthopedic surgery

I^2^: Too few strata

Egger's p-value: Too few strata

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of injectable low molecular weight heparin prophylaxis versus oral vitamin K antagonist prophylaxis on major surgical site bleeding in patients who had major orthopedic surgery. Two trials were included in this analysis. The first trial by Colwell and colleagues in 1999 provided an odds ratio of 2.56 with a 95 percent confidence interval of 1.04 to 6.30. The second trial by Hull and colleagues in 1993 provided an odds ratio of 2.47 with a 95 percent confidence interval of 1.12 to 5.44. The combined effect of the two trials showed an odds ratio of 2.51 with a 95 percent confidence interval of 1.38 to 4.54. The I-squared value and Egger's p-value could not be calculated because only two studies were available.

Figure 196 Impact of injectable low molecular weight heparin versus oral vitamin K antagonists on major surgical site bleeding during days 0 to 1 in patients who had total hip replacement surgery

I^2^: Too few strata

Egger's p-value: Too few strata

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of injectable low molecular weight heparin versus oral vitamin K antagonists on major surgical site bleeding during days 0 to 1 in patients who had total hip replacement surgery. One trial by Hull and colleagues in 2000 was included in the analysis, with this trial contributing two separate comparisons presented individually here. The first comparison provided a relative risk of 1.86 with a 95 percent confidence interval of 0.90 to 3.85. The second comparison provided a relative risk of 1.59 with a 95 percent confidence interval of 0.77 to 3.35. The combined effect of the two analyses showed a relative risk of 1.72 with a 95 percent confidence interval of 1.02 to 2.92. The I-squared value and the Egger's p-value could not be calculated because only one study was available

Figure 197 Impact of injectable low molecular weight heparin versus oral vitamin K antagonists on major surgical site bleeding during days 2 to 8 in patients who had total hip replacement surgery

I^2^: Too few strata

Egger's p-value: Too few strata

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of injectable low molecular weight heparin versus oral vitamin K antagonists on major surgical site bleeding during days 2 to 8 in patients who had total hip replacement surgery. One trial by Hull and colleagues in 2000 was included in the analysis, with this trial contributing two separate comparisons presented individually here. The first comparison provided a relative risk of 4.44 with a 95 percent confidence interval of 0.74 to 27.03. The second comparison provided a relative risk of 1.51 with a 95 percent confidence interval of 0.22 to 10.49. The combined effect of the two analyses showed a relative risk of 2.72 with a 95 percent confidence interval of 0.59 to 12.44. The I-squared value and the Egger's p-value could not be calculated because only one study was available.

Figure 198 Impact of injectable low molecular weight heparin prophylaxis versus oral vitamin K antagonist prophylaxis on minor surgical site bleeding in patients undergoing major orthopedic surgery

I^2^: Too few strata

Egger's p-value: Too few strata

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of injectable low molecular weight heparin prophylaxis versus oral vitamin K antagonist prophylaxis on minor surgical site bleeding in patients who had major orthopedic surgery. Two trials were included in this analysis. The first trial by Colwell and colleagues in 1999 provided an odds ratio of 1.37 with a 95 percent confidence interval of 0.93 to 2.02. The second trial by Hull and colleagues in 1993 provided an odds ratio of 0.14 with a 95 percent confidence interval of 0.003 to 6.88. The combined effect of the two trials showed an odds ratio of 1.34 with a 95 percent confidence interval of 0.91 to 1.97. The I-squared value and Egger's p-value could not be calculated because only two studies were available.

Figure 199 Impact of injectable low molecular weight heparin prophylaxis versus injectable or oral direct thrombin inhibitor prophylaxis on bleeding leading to transfusion in patients who had major orthopedic surgery limited to total hip replacement surgery

I^2^: Too few strata

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of injectable low molecular weight heparin prophylaxis versus injectable or oral direct thrombin inhibitor prophylaxis on bleeding leading to transfusions in patients who had major orthopedic surgery limited to total hip replacement surgery. One trial by Eriksson and colleagues in 2007 was included in the analysis with this trial contributing two separate comparisons presented individually here. The first comparison provided a relative risk of 2.02 with a 95 percent confidence interval of 0.79 to 5.16. The second comparison provided a relative risk of 0.76 with a 95 percent confidence interval of 0.34 to 1.66. The combined effect of the two analyses showed a relative risk of 1.19 with a 95 percent confidence interval of 0.46 to 3.10. The I-squared value could not be calculated because only one study was available.

Figure 200 Impact of injectable low molecular weight heparin prophylaxis versus injectable or oral direct thrombin inhibitor prophylaxis on bleeding leading to transfusion in patients who had major orthopedic surgery limited to total knee replacement surgery

I^2^: Too few strata

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of injectable low molecular weight heparin prophylaxis versus injectable or oral direct thrombin inhibitor prophylaxis on bleeding leading to transfusions in patients who had major orthopedic surgery limited to total knee replacement surgery. One trial by Eriksson and colleagues in 2007 was included in the analysis with this trial contributing two separate comparisons presented individually here. The first comparison provided a relative risk of 0.84 with a 95 percent confidence interval of 0.22 to 3.29. The second comparison provided a relative risk of 0.61 with a 95 percent confidence interval of 0.16 to 2.27. The combined effect of the two analyses showed a relative risk of 0.71 with a 95 percent confidence interval of 0.26 to 1.98. The I-squared value could not be calculated because only one study was available.

Figure 201 Impact of injectable low molecular weight heparin prophylaxis versus injectable unfractionated heparin prophylaxis on heparin-induced thrombocytopenia in patients who had major orthopedic surgery (same as analysis limited to total hip replacement surgery)

I^2^: 0 percent

Egger's p-value: Too few strata

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of injectable low molecular weight heparin prophylaxis versus injectable unfractionated heparin prophylaxis on heparin-induced thrombocytopenia in patients who had major orthopedic surgery. This figure also depicts the analysis of the impact of injectable low molecular weight heparin prophylaxis versus injectable unfractionated heparin prophylaxis on heparin-induced thrombocytopenia in patients who had major orthopedic surgery limited to total hip replacement surgery. Three trials were included in the analysis with one trial contributing two separate comparisons presented individually here. The first trial by Senaran and colleagues in 2006 was excluded because no events occurred in the groups compared. The second trial by Colwell and colleagues in 1994 included two comparisons. The first comparison provided an odds ratio of 0.06 with a 95 percent confidence interval of 0.0002 to 19.09. The second comparison provided an odds ratio of 0.05 with a 95 percent confidence interval of 0.0002 to 18.35. The third trial by Levine and colleagues in 1991 provided an odds ratio of 0.13 with a 95 percent confidence interval of 0.04 to 0.49. The combined effect of the two trials showed an odds ratio of 0.12 with a 95 percent confidence interval of 0.04 to 0.43. The I-squared value was 0 percent and the Egger's p-value could not be calculated because only three studies were available.

Figure 202 Impact of injectable low molecular weight heparin prophylaxis versus injectable unfractionated heparin prophylaxis on readmission in patients who had major orthopedic surgery (same as analysis limited to total hip replacement surgery)

I^2^: 14.1 percent

Egger's p-value: Too few strata

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of injectable low molecular weight heparin prophylaxis versus injectable unfractionated heparin prophylaxis on readmission in patients who had major orthopedic surgery. This figure also depicts the analysis of the impact of injectable low molecular weight heparin prophylaxis versus injectable unfractionated heparin prophylaxis on readmission in patients who had major orthopedic surgery limited to total hip replacement surgery. Two trials were included in this analysis with one trial contributing to two separate comparisons presented individually here. The first trial by Senaran and colleagues in 2006 provided a relative risk of 5.00 with a 95 percent confidence interval of 0.46 to 55.16. The second trial by Colwell and colleagues in 1994 included two comparisons. The first comparison provided a relative risk of 0.80 with a 95 percent confidence interval of 0.16 to 3.99. The second comparison provided a relative risk of 0.26 with a 95 percent confidence interval of 0.03 to 1.95. The combined effect of the two trials provided a relative risk of 0.82 with a 95 percent confidence interval of 0.20 to 3.88. The I-squared value was 14.1 percent and Egger's p-value could not be calculated because only two studies were available.

Figure 203 Impact of injectable low molecular weight heparin prophylaxis versus mechanical prophylaxis on readmission in patients who had major orthopedic surgery

I^2^: Too few strata

Egger's p-value: Too few strata

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of injectable low molecular weight heparin prophylaxis versus mechanical prophylaxis on readmission in patients who had major orthopedic surgery. Two trials were included in the analysis. The first trial by Warwick and colleagues in 2002 provided an odds ratio of 0.78 with a 95 percent confidence interval of 0.17 to 3.50. The second trial by Warwick and colleagues in 1998 provided an odds ratio of 1.03 with a 95 percent confidence interval of 0.06 to 16.52. The combined effect of the two trials showed an odds ratio of 0.83 with a 95 percent confidence interval of 0.22 to 3.11. The I-squared value and the Egger's p-value could not be calculated because only two studies were available.

Figure 204 Impact of enoxaparin versus other low molecular weight heparin agents on deep vein thrombosis in patients who had major orthopedic surgery

I^2^: Too few strata

Egger's p-value: Too few strata

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of enoxaparin versus other low molecular weight heparin agents on deep vein thrombosis in patients who had major orthopedic surgery. Two trials were included in this analysis. The first trial by Planes and colleagues in 1999 provided a relative risk of 0.93 with a 95 percent confidence interval of 0.64 to 1.33. The second trial by TIFDED Study Group in 1999 provided a relative risk of 1.75 with a 95 percent confidence interval of 0.64 to 4.84. The combined effect of these two trials showed a relative risk of 1.05 with a 95 percent confidence interval of 0.64 to 1.71. The I-squared value and Egger's p-value could not be calculated because of too few strata.

Figure 205 Impact of intermittent pneumatic compression versus graduated compression on deep vein thrombosis in patients who had major orthopedic surgery

I^2^: Too few strata

Egger's p-value: Too few strata

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of intermittent pneumatic compression versus graduated compression on deep vein thrombosis in patients who had major orthopedic surgery. One trial by Silbersack and colleagues in 2004 was included in the analysis and this trial included two separate comparisons. The first comparison provided a relative risk of 0.10 with a 95 percent confidence interval of 0.01 to 0.92. The second comparison provided a relative risk of 0.03 with a 95 percent confidence interval of 0.004 to 0.31. The combined effect of these two comparisons showed a relative risk of 0.06 with a 95 percent confidence interval of 0.01 to 0.42. The I-squared value and Egger's p-value could not be calculated because of too few strata.

Figure 206 Impact of enoxaparin versus other low molecular weight heparin agents on proximal deep vein thrombosis in patients who had major orthopedic surgery

I^2^: Too few strata

Egger's p-value: Too few strata

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of enoxaparin versus other low molecular weight heparin agents on proximal deep vein thrombosis in patients who had major orthopedic surgery. Two trials were included in this analysis. The first trial by Planes and colleagues in 1999 provided a relative risk of 1.11 with a 95 percent confidence interval of 0.64 to 1.92. The second trial by TIFDED Study Group in 1999 provided a relative risk of 0.73 with a 95 percent confidence interval of 0.15 to 3.53. The combined effect of these two trials showed a relative risk of 1.06 with a 95 percent confidence interval of 0.62 to 1.81. The I-squared value and Egger's p-value could not be calculated because of too few strata.

Figure 207 Impact of intermittent pneumatic compression versus graduated compression on proximal deep vein thrombosis in patients who had major orthopedic surgery

I^2^: Too few strata

Egger's p-value: Too few strata

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of intermittent pneumatic compression versus graduated compression on proximal deep vein thrombosis in patients who had major orthopedic surgery. One trial by Silbersack and colleagues in 2004 was included in the analysis and this trial included two separate comparisons. The first comparison provided a relative risk of 0.11 with a 95 percent confidence interval of 0.002 to 5.78. The second comparison provided a relative risk of 0.14 with a 95 percent confidence interval of 0.003 to 6.82. The combined effect of these two comparisons showed a relative risk of 0.12 with a 95 percent confidence interval of 0.01 to 1.99. The I-squared value and Egger's p-value could not be calculated because of too few strata.

Figure 208 Impact of intermittent pneumatic compression versus graduated compression on distal deep vein thrombosis in patients who had major orthopedic surgery

I^2^: Too few strata

Egger's p-value: Too few strata

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of intermittent pneumatic compression versus graduated compression on distal deep vein thrombosis in patients who had major orthopedic surgery. One trial by Silbersack and colleagues in 2004 was included in the analysis and this trial included two separate comparisons. The first comparison provided a relative risk of 0.15 with a 95 percent confidence interval of 0.01 to 1.53. The second comparison provided a relative risk of 0.04 with a 95 percent confidence interval of 0.004 to 0.33. The combined effect of these two comparisons showed a relative risk of 0.07 with a 95 percent confidence interval of 0.01 to 0.54. The I-squared value and Egger's p-value could not be calculated because of too few strata.

Figure 209 Impact of enoxaparin versus other low molecular weight heparin agents on major bleeding in patients who had major orthopedic surgery

I^2^: Too few strata

Egger's p-value: Too few strata

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of enoxaparin versus other low molecular weight heparin agents on major bleeding in patients who had major orthopedic surgery. Two trials were included in this analysis. The first trial by Planes and colleagues in 1999 provided a relative risk of 1.98 with a 95 percent confidence interval of 0.40 to 9.91. The second trial by TIFDED Study Group in 1999 provided a relative risk of 1.97 with a 95 percent confidence interval of 0.20 to 19.25. The combined effect of these two trials showed a relative risk of 1.98 with a 95 percent confidence interval of 0.53 to 7.37. The I-squared value and Egger's p-value could not be calculated because of too few strata.

Figure 210 Impact of enoxaparin versus other low molecular weight heparin agents on surgical site bleeding in patients who had major orthopedic surgery

I^2^: Too few strata

Egger's p-value: Too few strata

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of enoxaparin versus other low molecular weight heparin agents on surgical site bleeding in patients who had major orthopedic surgery. Two trials were included in this analysis. The first trial by Planes and colleagues in 1999 provided a relative risk of 1.99 with a 95 percent confidence interval of 0.40 to 9.92. The second trial by TIFDED Study Group in 1999 provided a relative risk of 0.14 with a 95 percent confidence interval of 0.003 to 6.82. The combined effect of these two trials showed a relative risk of 1.35 with a 95 percent confidence interval of 0.30 to 5.97. The I-squared value and Egger's p-value could not be calculated because of too few strata.

Figure 211 Impact of pharmacologic plus mechanical prophylaxis versus pharmacologic prophylaxis alone on pulmonary embolism in patients who had major orthopedic surgery (same as the analysis of nonfatal pulmonary embolism)

I^2^: Too few strata

Egger's p-value: Too few strata

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of pharmacologic plus mechanical prophylaxis versus pharmacologic prophylaxis alone on pulmonary embolism in patients who had major orthopaedic surgery. This figure also represents the analysis of pharmacologic plus mechanical prophylaxis versus pharmacologic prophylaxis alone on nonfatal pulmonary embolism in patients who had major orthopaedic surgery. Two trials were included in this analysis, with the trial by Edwards and colleagues in 2008 including two separate comparisons. The first trial by Edwards and colleagues in 2008 provided two separate comparisons. The first comparison was excluded because no events occurred in the groups compared. The second comparison provided an odds ratio of 1.01 with a 95 percent confidence interval of 0.06 to 16.35. The second trial by Lieberman and colleagues in 1994 provided an odds ratio 1.04 with a 95 percent confidence interval of 0.06 to 16.81. The combined effect of these two trials showed an odds ratio of 1.03 with a 95 percent confidence interval of 0.14 to 7.34. The I-squared value and Egger's p-value could not be calculated because of too few strata.

Figure 212 Impact of pharmacologic plus mechanical prophylaxis versus pharmacologic prophylaxis alone on deep vein thrombosis in patients who had major orthopedic surgery

I^2^: 0 percent

Egger's p-value: 0.831

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of pharmacologic plus mechanical prophylaxis versus pharmacologic prophylaxis alone on deep vein thrombosis in patients who had major orthopedic surgery. Three trials were included in this analysis, with the trial by Edwards and colleagues in 2008 including two separate comparisons. The first trial by Edwards and colleagues in 2008 provided two separate comparisons. The first comparison provided a relative risk of 0.45 with a 95 percent confidence interval of 0.06 to 3.39. The second comparison provided a relative risk of 0.45 with a 95 percent confidence interval of 0.15 to 1.32. The second trial by Kalodiki and colleagues in 1996 provided a relative risk of 0.67 with a 95 percent confidence interval of 0.31 to 1.38. The third trial by Westrich and colleagues in 1996 provided a relative risk of 0.40 with a 95 percent confidence interval of 0.23 to 0.68. The combined effect of these three trials showed a relative risk of 0.48 with a 95 percent confidence interval of 0.32 to 0.72. The I-squared value was 0 percent and the Egger's p-value was 0.831.

Figure 213 Impact of anticoagulant plus mechanical prophylaxis versus anticoagulant prophylaxis alone on deep vein thrombosis in patients who had major orthopedic surgery

I^2^: 0 percent

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of anticoagulant plus mechanical prophylaxis versus anticoagulant prophylaxis alone on deep vein thrombosis in patients who had major orthopaedic surgery. Two trials were included in this analysis, with the trial by Edwards and colleagues in 2008 including two separate comparisons. The first trial by Edwards and colleagues in 2008 provided two separate comparisons. The first comparison provided a relative risk of 0.45 with a 95 percent confidence interval of 0.06 to 3.39. The second comparison provided a relative risk of 0.45 with a 95 percent confidence interval of 0.15 to 1.32. The second trial by Kalodiki and colleagues in 1996 provided a relative risk of 0.67 with a 95 percent confidence interval of 0.31 to 1.38. The combined effect of these two trials showed a relative risk of 0.58 with a 95 percent confidence interval of 0.32 to 1.06. The I-squared value was 0 percent.

Figure 214 Impact of pharmacologic plus mechanical prophylaxis versus pharmacologic prophylaxis alone on deep vein thrombosis in patients who had major orthopedic surgery limited to trials published from 2001-present

I^2^: Too few strata

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of pharmacologic plus mechanical prophylaxis versus pharmacologic prophylaxis alone on deep vein thrombosis in patients who had major orthopaedic surgery limited to trials published from 2001 to present. One trial by Edwards and colleagues in 2008 was included in this analysis although it included two separate comparisons. The first comparison provided a relative risk of 0.45 with a 95 percent confidence interval of 0.06 to 3.39. The second comparison provided a relative risk of 0.45 with a 95 percent confidence interval of 0.15 to 1.32. The combined effect of these two comparisons showed a relative risk of 0.45 with a 95 percent confidence interval of 0.16 to 1.26. The I-squared value could not be calculated because of too few strata.

Figure 215 Impact of pharmacologic plus mechanical prophylaxis versus pharmacologic prophylaxis alone on deep vein thrombosis in patients who had major orthopedic surgery limited to total hip replacement

I^2^: Too few strata

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of pharmacologic plus mechanical prophylaxis versus pharmacologic prophylaxis alone on deep vein thrombosis in patients who had major orthopaedic surgery limited to total hip replacement. Two trials were included in this analysis. The first trial by Edwards and colleagues in 2008 provided a relative risk of 0.45 with a 95 percent confidence interval of 0.06 to 3.39. The second trial by Kalodiki and colleagues in 1996 provided a relative risk of 0.67 with a 95 percent confidence interval of 0.31 to 1.38. The combined effect of these two trials showed a relative risk of 0.64 with a 95 percent confidence interval of 0.32 to 1.31. The I-squared value could not be calculated because of too few strata.

Figure 216 Impact of pharmacologic plus mechanical prophylaxis versus pharmacologic prophylaxis alone on deep vein thrombosis in patients who had major orthopedic surgery limited to total knee replacement

I^2^: Too few strata

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of pharmacologic plus mechanical prophylaxis versus pharmacologic prophylaxis alone on deep vein thrombosis in patients who had major orthopaedic surgery limited to total knee replacement. Two trials were included in this analysis. The first trial by Edwards and colleagues in 2008 provided a relative risk of 0.45 with a 95 percent confidence interval of 0.15 to 1.32. The second trial by Westrich and colleagues in 1996 provided a relative risk of 0.40 with a 95 percent confidence interval of 0.23 to 0.68. The combined effect of these two trials showed a relative risk of 0.41 with a 95 percent confidence interval of 0.25 to 0.68. The I-squared value could not be calculated because of too few strata.

Figure 217 Impact of pharmacologic plus mechanical prophylaxis versus pharmacologic prophylaxis alone on proximal deep vein thrombosis in patients who had major orthopedic surgery

I^2^: Too few strata

Egger's p-value: Too few strata

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of pharmacologic plus mechanical prophylaxis versus pharmacologic prophylaxis alone on proximal deep vein thrombosis in patients who had major orthopedic surgery. Three trials were included in this analysis, with the trial by Edwards and colleagues in 2008 including two separate comparisons. The first trial by Edwards and colleagues in 2008 provided two separate comparisons. The first comparison was excluded because no events occurred in the groups compared. The second comparison was excluded because no events occurred in the groups compared. The second trial by Westrich and colleagues in 1996 provided a relative risk of 0.09 with a 95 percent confidence interval of 0.01 to 0.84. The third trial by Kalodiki and colleagues in 1996 provided a relative risk of 0.44 with a 95 percent confidence interval of 0.16 to 1.21. The combined effect of these two trials showed a relative risk of 0.33 with a 95 percent confidence interval of 0.09 to 1.22. The I-squared value and Egger's p-value could not be calculated because of too few strata.

Figure 218 Impact of pharmacologic plus mechanical prophylaxis versus mechanical prophylaxis alone on proximal deep vein thrombosis in patients who had major orthopedic surgery

I^2^: Too few strata

Egger's p-value: Too few strata

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of pharmacologic plus mechanical prophylaxis versus mechanical prophylaxis alone on proximal deep vein thrombosis in patients who had major orthopedic surgery. One trial by Woolson and colleagues in 1991 was included in this analysis and this trial included two separate comparisons. The first comparison provided a relative risk of 0.82 with a 95 percent confidence interval of 0.29 to 2.42. The second comparison provided a relative risk of 0.73 with a 95 percent confidence interval of 0.25 to 2.23. The combined effect of these two comparisons showed a relative risk of 0.78 with a 95 percent confidence interval of 0.35 to 1.74. The I-squared value and Egger's p-value could not be calculated because of too few strata.

Figure 219 Impact of pharmacologic plus mechanical prophylaxis versus pharmacologic prophylaxis alone on distal deep vein thrombosis in patients who had major orthopedic surgery (same as the analysis of trial published from 2001-present; same as the comparison of anticoagulant plus mechanical prophylaxis versus anticoagulant alone in patients who had major orthopedic surgery)

I^2^: Too few strata

Egger's p-value: Too few strata

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of pharmacologic plus mechanical prophylaxis alone on distal deep vein thrombosis in patients who had major orthopaedic surgery. This is the same analysis as limiting the pooled analysis to trial published from 2001-present as well as comparing anticoagulant plus mechanical prophylaxis versus anticoagulant prophylaxis alone in patients who had major orthopaedic surgery. One trial by Edwards and colleagues in 2008 was included in this analysis although it included two separate comparisons. The first comparison provided a relative risk of 0.45 with a 95 percent confidence interval of 0.06 to 3.39. The second comparison provided a relative risk of 0.45 with a 95 percent confidence interval of 0.15 to 1.32. The combined effect of these two comparisons showed a relative risk of 0.45 with a 95 percent confidence interval of 0.16 to 1.26. The I-squared value and Egger's p-value could not be calculated because of too few strata.

Figure 220 Impact of prolonged prophylaxis versus standard duration of prophylaxis on symptomatic objectively confirmed venous thromboembolism in patients who had major orthopedic surgery

I^2^: 69.1 percent

Egger's p-value: 0.150

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of prolonged prophylaxis versus standard duration of prophylaxis on symptomatic objectively confirmed venous thromboembolism in patients who had major orthopedic surgery. Four trials were included in this analysis with the trial by Comp and colleagues contributing two comparisons presented individually here. The first trial by Eriksson and colleagues in 2003 provided a relative risk of 0.11 and a 95 percent confidence interval of 0.02 to 0.68. The second trial by Prandoni and colleagues in 2002 provided a relative risk of 0.32 with a 95 percent confidence interval of 0.09 to 1.07. The third trial by Comp and colleagues in 2001 provided two comparisons. The first comparison provided a relative risk of 0.35 with a 95 percent confidence interval of 0.21 to 0.57. The second comparison provided a relative risk of 0.84 with a 95 percent confidence interval of 0.57 to 1.23. The fourth trial by Nilsson and colleagues in 1997 provided relative risk of 0.20 and a 95 percent confidence interval of 0.05 to 0.79. The combined effect of the four trials showed a relative risk of 0.38 with a 95 percent confidence interval of 0.19 to 0.77. The I-squared value was 69.1 percent and the Egger's p-value was 0.150

Figure 221 Impact of prolonged prophylaxis versus standard duration of prophylaxis on symptomatic objectively confirmed venous thromboembolism in patients who had major orthopedic surgery limited to trial published from 2001-present

I^2^: 72.9 percent

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of prolonged prophylaxis versus standard duration of prophylaxis on symptomatic objectively confirmed venous thromboembolism in patients who had major orthopedic surgery limited to trials published from 2001-present. Three trials were included in this analysis with the trial by Comp and colleagues contributing two comparisons presented individually here. The first trial by Eriksson and colleagues in 2003 provided a relative risk of 0.11 with a 95 percent confidence interval of 0.02 to 0.68. The second trial by Prandoni and colleagues in 2002 provided a relative risk of 0.32 with a 95 percent confidence interval of 0.09 to 1.07. The third trial by Comp and colleagues in 2001 provided two comparisons. The first comparison provided a relative risk of 0.35 with a 95 percent confidence interval of 0.21 to 0.57. The second comparison provided a relative risk of 0.84 with a 95 percent confidence interval of 0.57 to 1.23. The combined effect of the three trials showed a relative risk of 0.43 with a 95 percent confidence interval of 0.20 to 0.89. The I-squared value was 72.9 percent.

Figure 222 Impact of prolonged prophylaxis versus standard duration of prophylaxis on symptomatic objectively confirmed venous thromboembolism in patients who had major orthopedic surgery limited to total hip replacement surgery

I^2^: 0 percent

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of prolonged prophylaxis versus standard duration of prophylaxis on symptomatic objectively confirmed venous thromboembolism in patients who had major orthopedic surgery limited to total hip replacement surgery. Three trials were included in this analysis. The first trial by Prandoni and colleagues in 2002 provided a relative risk of 0.32 with a 95 percent confidence interval of 0.09 to 1.07. The second trial by Comp and colleagues in 2001 provided a relative risk of 0.35 with a 95 percent confidence interval of 0.21 to 0.57. The third trial by Nilsson and colleagues in 1997 provided a relative risk of 0.20 with a 95 percent confidence interval of 0.05 to 0.79. The combined effect of the three trials showed a relative risk of 0.33 with a 95 percent confidence interval of 0.21 to 0.51. The I-squared value was 0 percent.

Figure 223 Impact of prolonged prophylaxis versus standard duration of prophylaxis on pulmonary embolism in patients who had major orthopedic surgery limited to trials published from 2001-present

I^2^: 0 percent

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of prolonged prophylaxis versus standard duration of prophylaxis on pulmonary embolism in patients who had major orthopedic surgery limited to trials published from 2001-present. Three trials were included in this analysis with the trial by Comp and colleagues including two separate comparisons. The first trial by Eriksson and colleagues in 2003 provided an odds ratio of 0.14 and a 95 percent confidence interval of 0.01 to 1.31. The second trial by Prandoni and colleagues in 2002 provided an odds ratio of 0.13 with a 95 percent confidence interval of 0.003 to 6.52. The third trial by Comp and colleagues in 2001 provided two comparisons. The first comparison provided an odds ratio of 0.13 with a 95 percent confidence interval of 0.003 to 6.42. The second comparison provided an odds ratio of 0.14 with a 95 percent confidence interval of 0.01 to 2.20. The combined effect of the three trials showed an odds ratio of 0.13 with a 95 percent confidence interval of 0.03 to 0.59. The I-squared value was 0 percent.

Figure 224 Impact of prolonged prophylaxis versus standard duration of prophylaxis on pulmonary embolism in patients who had major orthopedic surgery limited to total hip replacement surgery

I^2^: 0 percent

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of prolonged prophylaxis versus standard duration of prophylaxis on pulmonary embolism in patients who had major orthopedic surgery limited to total hip replacement surgery. Five trials were included in this analysis. The first trial by Prandoni and colleagues in 2002 provided an odds ratio of 0.13 with a 95 percent confidence interval of 0.003 to 6.52. The second trial by Comp and colleagues in 2001 provided an odds ratio of 0.13 with a 95 percent confidence interval of 0.003 to 6.42. The third trial by Andersen and colleagues in 1997 provided an odds ratio of 0.14 and a 95 percent confidence interval of 0.003 to 7.16. The fourth trial by Nilsson and colleagues in 1997 provided an odds ratio of 0.13 with a 95 percent confidence interval of 0.01 to 2.16. The fifth trial by Planes and colleagues in 1997 was excluded because no events occurred in the group compared. The combined effect of the four trials showed an odds ratio of 0.13 with a 95 percent confidence interval of 0.02 to 0.77. The I-squared value was 0 percent.

Figure 225 Impact of prolonged prophylaxis versus standard duration of prophylaxis on nonfatal pulmonary embolism in patients who had major orthopedic surgery

I^2^: 0 percent

Egger's p-value: 0.016

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of prolonged prophylaxis versus standard duration of prophylaxis on nonfatal pulmonary embolism in patients who had major orthopedic surgery. Five trials were included in this analysis with the trial by Comp and colleagues including two separate comparisons. The first trial by Eriksson and colleagues in 2003 provided an odds ratio of 0.14 with a 95 percent confidence interval of 0.01 to 2.19. The second trial by Prandoni and colleagues in 2002 provided an odds ratio of 0.13 with a 95 percent confidence interval of 0.003 to 6.52. The third trial by Comp and colleagues in 2001 included two comparisons. The first comparison provided an odds ratio of 0.13 with a 95 percent confidence interval of 0.003 to 6.42. The second comparison provided an odds ratio of 0.14 with a 95 percent confidence interval of 0.01 to 2.20. The fourth trial by Nilsson and colleagues in 1997 provided an odds ratio of 0.13 with a 95 percent confidence interval of 0.01 to 2.16. The fifth trial by Planes and colleagues in 1997 was excluded because no events occurred in the groups compared. The combined effect of the four trials showed an odds ratio of 0.13 with a 95 percent confidence interval of 0.03 to 0.54. The I-squared value was 0 percent and the Egger's p-value was 0.016.

Figure 226 Impact of prolonged prophylaxis versus standard duration of prophylaxis on nonfatal pulmonary embolism in patients who had major orthopedic surgery limited to trials published from 2001-present

I^2^: 0 percent

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of prolonged prophylaxis versus standard duration of prophylaxis on nonfatal pulmonary embolism in patients who had major orthopedic surgery limited to trials published from 2001-present. Three trials were included in this analysis with the trial by Comp and colleagues including two separate comparisons. The first trial by Eriksson and colleagues in 2003 provided an odds ratio of 0.14 with a 95 percent confidence interval of 0.01 to 2.19. The second trial by Prandoni and colleagues in 2002 provided an odds ratio of 0.13 with a 95 percent confidence interval of 0.003 to 6.52. The third trial by Comp and colleagues in 2001 included two comparisons. The first comparison provided an odds ratio of 0.13 with a 95 percent confidence interval of 0.003 to 6.42. The second comparison provided an odds ratio of 0.14 with a 95 percent confidence interval of 0.01 to 2.20. The combined effect of the three trials showed an odds ratio of 0.13 with a 95 percent confidence interval of 0.03 to 0.66. The I-squared value was 0 percent.

Figure 227 Impact of prolonged prophylaxis versus standard duration of prophylaxis on nonfatal pulmonary embolism in patients who had major orthopedic surgery limited to total hip replacement surgery

I^2^: 0 percent

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of prolonged prophylaxis versus standard duration of prophylaxis on nonfatal pulmonary embolism in patients who had major orthopedic surgery limited to total hip replacement surgery. Four trials were included in this analysis. The first trial by Prandoni and colleagues in 2002 provided an odds ratio of 0.13 with a 95 percent confidence interval of 0.003 to 6.52. The second trial by Comp and colleagues in 2001 provided an odds ratio of 0.13 with a 95 percent confidence interval of 0.003 to 6.42. The third trial by Nilsson and colleagues in 1997 provided an odds ratio of 0.13 with a 95 percent confidence interval of 0.01 to 2.16. The fourth trial by Planes and colleagues in 1997 was excluded because no events occurred in the groups compared. The combined effect of the three trials showed an odds ratio of 0.13 with a 95 percent confidence interval of 0.02 to 0.93. The I-squared value was 0 percent.

Figure 228 Impact of prolonged prophylaxis versus standard duration of prophylaxis on deep vein thrombosis in patients who had major orthopedic surgery

I^2^: 78.3 percent

Egger's p-value: 0.164

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of prolonged prophylaxis versus standard duration of prophylaxis on deep vein thrombosis in patients who had major orthopedic surgery. Seven trials were included in this analysis with the trial by Comp and colleagues including two separate comparisons. The first trial by Eriksson and colleagues in 2003 provided a relative risk of 0.04 with a 95 percent confidence interval of 0.01 to 0.12. The second trial by Prandoni and colleagues in 2002 provided a relative risk of 0.36 with a 95 percent confidence interval of 0.10 to 1.22. The third trial by Comp and colleagues in 2001 included two comparisons. The first comparison provided a relative risk of 0.35 with a 95 percent confidence interval of 0.21 to 0.57. The second comparison provided a relative risk of 0.84 with a 95 percent confidence interval of 0.57 to 1.23. The fourth trial by Lassen and colleagues in 1998 provided a relative risk of 0.38 with a 95 percent confidence interval of 0.14 to 0.99. The fifth trial by Andersen and colleagues in 1997 provided a relative risk of 0.70 with a 95 percent confidence interval of 0.15 to 3.20. The sixth trial by Nilsson and colleagues in 1997 provided a relative risk of 0.49 with a 95 percent confidence interval of 0.31 to 0.77. The seventh trial by Planes and colleagues in 1997 provided a relative risk of 0.37 with a 95 percent confidence interval of 0.15 to 0.85. The combined effect of the seven trials showed a relative risk of 0.37 with a 95 percent confidence interval of 0.21 to 0.64. The I-squared value was 78.3 percent and the Egger's p-value was 0.164.

Figure 229 Impact of prolonged prophylaxis versus standard duration of prophylaxis on deep vein thrombosis in patients who had major orthopedic surgery limited to trials published from 2001-present

I^2^: 90.9 percent

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of prolonged prophylaxis versus standard duration of prophylaxis on deep vein thrombosis in patients who had major orthopedic surgery limited to trials published from 2001-present. Three trials were included in this analysis with the trial by Comp and colleagues including two separate comparisons. The first trial by Eriksson and colleagues in 2003 provided a relative risk of 0.04 with a 95 percent confidence interval of 0.01 to 0.12. The second trial by Prandoni and colleagues in 2002 provided a relative risk of 0.36 with a 95 percent confidence interval of 0.10 to 1.22. The third trial by Comp and colleagues in 2001 included two comparisons. The first comparison proved a relative risk of 0.35 with a 95 percent confidence interval of 0.21 to 0.57. The second comparison provided a relative risk of 0.84 with a 95 percent confidence interval of 0.57 to 1.23. The combined effect of the three trials showed a relative risk of 0.28 with a 95 percent confidence interval of 0.09 to 0.87. The I-squared value was 90.9 percent.

Figure 230 Impact of prolonged prophylaxis versus standard duration of prophylaxis on deep vein thrombosis in patients who had major orthopedic surgery limited to total hip replacement surgery

I^2^: 0 percent

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of prolonged prophylaxis versus standard duration of prophylaxis on deep vein thrombosis in patients who had major orthopedic surgery limited to total hip replacement surgery. Six trials were included in this analysis. The first trial by Prandoni and colleagues in 2002 provided a relative risk of 0.36 with a 95 percent confidence interval of 0.10 to 1.22. The second trial by Comp and colleagues in 2001 provided a relative risk of 0.35 with a 95 percent confidence interval of 0.21 to 0.57. The third trial by Lassen and colleagues in 1998 provided a relative risk of 0.38 with a 95 percent confidence interval of 0.14 to 0.99. The fourth trial by Andersen and colleagues in 1997 provided a relative risk of 0.70 with a 95 percent confidence interval of 0.15 to 3.20. The fifth trial by Nilsson and colleagues in 1997 provided a relative risk of 0.49 and a 95 percent confidence interval of 0.31 to 0.77. The sixth trial by Planes and colleagues in 1997 provided a relative risk of 0.37 with a 95 percent confidence interval of 0.15 to 0.85. The combined effect of the six trials showed a relative risk of 0.41 with a 95 percent confidence interval of 0.31 to 0.55. The I-squared value was 0 percent.

Figure 231 Impact of prolonged prophylaxis versus standard duration of prophylaxis on symptomatic deep vein thrombosis in patients who had major orthopedic surgery limited to trials published from 2001-present

I^2^: Too few strata

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of prolonged prophylaxis versus standard duration of prophylaxis on symptomatic deep vein thrombosis in patients who had major orthopedic surgery limited to trials published from 2001-present. Two trials were included in this analysis. The first trial by Eriksson and colleagues in 2003 provided an odds ratio of 0.24 with a 95 percent confidence interval of 0.05 to 1.06. The second trial by Prandoni and colleagues in 2002 provided an odds ratio of 0.64 with a 95 percent confidence interval of 0.11 to 3.72. The combined effect of the two trials showed an odds ratio of 0.36 with a 95 percent confidence interval of 0.12 to 1.12. The I-squared value could not be calculated because of too few strata.

Figure 232 Impact of prolonged prophylaxis versus standard duration of prophylaxis on symptomatic deep vein thrombosis in patients who had major orthopedic surgery limited to total hip replacement surgery

I^2^: 0 percent

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of prolonged prophylaxis versus standard duration of prophylaxis on symptomatic deep vein thrombosis in patients who had major orthopedic surgery limited to total hip replacement surgery. Three trials were included in this analysis. The first trial by Prandoni and colleagues in 2002 provided an odds ratio of 0.64 with a 95 percent confidence interval of 0.11 to 3.72. The second trial by Andersen and colleagues in 1997 provided an odds ratio of 1.05 with a 95 percent confidence interval of 0.06 to 17.43. The third trial by Nilsson and colleagues in 1997 provided an odds ratio of 0.29 with a 95 percent confidence interval of 0.08 to 1.02. The combined effect of the three trials showed an odds ratio of 0.43 with a 95 percent confidence interval of 0.16 to 1.12. The I-squared value was 0 percent.

Figure 233 Impact of prolonged prophylaxis versus standard duration of prophylaxis on proximal deep vein thrombosis in patients who had major orthopedic surgery limited to trials published from 2001-present

I^2^: 65.5 percent

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of prolonged prophylaxis versus standard duration of prophylaxis on proximal deep vein thrombosis in patients who had major orthopedic surgery limited to trials published from 2001-present. Three trials were included in this analysis and the trial by Comp and colleagues including two separate comparisons presented individually here. The first trial by Eriksson and colleagues in 2003 provided a relative risk of 0.06 with a 95 percent confidence interval of 0.02 to 0.21. The second trial by Prandoni and colleagues in 2002 provided a relative risk of 0.32 with a 95 percent confidence interval of 0.05 to 2.20. The third trial by Comp and colleagues in 2001 included two separate comparisons. The first comparison provided a relative risk of 0.21 with a 95 percent confidence interval of 0.09 to 0.48. The second comparison provided a relative risk of 0.54 with a 95 percent confidence interval of 0.25 to 1.16. The combined effect of the three trials showed a relative risk of 0.23 with a 95 percent confidence interval of 0.08 to 0.61. The I-squared value could not be calculated because of too few strata.

Figure 234 Impact of prolonged prophylaxis versus standard duration of prophylaxis on proximal deep vein thrombosis in patients who had major orthopedic surgery limited total hip replacement surgery

I^2^: 0 percent

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of prolonged prophylaxis versus standard duration of prophylaxis on proximal deep vein thrombosis in patients who had major orthopedic surgery limited total hip replacement surgery. Five trials were included in this analysis. The first trial by Prandoni and colleagues in 2002 provided a relative risk of 0.32 with a 95 percent confidence interval of 0.05 to 2.20. The second trial by Comp and colleagues in 2001 provided a relative risk of 0.21with a 95 percent confidence interval of 0.09 to 0.48. The third trial by Lassen and colleagues provided a relative risk of 0.18 with a 95 percent confidence interval of 0.03 to 1.15. The fourth trial by Nilsson and colleagues in 1997 provided a relative risk of 0.29 with a 95 percent confidence interval of 0.14 to 0.59. The fifth trial by Planes and colleagues in 1997 provided a relative risk of 0.74 with a 95 percent confidence interval of 0.26 to 2.12. The combined effect of the five trials showed a relative risk of 0.30 with a 95 percent confidence interval of 0.19 to 0.49. The I-squared value was 0 percent.

Figure 235 Impact of prolonged prophylaxis versus standard duration of prophylaxis on distal deep vein thrombosis in patients who had major orthopedic surgery

I^2^: 83.6 percent

Egger's p-value: 0.023

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of prolonged prophylaxis versus standard duration of prophylaxis on distal deep vein thrombosis in patients who had major orthopedic surgery. Four trials were included in this analysis with the trial by Comp and colleagues including two separate comparisons presented individually here. The first trial by Eriksson and colleagues in 2003 provided a relative risk of 0.02 with a 95 percent confidence interval of 0.004 to 0.14. The second trial by Comp and colleagues in 2001 provided two separate comparisons. The first comparison provided a relative risk of 0.51 with a 95 percent confidence interval of 0.26 to 1.00. The second comparison provided a relative risk of 1.09 with a 95 percent confidence interval of 0.67 to 1.78. The third trial by Nilsson and colleagues in 1997 provided a relative risk of 0.87 with a 95 percent confidence interval of 0.44 to 1.72. The fourth trial by Planes and colleagues in 1997 provided a relative risk of 0.10 with a 95 percent confidence interval of 0.02 to 0.60. The combined effect of the four trials showed a relative risk of 0.39 with a 95 percent confidence interval of 0.15 to 1.04. The I-squared value was 83.6 percent and Egger's p-value was 0.023.

Figure 236 Impact of prolonged prophylaxis versus standard duration of prophylaxis on distal deep vein thrombosis in patients who had major orthopedic surgery limited to trials published from 2001-present

I^2^: 90.3 percent

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of prolonged prophylaxis versus standard duration of prophylaxis on distal deep vein thrombosis in patients who had major orthopedic surgery limited to trials published from 2001-present. Two trials were included in this analysis with the trial by Comp and colleagues including two separate comparisons presented individually here. The first trial by Eriksson and colleagues in 2003 provided a relative risk of 0.02 with a 95 percent confidence interval of 0.004 to 0.14. The second trial by Comp and colleagues in 2001 provided two separate comparisons. The first comparison provided a relative risk of 0.51 with a 95 percent confidence interval of 0.26 to 1.00. The second comparison provided a relative risk of 1.09 with a 95 percent confidence interval of 0.67 to 1.78. The combined effect of the two trials showed a relative risk of 0.33 with a 95 percent confidence interval of 0.07 to 1.51. The I-squared value was 90.3 percent.

Figure 237 Impact of prolonged prophylaxis versus standard duration of prophylaxis on distal deep vein thrombosis in patients who had major orthopedic surgery limited to total hip replacement surgery

I^2^: 53.4 percent

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of prolonged prophylaxis versus standard duration of prophylaxis on distal deep vein thrombosis in patients who had major orthopedic surgery limited to total hip replacement surgery. Three trials were included in this analysis. The first trial by Comp and colleagues in 2001 provided a relative risk of 0.51 with a 95 percent confidence interval of 0.26 to 1.00. The second trial by Nilsson and colleagues in 1997 provided a relative risk of 0.87 with a 95 percent confidence interval of 0.43 to 1.72. The third trial by Planes and colleagues in 1997 provided a relative risk of 0.10 with a 95 percent confidence interval of 0.02 to 0.60. The combined effect of the three trials showed a relative risk of 0.53 with a 95 percent confidence interval of 0.24 to 1.17. The I-squared value was 53.4 percent.

Figure 238 Impact of prolonged prophylaxis versus standard duration of prophylaxis on major bleeding in patients who had major orthopedic surgery

I^2^: 35.6 percent

Egger's p-value: 0.334

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of prolonged prophylaxis versus standard duration of prophylaxis on major bleeding in patients who had major orthopedic. Five trials were included in this analysis with the trial by Comp and colleagues including two comparisons presented individually here. The first trial by Eriksson and colleagues in 2003 provided an odds ratio of 3.40 with a 95 percent confidence interval of 0.98 to 11.84. The second trial by Prandoni and colleagues in 2002 provided an odds ratio of 7.08 with a 95 percent confidence interval of 0.14 to 356.89. The third trial by Comp and colleagues in 2001 provided two comparisons. The first comparison was excluded because there were no events in the groups compared. The second comparison provided an odds ratio of 0.14 with a 95 percent confidence interval of 0.003 to 6.95. The fourth trial by Lassen and colleagues in 1998 provided an odds ratio of 0.14 with a 95 percent confidence interval of 0.003 to 6.87. The fifth trial by Planes and colleagues in 1997 was excluded because no events occurred in the groups compared. The combined effect of the five trials showed an odds ratio of 2.18 with a 95 percent confidence interval of 0.73 to 6.51. The I-squared value was 35.6 percent and the Egger's p-value was 0.334.

Figure 239 Impact of prolonged prophylaxis versus standard duration of prophylaxis on major bleeding in patients who had major orthopedic surgery limited to trials published from 2001-present

I^2^: 22.3 percent

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of prolonged prophylaxis versus standard duration of prophylaxis on major bleeding in patients who had major orthopedic surgery limited to trials published from 2001-present. Three trials were included in this analysis with the trial by Comp and colleagues including two comparisons presented individually here. The first trial by Eriksson and colleagues in 2003 provided an odds ratio of 3.40 with a 95 percent confidence interval of 0.98 to 11.84. The second trial by Prandoni and colleagues in 2002 provided an odds ratio of 7.08 with a 95 percent confidence interval of 0.14 to 356.89. The third trial by Comp and colleagues in 2001 provided two comparisons. The first comparison was excluded because there were no events in the groups compared. The second comparison provided an odds ratio of 0.14 with a 95 percent confidence interval of 0.003 to 6.95. The combined effect of the three trials showed an odds ratio of 2.76 with a 95 percent confidence interval of 0.88 to 8.61. The I-squared value was 22.3 percent.

Figure 240 Impact of prolonged prophylaxis versus standard duration of prophylaxis on major bleeding in patients who had major orthopedic surgery limited to total hip replacement surgery

I^2^: Too few strata

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each tudy in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of prolonged prophylaxis versus standard duration of prophylaxis on major bleeding in patients who had major orthopedic surgery limited to total hip replacement surgery. Four trials were included in this analysis. The first trial by Prandoni and colleagues in 2002 provided an odds ratio of 7.08 with a 95 percent confidence interval of 0.14 to 356.89. The second trial by Comp and colleagues in 2001 was excluded because no events occurred in the groups compared. The third trial by Lassen and colleagues in 1998 provided an odds ratio of 0.14 with a 95 percent confidence interval of 0.003 to 6.87. The fourth trial by Planes and colleagues in 1997 was excluded because no events occurred in the groups compared. The combined effect of the two trials showed an odds ratio of 0.98 with a 95 percent confidence interval of 0.06 to 15.70. The I-squared value could not be calculated because of too few strata.

Figure 241 Impact of prolonged prophylaxis versus standard duration of prophylaxis on minor bleeding in patients who had major orthopedic surgery limited to total hip replacement surgery

I^2^: Too few strata

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of prolonged prophylaxis versus standard duration of prophylaxis on minor bleeding in patients who had major orthopedic surgery limited to total hip replacement surgery. Two trials were included in this analysis. The first trial by Lassen and colleagues in 1998 provided an odds ratio of 1.72 with a 95 percent confidence interval of 0.80 to 3.71. The second trial by Planes and colleagues in 1997 provided an odds ratio of 3.98 with a 95 percent confidence interval of 1.61 to 9.88. The combined effect of the two trials showed an odds ratio of 2.44 with a 95 percent confidence interval of 1.36 to 4.39. The I-squared value could not be calculated because of too few strata.

Figure 242 Impact of prolonged prophylaxis versus standard duration of prophylaxis on readmission in patients who had major orthopedic surgery (same as limited to trials published from 2001-present)

I^2^: Too few strata

Legend: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95 percent confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

This figure depicts the meta-analysis of the impact of prolonged prophylaxis versus standard duration of prophylaxis on readmission in patients who had major orthopedic surgery. This figure also depicts the meta-analysis of the impact of prolonged prophylaxis versus standard duration of prophylaxis on readmission in patients who had major orthopedic surgery limited to trials published from 2001-present. One trial by Comp and colleagues 2001 was included in this analysis and included two separate comparisons presented individually here. The first comparisons provided a relative risk of 0.13 with 95 percent confidence interval of 0.04 to 0.39. The second comparison provided a relative risk of 0.59 with a 95 percent confidence interval of 0.24 to 1.44. The combined effect of the two comparisons showed a relative risk of 0.29 with a 95 percent confidence interval of 0.06 to 1.34. The I-squared value could not be calculated because of too few strata.