# Baseline and Procedural Characteristics of Included Trials and Studies

Table 6 Baseline characteristics of patient enrolled in randomized controlled trials evaluating major orthopedic surgery

Table 7 Procedural characteristics of randomized controlled trials evaluating patinets who had major orthopedic surgery

Table 8 Baseline characteristics of randomized controlled trials in nonmajor orthopedic surgery

Table 9 Procedural characteristics of randomized controlled trials in nonmajor orthopedic surgery

Table 10 Baseline characteristics of observational studies evaluating venous thromboembolism prophylaxis in major orthopedic surgery

Table 11 Procedural characteristics of observational studies evaluating venous thromboembolism prophylaxis in major orthopedic surgery