# Quality and Characteristics of Included Trials and Studies

Table 3 Quality and characteristics of randomized controlled trials in major orthopedic surgery

Table 4 Quality and characteristics of randomized controlled trials evaluating nonmajororthopedic surgery

Table 5 Quality and characteristics of observational studies