# Excluded Studies From Full-Text Review

Table 1 Excluded studies at the full text level from search one

Excluded as a duplicate publication (n=21)
1. | Anders JO, Fuhrmann R, Roth A, et al. How can we deereose the number of thrombosis and pulmonary embolism in total hip replacement? Z Orthop Ihre 2004;142:328-32.
2. | Banssillon V, Dejour H, Besson L, et al. Prevention of deep venous thromboses (DVT) in orthopaedic surgery for total hip replacement (THR). Randomised dose-ranging trial. ANN-CHIR 1987;41:377-85.
3. | Bergqvist D, Breddin K, Ten Cate JW, et al. Thromboprophylaxis in hip fracture surgery: A pilot study comparing danaparoid, enoxaparin and dalteparin. Haemostasis 1999;29:310-7.
4. | Camporese G, Bernardi E, Prandoni P, et al. Low-molecular-weight heparin versus compression stockings for thromboprophylaxis after knee arthroscopy: a randomized trial. Ann Intern Med 2008;149:73-82.
5. | Enyart JJ, Jones RJ. Low-dose warfarin for prevention of symptomatic thromboembolism after orthopedic surgery. Ann Pharmacother 2005;39:1002-7.
6. | Friksson BI, Ekman S, Lindbratt S, et al. Prevention of thromboembolism with use of recombinant hirudin. Results of a double-blind, multicenter trial comparing the efficacy of desirudin (revase) with Thai of unfractionated heparin in patients having a total hip replacement. Journal of Bone and Joint Surgery - Series A 1997;79:326-33.
7. | Handoll HH, Farrar MJ, McBirnie J, et al. Heparin, low molecular weight heparin and physical methods for preventing deep vein thrombosis and pulmonary embolism following surgery for hip fractures. Cochrane database of systematic reviews (Online : Update Software) 2000.
8. | Kakkar AK, Brenner B, Dahl OE, et al. Lancet 2008;372:31-9.
9. | Kim YH, Choi IY, Park MR, et al. Deep vein thrombosis after uncemented total hip replacement. Bull Hosp Jt Dis 1997;56:133-9.
10. | Lassen MR, Ageno W, Borris LC, et al. N Engl J Med 2008;358:2776-86.
11. | Navarro-Quilis A, Castellet E, Rocha E, et al. Efficacy and safety of bemiparin compared with enoxaparin in the prevention of venous thromboembolism after total knee arthroplasty: a randomized, double-blind clinical trial. J Thromb Haemost 2003;1:425-32.
12. | Paiement GD, Wessinger SJ, Walter AC, et al. Low dose warfarin versus external pneumatic compression against venous thromboembolism following total hip replacement. J Arthroplasty 1987;2:23-6.
13. | Patel A, Couband D, Feron JM, et al. Prevention of deep venous thrombosis in arthroplastic surgery of the hip by the combination of heparinotherapy and the antithrombosis stocking. Presse medicale (Paris 1983;France.
14. | Planes A, Vochelle N, Mazas F, et al. Enoxaparin versus standard heparin in the prophylaxis of deep vein thrombosis after total hip replacement: A double-blind randomized trial. Rev Med Interne 1988;9:327-33.
15. | Rader CP, Kramer C, Hendrich C, et al. Experiences with an ankle joint moving device in thromboprophylaxis after total knee arthroplasty. Z Orthop Ihre 1998;136:467-70.
16. | RE-MOBILIZE Writing C, Ginsberg JS, Davidson BL, et al. Oral thrombin inhibitor dabigatran etexilate vs North American enoxaparin regimen for prevention of venous thromboembolism after knee arthroplasty surgery. J Arthroplasty 2009;24:1-9.
17. | Sevestre MA, Labarere J, Brin S, et al. Optimizing history taking for evaluating the risk of venous thromboembolism: The OPTIMEV study. J Mal Vasc 2005;30:217-27.
18. | The German Hip Arthroplasty Trial,Group. Prevention of deep vein thrombosis with low molecular-weight heparin in patients undergoing total hip replacement. Arch Orthop Trauma Surg 1992;111:110-20.
19. | Tian H, Song F, Zhang K, et al. Efficacy and safety of aspirin in prevention of venous thromboembolism after total joint arthroplasty. National Medical Journal of China 2007;87:3349-52.
20. | Turpie AG, Lassen MR, Davidson BL, et al. Lancet 2009;373:1673-80.
21. | Welin-Berger T, Bygdeman S, Mebius C. Deep vein thrombosis following hip surgery. Relation to activated factor X inhibitor activity: effect of heparin and dextran. Acta Orthop Scand 1982;53:937-45.
Excluded as a publication prior to 1980 (n=4)
22. | Hull RD, Raskob GE, Gent M, et al. Effectiveness of intermittent pneumatic leg compression for preventing deep vein thrombosis after total hip replacement. J Am Med Assoc 1990;263:2313-7.
23. | Lahnborg G. Effect of low-dose heparin and dihydroergotamine on frequency of postoperative deep-vein thrombosis in patients undergoing post-traumatic hip surgery. Acta Chir Scand 1980;146:319-22.
24. | Paiement GD, Schutzer SF, Wessinger SJ, et al. Influence of prophylaxis on proximal venous thrombus formation after total hip arthroplasty. J Arthroplasty 1992;7:471-5.
25. | Sarmiento A, Goswami AD. Thromboembolic prophylaxis with use of aspirin, exercise, and graded elastic stockings or intermittent compression devices in patients managed with total hip arthroplasty. J Bone Joint Surg Am 1999;81:339-46.
Excluded because citation was not a full text systematic review, study or trial (n=196)
26. | Abdool-Carrim T, Adler H, Becker P, et al. The cost and benefit of prophylaxis against deep vein thrombosis in elective hip replacement. DVT/PE Prophylaxis Consensus Forum. SAMJ, S Afr med j 1997;87:594-600.
27. | Adequate prophylaxis reduces deaths from venous thromboembolism. Drugs and Therapy Perspectives 1996;8:11-3.
28. | Agnelli G, Cimminiello C. Prevention of venous thromboembolism in orthopedic surgery and traumatology. Recenti Prog Med 2007;98:25S-32S.
29. | Agnelli G, Sonaglia F. Clinical status of direct thrombin inhibitors. Crit Rev Oncol 1999;31:97-117.
30. | Agudelo JF, Morgan SJ, Smith WR. Venous thromboembolism in orthopedic trauma patients. Orthopedics 2005;28:1164-71.
31. | Ahmed A. Prevention of deep vein thrombosis and pulmonary embolism in the perioperative period: A review. Journal of the Pakistan Medical Association 2005;55:343-7.
32. | Alexander P, Giangola G. Deep venous thrombosis and pulmonary embolism: Diagnosis, prophylaxis, and treatment. Ann Vasc Surg 1999;13:318-27.
33. | Alhenc-Gelas M. Heparin induced thrombocytopenia: Is it over? Revue Francophone des Laboratoires 2008;38:12-4.
34. | Anbar M. Shifting from phenomenological thermography to pathophysiology based thermal imaging. IEEE Engineering in Medicine and Biology Magazine 1998;17:25-33.
35. | Andreozzi GM, Mannucci P, Nuzzaci G, et al. Linee-guida per la diagnosi e il trattamento della trombosi venosa profonda. Minerva Cardioangiol 2000;48:201-75.
36. | Annemans L, Minjoulat-Rey MC, De Knock M, et al. Cost consequence analysis of fondaparinux versus enoxaparin in the prevention of venous thromboembolism after major orthopaedic surgery in Belgium. Acta Clin Belg 2004;59:346-57.
37. | Archibeck MJ, White Jr. RE. What's new in adult reconstructive knee surgery. Journal of Bone and Joint Surgery - Series A 2005;87:1656-66.
38. | Ardeparin and danaparoid for prevention of deep vein thrombosis. Med Lett Drugs Ther 1997;39:94-5.
39. | Arora VM, McGory ML, Fung CH. Quality indicators for hospitalization and surgery in vulnerable elders. J Am Geriatr Soc 2007;55.
40. | Barrellier MT. Thromboprophylaxis and total hip replacement: A cost-efficacy study comparing duplex screening of asymptomatic venous thrombosis versus prolonged prophylaxis with low-molecular-weight heparins. Phlebology 2002;17:93-7.
41. | Bauer KA, Eriksson BI, Lassen MR, et al. Influence of the duration of fondaparinux prophylaxis in preventing venous thromboembolism following hip fracture surgery. Blood 2002;100.
42. | Berger R. Comparing options for preventing PE: Pneumatic compression vs anticoagulation. J Crit Illn 2001;16:9-11.
43. | Bergqvist D. Inferior vena cava filters. World J Surg 2007;31:265-6.
44. | Bergqvist D, Jonsson B. Cost-effectiveness of prolonged out-of-hospital prophylaxis with low-molecular-weight heparin following total hip replacement. Haemostasis 2000;30:130-5.
45. | Berry DJ. DVT prophylaxis after THA is safe and effective. Orthopedics 2000;23:1028-30.
46. | Bjorvatn A, Kristiansen F. Fondaparinux sodium compared with enoxaparin sodium: a cost-effectiveness analysis. Am J Cardiovasc Drugs 2005;5:121-30.
47. | Borris LC, Hauch O, Jorgensen LN, et al. Low molecular weight heparin (Enoxaparin) versus Dextran 70 in the prevention of postoperative deep vein thrombosis after total hip replacement: A Danish multicenter study [Abstract]. Acta Orthop Scand 1990;61:52.
48. | Borris LC, Petersen MB, Lassen MR. Prevention of thrombosis in hip alloplasty. Ugeskr Laeger 2001;163:934-5.
49. | Botteman MF, Caprini J, Stephens JM, et al. Results of an economic model to assess the cost-effectiveness of enoxaparin, a low-molecular-weight heparin, versus warfarin for the prophylaxis of deep vein thrombosis and associated long-term complications in total hip replacement surgery in the United States. Clin Ther 2002;24:1960-86.
50. | Bouee S, Zufferey P, Fagnani F. Budget impact analysis of Pradaxa thromboprophylaxis after total hip or total knee replacement. Therapie 2009;64:249-57.
51. | Brand RA. 50 Years ago in CORR: Postspinal anesthesia osteomyelitis of the lumbar spine P. L. Day MD and J. J. Hinchey MD CORR 1958;11:185-193. Clin Orthop 2008;466:1755-6.
52. | Capri S, Ageno W, Imberti D, et al. Extended prophylaxis of venous thromboembolism with fondaparinux in patients undergoing major orthopaedic surgery in Italy: A cost-effectiveness analysis. Internal and Emergency Medicine 2010;5:33-40.
53. | Caprini JA, Arcelus JI, Kudrna JC, et al. Cost-effectiveness of venous thromboembolism prophylaxis after total hip replacement. Phlebology 2002;17:126-33.
54. | Chard R. Perioperative prevention of deep vein thrombosis. AORN J 2009;90:119-20.
55. | Chard R, Maxwell-Downing D, Mitchell S, et al. The Best of Clinical Issues. AORN J 2009;90.
56. | Cheng JW. Fondaparinux: a new antithrombotic agent. Clin Ther 2002;24:1757-69.
57. | Chesser TJS, Hammett RB, Norton SA. Orthopaedic trauma in the obese patient. Injury 2010;41:247-52.
58. | Chilov MN, Cameron ID, March LM. Evidence-based guidelines for fixing broken hips: An update. Med J Aust 2003;179:489-93.
59. | Clagett GP, Anderson Jr. FA, Geerts W, et al. Prevention of venous thromboembolism. Chest 1998;114.
60. | Clagett GP, Anderson Jr. FA, Levine MN, et al. Prevention of venous thromboembolism. Chest 1992;102.
61. | Cohen AT, Hirst C, Sherrill B, et al. Meta-analysis of trials comparing ximelagatran with low molecular weight heparin for prevention of venous thromboembolism after major orthopaedic surgery. Br J Surg 2005;92:1335-44.
62. | Colwell Jr. CW. Dosing and timing of low-molecular-weight heparin thromboprophylaxis in total hip arthroplasty. Orthopedics 2003;26:1155-61.
63. | Colwell CW,Jr. Consortium data: comparative efficacy of low molecular weight heparin and warfarin following total hip replacement. Orthopedics 1995;18:21-3.
64. | Colwell CW. DVT prevention: Mobile compression device vs low-molecular-weight heparin. Orthopedics 2010;33.
65. | Colwell CW,Jr, Paiement G, Pellegrini VD,Jr, et al. Advances in the prevention of venous thromboembolic disease in orthopaedics: the introduction of LMWH. Contemp Orthop 1993;27:551-77.
66. | Crutcher J, Stickney J, Miller B. Comparison of enoxaparin and warfarin for prevention of DVT after total hip arthroplasty [Abstract]. Orthopaedic Transactions 1997;21:693.
67. | Cushner F. Deep vein thrombosis - Concepts and controversy. Orthopedics 2008;31.
68. | Dahl OE, Pleil AM. Investment in prolonged thromboprophylaxis with dalteparin improves clinical outcomes after hip replacement. J Thromb Haemost 2003;1:896-906.
69. | Dalen JE. Pulmonary embolism: what have we learned since virchow: natural history, pathophysiology, and diagnosis. Chest 2002;122:1440-1456.
70. | Dalen JE. Pulmonary embolism: What have we learned since virchow? Treatment and prevention. Chest 2002;122:1801-17.
71. | Davies RR, Coady MA, Hammond GL, et al. Low molecular weight heparin: An evaluation of current and potential clinical utility in surgery. International Journal of Angiology 1999;8:203-15.
72. | Detournay B, Planes A, Vochelle N, et al. Cost effectiveness of a low-molecular-weight heparin in prolonged prophylaxis against deep vein thrombosis after total hip replacement. Pharmacoeconomics 1998;13:81-9.
73. | Devlin JW, Petitta A, Shepard AD, et al. Cost-effectiveness of enoxaparin versus low-dose heparin for prophylaxis against venous thrombosis after major trauma. Pharmacotherapy 1998;18:1335-42.
74. | Dihydroergotamine/heparin in the prevention of deep-vein thrombosis after total hip replacement. J Bone Joint Surg Am 1989;71:311-2.
75. | Dobesh PP. Novel concepts: emerging data and the role of extended prophylaxis following hip fracture surgery. Am J Health-Syst Pharm 2003;60:S15-9.
76. | Dranitsaris G, Stumpo C, Smith R, et al. Extended dalteparin prophylaxis for venous thromboembolic events: cost-utility analysis in patients undergoing major orthopedic surgery. Am J Cardiovasc Drugs 2009;9:45-58.
77. | Eikelboom JW, Weitz JI. New oral anticoagulants for thromboprophylaxis in patients having hip or knee arthroplasty. BMJ 2011;342:7270.
78. | Enneking FK, Chan V, Greger J, et al. Lower-extremity peripheral nerve blockade: Essentials of our current understanding. Reg Anesth Pain Med 2005;30:4-35.
79. | Eriksson B. The PENTHIFRA study: Comparison of the first synthetic Factor Xa inhibitor with low molecular weight heparin (LMWH) for the prevention of venous thromboembolism (VTE) after hip fracture surgery. Blood 2000;96:-Abstract.
80. | Eriksson BI. A multicenter, randomized, placebo-controlled, double-blind study of fondaparinux for the prolonged prevention of venous thromboembolism in hip fracture surgery. Abstracts of the Sicot/Sirot XXII World Congress 2002;318p.
81. | Eriksson BI, Dahl OE, van Dijk CN, et al. A New Oral Aniticoagulant, Dabigatran Etexilate, Is Effective and Safe in Preventing Venous Thromboembolism after Total Knee Replacement Surgery (The RE-MODEL Trial) [abstract]. Blood 2006;108:173.
82. | Eriksson BI, Eriksson E, Wadenvik H, et al. Comparison of low molecular weight heparin and unfractionated heparin in prophylaxis of deep vein thrombosis and pulmonary embolism in total hip replacement. Thromb Haemost 1989;62:470-Abstract.
83. | Eriksson BI, Lassen MR. Consistency of efficacy of extended thromboprophylaxis with fondaparinux (Arixtra) in prevention of venous thromboembolism (VTE) after hip fracture surgery according to different composite efficacy endpoints: the PENTHIFRA-PLUS study. Journal of Thrombosis & Haemostasis 2003;1:Abstract.
84. | Fitzgerald RH,Jr. Preventing DVT following total knee replacement: a review of recent clinical trials. Orthopedics 1995;18:10-1.
85. | Fordyce MJF, Ling RSM. The prevention of deep vein thrombosis following total hip replacement by use of the A-V impulse system: Artificial stimulation of the physiological venous foot pump [Abstract]. Journal of Bone and Joint Surgery - British Volume 1992;74 Suppl 2:156-7.
86. | Francis CW, Pellegrini Jr. VD, Leibert KM, Totterman S, Azodo MV, Harris CM, Cox C,Marder V.J. Comparison of two warfarin regimens in the prevention of venous thrombosis following total knee replacement. Thromb Haemost 1995;73:1105-Abstract.
87. | Francis C, Pellegrini V, Marder V, et al. A prospective clinical and economic comparison of warfarin and dalteparin in prevention of deep vein thrombosis following total hip replacement. Journal of Vascular Surgery 1997;Issue:O1577.
88. | Friedman RJ, Caprini JA, Comp PC, et al. Dabigatran etexilate versus enoxaparin in preventing venous thromboembolism following total knee arthroplasty [abstract no:O-W-051]. Journal of Thrombosis & Haemostasis 2007;5.
89. | Friedman RJ, Dunsworth GA. Cost analyses of extended prophylaxis with enoxaparin after hip arthroplasty. Clin Orthop 2000;:171-82.
90. | Funk L, Cohen A, Woodcock N, et al. Comparison of the efficacy and safety of the A-V impulse system with that of enoxaparin in the prophylaxis of deep venous thrombosis in total knee arthroplasty. Journal of Bone and Joint Surgery - British Volume 2000;82:62.
91. | Garcia-Zozaya I. Warfarin vs enoxaparin for deep venous thrombosis prophylaxis after total hip & total knee arthroplasty: a cost comparison. J Ky Med Assoc 1998;96:143-8.
92. | Gillespie W, Murray D, Gregg PJ, et al. Risks and benefits of prophylaxis against venous thromboembolism in orthopaedic surgery. Journal of Bone and Joint Surgery - Series B 2000;82:475-9.
93. | González Della Valle A, Reynoso FJ, Ben Ari J, et al. The Multimodal Approach for the Prevention of Thromboembolic Disease After Total Joint Arthroplasty. Semin Arthroplasty 2009;20:241-50.
94. | Gordois A, Posnett J, Borris L, et al. The cost-effectiveness of fondaparinux compared with enoxaparin as prophylaxis against thromboembolism following major orthopedic surgery. J Thromb Haemost 2003;1:2167-74.
95. | Grover VK, Saini D, Bharti N. Deep venous thrombosis: Prophylaxis. Journal of Anaesthesiology Clinical Pharmacology 2008;24:3-12.
96. | Gurney JW. No fooling around: direct visualization of pulmonary embolism. Radiology 1993;188:618-619.
97. | Haentjens P. Post-hospital discharge prevention of deep vein thrombosis with nadroparin calcium after elective total hip replacement. The Belgian Nadroparin Post-Hospital Discharge in Orthopedics (NPHDO) Study Group. Br-J-Anaesth 1999;82 Suppl 1:78.
98. | Haentjens P, De Groote K, Annemans L. Prolonged enoxaparin therapy to prevent venous thromboembolism after primary hip or knee replacement. A cost-utility analysis. Arch Orthop Trauma Surg 2004;124:507-17.
99. | Haentjens P, on behalf of the Bellgian Nadroparin PostHospital Discharge in Orthopedics Study,Group. Post-hospital discharge prevention of deep vein thrombosis with nadroparin calcium after elective total hip replacement. Haemostasis 1998;28:292.
100. | Hauch O, Khattar SC, Jorgensen LN. Cost-benefit analysis of prophylaxis against deep vein thrombosis in surgery. Semin Thromb Hemost 1991;17:280-3.
101. | Hauer W, Sinz G, Niessner H. Hirudin versus enoxaparin as prophylaxis of venous thromboembolism in patients undergoing total hip replacement [abstract]. Ann Hematol 1997;74 Suppl 2:A130.
102. | Hawkins DW, Langley PC, Krueger KP. A pharmacoeconomic assessment of enoxaparin and warfarin as prophylaxis for deep vein thrombosis in patients undergoing knee replacement surgery. Clin Ther 1998;20:182-95.
103. | Hawkins DW, Langley PC, Krueger KP. Pharmacoeconomic model of enoxaparin versus heparin for prevention of deep vein thrombosis after total hip replacement. Am J Health-Syst Pharm 1997;54:1185-90.
104. | Heit J, Berkowitz S, Bona R, et al. Efficacy and safety of normiflo (a LMWH) compared to wafarin for prevention of venous thromboembolism following total knee replacement: a double-blind, dose-ranging study. Thromb Haemost 1995;73:978-Abstract.
105. | Howard AW, Aaron SD. Low molecular weight heparin is efficacious as DVT prophylaxis following total knee arthroplasty - a meta-analysis of randomized controlled trials [Abstract]. Journal of Bone and Joint Surgery-British Volume 1999;81 Suppl 1:104.
106. | Howard PA. Dalteparin: a low-molecular-weight heparin. Ann Pharmacother 1997;31:192-203.
107. | Hull RD. New insights into extended prophylaxis after orthopaedic surgery - the North American Fragmin Trial experience. Haemostasis 2000;30:95-100.
108. | Hull RD, Pineo GF, MacIsaac S. Low-molecular-weight heparin prophylaxis: preoperative versus postoperative initiation in patients undergoing elective hip surgery. Thromb Res 2001;101:155-62.
109. | Hull RD, Raskob G, Pineo GF, et al. Subcutaneous low-molecular-weight heparin (LMWH) versus warfarin sodium (WS) for prophylaxis of deep-vein thrombosis (DVT) after total hip or total knee replacement (THR/TKR): an economic perspective. Blood 1994;84:70a.
110. | Hull RD, Raskob GE, Pineo GF, et al. Subcutaneous low-molecular-weight heparin (LMWH) versus warfarin sodium (WS) for prophylaxis of deep-vein thrombosis (DVT) after total hip or total knee replacement (THR/TKR): An economic perspective. Journal of Vascular Surgery 1997;Issue:O1579.
111. | Jaffe D, Noff M, Peer A, et al. Prophylaxis against deep-vein thrombosis in total knee replacement: comparison of low molecular weight heparin and the A-V Impulse System. Journal of bone and joint surgery British volume 1999;81:71.
112. | Kaboli PJ. Using elastic compression stockings to prevent post-thrombotic syndrome. Journal of Respiratory Diseases 2008;29:100.
113. | Kalodiki E, Nicolaides A, AlKutoubi A, et al. Low molecular weight heparin (LMWH) and LMWH plus graduated elastic compression for deep venous thrombosis (DVT) prophylaxis in total hip replacement. Thromb Haemost 1993;69:650-Abstract.
114. | Kahn SR. Natural history of postthrombotic disease: Transition from acute to chronic disease. J Vasc Surg 2010;52:62S-64S.
115. | Kalodiki E, Nicolaides AN, AlKutoubi A, et al. LMWH and LMWH plus graduated elastic compression for DVT prophylaxis in total hip replacement. Thromb Haemost 1993;69:619-Abstract.
116. | Kearon C, Hirsh J. Management of venous thromboembolism. N Engl J Med 1997;336:1506-11.
117. | Kennon RE, Keggi JM, Wetmore RS, et al. Total hip arthroplasty through a minimally invasive anterior surgical approach. Journal of Bone and Joint Surgery - Series A 2003;85:39-48.
118. | Kimura S. Perioperative measures of total knee arthroplasty. Hokkaido Journal of Orthopaedics and Traumatology 2009;50:185-9.
119. | Koss S, Dunn E. Enoxaparin versus adjusted dose heparin in the prevention of deep vein thrombosis after a total hip replacement [Abstract]. Orthopaedic Transactions 1996;20:221.
120. | Kurth AA, Dahl OE, vanDijk CN, et al. A new oral anticoagulant, dabigatran etexilate, is effective and safe for the prevention of venous thromboembolism after total knee replacement. The Journal of Bone and Joint Surgery 2009;91-B:74.
121. | Kwong L, Diamantopoulos A, Forster F, et al. Will Rivaroxaban Be Cost-Effective for Prevention of Venous Thromboembolism after Total Hip Replacement in US Patients [Abstract No. 1290]. Blood 2008;112:467.
122. | Kwong L, Lees M, Sengupta N. Rivaroxaban for Prevention of Venous Thromboembolism after Total Knee Arthroplasty: Impact on Healthcare Costs Based on the RECORD3 Study. Blood 2007;110.
123. | Kwong L, Sengupta N, Lees M. Rivaroxaban for Prevention of Venous Thromboembolism after Total Knee Replacement: Impact on Healthcare Costs Based on the RECORD4 Study [Abstract No. 1289]. Blood 2008;112:466.
124. | Kwong LM, Muntz JE. Thromboprophylaxis dosing: the relationship between timing of first administration, efficacy, and safety. Am J Orthop 2002;31:16-20.
125. | Lassen MR. Comparative efficacy of low-molecular-weight heparins in orthopedic surgery. Semin Thromb Hemost 2000;26:53-6.
126. | Lassen MR, Turpie AG, Rosencher N, et al. Rivaroxaban: An oral, direct factor Xa inhibitor for the prevention of venous thromboembolism in total knee replacement surgery - Results of the RECORD 3 study.
127. | Lassen MR, Turpiew AGG, Rosencherz N, et al. The oral, direct factor Xa inhibitor rivaroxaban vs enoxaparin for prevention of venous thromboembolism after total knee replacement: RECORD3. Br J Haematol 2008;141:50-1.
128. | Le Balc'h T, Landais A, Butel J, et al. Enoxaparine (Lovenox(R)), versus standard heparin in prophylaxis of deep vein thrombosis (DVT) after total hip replacement (THR) [Abstract]. Thromb Haemost 1987;58:241.
129. | Leclerc JR, Geerts WH, Desjardins L. Prevention of venous thromboembolism (VTE) after knee arthroplasty - a randomized, double-blind trial, comparing a low molecular weight heparin fragment (enoxaparin) to warfarin. Blood 1994;84:246a-Abstrat.
130. | Leclerc JR, Geerts WH, Desjardins L, et al. Prevention of venous thromboembolism (VTE) after knee arthroplasty - A randomized, double-blind trial, comparing a low molecular weight heparin fragment (enoxaparin) to warfarin. Thromb Haemost 1995;73:1103-Abstract.
131. | Levin LA, Horst M, Bergqvist D. Economic evaluation of desirudin vs heparin in deep vein thrombosis prevention after hip replacement surgery. Pharmacoeconomics 1998;13:111-8.
132. | Levine MN, Gent M, Hirsh J. Ardeparin plus graduated compression stockings prevented DVT after knee surgery. Evidence-Based Medicine 1996;1:213.
133. | Lieberman JR, Barnes CL, Lachiewicz PF, et al. Venous thromboembolism debate in joint arthroplasty. J Bone Joint Surg Am 2009;91:29-32.
134. | Lieberman JR, Huo MM, Hanway J, et al. A comparison of pneumatic compression boots and aspirin versus aspirin alone in prevention of deep venous thrombosis after total hip arthroplasty: A randomized prospective trial [Abstract]. Orthopaedic Transactions 1992;16:712-3.
135. | Lipp H-. Heparins, heparinoids and hirudin derivatives. Prophylaxis and therapy of venous thromboembolism. Krankenhauspharmazie 1999;20:317-32.
136. | Livesley E. The A-V impulse system. Physiotherapy 1997;83:417-8.
137. | Lobo BL. Emerging options for thromboprophylaxis after orthopedic surgery: a review of clinical data. Pharmacotherapy 2004;24:66S-72S.
138. | Lotke PA. Aspirin prophylaxis for thromboembolic disease after total joint arthroplasty. Am J Orthop 2007;36:14-5.
139. | Lundkvist J, Bergqvist D, Jonsson B. Cost-effectiveness of extended prophylaxis with fondaparinux compared with low molecular weight heparin against venous thromboembolism in patients undergoing hip fracture surgery. Eur J Health Econ 2007;8:313-23.
140. | Lyne E, O'Meara PM. Prophylaxis for venous thromboembolism in total hip arthroplasty [1]. Orthopedics 1991;14:226,227+230.
141. | Mak JCS, Cameron ID, March LM. Evidence-based guidelines for the management of hip fractures in older persons: An update. Med J Aust 2010;192:37-41.
142. | Marchetti M, Liberato NL, Ruperto N, et al. Long-term cost-effectiveness of low molecular weight heparin versus unfractionated heparin for the prophylaxis of venous thromboembolism in elective hip replacement. Haematologica 1999;84:730-7.
143. | McCullagh L, Tilson L, Walsh C, et al. A cost-effectiveness model comparing rivaroxaban and dabigatran etexilate with enoxaparin sodium as thromboprophylaxis after total hip and total knee replacement in the irish healthcare setting. Pharmacoeconomics 2009;27:829-46.
144. | McLafferty RB. Evidence of prevention and treatment of postthrombotic syndrome. J Vasc Surg 2010;52:69S-73S.
145. | Menzin J, Colditz GA, Regan MM, et al. Cost-effectiveness of enoxaparin vs low-dose warfarin in the prevention of deep-vein thrombosis after total hip replacement surgery. Arch Intern Med 1995;155:757-64.
146. | Mol WE, Egberts TC. Prophylaxis for venous thromboembolism in hip fracture surgery: total costs and cost effectiveness in The Netherlands. Pharmacoeconomics 1994;5:48-55.
147. | More effective, simpler-to-use clot-buster is on the way. Clot-prevention drug could save lives after joint replacement. Duke Med Health News 2008;14:6.
148. | Morris RJ, Woodcock JP. Evidence-Based Compression: Prevention of Stasis and Deep Vein Thrombosis. Ann Surg 2004;239:162-71.
149. | Mueck W, Borris LC, Dahl OE, et al. Population pharmacokinetics and pharmacodynamics of once- and twice-daily rivaroxaban for the prevention of venous thromboembolism in patients undergoing total hip replacement. Thromb Haemost 2008;100:453-61.
150. | Nerurkar J, Wade WE, Martin BC. Cost/death averted with venous thromboembolism prophylaxis in patients undergoing total knee replacement or knee arthroplasty. Pharmacotherapy 2002;22:990-1000.
151. | Obalum DC, Giwa SO, Adekoya-Cole TO, et al. Deep vein thrombosis: Risk factors and prevention in surgical patients. West Afr J Med 2009;28:77-82.
152. | Olsen J, Gundgaard J, Borris LC. [The cost-effectiveness of fondaparinux compared to enoxaparin as prophylaxis for deep-vein thrombosis in Denmark]. Ugeskr Laeger 2005;167:2273-9.
153. | Ooy A, Hamulyak K. The 'froac trial' - low molecular heparin (LMWH) versus oral anticoagulants (OAC) for prevention of deep venous thrombosis (DVT) in elective hip and knee prosthesis implantations [abstract]. Acta Orthop Scand 1995;66:65.
154. | Palla A, Manganelli D, Rossi G. Prolonged prophylaxis with unfractioned heparin (UH) is effective to reduce delayed deep vein thrombosis (DVT) in total hip replacement (THR). European Respiratory Journal 1997;10:5S.
155. | Pechlaner C, Marschang P. Dabigatran versus enoxaparin after total hip replacement. Lancet 2007;370:2002.
156. | Pellegrini VD, Totterman S, Ayers DC, et al. Comparison of a low molecular weight heparin and warfarin in prevention of deep vein thrombosis after total hip arthroplasty [Abstract]. Orthopaedic Transactions 1997;21:520-1.
157. | Pineo GF, Hull RD, Raskob GE, et al. Subcutaneous low-molecular-weight heparin (LMWH) versus warfarin sodium (WS) for prophylaxis of deep-vein thrombosis (DVT) after total hip or total knee replacement (THR/TKR): An economic perspective. Sangre 1995;40:250.
158. | Planes A, Chastang C, Vochelle N, et al. An equivalence study of two low-molecular-weight heparins (LMWH) in the prevention of deep vein thrombosis (DVT), after total hip replacement (THR) (440 patients). Thromb Haemost 1993;69:651-Abstract.
159. | Planes A, Vochelle N, Fagola J, et al. Efficacy and safety of enoxaparin in prevention of deep venous thrombosis after total hip replacement under spinal anesthesia. Comparison with general anesthesia. Thromb Haemost 1989;62:489-Abstract.
160. | Planes A, Vochelle N, Ferru J, et al. Enoxaparin, low molecular weight heparin: its use in prevention of deep venous thrombosis following total hip replacement. Thromb Haemost 1985;54:319-Abstract.
161. | Preventing blood clots after knee arthroscopy. Ann Intern Med 2008;149:40.
162. | Prevention of venous thrombosis after total hip replacement. N Engl J Med 1984;310:927-8.
163. | Rangarajan S. Inhibitors of coagulation. Haemophilia 2011;17:90-94.
164. | Ranze O, Greinacher A, Hohlfeld RR, et al. Aktuelle Behandlungskonzepte bei Heparin-induzierterThrombozytopenie. Dtsch Med Wochenschr 1999;124:865-73.
165. | Ruiz Manzano J, Alberich P, Blanquer J, et al. Normativa de profilaxis de la enfermedad tromboembólica venosa. Arch Bronconeumol 1996;32:348-56.
166. | Salvati EA. Thromboembolism after THR: prophylaxis and treatment. Orthopedics 1995;18:838-41.
167. | Samama C-. Épidémiologie de la thrombose veineuse péri-opératoire : Précisions sur les différents niveaux de risque. Medecine Therapeutique 1996;2:340-4.
168. | Sarasin FP, Bounameaux H. Out of hospital antithrombotic prophylaxis after total hip replacement: low-molecular-weight heparin, warfarin, aspirin or nothing? A cost-effectiveness analysis. Thromb Haemost 2002;87:586-92.
169. | Sarasin FP, Bounameaux H. Antithrombotic strategy after total hip replacement. A cost-effectiveness analysis comparing prolonged oral anticoagulants with screening for deep vein thrombosis. Arch Intern Med 1996;156:1661-8.
170. | Schulz SL, Stechemesser B, Seeberger U, et al. Graduated compression stockings for the prevention of venous thromboembolism in surgical patients in the age of low molecular weight heparins [10]. Journal of Thrombosis and Haemostasis 2005;3:2363-5.
171. | Schwartsmann CR, Teloken Drummond SN, Costa RC. Prophylaxis of deep venous thrombosis after total hip replacement: A randomized trial comparing low molecular weight heparin and unfractioned heparin [Poster]. Final programme of 20th World Congress SICOT.Vol.Final programme, pp.486, 1996.
172. | Scott IA, Lodge RS, Russell DM. Evidence-based guide to perioperative medicine. Intern Med J 2007;37:389-401.
173. | Sculco TP, Colwell Jr. CW, Pellegrini Jr. VD, et al. Prophylaxis against venous thromboembolic disease in patients having a total hip or knee arthroplasty. Journal of Bone and Joint Surgery - Series A 2002;84:466-77.
174. | Sen RK, Kumar A. Venous thrombo-embolism in orthopaedics. J Indian Med Assoc 2010;108:215-220.
175. | Sharrock NE, Brien WW, Salvati EA, et al. The effect of intravenous fixed-dose heparin during total hip arthroplasty on the incidence of deep-vein thrombosis. Journal of Vascular Surgery 1992;15:1089.
176. | Shorr AF, Ramage AS. Enoxaparin for thromboprophylaxis after major trauma: Potential cost implications. Crit Care Med 2001;29:1659-65.
177. | Silbersack Y, Taute BM, Hein W, et al. Prophylactic use of LMWH plus intermittent pneumatic compression prevented DVT in hip or knee arthroplasty. Evidence-Based Medicine 2005;10:48.
178. | Skedgel C, Goeree R, Pleasance S, et al. The cost-effectiveness of extended-duration antithrombotic prophylaxis after total hip arthroplasty. J Bone Joint Surg Am 2007;89:819-28.
179. | Spruill WJ, Wade WE, Leslie RB. Cost analysis of fondaparinux versus enoxaparin as venous thromboembolism prophylaxis in elective hip replacement surgery. Blood Coagul Fibrinolysis 2004;15:539-43.
180. | Spruill WJ, Wade WE, Leslie RB. A cost analysis of fondaparinux versus enoxaparin in total knee arthroplasty. Am J Ther 2004;11:3-8.
181. | Sullivan SD, Kwong L, Nutescu E. Cost-effectiveness of fondaparinux compared with enoxaparin as prophylaxis against venous thromboembolism in patients undergoing hip fracture surgery. Value Health 2006;9:68-76.
182. | Ten Cate JW. Prevention of deep vein thrombosis following total hip replacement surgery by Orgaran. Summary. Haemostasis 1992;22:109-11.
183. | Thomas DP. Thromboprophylaxis after replacement arthroplasty. Br Med J 2001;322:686-7.
184. | Thomas DP. Whither thromboprophylaxis after total hip replacement? Journal of Bone and Joint Surgery - Series B 2000;82:469-72.
185. | Thomas S, Phillips P, Hughes G. CLOTS: an opportunity missed. The Lancet 2009;374:1143.
186. | Thrombin inhibitor shows stable safety profile in the practice. MMW Fortschr Med 2008;150:38-9.
187. | Tran AH, Lee G. Fondaparinux for prevention of venous thromboembolism in major orthopedic surgery. Ann Pharmacother 2003;37:1632-43.
188. | Tribout B, Colin-Mercier F. New versus established drugs in venous thromboprophylaxis: efficacy and safety considerations related to timing of administration. Am J Cardiovasc Drugs 2007;7:1-15.
189. | Turpie AG. Venous thromboembolism prophylaxis: role of factor xa inhibition by fondaparinux. Surg Technol Int 2004;13:261-7.
190. | Turpie AG. Efficacy of a postoperative regimen of enoxaparin in deep vein thrombosis prophylaxis. Am J Surg 1991;161:532-6.
191. | Turpie AG. Low molecular weight heparins: deep vein thrombosis prophylaxis in elective hip surgery and thrombotic stroke. Acta Chir Scand Suppl 1988;543:85-6.
192. | Turpie AG, Kher A. Prevention of venous thrombosis after elective hip surgery. Orthopedics 1998;21:1275-81.
193. | Urbankova J, Quiroz R, Goldhaber SZ. Intermittent pneumatic compression and deep vein thrombosis prevention in postoperative patients. Phlebology 2006;21:19-22.
194. | Van Ooy A. The "Focal" trial. Low molecular heparin (LMWH) versus oral anticoagulants (OAC) in the prevention of deep venous thrombosis (DVT) in elective hip- and knee prosthesis implants [Abstract]. Nederlands Tijdschrift voor Orhopaedie 1995;2:30.
195. | Verhaeghe R, Verstraete M. Prophylaxis of Venous Thromboembolism in Surgery. Acta Chir Belg 1997;:106-9.
196. | Wade WE. Cost analysis of ardeparin versus enoxaparin for the prophylaxis of deep vein thrombosis after knee arthroplasty. Clin Ther 1998;20:347-51.
197. | Wade WE, Hawkins DW. Cost effectiveness of outpatient anticoagulant prophylaxis after total hip arthroplasty. Orthopedics 2000;23:335-8.
198. | Wade WE, Spruill WJ, Leslie RB. Cost analysis of fondaparinux versus enoxaparin as venous thromboembolism prophylaxis in hip fracture surgery. Am J Ther 2004;11:194-8.
199. | Wade WE, Spruill WJ, Leslie RB. Cost analysis: fondaparinux versus preoperative and postoperative enoxaparin as venous thromboembolic event prophylaxis in elective hip arthroplasty. Am J Orthop 2003;32:201-5.
200. | Warwick D, Bannister G. Does a 3 day peri-operative course of low molecular weight heparin reduce deep venous thrombosis after total hip replacement? Journal of Bone and Joint Surgery - British Volume 1995;77-B:173.
201. | Warwick D, Harrison J. Pneumatic plantar compression versus low molecular weight heparin in the prevention of deep vein thrombosis after total hip replacement [abstract]. Journal of Bone and Joint Surgery - British Volume 1997;79 Suppl 2:259.
202. | Warwick D, Harrison J, Mitchelmore A, et al. Foot pump versus LMWH in the prevention of DVT after THR [abstract]. Journal of Bone and Joint Surgery - British Volume 2000;82 Suppl 2:159-60.
203. | Warwick D, Mitchelmore A. Is a short peri-operative course of low molecular weight heparin effective in preventing deep venous thrombosis after total hip replacement? [abstract]. Journal of Bone and Joint Surgery - British Volume 1994;76-B Suppl II, III:151.
204. | Warwick D, Samama MM. The contrast between venographic and clinical endpoints in trials of thromboprophylaxis in hip replacement. Journal of Bone and Joint Surgery - Series B 2000;82:480-2.
205. | Warwick DJ, Harrison J, Whitehouse SL, et al. Pneumatic plantar compression versus low molecular weight heparin for the prevention of deep vein thrombosis after total knee replacement [abstract]. Journal of Bone and Joint Surgery - British Volume 1999;81 Suppl 2:210.
206. | Webb MS, Murphy TP, Dorfman GS. Use and selection of inferior vena cava filters. Seminars in Respiratory and Critical Care Medicine 1996;17:71-85.
207. | Weinmann EE, Salzman EW. Trombosis venosa profunda. Rev Cubana Med 1996;35:118-35.
208. | Wells P, Diamantopoulos A, Forster F, et al. Cost-Effectiveness of Rivaroxaban as VTE Prophylaxis after Total Hip Replacement in Canada [Abstract No. 1291]. Blood 2008;112:467.
209. | Westrich GH, Sculco TP. Pneumatic plantar compression compared with aspirin for deep venous thrombosis prophylaxis after total knee arthroplasty [Abstract]. Orthopaedic Transactions 1996;20:398.
210. | Wienert V, Altenkämper H, Berg D, et al. Leitlinien zur apparativen intermittierenden Kompression (AIK). Phlebologie 1998;27:96-7.
211. | Wienert V, Altenkämper H, Berg D, et al. Leitlinien zur apparativen intermittierenden Kompression (AIK). Phlebologie 1996;25:211-2.
212. | Wilke T, Neumann K, Klapper U, et al. [Oral anticoagulation after major hip or knee replacement surgery: a process-driven managerial pharmacoeconomic analysis in German hospitals]. Orthopade 2008;37:448-56.
213. | Wille-Jørgensen P. Prophylaxis of postoperative thromboembolism with a combination of heparin and graduated compression stockings. International Angiology 1996;15:15-20.
214. | Wilson JF. In the clinic preoperative evaluation. Ann Intern Med 2009;151.
215. | Winslow KA, Hartmannsgruber MWB, Chung JH, et al. Combination of two standard pneumatic calf compression devices to fit the morbidly obese [7]. Anesthesiology 2000;93:1159.
216. | Wolowacz SE, Roskell NS, Maciver F, et al. Economic evaluation of dabigatran etexilate for the prevention of venous thromboembolism after total knee and hip replacement surgery. Clin Ther 2009;31:194-212.
217. | Wolowacz SE, Roskell NS, Plumb JM, et al. Economic evaluation of dabigatran etexilate for the prevention of venous thromboembolism in patients aged over 75 years or with moderate renal impairment undergoing total knee or hip replacement. Thromb Haemost 2010;103:360-71.
218. | Working method. Sang Thrombose Vaisseaux 2008;20:9-20.
219. | Yeung JMC, Lingam K. Flight related deep vein thrombosis. Scott Med J 2002;47:123-6.
220. | Zacharski LR, Ornstein DL. Heparin and cancer. Thromb Haemost 1998;80:10-23.
221. | Zonzin P, Agnelli G, Casazza F, et al. Comments on the guidelines of the European Society of Cardiology Task Force on Pulmonary Embolism. Italian Heart Journal Supplement 2001;2:1342-56.
Excluded because the population was not major orthopedic surgery (n=74)
222. | Antiplatelet Trialists' Collaboration. Collaborative overview of randomised trials of antiplatelet therapy-ill: reduction in venous thrombosis and pulmonary embolism by antplatelet prophylaxis among surgical and medical patients. BMY 1994;308:235-46
223. | Barrett JS, Gibiansky E, Hull RD, et al. Population pharmacodynamics in patients receiving tinzaparin for the prevention and treatment of deep vein thrombosis. Int J Clin Pharmacol Ther 2001;39:431-46
224. | Camporese G. Bernardi E. Prandoni P. Noventa F. Verlato F. Simioni P. Ntita K. Salmistraro G. Frangos C. Rossi F. Cordova R. Franz F. Zucchetta P. Kontothanassis D. Andreozzi GM. KANT (Knee Arthroscopy Nadroparin Thromboprophylaxis) Study Group. Ann Intern Med 2008;149:73-82
225. | Cohn SM, Moller BA, Feinstein AJ, et al. Prospective trial of low-molecular-weight heparin versus unfractionated heparin in moderately injured patients. Vasc Surg 1999;33:219-23
226. | Decousus H, Leizorovicz A, Parent F, Page Y, Tardy B, Girard P, Laporte S et al. A clinical trial of vena caval filters in the prevention of pulmonary embolism in patients with proximal deep-vein thrombosis. Prévention du Risque d'Embolie Pulmonaire par Interruption Cave Study Group. N Engl J Med 1998; 338:409-416
227. | Elliott CG, Dudney TM, Egger M, et al. Calf-thigh sequential pneumatic compression compared with plantar venous pneumatic compression to prevent deep-vein thrombosis after non-lower extremity trauma. Journal of Trauma - Injury, Infection and Critical Care 1999;47:25-32
228. | Eppsteiner RW, Shin JJ, Johnson J, et al. Mechanical compression versus subcutaneous heparin therapy in postoperative and posttrauma patients: A systematic review and meta-analysis. World J Surg 2010;34:10-9
229. | Ettema HB, Kollen BJ, Verheyen CC, Büller HR. Prevention of venous thromboembolism in patients with immobilization of the lower extremities: a meta-analysis of randomized controlled trials. J Thromb Haemost. 2008;6(7):1093-8
230. | Fuchs S, Heyse T, Rudofsky G, et al. Continuous passive motion in the prevention of deep-vein thrombosis. A randomised comparison in trauma patients. Journal of Bone and Joint Surgery - Series B 2005;87:1117-22
231. | Gajic O, Warner DO, Decker PA, et al. Long-haul air travel before major surgery: A prescription for thromboembolism? Mayo Clin Proc 2005;80:728-31
232. | Gangireddy C, Rectenwald JR, Upchurch GR, et al. Risk factors and clinical impact of postoperative symptomatic venous thromboembolism. Journal of Vascular Surgery 2007;45(2):335-341; discussion 341-2
233. | Geerts WH, Jay RM, Code KI, et al. A comparison of low-dose heparin with low-molecular-weight heparin as prophylaxis against venous thromboembolism after major trauma. N Engl J Med 1996;335:701-7
234. | Ginsberg JS, Brill-Edwards P, Panju A, et al. Pre-operative plasma levels of thrombin-antithrombin III complexes correlate with the development of venous thrombosis after major hip or knee surgery. Thromb Haemost 1995;74:602-5
235. | Goldhaber SZ, Visani L, De Rosa M, for ICOPER. Acute pulmonary embolism: clinical outcomes in the international cooperative pulmonary embolism registry. Lancet 1999:353:1386-1389
236. | Greenfield LJ, Proctor MC, Rodriguez JL, et al. Posttrauma thromboembolism prophylaxis. Journal of Trauma - Injury, Infection and Critical Care 1997;42:100-3
237. | Haentjens P, Blaimont, Blairon, et al. Thromboembolic propylaxis in orthopaedic trauma patients: A comparison between a fixed dose and an individually adjusted dose of a low molecular weight heparin (nadroparin calcium). Injury 1996;27:385-90
238. | Hakki SI, Fareed J, Hoppensteadt DA, et al. Plasma tissue factor pathway inhibitor levels as a marker for postoperative bleeding after enoxaparin use in deep vein thrombosis prophylaxis in orthopedics and general surgery. Clin Appl Thromb Hemost 2001;7:65-71
239. | Hakki SI, Fareed J, Hoppensteadt DA, et al. Plasma tissue factor pathway inhibitor levels as a marker for postoperative bleeding after enoxaparin use in deep vein thrombosis prophylaxis in orthopedics and general surgery. Clin Appl Thromb Hemost 2000;6:206-12
240. | Hansson P-, Eriksson H, Welin L, et al. Smoking and abdominal obesity: Risk factors for venous thromboembolism among middle-aged men: 'The study of men born in 1913'. Arch Intern Med 1999;159:1886-90
241. | Headrick JR, Barker DE, Pate LM, et al. The role of ultrasonography and inferior vena cava filter placement in high-risk trauma patients. Am Surg 1997;63:1-8
242. | Hilbert P, Zur Nieden K, Stuttmann R. [D-dimer screening in surgical long-term intensive care patients]. Anaesthesist 2005;54:210-4
243. | Howard A, Zaccagnini D, Ellis M, et al. Randomized clinical trial of low molecular weight heparin with thigh-length or knee-length antiembolism stockings for patients undergoing surgery. Br J Surg 2004;91:842-7
244. | Iskander GAP, Nelson RS, Morehouse DL, et al. Incidence and propagation of infrageniculate deep venous thrombosis in trauma patients. Journal of Trauma - Injury, Infection and Critical Care 2006;61:695-700
245. | Janni W, Bergauer F, Rjosk D, et al. [Prospective randomized study comparing the effectiveness and tolerance of various low-molecular-weight heparins in high risk patients]. Zentralbl Chir 2001;126:32-8.
246. | Jorgesen PS, Warming T, Hansen K, Paltved C, et al. Low molecular weight heparin (Innohep) as thromboprophylaxis in outpaitents with a plaster cast: a venografic controlled study. Thrombosis Research 12002;105:477-480
247. | Kakkos SK, Caprini JA, Geroulakos G, et al. Combined intermittent pneumatic leg compression and pharmacological prophylaxis for prevention of venous thromboembolism in high-risk patients. Cochrane Database of Systematic Reviews 2008;Oct 8;(4)
248. | Kakkos SK, Caprini JA, Nicolaides AN, et al. Combined modalities in the prevention of venous thromboembolism: A review of the literature. Phlebology 2006;21:23-8
249. | Kakkos SK, Daskalopoulou SS, Daskalopoulos ME, et al. Review on the value of graduated elastic compression stockings after deep vein thrombosis. Thromb Haemost 2006;96:441-5
250. | Keller ME, Metzler MH, Phillips JO, et al. Evaluation of a disease management plan for prevention and diagnosis of thromboembolic disease in major trauma patients. Curr Surg 2000;57:456-9
251. | Knesek MJ, Litinas E, Adiguzel C, et al. Inflammatory biomarker profiling in elderly patients with acute hip fracture treated with heparins. Clin Appl Thromb Hemost 2010;16:42-50
252. | Knudson MM, Lewis FR, Clinton A, Atkinson K, Megerman J. Prevention of venouos thromboembolism in trauma patients. The Journal of Trauma 1994;37:480-487
253. | Knudson MM, Morabito D, Paiement GD, et al. Use of low molecular weight heparin in preventing thromboembolism in trauma patients. Journal of Trauma - Injury, Infection and Critical Care 1996;41:446-59
254. | Kock H-J, Schmit-Neueburg KP, Hanke J, Rudofsky G, Hirche H. Thromboprophylaxis with low-molecular-weight heparin in outpatients with plaster-cast immobilisation of the leg. Lancet 1995;346:459-461
255. | Kohro S, Yamakage M, Takahashi T, et al. Intermittent pneumatic compression prevents venous stasis in the lower extremities in the lithotomy position. Canadian Journal of Anesthesia 2002;49:144-7
256. | Kosir MA, Schmittinger L, Barno-Winarski L, et al. Prospective double-arm study of fibrinolysis in surgical patients. J Surg Res 1998;74:96-101
257. | Kujath P, Spannagel U, Habscheid W. Incidence and prophylaxis of deep venous thrombosis in outpatients with injury of the lower limb. Haemostasis 1993;23:20-26
258. | Kurtoǧlu M, Büyükkurt CD, Dural AC, et al. Venous thromboembolism prophylaxis with low molecular weight heparins in polytraumatized patients in intensive care unit. Turkish Journal of Surgery 2001;17:233-42
259. | Kussmann J. [Prevention of thromboembolism with low-dose heparin]. Langenbecks Arch Chir 1986;369:473-8
260. | Laporte S, Mismetti P, Decousus H, Uresandi F, Otero R, Lobo JL, Monreal M, and the RIETE Investigators.
261. | Clinical predictors for fatal pulmonary embolism in 15,520 patients with venous thromboembolism: findings from the registro informatizado de la enfermedad tromboembolica venosa (riete) registry. Circulation. 2008;117:1711-1716
262. | Leclerc JR, Geerts WH, Desjardins L, et al. Prevention of deep vein thrombosis after major knee surgery--a randomized, double-blind trial comparing a low molecular weight heparin fragment (enoxaparin) to placebo. Thromb Haemost 1992;67:417-23
263. | Lee AD, Stephen E, Agarwal S, et al. Venous Thrombo-embolism in India. European Journal of Vascular and Endovascular Surgery 2009;37:482-5
264. | Liem TK, Huynh TM, Moseley SE, et al. Symptomatic perioperative venous thromboembolism is a frequent complication in patients with a history of deep vein thrombosis. J Vasc Surg 2010;52:651-657.
265. | Lu J-, Knudson MM, Bir N, et al. Fondaparinux for Prevention of Venous Thromboembolism in High-Risk Trauma Patients: A Pilot Study. J Am Coll Surg 2009;209:589-94
266. | Martel N, Lee J, Wells PS. Risk for heparin-induced thrombocytopenia with unfractionated and low-molecular-weight heparin thromboprophylaxis: A meta-analysis. Blood 2005;106:2710-5
267. | McMurtry AL, Owings JT, Anderson JT, et al. Increased use of prophylactic vena cava filters in trauma patients failed to decrease overall incidence of pulmonary embolism. J Am Coll Surg 1999;189:314-20
268. | Mittlmeier T. The relationship of foot and ankle movements to venous return in the lower limb. Unfallchirurg 1999;102:986-7
269. | Morris RJ, Woodcock JP. Intermittent pneumatic compression or graduated compression stockings for deep vein thrombosis prophylaxis?: A systematic review of direct clinical comparisons. Ann Surg 2010;251:393-6
270. | Murakami M, McDill TL, Cindrick-Pounds L, et al. Deep venous thrombosis prophylaxis in trauma: Improved compliance with a novel miniaturized pneumatic compression device. Journal of Vascular Surgery 2003;38:923-7
271. | Onat L, Ganiyusufoglu AK, Mutlu A, et al. Optease and trapease vena cava filters: A single-center experience in 258 patients. Cardiovasc Intervent Radiol 2009;32:992-7
272. | Pagella P, Cipolle M, Sacco E, et al. A randomized trial to evaluate compliance in terms of patient comfort and satisfaction of two pneumatic compression devices. Orthopaedic Nursing 2007;26:169-74
273. | Prandoni P, Lensing AWA, Prins MH, et al. Below-knee elastic compression stockings to prevent the post-thrombotic syndrome. A randomized, controlled trial. Ann Intern Med 2004;141:249,256+I
274. | Regier DA, Marra CA, Lynd L. Economic evaluations of anticoagulants for the prophylaxis of venous thromboembolism following major trauma. Expert Review of Pharmacoeconomics and Outcomes Research 2007;7:403-13
275. | Ricotta S, Iorio A, Parise P, et al. Post discharge clinically overt venous thromboembolism in orthopaedic surgery patients with negative venography - An overview analysis. Thromb Haemost 1996;76:887-92
276. | Roderick P, Ferris G, Wilson K, et al. Towards evidence-based guidelines for the prevention of venous thromboembolism: Systematic reviews of mechanical methods, oral anticoagulation, dextran and regional anaesthesia as thromboprophylaxis. Health Technol Assess 2005 Dec;9(49):iii-iv, ix-x, 1-78
277. | Rogers FB, Shackford SR, Ricci MA, et al. Prophylactic Vena Cava Filter Insertion in Selected High-Risk Orthopaedic Trauma Patients. J Orthop Trauma 1997;11:267-72
278. | Sachdeva A, Dalton M, Amaragiri SV, Lees T. Elastic compression stockings for prevention of deep vein thrombosis. Cochrane Database of Systematic Reviews 2010, Issue 7
279. | Sajid MS, Tai NRM, Goli G, et al. Knee versus Thigh Length Graduated Compression Stockings for Prevention of Deep Venous Thrombosis: A Systematic Review. European Journal of Vascular and Endovascular Surgery 2006;32:730-6
280. | Schädlich PK, Kentsch M, Weber M, et al. Cost effectiveness of enoxaparin as prophylaxis against venous thromboembolic complications in acutely ill medical inpatients: Modelling study from the hospital perspective in Germany. Pharmacoeconomics 2006;24:571-91
281. | Schultz DJ, Brasel KJ, Washington L, et al. Incidence of Asymptomatic Pulmonary Embolism in Moderately to Severely Injured Trauma Patients. Journal of Trauma - Injury, Infection and Critical Care 2004;56:727-33
282. | Selby R, Geerts W, Ofosu FA, et al. Hypercoagulability after trauma: Hemostatic changes and relationship to venous thromboembolism. Thromb Res 2009;124:281-7
283. | Sevestre MA, Labarere J, Brin S, et al. Optimizing history taking for evaluating the risk of venous thromboembolism: The OPTIMEV study. J Mal Vasc 2006;31:217-27
284. | Sharma OP, Oswanski MF, Joseph RJ, et al. Venous thromboembolism in trauma patients. Am Surg 2007;73:1173-80
285. | Stannard JP, Lopez-Ben RR, Volgas DA, et al. Prophylaxis against deep-vein thrombosis following trauma: A prospective, randomized comparison of mechanical and pharmacologic prophylaxis. Journal of Bone and Joint Surgery - Series A 2006;88:261-6
286. | Testroote M, Stigter W, de Visser DC, Janzing H. Low molecular weight heparin for prevention of venous thromboembolism in patients with lower-leg immobilization. Cochrane Database Syst Rev. 2008 Oct 8;(4):CD006681
287. | Urayama H, Tanaka K, Fukui D, et al. Increasing Circulation in the Lower Limb under General Anesthesia Using the A-V Impulse System. Angiology 2003;54:691-4
288. | Urban MK, Jules-Elysee K, MacKenzie CR. Pulmonary embolism after IVC filter. HSS Journal 2008;4:74-5
289. | Urbankova J, Quiroz R, Goldhaber SZ. Intermittent pneumatic compression and deep vein thrombosis prevention in postoperative patients. Phlebology 2006;21:19-22
290. | Van Den Berg E, Bathgate B, Panagakos E, et al. Duplex screening as a method of quality assurance of perioperative thromboembolism prophylaxis. International Angiology 1999;18:210-9
291. | Von Bary S, Krieger S, Sobala KH. Vena-cava filter - Prophylaxis of pulmonary re-embolism. Clinical experience report. Zentralbl Chir 1999;124:27-31
292. | Wildin CJ, Hui ACW, Esler CNA, et al. In vivo pressure profiles of thigh-length graduated compression stockings. Br J Surg 1998;85:1228-31
293. | Winslow EH, Brosz DL. Graduated compression stockings in hospitalized postoperative patients: Orrectness of usage and size. Am J Nurs 2008;108:40-50
294. | Wirth T, Schneider B, Misselwitz F, et al. Prevention of venous thromboembolism after knee arthroscopy with low-molecular weight heparin (reviparin): Results of a randomized controlled trial. Arthroscopy 2001;17:393-9
295. | Wu O, Robertson L, Twaddle S, et al. Screening for thrombophilia in high-risk situations: Systematic review and cost-effectiveness analysis. The Thrombosis: Risk and Economic Assessment of Thrombophilia Screening (TREATS) study. Health Technol Assess 2006;10:1-75
296. | Yenna ZC, Roberts C. Thromboprophylaxis after multiple trauma: what treatment and for how long? Injury 2009 Nov;40 Suppl 4:S90-4.
Excluded because the study was not controlled (n=70)
297. | Altintas F, Gurbuz H, Erdemli B, et al. [Venous thromboembolism prophylaxis in major orthopaedic surgery: A multicenter, prospective, observational study]. Acta Orthop Traumatol Turc 2008;42:322-7
298. | Altintas F, Gurbuz H, Erdemli B, et al. Venous thromboembolism prophylaxis in major orthopaedic surgery: A multicenter, prospective, observational study. Acta Orthopaedica et Traumatologica Turcica 2008;42:322-7
299. | Anand S, Asumu T. Patient acceptance of a foot pump device used for thromboprophylaxis. Acta Orthop Belg 2007;73:386-9
300. | Anderson FA,Jr, Hirsh J, White K, et al. Temporal trends in prevention of venous thromboembolism following primary total hip or knee arthroplasty 1996-2001: findings from the Hip and Knee Registry. Chest 2003;124:349S-56S
301. | Ball ST, Pinsorsnak P, Amstutz HC, et al. Extended travel after hip arthroplasty surgery. Is it safe?. J Arthroplasty 2007;22:29-32
302. | Beksac B, Gonzalez Della Valle A, Salvati EA. Thromboembolic disease after total hip arthroplasty: who is at risk? Clin Orthop 2006;453:211-24
303. | Beksaç B, Valle AGD, Salvati EA. Thromboembolic disease after total hip arthroplasty: Who is at risk? Clin Orthop 2006;:211-24
304. | Berend KR, Lombardi AV,Jr, Mallory TH, et al. Ileus following total hip or knee arthroplasty is associated with increased risk of deep venous thrombosis and pulmonary embolism. J Arthroplasty 2004;19:82-6
305. | Best AJ, Williams S, Crozier A, et al. Graded compression stockings in elective orthopaedic surgery. An assessment of the in vivo performance of commercially available stockings in patients having hip and knee arthroplasty. J Bone Joint Surg Br 2000;82:116-8
306. | Caprini JA, Arcelus JI, Motykie G, et al. The influence of oral anticoagulation therapy on deep vein thrombosis rates four weeks after total hip replacement. J Vasc Surg 1999;30:813-20
307. | Chelly JE, Schilling D. Thromboprophylaxis and peripheral nerve blocks in patients undergoing joint arthroplasty. J Arthroplasty 2008;23:350-4
308. | Chotanaphuti T, Ongnamthip P, Silpipat S, et al. The prevalence of thrombophilia and venous thromboembolism in total knee arthroplasty. Journal of the Medical Association of Thailand 2007;90:1342-7
309. | Cofrancesco E, Cortellaro M, Corradi A, et al. Clinical utility of prothrombin fragment 1+2, thrombin antithrombin III complexes and D-dimer measurements in the diagnosis of deep vein thrombosis following total hip replacement. Thromb Haemost 1998;79:509-10
310. | Dahl OE, Gudmundsen TE, Bjornara BT, et al. Risk of clinical pulmonary embolism after joint surgery in patients receiving low-molecular-weight heparin prophylaxis in hospital: a 10-year prospective register of 3,954 patients. Acta Orthop Scand 2003;74:299-304
311. | Dale C, Gallus A, Wycherley A, et al. Prevention of venous thrombosis with minidose warfarin after joint replacement. BMJ 1991;303:224
312. | de la Caffiniere JY, Mignot M, Bruch JM. [The dangerous blood clot in orthopaedic surgery (author's transl)]. Rev Chir Orthop Reparatrice Appar Mot 1981;67:47-58.
313. | Della Valle AG, Serota A, Go G, et al. Venous thromboembolism is rare with a multimodal prophylaxis protocol after total hip arthroplasty. Clin Orthop 2006;:146-53
314. | Ennis RS. Postoperative deep vein thrombosis prophylaxis: a retrospective analysis in 1000 consecutive hip fracture patients treated in a community hospital setting. J South Orthop Assoc 2003;12:10-7
315. | Finsen V. Duration of thrombosis prophylaxis in orthopaedic surgery. Ann Chir Gynaecol 2001;90:105-8
316. | Fluh D. [Clinical monitoring and prevention of deep vein thrombosis in an orthopedic department: use of enoxaparin for a year]. Agressologie 1990;31:151-3
317. | Fujita S, Hirota S, Oda T, Kato Y, Tsukamoto Y, Fuji T. Deep venous thrombosis after total hip or total knee arthroplasty in patients in Japan. Clin Orthop Relat Res. 2000 Jun;(375):168-74
318. | Gonzalez Della Valle A, Serota A, Go G, et al. Venous thromboembolism is rare with a multimodal prophylaxis protocol after total hip arthroplasty. Clin Orthop 2006;444:146-53
319. | Hernigou P, Fevrier MJ, Kergrohen F. [Prevention of thromboembolic complications with adapted low-dose of antivitamins K after total hip prosthesis]. Rev Chir Orthop Reparatrice Appar Mot 1993;79:577-85
320. | Hogdall CK, Hogdall EV, Jorgensen LN, et al. Changes in plasma tetranectin following hip surgery with or without thrombotic complications. Thromb Res 1992;67:399-405
321. | Ishii Y, Matsuda Y, Sakata S, et al. Primary total knee arthroplasty using the Genesis I total knee prosthesis: A 5- to 10-year follow-up study. Knee 2005;12:341-5
322. | Keeney JA, Clohisy JC, Curry MC, et al. Efficacy of combined modality prophylaxis including short-duration warfarin to prevent venous thromboembolism after total hip arthroplasty. J Arthroplasty 2006;21:469-75
323. | Kennon R, Keggi J, Zatorski LE, et al. Anterior approach for total hip arthroplasty: Beyond the minimally invasive technique. Journal of Bone and Joint Surgery - Series A 2004;86:91-7
324. | Khan A, Emberson J, Dowd GS. Standardized mortality ratios and fatal pulmonary embolism rates following total knee replacement: a cohort of 936 consecutive cases. J Knee Surg 2002;15:219-22
325. | Khatod M, Inacio M, Paxton EW, Bini SA, Namba RS, Burchette RJ, Fithian DC. Knee replacement: epidemiology, outcomes, and trends in Southern California. Acta Orthop. 2008 Dec;79(6):812-9
326. | Kim Y-H, Yoo J-H, Kim J-S. Factors leading to decreased rates of deep vein thrombosis and pulmonary embolism after total knee arthroplasty. The Journal of Arthroplasty 2007;22:974-980
327. | Kornberg A, Francis CW, Pellegrini VD,Jr, et al. Comparison of native prothrombin antigen with the prothrombin time for monitoring oral anticoagulant prophylaxis. Circulation 1993;88:454-60
328. | Lachiewicz PF, Soileau ES. Multimodal prophylaxis for THA with mechanical compression. Clin Orthop 2006;453:225-30
329. | Leali A, Fetto J, Moroz A. Prevention of thromboembolic disease after non-cemented hip arthroplasty. A multimodal approach. Acta Orthop Belg 2002;68:128-34
330. | Leclerc JR, Gent M, Hirsh J, et al. The incidence of symptomatic venous thromboembolism after enoxaparin prophylaxis in lower extremity arthroplasty: a cohort study of 1,984 patients. Canadian Collaborative Group. Chest 1998;114:115S-8S
331. | Lieberman DV, Lieberman D. Proximal deep vein thrombosis after hip fracture surgery in elderly patients despite thromboprophylaxis. Am J Phys Med Rehabil 2002;81:745-50.
332. | Lombardi AV,Jr, Berend KR, Tucker TL. The incidence and prevention of symptomatic thromboembolic disease following unicompartmental knee arthroplasty. Orthopedics 2007;30:46-8.
333. | Lotke PA, Lonner JH. The benefit of aspirin chemoprophylaxis for thromboembolism after total knee arthroplasty. Clin Orthop 2006;452:175-80
334. | Mayer A, Hansen M, Peetz D, et al. [Prevention of thromboembolism in trauma surgery by dose adjustment of low molecular weight heparin depending on levels of TAT and D-dimer]. Unfallchirurg 2003;106:1020-8
335. | Mayer A, Hansen M, Peetz D, et al. Prevention of thromboembolism in trauma surgery by dose adjustment of low molecular weight heparin depending on levels of TAT and D-dimer. Unfallchirurg 2003;106:1020-8
336. | Meyer G, Gellert R, Schlömer G, et al. Graduated compression stockings in surgery - Optional or obligatory? Chirurg 2004;75:45-57
337. | Milbrink J, Bergqvist D. The incidence of symptomatic venous thromboembolic events in orthopaedic surgery when using routine thromboprophylaxis. Vasa 2008;37:353-7
338. | Montgomery KD, Potter HG, Helfet DL. The detection and management of proximal deep venous thrombosis in patients with acute acetabular fractures: A follow-up report. J Orthop Trauma 1997;11:330-6
339. | Nathan S, Aleem MA, Thiagarajan P, Das De S. The incidence of proximal deep vein thrombosis following total knee arthroplasty in an Asian population: a Doppler ultrasound study. J Orthop Surg (Hong Kong). 2003 Dec;11(2):184-9
340. | Otero-Fernandez R, Gomez-Outes A, Martinez-Gonzalez J, et al. Evaluation of the effectiveness and safety of bemiparin in a large population of orthopedic patients in a normal clinical practice. Clin Appl Thromb Hemost 2008;14:75-83
341. | Piovella F, Wang CJ, Lu H, Lee K, Lee LH, Lee WC, Turpie AG, Gallus AS, Planès A, Passera R, Rouillon A; AIDA investigators. Deep-vein thrombosis rates after major orthopedic surgery in Asia. An epidemiological study based on postoperative screening with centrally adjudicated bilateral venography. J Thromb Haemost. 2005 Dec;3(12):2664-70
342. | Pookarnjanamorakot C, Sirisriro R, Eurvilaichit C, Jaovisidha S, Koysombatolan I. The incidence of deep vein thrombosis and pulmonary embolism after total knee arthroplasty: the screening study by radionuclide venography. J Med Assoc Thai. 2004 Aug;87(8):869-76
343. | Reitman RD, Emerson RH, Higgins LL, et al. A multimodality regimen for deep venous thrombosis prophylaxis in total knee arthroplasty. J Arthroplasty 2003;18:161-8
344. | Scherff Sorensen T, Jorgensen J. Mechanical prophylaxis against deep vein thrombosis in Charnley hip arthroplasty. Acta Orthop Scand 1981;52:69-72.
345. | Schellong S, Hesselschwerdt HJ, Paar WD, von Hanstein KL. Rates of proximal deep vein thrombosis as assessed by compression ultrasonography in patients receiving prolonged thromboprophylaxis with low molecular weight heparin after major orthopedic surgery. Thromb Haemost. 2005 Sep;94(3):532-6
346. | Sharnoff JG, Rosen RL, Palazzo PJ, et al. Prevention of fatal pulmonary thromboembolism by small dose heparin prophylaxis in acute hip fracture surgery. Br J Clin Pract 1981;35:390-2
347. | Stringer MD, Steadman CA, Hedges AR, et al. Deep vein thrombosis after elective knee surgery. An incidence study in 312 patients. J Bone Joint Surg Br 1989;71:492-7
348. | Suomalainen O, Kettunen K, Rissanen V, et al. Postoperative thromboembolism and risk factors in elective hip surgery. Ann Chir Gynaecol 1983;72:207-13
349. | Tsuda K, Kawasaki T, Nakamura N, et al. Natural Course of Asymptomatic Deep Venous Thrombosis in Hip Surgery without Pharmacologic Thromboprophylaxis in an Asian Population. Clin Orthop 2010;:1-7
350. | Turpie AG, Lensing AW, Fuji T, et al. Pharmacokinetic and clinical data supporting the use of fondaparinux 1.5 mg once daily in the prevention of venous thromboembolism in renally impaired patients. Blood Coagul Fibrinolysis 2009;20:114-21
351. | Van Heereveld HA, Laan RF, van den Hoogen FH, et al. Prevention of symptomatic thrombosis with short term (low molecular weight) heparin in patients with rheumatoid arthritis after hip or knee replacement. Ann Rheum Dis 2001;60:974-6
352. | Vogel G, Spanuth E. Predictive value of fibrin monomers in postoperative deep vein thrombosis. Klin Wochenschr 1990;68:1020-6
353. | Walsh M, Preston C, Bong M, et al. Relative risk factors for requirement of blood transfusion after total hip arthroplasty. J Arthroplasty 2007;22:1162-7
354. | Wang CJ, wang JW, Chen LM, Chen HS, Yang BY, Cheng SM. Deep Vein Thrombosis after total knee arthroplasty. J Formos Med Assoc. 2000;99:848-53
355. | Wang CJ, Wang JW, Weng LH, Huang CC, Yu PC. Clinical significance of muscular deep-vein thrombosis after total knee arthroplasty. Chang Gung Med J. 2007 Jan-Feb;30(1):41-6
356. | Warwick DJ, Whitehouse S. Symptomatic venous thromboembolism after total knee replacement. J Bone Joint Surg Br 1997;79:780-6
357. | Webb LX, Rush PT, Fuller SB, et al. Greenfield filter prophylaxis of pulmonary embolism in patients undergoing surgery for acetabular fracture. J Orthop Trauma 1992;6:139-45
358. | Westlich GH, Specht LM, Sharrock NE, et al. Venous haemodynamics after total knee arthroplasty. Evaluation of active dorsal to plantar flexion and several mechanical compression devices. Journal of Bone and Joint Surgery - Series B 1998;80:1057-66
359. | Westrich GH, Menezes A, Sharrock N, et al. Thromboembolic disease prophylaxis in total knee arthroplasty using intraoperative heparin and postoperative pneumatic foot compression. J Arthroplasty 1999;14:651-6
360. | Westrich GH, Specht LM, Sharrock NE, et al. Pneumatic compression hemodynamics in total hip arthroplasty. Clin Orthop 2000;:180-91.
361. | White RH, Romano PS, Zhou H, et al. Incidence and time course of thromboembolic outcomes following total hip or knee arthroplasty. Arch Intern Med 1998;158:1525-31
362. | Wicky J, Bongard O, Peter R, et al. Screening for proximal deep venous thrombosis using B-mode venous ultrasonography following major hip surgery: implications for clinical management. Vasa 1994;23:330-6
363. | Wilson D, Cooke EA, McNally MA, et al. Altered venous function and deep venous thrombosis following proximal femoral fracture. Injury 2002;33:33-9
364. | Yoo M-, Cho Y-, Ghanem E, et al. Deep vein thrombosis after total hip arthroplasty in Korean patients and D-dimer as a screening tool. Arch Orthop Trauma Surg 2009;129:887-94
365. | Zakarija A, Aledort L. How we treat: Venous thromboembolism prevention in haemophilia patients undergoing major orthopaedic surgery. Haemophilia 2009;15(6):1308-10
366. | Zurawska U, Parasuraman S, Goldhaber SZ. Prevention of pulmonary embolism in general surgery patients. Circulation 2007;115
Excluded because the study did not evaluate a comparison of interest (n=138)
367. | Prevention of pulmonary embolism and deep vein thrombosis with low dose aspirin: Pulmonary Embolism Prevention (PEP) trial. Lancet 2000;355:1295-302
368. | RD heparin compared with warfarin for prevention of venous thromboembolic disease following total hip or knee arthroplasty. RD Heparin Arthroplasty Group. J Bone Joint Surg Am 1994;76:1174-85
369. | Prevention of deep vein thrombosis with low molecular-weight heparin in patients undergoing total hip replacement. A randomized trial. The German Hip Arthroplasty Trial (GHAT) Group. Arch Orthop Trauma Surg 1992;111:110-20
370. | Low-molecular-weight heparin (enoxaparin) vs dextran 70. The prevention of postoperative deep vein thrombosis after total hip replacement. The Danish Enoxaparin Study Group. Arch Intern Med 1991;151:1621-4
371. | Adolf J, Fritsche HM, Haas S, et al. Comparison of 3,000 IU aXa of the low molecular weight heparin certoparin with 5,000 IU aXa in prevention of deep vein thrombosis after total hip replacement. German Thrombosis Study Group. Int Angiol 1999;18:122-6
372. | Anderson DR, Gross M, Robinson KS, et al. Ultrasonographic screening for deep vein thrombosis following arthroplasty fails to reduce posthospital thromboembolic complications: the Postarthroplasty Screening Study (PASS). Chest 1998;114:119S-22S
373. | Arcelus JI, Monreal M, Caprini JA, et al. Clinical presentation and time-course of postoperative venous thromboembolism: Results from the RIETE Registry. Thromb Haemost 2008;99:546-51
374. | Bae,H.;Westrich,G. H.;Sculco,T. P.;Salvati,E. A.;Reich,L. M. The effect of preoperative donation of autologous blood on deep-vein thrombosis after total hip arthroplasty. Journal of Bone and Joint Surgery - Vol 83-B, Issue 5, 676-679
375. | Banssillon V, Dejour H, Besson L, et al. [Prevention of deep venous thrombosis in orthopedic surgery for total hip prosthesis. Randomized trial for determining optimal dosage]. Ann Chir 1987;41:377-85
376. | Barrellier MT, Lebel B, Parienti JJ, et al. Thromb Res 2010;126:e298-304.
377. | Barsotti J, Gruel Y, Rosset P, et al. Comparative double-blind study of two dosage regimens of low-molecular weight heparin in elderly patients with a fracture of the neck of the femur. J Orthop Trauma 1990;4:371-5
378. | Berkowitz SD, Marder VJ, Kosutic G, et al. Oral heparin administration with a novel drug delivery agent (SNAC) in healthy volunteers and patients undergoing elective total hip arthroplasty. J Thromb Haemost 2003;1:1914-9
379. | Bern MM, Bierbaum B, Wetzner S, et al. Very low dose warfarin as prophylaxis against ultrasound detected deep vein thrombosis following primary hip replacement. Am J Hematol 2002;71:69-74
380. | Bicalho PS, Hozack WJ, Rothman RH, et al. Treatment of early symptomatic pulmonary embolism after total joint arthroplasty. J Arthroplasty 1996;11:522-4
381. | Blanchard J, Meuwly JY, Leyvraz PF, et al. Prevention of deep-vein thrombosis after total knee replacement. Randomised comparison between a low-molecular-weight heparin (nadroparin) and mechanical prophylaxis with a foot-pump system. J Bone Joint Surg Br 1999;81:654-9
382. | Bongard O, Wicky J, Peter R, et al. D-dimer plasma measurement in patients undergoing major hip surgery: use in the prediction and diagnosis of postoperative proximal vein thrombosis. Thromb Res 1994;74:487-93
383. | Borghi B, Casati A, Rizzoli Study Group on Orthopaedic,Ananesthesia. Thromboembolic complications after total hip replacement. Int Orthop 2002;26:44-7
384. | Borris LC, Breindahl M, Lassen MR, et al. Differences in urinary prothrombin fragment 1 + 2 levels after total hip replacement in relation to venous thromboembolism and bleeding events. J Thromb Haemost 2008;6:1671-9
385. | Borris LC, Lassen MR, Jensen HP, et al. Perioperative thrombosis prophylaxis with low molecular weight heparins in elective hip surgery. Clinical and economic considerations. Int J Clin Pharmacol Ther 1994;32:262-8
386. | Borris LC, Sorensen JV, Lassen MR, et al. Components of coagulation and fibrinolysis during thrombosis prophylaxis with a low molecular weight heparin (Enoxaparin) versus Dextran 70 in hip arthroplasty. Thromb Res 1991;63:21-8
387. | Calfon M, Seddighzadeh A, Piazza G, et al. Deep vein thrombosis in orthopedic surgery. Clinical and Applied Thrombosis/Hemostasis 2009;15:512-6
388. | Chin CC, Paramsothy M, Aziz YFA. Pulmonary embolism in patients undergoing lower limb orthopaedic surgery. Asian Oceanian Journal of Radiology 2003;8:113-5
389. | Cohen AT, Skinner JA, Warwick D, et al. The use of graduated compression stockings in association with fondaparinux in surgery of the hip. A multicentre, multinational, randomised, open-label, parallel-group comparative study. J Bone Joint Surg Br 2007;89:887-92
390. | Colwell CW,Jr, Froimson MI, Mont MA, et al. Thrombosis prevention after total hip arthroplasty: a prospective, randomized trial comparing a mobile compression device with low-molecular-weight heparin. J Bone Joint Surg Am 2010;92:527-35
391. | Colwell CW,Jr, Kwong LM, Turpie AG, et al. Flexibility in administration of fondaparinux for prevention of symptomatic venous thromboembolism in orthopaedic surgery. J Arthroplasty 2006;21:36-45
392. | Comerota AJ, Stewart GJ, Alburger PD, et al. Operative venodilation: a previously unsuspected factor in the cause of postoperative deep vein thrombosis. Surgery 1989;106:301-8
393. | Dulíček P, Pavlata J, Karpaš K, et al. Prophylaxis of tromboembolic disease after total hip replacement. Acta Chir Orthop Traumatol Cech 2000;67:243-5
394. | Eikelboom JW. Effect of fondaparinux 2.5 mg once daily on mortality: A meta-analysis of phase III randomized trials of venous thromboembolism prevention. European Heart Journal, Supplement 2008;10
395. | Eisele R, Kinzl L, Koelsch T. Rapid-inflation intermittent pneumatic compression for prevention of deep venous thrombosis. J Bone Joint Surg Am 2007;89:1050-6
396. | Eriksson BI, Borris L, Dahl OE, et al. Oral, direct Factor Xa inhibition with BAY 59-7939 for the prevention of venous thromboembolism after total hip replacement. J Thromb Haemost 2006;4:121-8
397. | Eriksson BI, Borris LC, Dahl OE, et al. Dose-escalation study of rivaroxaban (BAY 59-7939)--an oral, direct Factor Xa inhibitor--for the prevention of venous thromboembolism in patients undergoing total hip replacement. Thromb Res 2007;120:685-93
398. | Eriksson BI, Borris LC, Dahl OE, et al. A once-daily, oral, direct Factor Xa inhibitor, rivaroxaban (BAY 59-7939), for thromboprophylaxis after total hip replacement. Circulation 2006;114:2374-81
399. | Eriksson BI, Borris LC, Friedman RJ, et al. Rivaroxaban versus enoxaparin for thromboprophylaxis after hip arthroplasty. N Engl J Med 2008;358:2765-75
400. | Eriksson BI, Borris LC, Friedman RJ, et al. Rivaroxaban versus enoxaparin for thromboprophylaxis after hip arthroplasty. N Engl J Med 2008;358:2765-75
401. | Eriksson BI, Dahl OE, Ahnfelt L, et al. Dose escalating safety study of a new oral direct thrombin inhibitor, dabigatran etexilate, in patients undergoing total hip replacement: BISTRO I. J Thromb Haemost 2004;2:1573-80
402. | Eriksson BI, Kakkar AK, Turpie AG, et al. Oral rivaroxaban for the prevention of symptomatic venous thromboembolism after elective hip and knee replacement. J Bone Joint Surg Br 2009;91:636-44
403. | Eriksson BI, Kalebo P, Ekman S, et al. Direct thrombin inhibition with Rec-hirudin CGP 39393 as prophylaxis of thromboembolic complications after total hip replacement. Thromb Haemost 1994;72:227-31
404. | Eskander MBF, Limb D, Stone MH, et al. Sequential mechanical and pharmacological thromboprophylaxis in the surgery of hip fractures. Int Orthop 1997;21:259-61
405. | Faghri PD, Van Meerdervort HF, Glaser RM, et al. Electrical stimulation-induced contraction to reduce blood stasis during arthroplasty. IEEE Trans Rehabil Eng 1997;5:62-9
406. | Feller JA, Parkin JD, Phillips GW, et al. Prophylaxis against venous thrombosis after total hip arthroplasty. Aust N Z J Surg 1992;62:606-10
407. | Fender D, Harper WM, Thompson JR, et al. Mortality and fatal pulmonary embolism after primary total hip replacement. Results from a regional hip register. J Bone Joint Surg Br 1997;79:896-9
408. | Fisher WD, Eriksson BI, Bauer KA, et al. Rivaroxaban for thromboprophylaxis after orthopaedic surgery: pooled analysis of two studies. Thromb Haemost 2007;97:931-7
409. | Fisher CG, Blachut PA, Salvian AJ, Meek RN, O'Brien PJ. Effectiveness of pneumatic leg compression devices for the prevention of thromboembolic disease in orthopaedic trauma patients: a prospective, randomized study of compression alone versus no prophylaxis. J Orthop Trauma. 1995 Feb;9(1):1-7
410. | Francis CW, Marder VJ, Evarts CM. Lower risk of thromboembolic disease after total hip replacement with non-cemented than with cemented prostheses. Lancet 1986;1:769-71
411. | Francis CW, Pellegrini VD,Jr, Leibert KM, et al. Comparison of two warfarin regimens in the prevention of venous thrombosis following total knee replacement. Thromb Haemost 1996;75:706-11
412. | Fredin H, Gustafson C, Rosberg B. Hypotensive anesthesia, thromboprophylaxis and postoperative thromboembolism in total hip arthroplasty. Acta Anaesthesiol Scand 1984;28:503-7
413. | Fredin HO, Nillius AS. Fatal pulmonary embolism after total hip replacement. Acta Orthop Scand 1982;53:407-11
414. | Fuji T, Fujita S, Ochi T. Fondaparinux prevents venous thromboembolism after joint replacement surgery in Japanese patients. Int Orthop 2008;32:443-51
415. | Gallus A, Raman K, Darby T. Venous thrombosis after elective hip replacement - the influence of preventive intermittent calf compression and of surgical technique. Br J Surg 1983;70:17-19
416. | Gelfer Y, Tavor H, Oron A, et al. Deep vein thrombosis prevention in joint arthroplasties: continuous enhanced circulation therapy vs low molecular weight heparin. J Arthroplasty 2006;21:206-14
417. | Giachino AA, Rody K, Turek MA, et al. Systemic fat and thrombus embolization in patients undergoing total knee arthroplasty with regional heparinization. J Arthroplasty 2001;16:288-92
418. | Ginsberg JS, Nurmohamed MT, Gent M, et al. Use of Hirulog in the prevention of venous thrombosis after major hip or knee surgery. Circulation 1994;90:2385-9
419. | Haas S. Prevention of deep vein thrombosis in surgical departments. Unfallchirurg 2004;107:1065-88
420. | Harris WH, Athanasoulis CA, Waltman AC, et al. Prophylaxis of deep-vein thrombosis after total hip replacement. Dextran and external pneumatic compression compared with 1.2 or 0.3 gram of aspirin daily. J Bone Joint Surg Am 1985;67:57-62
421. | Harris WH, Athanasoulis CA, Waltman AC, et al. High and low-dose aspirin prophylaxis against venous thromboembolic disease in total hip replacement. J Bone Joint Surg Am 1982;64:63-6
422. | Hartrick CT, Martin G, Kantor G, et al. Evaluation of a single-dose, extended-release epidural morphine formulation for pain after knee arthroplasty. Journal of Bone and Joint Surgery - Series A 2006;88:273-81
423. | Heit JA, Berkowitz SD, Bona R, et al. Efficacy and safety of low molecular weight heparin (ardeparin sodium) compared to warfarin for the prevention of venous thromboembolism after total knee replacement surgery: a double-blind, dose-ranging study. Ardeparin Arthroplasty Study Group. Thromb Haemost 1997;77:32-8
424. | Heit JA, Elliott CG, Trowbridge AA, et al. Ardeparin sodium for extended out-of-hospital prophylaxis against venous thromboembolism after total hip or knee replacement. A randomized, double-blind, placebo-controlled trial. Ann Intern Med 2000;132:853-61
425. | Hoek JA, Nurmohamed MT, ten Cate JW, et al. Thrombin-antithrombin III complexes in the prediction of deep vein thrombosis following total hip replacement. Thromb Haemost 1989;62:1050-2
426. | Huang J, Cao Y, Wu L, Gao F. Apixaban versus enoxaparin in patients with total knee arthroplasty: a meta-analysis of randomized trials. Thromb Haem 2011;105(2):245-53
427. | Hui AC, Heras-Palou C, Dunn I, et al. Graded compression stockings for prevention of deep-vein thrombosis after hip and knee replacement. J Bone Joint Surg Br 1996;78:550-4
428. | Hull RD, Brant RF, Pineo GF, et al. Preoperative vs postoperative initiation of low-molecular-weight heparin prophylaxis against venous thromboembolism in patients undergoing elective hip replacement. Arch Intern Med 1999;159:137-41
429. | Hull RD, Pineo GF, Stein PD, et al. Timing of initial administration of low-molecular-weight heparin prophylaxis against deep vein thrombosis in patients following elective hip arthroplasty: a systematic review. Arch Intern Med 2001;161:1952-60
430. | Ishak M, Morely K. Deep venous thrombosis after total hip arthroplasty: a prospective controlled study to determine the prophylactic effect of graded pressure stockings. Br j Surg 1981;68:429-432
431. | Ivanic GM, Moser I, Homann NC, et al. [Intermittent compression devices for swelling reduction and thrombosis prophylaxis--a pilot study after total hip replacement. Is the 2 hour daily minimum application sufficient?]. Unfallchirurg 2006;109:786-92
432. | Ivanic GM, Moser I, Homann NC, et al. Intermittent compression devices for swelling reduction and thrombosis prophylaxis - A pilot study after total hip replacement: Is the 2 hour daily minimum application sufficient? Unfallchirurg 2006;109:786-92
433. | Jeong GK, Gruson KI, Egol KA, et al. Thromboprophylaxis after hip fracture: evaluation of 3 pharmacologic agents. Am J Orthop 2007;36:135-40
434. | Jorgensen PS, Strandberg C, WilleJorgensen P, et al. Early preoperative thromboprophylaxis with Klexane (R) in hip fracture surgery: A placebo-controlled study. Clinical and Applied Thrombosis/Hemostasis 1998;4:140-2
435. | Kakkar AK, Brenner B, Dahl OE, et al. Extended duration rivaroxaban versus short-term enoxaparin for the prevention of venous thromboembolism after total hip arthroplasty: a double-blind, randomised controlled trial. Lancet 2008;372:31-9
436. | Kakkar VV, Howes J, Sharma V, et al. A comparative double-blind, randomised trial of a new second generation LMWH (bemiparin) and UFH in the prevention of post-operative venous thromboembolism. The Bemiparin Assessment group. Thromb Haemost 2000;83:523-9
437. | Kalodiki E, Domjan J, Nicolaides AN, et al. V/Q defects and deep venous thrombosis following total hip replacement. Clin Radiol 1995;50:400-3
438. | Kalodiki E, Nicolaides AN, Al-Kutoubi A, et al. How "gold" is the standard? Interobservers' variation on venograms. Int Angiol 1998;17:83-8
439. | Kew J, Lee YL, Davey IC, Ho SY, Fung KC, Metreweli C. Deep vein thrombosis in elderly Hong Kong Chinese with hip fractures detected with compression ultrasound and Doppler imaging: incidence and effect of low molecular weight heparin. Arch Orthop Trauma Surg (1999) 119 :156–158
440. | Kurt N, Tolunay M, Yüzbaşioǧlu Aslan B. Postoperative venous insufficiency and deep venous thrombosis in total hip replacement: The effects of epidural and general anesthesia. Artroplasti Artroskopik Cerrahi 2002;13:215-20
441. | Labarere J, Bosson J-, Sevestre M-, et al. Thromboprophylaxis with graduated compression stockings for elderly inpatients: More evidence is needed [5]. Journal of Thrombosis and Haemostasis 2006;4:1838-40
442. | Labek G, Bohler N. [Blood transfusion in total hip endoprosthesis operations in relation to Redon drainage and pressure bandages. An innovation in surgical method]. Z Orthop Ihre Grenzgeb 1998;136:433-8
443. | Laguardia AM, Caroli GC. Prevention of deep vein thrombosis in orthopaedic surgery. Comparison of two different treatment protocols with low molecular weight heparin ('Fluxum'). Curr Med Res Opin 1992;12:584-93
444. | Lassen MR, Ageno W, Borris LC, et al. Rivaroxaban versus enoxaparin for thromboprophylaxis after total knee arthroplasty. N Engl J Med 2008;358:2776-86
445. | Lassen MR, Raskob GE, Gallus A, Pineo G, Chen D, Portman RJ. Apixaban or Enoxaparin for
446. | Thromboprophylaxis after Knee Replacement. N Engl J Med 2009;361:594-604.
447. | Lassen MR, Raskob GE, Gallus A, Pineo G, Chen D, Hornick P, and the ADVANCE-2 investigators. Apixaban versus enoxaparin for thromboprophylaxis after knee replacement (ADVANCE-2): a randomised double-blind trial. Lancet 2010; 375: 807–15
448. | Lassen MR, Gallus A, Raskob GE, Pineo G, Chen D, Ramirez LZ, and the ADVANCE-3 investigators. Randomized Double-Blind Comparison of Apixaban and Enoxaparin for Thromboprophylaxis After Hip Replacement: The ADVANCE-3 Trial. ADVANCE-3 powerpoint presentation
449. | Levine MN, Gent M, Hirsh J, et al. Ardeparin (low-molecular-weight heparin) vs graduated compression stockings for the prevention of venous thromboembolism. A randomized trial in patients undergoing knee surgery. Arch Intern Med 1996;156:851-6
450. | Leyvraz PF, Postel M, Bachmann F, Hoeck JA, Samama M, Vandenbroek D. Prevention of deep vein thrombosis after total hip replacement: randomized comparison between adjusted dose unfractionated heparin and low molecular weight heparin (CY216). In: Hoek JA, ed. Deep vein thrombosis following total hip replacement. PhD thesis, University of Amsterdam, 1990: 105-17.
451. | Leyvraz PF, Bachmann F, Hoek J, et al. Prevention of deep vein thrombosis after hip replacement: randomised comparison between unfractionated heparin and low molecular weight heparin. BMJ 1991;303:543-8
452. | Leyvraz PF, Richard J, Bachmann F, et al. Adjusted versus fixed-dose subcutaneous heparin in the prevention of deep-vein thrombosis after total hip replacement. N Engl J Med 1983;309:954-8
453. | Li T, Lv M, Li Q. [Comprehensive prophylaxis for deep venous thrombosis after proximal femur fractures in geriatric patients]. Chung Kuo Hsiu Fu Chung Chien Wai Ko Tsa Chih 2008;22:453-5
454. | Li XL, Lu WJ, Yu NS. [Prophylaxis for deep vein thrombosis with low molecular weight heparin following hip and knee surgery]. Chung Kuo Hsiu Fu Chung Chien Wai Ko Tsa Chih 2001;15:39-41
455. | Lie SA, Engesaeter LB, Havelin LI, et al. Early postoperative mortality after 67,548 total hip replacements: causes of death and thromboprophylaxis in 68 hospitals in Norway from 1987 to 1999. Acta Orthop Scand 2002;73:392-9
456. | Messieh M, Huang Z, Johnson LJ, et al. Warfarin responses in total joint and hip fracture patients. J Arthroplasty 1999;14:724-9
457. | Monreal M, Lafoz E, Roca J, et al. Platelet count, antiplatelet therapy and pulmonary embolism--a prospective study in patients with hip surgery. Thromb Haemost 1995;73:380-5
458. | Moretti B, Patella V, Pesce V, et al. Combined pharmacological and mechanical prophylaxis for DVT following hip and knee arthroplasty. Journal of Orthopaedics and Traumatology 2002;3:149-55
459. | Navarro-Quilis A, Castellet E, Rocha E, et al. Efficacy and safety of bemiparin compared with enoxaparin in the prevention of venous thromboembolism after total knee arthroplasty: a randomized, double-blind clinical trial. J Thromb Haemost 2003;1:425-32
460. | Ndiaye A, Ville D, Clermont N, et al. [Evaluation of the predictive value of fibrin degradation products in the detection of deep venous thrombosis after total knee prosthesis]. Dakar Med 1997;42:36-9
461. | Norgren L, Austrell C, Brummer R, et al. Low incidence of deep vein thrombosis after total hip replacement: An interim analysis of patients on low molecular weight heparin vs sequential gradient compression prophylaxis. International Angiology 1996;15:11-4
462. | Norgren L, Toksvig-Larsen S, Magyar G, et al. Prevention of deep vein thrombosis in knee arthroplasty. Preliminary results from a randomized controlled study of low molecular weight heparin vs foot pump compression. Int Angiol 1998;17:93-6
463. | O'Brien BJ, Anderson DR, Goeree R. Cost-effectiveness of enoxaparin versus warfarin prophylaxis against deep-vein thrombosis after total hip replacement. CMAJ 1994;150:1083-90
464. | Patel VP, Walsh M, Sehgal B, et al. Factors associated with prolonged wound drainage after primary total hip and knee arthroplasty. J Bone Joint Surg Am 2007;89:33-8
465. | Pellegrini VD,Jr, Donaldson CT, Farber DC, et al. The Mark Coventry Award: Prevention of readmission for venous thromboembolism after total knee arthroplasty. Clin Orthop 2006;452:21-7
466. | Pellegrini VD,Jr, Donaldson CT, Farber DC, et al. The John Charnley Award: Prevention of readmission for venous thromboembolic disease after total hip arthroplasty. Clin Orthop 2005;441:56-62
467. | Pietsch M, Kuhle J, Hamer H, et al. [Mechanical versus drug prevention of thrombosis after total hip endoprosthesis implantation. A randomized, controlled clinical study]. Biomed Tech (Berl) 2003;48:207-12
468. | Pietsch M, Kuhle J, Hamer H, et al. Mechanical versus pharmacological prophylaxis of deep-vein thrombosis in patients undergoing total hip replacement. A randomized, controlled clinical trial. Biomed Tech 2003;48:207-12
469. | Pini M, Tagliaferri A, Manotti C, lasagne F, Rinaldi E, Detorri AG. Low molecular weight heparin (Alfa LMWH) compared with unfractionated heparin in prevention of deep-vein thrombosis after hip fractures
470. | Pitto RP, Hamer H, Heiss-Dunlop W, et al. Mechanical prophylaxis of deep-vein thrombosis after total hip replacement a randomised clinical trial. J Bone Joint Surg Br 2004;86:639-42
471. | Pitto RP, Young S. Foot pumps without graduated compression stockings for prevention of deep-vein thrombosis in total joint replacement: efficacy, safety and patient compliance. A comparative, prospective clinical trial. Int Orthop 2008;32:331-6
472. | Planes A. Comparison of antithrombotic efficacy and haemorrhagic side-effects of Clivarin versus enoxaparin in patients undergoing total hip replacement surgery. Blood Coagul Fibrinolysis 1993;4:S33-5.
473. | Planes A, Vochelle N, Fagola M, et al. Comparison of two low-molecular-weight heparins for the prevention of postoperative venous thromboembolism after elective hip surgery. Reviparin Study Group. Blood Coagul Fibrinolysis 1998;9:499-505
474. | Planes,A.;Vochelle,N.;Ferru,J.;Przyrowski,D.;Clerc,J.;Fagola,M.;Planes,M. Enoxaparine low molecular weight heparin: its use in the prevention of deep venous thrombosis following total hip replacement. Haemostasis. 1986;16(2):152-8
475. | Poller L, Taberner DA, Sandilands DG, et al. An evaluation of APTT monitoring of low-dose heparin dosage in hip surgery. Thromb Haemost 1982;47:50-3
476. | Rader CP, Kramer C, Hendrich C, et al. [Experiences with an ankle joint motion device in prevention of thrombosis in patients after total endoprosthesis knee replacement]. Z Orthop Ihre Grenzgeb 1998;136:467-70
477. | Reber G, Blanchard J, Bounameaux H, et al. Inability of serial fibrin monomer measurements to predict or exclude deep venous thrombosis in asymptomatic patients undergoing total knee arthroplasty. Blood Coagulation and Fibrinolysis 2000;11:305-8
478. | Rocha E, Alfaro MJ, Paramo JA, et al. Preoperative identification of patients at high risk of deep venous thrombosis despite prophylaxis in total hip replacement. Thromb Haemost 1988;59:93-5
479. | Salazar CA, Malaga G, Malasquez G. Direct thrombin inhibitors versus vitamin K antagonists or low molecular weight heparins for prevention of venous thromboembolism following total hip or knee replacement. Cochrane Database Syst Rev 2010;4:005981
480. | Schuh A, Hausel M, Salminen S. Effect of Tourniquet Use on Blood Loss in Total Knee Arthroplasty. Zentralbl Chir 2003;128:866-70
481. | Schmidt B, Michler R, Klein M, Faulmann G, Weber C, Schellong S. Ultrasound screening for distal vein thrombosis is not beneficial after major orthopedic surgery. A randomized controlled trial. Thromb Haemost. 2003 Nov;90(5):949-54
482. | Sharrock NE, Brien WW, Salvati EA, et al. The effect of intravenous fixed-dose heparin during total hip arthroplasty on the incidence of deep-vein thrombosis. A randomized, double-blind trial in patients operated on with epidural anesthesia and controlled hypotension. J Bone Joint Surg Am 1990;72:1456-61
483. | Sharrock NE, Go G, Mayman D, et al. Decreases in pulmonary artery oxygen saturation during total hip arthroplasty: Variations using 2 leg positioning techniques. J Arthroplasty 2005;20:499-502
484. | Sharrock NE, Go G, Sculco TP, et al. Dose response of intravenous heparin on markers of thrombosis during primary total hip replacement. Anesthesiology 1999;90:981-7
485. | Sharrock NE, Go G, Williams-Russo P, et al. Comparison of extradural and general anaesthesia on the fibrinolytic response to total knee arthroplasty. Br J Anaesth 1997;79:29-34
486. | Spiro TE, Johnson GJ, Christie MJ, et al. Efficacy and safety of enoxaparin to prevent deep venous thrombosis after hip replacement surgery. Enoxaparin Clinical Trial Group. Ann Intern Med 1994;121:81-9
487. | Swierstra BA, Stibbe J, Schouten HJ. Prevention of thrombosis after hip arthroplasty. A prospective study of preoperative oral anticoagulants. Acta Orthop Scand 1988;59:139-43
488. | Taberner DA, Poller L, Thomson JM, et al. Randomized study of adjusted versus fixed low dose heparin prophylaxis of deep vein thrombosis in hip surgery. Br J Surg 1989;76:933-5
489. | Tamir L, Hendel D, Neyman C, et al. Sequential foot compression reduces lower limb swelling and pain after total knee arthroplasty. J Arthroplasty 1999;14:333-8
490. | Turpie AG, Fisher WD, Bauer KA, et al. BAY 59-7939: an oral, direct factor Xa inhibitor for the prevention of venous thromboembolism in patients after total knee replacement. A phase II dose-ranging study. J Thromb Haemost 2005;3:2479-86
491. | Turpie AG, Gallus AS, Hoek JA, et al. A synthetic pentasaccharide for the prevention of deep-vein thrombosis after total hip replacement. N Engl J Med 2001;344:619-25
492. | Turpie AG, Lassen MR, Davidson BL, et al. Rivaroxaban versus enoxaparin for thromboprophylaxis after total knee arthroplasty (RECORD4): a randomised trial. Lancet 2009;373:1673-80
493. | Vanek VW. Meta-analysis of effectiveness of intermittent pneumatic compression devices with a comparison of thigh-high to knee-high sleeves. Am Surg 1998;64:1050-8
494. | Vives MJ, Hozack WJ, Sharkey PF, et al. Fixed minidose versus-adjusted low-dose warfarin after total joint arthroplasty: A randomized prospective study. J Arthroplasty 2001;16:1030-7
495. | Vochelle N, Planes A. [Prevention of deep vein thrombosis by enoxaparin after total hip prosthesis]. Agressologie 1990;31:145-8
496. | Vresilovic EJ, Hozack WJ, Booth RE,Jr, et al. Comparative risk of early postoperative pulmonary embolism after cemented total knee versus total hip arthroplasty with low-dose warfarin prophylaxis. Am J Knee Surg 1996;9:2-6
497. | Wahlander K, Larson G, Lindahl TL, et al. Factor V Leiden (G1691A) and prothrombin gene G20210A mutations as potential risk factors for venous thromboembolism after total hip or total knee replacement surgery. Thromb Haemost 2002;87:580-5
498. | Weber U, Koppenhagen K, Malzer H, et al. [Different effectiveness of two preparations of low molecular weight heparin in patients with elective hip joint replacement]. Langenbecks Arch Chir 1991;376:147-51
499. | Westrich GH, Bottner F, Windsor RE, et al. VenaFlow plus Lovenox vs VenaFlow plus aspirin for thromboembolic disease prophylaxis in total knee arthroplasty. J Arthroplasty 2006;21:139-43
500. | Westrich GH, Farrell C, Bono JV, et al. The incidence of venous thromboembolism after total hip arthroplasty: a specific hypotensive epidural anesthesia protocol. J Arthroplasty 1999;14:456-63
501. | Westrich GH, Menezes A, Sharrock N, et al. Thromboembolic disease prophylaxis in total knee arthroplasty using intraoperative heparin and postoperative pneumatic foot compression. J Arthroplasty 1999;14:651-6
502. | Westrich GH, Salvati EA, Sharrock N, et al. The effect of intraoperative heparin administered during total hip arthroplasty on the incidence of proximal deep vein thrombosis assessed by magnetic resonance venography. J Arthroplasty 2005;20:42-50
503. | Wilson MG, Pei LF, Malone KM, et al. Fixed low-dose versus adjusted higher-dose warfarin following orthopedic surgery. A randomized prospective trial. J Arthroplasty 1994;9:127-30
504. | Yoo MC, Kang CS, Kim YH, et al. A prospective randomized study on the use of nadroparin calcium in the prophylaxis of thromboembolism in Korean patients undergoing elective total hip replacement. Int Orthop 1997;21:399-402
Excluded because the study was not a randomized controlled trial or a controlled observational study greater than or equal to 750 participants (n=117)
505. | Anders MJ, Lifeso RM, Landis M, et al. Effect of preoperative donation of autologous blood on deep-vein thrombosis following total joint arthroplasty of the hip or knee. Journal of Bone and Joint Surgery - Series A 1996;78:574-80.
506. | Ares-Rodriguez O, Martinez AH, Fernandez AH, et al. Survival curve and factors related to drainage during the first 24 h after total knee arthroplasty. Knee Surg Sports Traumatol Arthrosc 2008;16:585-9.
507. | Arimune M, Morita H. [Safety of low dose unfractionated heparin (LDUH) in patients undergoing hip fracture operation]. Masui 2008;57:1223-6.
508. | Asensio A, Antolin FJ, Sanchez-Garcia JM, et al. Timing of DVT prophylaxis and risk of postoperative knee prosthesis infection. Orthopedics 2010;33:800.
509. | Aulmann M, Kwasniki S, Bottiger BW, et al. Effects of standard unfractionated and low-molecular-weight heparins on platelets of patients undergoing total hip replacement surgery. Beitr Infusionsther Transfusionsmed 1997;34:242-7.
510. | Bagaria V, Modi N, Panghate A, et al. Incidence and risk factors for development of venous thromboembolism in Indian patients undergoing major orthopaedic surgery: Results of a prospective study. Postgrad Med J 2006;82:136-9.
511. | Bedair H, Berli M, Gezer S, et al. Hematologic genetic testing in high-risk patients before knee arthroplasty: a pilot study. Clin Orthop 2011;469:131-137.
512. | Beksac B, Gonzalez Della Valle A, Anderson J, et al. Symptomatic thromboembolism after one-stage bilateral THA with a multimodal prophylaxis protocol. Clin Orthop 2007;463:114-9.
513. | Beksaç B, Valle AGD, Anderson J, et al. Symptomatic thromboembolism after one-stage bilateral THA with a multimodal prophylaxis protocol. Clin Orthop 2007;114-9.
514. | Bell DF, Harris WH, Kuter DJ, et al. Elevated partial thromboplastin time as an indicator of hemorrhagic risk in postoperative patients on warfarin prophylaxis. J Arthroplasty 1988;3:181-4.
515. | Bradley JG, Krugener GH, Jager HJ. The effectiveness of intermittent plantar venous compression in prevention of deep venous thrombosis after total hip arthroplasty. J Arthroplasty 1993;8:57-61.
516. | Britt SL, Barker DE, Maxwell RA, et al. The impact of pelvic and lower extremity fractures on the incidence of lower extremity deep vein thrombosis in high-risk trauma patients. Am Surg 2003;69:459-63.
517. | Brooks PJ, Keramati M, Wickline A. Thromboembolism in patients undergoing total knee arthroplasty with epidural analgesia. J Arthroplasty 2007;22:641-3.
518. | Brotman DJ, Jaffer AK, Hurbanek JG, et al. Warfarin prophylaxis and venous thromboembolism in the first 5 days following hip and knee arthroplasty. Thromb Haemost 2004;92:1012-7.
519. | Bruce W, Van der Wall H, Peters M, et al. Occurrence of pulmonary thromboembolism immediately after arthroplasty. Nucl Med Commun 2001;22:1237-42.
520. | Buchan DS, Bajorek B. Incidence of venous thromboembolism and thromboprophylaxis after total hip or knee arthroplasty. Journal of Pharmacy Practice and Research 2008;38:200-4.
521. | Buehler KO, D'Lima DD, Petersilge WJ, et al. Late deep venous thrombosis and delayed weightbearing after total hip arthroplasty. Clin Orthop 1999;123-30.
522. | Chandrasekaran S, Ariaretnam SK, Tsung J, et al. Early mobilization after total knee replacement reduces the incidence of deep venous thrombosis. ANZ J Surg 2009;79:526-9.
523. | Chotanaphuti T, Jareonarpornwatana A, Laoruengthana A. The mortality rate after thromboembolism prophylaxis in the hip fracture surgery. J Med Assoc Thai 2009;92:S115-9.
524. | Comfere TB, Sprung J, Case KA, et al. Predictors of mortality following symptomatic pulmonary embolism in patients undergoing noncardiac surgery. Canadian Journal of Anesthesia 2007;54:634-41.
525. | Dambrosio M, Tullo L, Moretti B, et al. Hemodynamic and respiratory changes during hip and knee arthroplasty: An echocardiographic study. Minerva Anestesiol 2002;68:537-47.
526. | Daniel J, Pradhan A, Pradhan C, et al. Multimodal thromboprophylaxis following primary hip arthroplasty: the role of adjuvant intermittent pneumatic calf compression. J Bone Joint Surg Br 2008;90:562-9.
527. | Davidson HC, Mazzu D, Gage BF, et al. Screening for deep venous thrombosis in asymptomatic postoperative orthopedic patients using color Doppler sonography: Analysis of prevalence and risk factors. Am J Roentgenol 1996;166:659-62.
528. | De Thomasson E, Strauss C, Girard P, et al. Duplex Doppler detection of asymptomatic venous thrombosis after lower limb prosthetic surgery: Retrospective analysis in 400 patients. Presse Medicale 2000;29:351-6.
529. | Demir M, Iqbal O, Hoppensteadt DA, et al. Anticoagulant and antiprotease profiles of a novel natural heparinomimetic mannopentaose phosphate sulfate (PI-88). Clinical and Applied Thrombosis/Hemostasis 2001;7:131-40.
530. | Di Panfilo A, Cornette M. [Echo Doppler post total hip arthroplasty: retrospective: study of 111 patients at CHBAH]. Rev Med Liege 2004;59:497-503.
531. | Eikelboom JW, Mazzarol A, Quinlan DJ, et al. Thromboprophylaxis practice patterns in two Western Australian teaching hospitals. Haematologica 2004;89:586-93.
532. | Fong YK, Ruban P, Yeo SJ, et al. Use of low molecular weight heparin for prevention of deep vein thrombosis in total knee arthroplasty--a study of its efficacy in an Asian population. Ann Acad Med Singapore 2000;29:439-41.
533. | Gallay S, Waddell JP, Cardella P, et al. A short course of low-molecular-weight heparin to prevent deep venous thrombosis after elective total hip replacement. Can J Surg 1997;40:119-23.
534. | Gnudi S, Picci P, Figus E. Thrombo-embolism as a complication of prosthetic replacement operations of the hip: prophylaxis with heparin at low doses. Ital J Orthop Traumatol 1980;6:147-51.
535. | Gómez Navalón LA, Marín Morales LA, Zorrilla Ribot P, et al. Spinal anesthesia: A protective factor in thromboembolic disease. A retrospective study of 484 arthroplasties. Rev Esp Anestesiol Reanim 2001;48:113-6.
536. | Grion AM, Gallo U, Bano F, et al. Differences in mortality after hip fracture is associated with postdischarge prescription of antithrombotic prophylaxis: a case control study. Clin Appl Thrombosis/Hemostasis 2002;8(2):143-146.
537. | Guan Z, Chen Y, Song Y. [Influence of body mass index and age on deep vein thrombosis after total hip and knee arthroplasty]. Chung Kuo Hsiu Fu Chung Chien Wai Ko Tsa Chih 2006;20:611-5.
538. | Guan ZP, Lu HS, Chen YZ, et al. [Clinical risk factors for deep vein thrombosis after total hip and knee arthroplasty]. Chung Hua Wai Ko Tsa Chih 2005;43:1317-20.
539. | Guyer RD, Booth RE,Jr, Rothman RH. The detection and prevention of pulmonary embolism in total hip replacement. A study comparing aspirin and low-dose warfarin. J Bone Joint Surg Am 1982;64:1040-4.
540. | Hartman JT, Pugh JL, Smith RD. Cyclic sequential compression of the lower limb in prevention of deep venous thrombosis. Journal of Bone and Joint Surgery - Series A 1982;64:1059-62.
541. | Heiz-Valle C, de Maistre E, Commun N, et al. [Desirudin (Revasc) to prevent thromboembolic complications after hip or knee replacement surgery]. Therapie 2002;57:34-8.
542. | Hitos K, Fletcher JP. Venous thromboembolism following primary total knee arthroplasty. Int Angiol 2006;25:343-51.
543. | Hitos K, Fletcher JP. Venous thromboembolism and fractured neck of femur. Thromb Haemost 2005;94:991-6.
544. | Hodge WA. Prevention of deep vein thrombosis after total knee arthroplasty. Coumadin versus pneumatic calf compression. Clin Orthop 1991;101-5.
545. | Hooker JA, Lachiewicz PF, Kelley SS. Efficacy of prophylaxis against thromboembolism with intermittent pneumatic compression after primary and revision total hip arthroplasty. J Bone Joint Surg Am 1999;81:690-6.
546. | Jaffer AK, Barsoum WK, Krebs V, et al. Duration of anesthesia and venous thromboembolism after hip and knee arthroplasty. Mayo Clin Proc 2005;80:732-8.
547. | Jain V, Dhal AK, Dhaon BK, et al. Deep vein thrombosis after total hip arthroplasty in Indian patients with and without enoxaparin. J Orthop Surg 2004;12:173-7.
548. | Jain V, Dahl AK, Dhaon BK, et al. Deep vein thrombosis after total hip arthroplasty in Indian patients. Postgrad Med J 2004;80:729-731.
549. | Joseph JE, Low J, Courtenay B, et al. A single-centre prospective study of clinical and haemostatic risk factors for venous thromboembolism following lower limb arthroplasty. Br J Haematol 2005;129:87-92.
550. | Kalodiki E, Domjan J, Nicoladides AN, et al. V/Q defects and deep venous thrombosis following total hip replacement. Clin Radiology 1995;50:400-403
551. | Keays AC, Mason M, Keays SL, et al. The effect of anticoagulation on the restoration of range of motion after total knee arthroplasty: enoxaparin versus aspirin. J Arthroplasty 2003;18:180-5.
552. | Kerr J, Linkins LA. High incidence of in-hospital pulmonary embolism following joint arthroplasty with dalteparin prophylaxis. Thromb Haemost 2010;103:123-8.
553. | Kim GH, Hahn DK, Kellner CP, et al. The incidence of heparin-induced thrombocytopenia Type II in patients with subarachnoid hemorrhage treated with heparin versus enoxaparin: Clinical article. J Neurosurg 2009;110:50-7.
554. | Kim YH, Kim JS. Factors leading to low prevalence of DVT and pulmonary embolism after THA. Analysis of Genetic and Prothrombotic Factors.
555. | Kim YH, Suh JS. Low incidence of deep-vein thrombosis after cementless total hip replacement. J Bone Joint Surg Am 1988;70:878-82.Clin orthop and related research 2007;465:33-39.
556. | Kimura K, Ohtani S, Okamura H, et al. Anticoagulation therapy with heparin and warfarin in total knee arthroplasty for osteoarthritis knee. Clin Appl Thromb Hemost 2009;15:109-12.
557. | Kovacs MJ, Weir K, MacKinnon K, et al. Body weight does not predict for anti-Xa levels after fixed dose prophylaxis with enoxaparin after orthopedic surgery. Thromb Res 1998;91:137-42.
558. | Krotenberg R, Adler U, Pomeranz B, et al. Dalteparin vs. enoxaparin as prophylaxis for deep-vein thrombosis after total hip or knee arthroplasty: a retrospective analysis. Am J Phys Med Rehabil 2001;80:889-95.
559. | Lachiewicz PF, Klein JA, Holleman JB,Jr, et al. Pneumatic compression or aspirin prophylaxis against thromboembolism in total hip arthroplasty. J South Orthop Assoc 1996;5:272-80.
560. | Laflamme GY, Laflamme GH, Paiement GD, et al. [Efficacy and safety of prophylactic preoperative administration of low-dose warfarin in cemented total knee prostheses]. Ann Chir 1994;48:717-22.
561. | Larson CM, MacMillan DP, Lachiewicz PF. Thromboembolism after total knee arthroplasty: intermittent pneumatic compression and aspirin prophylaxis. J South Orthop Assoc 2001;10:155-63.
562. | Lawton RL, Morrey BF. The use of heparin in patients in whom a pulmonary embolism is suspected after total hip arthroplasty. J Bone Joint Surg Am 1999;81:1063-72.
563. | Lawton RL, Morrey BF, Narr BJ. Validity of index of suspicion for pulmonary embolism after hip arthroplasty. Clin Orthop 2003;180-92.
564. | Lee BY, Butler G, Al-Waili N, et al. Role of thrombelastograph haemostasis analyser in detection of hypercoagulability following surgery with and without use of intermittent pneumatic compression. Journal of Medical Engineering and Technology 2010;34:166-71.
565. | Leizorovicz A. Epidemiology of post-operative venous thromboembolism in Asian patients. Results of the SMART venography study. Haematologica 2007;92:1194-200.
566. | Lin PP, Graham D, Hann LE, et al. Deep venous thrombosis after orthopedic surgery in adult cancer patients. J Surg Oncol 1998;68:41-7.
567. | Lindahl TL, Lundahl TH, Nilsson L, et al. APC-resistance is a risk factor for postoperative thromboembolism in elective replacement of the hip or knee--a prospective study. Thromb Haemost 1999;81:18-21
568. | Lobjoit K. [A retrospective evaluation of venous thrombosis prevention in regulated orthopedic surgery (1986-1989) at the Saint-Germain-en-Laye hospital center]. Agressologie 1990;31:158-9.
569. | Lowe GDO, Haverkate F, Thompson SG, et al. Prediction of deep vein thrombosis after elective hip replacement surgery by preoperative clinical and haemostatic variables: The ECAT DVT Study. Thromb Haemost 1999;81:879-86.
570. | Mahlfeld K, Franke J, Schaeper O, et al. [Heparin-induced thrombocytopenia as a complication of postoperative prevention of thromboembolism with unfractionated heparin/low molecular weight heparin after hip and knee prosthesis implantation]. Unfallchirurg 2002;105:327-31.
571. | Mantilla CB, Horlocker TT, Schroeder DR, et al. Risk factors for clinically relevant pulmonary embolism and deep venous thrombosis in patients undergoing primary hip or knee arthroplasty. Anesthesiology 2003;99:552-60.
572. | Masri BA, Dunlop DJ, McEwen JA, et al. Can a new design of pneumatic compression device reduce variations in delivered therapy for the mechanical prophylaxis of thromboembolic disease after total hip arthroplasty? Canadian Journal of Surgery 2004;47:263-9.
573. | McCardel BR, Lachiewicz PF, Jones K. Aspirin prophylaxis and surveillance of pulmonary embolism and deep vein thrombosis in total hip arthroplasty. J Arthroplasty 1990;5:181-5.
574. | McLaughlin JR, Lee KR. The outcome of total hip replacement in obese and non-obese patients at 10- to 18-years. Journal of Bone and Joint Surgery - Series B 2006;88:1286-92.
575. | Messieh M. Preoperative risk factors associated with symptomatic pulmonary embolism after total knee arthroplasty. Orthopedics 1999;22:1147-9.
576. | Mika P, Behounek J, Skotak M, et al. [Complications and risks associated with an anticoagulation therapy combining low molecular weight heparin and Warfarin after total replacement of large joints--our experience]. Acta Chir Orthop Traumatol Cech 2004;71:237-44.
577. | Míka P, Běhounek J, Skoták M, et al. Complications and risks associated with an anticoagulation therapy combining low molecular weight heparin and warfarin after total replacement of large joints - Our experience. Acta Chir Orthop Traumatol Cech 2004;71:237-44.
578. | Montrey JS, Kistner RL, Kong AYT. Thromboembolism following hip fracture. J Trauma 1985;25:534-7.
579. | Nakase J, Toribatake Y, Mouri Y, et al. Heparin versus danaproid for prevention of venous thromboembolism after hip surgery. J Orthop Surg 2009;17:6-9.
580. | Nathan SS, Simmons KA, Lin PP, et al. Proximal deep vein thrombosis after hip replacement for oncologic indications. J Bone Joint Surg Am 2006;88:1066-70.
581. | O.buehler K, D'Lima DD, Petersilge WJ, et al. Late deep venous thrombosis and delayed weightbearing after total hip arthroplasty. Clin Orthop 1999;:123-30.
582. | Patel A, Couband D, Feron JM, et al. [Prevention of deep venous thrombosis in arthroplastic surgery of the hip by the combination of heparinotherapy and the antithrombosis stocking]. Presse medicale 1988;17(23):1201-3.
583. | Pearse EO, Caldwell BF, Lockwood RJ, et al. Early mobilisation after conventional knee replacement may reduce the risk of postoperative venous thromboembolism. J Bone Joint Surg Br 2007;89:316-22.
584. | Philipp CS, Dilley A, Saidi P, et al. Deletion polymorphism in the angiotensin-converting enzyme gene as a thrombophilic risk factor after hip arthroplasty. Thromb Haemost 1998;80:869-73.
585. | Piecuch W, Sokolowska B, Dmoszynska A, et al. [Evaluation of selected parameters of blood coagulation and fibrinolysis system in patients undergoing total hip replacement surgery with normovolemic hemodilution procedure and standard enoxaparine prophylaxis]. Chir Narzadow Ruchu Ortop Pol 2003;68:95-9.
586. | Qiu XS, Wang F, Yao C, et al. Association Between Deep Vein Thrombosis and the Temperature at the Popliteal Fossa During Cement Curing in Total Knee Arthroplasty. J Arthroplasty 2011;26:414-418.
587. | Rader CP, Kramer C, Konig A, et al. Comparison of low molecular weight and PTT adjusted heparin for thromboprophylaxis in patients with total hip and total knee arthroplasty. Z Orthop Ihre 1997;135:52-7.
588. | Radziejewicz P, Gregosiewicz A, Bednarek A, et al. [The attempt of identification of the essentials risk factors of venous thromboembolism after hip arthroplasty despite of pharmacological prophylaxis]. Chir Narzadow Ruchu Ortop Pol 2010;75:242-247.
589. | Saltiel E, Shane R. Evaluating costs of a pharmacist-run thromboprophylaxis program. Formulary 1996;31:276-90.
590. | Salvati EA, Della Valle AG, Westrich GH, et al. The John Charnley award: Heritable thrombophilia and development of thromboembolic disease after total hip arthroplasty. Clin Orthop 2005;40-55.
591. | Sanchez-Ballester J, Smith M, Hassan K, et al. Wound infection in the management of hip fractures: a comparison between low-molecular weight heparin and mechanical prophylaxis. Acta Orthop Belg 2005;71:55-9.
592. | Sasaki S, Miyakoshi N, Matsuura H, et al. Prospective randomized controlled trial on the effect of fondaparinux sodium for prevention of venous thromboembolism after hip fracture surgery. J Orthop Sci 2009;14:491-6.
593. | Saunders ME, Grant RE. Cost effectiveness of low-molecular weight heparin versus warfarin following hip replacement surgery. J Natl Med Assoc 1998;90:677-80.
594. | Schiff RL, Kahn SR, Shrier I, et al. Identifying orthopedic patients at high risk for venous thromboembolism despite thromboprophylaxis. Chest 2005;128:3364-71.
595. | Seyfert C, Schulz K, Pap G. The influence of the drain suction in knee arthroplasty. Zentralbl Chir 2002;127:886-9
596. | Shaieb MD, Watson BN, Atkinson RE. Bleeding complications with enoxaparin for deep venous thrombosis prophylaxis. J Arthroplasty 1999;14:432-8.
597. | Sharrock NE, Hargett MJ, Urquhart B, et al. Factors affecting deep vein thrombosis rate following total knee arthroplasty under epidural anesthesia. J Arthroplasty 1993;8:133-9.
598. | Sokolowska B, Piecuch W, Walter-Croneck A, et al. [Evaluation of selected parameters of blood coagulation and the fibrinolysis system in patients undergoing total hip replacement]. Przegl Lek 2002;59:502-8.
599. | Solis MM, Ranval TJ, Nix ML, et al. Is anticoagulation indicated for asymptomatic postoperative calf vein thrombosis?. J Vasc Surg 1992;16:414-8.
600. | Stern SH, Wixson RL, O'Connor D. Evaluation of the safety and efficacy of enoxaparin and warfarin for prevention of deep vein thrombosis after total knee arthroplasty. J Arthroplasty 2000;15:153-8.
601. | Stulberg BN, Insall JN, Williams GW, et al. Deep-vein thrombosis following total knee replacement. An analysis of six hundred and thirty-eight arthroplasties. J Bone Joint Surg Am 1984;66:194-201.
602. | Svensson PJ, Benoni G, Fredin H, et al. Female gender and resistance to activated protein C (FV:Q506) as potential risk factors for thrombosis after elective hip arthroplasty. Thromb Haemost 1997;78:993-6.
603. | Szucs G, Ajzner E, Muszbek L, et al. Assessment of thrombotic risk factors predisposing to thromboembolic complications in prosthetic orthopedic surgery. J Orthop Sci 2009;14:484-90.
604. | Tian H, Song F, Zhang K, et al. [Efficacy and safety of aspirin in prevention of venous thromboembolism after total joint arthroplasty]. Chung Hua I Hsueh Tsa Chih 2007;87:3349-52.
605. | Torigoshi T, Motokawa S, Maeda Y, et al. Clinical relevance of heparin-PF4 complex antibody in DVT after total joint replacement. BMC Musculoskelet Disord 2009;10:42.
606. | Trowbridge A, Boese CK, Woodruff B, et al. Incidence of posthospitalization proximal deep venous thrombosis after total hip arthroplasty. Clin Orthop and related research 1993;299:203-208.
607. | Tsiridis E, Gamie Z, George MJ, et al. Early postoperative bleeding in polytrauma patients treated with fondaparinux: literature review and institutional experience. Curr Vasc Pharmacol 2011;9:42-47.
608. | Urbach D, Matzen KA, Heitmann D, et al. Relation between peri-operative antithrombin activity and deep vein thrombosis after elective hip replacement surgery. Vasa 2003;32:14-7.
609. | Villemur B, Bosson JL, Diamand JM. [Deep venous thrombosis (DVT) after hip or knee prosthesis. Evaluation of practices for prevention and prevalence of DVT on doppler ultrasonography]. J Mal Vasc 1998;23:257-62.
610. | Wang CJ, Wang JW, Weng LH, et al. Prevention of deep-vein thrombosis after total knee arthroplasty in Asian patients. Comparison of low-molecular-weight heparin and indomethacin. J Bone Joint Surg Am 2004;86-A:136-40.
611. | Westrich GH, Weksler BB, Glueck CJ, et al. Correlation of thrombophilia and hypofibrinolysis with pulmonary embolism following total hip arthroplasty: An analysis of genetic factors. Journal of Bone and Joint Surgery - Series A 2002;84:2161-7.
612. | Wille-Jorgensen P, Christensen SW, Bjerg-Nielsen A, et al. Prevention of thromboembolism following elective hip surgery. The value of regional anesthesia and graded compression stockings. Clin Orthop 1989;:163-7.
613. | Wolf LR, Hozack WJ, Balderston RA, et al. Pulmonary embolism. Incidence in primary cemented and uncemented total hip arthroplasty using low-dose sodium warfarin prophylaxis. J Arthroplasty 1992;7:465-70.
614. | Woolson ST. Intermittent pneumatic compression prophylaxis for proximal deep venous thrombosis after total hip replacement. J Bone Joint Surg Am 1996;78:1735-40.
615. | Woolson ST. The resolution of deep venous thrombosis that occurs after total joint arthroplasty. A study of thrombi treated with anticoagulation and observed by repeat venous ultrasound scans. Clin Orthop 1994;:86-91.
616. | Woolson ST, Zehnder JL, Maloney WJ. Factor V Leiden and the risk of proximal venous thrombosis after total hip arthroplasty. J Arthroplasty 1998;13:207-10.
617. | Yang G, Lu H, Gao J, et al. [Low-molecular-weight heparin for preventing deep-vein thrombosis after total joint arthroplasty]. Chung Hua Wai Ko Tsa Chih 2000;38:25-7.
618. | Yang Y-, Wang J-, Wu Y-, et al. Effects of different operation on postoperative deep venous thrombosis in lower extremities of old patients with femoral neck fracture. Journal of Jilin University Medicine Edition 2008;34:150-2.
619. | Yang Z, Liu X, Dai S, et al. [Effectiveness of low molecular weight heparin for prevention of deep vein thrombosis after total hip arthroplasty]. Chung-Kuo Hsiu Fu Chung Chien Wai Ko Tsa Chih/Chinese Journal of Reparative & Reconstructive Surgery 2010;24:1058-1061.
620. | Yoon H-, Han C-, Yang I-. Comparison of Simultaneous Bilateral and Staged Bilateral Total Knee Arthroplasty in Terms of Perioperative Complications. J Arthroplasty 2010;25:179-85.
621. | Zhao JZ; Song ZZ, Jian H, et al. Venous thromboembolism following total hip replacement and acute physiology and chronic health evaluation scores: A retrospective analysis of 98 cases. J Clin Rehab Tissue Eng Res 2010;14:4050-4052.
622. | Zhou W, Liu DH, Ma GT, et al. Relationship between pneumatic tourniquet application in total knee arthroplasty and hypercoagulability. J Clin Rehab Tissue Eng Res 2011;15:1541-1544.
Excluded because the study did no report an outcome of interest (n=20)
623. | Aglietti P, Baldini A, Vena LM, et al. Effect of tourniquet use on activation of coagulation in total knee replacement. Clin Orthop 2000;169-77.
624. | Bell GK, Goldhaber SZ. Cost implications of low molecular weight heparins as prophylaxis following total hip and knee replacement. Vasc Med 2001;6:23-9.
625. | Benkö T, Cooke EA, McNally MA, et al. Graduated compression stockings: Knee length or thigh length. Clin Orthop 2001;197-203.
626. | Cooke EA, Benkö T, O'Connell BM, et al. The effect of graduated compression stockings on lower limb venous haemodynamics. Phlebology 1996;11:141-5.
627. | Dranitsaris G, Kahn SR, Stumpo C, et al. Pharmacoeconomic analysis of fondaparinux versus enoxaparin for the prevention of thromboembolic events in orthopedic surgery patients. Am J Cardiovasc Drugs 2004;4:325-33.
628. | Fujisawa M, Naito M, Asayama I, et al. Effect of calf-thigh intermittent pneumatic compression device after total hip arthroplasty: comparative analysis with plantar compression on the effectiveness of reducing thrombogenesis and leg swelling. J Orthop Sci 2003;8:807-11.
629. | Honorato J, Gomez-Outes A, Navarro-Quilis A, et al. Pharmacoeconomic analysis of bemiparin and enoxaparin as prophylaxis for venous thromboembolism in total knee replacement surgery. Pharmacoeconomics 2004;22:885-94.
630. | Hull RD, Raskob GE, Pineo GF, et al. Subcutaneous low-molecular-weight heparin vs warfarin for prophylaxis of deep vein thrombosis after hip or knee implantation. An economic perspective. Arch Intern Med 1997;157:298-303.
631. | Hull RD, Raskob GE, Pineo GF, et al. Subcutaneous low-molecular-weight heparin vs warfarin for prophylaxis of deep vein thrombosis after hip or knee implantation: An economic perspective. Arch Intern Med 1997;157:298-303.
632. | Ilfeld BM, Le LT, Meyer RS, et al. Ambulatory continuous femoral nerve blocks decrease time to discharge readiness after tricompartment total knee arthroplasty: A randomized, triple-masked, placebo-controlled study. Anesthesiology 2008;108:703-13.
633. | Ishii Y, Matsuda Y. Effect of the timing of tourniquet release on perioperative blood loss associated with cementless total knee arthroplasty: A prospective randomized study. J Arthroplasty 2005;20:977-83.
634. | Levin LA, Bergqvist D. Cost effectiveness of desirudin compared with a low molecular weight heparin in the prevention of deep vein thrombosis after total hip replacement surgery. Pharmacoeconomics 2001;19:589-97.
635. | Macaulay W, Westrich G, Sharrock N, et al. Effect of pneumatic compression on fibrinolysis after total hip arthroplasty. Clin Orthop 2002;:168-76.
636. | Markel DC, Urquhart B, Derkowska I, et al. Effect of epidural analgesia on venous blood flow after hip arthroplasty. Clin Orthop 1997;:168-74.
637. | Neal BC, Rodgers A, Gray H, et al. No effect of low-dose aspirin for the prevention of heterotopic bone formation after total hip replacement: a randomized trial of 2,649 patients. Acta Orthop Scand 2000;71:129-34.
638. | Ofosu FA, Leclerc J, Delorme F, et al. The low molecular weight heparin Enoxaparin inhibits the consumption of factor VII and prothrombin activation in vivo associated with elective knee replacement surgery. Br J Haematol 1992;82:391-9.
639. | Ofosu FA, Levine M, Craven S, et al. Prophylactically equivalent doses of Enoxaparin and unfractionated heparin inhibit in vivo coagulation to the same extent. Br J Haematol 1992;82:400-5.
640. | Sorensen JV, Lassen MR, Borris LC, et al. Reduction of plasma levels of prothrombin fragments 1 and 2 during thromboprophylaxis with a low-molecular-weight heparin. Blood Coagul Fibrinolysis 1992;3:55-9.
641. | Tetro AM, Rudan JF. The effects of a pneumatic tourniquet on blood loss in total knee arthroplasty. Canadian Journal of Surgery 2001;44:33-8.
642. | Williams LA, Owen TD. Above-knee versus below-knee stockings in total knee arthroplasty. Ann R Coll Surg Engl 2006;88:302-5.
Excluded because the reported outcomes of interest did not meet diagnostic inclusion criteria (n=15)
643. | Anders JO, Fuhrmann R, Roth A, et al. [Can the number of thromboembolisms incidents in total hips replacement be further reduced?]. Z Orthop Ihre Grenzgeb 2004;142:328-32.
644. | Asano H, Matsubara M, Suzuki K, et al. Prevention of pulmonary embolism by a foot sole pump. Journal of Bone and Joint Surgery - Series B 2001;83:1130-2.
645. | Comp P, Happe LE, Sarnes M, et al. Venous thromboembolism clinically detected after hip fracture surgery with prophylaxis in a clinical practice setting. Am J Orthop 2008;37:470-5.
646. | Figus E, Gnudi S, Cagnano R. Thromboembolism in total hip replacement. Ital J Orthop Traumatol 1983;9:67-70.
647. | Fordyce MJ, Baker AS, Staddon GE. Efficacy of fixed minidose warfarin prophylaxis in total hip replacement. BMJ 1991;303:219-20.
648. | Kaempffe FA, Lifeso RM, Meinking C. Intermittent pneumatic compression versus coumadin. Prevention of deep vein thrombosis in lower-extremity total joint arthroplasty. Clin Orthop 1991;:89-97.
649. | Maezawa K, Nozawa M, Aritomi K, et al. Changes of D-dimer after total hip arthroplasty in patients with and without intraoperative heparin. Arch Orthop Trauma Surg 2008;128:37-40.
650. | Mohr DN, Silverstein MD, Ilstrup DM, et al. Venous thromboembolism associated with hip and knee arthroplasty: current prophylactic practices and outcomes. Mayo Clin Proc 1992;67:861-70.
651. | Muntz JE, O'Connor PJ, Yin H, et al. Factors associated with thromboprophylaxis for orthopedic patients and their impact on outcome. Am J Orthop 2007;36:193-7.
652. | Ohlund C, Fransson SG, Starck SA. Calf compressin for prevention of thromboembolism following hip surgery. Acta Orthop Scand 1983;54:896-899.
653. | Paramo JA, Alfaro MJ, Rocha E. Postoperative changes in the plasmatic levels of tissue-type plasminogen activator and its fast-acting inhibitor--relationship to deep vein thrombosis and influence of prophylaxis. Thromb Haemost 1985;54:713-6.
654. | Proctor MC, Greenfield LJ, Wakefield TW, et al. A clinical comparison of pneumatic compression devices: The basis for selection. Journal of Vascular Surgery 2001;34:459-64.
655. | Sweetland S, Green J, Liu B, et al. Duration and magnitude of the postoperative venous thromboembolism in middle aged women:prospective cohort study. BMJ 2009;339:b4583
656. | Tomita M, Motokawa S. Intraoperative heparin injection reduced D-dimer and TAT levels after total hip arthroplasty. Acta Med Nagasaki 2008;53:9-13.
657. | White RH, Gettner S, Newman JM, et al. Predictors of rehospitalization for symptomatic venous thromboembolism after total hip arthroplasty. N Engl J Med 2000;343:1758-64.

Table 2 Excluded studies at the full text level from search two

Excluded as a duplicate publication (n=1)
658. | Camporese G, Bernardi E, Prandoni P, et al. Low-molecular-weight heparin versus compression stockings for thromboprophylaxis after knee arthroscopy: a randomized trial. Ann Intern Med 2008;149:73-82.
Excluded because citation was not a full text systematic review, study or trial (n=25)
659. | Heparin prophylaxis for a leg cast?. Prescrire Int 2003;12:159.
660. | Archibeck MJ, White Jr. RE. What's new in adult reconstructive knee surgery. Journal of Bone and Joint Surgery – Series A 2003;85:1404-11.
661. | Balleisen L. [Prevention of embolisms]. Internist (Berl) 1998;39:1078-9.
662. | Camporese G, Bernardi E, Prandoni P, et al. Graduated compression stockings versus low molecular- weight heparin for prevention of deep vein thrombosis after knee arthroscopy. A randomized trial. Pathophysiology of Haemostasis and Thrombosis 2008;36:A21.
663. | Cole PA. What's New in Orthopaedic Trauma. Journal of Bone and Joint Surgery – Series A 2003;85:2260-9.
664. | Cole PA, Bhandari M. What's new in orthopaedic trauma. Journal of Bone and Joint Surgery – Series A 2006;88:2545-61.
665. | Cole PA, Bhandari M. What's new in orthopaedic trauma. Journal of Bone and Joint Surgery – Series A 2005;87:2823-38.
666. | Cole PA, Bhandari M. Specialty update: What's new in orthopaedic trauma. Journal of Bone and Joint Surgery – Series A 2004;86:2782-95.
667. | Gadgil A, Thomas RH. Current trends in thromboprophylaxis in surgery of the foot and ankle. Foot Ankle Int 2007;28:1069-73.
668. | Graftieaux JP. Neurosurgical air embolisms. Transesophageal echocardiography and dogmatic positions. Ann Fr Anesth Reanim 2001;20:587-91.
669. | Gupta A, Lutz GE. Synovial cysts: To fuse or not to fuse? Spine J 2010;10:817-819.
670. | Habscheid W, Spannagel U, Kujath P, et al. [Prevention of thrombosis with low molecular weight heparin in ambulatory patients with injury of the lower extremity: an ultrasound study]. Vasa Suppl 1991;33:222-3.
671. | Habscheid W, Spannagel U, Kujath P, et al. Thrombosis prophylaxis with low molecular heparin in ambulatory patients with injuries of the lower limb: A sonographic study. THROMBOSEPROPHYLAXE MIT NIEDERMOLEKULAREM HEPARIN BEI AMBULANTEN PATIENTEN MIT VERLETZUNG DER UNTEREN EXTREMITAT: EINE SONOGRAPHISCHE STUDIE. VASA J.VASC.DIS 1991;20:222-3.
672. | Jorgensen LN, Lykke J. [Thrombosis prophylaxis in knee arthroscopy. A survey of a Cochrane review]. Ugeskr Laeger 2008;170:3646-9.
673. | Kooli M, Houissa M, Zlitni M. Thromboembolic diseases in the orthopedic setting. Tunisie Medicale 2005;83:17-23.
674. | Kotani N, Tanioka F, Tsubo T, et al. Systemic heparinization during postoperative pulmonary embolism induces fatal complications [3]. Eur J Anaesthesiol 2002;19:382-4.
675. | Leyes M, Torres R, Guillén P. Complications of open reduction and internal fixation of ankle fractures. Foot Ankle Clin 2003;8:131-47.
676. | Ozier Y, Lentschener C. Non-pharmacological approaches to decrease surgical blood loss. Canadian Journal of Anesthesia 2003;50
677. | Ploumis A, Ponnappan RK, Bessey JT, et al. Thromboprophylaxis in spinal trauma surgery: consensus among spine trauma surgeons. Spine Journal 2009;9:530-6.
678. | Sabharwal S. Blount disease. J Bone Jt Surg Ser A 2009;91:1758-76.
679. | Scalea TM. Optimal timing of fracture fixation: Have we learned anything in the past 20 years? J Trauma Inj Infect Crit Care 2008;65:253-60.
680. | Weinlein J, Schmidt AH. What's new in orthopaedic trauma? J Bone Jt Surg Ser A 2010;92:2247-2260.
681. | Wirth T, Misselwitz F, Schneider B, et al. Low molecular weight heparin (reviparin) for the prevention of venous thromboembolism after knee arthroscopy. Results of a randomized controlled trial. Ann Hematol 2001;80:A72.
682. | Wolf N, Meiser H, Berg U, et al. [Ambulatory prevention of thrombosis in a traumatologic patient sample]. Vasa Suppl 1992;35:109.
683. | Yuan PS, Albert TJ. Nonsurgical and surgical management of lumbar spinal stenosis. Journal of Bone and Joint Surgery - Series A 2004;86:2320-30.
Excluded because the study was not conducted in humans (n=1)
684. | Duhautois B. L'enclouage verrouillé dans le traitement des fractures du chien et du chat: Étude rétrospective sur 121 cas (1992-1999). Pratique Medicale et Chirurgicale de l'Animal de Compagnie 2001;36:481-96.
Excluded because the population was outside of orthopedic surgeries of interest (n=24)
685. | Aito S, Pieri A, D'Andrea M, et al. Primary prevention of deep venous thrombosis and pulmonary embolism in acute spinal cord injured patients. Spinal Cord 2002;40:300-3.
686. | Baba-Ahmed M, Le Gal G, Couturaud F, et al. High frequency of factor V Leiden in surgical patients with symptomatic venous thromboembolism despite prophylaxis. Thromb Haemost 2007;97:171-5.
687. | Catre MG. Anticoagulation in spinal surgery. A critical review of the literature. Canadian Journal of Surgery 1997;40:413-7.
688. | Cheng JS, Arnold PM, Anderson PA, et al. Anticoagulation risk in spine surgery. Spine 2010;35
689. | Chylarecki C, Hierholzer G, Rudofsky G. [Physical prevention of thrombosis with the ankle joint with the motorized ankle joint movement device. Initial results of a clinical study]. Unfallchirurgie 1995;21:137-47.
690. | Collen JF, Jackson JL, Shorr AF, et al. Prevention of venous thromboembolism in neurosurgery: A metaanalysis. Chest 2008;134:237-49.
691. | Gallus AS, Hirsh J, O'Brien SE, et al. Prevention of venous thrombosis with small, subcutaneous doses of heparin. JAMA 1976;235:1980-2.
692. | Glotzbecker MP, Bono CM, Wood KB, et al. Thromboembolic disease in spinal surgery: A systematic review. Spine 2009;34:291-303.
693. | Jameson SS, Bottle A, Malviya A, et al. The impact of national guidelines for the prophylaxis of venous thromboembolism on the complications of arthroplasty of the lower limb. J Bone Joint Surg Br 2010;92:123-9.
694. | Jorgensen PS, Warming T, Hansen K, et al. Low molecular weight heparin (Innohep) as thromboprophylaxis in outpatients with a plaster cast: a venografic controlled study. Thromb Res 2002;105:477-80.
695. | Kim HJ, Walcott-Sapp S, Adler RS, et al. Thromboembolic Complications Following Spine Surgery Assessed with Spiral CT Scans. HSS J 2011;7:37-40.
696. | Li T, Lv M, Li Q. [Comprehensive prophylaxis for deep venous thrombosis after proximal femur fractures in geriatric patients]. Chung Kuo Hsiu Fu Chung Chien Wai Ko Tsa Chih 2008;22:453-5.
697. | Maffulli N, Waterston SW, Squair J, et al. Changing incidence of achilles tendon rupture in Scotland: A 15-year study. Clin J Sport Med 1999; 9:157-60.
698. | Mora S, Zalavras CG, Wang L, et al. The role of pulsatile cold compression in edema resolution following ankle fractures: A randomized clinical trial. Foot and Ankle International 2002;23:999-1002.
699. | Ploumis A, Ponnappan RK, Maltenfort MG, et al. Thromboprophylaxis in patients with acute spinal injuries: An evidence-based analysis. Journal of Bone and Joint Surgery - Series A 2009;91:2568-76.
700. | Sansone JM, Del Rio AM, Anderson PA. The prevalence of and specific risk factors for venous thromboembolic disease following elective spine surgery. J Bone Jt Surg Ser A 2010;92:304-313.
701. | Schellong SM, Beyer J, Kakkar AK, et al. Ultrasound screening for asymptomatic deep vein thrombosis after major orthopaedic surgery: the VENUS study. J Thromb Haemost 2007; 5:1431-7.
702. | Smith WD, Dakwar E, Le TV, Christian G, et al. Minimally invasive surgery for traumatic spinal pathologies: A mini-open, lateral approach in the thoracic and lumbar spine. Spine 2010;35:S338-S346.
703. | Thordarson DB. Facilitating edema resolution with a foot pump after calcaneus fracture. J Orthop Trauma 1998;13:43-6.
704. | Thumbikat P, Poonnoose PM, Balasubrahmaniam P, et al. A comparison of heparin/warfarin and enoxaparin thromboprophylaxis in spinal cord injury: The Sheffield experience. Spinal Cord 2002;40:416-20.
705. | Turpie AGG, Bauer KA, Eriksson BI, et al. Superiority of fondaparinux over enoxaparin in preventing venous thromboembolism in major orthopedic surgery using different efficacy end points. CHEST 2004; 126:501-8.
706. | Vallier HA, Cureton BA, Ekstein C, et al. Early definitive stabilization of unstable pelvis and acetabulum fractures reduces morbidity. J Trauma Inj Infect Crit Care 2010;69:677-684.
707. | Wille-Jorgensen P, Jorgensen LN, Crawford M. Asymptomatic postoperative deep vein thrombosis and the development of postthrombotic syndrome: A systematic review and meta-analysis. Thromb Haemost 2005; 93:236-41.
708. | Yadla,S.;Malone,J.;Campbell,P. G.;Maltenfort,M. G.;Harrop,J. S.;Sharan,A. D.;Ratliff,J. K.
Excluded because the study was not controlled (n=9)
709. | Cullison TR, Muldoon MP, German JD, et al. The incidence of deep venous thrombosis in anterior cruciate ligament reconstruction. Arthroscopy 1996;12:657-9.
710. | Gerlach R, Raabe A, Beck J, et al. Postoperative nadroparin administration for prophylaxis of thromboembolic events is not associated with an increased risk of hemorrhage after spinal surgery. European Spine Journal 2004;13:9-13.
711. | Hara N, Minami T. Diffusive pulmonary embolism with bone fragments during spinal surgery [7]. Br J Anaesth 2006;97:119-20.
712. | Hönemann CW, Brodner G, Van Aken H, et al. Aortic perforation during lumbar laminectomy. Anesth Analg 1998;86:493-5.
713. | Quinn RH, Drenga J. Perioperative morbidity and mortality after reconstruction for metastatic tumors of the proximal femur and acetabulum. J Arthro 2006; 21(2):227-32.
714. | Saragaglia D, Blaysat M, Inman D, et al. Outcome of opening wedge high tibial osteotomy augmented with a BiosorbÂ® wedge and fixed with a plate and screws in 124 patients with a mean of ten years follow-up. Int Orthop 2010;1-6
715. | Shah AK, Moreno-Aspitia A. Acquired factor V inhibitor and single exposure to autologous growth factor. Thromb Res 2005;116:87-9.
716. | Smith JS, Fu KMG, Polly DW, et al. Complication rates of three common spine procedures and rates of thromboembolism following spine surgery based on 108,419 procedures: A report from the scoliosis research society morbidity and mortality committee. Spine 2010;35:2140-2149.
717. | Solis G, Saxby T. Incidence of DVT following surgery of the foot and ankle. Foot Ankle Int 2002; 23(5):411-14.
Excluded because the study did not evaluate a comparison of interest (n=27)
718. | Camporese G. Bernardi E. Prandoni P. Noventa F. Verlato F. Simioni P. Ntita K. Salmistraro G. Frangos C. Rossi F. Cordova R. Franz F. Zucchetta P. Kontothanassis D. Andreozzi GM. KANT (Knee Arthroscopy Nadroparin Thromboprophylaxis) Study Group. Ann Intern Med 2008;149:73-82.
719. | Ferree BA, Wright AM. Deep venous thrombosis following posterior lumbar spinal surgery. Spine 1993;18:1079-82.
720. | Gehling H, Giannadakis K, Lefering R, et al. [Prospective randomized pilot study of ambulatory prevention of thromboembolism. 2 times 500 mg aspirin (ASS) vs. clivarin 1750 (NMH)]. Unfallchirurg 1998;101:42-9.
721. | Kim HJ, Kepler C, Cunningham M, et al. Pulmonary embolism in spine surgery: A comparison of combined anterior/posterior approach versus posterior approach surgery. Spine 2011;36:177-179.
722. | Kock HJ, Schmit NKP, Hanke J, et al. Patient compliance during low molecular weight heparin thromboprophylaxis in outpatients with plaster cast immobilisation of the leg. Unfallchirurgie 1994;20:319-28.
723. | Kock HJ, Schmit-Neuerburg KP, Hanke J, et al. [Ambulatory prevention of thrombosis with low molecular weight heparin in plaster immobilization of the lower extremity]. Chirurg 1993;64:483-91.
724. | Kock HJ, Schmit-Neuerburg KP, Hanke J, et al. Thromboprophylaxis with low-molecular-weight heparin in outpatients with plaster-cast immobilisation of the leg. Lancet 1995;346:459-61.
725. | Kock HJ, Schmit-Neuerburg KP, Hanke J, et al. [Implementing ambulatory prevention of thrombosis with low molecular weight heparin in plaster immobilization of the lower extremity]. Unfallchirurgie 1994;20:319-28.
726. | Kock HJ, SchmittNeuerburg KP, Hanke J, et al. Prophylaxis of venous thromboembolism with low molecular weight heparin in surgical outpatients with immobilization of the lower limb by plaster cast. Hamostaseologie 1993;13:S36-9.
727. | Kujath P, Spannagel U, Habscheid W. Incidence and prophylaxis of deep venous thrombosis in outpatients with injury of the lower limb. Haemostasis 1993;23:20-6.
728. | Lapidus LJ, Ponzer S, Elvin A, et al. Prolonged thromboprophylaxis with Dalteparin during immobilization after ankle fracture surgery: a randomized placebo-controlled, double-blind study. Acta Orthop 2007;78:528-35.
729. | Lassen MR, Borris LC, Nakov RL. Use of the low-molecular-weight heparin reviparin to prevent deep-vein thrombosis after leg injury requiring immobilization. N Engl J Med 2002;347:726-30.
730. | Ma Y, Passias P, Gaber-Baylis LK, et al. Comparative in-hospital morbidity and mortality after revision versus primary thoracic and lumbar spine fusion. Spine J 2010;10:881-889.
731. | Marlovits S, Striessnig G, Schuster R, et al. Extended-duration thromboprophylaxis with enoxaparin after arthroscopic surgery of the anterior cruciate ligament: a prospective, randomized, placebo-controlled study. Arthroscopy 2007;23:696-702.
732. | Misselwitz F, Wirth T, Tuylu H, et al. Prevention of venous thromboembolism after knee arthroscopy. Combined data of a randomised controlled trial and a large outpatient cohort treated with reviparin. Ann Hematol 2002;81:A57
733. | Motycka T, Eggerth G, Landsiedl F. The incidence of thrombosis in high tibial osteotomies with and without the use of a tourniquet. Arch Orthop Trauma Surg 2000;120:157-9.
734. | Nasser R, Yadla S, Maltenfort MG, et al. Complications in spine surgery a review. J Neurosurg Spine 2010;13:141-143.
735. | Nelson LD,Jr, Montgomery SP, Dameron TB,Jr, et al. Deep vein thrombosis in lumbar spinal fusion: a prospective study of antiembolic and pneumatic compression stockings. J South Orthop Assoc 1996;5:181-4.
736. | Normand R, Mathieu JP. [Prevention of venous thromboses under plaster casts after leg injury. Comparison of heparin-calcium and pentosan sulfuric polyester]. Cah Anesthesiol 1987;35:559-62.
737. | Rokito SE, Schwartz MC, Neuwirth MG. Deep vein thrombosis after major reconstructive spinal surgery. Spine 1996;21:853-9.
738. | Roth VP. Prophylaxis of deep vein thrombosis in outpatients undergoing arthroscopic menisci operation. Orthopadische Praxis 1995; 5:345-8.
739. | Smith TO, Hing CB. The efficacy of the tourniquet in foot and ankle surgery? A systematic review and meta-analysis. Foot and Ankle Surgery 2010;16:3-8.
740. | Smith TO, Hing CB. A meta-analysis of tourniquet assisted arthroscopic knee surgery. Knee 2009;16:317-21.
741. | SooHoo NF, Eagan M, Krenek L, et al. Incidence and factors predicting pulmonary embolism and deep venous thrombosis following surgical treatment of ankle fractures. Foot Ankle Surg 2010.
742. | Spannagel U, Kujath P. Low molecular weight heparin for the prevention of thromboembolism in outpatients immobilized by plaster cast. Semin Thromb Hemost 1993;19:131-41.
743. | Wirth T, Schneider B, Misselwitz F, et al. Prevention of venous thromboembolism after knee arthroscopy with low-molecular weight heparin (reviparin): Results of a randomized controlled trial. Arthroscopy 2001;17:393-9.
744. | Wood KB, Kos PB, Abnet JK, et al. Prevention of deep-vein thrombosis after major spinal surgery: A comparison study of external devices. J Spinal Disord 1997;10:209-14.
Excluded because the study did no report an outcome of interest (n=4)
745. | Ahmad S, Bacher HP, Lassen MR, et al. Investigations of the immunoglobulin subtype transformation of anti-heparin-platelet factor 4 antibodies during treatment with a low-molecular-weight heparin (clivarin) in orthopedic patients. Arch Pathol Lab Med 2003;127:584-8.
746. | Stöckle U, Hoffmann R, Raschke M, et al. Intermittent impulse compression. A new method of reducing post-traumatic and postoperative edema. Chirurg 1996;67:539-45
747. | Stöckle U, Hoffmann R, Schütz M, et al. Fastest reduction of posttraumatic edema: Continuous cryotherapy or intermittent impulse compression? Foot and Ankle International 1997;18:432-8.
748. | Thordarson DB, Ghalambor N, Perlman M. Intermittent pneumatic pedal compression and edema resolution after acute ankle fracture: A prospective, randomized study. Foot and Ankle International 1997;18:347-50.