# Search Strategy

Search one and search two were originally conduceted in July 2010 and were both updated, following the same methodology, in May 2011.

## Search 1 Major orthopedic surgery

### Medline and Cochrane Central Register of Controlled Trials (OVID)

1. arthroplasty, replacement, knee/
2. knee.mp AND arthroplasty/
3. total knee replacement.mp
4. knee arthroplasty.mp
5. TKR.mp
6. knee prosthesis/
7. knee prosthesis.mp
8. knee joint.mp
9. arthroplasty, replacement, hip/
10. hip.mp AND arthroplasty/
11. total hip replacement.mp
12. hip arthroplasty.mp
13. THR.mp
14. hip prosthesis/
15. hip prosthesis.mp
16. hip fracture surgery.mp
17. HFS.mp
18. hip.mp AND fracture fixation, internal/
19. or/1-18
20. pulmonary embolism/
21. pulmonary embol*.mp
22. pulmonary thromboembol*.mp
23. PE.mp
24. deep vein thrombos*.mp
25. deep venous thrombos*.mp
26. deep venous thromboembol*.mp
27. deep vein thromboembol*.mp
28. DVT.mp
29. venous thromboembolism/
30. venous thromboembol*.mp
31. VTE.mp
32. venous thrombosis/
33. venous thrombos*.mp
34. clot.mp
35. or/20-34
36. anticoagulants/
37. aspirin/
38. aspirin.mp
39. clopidogrel.mp
40. ticlopidine.mp
41. prasugrel.mp
42. heparin/
43. heparinoids/
44. heparin.mp
45. UFH.mp
46. heparin, low-molecular weight/
47. low molecular weight heparin.mp
48. LMWH.mp
49. enoxaparin.mp
50. dalteparin.mp
51. nadroparin.mp
52. ardeparin.mp
53. bemiparin.mp
54. certoparin.mp
55. parnaparin.mp
56. reviparin.mp
57. tinzaparin.mp
58. danaparoid.mp
59. fondaparinux.mp
60. idraparinux.mp
61. rivaroxaban.mp
62. hirudins/
63. desirudin.mp
64. argatroban.mp
65. bivalirudin.mp
66. lepirudin.mp
67. dabigatran.mp
68. warfarin/
69. 4-Hydroxycoumarins/
70. warfarin.mp
71. acenocoumarol.mp
72. dicoumarol.mp
73. dextran sulfate/
74. dextran sulfate.mp
75. or/36-74
76. stockings, compression/
77. compression stocking.mp
78. compression stockings.mp
79. compression boot.mp
80. graduated compression stocking.mp
81. graduated compression stockings.mp
82. elastic stocking.mp
83. elastic stockings.mp
84. graduated compression stocking.mp
85. graduated compression stockings.mp
86. GCS.mp
87. venous foot pump.mp
88. VFP.mp
89. intermittent pneumatic compression devices/
90. intermittent pneumatic compression.mp
91. pneumatic compression stocking.mp
92. pneumatic compression stockings.mp
93. pneumatic hose.mp
94. pneumatic compression hose.mp
95. IPC.mp
96. or/76-95
97. vena cava filters/
98. vena cava filter.mp
99. vena cava filters.mp
100. IVC.mp
101. or/97-100
102. 75 or 96 or 101
103. 19 and 35 and 102

### Scopus

((((ALL(anticoagulants OR aspirin OR clopidogrel OR ticlopidine OR prasugrel OR heparin OR heparinoids OR ufh OR low-molecular weight heparin OR low molecular weight heparin OR lmwh OR enoxaparin OR dalteparin OR nadroparin OR ardeparin OR bemiparin OR certoparin OR parnaparin OR reviparin OR tinzaparin OR danaparoid OR fondaparinux OR idraparinux OR rivaroxaban OR hirudin OR desirudin OR argatroban OR bivalirudin OR lepirudin OR dabigatran OR warfarin OR 4-hydroxycoumarin OR acenocoumarol OR dicoumarol OR dextran sulfate)) OR (ALL(vena cava filters OR vena cava filter OR ivc)) OR (((((ALL(compression stocking$)) OR (ALL(graduated compression stocking$)) OR (ALL(elastic stocking$)) OR (ALL(venous foot pump)) OR (ALL(intermittent pneumatic compression)))) OR (ALL(pneumatic compression)))))) AND (((((ALL(deep vein thrombos*)) OR (ALL(deep venous thrombos*)) OR (ALL(venous thromboembol*)) OR (ALL(deep vein thrombos*)) OR (ALL(deep venous thrombos*)))) OR (((ALL(venous thromboembol*)) OR (ALL(pulmonary thromboembol*)) OR (ALL(pulmonary embol*)) OR (ALL(venous thrombos*)))))) AND (((ALL(knee replacement)) OR (ALL(knee arthroplasty)) OR (ALL(hip arthroplasty)) OR (ALL(hip replacement)) OR (ALL(hip fracture surgery)))))

## Search 2 Other orthopedic surgery

### Medline and Cochrane Central Register of Controlled Trials (OVID)

1. knee arthroscop*
2. arthroscop* adj knee
3. meniscectomy ADJ arthroscop*
4. synovectomy ADJ arthroscop*
5. cruciate ligament AND (arthroscop* OR repair)
6. casts, surgical/OR casts, surgical.mp
7. plaster cast.mp
8. splint*.mp OR splints/
9. Achilles ADJ tendon
10. tibial plateau fracture.mp
11. distal ADJ femur fracture.mp
12. lumbar ADJ laminectomy.mp
13. lumbar ADJ diskectomy.mp
14. lumbar ADJ spinal fusion.mp
15. (fracture fixation, internal/OR fracture fixation, intramedullary/) AND (femur OR femor* OR tibia* OR ankle OR foot)
16. osteotomy.mp AND (femur OR femor* OR tibia*)
17. or/1-16
18. anticoagulants/
19. aspirin/
20. aspirin.mp
21. clopidogrel.mp
22. ticlopidine.mp
23. prasugrel.mp
24. heparin/
25. heparinoids/
26. heparin.mp
27. UFH.mp
28. heparin, low-molecular weight/
29. low molecular weight heparin.mp
30. LMWH.mp
31. enoxaparin.mp
32. dalteparin.mp
33. nadroparin.mp
34. ardeparin.mp
35. bemiparin.mp
36. certoparin.mp
37. parnaparin.mp
38. reviparin.mp
39. tinzaparin.mp
40. danaparoid.mp
41. fondaparinux.mp
42. idraparinux.mp
43. rivaroxaban.mp
44. hirudins/
45. desirudin.mp
46. argatroban.mp
47. bivalirudin.mp
48. lepirudin.mp
49. dabigatran.mp
50. warfarin/
51. 4-Hydroxycoumarins/
52. warfarin.mp
53. acenocoumarol.mp
54. dicoumarol.mp
55. dextran sulfate/
56. dextran sulfate.mp
57. or/18-56
58. stockings, compression/
59. compression stocking.mp
60. compression stockings.mp
61. compression boot.mp
62. graduated compression stocking.mp
63. graduated compression stockings.mp
64. elastic stocking.mp
65. elastic stockings.mp
66. graduated compression stocking.mp
67. graduated compression stockings.mp
68. GCS.mp
69. venous foot pump.mp
70. VFP.mp
71. intermittent pneumatic compression devices/
72. intermittent pneumatic compression.mp
73. pneumatic compression stocking.mp
74. pneumatic compression stockings.mp
75. pneumatic hose.mp
76. pneumatic compression hose.mp
77. IPC.mp
78. or/58-77
79. pulmonary embolism/
80. pulmonary embol*.mp
81. pulmonary thromboembol*.mp
82. PE.mp
83. deep vein thrombos*.mp
84. deep venous thrombos*.mp
85. deep venous thromboembol*.mp
86. deep vein thromboembol*.mp
87. DVT
88. venous thromboembolism/
89. venous thromboembol*.mp
90. VTE
91. venous thrombosis/
92. venous thrombos*.mp
93. clot.mp
94. or/79-93
95. 57 or 78
96. 17 and 94 and 95

### Scopus

((((((lumbar PRE/1 spinal fusion) OR (lumbar PRE/1 diskectomy) OR (lumbar PRE/1 laminectomy) OR (open reduction internal fixation PRE/1 ankle) OR (open reduction internal fixation PRE/1 foot))) OR (((open reduction internal fixation PRE/1 tibia*) OR (open reduction internal fixation PRE/1 femur*) OR (osteotomy PRE/1 femur*) OR (osteotomy PRE/1 tibia*) OR (distal PRE/1 femur* fracture) OR (tibial plateau fracture) OR (intermedullary fixation))))) AND (((((ALL(deep vein thrombos*)) OR (ALL(deep venous thrombos*)) OR (ALL(venous thromboembol*)) OR (ALL(deep vein thrombos*)) OR (ALL(deep venous thrombos*)))) OR (((ALL(venous thromboembol*)) OR (ALL(pulmonary thromboembol*)) OR (ALL(pulmonary embol*)) OR (ALL(venous thrombos*)))))