# Appendixes

Appendix A Search Strategy

Appendix B Data Extraction Form

Appendix C Excluded Studies From Full-Text Review

Appendix D Quality and Characteristics of Included Trials and Studies

Appendix E Baseline and Procedural Characteristics of Included Trials and Studies

Appendix F Additional Evidence Tables

Appendix G Forest Plots

Appendix H Strength of Evidence Rating

Appendix I Applicability Rating for Individual Trials and Studies and the Body of Evidence

Appendix J Glossary