# Acronyms/Abbreviations

AOR: Adjusted odds ratio
CI: Confidence interval
EPC: Evidence-based Practice Center
Mg: Milligrams
NNH: Number needed to harm
NNT: Number needed to treat
OR: Peto's odds ratio
PRISMA: Preferred Reporting Items for Systematic Reviews and Meta-Analyses
RR: Relative risk