# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project: Sharone Giovonale, Robert Quercia, Jeffrey Mather, and Nancy White.