# Systematic Reviews

Table 36 lists the indications to be addressed as part of the systematic reviews of this report.

Table 36 Pediatric HSCT indications to be addressed with systematic review

Condition | Indication(s) | Type of Transplant | Comparator
Malignant Nonhematopoietic
Ewing sarcoma family of tumors (ESFT) | Consolidate high-risk (initial) Relapsed/refractory | Auto Auto Tandem Auto Auto | Conventional Chemotherapy Conventional Chemotherapy Single Autologous
Wilms | Consolidate high risk Relapsed/refractory | Auto Auto Tandem Auto Auto | Conventional Chemotherapy Conventional Chemotherapy Single Autologous
Rhabdomyosarcoma (RMS) | Metastatic Disease | Auto Tandem Auto Auto | Conventional Chemotherapy Single Autologous
Retinoblastoma | Extraocular Spread | Auto Tandem Auto Auto | Conventional Chemotherapy Single Autologous
Neuroblastoma (NB) | Consolidate high-risk (initial) Relapsed/refractory | Tandem Auto Auto | Single Autologous
Germ cell tumor (GCT) | Relapsed | Tandem Auto Auto | Single Autologous
Central Nervous System Embryonal Tumors | Initial therapy | Auto Tandem Auto Auto | Conventional Chemotherapy Single Autologous
CNS Glial Tumors | Consolidate high risk Relapsed/refractory | Auto Auto | Conventional Chemotherapy
Nonmalignant
Inherited metabolic diseases [underlined: Mucopolysaccharidosis] MPS II (Hunter's), MPS III (Sanfilippo), MPS IV (Morquio) [underlined: Sphingolipidosis] Fabry's, Farber's , Gaucher II-III, GM_1_ gangliosidosis, Niemann-Pick disease A, Tay-Sachs, Sandhoff's disease [underlined: Glycoproteinosis] Aspartylglucosaminuria, beta-Mannosidosis, Mucolipidosis III and IV [underlined: Other lipidoses] Niemann-Pick disease C, Wolman disease, Ceroid lipofuscinosis [underlined: Glycogen storage] GSD type II [underlined: Multiple enzyme deficiency] Galactosialidosis, Mucolipidosis type II [underlined: Lysosomal transport defects] Cystinosis, Sialic acid storage disease, Salla disease [underlined: Peroxisomal storage disorders] Adrenomyeloneuropathy | Variable | Allo | Enzyme-replacement therapy, substrate reduction with iminosugars and chaperones
Autoimmune including juvenile rheumatoid arthritis (JRA), systemic lupus erythematosus (SLE), scleroderma, immune cytopenias, Crohn's | Upfront for severe/ refractory or salvage | Auto/allo | Immunosuppressants, targeted biologic therapies and low-dose chemotherapy
Autoimmune type 1 diabetes mellitus (DM) | Variable | Auto | Immunosuppressants, targeted biologic therapies and low-dose chemotherapy, conventional management (i.e., insulin injections)

allo = allogeneic; auto = autologous; DM = diabetes mellitus; ESFT = Ewing sarcoma family of tumors; GCT = germ cell tumor; HL = Hodgkin's lymphoma; JRA = juvenile rheumatoid arthritis; MDS = myelodysplastic syndrome; OS = osteosarcoma; PNET = primitive neuroectodermal tumor; RMS = rhabdomyosarcoma; SLE = systemic lupus erythematosus; TKI = tyrosine kinase inhibitor

## Systematic Reviews: Malignant, Nonhematopoietic Disease

### Ewing's Sarcoma Family of Tumors Systematic Review

#### Background and Indication

The Ewing's sarcoma family of tumors (ESFT) is the second most common primary malignant bone tumor in children, adolescents and young adults. ESFTs include Ewing tumor of bone (classic Ewing sarcoma and primitive neuroectodermal tumor or PNET) and extraosseous Ewing (i.e., Ewing sarcoma in a site other than bone). The incidence of ESFT is approximately 3 cases per 1,000,000 persons per year. The incidence in the U.S. population is one per 1,000,000 in the population.352 The median age of patients is 15 years, and more than 50 percent of patients are adolescents. Primary sites of bone disease include lower extremity (41 percent), pelvis (26 percent), chest wall (16 percent), upper extremity (9 percent), spine (6 percent) and skull (2 percent).352 Primary sites of extraosseous Ewing's are trunk (32 percent), extremity (26 percent), head and neck (18 percent), retroperitoneum (16 percent) and other sites (9 percent).352 Approximately 25 percent of patients will have metastatic disease at diagnosis.352

Certain adverse prognostic factors place some patients with ESFT into a high-risk category: relapsed or resistant disease, primary tumor site in the axial skeleton, including pelvis, large tumor volume, and the presence of metastatic disease (patients with isolated lung metastases are considered to have better prognosis than patients with metastases to bone and/or bone marrow). Treatment of ESFT includes systemic chemotherapy in conjunction with either surgery or radiation or both for local tumor control.

Overall survival rates for localized ESFT have dramatically improved over the last 30 years, however, the prognosis for patients with high-risk tumors treated with conventional chemotherapy, radiation and surgery remain poor, with long-term survival rates for patients with metastatic disease less than 35 percent.352 Patients with lung-only metastases have been reported to have 4-year EFS of approximately 40 percent, whereas patients with bone/bone marrow metastases have 4-year EFS of approximately 28 percent and with combined lung and bone/bone marrow metastases 4-year EFS of approximately 14 percent. Relapsed ESFT treated with conventional-dose chemotherapy, radiation and surgery has been reported to have a 2-year event free survival of less than 10 percent.

Chemotherapy for patients with ESFT initially was based on four drugs: doxorubicin, cyclophosphamide, vincristine, and dactinomycin. More recently, treatment has included ifosfamide, with or without etoposide. Dose-intensive chemotherapy regimens as well as HSCT have been investigated in patients with high-risk ESFT in an effort to improve survival.

#### Evidence Summary

The overall grade of strength of evidence for overall survival and the use of single and tandem HSCT for the treatment of high-risk Ewing's Sarcoma Family of Tumors (ESFT) is shown in Table 37.

Table 37 Overall grade of strength of evidence for overall survival and the use of single and tandem HSCT for the treatment of high-risk Ewing's Sarcoma Family of Tumors (ESFT)

HSCT Type | Key Question | Study Design | Risk of Bias | Consistency | Directness | Precision | Strength of Association | Overall Grade/Conclusion
Single HSCT | For pediatric patients with high-risk ESFT, what is the comparative effectiveness and harms of HSCT and conventional chemotherapy regarding overall survival? Comparator is conventional chemotherapy. Outcome of interest is overall survival. | The evidence for HSCT consists of 24 case series and 6 case reports. Comparator data consists of 7 case series. Data consist of 446 HSCT patients and 283 conventional chemotherapy patients. | The risk of bias in this evidence is high. Studies consisted of case reports or small case series, and incorporated heterogeneous patient populations. | Results for overall survival are consistent. Among the larger studies, for both HSCT and chemotherapy, the 5-year OS outcomes fall within the same range. | The outcome reported, overall survival, is direct. The comparisons are indirect as the evidence base utilizes two or more bodies of evidence to make comparisons. | The evidence is precise. While the evidence is qualitative, it is unlikely that a clinically important superiority exists for HSCT for the treatment of high-risk ESFT compared to conventional chemotherapy. | Not applicable due to lack of obvious effect size. | Low strength evidence on overall survival suggests no benefit with single HSCT compared to conventional therapy for the treatment of high-risk ESFT.
Tandem autologous-autologous HSCT | For pediatric patients with high-risk ESFT, what is the comparative effectiveness and harms of tandem autologous-autologous HSCT and single HSCT regarding overall survival? Comparator is single HSCT. Outcome of interest is overall survival. | Evidence for tandem HSCT consists of 2 case series and 1 case report. Comparator data used consists of 24 case series and 6 case reports. Data consist of 22 tandem HSCT patients and 446 single HSCT patients. | The risk of bias in this evidence is high. Studies consisted of 1 case report and 2 small case series. | Results for overall survival are unknown. Among the 3 studies using tandem HSCT, overall survival was not reported, and overall survival data could be calculated from one study only. | The outcomes reported are direct. The comparisons are indirect as the evidence base utilizes two or more bodies of evidence to make comparisons. | The evidence is imprecise; effects are uncertain. There is uncertainty on whether tandem HSCT is inferior, equivalent or superior to single HSCT. | Not applicable due to lack of obvious effect size. | The body of evidence on overall survival with tandem HSCT compared to single HSCT for the treatment of high-risk ESFT is insufficient to draw conclusions.

##### Single HSCT

The literature using dose-intensive chemotherapeutic regimens or HSCT consists of case series with small numbers of patients and case reports without direct comparisons between conventional or dose-intensive chemotherapy and HSCT. The evidence compiled for this review includes, for HSCT, 24 case series353-376 (including two Phase II studies) and six case reports.377-382 The comparator is conventional chemotherapy and includes seven case series (including one Phase II study).116, 376, 383-387 No information on quality of life (QOL) was provided and data on adverse events were sparse and based on small numbers of patients.

The evidence suggests that treatment-related mortality is higher in the patients that underwent HSCT compared to the chemotherapy comparators. The rate of secondary malignancies appeared lower in some reports of dose-intensive chemotherapy compared to HSCT and similar in one report of dose-intensive chemotherapy compared to HSCT.

##### Tandem Autologous-Autologous HSCT

The literature using tandem HSCT consists of case series with small numbers of patients and a case report.355, 380 A direct comparison between tandem HSCT and single HSCT is reported in one case series.354 The evidence compiled for this review includes, for tandem HSCT, two case series and one case report. The comparator is single HSCT and includes 24 case series and six case reports. Data on transplant-related mortality and infectious complications were sparse; data on other adverse effects were not reported.

#### Results

Table 38 arrays the study selection criteria for ESFT.

Table 38 Study selection criteria for ESFT

Study Design | Population | Intervention | Comparators | Outcomes | Followup | Setting
Any study design | Pediatric patients (0-21-yr) with high-risk ESFT | Single Auto of Allo HSCT Tandem | Chemotherapy +/- RT Single auto HSCT | OS; EFS (DFS; PFS); adverse events; | All durations of followup | Inpatient for HSCT and/or conventional chemotherapy and outpatient for conventional chemotherapy.

Auto = autologous; DFS = disease-free survival; EFS = event-free survival; HSCT = hematopoietic stem-cell transplant; OS = overall survival; PFS = progression-free survival

Table 39 shows the study design and population. Seventeen studies were based in Europe,353, 354, 356, 360, 362, 363, 366, 368, 369, 372, 374-376, 378, 380, 385, 386 seven in Asia,357, 358, 370, 371, 379, 382 373 and 12 in the U.S. and Canada.355, 359, 361, 364, 365, 367, 377, 381, 383, 384, 387, 388 The total number of patients for which data was abstracted from the 36 studies was 751 (468 HSCT and 283 chemotherapy). Twenty-eight studies included patients who underwent a single autologous or allogeneic HSCT.353, 354, 356-371, 377-379, 381, 382 372-376 Three studies reported outcomes for tandem autologous-autologous HSCT.354, 355, 380

Table 39 ESFT study characteristics and population

Study | Design | Median Age (Range) | Gender (M,F%) | Histology, Site, Stage (%) | HSCT (N) | Comparator (N) | Treatment Period | Comment
Oberlin, France, 2008^366^ a | case series | 12.3 yrs (2 onths-25 years)^*^ | 59,41^*^ | ES/PNET Cannot separate out sites of primary tumor and metastases by age <15 yrs old. | Autologous Total study n=97 (patients <15 n=61) | Not applicable | 1991-1999 | Only abstracted data for patients <15 years old as survival was reported as < 15 and >/= 15 in a univariate analysis
Meyers, USA, 2001^364^ b | case series | 13 yrs (1-22 yrs) | 63,37 | primary site: pelvis n=12 chest wall n=5 femur n=3 multiple sites n=6 other n=6 | Autologous n=32 | Not applicable | 1996-1998 | 32 pts were eligible for HSCT, 9 did not proceed to consolidation: 4 secondary to progression, 3 secondary to toxicity or death during 1st two courses of induction CT, 1 patient refused therapy during induction, and insufficient data in 1 pt.
Burdach, Germany and Austria, 2003^354^ | case series | | | | Single auto HSCT n=18 Tandem auto HSCT n=14 | Not applicable | | Only abstracted for patients ≤17 yrs
Burdach, Germany and Austria, 2000^353^ c | case series | At HSCT 15 yrs (8-21 yrs) | 50, 50^*^ | Ewing's: Primary tumor site for relapsed patients: long bone n=9, pelvis n=1,scapula n=1, chest wall/ribs n=1 Primary tumor site for multifocal disease: various including long bones, pelvis, rib, vertebrae, skull, sternum, clavicle, liver, bone marrow, thigh, lungs, lymph node | Auto n=21 Allo n=7 | Not applicable | 1986-1994 | Study included a total of 32 patients; data only abstracted for pts <21 yrs at HSCT
Drabko, Poland, 2005^356^ d | case series | At tx 15 yrs (6-21 yrs) | 52,48 | primary tumor site (reported for 19 patients): long bone n=9 pelvis n=3 clavicle or sternum n=3 scapula n=1 vertebra n=1 skull n=1 rib n=1 metastatic sites: lung n=6 bones n=3 lung/BM n=1 lungs/skull n=1 bone marrow n=3 no data for 4 pts | 21 Auto | Not applicable | 1996-2002
Prete, Italy, 1998^369^ e | case series | At tx 8 yrs (5-14 yrs) | 65,35 | bone marrow involvement n=3 | 17 Auto | Not applicable | 1993-1997
Hawkins, USA, 2000^359^ f | case series | At tx 14.6 yrs (6-21) | NR | long bone n=7 Axial n=8 Kidney n=1 | 16 Auto | Not applicable | 1993-1997
Ozkaynak, USA, 1998^367^ g | case series | 15 yrs (5-21) | 53,47 | Ewing's/PNET | 15 Auto | Not applicable | 1992-1995 | Study included a total of 27 patients with solid tumors who underwent HSCT; only abstracted those with PNET/Ewing's
Yaniv, Israel, 2004^371^ h | case series | 13 yrs (0.3-19) | 64,36 | primary tumor site long bone n=3; pelvis n=5; cranium n=1; scapula n=1; abdomen n=1 | 11 Auto | Not applicable | NR
Kushner, USA, 2001^361^ i | case series | 16.5 yrs (8-21 yrs) | 70,30 | primary tumor site pelvis n=4; long bone n=3; perineum n=1; paraspinal n=1; chest wall n=1 | 10 Auto 5 of the 10 pts did not proceed to HSCT b/c of progressive disease | Not applicable | 1990-1998 | Study included 21 pts, only abstracted data for pts <21 yrs old.
Navid, USA and Canada, 2006^365^ j | prospective Phase II trial | 15 yrs (12-17 yrs) | 67,33 | primary tumor site long bone n=2; pelvis n=2; rib n=2; kidney n=1; chest wall n=1; thorax n=1 sites of metastases bone n=2; bone, BM n=1; bone, BM, lung n=1; lung n=1; regional LN n=1 | 9 Auto (4 pts did not undergo HSCT b/c did not achieve a PR or CR to induction CT) | Not applicable | 1996-2000 | Study included a total of 24 patients with various histologies; only abstracted pts with Ewing's
Burke, USA, 2007^355^ k | case series | 14 yrs (.5-17) | 71,29 | primary tumor site pelvis n=5 scapula n=1 chest wall n=1 metastatic disease n=4 | Tandem auto-auto N=6 Single auto n=1 (pt did not receive the second HSCT b/c of progressive disease) | Not applicable | 1992-2003 | 8 pts in study; only included <21 yrs
Tanaka, Japan, 2002^370^ l | case series | 17.5 yrs (8-19) | 67,33 | primary tumor site pelvis n=2 sternum n=1 chest wall/lung n=1 long bone n=1 spinal cord n=1 | 6 Auto | Not applicable | “since 1986” | Study Included 7 pts; only abstracted <21
Kasper, Germany, 2006^360^ m | case series | At tx 19 yrs (17-21) | NR | metastatic sites lung n=2 bone n=1 | 5 Auto | Not applicable | 1998-2004 | Study included a total of 30 pts with various histologies; only abstracted Ewing's pts <21 yrs (total of 9 Ewing's pts)
Hara, Japan, 1998^357^ n | case series | 5 yrs (2-12 yrs) | NR | stage 3 n=1 stage 4 n=1 relapsed n=1 | 3 Auto | Not applicable | 1993-1997
Pession, Italy, 1999^368^ o | case series | 6 yrs (3-12 yrs) | 33,66 | Ewing's Site and stage NR | 3 Auto | Not applicable | 1992-1994 | Study included 19 pts with various histologies; only abstracted pts with Ewing's
Lucidarme, France, 1998^363^ p | Phase II study | 8.5 yrs (2-17 yrs)^*^ | 68,32^*^ | Metastatic disease n=3 | Single auto n=1 auto × 2 n=2 | Not applicable | 1987-1995 | Study included a total of 22 patients with mixed histologies; only abstracted pts with ESFT. It is not clear whether the 2nd auto HSCTs were planned tandem.
Laws, Germany, 2003^362^ q | case series | 9 and 17 yrs | 0,100 | primary tumor femur n=2 metastatic site scapula n=1 skull, pleura, humerus n=1 | 2 Auto | Not applicable | 1988-1998 | Study included a total of 18 pts, but age was only reported for 2.
Harimaya, Japan, 2003^358^ r | case series | 13 yrs (12-14 yrs) | 50,50 | Spinal column | 2 Auto | Not applicable | NR | Study included 4 pts; did not abstract for 2 pts treated without HSCT
Costa, USA, 2008^377^ | case report | At first HSCT 15 yrs | NR | NR | 1 Auto | Not applicable | 2000-2007 | Pt developed AML at 53 months post HSCT and underwent a second HSCT.
Lucas, USA, 2008^381^ s | case report | 4 yrs | 0,100 | primary iliac crest, stage IV | 1 Allo | Not applicable | NR
Kogawa, Japan, 2004^379^ t | case report | 7 yrs | 0,100 | Cervical spine, epidural | 1 Auto | Not applicable | NR
Numata, Japan, 2002 u | case report | 20 yrs at HSCT | 0,100 | Tumor site inguinal | 1 Auto | Not applicable | 1993
Fazekas, Austria, 2008^378^ v | case report | 13 yrs | 100,0 | Stage IV | 1 Auto | Not applicable | NR
Koscielniak, Germany, 2005^380^ w | case report | 15 yr | 0,100 | primary tumor site thorax | 1 Tandem auto auto then an allo after relapse | Not applicable | 1998
Diaz, Spain, 2010^372^ x | case series | 13 yrs (3-21) | 68,32 | localized/regional at diagnosis in 57% metastases at diagnosis in 43% primary site of tumor distal extremity 23%, proximal extremity 13%, pelvis 30%, chest 19%, spine/paravertebral 15% | 47 | Not applicable | 1995-2009
Kwon, Korea, 2010^373^ | case series | 8 yrs^*^ | 100,0 | stage IV | 1 | Not applicable | 2005-2007 | Study included a total of 11 patients with mixed histologies; only abstracted pt with ESFT.
Ilari, Italy, 2010^374^ y | case series | 103 mo (12-192) | 42,58 | localized n=16 metastatic n=8 primary tumor extremity n=7 axial n=17 Sites of mets lung n=5, BM n=3, bone n=3, other n=2 | 24 | Not applicable | 1998-2007 | 2 patients rapidly progressed during induction and did not proceed to HSCT
Ladenstein, Austria/France/UK/ Switzerland/ Netherlands/ Germany/ Sweden, 2010^375^ z | case series | NR | NR | disseminated multifocal Ewing's sarcoma Primary not reported separately for ≤ 14 years but for entire study population of 281 patients, extremity 31%, chest/spine/head and neck 24%, abd/pelvis 45% and sites of mets BM plus lung 10%, bone plus lung 45%, bone plus BM plus lungs 36%, other plus lungs 10% | 99 | Not applicable | 1999-2005 | Age and gender not reported separately for ≤14 years (entire study included 281 patients median age 16.2 years (range 0.4-49 years) . Survival data divided ≤14 years of age and >14
Burdach, Germany and Austria, 2010^376^ aa | case series | HSCT:15 (6-17) Comparator: NR | HSCT: 37,63 Comparator: NR | multiple primary bone metastases in 100% sternum n=1, VC n=7, pelvis n=7, lung n=4, LN n=1, MB nonspecified n=1, rib n=1, humerus n=4, cranium n=3, scapula n=1, femur n=3, fibula n=1, tibia=1, talus n=1, clavicle n=1 | 8 | 13 | HSCT 1999-2000 Comparator1992-1996 | Age and gender not reported separately for ≤17 years (comparator n=26 patients median age 17 yrs (6-37). Survival data for comparator does not separate ≤17 yrs and >17.
Bernstein, USA/Canada 2006^388^ bb | Phase II study | 14.6 yrs (3.0-27.3) | 39,61 | Primary extremity 36%, pelvis 29%, spine 5%, chest wall 16%, other 14%) Metastatic sites: Isolated lung 35%, Lung plus other 15%, isolated bone 13%, isolated BM 7%, other 30% | Not applicable | 110 | NR | Study included 12% of patients between 20 and 30 yrs of age; survival data not separated by age.
Bhatia, USA, 2007^383^ cc | case series | 12 yrs (0-30)^*^ | 56,44 | | Not applicable | 60 | 1992-1994 | Study included 578 patients with Ewing's treated with one of three regimens, one of which was high-intensity and it is for this group only that data abstracted.
Sari, Turkey, 2010^386^ dd | case series, retrospective | 12 yrs (3-18)^*^ | 39;61 | Primary tumor site: Extremity 53%, pelvis 28%,vertebrae 8%,chest wall 11% | Not applicable | 36 | 1992-2005 | Study included a total of 87 pts- only abstracted data for the 36 patients with metastatic disease (high-risk) and b/c survival was reported by metastatic vs. nonmetastatic disease
Kushner, USA, 1995^384^ ee | prospective case series | nonmetastatic disease 15 yrs (1.5-21) metastatic disease 17 yrs (9-21) | Nonmet disease 76,24 Met disease 86,14 | Nonmet disease primary tumor site chest wall 24%long bone 41%paraspinal 6%pelvis18%thigh 6% retroperitoneum 6% Metastatic disease primary tumor site illium n=1 Fibula n=1 Femur n=1 Pubis bone n=1 Bone marrow, dura, cranium, sacrum n=1 Pubis, bone marrow n=2 | Not applicable | 24 | NR | Study included 36 patients; only abstracted data for those <21 yrs (17 patients with nonmetastatic disease and 7 with metastatic)
Van Winkle, USA, 2005^387^ ff | case series | 14.1 yrs (2.8-22,5)^*^ | 57,43 | Ewing's of bone n=21 Extraosseous Ewing's n=1 Sites of recurrence: lung 28%, extremity 28%, pelvis 10%, head/neck10%,other 24% | Not applicable | 22 | 1992-1996 | Study included a total of 97 patients with various histologies-only abstracted those with Ewing's.
Milano, Italy, 2006^385^ gg | case series | 115 mos (20-214) | NR | PNET/ES Metastatic disease in 33% | Not applicable | 18 | 1990-2005 | Only abstracted data for patients who received ICE/CAV CT (study included a total of 36 pts)

BM = bone marrow; CR = complete remission; CT = chemotherapy; LN = lymph node; NR = not reported; RT = radiation

* age or gender reported for all pts in study

Therapeutic setting

a Newly diagnosed with metastases;

b Newly diagnosed with metastases to bone and/or BM;

c Relapsed (early, late or multiple) n=12 primary multifocal disease n=16;

d high risk- poor local control or metastases at presentation (n=14; no data on metastatic status for 4 patients);

e Metastatic disease at diagnosis n=14 localized disease n=3;

f Metastatic disease n=2; Recurrent disease n=14;

g Relapsed or metastatic disease with bone and/or BM involvement;

h Metastatic at diagnosis, poor response defined as <90% necrosis at definitive surgery or primary tumor not resectable with clear margins, relapsed;

i Newly diagnosed with metastases to bone or BM

j Metastatic (n=6) or tumor >8 cm in greatest dimension;

k Pelvic primary and/or metastatic disease;

l Large tumor, pelvic primary, intracranial extension, lung mets or pleural cavity involvement;

m Newly diagnosed with metastatic disease n=3; Newly diagnosed without metastatic disease n=2;

n Relapsed n=1, or advanced stage;

o Relapsed or disseminated disease

p Refractory;

q Relapsed;

r primary tumor, high risk site;

s Relapsed with metastases

t Primary diagnosis, no metastatic disease

u primary diagnosis;

v primary diagnosis;

w Disseminated at diagnosis;

x high-risk localized tumor (tumor volume >200mL, inoperable tumor, or poor histological response to neoadjuvant CT) and those with mets at diagnosis;

y Poor prognosis ESFT (metastasis or axis location, or tumor >200 mL or necrosis <95%);

z primary treatment;

aa high-risk with multiple primary bone mets

bb Metastatic disease at diagnosis;

cc Metastatic disease;

dd Metastatic disease at diagnosis;

ee Newly diagnosed deemed poor-risk because of tumor volume >100 cm^3^ or metastases to bone or BM.;

ff Recurrent/refractory;

gg high risk including tumor volume >200 mL, site with poor prognosis or lung and/or bone marrow metastases

Seven studies included in this analysis involved patients who underwent conventional chemotherapy.383-388 376 The patients who underwent conventional therapy were used as the comparators to the single HSCT population and the single HSCT population was used as the comparator to tandem HSCT population.

Table 40 shows the outcomes that were reported across studies.

Table 40 ESFT outcomes reported

Study | OS | EFS (DFS, PFS) | Quality of Life | Treatment-Related Mortality | Second Malignancies | Other Adverse Effects
Oberlin, France, 2008^366^ | ✓ | ✓ | NR | ✓ | ✓ | ✓
Meyers, USA, 2001^364^ | ✓ | ✓ | NR | ✓ | NR | ✓
Burdach, Germany and Austria, 2000^353^ | NR | ✓ | NR | ✓ | ✓ | ✓
Drabko, Poland, 2005^356^ | ✓ | ✓ | NR | ✓ | NR | ✓
Prete, Italy, 1998^369^ | ✓ | ✓ | NR | ✓ | NR | NR
Hawkins, USA, 2000^359^ | NR | ✓ | NR | ✓ | ✓ | ✓
Ozkaynak, USA, 1998^367^ | NR | ✓ | NR | ✓ | NR | ✓
Yaniv, Israel, 2004^371^ | NR | NR | NR | ✓ | NR | NR
Kushner, USA, 2001^361^ | NR | ✓ | NR | ✓ | NR | ✓
Navid, USA and Canada, 2006^365^ | ✓ | ✓ | NR | ✓ | ✓ | ✓
Burke, USA, 2007^355^ | NR | NR | NR | ✓ | NR | ✓
Tanaka, Japan, 2002^370^ | ✓ | ✓ | NR | ✓ | ✓ | ✓
Kasper, Germany, 2006^360^ | ✓ | ✓ | NR | NR | NR | ✓
Hara, Japan, 1998^357^ | NR | NR | NR | ✓ | NR | ✓
Pession, Italy, 1999^368^ | NR | NR | NR | ✓ | NR | ✓
Lucidarme, France, 1998^363^ | NR | NR | NR | ✓ | NR | ✓
Harimaya, Japan, 2003^358^ | NR | NR | NR | NR | NR | NR
Laws, Germany, 2003^362^ | ✓ | ✓ | NR | NR | NR | NR
Numata, Japan, 2002^382^ | NR | NR | NR | NR | ✓ | NR
Costa, USA, 2008^377^ | NR | NR | NR | NR | ✓ | NR
Lucas, USA, 2008^381^ | NR | NR | NR | NR | NR | ✓
Kogawa, Japan, 2004^379^ | NR | NR | NR | NR | NR | ✓
Fazekas, Austria, 2008^378^ | NR | NR | NR | NR | NR | ✓
Koscielniak, Germany, 2005^380^ | NR | NR | NR | NR | NR | ✓
Diaz, Spain, 2010^372^ | NR | ✓ | NR | NR | NR | ✓
Kwon, Korea, 2010^373^ | ✓ | NR | NR | NR | NR | NR
Ilari, Italy, 2010^374^ | ✓ | ✓ | NR | ✓ | ✓ | ✓
Ladenstein, Austria/France/UK/ Switzerland/ Netherlands/ Germany/ Sweden, 2010^375^ | ✓ | ✓ | NR | ✓ | ✓ | ✓
Burdach, Germany and Austria, 2010 376 | ✓ | NR | NR | ✓ | ✓ | ✓
Bernstein, USA/Canada 2006^388^ | ✓ | ✓ | NR | ✓ | ✓ | ✓
Bhatia, USA, 2007^383^ | NR | NR | NR | NR | ✓ | NR
Sari, Turkey, 2010^386^ | ✓ | ✓ | NR | ✓ | ✓ | ✓
Kushner, USA, 1995^384^ | NR | ✓ | NR | ✓ | ✓ | ✓
Van Winkle, USA, 2005^387^ | ✓ | NR | NR | ✓ | NR | ✓
Milano, Italy, 2006^385^ | ✓ | ✓ | NR | NR | NR | ✓

DFS = disease-free survival; EFS = event-free survival; NR = not reported; OS = overall survival; PFS = progression-free survival

##### Overall Survival

Data on overall survival were reported or generated in 20 HSCT studies353, 355-358, 360, 362-366, 368-371, 373-376, 389 and four comparator studies (Table 41).385-388 No direct comparisons can be made from the published data as there are no comparative studies.

Table 41 Overall survival for treatment (single HSCT and tandem auto HSCT) and comparison (conventional chemotherapy +/- radiation) groups

Followup | Intervention Single (%; ± 95% CI) | Comparator Chemo (%; ± 95% CI) | P Value | Study
1 year | ∼75% | Not applicable | | Meyers, USA, 2001^364^ (n=32)
1 year | 54% (35-72)^*^ | Not applicable | | Burdach, Germany and Austria, 2000^353^ (n=28)
1 year | 82% (59-100)^*^ | Not applicable | | Yaniv, Israel, 2004^371^ (n=11)
1 year | 89% (68-100%)^*^ | Not applicable | | Navid, USA and Canada, 2006^365^ (n=9)
1 year | 71% (38-100)^*^ | Not applicable | | Burke, USA, 2007^355^ (n=7)
1 year | 100%^*^ | Not applicable | | Tanaka, Japan, 2002^370^ (n=6)
1 year | 100^*^ | Not applicable | | Kasper, Germany, 2006^360^ (n=5)
1 year | 100%^*^ | Not applicable | | Kasper, Germany, 2004^389^ (n=4)
1 year | 67% (13-100%)^*^ | Not applicable | | Hara, Japan, 1998^357^ (n=3)
1 year | 67% (13-100%)^*^ | Not applicable | | Pession, Italy, 1999^368^ (n=3)
1 year | 33% (0-87%)^*^ | Not applicable | | Lucidarme, France, 1998^363^ (n=3)
1 year | 100% (0-100%)^*^ | Not applicable | | Harimaya, Japan, 2003^358^ (n=2)
1 year | 50% (0-100%)^*^ | Not applicable | | Laws, Germany, 2003^362^ (n=2)
1 year | DOD at 11 mo | Not applicable | | Kwon, Korea, 2010^373^
1 year | Not applicable | 77% (+/-4%) [isolated lung mets vs. other or more than isolated lung mets 82% +/-6% and 74% +/-5% p=0.47] | | Bernstein, USA/Canada 2006 388 (n=110)
1 year | Not applicable | ∼68% | | Sari, Turkey, 2010^386^ (n=36)
1 year | Not applicable | 43% | | Van Winkle, USA, 2005^387^ (n=22)
1 year OS ranges | 54-75%^353, 364^ | 43-77%^386-388^
2 year | ∼35 | Not applicable | | Meyers, USA, 2001^364^ (n=32)
2 year | 68% | Not applicable | | Drabko, Poland, 2005^356^ (n=21)
2 year | 70% | Not applicable | | Prete, Italy, 1998^369^ (n=17)
2 year | 33% (0-87%)^*^ | Not applicable | | Lucidarme, France, 1998^363^ (n=3)
2 year | 50% (0-100%)^*^ | Not applicable | | Laws, Germany, 2003^362^ (n=2)
2 year | Not applicable | 46% (+/-5%) [isolated lung mets vs. other or more than isolated lung mets 49% +/-8% and 44% +/-6% p=0.47] | | Bernstein, USA/Canada 2006^388^ (n=110)
2 year | Not applicable | ∼36% | | Sari, Turkey, 2010^386^ (n=36)
2 year | Not applicable | 33% | | Van Winkle, USA, 2005^387^ (n=22)
3 year | 39% (21-57)^*^ | Not applicable | | Burdach, Germany and Austria, 2000^353^ (n=28)
3 year | 54% (16-75)^*^ | Not applicable | | Yaniv, Israel, 2004^371^ (n=11)
3 year | 56% (23-88%)^*^ | Not applicable | | Navid, USA and Canada, 2006^365^ (n=9)
3 year | 71% (38-100)^*^ | Not applicable | | Burke, USA, 2007^355^ (n=7)
3 year | 83% (54-100)^*^ | Not applicable | | Tanaka, Japan, 2002^370^ (n=6)
3 year | 80% (52-100)^*^ | Not applicable | | Kasper, Germany, 2006^360^ (n=5)
3 year | 75% (33-100)^*^ | Not applicable | | Kasper, Germany, 2004^389^ (n=4)
3 year | 67% (13-100%)^*^ | Not applicable | | Hara, Japan, 1998^357^ (n=3)
3 year | 67% (53-100%)^*^ | Not applicable | | Pession, Italy, 1999^368^ (n=3)
3 year | 50% (0-100%)^*^ | Not applicable | | Harimaya, Japan, 2003^358^ (n=2)
3 year | 46% | Not applicable | <.001 | Ladenstein, Austria/France/UK/ Switzerland/ Netherlands/ Germany/ Sweden, 2010^375^
3 year | Not applicable | isolated lung mets ∼34% other or more than isolated lung mets ∼24% | | Bernstein, USA/Canada 2006^388^ (n=110)
3 year | Not applicable | ∼32% | | Sari, Turkey, 2010^386^ (n=36)
3 year | Not applicable | 67% +/-12% | | Milano, Italy, 2006^385^ (n=18)
3 year OS ranges | 32-39%^353^ | 24-67%^385, 388^
5 year | 49% | Not applicable | | Oberlin, France, 2008^366^ (n=61)
5 year | 24% (8-40)^*^ | Not applicable | | Burdach, Germany and Austria, 2000^353^ (n=28)
5 year | 18% (0-41%)^*^ | Not applicable | | Yaniv, Israel, 2004^371^ (n=11)
5 year | 56% (23-88%)^*^ | Not applicable | | Navid, USA and Canada, 2006^365^ (n=9)
5 year | 54% (14-93%)^*^ | Not applicable | | Burke, USA, 2007^355^ (n=7)
5 year | 83% (54-100)^*^ | Not applicable | | Tanaka, Japan, 2002^370^ (n=6)
5 year | 80% (52-100)^*^ | Not applicable | | Kasper, Germany, 2006^360^ (n=5)
5 year | 67% (13-100%)^*^ | Not applicable | | Hara, Japan, 1998^357^ (n=3)
5 year | 67% (53-100%)^*^ | Not applicable | | Pession, Italy, 1999^368^ (n=3)
5 year | 50% (0-100%)^*^ | Not applicable | | Harimaya, Japan, 2003^358^ (n=2)
5 year | A NED at 73+ months | Not applicable | | Costa, USA, 2008^377^ (n=1)
5 year | A NED 60 months after surgery | Not applicable | | Kogawa, Japan, 2004^379^ (n=1)
5 year | 64% (38-81) | Not applicable | | Ilari, Italy, 2010^374^
5 year | 50%^*^ | Not applicable | | Burdach, Germany and Austria, 2010^376^
5 year | Not applicable | isolated lung mets ∼24% other or more than isolated lung mets ∼20% | | Bernstein, USA/Canada 2006^388^ (n=110)
5 year | Not applicable | 27% | | Sari, Turkey, 2010^386^ (n=36)
5 year | Not applicable | ∼67% | | Milano, Italy, 2006^385^ (n=18)
5 year OS ranges | 24-49% 353, 366 | 20-67%^385, 386, 388^

A = alive; NED = no evidence of disease; DOD = dead of disease

∼ = estimated from K-M curve in study

* =generated for this SR

Costa- pt underwent 2^nd^ HSCT at 53 months for AML- at 73 months NED (ESFT or AML)

##### Event-free Survival

Information on event-free survival can be found in Appendix D.

##### Adverse Effects

None of the studies evaluated quality of life. Data on treatment-related mortality was reported in 14 HSCT studies353, 355 356, 363-365, 367-371, 374, 375 376 and three comparative studies.385, 387 388 (Table 42). Eleven HSCT353, 355, 356, 359, 360, 364, 370, 372, 374, 375 376 and two comparator studies385, 388 reported serious infectious complications. Six HSCT studies353, 365, 374, 375, 377 376 and four comparator studies383, 384, 386, 388 reported a secondary malignancy. Seven HSCT studies356, 359, 361, 381 372, 374, 375 and one comparator study385 reported other long-term complications involving severe organ dysfunction.

Table 42 Adverse effects for single auto HSCT and comparison (conventional chemotherapy +/- radiation) groups

Outcome | Intervention (HSCT [%]) | Comparator (Chemo [%]) | Study
Treatment-related mortality | 12% | Not applicable | Meyers, USA, 2001^364^
Treatment-related mortality | 18% | Not applicable | Burdach, Germany and Austria, 2000^353^
Treatment-related mortality | 5% | Not applicable | Drabko, Poland, 2005^356^
Treatment-related mortality | 13% | Not applicable | Ozkaynak, USA, 1998^367^
Treatment-related mortality | 18% | Not applicable | Yaniv, Israel, 2004^371^
Treatment-related mortality | 2%^*^ | Not applicable | Ladenstein,Austria/France/UK/Switzerland/Netherl ands/Germany/Sweden, 2010^375^
Treatment-related mortality | 0% | Not applicable | Navid, 2006^365^; Prete, 1998^369^; Burke, 2007^355^; Tanaka, 2002^370^; Pession, 1999^368^; Lucidarme, 1998^363^ Ilari, 2010^374^
Treatment-related mortality | 38% | Not applicable | Burdach, Germany and Austria, 2010 376
Treatment-related mortality | Not applicable | 5% | Bernstein, USA/Canada 2006^388^
Treatment-related mortality | Not applicable | 0.6%^*^ | Van Winkle, USA, 2005^387^
Treatment-related mortality | Not applicable | 0% | Milano, Italy, 2006^385^
Infectious complications | 5% septic death | Not applicable | Meyers, USA, 2001^364^
Infectious complications | 18% septic death | Not applicable | Burdach, Germany and Austria, 2000^353^
Infectious complications | 5% septic death | Not applicable | Drabko, Poland, 2005^356^
Infectious complications | 6% death due to CMV infection | Not applicable | Hawkins, USA, 2000^359^
Infectious complications | Sepsis 28% (not leading to death) | Not applicable | Burke, USA, 2007^355^
Infectious complications | 4/24 (17%) cases of sepsis | Not applicable | Ilari, Italy, 2010^374^
Infectious complications | 1/47 (2%) septic shock 1/47 (2%) fungal infection | Not applicable | Diaz, Spain, 2010^372^
Infectious complications | 13% | Not applicable | Burdach, Germany and Austria, 2010 376
Infectious complications | 0% | Not applicable | Tanaka, 2002^370^; Kasper, 2006^360^
Infectious complications | Not applicable | 6/110 (5%) septic deaths | Bernstein, USA/Canada 2006^388^
Infectious complications | Not applicable | 2/18 (11%) cases of sepsis | Milano, Italy, 2006^385^
Secondary malignancies | 11% (MDS n=2 liposarcoma n=1) | Not applicable | Burdach, Germany and Austria, 2000^353^
Secondary malignancies | 0% | Not applicable | Navid, 2006^365^, Ilari, 2010^374^, Ladenstein, 2010^375^
Secondary malignancies | n=1 (AML) | Not applicable | Costa, USA, 2008^377^
Secondary malignancies | 25% | Not applicable | Burdach, Germany and Austria, 2010 376
Secondary malignancies | Not applicable | 1/110 (1%) MDS | Bernstein, USA/Canada 2006^388^
Secondary malignancies | Not applicable | 10% (MDS/AML) | Bhatia, USA, 2007^383^
Secondary malignancies | Not applicable | 1/1 CML | Numata, Japan, 2002^382^
Secondary malignancies | Not applicable | 0% | Sari, Turkey, 2010^386^
Secondary malignancies | Not applicable | 1/24 (4%) AML | Kushner, USA, 1995^384^
Long-term complications | 10% n=1 died (pulmonary failure) | Not applicable | Kushner, USA, 2001^361^
Long-term complications | n=1 dilated CMP, pulmonary HTN, renal failure, interstitial pneumonia | Not applicable | Lucas, USA, 2008^381^
Long-term complications | n=1 short stature/growth retardation n=5 ovarian impairment | Not applicable | Ilari, Italy, 2010^374^
Long-term complications | Not applicable | 0/18 (0%) | Milano, Italy, 2006^385^
Veno-occlusive disease | 10% (n=2 moderate/severe VOD) | Not applicable | Drabko, Poland, 2005^356^
Veno-occlusive disease | 6% (n=1 severe VOD) | Not applicable | Hawkins, USA, 2000^359^
Veno-occlusive disease | n=5^*^ (grade 3 VOD) | Not applicable | Ladenstein,Austria/France/UK/Switzerland/Netherl ands/Germany/Sweden, 2010^375^

AML = acute myelogenous leukemia; MDS = myelodysplastic syndrome; vod = veno-occlusive disease

* For total population

#### Ongoing Studies

Two ongoing Phase III trials will include an HSCT arm in the treatment of patients with high-risk ESFT:

- A study in localized and disseminated Ewing Sarcoma (EWING 2008; NCT00987636) will include a randomized trial arm for high-risk Ewing's (localized and unfavorable histological response or tumor volume greater than 200 mL) examining whether HSCT compared with standard chemotherapy improves EFS. Patients with pulmonary metastases will be randomized to HSCT versus standard chemotherapy and whole lung irradiation. Very high-risk patients (with primary disseminated disease) will be randomized to HSCT versus standard chemotherapy. Estimated enrollment is 1,383 with an estimated study completion date of March 2018.
- A randomized trial is comparing chemotherapy with or without peripheral stem-cell transplantation, radiation, and/or surgery (EURO-EWING 99; NCT00020566). Primary outcome measures include EFS and OS. Estimated enrollment is 1,200 with an estimated primary completion date of December 2011.

#### Conclusion

Low strength evidence on overall survival suggests no benefit with single HSCT compared to conventional therapy for the treatment of high-risk ESFT.

The body of evidence on overall survival with tandem HSCT compared to single HSCT for the treatment of high-risk ESFT and overall survival is insufficient to draw conclusions.

### Wilms Tumor Systematic Review

#### Background and Setting

Wilms tumor is the fifth most common pediatric malignancy and the most common type of renal tumor in children. The incidence of Wilms tumor is approximately 0.8 cases per 100,000 persons, with approximately 500 new cases diagnosed each year in the U.S., 6 percent involving both kidneys.390 Most cases occur sporadically, whereas some are hereditary or associated with certain syndromes. Wilms tumor is diagnosed at a mean age of 3.5 years, and is unusual after the age of 6.^391^Overall survival rates for Wilms tumor are approximately 90 percent with first-line therapy consisting of surgery, chemotherapy and in some cases radiation therapy (to the abdomen and/or lungs).390 However, approximately 15 percent of patients with favorable (nonanaplastic) histology and 50 percent of patients with anaplastic histology experience tumor recurrence.381 Recurrent Wilms tumor is a heterogeneous disease and treatment is generally based upon patient risk stratification. For patients with favorable prognostic features, standard-dose chemotherapy may be curative.

Patients with relapsed disease and adverse prognostic factors are considered as a high-risk relapse category. Adverse prognostic factors include initial advanced tumor stage, anaplastic histology, early recurrence (less than 6 months after diagnosis), recurrence in multiple organs or in a previously irradiated field, and initial chemotherapy consisting of vincristine, actinomycin D, and doxorubicin (versus vincristine and actinomycin D alone). Since the identification of this high-risk group of patients with relapsed disease and the poor outcome after initial treatment with chemotherapy consisting of vincristine, actinomycin D, and doxorubicin (VAD) and radiation therapy, investigation now focuses on the activity of ifosfamide, etoposide, and platinum analogs as single agents or in combination, and in more intensive doses. Other intensive dose strategies include the use of myeloablative chemotherapeutic regimens and HSCT.

#### Evidence Summary

The overall grade of strength of comparative study evidence for overall survival and the use of HSCT for the treatment of high-risk relapsed Wilms tumor is shown in Table 43.

Table 43 Overall grade of strength of evidence for overall survival and the use of HSCT for the treatment of high-risk relapsed Wilms tumor

Key Question | Study Design | Risk of Bias | Consistency | Directness | Precision | Strength of Association | Overall Grade/Conclusion
For pediatric patients with high-risk relapsed Wilms tumor, what is the comparative effectiveness and harms of HSCT and conventional chemotherapy regarding overall survival? Outcome of interest is overall survival. The comparator is conventional chemotherapy. | The data for HSCT consists of 11 case series and 7 case reports. The comparator data used consists of 2 case series. Total number of patients HSCT n=114 Comparator n=88 | The risk of bias in this evidence is high. Studies consisted of case reports or small case series and incorporated heterogeneous patient populations. | Results for overall survival are consistent. Ranges of outcomes across the different studies are similar. | Where outcomes were reported, the evidence is direct. The comparators are indirect in that the evidence base utilizes two or more bodies of evidence to make comparisons. | The evidence is precise. While the evidence is qualitative, it is unlikely that a clinically important superiority exists for HSCT for the treatment of high-risk relapsed Wilms compared to conventional chemotherapy. | Not applicable due to lack of obvious effect size. | Low strength evidence on overall survival suggests no benefit with single HSCT compared to conventional therapy for the treatment of high-risk relapsed Wilms tumor.

The literature using dose-intensive chemotherapeutic regimens consists of case series with small numbers of patients, without direct comparisons between conventional intensive chemotherapy and HSCT.

The evidence compiled for this review includes 13 case series364, 392-403 and seven case reports.378, 404-409 The comparator is conventional chemotherapy. Although direct comparisons are difficult to make between dose-intensive chemotherapy and HSCT in high-risk relapsed Wilms, based on the current systematic review, there does not appear to be a difference in progression-free or overall survival between the two groups. No information on quality of life was provided and data on adverse events was sparse and therefore insufficient to make conclusions regarding adverse effects and quality of life.

#### Results

Thirty-eight articles were retrieved for full-text screening. Twenty reports were included in this review, and the remaining 18 articles were excluded. Table 44 arrays the criteria that were used to select studies for this section.

Table 44 Wilms tumor study selection criteria

Study Design | Population | Intervention | Comparators | Outcomes | Followup | Setting
Any study design | Pediatric patients (0-21-yr) with high-risk relapsed or resistant Wilms tumor | Single Auto HSCT Tandem Auto HSCT | Chemotherapy +/- RT Single auto HSCT | OS; EFS (DFS; PFS); adverse events; | All durations of followup | Inpatient (HSCT and /or comparator chemotherapy) and outpatient (comparator chemotherapy)

Auto = autologous; DFS = disease-free survival; EFS = event-free survival; HSCT = hematopoietic stem-cell transplant; OS = overall survival; PFS = progression-free survival

Table 45 shows the study designs and population. Of the included publications, 13 were case series364, 392-403 and seven were case reports.378, 404-407 Nine studies were based in Europe,378, 392-394, 397, 398, 400, 404, 405 one in Asia,401 two in South America,399, 410 and eight in the U.S.395, 396, 402, 403, 406-409

Table 45 Wilms tumor study characteristics and population

Study | Design | Median Age (Range) | Sex (M, F%) | Histology, Site, Stage (%) | HSCT (N) | Comparator (N) | Treatment Period | Comment
Pein, France, 1998^398^ | Case Series | 6 years (2-16 years) | 41, 59 | Initial stage: I n=4 II n=12 (5 were LN +) III n=5 IV n=6 V n=2 FH n=23 UH n=6 | Autologous HSCT (n=28) | Not applicable | 1988-1994 | Includes 3 patients with clear cell sarcoma of the kidney 1 pt. lost to follow up
Kremens, Germany, 2002^392^ | Case Series | at diagnosis 74 months (11-210 months) | 52, 48 | Initial stage: I n=4 II n=4 III n=3 IV n=13 (does not total 23) Intermediate risk n=14 High-risk n=5 Completely necrotic tumor n=1 | Autologous HSCT (n=23) | Not applicable | 1992-1998 | Includes one patient with clear cell sarcoma
Spreafico, Italy, 2008^394^ | Case Series | at diagnosis 4.1 years (1.1-11.2 years) | 30, 70 | High risk n=3 relapsed in prior RT field Initial stage: I n=1 II n=2 III n=8 IV n=8 Wilms n=19 CCSK n=1 | Autologous HSCT (n=20) | Not applicable | 2001-2006 | 20 patients were enrolled; 5 did not receive HSCT (3 due to progressive disease and 2 at the discretion of the treating physician) Includes one patient with clear cell sarcoma
Campbell, USA, 2004^395^ | Case Series | at diagnosis 4.8 years (1-15 years) | 31, 69 | Initial stage: I n=2 II n=1 III n=5 IV n=5 FH n=12 UH n=1 | Autologous HSCT (n=13) | Not applicable | 1991-2001
Hempel, Germany, 1996^400^ | Case Series | at HSCT 6.25 years (3.9-14.8 years)^*^ | 86, 14 | UH n=1, FH n=6 | Autologous HSCT (n=7) | Not applicable | 1992-1995 | Study included 8 patients; one patient was misdiagnosed as Wilms (had a rhabdomyosarcoma) and is not included in this analysis.
Kullendorff, Sweden, 1997^397^ | Case Series | at diagnosis median 55 months (43-119 months) | 33,66 | Initial stage: I n=2 III n=2 FH n=3 UH n=1 Site of relapse lung n=2 and bone n=2 | Autologous HSCT (n=4) | Not applicable | 1987-1992 | Includes one patient with clear cell sarcoma of the kidney
Valera, Brazil, 2004^399^ | Case Series | at diagnosis 7 years (3-9 years) | 66,33 | Initial stage: II n=1 III n=1 IV n=1 | Autologous HSCT (n=3) | Not applicable
Saarinen-Pihkala, Finland, 1998^393^ | Case Series | at diagnosis 46 months (6-60 months) | 66,33 | Stage: V n=3 Metastases to lung n=1 FH n=2, rhabdomyomatous n=1 | Autologous HSCT (n=3) | Not applicable
Termuhlen, USA, 2006^396^ | Case Series phase 1 study | 40.5 months (21-60 months) | 0,100 | Stage V n=2 | Autologous HSCT (n=2) | Not applicable | | Study included 4 patients (2 had neuroblastoma)
Fazekas, Austria, 2008^378^ | Case Report | 5 yrs at HSCT | 100,0 | “intermediate risk”- not further defined | Autologous HSCT (n=1) | Not applicable
Goldman, USA, 2001^406^ | Case Report | 2 years at HSCT | 100,0 | Relapse 6 months after diagnosis Initial stage III Relapse in lungs and abdomen | Autologous HSCT (n=1) | Not applicable | 1994-1998 | Study included 8 patients with various histologies; only abstracted Wilms.
Dagher, USA, 1998^407^ | Case Report | 7 years at HSCT | 0,100 | Recurred in right-sided tumor bed | Autologous HSCT (n=1) | Not applicable | | Patient had a left-sided Wilms tumor, FH, stage II at age 9 months and underwent L nephrectomy and CT. At age 6 years, patients developed a right kidney Wilms tumor for which she underwent right nephrectomy, CT and RT. At 7 years of age she had a right-sided recurrence and underwent HSCT.
Hempel, Germany, 1998^404^ | Case Report | 11 months | 100,0 | Stage II “medium” malignancy | Autologous HSCT (n=1) | Not applicable
Maurer, Austria, 1997^405^ | Case Report | at diagnosis 8 years | 0,100 | Initial stage IV with lung metastases UH | Double sequential high-dose chemotherapy and autologous HSCT (n=1) | Not applicable
Park, Korea, 2006^401^ | Case Series | 2 yrs (2-3 yrs) | 70,30 | Autologous HSCT: Initial stage: II n=3 FH n=1 UH n=2 Site of relapse lung n=2 abdomen n=1 Comparator: Initial stage: I n=1 II n=3 III n=1 IV n=2 FH =7 Site of relapse lung n=6 Abdomen n=4 Liver n=1 BM n=1 Bone n=1 | Autologous HSCT (n=3) | Chemotherapy +/- RT (n=7) | 1994-2004 | Comparators were relapsed with at least one risk factor.
Tucci, Brazil, 2007^410^ | Case Series | 2 years^*^ | | Metastases in the liver and lungs. | Autologous HSCT (n=1) | Chemotherapy +/- RT (n=10) | | One patient included in the comparator group underwent HSCT. Overall the study included 53 patients. Only abstracted relapsed patients for comparators and one of the relapsed patients had favorable prognostic factors.
Malogolowkin, USA, 2008^403^ | Case Series | at diagnosis 0-23 months n=4 24-47 months n=21 48+ n=35 | 47,53 | Initial stage II n=1 III n=39 IV n=20 FH n=56 Focal anaplasia n=3 Diffuse anaplasia n=1 | Not applicable | Chemotherapy +/- RT (n=60) | 1995-2002
Abu-Ghosh, USA, 2002^402^ | Case Series | at diagnosis 36 months (13-192 months) | | High-risk Initial stage: I 18% II 9% III 36% IV 27% V 9% FH 82%, UH 18% Site of relapse: lung 36%, pleura 9%, kidney 18%, kidney and lung 18%, liver 9% | Not applicable | Chemotherapy +/- RT (n=11) | 1992-1999
Brown, USA, 2010^408^ | Case Report | At diagnosis 48 months | 100,0 | Initial stage I n=1 | Autologous HSCT (n=1) | Not applicable | | Patient treated with chemotherapy, surgical resection, and high-dose chemotherapy with autologous stem-cell transplant in CR3 followed by radiation
Lucas, USA, 2010^409^ | Case Report | At diagnosis 12 months | 100,0 | favorable histology, Wilms - left kidney plus right lung nodules | Allogeneic HSCT (n=1) | Not applicable

CR = complete remission; CSSK = clear cell sarcoma of the kidney; CT = chemotherapy; FH = favorable histology; LN = lymph node; NR = not reported; RT = radiation; UH = unfavorable histology

* Included all patients in study.

The total number of patients for which data was abstracted from the twenty studies was 202: 114 patients received HSCT, whereas 88 patients received chemotherapy.

Fifteen studies included patients who underwent HSCT,378, 392-400, 404, 406, 407 two studies contained data for patients treated either with HSCT or conventional therapy,401, 410 one study contained a report of double sequential high-dose chemotherapy with HSCT,405 and two studies included in this analysis contained only patients that underwent conventional chemotherapy.402, 403 The patients who underwent conventional therapy were used as the comparators to the HSCT population. No studies were identified using tandem autologous HSCT. Patients from these 20 studies received HSCT or conventional chemotherapy for relapsed (first or subsequent), progressive disease, or metastatic disease and one study included patients in first complete remission with bilateral disease (stage V).

Table 46 shows the outcomes that were reported across studies.

Table 46 Wilms tumor outcomes reported

Study | OS | EFS (DFS, PFS) | Quality of Life | Treatment-Related Mortality | Second Malignancies | Other Adverse Effects
Fazekas, Austria, 2008^378^ | ✓ | NR | NR | ✓ | NR | NR
Spreafico, Italy, 2008^394^ | ✓ | ✓ | NR | ✓ | NR | ✓
Malogolowkin, USA, 2008^403^ | ✓ | ✓ | NR | ✓ | ✓ | ✓
Tucci, Brazil, 2007^410^ | ✓ | ✓ | NR | NR | NR | ✓
Termuhlen, USA, 2006^396^ | NR | NR | NR | NR | NR | ✓
Park, Korea, 2006^401^ | ✓ | ✓ | NR | NR | NR | ✓
Campbell, USA, 2004^395^ | ✓ | ✓ | NR | ✓ | NR | ✓
Valera, Brazil, 2004^399^ | NR | NR | NR | NR | NR | ✓
Kremens, Germany, 2002^392^ | ✓ | ✓ | NR | ✓ | NR | ✓
Abu-Ghosh, USA, 2002^402^ | ✓ | ✓ | NR | ✓ | NR | ✓
Goldman, USA, 2001^406^ | NR | NR | NR | ✓ | NR | ✓
Saarinen-Pihkala, Finland, 1998^393^ | NR | ✓ | NR | NR | NR | ✓
Pein, France, 1998^398^ | ✓ | ✓ | NR | ✓ | NR | ✓
Dagher, USA, 1998^407^ | NR | NR | NR | NR | NR | ✓
Hempel, Germany, 1998^404^ | NR | NR | NR | NR | NR | ✓
Kullendorff, Sweden, 1997^397^ | NR | NR | NR | ✓ | NR | NR
Maurer, Austria, 1997^405^ | NR | NR | NR | NR | NR | ✓
Hempel, Germany, 1996^400^ | NR | NR | NR | ✓ | NR | ✓
Brown, USA, 2010^408^ | NR | ✓ | NR | NR | NR | ✓
Lucas, USA, 2010^409^ | NR | ✓ | NR | NR | NR | NR

DFS = disease-free survival; EFS = event-free survival; NR = not reported; OS = overall survival; PFS = progression-free survival

##### Overall Survival

Data on overall survival were reported in fifteen studies (Table 47).378, 392, 394-398, 400-403, 405-407, 410 No direct comparisons can be made from the published data as there are no comparative studies.

Table 47 Overall survival for treatment (single auto HSCT) and comparison (conventional chemotherapy +/- radiation) groups

Followup | Intervention Single (%; ± 95% CI) | Comparator Chemo (%; ± 95% CI) | Study
1 year | 1 yr 86% [73-100] (n=28) | Not applicable | Pein,1998^398^
1 year | Not applicable | 1 yr ∼73% (n=11) | Abu-Ghosh, 2002^402^
1 year | 1 yr 70% [51-88] (n=23) | Not applicable | Kremens, 2002^392^
1 year | 1yr 90% [77-100]% (n=20) | Not applicable | Spreafico,2008^394^
1 year | 1 yr 100%^*^ (n=7) | Not applicable | Hempel, 1996^400^
1 year | All patients 1 year 75% [33-100]^*^ (n=4) Only Wilms 1 year 100%^*^ (n=3) | Not applicable | Kullendorf, 1997^397^
1 year | median 53+ months (31+-76+) (n=3) | Median 15 months (2-30 months) (n=5) | Park, 2006^401^
1 year | 1yr 100% (n=2) | Not applicable | Termuhlen, 2006^396^
1 year | A NED at 12 mos (n=1) | Not applicable | Fazekas, 2008^378^
1 year | A NED at 16+ mos (n=1) | Not applicable | Goldman,2001^406^
1 year | 1.8 years (n=1) | Not applicable | Dagher, 1998^407^
2 year | 2 yr 60% [41-78] (n=28) | Not applicable | Pein,1998^398^
2 year | 2 yr 61% [41-81] (n=23) | Not applicable | Kremens, 2002^392^
2 year | Not applicable | 2 yr 64% (n=11) | Abu-Ghosh, 2002^402^
2 year | 2 yr 86% [60-100]^*^ (n=7) | Not applicable | Hempel, 1996^400^
2 year | All patients 2 year 75% [33-100]^*^ Only Wilms 2 year 100%^*^ (n=4) | Not applicable | Kullendorf, 1997^397^
2 year | 2 yr 100% (n=2) | Not applicable | Termuhlen, 2006^396^
3 year | 3yr 60% [41-78] (n=28) | Not applicable | Pein, 1998^398^
3 year | 3 yr 61% [41-81] (n=23) | Not applicable | Kremens, 2002^392^
3 year | 3yr 55% +/-13% (n=20) | Not applicable | Spreafico,2008^394^
3 year | Not applicable | 3 yr 64% (n=11) | Abu-Ghosh, 2002^402^
3 year | Not applicable | 3 year 83.3%^*^ (n=10) | Tucci, 2007^410^
4 year | 4 yr 50% [29-70] (n=28) | Not applicable | Pein, 1998^398^
4 year | Not applicable | 4 yr 48% [33-62] (n=60) | Malogolowkin, 2008^403^
4 year | 4 yr 61% [41-81] (n=23) | Not applicable | Kremens, 2002^392^
4 year | Not applicable | 4yr 64% (n=11) | Abu-Ghosh, 2002^402^
4 year | 4-year 73% (n=13) | Not applicable | Campbell, 2004^395^
4 year | 4 yr 100% (n=2) | Not applicable | Termuhlen, 2006^396^
4 year | A NED at 4 yrs (n=1) | Not applicable | Maurer, 1997^405^
5 year | 5 yr 50% [29-70]^*^ (n=28) | Not applicable | Pein, 1998^398^
5 year | 5 yr 61% [41-81]^*^ (n=23) | Not applicable | Kremens, 2002^392^
5 year | Not applicable | 5 yr 64% (n=11) | Abu-Ghosh, 2002^402^
5 year | Not applicable | 5 year 43%^*^ (n=10) | Tucci, 2007^410^
5 year | 5 yr 100% (n=2) | Not applicable | Termuhlen, 2006^396^
5 year OS range across studies | 50%-61% 392, 398 | 43-64%^402, 410^

A = alive; DOD = dead of disease; NED = no evidence of disease

* Survival generated for this review.

##### Event-free Survival

Information on event-free survival can be found in Appendix D.

##### Adverse Effects

None of the studies evaluated quality of life. Data on treatment-related mortality was reported in 10 studies (Table 48).378, 392, 394, 395, 397, 398, 400, 402, 403, 406 Two studies reported a case of serious infection leading to death394, 403 and one study reported no serious infectious complications.407 One study reported a secondary malignancy.403 One study reported a case of mild veno-occlusive disease.408 There were no reports of other long-term complications.

Table 48 Adverse effects for single auto HSCT and comparison (conventional chemotherapy +/-radiation) groups

Outcome | Intervention HSCT (%) | Comparator Chemo (%) | Study
Treatment-related mortality | 0 | Not applicable | Fazekas, 2008^378^; Spreafico, 2008^394^; Campbell, 2004^395^; Kremens, 2002^392^; Goldman, 2001^406^; Pein, 1998^398^; Kullendorff, 1997^397^; Hempel, 1996^400^
Treatment-related mortality | Not applicable | 0 | Abu-Ghosh, 2002^402^; Malogolowkin, 2008^403^
Infectious complications | Died of sepsis 4 months after HSCT in CR n=1 (7%) | Not applicable | Spreafico, 2008^394^
Infectious complications | 0% (n=1) | Not applicable | Dagher,1998^407^
Infectious complications | Not applicable | Died of influenza B and aspergillus n=1 (2%) | Malogolowkin, 2008^403^
Infectious complications | 33% septic (n=1) | Not applicable | Saarinen-Pihkala, Finland, 1998^393^
Secondary malignancies | Not applicable | n=1 MDS (2%) | Malogolowkin, 2008^403^
Other adverse effects | 100% (n=1) mild VOD and mucositis | Not applicable | Brown, 2010^408^

MDS = myelodysplastic syndrome; VOD = veno-occlusive disease

#### Ongoing Studies

One Phase II trial is ongoing studying chemotherapy followed by surgery and radiation, with or without HSCT in patients with relapsed or refractory Wilms tumor or clear cell sarcoma of the kidney. The study design is interventional and uses one of three regimens (one of which includes HSCT) depending upon patient risk stratification. Primary outcome measures include unified treatment strategy, improvement of current survival rates, efficacy and toxicity and prognostic variables. Estimated enrollment is 75 (50 for HSCT and 25 for each of the non-HSCT regimens). Estimated final data collection date is November 2008 (NCT00025103).

#### Conclusion

Low strength evidence on overall survival suggests no benefit with single HSCT compared to conventional therapy for the treatment of high-risk relapsed Wilms tumor.

### Rhabdomyosarcoma Systematic Review

#### Background and Setting

The incidence of rhabdomyosarcoma is 4 to 7 cases per 1 million children age 15 or younger;411 approximately 350 new cases are diagnosed each year in the United States.412 The majority of children have an initial presentation of nonmetastatic disease. In this setting conventional treatments have produced at least a 60-70 percent chance of cure.411 Metastatic rhabdomyosarcoma in comparison is generally a lethal disease, with less than 20 percent of patients being cured from their disease.411 Despite the development of new chemotherapy options, the prognosis of these patients remains generally poor.

Some centers have used HDC with HSCT in the setting of high-risk rhabdomyosarcoma. High-risk rhabdomyosarcoma includes primary metastatic or stage III or greater disease and relapsed or refractory disease. Patients with relapsed or refractory disease experience 5-year survival of approximately 30 percent.413 In most series, numbers remain small as the majority of rhabdomyosarcoma cases are cured with conventional treatment; no randomized controlled trials exist.

Data are generally from case series, save two comparative studies414, 415 with patients who received high-dose chemotherapy and HSCT; case reports are also available. While comparative, the study by McDowell and colleagues415 is treated here as two single arms. The focus was to treat a subgroup of high-risk patients with sequential HDC and HSCT and compare them to standard high-risk patients receiving standard chemotherapy. This stratification makes this patient population treated with HSCT not comparable to other treated groups, as they are of generally higher risk than is found in other studies. Prognostic factors identified in prior research were used in identifying those with the poorest prognosis.366, 416, 417 This study provides outcome data for the stratified high-risk rhabdomyosarcoma group, and tested the hypothesis that the highest risk patients may benefit from sequential HDC and stem-cell rescue. Patients traditionally viewed as high-risk, may not have uniform survival outcomes, and may be further stratified based on prognostic factors. Evidence was evaluated in three groups: studies confined to patients with metastatic disease, studies of mixed tumor stage, and “other” (congenital alveolar, cranial parameningeal disease with metastases, and allogeneic transplantation for metastatic disease).

#### Evidence Summary

The overall grade of strength of evidence for overall survival and the use of HSCT for the treatment of high-risk rhabdomyosarcoma is shown in Table 49.

Table 49 Overall grade of strength of evidence for overall survival and the use of HSCT for the treatment of high-risk rhabdomyosarcoma

Key Question | Study Design | Risk of Bias | Consistency | Directness | Precision | Strength of Association | Overall Grade/Conclusion
For pediatric patients with high-risk metastatic rhabdomyosarcoma, what is the comparative effectiveness and harms of HSCT and conventional chemotherapy regarding overall survival? Outcome of interest is overall survival. The comparator is conventional chemotherapy | There are three comparative studies; one study was comprised of two single arms. Seven case series (four on HSCT and three on the comparator conventional chemotherapy) and three case reports on HSCT. Data from 255 patients treated with HSCT and 429 treated with conventional therapy were abstracted for this review. | The risk of bias in this evidence is high. In our synthesis we incorporated larger studies with adequate descriptions of patient populations with complete reporting of overall survival. | Overall survival data are consistent. Evidence is from the European Collaborative Studies in which patients with similar disease characteristics were assigned to a protocol. A modification to the protocol to include HDC and stem cell rescue offered the opportunity for comparison and showed no difference in survival. While not powered to detect a 10-15% absolute difference the other studies, with some variation show essentially the same survival. Evidence suggests no survival advantage for HSCT over conventional therapy. | The primary outcome, overall survival, is direct. The comparisons are indirect as the evidence base utilizes two or more bodies of evidence to make comparisons. The best evidence was comparative but the comparison was made with historical controls entered in a previous protocol. | The evidence is precise suggesting no overall survival advantage for HSCT over conventional therapy. While the evidence is qualitative it is unlikely that a clinically important superiority exists for HSCT. | Not applicable due to lack of obvious effect size. | Moderate strength evidence on overall survival suggests no benefit with single HSCT compared to conventional therapy for the treatment of high-risk metastatic rhabdomyosarcoma.
For pediatric patients with high-risk rhabdomyosarcoma, of mixed tumor stage what is the comparative effectiveness and harms of HSCT and conventional chemotherapy regarding overall survival? Outcome of interest is overall survival. The comparator is conventional chemotherapy | There are six case series (five on HSCT and one on the comparator conventional chemotherapy) and one case reports on HSCT. Data from seventy-nine patients treated with HSCT and twenty-seven treated with conventional therapy were abstracted for this review. | The risk of bias in this evidence is high. In our synthesis we incorporated studies containing a mixture of tumor stages. Tumor stage may modify the overall survival within the high-risk category. | Results for overall survival are inconsistent. Five year survival for the three largest studies reporting overall survival range from 12.5 to 57%. | The outcomes reported are direct. The comparisons are indirect as the evidence base utilizes two or more bodies of evidence to make comparisons. | The evidence is imprecise. There is uncertainty on whether HSCT is inferior, equivalent or superior to conventional chemotherapy. While no comparator data was available a commonly used estimate is 30% overall survival at 5 years (Pappo, 1999). In these data survival ranged from 12.5 to 57%. | Not applicable due to lack of obvious effect size. | The body of evidence on overall survival with single HSCT compared to conventional therapy for the treatment of high-risk rhabdomyosarcoma of mixed tumor type is insufficient to draw conclusions.
For pediatric patients with congenital alveolar rhabdomyosarcoma, cranial parameningeal rhabdomyosarcoma with metastasis or the use of allogeneic transplantation for metastatic rhabdomyosarcoma, what is the comparative effectiveness and harms of HSCT and conventional chemotherapy regarding overall survival? Outcome of interest is overall survival. The comparator is conventional chemotherapy | There are two case reports for congenital alveolar, one case series for cranial parameningeal, and three case studies of allogeneic transplantation for metastatic rhabdomyosarcoma. Data from two patients with congenital alveolar rhabdomyosarcoma and treated with HSCT, four treated with allogeneic HSCT and ninety-one with cranial parameningeal rhabdomyosarcoma treated with conventional therapy were abstracted for this review. | The risk of bias in the evidence for congenital alveolar rhabdomyosarcoma is high. Very few cases of this disease have ever been diagnosed, but the natural history is well known. The risk of bias in the evidence for cranial parameningeal rhabdomyosarcoma and allogeneic transplantation is high. | Consistency cannot be assessed for these diseases as the data is limited to either one case series (cranial parameningeal) or a few case reports (congenital alveolar and allogeneic transplantation) For congenital alveolar rhabdomyosarcoma available evidence may suggest a survival advantage for HSCT over conventional therapy. | The outcomes reported are direct. The comparisons are indirect as the evidence base utilizes two or more bodies of evidence to make comparisons. | The evidence is precise for congenital alveolar rhabdomyosarcoma and imprecise for cranial parameningeal rhabdomyosarcoma with metastasis or the use of allogeneic transplantation for metastatic rhabdomyosarcoma. | Not applicable due to lack of obvious effect size. | The body of evidence on overall survival with HSCT compared to conventional therapy for the treatment of pediatric patients with congenital alveolar rhabdomyosarcoma, cranial parameningeal rhabdomyosarcoma with metastasis or the use of allogeneic transplantation for metastatic rhabdomyosarcoma is insufficient to draw conclusions.

The evidence compiled for this review includes two comparative studies,414, 418 one study comprising two single arms,415 15 case series (nine on HSCT357, 363, 365, 419-424 and six on the comparator conventional chemotherapy387, 413, 416, 425-427) and eight case reports on HSCT.428-435 Two case reports on allogeneic transplantation were also included.420, 436 The total number of patients abstracted from the 26 studies was 887: 340 patients received HSCT, whereas 547 patients received conventional chemotherapy. Patients with embryonal tumors have a better prognosis than those with alveolar histology. Prognostic factors such as age at diagnosis and location of the metastatic disease may help stratify high-risk patients into two groups, those of standard risk and those of poor risk. Treatment with conventional chemotherapy offers three-year survival of about 39 percent.416 Treatment with HSCT does not appear to alter the survival for patients with metastatic rhabdomyosarcoma above what is already achieved with conventional chemotherapy.

The effects of HSCT on survival for pediatric patients with high-risk rhabdomyosarcoma of mixed tumor stage and those with congenital alveolar rhabdomyosarcoma, cranial parameningeal rhabdomyosarcoma with metastasis or the use of allogeneic transplantation for metastatic rhabdomyosarcoma is uncertain. No information on quality of life (QOL) was provided, and data on adverse events was sparse and therefore insufficient to make conclusions regarding adverse effects and quality of life. Two ongoing trials focused on treatment for malignant solid tumors are enrolling children with rhabdomyosarcoma. One is focused on the toxicity of killer IG-like receptor mismatched cord blood, and the other is investigating a tumor lysate-pulsed dendritic cell vaccine for immune augmentation after stem-cell transplantation. Future research aimed to further stratify high-risk pediatric patients with nonmetastatic disease will be important as the field moves towards more targeted therapies.

#### Results

Sixty articles were retrieved for full-text screening, including articles identified from the bibliography of identified articles and articles containing patients with rhabdomyosarcoma identified in another disease search. Twenty-six reports were included in this review, and the remaining 34 articles were excluded. The total number of patients abstracted from the 26 studies was 887: 346 patients received HSCT, whereas 547 patients received conventional chemotherapy.

Table 50 shows the criteria that were used to select studies for this section.

Table 50 Rhabdomyosarcoma study selection criteria

Study Design | Population | Intervention | Comparators | Outcomes | Followup | Setting
Any study design | Pediatric patients (0-21-yr) with high-risk disease | Single Auto HSCT Tandem Auto HSCT | Chemotherapy +/- RT Chemotherapy +/- RT | OS; EFS (DFS; PFS); long-term adverse events; QOL | All durations of followup | In-patient for HSCT In or out-patient for conventional chemotherapy

Auto = autologous; DFS = disease-free survival; EFS = event-free survival; HSCT = hematopoietic stem-cell transplant; OS = overall survival; PFS = progression-free survival; QOL = quality of life

Table 51 shows the study design and population. Of the included publications, two were comparative studies (McDowell et al.415 was abstracted as two single arms); one study was comprised of two single arms. There were 15 case series (nine on HSCT357, 363, 365, 419-424and six on the comparator conventional chemotherapy387, 413, 416, 425-427) and seven case reports on HSCT.428-435 Two case reports on allo-transplantation were also included.420, 436 Eight studies were based in Europe,363, 414, 415, 419, 420, 428, 429, 436 eight in Asia,357, 421, 422, 430-434 one in the Middle East,423 and nine in North America.365, 387, 416, 418, 424-427, 435

Table 51 Rhabdomyosarcoma study characteristics and population

Setting | Study | Design | Median Age | Range | Mean Age | Gender (%) | Histology [Site] (%) | HSCT (N) | Comparator (N) | Treatment Period
Metastatic Autologous HSCT | Carli, Italy, 1999^414^ | Comparative | [underlined: Tx.] 60% <10 40% >10 [underlined: Comp.] 7% < 1 61% < 10 32% ≥ 10 | NR | NR | NR | [underlined: Treatment] 44% Alveolar 56% Embryonal [Primary extremity, parameningeal, other (75%) genitourinary tract and H&N (25%)] [underlined: Comparator] 30% Alveolar 70% Embryonal or unspecified [Primary extremity parameningeal, other (80%) genitourinary tract and H&N (20%)] | 52 | 44 | 1989-1996
Metastatic Autologous HSCT | McDowell, UK, 2010^415^ | Two single arms | [underlined: high risk] 10.6 [underlined: Standard risk] 4.28 | [underlined: high risk] 1.7-17.5 [underlined: Standard risk] 0.52-9.93 | NR | [underlined: high risk] 56% Male 44% Female [underlined: Standard risk] 60% Male 40% Female Standard risk | [underlined: high risk] 64% Alveolar 22% Embryonal 8% Undifferentiated 6% Unknown [most common primary site Orbit (28%)] Metastatic [underlined: standard risk] 33% Alveolar 57% Embryonal 9% Unspecified or unknown [most common primary site parameningeal (22%) and pelvis (31%)] 71% had Metastatic disease to lung | 101 | 45 | 1998-2005
Metastatic Autologous HSCT | Williams, Canada, 2004^418^ | retrospective review two single arms | [underlined: Tx.] 4 <10 [underlined: Comp] 7 <10 6 >10 | NR | NR | [underlined: Tx.] 25% Male 75% Female [underlined: Comp] 53% Male 47% female | [underlined: Treatment] Embryonal with metastatic disease to lung [Primary H&N, parameningeal, bladder/prostate] Stage IV [underlined: Comparator] 69% Alveolar 23% Embryonal 8% Mixed [Primary Trunk, bladder/prostate, extremity, genitourinary] Stage IV | 4 | 13 | 1989-1999
Metastatic Autologous HSCT | Bisogno, Italy, 2009^419^ | prospective single arm | NR | NR | <1 (1) <10 (38) ≥10 (32) | 47% Male 53% Female | 63% Alveolar 36% Embryonal 1% Not otherwise specified [Primary sites H&N, limbs, abdomen/pelvis] | 70 | NA | 1999-2006
Metastatic Autologous HSCT | Navid, USA, 2006^365^ | case series | 15.5 | 1.5-18.7 | 13.1 | 38% Male 62% Female | Alveolar [various primary sites] Metastatic | 8 | NA | 1996-2000
Metastatic Autologous HSCT | Walterhouse, USA, 1999^424^ | case series | 14 | 3-17 | 12.5 | 37% Male 63% Female | 63% Alveolar 25% Embryonal 12% Unknown Stage IV | 8 | NA | 1992-1994
Metastatic Autologous HSCT | Moritake, Japan, 1998^433^ | case report | NA | NA | 10 at diagnosis | Male | Unspecified metastatic to bone marrow [Primary nasal tumor] | 1 | NA | 1994
Metastatic Autologous HSCT | Kwan, Hong Kong, 1996^431^ | case report | NA | NA | 14 years | Female | Alveolar [primary site was left thenar, metastatic to breast] Stage IV | 1 | NA | NR
Metastatic Autologous HSCT | Shaw, Israel, 1996^423^ | prospective case series | 8 years at diagnosis | 4-15 | 8.8 years at diagnosis | NR | Various primary sites Stage IV | 9 | NA | NR
Metastatic Autologous HSCT | Oue, Japan, 2003^434^ | Case report from a case series. Abstracted only one patient receiving a tandem transplant | NA | NA | 4.5 | Female | Lt. buttock primary site metastatic to lt. femur | 1 | NA | 1991-2001
Metastatic Autologous HSCT | Breneman, USA, 2003^416^ | Case series | 7 | 0-19 | NR | 56% Male 44% Female | 46% Alveolar 36% Embryonal 3% Undifferentiated [most common 1° site extremity (28%), parameningeal (20%), trunk (20%)] Stage IV Lung most common metastatic site followed by bone marrow and lymph nodes | NA | 127 | 1991-1997
Metastatic Autologous HSCT | Pappo, USA, 2001^425^ | Case series | 10 at diagnosis | 0-19 | NR | 52% Male 48% Female | 48% Alveolar 29% Embryonal 4% Undifferentiated 19% Unspecified [most common 1° site retroperitoneum/perineum/trunk (43%), extremity (23%), GU/bladder/prostate (15%), other (19%)] Metastatic | NA | 48 | 1994-1996
Metastatic Autologous HSCT | Sandler, USA, 2001^427^ | Case series | 8.5 | 0-19 | NR | 58% Male 42% Female | 37% Alveolar 48% Embryonal 15% Unspecified [most common 1° site extremity (31%), H&N (7%) retroperitoneum (18%) other (44%)] Metastatic | NA | 152 | 1988-1991
Metastatic Allo Transplant | Doelken, Germany, 2005^436^ | Case reports | NA | NA | Pt 1-11.5 Pt 2- 13 | M 100% | Alveolar with metastatic disease Stage IV | 2 | NA | NR
Metastatic Allo Transplant | Donker, Netherlands, 2009^428^ | Case study Allo transplant | NA | NA | 8 years | Female | Stage IV Metastatic | 1 | NA | NR
Metastatic Allo Transplant | Misawa, Japan, 2003^432^ | Case Study Allo transplant | NA | NA | 17 at diagnosis | Female | Alveolar Stage I, group III undifferentiated | 1 | NA | 1997
Mixed tumor stage | Matsubara^**^, Japan, 2003^421^ | Case series | 8 at transplant | 2-20 | 9.5 | 62% Male 38% Female | 33% Alveolar 67% Embryonal [Parameningeal most common primary site n=7] Group III/IV at transplant | 21 | NA | 1990-1999
Mixed tumor stage | Scully, USA, 2000^435^ | Case report | NA | NA | ∼5 at transplant | Female | Embryonal [Primary site was upper arm] Local recurrence | 1 | NA | NR
Mixed tumor stage | Hara, Japan, 1998^357^ | Case series | 3 | 1-18 | 6.8 | NR | 43% Alveolar 57% Embryonal Stage III (2) Stage IV (3) Relapsed (2) | 7 | NA | 1993-1997
Mixed tumor stage | Lucidarme, France, 1998^363^ | single arm phase II | NR for our subset | 2-17 for the whole study | NR | NR | 63% metastatic at transplant Relapsed or Refractory | 8 | NA | 1987-1995
Mixed tumor stage | Sato, Japan, 1998^422^ | case series | 7 at diagnosis | .7-10 year | 5.34 at diagnosis | 60% Male 40% Female | 60% Embryonal 40% Undifferentiated [Primary retroperitoneum, parameningeal, femur, orbit] Stage III | 5 | NA | 1993-1998
Mixed tumor stage | Koscielniak^*^, Germany, 1997^420^ | retrospective case series | 6 at diagnosis | <1-22 | NR | NR | 61% Alveolar 36% Embryonal 3% Undifferentiated Stage IV | 36 | NA | 1986-1994
Mixed tumor stage | Van Winkle, USA, 2005^387^ | Case series | NR | 2.1-20.5 | 11.3 | 52% Male 48% Female | 37% Alveolar 41% Embryonal 11% Undifferentiated 11% Unknown At recurrence 4% Stage I, 0 Stage II, 11% stage III, 63% Stage IV, 22% unknown | NA | 27 | 1992-1996
Congenital Alveolar RMS | Kuroiwa, Japan, 2009^430^ | case report | NA | NA | <1 at transplant | | Congenital Alveolar RMS [Primary skin lesions] | 1 | NA | NR
Congenital Alveolar RMS | Grundy, UK, 2001^429^ | case report | NA | NA | Diagnosed at birth | Male | Congenital alveolar RMS [primary right thigh and multiple skin lesions] | 1 | NA | NR
Cranial Parameningeal | Raney, USA, 2008^426^ | case series | 5 at diagnosis | <1-19 | NR | 59% Male 41% Female | 15% Alveolar 71% Embryonal 13% Unspecified Cranial parameningeal with metastatic disease | NA | 91 | 1978-1997

NR = not reported

* This paper contains both Allo and Auto transplants as they could not be separated, as well as at least one patient over the age of 21.

** study included one patient who was 22, his survival was similar when compared to a 16 and a 20 year old with similar site of relapse and status at transplant.

All patients across 18 treatment studies received autologous HSCT as consolidation of primary treatments. Patients in three studies received allogeneic HSCT as consolidation of primary treatments. All patients were considered to have high-risk disease prior to transplant.

For the comparison of tandem to single HSCT, no studies were identified in the search.

All studies were specific to the pediatric age group, with age primarily reported as age at diagnosis; 15 studies reported either mean age or only had one patient. Mean age at diagnosis was approximately 8 years with a range of birth to 17 years. Median or categorical age at diagnosis, reported by 15 studies, was 8 years with a range of 3 to 13.1 years. Across all studies patients were approximately split equally by gender. Studies included patients with diverse histology, approximately 40-50 percent of the patients of alveolar histology, save two studies419, 424 where 63 percent were of alveolar histology. The majority of the remaining patients had embryonal tumors with a small proportion diagnosed with a tumor not otherwise specified or unknown. Induction regimens varied across and within study (i.e., different chemotherapeutic agents and different (cumulative) dosages). The induction regimen consisted of multiple cycles of chemotherapy with or without radiation and/or surgery.

Conditioning regimens also varied across and within studies. The most common regimens included the following agents: melphalan, thiotepa, busulfan, cyclophosphamide, carboplatin and etoposide, either alone or in combination; MEC (melphalan, VP16, and carboplatin) is a common backbone used alone or in combination with radiation therapy or additional drugs. Treatment periods ranged from 1989 to 2005.

Table 52 shows the pediatric outcomes that were reported across the 26 included studies.

Table 52 Rhabdomyosarcoma outcomes reported

Setting | Study | OS | EFS (DFS, PFS) | Quality of Life | Treatment-Related Mortality | Second Malignancies | Other Adverse Effects
Metastatic Auto transplant | Carli, Italy, 1999^414^ | ✓ | ✓ | NR | ✓ | NR | ✓
Metastatic Auto transplant | McDowell, UK, 2010^415^ | ✓ | NR | NR | ✓ | NR | ✓
Metastatic Auto transplant | Williams, Canada, 2004^418^ | ✓ | ✓ | NR | NR | NR | NR
Metastatic Auto transplant | Bisogno, Italy, 2009^419^ | ✓ | NR | NR | ✓ | NR | ✓
Metastatic Auto transplant | Navid, USA, 2006^365^ | ✓ | NR | NR | ✓ | NR | ✓
Metastatic Auto transplant | Walterhouse, USA, 1999^424^ | ✓ | NR | NR | ✓ | NR | NR
Metastatic Auto transplant | Moritake, Japan, 1998^433^ | ✓ | NR | NR | NR | NR | NR
Metastatic Auto transplant | Kwan, Hong Kong, 1996^431^ | ✓ | NR | NR | NR | NR | NR
Metastatic Auto transplant | Shaw, Israel, 1996^423^ | ✓ | NR | NR | ✓ | NR | ✓
Metastatic Auto transplant | Oue, Japan, 2003^434^ | ✓ | NR | NR | ✓ | NR | NR
Metastatic Auto transplant | Breneman, USA, 2003^416^ | ✓ | ✓ | NR | NR | NR | NR
Metastatic Auto transplant | Pappo, USA, 2001^425^ | ✓ | ✓ | NR | ✓ | NR | NR
Metastatic Auto transplant | Sandler, USA, 2001^427^ | ✓ | ✓ | NR | ✓ | NR | ✓
Metastatic Allo Transplant | Doelken, Germany, 2005^436^ | ✓ | NR | NR | NR | NR | NR
Metastatic Allo Transplant | Donker, Netherlands, 2009^428^ | ✓ | NR | NR | NR | NR | NR
Metastatic Allo Transplant | Misawa, Japan, 2003^432^ | ✓ | NR | NR | NR | NR | NR
Mixed tumor stage | Matsubara**, Japan, 2003^421^ | ✓ | ✓ | NR | NR | ✓ | NR
Mixed tumor stage | Scully, USA, 2000^435^ | ✓ | NR | NR | NR | ✓ | NR
Mixed tumor stage | Hara, Japan, 1998^357^ | ✓ | NR | NR | ✓ | NR | ✓
Mixed tumor stage | Lucidarme, France, 1998^363^ | ✓ | NR | NR | ✓ | NR | ✓
Mixed tumor stage | Sato, Japan, 1998^422^ | NR | ✓ | NR | NR | NR | NR
Mixed tumor stage | Koscielniak*, Germany, 1997^420^ | NR | ✓ | NR | NR | NR | ✓
Mixed tumor stage | Van Winkle, USA, 2005^387^ | ✓ | NR | NR | ✓ | NR | NR
Congenital Alveolar | Kuroiwa, Japan, 2009^430^ | ✓ | NR | NR | NR | NR | NR
Congenital Alveolar | Grundy, UK, 2001^429^ | ✓ | NR | NR | NR | NR | NR
Cranial Parameningeal with metastatic disease | Raney, USA, 2008^426^ | ✓ | ✓ | NR | NR | NR | NR

DFS = disease-free survival; EFS = event-free survival; NR = not reported; OS = overall survival; PFS = progression-free survival

##### Overall Survival

Data on overall survival were reported in all but two studies420, 422 (Table 52). Survival data is presented (Table 53). Individual studies varied in their method for calculating overall survival. In general studies of patients with metastatic disease used time since diagnosis, where studies with patients of mixed tumor stage used time from treatment. Similar trends were observed in the 1-, 3-, and 5-year OS across studies. While not direct, comparisons with adequate numbers of participants can be made from both the McDowell415 and Carli414 studies.

Table 53 Overall survival for treatment (single auto HSCT) and comparison (conventional chemotherapy +/- radiation) groups

Setting | Outcome | Intervention Single (%; ± 95% CI) | Comparator Chemo (%; ± 95% CI) | P Value | Study
Metastatic Auto | 1 Year | ∼86% at 1 year^a^ (n=52) | ∼66% at one year^a^ (n=44) | | Carli, Italy, 1999^414^
Metastatic Auto | 1 Year | 66.7 (35.9, 97.5) at 1 year (n=9) | Not applicable | | Shaw, Israel, 1996^b^ 423
Metastatic Auto | 1 Year | 50.0 (15.4, 84.6) at 1 year (n=8) | Not applicable | | Navid, USA, 2006 b 365
Metastatic Auto | 1 Year | 87.5 (64.6, 100) (n=8) | Not applicable | | Walterhouse, USA, 1999 b 424
Metastatic Auto | 1 Year | NED 3 months post transplant (n=1) | Not applicable | | Kwan, Hong Kong, 1996^431^
Metastatic Auto | 1 Year | DOD 21 months after transplant (n=1) | Not applicable | | Moritake, Japan, 1998^433^
Metastatic Auto | 1 Year | NED 19 months after diagnosis (n=1) | Not applicable | | Oue, Japan, 2003^434^
Metastatic Auto | 1 Year | Not applicable | ∼75% at 1 year^a^ (n=152) | | Sandler, USA, 2001^427^
Metastatic Auto | 1 Year | Not applicable | ∼75% at 1 year^a^ (n=127) | | Breneman, USA, 2003^416^
Mixed tumor stage | 1 Year | 37.5% (4, 71.0) at 1 year (n=8) | Not applicable | | Lucidarme, France, 1998^b^ 363
Mixed tumor stage | 1 Year | 57.1 (20.5, 93.8) at 1 years (n=7) | Not applicable | | Hara, Japan, 1998 b 357
Mixed tumor stage | 1 Year | Not applicable | 56 ±10 at 1 year (n=27) | | Van Winkle, USA, 2005^387^
Metastatic Allo | 1 Year | DOD at 5.5 months after transplant (n=1) | Not applicable | | Misawa, Japan, 2003^432^
Metastatic Auto | 3 year | 40.0 (25.5-54.7) at 3 years (n=52) | 27.7 (13.3-42.1) at 3 years (n=44) | 0.2 | Carli, Italy, 1999^414^
Metastatic Auto | 3 year | 23.7 at 3 years (n=101) | 62.14 at 3 years (n=45) | | McDowell, UK, 2010^415^
Metastatic Auto | 3 year | All 35% (13-58) at 3 years HSCT only (n=4) 100% at 3 years | 15% (-4-35) at 3 years (n=13) | | Williams, Canada, 2004^418^
Metastatic Auto | 3 year | 42.3% (30.5-53.6) at 3 years (n=70) | Not applicable | | Bisogno, Italy, 2009^419^
Metastatic Auto | 3 year | 53.3 (19.4, 87.3) at 3 years (n=9) | Not applicable | | Shaw, Israel, 1996^b^ 423
Metastatic Auto | 3 year | 37.5 (4-71) at 2 years (n=8) | Not applicable | | Navid, USA, 2006 b 365
Metastatic Auto | 3 year | 12.5 (0, 35.4) (n=8) | Not applicable | | Walterhouse, USA, 1999^b^ 424
Metastatic Auto | 3 year | Not applicable | ∼40% at 3 years (n=152) | | Sandler, USA, 2001^427^
Metastatic Auto | 3 year | Not applicable | 39% (30-48) at 3 years (n=127) | | Breneman, USA, 2003^416^
Mixed tumor stage | 3 year | 12.5 (0, 35.4) at 3 years (n=8) | Not applicable | | Lucidarme, France, 1998^b^ 363
Mixed tumor stage | 3 year | 57.1 (20.5, 93.8) at 3 years (n=7) | Not applicable | | Hara, Japan, 1998± 357
Mixed tumor stage | 3 year | Alive with secondary malignancy at 3 years post transplant (n=1) | Not applicable | | Scully, USA, 2000^435^
Congenital Alveolar | 3 year | NED at 46 months after diagnosis (n=1) | Not applicable | | Kuroiwa, Japan, 2009^430^
Congenital Alveolar | 3 year | 1 pt DOD at 2 years (n=1) | Not applicable | | Grundy, UK, 2001^429^
Metastatic Auto | 5 year | ∼40% at 5 years (n=52) | ∼26% at 5 years (n=44) | | Carli, Italy, 1999^414^
Metastatic Auto | 5 year | 17.9 at 5 years (n=101) | 47.7% at 5 years (n=45) | | McDowell, UK, 2010^415^
Metastatic Auto | 5 year | 12.5 (0, 35.4) (n=8) | Not applicable | | Walterhouse, USA, 1999^b^ 424
Metastatic Auto | 5 year | Not applicable | ∼34% at 5 years (n=152) | | Sandler, USA, 2001^427^
Metastatic Auto | 5 year | Not applicable | ∼25% at 5 years (n=127) | | Breneman, USA, 2003^416^
Mixed tumor stage | 5 year | 48% at 5 years (n=21) | Not applicable | | Matsubara, Japan, 2003^c^ 421
Cranial Parameningeal with metastatic disease | 5 year | Not applicable | 33% (23-43) at 10 years (n=91) | | Raney, USA, 2008^426^
Metastatic Allo | 5 year | 1 pt alive in CR at 4 years (n=1) | Not applicable | | Donker, Netherlands, 2009^428^
Metastatic Allo | 5 year | 4.8 months post allo-transplant 1 pt died Approximately 6 years after allo transplant pt. 2 died (pt had a allo- transplant 5 years after the auto transplant) (n=2) | Not applicable | | Doelken, Germany, 2005^436^
Metastatic | OS range for 3-5 years for studies with > 20 patients | 40-42.3%^414, 419^ Survival estimates are measured from the time since diagnosis | 27.7-39% 414, 416, 427 Survival estimates are measured from the time since diagnosis | | This range does not include the McDowell 415 study as the patients in the treatment arm are not comparable to other studies due to their higher risk category.
Mixed Tumor stage | OS range for 3-5 years for studies with > 5 patients | 12.5-57% 357, 363, 421 Survival estimates are measured from the time since treatment | No Comparator

a Estimates preceded by a ∼ were estimated from published Kaplan-Meier curves.

b Survival curves were constructed using the raw data published in the articles.

c Study included one patient who was 22, his survival was similar when compared to a 16- and a 20-year-old with similar site of relapse and status at transplant.

The study published by McDowell and colleagues415 stratified patients with metastatic rhabdomyosarcoma into two groups, poor risk and standard risk. Poor-risk patients were identified as those 10 years of age or older with bone or bone marrow involvement.415 These patients were given sequential HDC and HSCT, while the standard-risk patients (younger than 10 years of age and not bone or bone marrow involvement) were treated with conventional chemotherapy. Patients in the standard risk group had 3 year EFS and OS of 54.92 percent and 62.14 percent, respectively, comparable to rates in other studies. While those in the poor-risk group had 3 year EFS and OS of 16.17 percent and 23.17 percent, respectively, statistically worse than those in the standard-risk group in this study and no improvement on prior studies.

Carli et al.414 published results from the European Collaborative MMT4-91. Fifty-two patients in complete remission after induction were given HDC and stem-cell rescue. Outcomes were then compared to 44 patients also in complete remission after induction, but went onto receive conventional chemotherapy. No differences in OS were observed.

The data from additional case series and case reports appear consistent with these findings.

##### Event-free Survival

Information on event-free survival can be found in Appendix D.

##### Adverse Effects

None of the studies evaluated quality of life, and serious adverse events were reported by fifteen studies (Table 52). Data on treatment-related mortality was reported in twelve studies (Table 54).357, 363, 365, 387, 414, 415, 419, 423-425, 427, 434 McDowell reported two cases of treatment-related mortality in the comparator group and there were seven serious adverse events in the treatment group with five resulting in death; however it is unclear how many occurred in 100 days of treatment.415 Toxic death from sepsis was reported in the treatment group in two studies.414, 420 Bisogno et al.419 reported seven of 55 evaluable patients experienced serious infectious complications while Sandler and colleagues427 reported 40 percent of patients experiencing serious infection with seven leading to death. One study reported a secondary malignancy, myelodysplastic syndrome related to alkylating agents.435 No treatment related mortality was observed in 11 studies.363, 421, 422, 424, 429-433, 435, 436 Two studies416, 426 did not report on adverse events. There were no reports of secondary malignancies, serious hemorrhagic events, irreversible veno-occlusive disease or other long term complications.

Table 54 Adverse effects for single auto HSCT and comparison (conventional chemotherapy +/- radiation) groups

Outcome | Intervention (HSCT [%]) | Comparator Chemo (%) | Study
Treatment-related mortality | 0 a | Not applicable | Dolken, 2005^436^; Grundy, 2001^429^; Kurioiwa, 2009^430^; Kwan, 1996^431^; Lucidarme, 1998^363^; Matsubara, 2003^421^; Misawa, 2003^432^; Moritake, 1998^433^; Sato, 1998^422^; Scully, 2000^435^; Walterhouse, 1999^424^
Treatment-related mortality | 1.9 | 2.2 | Carli, 1999^414^
Treatment-related mortality | 4.3 | Not applicable | Bisogno, 2009^419^
Treatment-related mortality | 1/7 of RMS patients *one additional patient non-RMS experienced TRM; of all patients 2/28 (7.1%) | Not applicable | Hara, 1998^357^
Treatment-related mortality | Not applicable | 5.9% Unclear if these were within 100 days | Sandler, 2001^427^
Treatment-related mortality | 5.0% This represents 5 adverse events resulting in death, unclear how many occurred within 100 days of treatment | 4.4% | McDowell, 2010^415^
Treatment-related mortality | 25% Two of eight RMS patients in a study of mixed cancers | Not applicable | Navid, 2006^365^
Treatment-related mortality | 8.3 In a mixed tumor study. Neither patient had RMS. | Not applicable | Oue, 2003^434^
Treatment-related mortality | 6.6 In a mixed tumor study. Neither patient had RMS. | Not applicable | Shaw, 1996^423^
Treatment-related mortality | Not applicable | 6.2% | Pappo, 2001^425^
Treatment-related mortality | Not applicable | 0.6 (TRM rate from infection among 336 chemo courses) | Van Winkle, 2005^387^
Secondary malignancies | 1 patient in a case report | Not applicable | Scully, 2000^435^
Infectious complications ≥ grade III | 12.7 | Not applicable | Bisogno, 2009^419^
Infectious complications ≥ grade III | Not applicable | 4 (8.3%) bacteremia 1 (2.1%) pneumonia | Pappo, 2001^425^
Infectious complications ≥ grade III | 2.8^b^ | Not applicable | Koscielniak, 1997^420^
Infectious complications ≥ grade III | Not applicable | 40 7 infections lead to death | Sandler, 2001^427^
Infectious complications ≥ grade III | 4 (50%) Sepsis 1 (13%) Fungal infection | Not applicable | Walterhouse, 1999^424^
Serious hemorrhagic event | NR | NR
Veno-occlusive disease | NR | NR
Long-term complications | NR | NR

HSCT = hematopoietic stem-cell transplantation; NR = not reported

a No cases of TRM occurred in these studies.

b Unclear if this occurred in first 100 days.

#### Ongoing Research

Twenty children age 21 or younger were to be enrolled in a Phase I study examining the toxicity of killer IG-like receptor mismatched umbilical cord blood for pediatric patients with malignant solid tumors. This study is ongoing and no longer recruiting, and no results have been published.

There are no trials specifically looking at HSCT outcomes in patients with rhabdomyosarcoma; however, ongoing trials are investigating support networks for transplant recipients (NCT00782145), prevention of fungal infection (NCT00079222) and genetic susceptibility (NCT00949052) to secondary malignancy among stem-cell recipients.

One ongoing open-label nonrandomized study, at the University of Michigan Cancer Center, is investigating a tumor lysate-pulsed dendritic cell vaccine for immune augmentation after stem-cell transplantation for pediatric patients with high-risk solid tumors (NCT00405327). This study is ongoing and no longer recruiting patients, and final data collection for the primary outcome is scheduled for June 2012.

#### Conclusion

Moderate strength evidence on overall survival suggests no benefit with single HSCT compared to conventional therapy for the treatment of high-risk metastatic rhabdomyosarcoma.

The body of evidence on overall survival with single HSCT compared to conventional therapy for the treatment of high-risk rhabdomyosarcoma of mixed tumor type is insufficient to draw conclusions

The body of evidence on overall survival with single HSCT compared to conventional therapy for the treatment of congenital alveolar rhabdomyosarcoma, cranial parameningeal rhabdomyosarcoma with metastasis, or the use of allogeneic transplantation for metastatic rhabdomyosarcoma was insufficient to draw conclusions.

### Retinoblastoma Systematic Review

#### Background and Setting

Retinoblastoma is the most common primary intraocular tumor in children, with an incidence of 1 in 15,000 births,437 and accounts for 4 percent of all childhood cancers. Majority of children present with intraocular disease where conventional treatments have produced at least a 90 percent chance of cure.438 Patients with trilateral retinoblastoma have an initial diagnosis of intraocular disease, with the subsequent development of a primary intra-cranial primitive neuro-ectodermal tumor and have traditionally had extremely poor prognosis and are included in this review. Extraocular or metastatic retinoblastoma in comparison to intraocular disease is generally lethal specifically when the disease has reached the central nervous system. Despite the development of new chemotherapy options, the prognosis of these patients is generally poor. Some centers have used HDC with HSCT in the setting of extraocular disease. Data from case series and case reports are available. Numbers remain small, as extraocular and trilateral retinoblastoma are rare conditions; no randomized controlled trials exist. Evidence was evaluated in three groups; studies confined to patients with CNS involvement, those with patients without CNS disease and patients with trilateral retinoblastoma.

#### Evidence Summary

The overall grade of strength of evidence for overall survival and the use of HSCT for the treatment of metastatic retinoblastoma is shown in Table 55.

Table 55 Overall grade of strength of evidence for overall survival and the use of HSCT for the treatment of metastatic retinoblastoma

Key Question | Study Design | Risk of Bias | Consistency | Directness | Precision | Strength of Association | Overall Grade/Conclusion
For pediatric patients with extraocular retinoblastoma with CNS involvement what is the comparative effectiveness and harms of HSCT and conventional chemotherapy regarding overall survival? Outcome of interest is overall survival. The comparator is conventional chemotherapy | There are two case reports on HSCT and nine case series (three on HSCT and six on the comparator conventional chemotherapy. Data from 16 patients treated with HSCT and 49 treated with conventional therapy were abstracted for this review. | The risk of bias in this evidence is high as our review consisted of small case series and case reports. | Results for overall survival are of unknown consistency. While in most cases confidence intervals may overlap and clinical heterogeneity exists the data consistently show poor outcome for both HSCT and conventional therapy. | The outcomes reported are direct. The comparisons are indirect as the evidence base utilizes two or more bodies of evidence to make comparisons. | The evidence is precise suggesting no overall survival advantage for HSCT over conventional therapy. While the evidence is qualitative it is unlikely that a clinically important superiority exists for HSCT for the treatment of extraocular retinoblastoma with CNS involvement. | Not applicable due to lack of obvious effect size. | Low strength evidence on overall survival suggests no benefit with single HSCT compared to conventional therapy for the treatment of extraocular retinoblastoma with CNS involvement.
For pediatric patients extraocular retinoblastoma without CNS involvement what is the comparative effectiveness and harms of HSCT and conventional chemotherapy regarding overall survival? Outcome of interest is overall survival. The comparator is conventional chemotherapy. | There are two case reports on HSCT and ten case series (five on HSCT and four on the comparator conventional chemotherapy and one retrospective review with data on both HSCT and conventional chemotherapy). Data from 41 patients treated with HSCT and 118 treated with conventional therapy were abstracted for this review. | Risk of bias in this evidence is high as our review consisted of small case series and case reports; these reports also included patients with various metastatic sites. Prognostic factors not well defined. The clinical course of disease may be modified by site of metastasis. | Results for overall survival of unknown consistency. While in most cases confidence intervals may overlap and clinical heterogeneity exists the range of results for overall survival are similar for both HSCT and conventional tx. However, some studies report high in the range while others report lower. With small numbers it is impossible to assess consistency. | The outcomes reported are direct. The comparisons are indirect as the evidence base utilizes two or more bodies of evidence to make comparisons. | The evidence is imprecise, effects are uncertain. There is uncertainty on whether HSCT is inferior, equivalent or superior to conventional chemotherapy. | Not applicable due to lack of obvious effect size. | The body of evidence on overall survival with single HSCT compared to conventional therapy for the treatment of extraocular retinoblastoma without CNS involvement is insufficient to draw conclusions.
For pediatric patients with trilateral retinoblastoma what is the comparative effectiveness and harms of HSCT and conventional chemotherapy regarding overall survival? Outcome of interest is overall survival. The comparator is conventional chemotherapy | There is one case series. Data from thirteen patients treated with HSCT were abstracted for this review. No comparator data was abstracted. | The risk of bias in this evidence is high as our review consisted of one case series with thirteen patients. | Consistency cannot be assessed as the data is limited to one case series. | The outcomes reported are direct. No comparator studies were identified. | The evidence is imprecise, effects are uncertain. There is uncertainty on whether HSCT is inferior, equivalent or superior to conventional chemotherapy. | Not applicable due to lack of obvious effect size. | The body of evidence on overall survival with single HSCT compared to conventional therapy for the treatment of trilateral retinoblastoma is insufficient to draw conclusions.

The evidence compiled for this review includes five case reports439-443 on HSCT and 15 case series (eight on HSCT438, 444-450 and five on the comparator conventional chemotherapy451-455 and two retrospective reviews with data on both HSCT and conventional chemotherapy456, 457). The total number of patients abstracted from the 20 studies was 267: 91 patients in 15 studies received HSCT, whereas 176 patients in seven studies received conventional chemotherapy.

Prognostic factors are not well defined except that patients with metastatic disease to the CNS have shorter survival than those with metastatic disease to other areas. Treatment with HSCT does not appear to alter the survival for patients with metastatic retinoblastoma to the CNS. These patients continue to have very poor prognosis. Treatment with HSCT may alter the 5-year survival for patients with metastatic retinoblastoma to sites other than the CNS, but these effects are uncertain. Treatment with HSCT may alter the 5-year survival for patients with trilateral retinoblastoma, but these effects are uncertain. Additional research with more patients is needed to confirm these findings. No information on quality of life was provided and data on adverse events was sparse and therefore insufficient to make conclusions regarding adverse effects and quality of life. One Phase III multicenter study of multimodal therapy (induction, HDC, and HSCT and/or radiotherapy) for young children with extraocular retinoblastoma is ongoing.

#### Results

Forty-one articles were retrieved for full-text screening. Twenty reports were included in this review, and the remaining 21 articles were excluded. The total number of patients abstracted from the twenty studies was 267: 91 patients in 15 studies received HSCT, whereas 176 patients in seven studies received conventional chemotherapy.

Table 56 shows the criteria that were used to select retinoblastoma studies.

Table 56 Retinoblastoma study selection criteria

Study Design | Population | Intervention | Comparators | Outcomes | Followup | Setting
Any study design | Pediatric patients (0-21-yr) with extraocular disease | Single Auto HSCT Tandem Auto HSCT | Chemotherapy +/- RT Chemotherapy +/- RT | OS; EFS (DFS; PFS); long-term adverse events; QOL | All durations of followup | In patient for HSCT. In or out-patient for conventional chemotherapy

Auto = autologous; DFS = disease-free survival; EFS = event-free survival; HSCT = hematopoietic stem-cell transplant; OS = overall survival; PFS = progression-free survival; QOL = quality of life

Table 57 shows the study design and population. Of the included publications, five were case reports on HSCT and 15 were case series (eight on HSCT438, 444-450 and five on the comparator conventional chemotherapy451-455 and two retrospective reviews with data on both HSCT and conventional chemotherapy456, 457). Five studies were based in Europe,441, 445, 447, 454, 456 three in Asia,439, 446, 452 three in South America,451, 453, 455 and nine in North America.438, 440, 442-444, 448-450, 457

Table 57 Retinoblastoma study characteristics and population

Study | Design | Median age | Range | Mean Age | Gender (%) | Histology [Site] (%) | HSCT (N) | Comparator (N) | Treatment Period
Cozza, Italy, 2009^456^ | retrospective review case series | 41.5 months at diagnosis (n=6) | 3-110 months (n=6) | NR | 50% Male, 50% Female (n=6) | CSF, Pineal, orbit, bone and bone marrow | HSCT (n=3) | Chemotherapy +/- RT (n=3) | 1988-2007
Jubran, USA, 2004^457^ | retrospective review case series | 11.5 months at diagnosis | 2-96 months | 23.7 month at diagnosis | NR | distant no CNS involvement | HSCT (n=4) | Chemotherapy +/- RT (n=6) | 1991-1999
Dunkel, USA, 2010^444^ | case series | 8 months at diagnosis | 1 week-20 months | NR | NR | suprasellar (n=2) pineal (n=11) | HSCT (n=13) | NA | 1997-2005
Dai, Canada, 2008^442^ | case report | NR | NR | 4 months at diagnosis 12 months at treatment | Female | with CSF involvement | HSCT (n=1) | NA | NR
Matsubara, Japan, 2005^446^ | case series | 16 months at diagnosis | 3-41 months at diagnosis | 17.6 months at diagnosis | 20% Male 80% Female | distant metastasis | HSCT (n=5) | NA | 1986-2000
Taguchi, Japan, 2005^439^ | case report | NA | NA | 4 | Male | maxilla and mandible | HSCT (n=1) | NA | NR
Kremens, Germany, 2003^445^ | case series | 34 months at diagnosis | 20-110 months at diagnosis | 51.8 months at diagnosis | NR | bone marrow, extraocular tumor | HSCT (n=5) | NA | 1992-2001
Rodriguez-Galindo, USA, 2003^448^ | case series | 30.5 at diagnosis | 17-36 months | 28.5 age at diagnosis | 75% Male 25% Female | distant metastasis no CNS involvement | HSCT (n=4) | NA | NR
Moshfeghi et al. USA, 2002^440^ | case report | NA | NA | 5 | Female | bone marrow, right humerus, both supraorbital bones, and both tibias, ovary | HSCT (n=1) | NA | NR
Hertzberg et al. Germany, 2001^441^ | case report | NA | NA | 7 | Female | lymph nodes, bones and bone marrow | HSCT (n=1) | NA | NR
Dunkel, USA, 2000^438^ | case series | 30.5 months at diagnosis | 17-44 months | 30.5 months at diagnosis | 50% Male 50 % Female | distant metastasis (BM, Orbit, liver, bone) no CNS involvement | HSCT (n=4) | NA | 1993-1996
Namouni, France, 1997^447^ | case series | 34 months | 9-125 months | NR | 76% Male 24% Female | cut end of optic nerve (n=5) disruption of ocular globe(n=1) isolated orbital relapse (n=7) various metastases (n=8) CNS/spinal axis (n=4) | HSCT (n=25) | NA | 1989-1994
Chang, Taiwan, 2006^452^ | case series | 26.3 months at diagnosis for all patients^*^ | 1.7 months-89 months^*^ | NR | NR | most common sites Orbit (n=7) and CNS (n=7) | NA | Chemotherapy +/- RT (n=15) | 1982-2004
Gunduz, Turkey, 2006^454^ | case series | NR | 13-86 | 45 months at diagnosis | NR | distant and CNS (n=5) CNS (n=9) distant only (n=4) | NA | Chemotherapy +/- RT (n=18) | 1999-2005
Antoneli, Brazil, 2003^451^ | case series | 32.9 months at diagnosis | 2-145 | NR | 53% Male 47% Female | 69 class I/III CCG classification 14 Class IV/V | NA | Chemotherapy +/- RT (n=83) | 1987-1991 period 1 1992-2000 period 2
Chantada, Argentina, 1999^453^ | case series | 24 months | 1-7 years | 37 months | 30% Male 70% Female | Orbit with only one patient with CNS involvement | NA | Chemotherapy +/- RT (n=10) 1 pt dead of parental abuse | 1995-1998
Schvartzman, Argentina, 1996^455^ | case series | Age NR for the subgroup abstracted | NR | NR | NR | Orbital (n=29) intracranial (n=6) hematogenous metastasis (n=6) | NA | Chemotherapy +/- RT (n=41) Stage II(n=29) Stage III (n=6) Stage Iv (n=6) | 1987-1993
Dimaras, Canada, 2009^443^ | case report | NA | NA | 4 months at diagnosis | Male | with CSF involvement | HSCT (n=1) | NA | 2001
Dunkel, USA, 2010^449^ | case series | 24.5 months | 4-38 months | 22 months at diagnosis | NR | With CNS involvement | HSCT (n=8) | NA | 2000-2006
Dunkel, USA, 2010^450^ | case series | 26 months | 1-44 months | 25 months at diagnosis | NR | Orbit (n=9), bone (n=11), bone marrow (n=14), liver (n=4) | HSCT (n=15) | NA | 1993-2006

NR = not reported

* This age estimate included patients excluded from the report for having intraocular disease.

All patients across the 15 treatment studies received HSCT as consolidation of primary treatments. Other than the patients with trilateral retinoblastoma442, 444 all patients had metastatic disease prior to transplant. For the comparison of tandem HSCT to single HSCT; no studies were identified in the search.

All studies were specific to the pediatric age group, with age primarily reported as age at diagnosis; 14 studies reported either mean age or only had one patient. Mean age at diagnosis was 21.8 months with a range of 4 months to 51.8 months. Median age, reported by 13 studies, was 26.3 months with a range of 1 week to 145 months. Patients were approximately split equally by gender. Induction regimens varied across and within study (i.e., different chemotherapeutic agents and different (cumulative) dosages). The induction regimen consisted of multiple cycles of chemotherapy with or without radiation, following primary enucleation.

Conditioning regimens also varied across and within studies. The most common regimens included the following agents; cyclophosphamide, thiotepa, etoposide, carboplatin and etoposide either alone or in combination, ICE (ifosfamide, carboplatin, and etoposide) is a common backbone used alone or in combination with radiation therapy or additional drugs. Treatment periods ranged from 1982 to 2007.

Table 58 shows the outcomes that were reported across studies.

Table 58 Retinoblastoma outcomes reported

Study | OS | EFS (DFS, PFS) | Quality of Life | Treatment-Related Mortality | Second Malignancies | Other Adverse Effects
Cozza, Italy, 2009^456^ | ✓ | NR | NR | NR | NR | NR
Jubran, USA, 2004^457^ | ✓ | NR | NR | NR | NR | NR
Dunkel, USA, 2010^444^ | ✓ | ✓ | NR | ✓ | NR | ✓
Dai, Canada, 2008^442^ | ✓ | NR | NR | NR | NR | NR
Matsubara, Japan, 2005^446^ | ✓ | NR | NR | NR | NR | ✓
Taguchi, Japan, 2005^439^ | ✓ | NR | NR | NR | NR | NR
Kremens, Germany, 2003^445^ | ✓ | NR | NR | NR | NR | ✓
Rodriguez-Galindo, USA, 2003^448^ | ✓ | NR | NR | NR | NR | ✓
Moshfeghi, USA, 2002^440^ | ✓ | NR | NR | NR | NR | NR
Hertzberg, Germany, 2001^441^ | ✓ | NR | NR | NR | NR | NR
Dunkel, USA, 2000^438^ | ✓ | NR | NR | ✓ | NR | ✓
Namouni, France, 1997^447^ | ✓ | ✓ | NR | NR | NR | ✓
Chang, Taiwan, 2006^452^ | ✓ | NR | NR | NR | ✓ | NR
Gunduz, Turkey, 2006^454^ | ✓ | NR | NR | NR | NR | NR
Antoneli, Brazil, 2003^451^ | ✓ | NR | NR | NR | ✓ | NR
Chantada, Argentina, 1999^453^ | ✓ | NR | NR | ✓ | NR | NR
Schvartzman, Argentina, 1996^455^ | ✓ | NR | NR | NR | NR | ✓
Dimaras, Canada, 2009^443^ | ✓ | NR | NR | NR | NR | NR
Dunkel, USA, 2010^449^ | ✓ | NR | NR | ✓ | NR | NR
Dunkel, USA, 2010^450^ | ✓ | ✓ | NR | NR | ✓ | NR

DFS = disease-free survival; EFS = event-free survival; NR = not reported; OS = overall survival; PFS = progression-free survival

##### Overall Survival

Data on overall survival were reported in all 20 studies (Table 58). Survival data are presented stratified by if patients were identified as having metastatic spread to the CNS, then by year (Table 59). A study of trilateral retinoblastoma was also separated into its own category. Ten studies presented data for patients with CNS involvement442, 443, 447, 449, 451, 453-457 and the same ten studies plus nine more 438-441, 445, 446, 448, 450 presented data on patients without CNS involvement. One study presented data exclusively on trilateral retinoblastoma.444 The individual studies either did not define overall survival or used different starting points for this variable (i.e., either years from diagnosis or years from first transplant). No direct comparisons can be made from the published data as there are no comparative studies.

Table 59 Overall survival for treatment (single auto HSCT) and comparison (conventional chemotherapy +/- radiation) groups: Retinoblastoma

Outcome | Intervention Single (%; ± 95% CI) | Comparator Chemo (%; ± 95% CI) | P Value | Study
1 year CNS | 50% (0.01-99) at 1 years (n=4) | Not applicable | 0.248@ | Namouni, 1997±447
1 year CNS | 50% (0,100) at 1 year (n=2)^b^ | Not applicable | | Matsubara, 2005^446^
1 year CNS | Not applicable | 71.4% (47.8,95.1) at 1 year (n=14) | | Gunduz, 2006^454^
1 year CNS | Not applicable | 0% at median 2 months (1-3)^*^ (n=4) | | Jubran, 2004^457^
1 year CNS | Not applicable | 33.3% (0, 86.7) at 1 year (n=3) | | Cozza, 2009^456^
1 year CNS | Not applicable | DOD at 3 months (n=1) | | Chantada,1999^453^
1 year CNS | Trilateral retinoblastoma with CNS DOD at 32 months (n=1) | Not applicable | | Dai, 2008^442^
1 year CNS | 50% | Not applicable | | Dunkel, 2010^449^
3 Year CNS | 25% (0-67.4) at 3 years (n=4) | Not applicable | 0.248@ | Namouni, 1997±447
3 Year CNS | 50% (0,100) at 3 years (n=2)^b^ | Not applicable | | Matsubara, 2005^446^
3 Year CNS | Not applicable | 14.3 (0, 42.9) at 3 years (n=14) | | Gunduz, 2006^454^
3 Year CNS | 0% at 16 months (n=1) | 0% at 3 years (n=3) | | Cozza, 2009^456^
3 Year CNS | NED at 2.7+ years | Not applicable | | Dimaras, 2009^443^
3 Year CNS | 50% | Not applicable | | Dunkel, 2010^449^
5 years CNS | 25% (0-67.4) at 5 years (n=4) | Not applicable | 0.248@ | Namouni, 1997±447
5 years CNS | 0% at 5 year (n=2)^b^ | Not applicable | | Matsubara, 2005^446^
5 years CNS | Not applicable | 0% survival^**^ at 5 years (t1, n=7) 20% survival at 5 years (t2, n=7) | 0.003^^ <0.001 | Antoneli, 2003^451^
5 years CNS | Not applicable | Stage III (CNS) 0% survival (n=6) | | Schvartzman, 1996 # 455
1 year No CNS | 75% (33-100) at 1 year (n=4) | 0% at 12 months (n=2) | | Jubran, 2004± 457
1 year No CNS | Patients with Trilateral retinoblastoma (n=13) 78% (37-104) at 1 year | Not applicable | | Dunkel, 2010^444^
1 year No CNS | Disease at cut end of optic nerve or in the ocular globe (n=6) 80% (44.9-100)1 years Bone or Bone marrow disease (n=8) 87.5 (64.6-100) at 1 year | Not applicable | 0.248@ | Namouni, 1997±447
1 year No CNS | Bone and bone marrow metastasis (n=4) 100% at 1 year | Not applicable | | Rodriguez-Galindo, 2003± 448
1 year No CNS | 100% at 1 years (n=2) | Not applicable | | Cozza et al. 2009^456^
1 year No CNS | DOD at 16 months (n=1) | Not applicable | | Moshfeghi, 2002^440^
1 year No CNS | DOD at 19 months (n=1) | Not applicable | | Taguchi, 2005^439^
1 year No CNS | Not applicable | 68.6% (32.1 – 100.0) at 1 year (n=8) | | Chantada,1999^453^
3 year No CNS | Patients with trilateral retinoblastoma (n=13) ∼38 at 3 years | Not applicable | | Dunkel, 2010^444^
3 year No CNS | Disease at cut end of optic nerve or in the ocular globe (n=6) 80% (44.9-100) 3 years Bone or bone marrow disease (n=8) 58.3 (22-94.7) at 3 years | Not applicable | 0.248@ | Namouni, 1997±447
3 year No CNS | Bone and bone marrow metastasis (n=4) 100% at 3 years | Not applicable | | Rodriguez-Galindo, 2003± 448
3 year No CNS | 50% (0-100) at 3years (n=4) | Not applicable | | Jubran, 2004±457
3 year No CNS | 100% at mean Followup of 86 months (n=3) | Not applicable | | Matsubara, 2005^446^
3 year No CNS | 100% at 3years (n=2) | Not applicable | | Cozza et al. 2009^456^
3 year No CNS | NED at 4+ years (n=1) | Not applicable | | Hertzberg, 2001^441^
3 year No CNS | Not applicable | 100% at mean 37 months followup (9-62) (n=4) | | Gunduz, 2006^454^
5 year No CNS | Bone or bone marrow disease (n=8) 58.3 (22-94.7) at 5 years | Not applicable | 0.248@ | Namouni, 1997±447
5 year No CNS | Bone or bone marrow disease (n=4) 100% survival at median follow up of 57 months (46-80) | Not applicable | | Dunkel, 2000^438^
5 year No CNS | Bone and bone marrow metastasis (n=4) 75% at 5 years^b^ | Not applicable | | Rodriguez-Galindo, 2003± 448
5 year No CNS | 100% at 5 years (n=2) | Not applicable | | Cozza et al. 2009^456^
5 year No CNS | Not applicable | 65.3% at 5 years (t1, n=36) 75.5% at 5 years (t2, n=33) | 0.003^^ <0.001 | Antoneli, 2003 451
5 year No CNS | Not applicable | Stage II 85% ± 0.06 (n=29) Stage IV 50% ± 0.20^ (n=6) | | Schvartzman, 1996 #455
5 year No CNS | 67% survival (38-85) at 5 years | Not applicable | | Dunkel, 2010^450^
5 year No CNS | Patients with trilateral retinoblastoma (n=13) 38% (14-63) at 5 years | Not applicable | | Dunkel, 2010^444^
Overall Survival mixed | ∼88% at 1 year^c^ ∼ 60% at 2 years ∼57% at 3 years ∼52% at 4-5years (n=34)^a^ | Not applicable | | Namouni, 1997^447^
Overall Survival mixed | Not applicable | 39.2 ± 14.7% at 5 years (n=15) | | Chang, 2006^452^
5 year OS range in studies with > 1 patients with extraocular retinoblastoma with CNS involvement | 25%^447^ | 0-20% 451, 455
5 year OS range in studies with > 2 patients with extraocular retinoblastoma without CNS involvement not including trilateral retinoblastoma | 58.3-100%^447, 448, 450^ Dunkel, 2000^d^ 438 | 50-75.5%^451, 455^
5 year OS range in studies with > 1 patients with trilateral retinoblastoma | 38% (14-63)444 | No comparator study identified

DOD = dead of disease; DOT = dead of toxicity; NED = no evidence of disease

* Only one of these patients was treated.

^ Three of these patients had CNS involvement.

** Two treatment periods are displayed.

^^ P-values are for the comparison of class IV/V (CNS and bone and lymph) to class I/III (non CNS bone or lymph mets).

a This includes all patients including those who died prior to treatment.

b Two patients developed CNS disease and died.

c Estimated preceded by a ∼ were estimated from published Kaplan-Meier curves.

± Survival curves were constructed using the raw data published in the articles.

@ Comparison of the three overall survival curves for cut end of optic nerve, bone mets, and CNS disease.

d Survival was 100% at a median followup of 57 months (46-80).

##### Event-free Survival

Information on event-free survival can be found in Appendix D.

##### Adverse Effects

No studies evaluated quality of life, and adverse effects were only reported by intervention studies. Data on treatment-related mortality was reported in two intervention studies (Table 60). Two patients died from septicemia and multi-organ failure during induction therapy.444, 449 Two studies reported cases of serious infection, both attributed to Candida albicans.447, 448 One comparator study451 reported three secondary malignancies (two osteogenic sarcoma, and one nonlymphocytic leukemia) and one intervention study450 reported three secondary malignancies (osteosarcoma, two occurring in irradiated fields). There were no reports of serious hemorrhagic events, irreversible veno-occlusive disease or other long-term complications among patients treated with HSCT or conventional chemotherapy.

Table 60 Adverse effects for single auto HSCT and comparison (conventional chemotherapy +/- radiation) groups: Retinoblastoma

Outcome | Disease | Intervention HSCT (%) | Comparator Chemo (%) | Study
Treatment related mortality | CNS | 0^a^ | NA | Dai, 2008^442^; Gunduz, 2006^454^; Matsubara, 2005^446^; Namouni, 1997^447^; Dimaras, 2009^443^
Treatment related mortality | CNS | NA | 0^a^ | Cozza, 2009^456^; Chantada, 1999^453^; Jubran, 2004^457^;
Treatment related mortality | CNS | 12.5^b^ | NA | Dunkel, 2010^449^
Treatment related mortality | No CNS | 0^a^ | NA | Dunkel, 2000^438^; Hertzberg, 2001^441^; Kremens, 2003^445^; Matsubara, 2005^446^; Moshfeghi, 2002^440^; Taguchi, 2005^439^; Dunkel, 2010^450^
Treatment related mortality | No CNS | NA | 0^a^ | Gunduz, 2006^454^; Jubran, 2004^457^;
Treatment related mortality | Trilateral retinoblastoma | 7.7^b^ | NA | Dunkel, 2010^444^
Secondary malignancies | CNS | NR | NR
Secondary malignancies | No CNS | | 3.6 | Antoneli, 2003^451^
Secondary malignancies | No CNS | 20 | NA | Dunkel, 2010^450^
Secondary malignancies | Trilateral retinoblastoma | NR | NR
Infectious complications | CNS | 4 | NR | Namouni, 1997^447^
Infectious complications | No CNS | 25 | NR | Rodriguez-Galindo, 2003^448^
Infectious complications | Trilateral retinoblastoma | NR | NR
Serious hemorrhagic event | CNS | NR | NR | There were no reports from any study
Serious hemorrhagic event | No CNS | NR | NR | There were no reports from any study
Serious hemorrhagic event | Trilateral retinoblastoma | NR | NR | There were no reports from any study
Veno-occlusive disease | CNS | NR | NR | There were no reports from any study
Veno-occlusive disease | No CNS | NR | NR | There were no reports from any study
Veno-occlusive disease | Trilateral retinoblastoma | NR | NR | There were no reports from any study
Long-term complications | CNS | NR | NR | There were no reports from any study.
Long-term complications | No CNS | NR | NR | There were no reports from any study.
Long-term complications | Trilateral retinoblastoma | NR | NR | There were no reports from any study.

a No cases of TRM occurred in these studies.

b Death occurred during induction chemo.

#### Ongoing Studies

A Phase III multicenter study of multimodal therapy (induction, HDC, and HSCT and/or radiotherapy) for young children with extraocular retinoblastoma was identified (NCT00554788). This trial estimates it will enroll 60 children ages 10 years of age and younger and will be complete in February 2014. Event-free survival is the primary outcome measure.

Twenty children ages 21 or younger were to be enrolled in a Phase I study examining the toxicity of killer IG-like receptor mismatched umbilical cord blood for pediatric patients with malignant solid tumors. This study is ongoing and no longer recruiting, and no results have been published.

#### Conclusion

Low strength evidence on overall survival suggests no benefit with single HSCT compared to conventional therapy for the treatment of extraocular retinoblastoma with CNS involvement.

The body of evidence on overall survival with single HSCT compared to conventional therapy for the treatment of extraocular retinoblastoma without CNS involvement was insufficient to draw conclusions.

The body of evidence on overall survival with single HSCT compared to conventional therapy for the treatment of trilateral retinoblastoma without CNS involvement was insufficient to draw conclusions.

### Neuroblastoma Systematic Review

#### Background and Setting

Neuroblastoma is the most common extracranial solid tumor of childhood, and accounts for 8 to 10 percent of all childhood cancers and for approximately 15 percent of cancer deaths in children.103 At least 40 percent of all children with neuroblastoma are designated as high-risk patients.103, 104 Despite the development of new treatment options, the prognosis of patients with high-risk neuroblastoma is generally poor; more than half of patients experience disease recurrence and long-term survival with current treatments is about 30 percent.104

Many centers have used HDC with HSCT in the setting of high-risk or recurrent disease.103, 106 Results from randomized controlled trials (RCTs) comparing HDC/HSCT with conventional therapy have shown higher survival rates with HSCT, although higher levels of adverse effects have been reported and overall rates are unsatisfactory.105, 107, 108 Sequential tandem HSCT has been developed to improve further the outcome of patients with high-risk neuroblastoma.

#### Evidence Summary

The overall grade of strength of evidence for overall survival in pediatric patients with high-risk neuroblastoma is shown in Table 61.

Table 61 Overall grade of strength of evidence for overall survival: Neuroblastoma

Key Question | Study Design | Risk of Bias | Consistency | Directness | Precision | Strength of Association | Overall Grade/ Conclusion
For pediatric patients with high-risk neuroblastoma, what is the comparative effectiveness and harms of tandem HSCT and single HSCT regarding overall survival? Outcome of interest is overall survival. The comparator is single HSCT. | There are six observational studies on tandem HSCT (three provided comparisons of tandem vs. single HSCT, and three of tandem HSCT. There are three RCTs on single HSCT (vs. conventional therapy). | The risk of bias in this evidence is medium. The EBMT cohort represents the largest cohort of patients in this setting. While this is an uncontrolled design, the risk of bias is mitigated by the similarity of the study patients given well established staging and prognostic factors. | Results for overall survival for tandem HSCT are inconsistent. Recruitment of patients in the EBMT cohort spans over 25 years and includes various treatment regimens and reports similar survival rates. Two more recent case series report higher survival rates. Results for overall survival for single HSCT consistently show improved outcome compared to conventional therapy. | The outcomes reported are direct. The comparisons are indirect as the evidence base utilizes two or more bodies of evidence to make comparisons. | The evidence is imprecise, effects are uncertain. There is uncertainty on whether tandem HSCT is inferior, equivalent or superior to single HSCT. | Not applicable due to lack of obvious effect size. | The body of evidence on overall survival with tandem HSCT compared to single HSCT for the treatment of high-risk neuroblastoma was insufficient to draw conclusions.

The evidence compiled for this review includes six observational studies on HSCT, and three RCTs reporting outcomes data on single HSCT. The total number of patients included in the nine studies was 4,044: 682 patients received tandem HSCT, whereas 3,362 patients received single HSCT.

Tandem HSCT results in no significant differences in survival rates than single HSCT. In addition, no significant differences in secondary malignant disease and treatment-related mortality between treatment groups were identified. No information on QOL was provided and data on adverse effects are very limited; no definitive conclusions can be made regarding adverse effects and quality of life.

The ongoing randomized trial by the Children's Oncology Group will address whether tandem HSCT is superior to single HSCT in patients with high-risk neuroblastoma.

#### Results

Eighteen reports describing nine unique studies were included in this review. Data from the European Group for Blood and Marrow Transplantation (EBMT) registry on outcomes for single and tandem HSCT have been reported in two publications.113, 458 George et al. have reported outcomes of tandem HSCT across four U.S. centers in seven publications.459-465 Two further studies have been reported in multiple publications; two reports by Sung et al. on tandem HSCT466, 467 and two reports of the RCT by Matthay et al. on single HSCT.107, 111 The report with the largest sample size and longest followup period from each of the above series was included in the primary analysis for this review. The total number of patients included in the nine studies was 4,044: 682 patients received tandem HSCT, whereas 3,362 patients received single HSCT.

Table 62 shows the criteria that were used to select studies for this section.

Table 62 Study selection criteria: Neuroblastoma

Study Design | Population | Intervention | Comparators | Outcomes | Time | Setting
Controlled trial, cohort, case-series | Pediatric patients (0-21 yr) with high-risk or relapsed/refractory disease | Tandem (Auto Auto) HSCT | Single (Auto) HSCT | OS; EFS (DFS; PFS); long-term adverse events; QOL | All durations of followup | In-patient

Auto = autologous; DFS = disease-free survival; EFS = event-free survival; HSCT = hematopoietic stem-cell transplant; OS = overall survival; PFS = progression-free survival; QOL = quality of life

Table 63 shows the study design and population. Of the included publications, six were observational studies (three provided comparisons of tandem vs. single HSCT466, 468, 469; three of tandem HSCT459, 462), and three were RCTs reporting outcomes data on single HSCT.105, 107, 108, 111 Five were multicenter studies (two reporting on outcomes for tandem HSCT and three trials on single HSCT). Three studies were based in Europe,105, 108, 113 three in Asia,466, 468, 469 and three in North America.107, 459, 462The EBMT data represents the largest cohort of patients recruited over 28 years (1978–2006).113

Table 63 Study characteristics and population: Neuroblastoma

Study | Design | Median Age in Months (Range) | Sex (M%) | Histology [Site] (%) | Tandem | Single | Treatment Period
Ladenstein, 2008;1998^113, 458^ | Cohort | 47 (4-744) | 59 | NR | 455 | 2,895 | 1978-2006
Kim, 2007^468^ | Case-Series | 36 (7-121) | 69 | NR [Abdomen (89); Other (11)] | 9 | 27 | 1996-2004
Sung, 2007^466^ | Case-Series | 36 (13-129); 45.5 (24-140)^a^ | NR | Favorable (27); Unfavorable (71); Unknown (2) | 52 | NA | 1997-2005
George, 2006^459^ | Case-Series | 35 (6-216) | NR | [Adrenal (54); Abdomen (37); Other (9)]^b^ | 82^b^ | NA | 1994-2002
Hobbie, 2008^462^ | Case-series | 22 (13-72) | 85 | NR | 13 | NA | 1997-2001
Sung, 2010^469^ | Case-series | 36 (13-144) c 39 (13-159)^d^ | 46^c^ 50^d^ | NR | 71 | 70 | 2000-2005
Matthay, 2009; 1999^107, 111^ | RCT | (0-216) | NR | Favorable (3); Unfavorable (63); Unknown (33) | NA | 189 | 1991-1996
Berthold, 2005^105^ | RCT | (0-240) | NR | NR | NA | 149 | 1997-2002
Pritchard, 2005^108^ | RCT | (6-240) | 50% | [Abdomen (88); Other (12)] | NA | 32 | 1982-1985

M = male; NA = not applicable; NR = not reported; RCT = randomized controlled trial

a Age at transplant.

b Population characteristics based on 97 study patients.

c Tandem HSCT group.

d Single HSCT group.

All patients across eight (of nine) studies received HSCT as consolidation of primary treatments, Eighty percent of patients in the EBMT cohort received HSCT as consolidation therapy; relapse was the indication in another 10 percent while the status prior to HSCT was not specified in a further 10 percent of patients.113 The vast majority of patients across studies presented with stage IV disease at diagnosis (range: 81 to 100 percent For the EBMT data, the stage was reported only in 53 percent of the cohort but there was a high prevalence for advanced disease with stage IV in more than 90 percent of the reported cases.113

Eight studies were specific to the pediatric age group; the EBMT cohort consisted of 2 percent (of 3,421) patients over 18 years of age. Eight studies reported the age of the participants at diagnosis; Sung et al. (2007) reported age at both diagnosis and HSCT.466 The median age was reported in six studies on tandem HSCT; the remaining three trials on single HSCT reported only the number of cases above and below one year of age. The majority of patients (86 to 97 percent across all studies were over 12 months of age at diagnosis.

All studies used different induction regimens (i.e., different chemotherapeutic agents and different (cumulative) dosages). The induction regimen across studies consisted of multiple cycles (1-10) of chemotherapy followed by surgery for resection of the primary tumor. The timing of surgery varied during induction and took place at diagnosis or after 2 to 7 cycles of chemotherapy. Tumor-field radiotherapy was used in patients with residual tumor and/or metastatic disease in at least six (of nine) studies: Sung et al. employed radiotherapy in the early study period (diagnosis by December 2003).466 There was no postoperative radiotherapy in Pritchard et al.; in this latter study, 41 percent of patients randomized to the single HSCT arm received nine or more cycles of induction chemotherapy.108

Various conditioning regimens were used across studies. The primary conditioning regimen consisted of carboplatin, etoposide and melphalan. Total body radiation was used as part of the treatment regimen in six studies.107, 113, 459, 462, 466, 469 In at least four studies, there were also differences in treatment that patients received within the study itself (for example, in external radiotherapy, immunotherapy, and retinoic acid).

Peripheral blood stem cells were used as the sole source of support in six studies,105, 459, 462, 466, 468, 469 and bone marrow in two studies;107, 108 the EBMT cohort used peripheral stem cells (56 percent), bone marrow (41 percent) and a combination of both (3 percent) as a source of support after HDC.113 The median follow-up durations from first transplant across three studies comparing tandem and single HSCT were 2.3 years, 9 years, and 5 years, respectively.113, 468, 469

Table 64 shows the outcomes that were reported across nine studies. Of note, the study by Hobbie et al.462 was a subgroup analysis of George et al.459 reporting on the long-term adverse events of tandem HSCT for high-risk disease. For purposes of data analysis and synthesis, these two reports were considered as unique studies; George et al.459 reported on overall survival (OS), event-free survival (EFS), treatment-related mortality and secondary malignancies, while Hobbie et al.462 reported on other adverse effects of HSCT.

Table 64 Outcomes reported: Neuroblastoma

Study | OS | EFS (DFS, PFS) | QOL | Treatment-related Mortality | Second Malignancies | Other Adverse Effects
Ladenstein, 2008^113^ | ✓ | ✓ | NR | NR | NR | NR
Kim, 2007^468^ | ✓ | ✓ | NR | NR | NR | NR
Sung, 2007^466^ | ✓ | ✓ | NR | ✓ | ✓ | ✓
George, 2006^459^ | ✓ | ✓ | NR | ✓ | ✓ | ✓
Hobbie, 2008^462^ | NR | NR | NR | NR | NR | ✓
Matthay, 2009^111^ | ✓ | ✓ | NR | ✓ | ✓ | ✓
Berthold, 2005^105^ | ✓ | ✓ | NR | ✓ | ✓ | NR
Pritchard, 2005^108^ | ✓ | ✓ | NR | ✓ | NR | ✓
Sung, 2010^469^ | NR | ✓ | NR | ✓ | ✓ | NR

DFS = disease-free survival; EFS = event-free survival; NR = not reported; OS = overall survival; PFS = progression-free survival; QOL = quality of life

##### Overall Survival

Data on OS were reported in seven (of nine) primary studies (Table 64). Six studies presented 3- and/or 5-year rates and the study by George et al.459 also presented 7-year rates (Table 65). No significant differences in either the 3-year or 5-year OS between treatment groups were identified in the two comparative studies (Table 65).113, 468 Multivariate analysis of EBMT data showed significantly better OS rates in patients younger than 2 years of age at diagnosis (Hazard Ratio [HR], 1.6; 95 percent; Confidence Interval [CI], 1.4-1.9; p<0.0001).113 It should be noted that the individual studies either did not define OS or used different starting points for this variable (i.e., either years from diagnosis or years from first transplant).

Table 65 Overall survival for treatment (tandem HSCT) and comparison (single HSCT) groups: Neuroblastoma

Outcome | Intervention Tandem (%; ± 95% CI; SE) [N] | Comparator Single (%; ± 95% CI; SE) [N] | P Value | Study
3-year rate | 66.7 (19.3) [9] | 55.1 (13.9) [27] | >0.05 | Kim, 2007^468^
3-year rate | 74 (62-82) [82] | Not applicable | NR | George, 2006^459^
3-year rate | Not applicable | 43 (4) [189] | NR | Matthay, 2009^111^
3-year rate | Not applicable | 62 (54-70) [149] | NR | Berthold, 2005^105^
5-year rate | 33 (3) [455] | 38 (1) [2,895] | 0.105 | Ladenstein, 2008^113^
5-year rate | 64 (52-74) [82] | Not applicable | NR | George, 2006^459^
5-year rate | 64.3 (14.3) [52] | Not applicable | NR | Sung, 2007^466^
5-year rate | Not applicable | 29 (4) [189] | NR | Matthay, 2009^111^
5-year rate | Not applicable | 47 (30-64) [32] | NR | Pritchard, 2005^108^
7-year rate | 54 (38-67) [82] | Not applicable | NR | George, 2006^459^
7-year rate | Not applicable | ∼25 [189] | NR | Matthay, 2009^111^
OS range for ≥5 years, studies with >10 pts | 33-64 | 29-47 | NR

CI = confidence interval; N = number of patients; NR = not reported; SE = standard error

##### Event-free Survival

Information on event-free survival can be found in Appendix D.

##### Adverse Effects

None of the studies evaluated quality of life (Table 64). Data on treatment-related mortality were reported in six studies (Table 66). There were 20 (of 197) cases in the tandem group and 36 (of 373) cases in the single HSCT group. Secondary malignancies were reported in five studies (Table 66). There were three (of 212) cases in the tandem group (one synovial cell sarcoma, one myelodysplasia with clonal trisomy 8, and one thyroid cancer); two cases were reported in the George et al.459 study. The case of thyroid cancer was reported in the 2010 study by Sung et al.469, and occurred in a patient receiving only the first HSCT. Three (of 408) cases of secondary malignancies were reported in the single HSCT group (two acute myeloblastic leukemias and one follicular carcinoma of the thyroid).

Table 66 Adverse effects for treatment (tandem HSCT) and comparison (single HSCT) groups: Neuroblastoma

Outcome | Intervention Tandem (%) | Comparator Single (%) | Study
Treatment-related mortality | 16 | Not applicable | Sung, 2007^466^
Treatment-related mortality | 6 | Not applicable | George, 2006^459^
Treatment-related mortality | Not applicable | 6 | Matthay, 2009^111^
Treatment-related mortality | Not applicable | 3.3 | Berthold, 2005^105^
Treatment-related mortality | Not applicable | 7 | Pritchard, 2005^108^
Treatment-related mortality | 11 | 13 | Sung, 2010^469^
Secondary malignancies | 0 | Not applicable | Sung, 2007^466^
Secondary malignancies | 2 | Not applicable | George, 2006^459^
Secondary malignancies | Not applicable | 1 | Matthay, 2009^111^
Secondary malignancies | Not applicable | 1 | Berthold, 2005^105^
Secondary malignancies | 1 | 0 | Sung, 2010^469^
Infectious complications | 3.8 | Not applicable | Sung, 2007^466^
Infectious complications | 5 | Not applicable | George, 2006^459^
Infectious complications | Not applicable | 26 | Matthay, 2009^111^
Infectious complications | Not applicable | 23 | Pritchard, 2005^108^
Infectious complications | 2 | Not applicable | Sung, 2007^466^
Serious hemorrhagic event | Not applicable | 10 | Pritchard, 2005^108^
Serious hemorrhagic event | 18 | Not applicable | Sung, 2007^466^
Veno-occlusive disease | 1 | Not applicable | George, 2006^459^
Veno-occlusive disease | Not applicable | 9 | Matthay, 2009^111^
Veno-occlusive disease | Not applicable | 7 | Pritchard, 2005^108^
Long-term complications | (8-92)^a^ | Not applicable | Hobbie, 2008^462^

a range of late-effects including endocrine, sensory, musculoskeletal, pulmonary, dental, renal, and cardiovascular complications

Infectious complications were reported in four studies (Table 66). Sepsis was more prevalent in the single HSCT group (n=219) compared to the tandem group (n=126) (26 vs. 2 percent). All infectious complications were attributed to sepsis in the single HSCT group. Further serious infections in the tandem group included two cases of viral pneumonia and three cases of Epstein-Barr virus and cytomegalovirus, all resulting in toxicity-related deaths. Other reported serious adverse effects included one case of pulmonary hemorrhage in the tandem group and three cases of bleeding in the single HSCT group.

The frequency of veno-occlusive disease was reported across four studies (Table 66).108, 111, 459, 466 There were nine (of 126) cases in the tandem group and two (of 30) cases in the single HSCT group. Only one study (n=13) by Hobbie et al.462 reported further long-term complications including developmental delays (i.e., hearing loss, 92 percent), cataracts (54 percent), and growth-hormone deficiency (54 percent) following tandem HSCT.

#### Ongoing Research

In North America, the Children's Oncology Group is studying, in a randomized fashion, whether tandem HDC/HSCT is superior to a single HDC/HSCT in patients with high-risk neuroblastoma up to 30 years of age. This is an international trial (U.S., Canada, Australia, New Zealand) being undertaken across 142 centers and is currently recruiting patients with an expected enrollment of 495 patients. The primary outcomes of interest include 3-year EFR, response after induction therapy, and incidence rate of local recurrence. The projected completion of accrual is spring 2012 (NCT00567567).^a^

a The projected date was confirmed as personal communication to Hussein Noorani by Dr. Julie Park, Study Chair of the Children's Oncology Group, October 15, 2010.

#### Conclusion

The body of evidence on overall survival with tandem HSCT compared to single HSCT for the treatment of high-risk neuroblastoma was insufficient to draw conclusions.

### Germ-Cell Tumors Systematic Review

#### Background and Setting

Germ cell tumors (GCT) are rare in children younger than 15 years, accounting for approximately 3 percent of cancer cases in this age group.115 Childhood GCT can be divided into gonadal (ovarian and testicular) and extragonadal (e.g., mediastinal or retroperitoneal) neoplasms.118 Gonadal GCT (particularly testicular GCT) are much more common among adolescents aged 15 to 19 years, representing approximately 14 percent of cancer diagnoses in this age group.115 GCTs are highly sensitive to chemotherapy. Cisplatin-based combination chemotherapy, followed by appropriate surgical resection of residual disease, is curative in 80 percent of patients; however, about 20-30 percent of patients may develop recurrent disease.114, 118, 119 HDC with HSCT has been explored primarily in adults with relapsed testicular GCT through observational studies.115, 118, 119, 470

Reports from salvage treatment strategies used in adult recurrent GCT include larger numbers of patients, but the differences between children and adults regarding the location of the primary GCT site, pattern of relapse, and the biology of childhood disease may limit the applicability of adult salvage approaches to children. Sequential tandem HSCT has been developed to improve further the outcome for children with relapsed GCT.

#### Evidence Summary

The overall grade of strength of evidence for overall survival in pediatric patients with tandem HSCT compared to single HSCT for the treatment of relapsed germ cell tumors is shown in Table 67. The evidence compiled for this review includes four observational studies.114, 119, 120, 470 The total number of pediatric patients included in the four studies was 71: 29 patients received tandem HSCT, whereas 42 patients received single HSCT. Tandem HSCT results in no significant differences in survival rates than single HSCT. No information on QOL was provided, and data on adverse effects are very limited; no definitive conclusions can be made regarding adverse effects and QOL. Results to date are based on small observational studies that have focused on adult patients with gonadal disease. Tandem HSCT may be particularly beneficial in patients with more advanced testicular cancer at diagnosis and greater likelihood of exhibiting cisplatin resistance when compared to single HSCT. However, the reports have great variability in patient selection, prior treatments, the choice of the conditioning regimen and variability of doses within the same regimen. Furthermore, many reports have either combined the data from single and tandem transplants or the numbers are very small.

Table 67 Overall grade of strength of evidence for overall survival: Germ cell tumor

Key Question | Study Design | Risk of Bias | Consistency | Directness | Precision | Strength of Association | Overall Grade/ Conclusion
For pediatric patients with relapsed germ cell tumors, what is the comparative effectiveness and harms of tandem HSCT and single HSCT regarding overall survival? Outcome of interest is overall survival. The comparator is single HSCT. | There are two observational studies on tandem HSCT (one provided comparison of tandem vs. single HSCT, and one of tandem HSCT). There are two observational studies on single HSCT. | The risk of bias in this evidence is high as our review consisted of small cohorts and case series. | Results for overall survival are inconsistent. Confidence intervals overlap and clinical heterogeneity exists between studies. | The outcomes reported are direct. The comparisons are indirect as the evidence base utilizes two or more bodies of evidence to make comparisons. | The evidence is imprecise; effects are uncertain. There is uncertainty on whether tandem HSCT is inferior, equivalent or superior to single HSCT. | Not applicable due to lack of obvious effect size. | The body of evidence on overall survival with tandem HSCT compared to single HSCT for the treatment of relapsed pediatric germ cell tumors was insufficient to draw conclusions.

Randomized (prospective) trials focused on young children and adolescents will be needed to determine if tandem HSCT transplants is superior to single HSCT utilizing an optimal conditioning regimen.

#### Results

Seventeen articles were retrieved for full-text screening. Four reports were included in this review, and the remaining 13 articles were excluded. The total number of pediatric patients included in the four studies was 71 (of 539): 29 patients received tandem HSCT, whereas 42 patients received single HSCT. Table 68 shows the study selection criteria.

Table 68 Germ cell tumor study selection criteria

Study Design | Population | Intervention | Comparators | Outcomes | Time | Setting
Controlled trial, cohort, case-series | Pediatric patients (0-21-yr) with relapsed disease | Tandem (Auto Auto) HSCT | Single (Auto) HSCT | OS; EFS (DFS; PFS); long-term adverse events; QOL | All durations of followup | In-patient

Auto = autologous; DFS = disease-free survival; EFS = event-free survival; HSCT = hematopoietic stem-cell transplant; OS = overall survival; PFS = progression-free survival; QOL = quality of life

Table 69 shows the study design and population. All four publications were observational studies. Tandem transplants were performed in two (50 percent) studies. Only one study reported outcomes data of tandem versus single HSCT.119 Two were multicenter studies (Center for International Blood and Marrow Transplant Research [CIBMTR] cohort by Lazarus et al.119 and a European Group for Blood and Marrow Transplantation [EBMT] cohort by De Giorgi et al.114 and two were U.S. single-center studies.120, 470

Table 69 Germ cell tumor study characteristics and population

Study | Design | Median Age in Years (range) | Sex (M%) | Histology [Site] (%) | Tandem | Single | Treatment Period
Lazarus, 2007^119^ [CIBMTR, 2010^471^] | Cohort | 19 (15-20)^a^ 20 (17-20)^b^ | NR | NS (53^a^, 67^b^); SM (21^a^, 0^b^); CC (16^a^,0^b^); EB (5^a^,33^b^); Other (5^a^,0^b^) [Testes (90^a^, 100^b^); Extragonadal (10^a^, 0^b^)] | 12 | 20 | 1989-2001
Einhorn, 2007^470^ | Case series | 20 (17-21)^c^ | NR | NS (81); SM (19) [Testes] | 17^c^ | 0 | 1996-2004
Agarwal, 2009^120^ | Case series | NR (0-19)^d^ | 92 | NS (84); SM (16) [Testes (65); Chest/ Neck/RP (27); CNS (8)] | 0 | 4^d^ | 1995-2005
De Giorgi, 2005^114^ | Cohort | 6.5 (1-18) | 56 | NG (94); GM (6) [CNS (39); Sacr (39); Retr (17); Med (6)] | 0 | 18 | 1987-2003

CC = pure choriocarcinoma; CNS = central nervous system; EB = pure embryonal; GM = germinoma; M = male; NG = nongerminoma; NR = not reported; NS = nonseminoma; RP = retroperitoneal; SM = seminoma

a Single transplant.

b Tandem transplant.

c 184 patients in study (median age of 31 yrs (range, 15-58 yrs).

d 37 patients in study (median age of 28 yrs (range, 9-59 yrs).

Only one small study by De Giorgi et al.114 was specific to the pediatric age group; approximately 10 percent of all patients across the remaining three studies were in the pediatric age range (Einhorn, 2007: n=17 [of 184];470 Lazarus, 2007: n=32 [of 300];119 Agarwal, 2009: n=4 [of 37]120 ). The corresponding authors for the three studies were approached for outcomes data (and if available, patient characteristics) specific to the pediatric age groups.^b^ Data on study variables and outcome events for the pediatric age range (11-20 years) for Lazarus et al.119 were obtained from the CIBMTR.471,c

b Data from Einhorn et al. (2007) were provided as personal communication to Hussein Noorani by Dr. Lawrence Einhorn, August 11 and September 1, 2010, respectively; data on outcome events from Agarwal et al. (2009) was provided as personal communication to Hussein Noorani by Dr. Rajni Agarwal, August 10, 2010.

c The data presented here are preliminary and were obtained from the Statistical Center of the Center for International Blood and Marrow Transplant Research. The analysis has not been reviewed or approved by the Advisory or Scientific Committees of the CIBMTR.

All study patients received HSCT as salvage treatment for relapsed disease. The majority of patients (65-100 percent) across three studies had advanced testicular cancer; the EBMT cohort consisted of pediatric patients with extragonadal GCT.114 Most patients received a cisplatin-based chemotherapy regimen initially and surgery for residual disease when appropriate. Various conditioning regimens were used across studies. The primary conditioning regimen consisted of carboplatin and etoposide. Peripheral blood stem cells were used as either the sole or primary source of support in all studies.

For the CIBMTR cohort, the tandem and single HSCT groups were comparable for median age, testicular versus abdominal origin, number of chemotherapy regimens prior to HSCT, and year of HSCT (over 50 percent of transplants were performed between 1996 and 1998).471 The interval from diagnosis to first HSCT for the CIBMTR cohort was 12 (range: 2-34) months for the tandem group and 9 (range: 3-17) months for the single HSCT group. Eighty-three percent and 65 percent of patients had residual cancer at time of HSCT, respectively.471 There were observed differences in the intensity of the transplant preparative regimen between the two study groups; 58 percent of the tandem group received a regimen containing 3 or more chemotherapeutic agents in contrast to 95 percent in the single HSCT group.471 In addition, in comparison to the single HSCT group, the tandem group had a greater likelihood of cisplatin-resistance at time of transplantation (58 percent vs. 10 percent), and was more likely to receive blood (83 percent vs. 60 percent) rather than marrow as the stem cell source.471 Median followup in the CIBMTR cohort was 56 (range: 45-74) months for the tandem group and 59 (range: 13-124) months for the single HSCT group, respectively.471

The Einhorn et al.470 tandem series exhibited more favorable prognostic features compared to the CIBMTR tandem cohort. No patients in this series received more than two chemotherapeutic agents as part of their transplant preparative regimen.470 Seventy-eight percent of patients exhibited platinum sensitivity and all patients received peripheral-blood stem cells.470 Median followup in the Einhorn series was comparable to the CIBMTR cohort (48 [range: 14-118] months).470

Table 70 shows the pediatric outcomes that were reported across the four studies.

Table 70 Germ cell tumor outcomes reported

Study | OS | EFS (DFS, PFS) | Quality of Life | Treatment-related Mortality | Second Malignancies | Other Adverse Effects
CIBMTR, 2010^471^ | ✓ | ✓ | NR | ✓ | NR | ✓
Einhorn, 2007^470^ | ✓ | ✓ | NR | NR | NR | NR
Agarwal, 2009^120^ | ✓ | ✓ | NR | ✓ | ✓ | ✓
De Giorgi, 2005^114^ | ✓ | ✓ | NR | ✓ | ✓ | ✓

DFS = disease-free survival; EFS = event-free survival; NR = not reported; OS = overall survival; PFS = progression-free survival

##### Overall Survival

Data on OS were reported in all four studies (Table 70). Data were available to compute three-year rates across all studies, and five-year rates for three studies (Table 71). Similar trends were observed between treatment groups in the one-, three-, and five-year OS across studies (Table 71). For the CIBMTR cohort, five-year survival probability was 36 percent (95 percent confidence interval (CI), 10-69 percent) in the tandem group compared to 49 percent (24-68 percent) in the single HSCT group.471 OS was defined across three studies as the interval between salvage chemotherapy or transplant and death from any cause.

Table 71 Overall survival for tandem HSCT and comparison (single HSCT) groups: Germ cell tumor

Outcome | Intervention Tandem (%; ± 95% CI) [N] | Comparator Single (%; ± 95% CI) [N] | p Value | Study
1-year rate | 67 (34-86) [12] | 65 (40-82) [20] | NR | CIBMTR, 2010^471^
1-year rate | 76.5 (59-99.5) [17] | NA | NR | Einhorn, 2007^470^
1-year rate | NA | 67 (45-88) [18] | NR | De Giorgi, 2005^114^
3 year rate | 42 (15-67) [12] | 49 (24-68) [20] | NR | CIBMTR, 2010^471^
3 year rate | 63 (43-92) [17] | NA | NR | Einhorn, 2007^470^
3 year rate | NA | 50 (7-93) [4] | NR | Agarwal, 2009^120^
3 year rate | NA | 56 (33-78.5) [18] | NR | De Giorgi, 2005^114^
5 year rate | 36 (10-59) [12] | 49 (24-68) [20] | NR | CIBMTR, 2010^471^
5 year rate | 63 (43-92) [17] | NA | NR | Einhorn, 2007^470^
5 year rate | NA | 49 (25-72) [4] | NR | De Giorgi, 2005^114^
OS range for 5 years for studies with > 10 patients | 36-63 | 49 | NA

CI = confidence interval; N = number of patients; NA = not applicable; NR = not reported

##### Event-free Survival

Information on event-free survival can be found in Appendix D.

##### Adverse Effects

None of the studies evaluated quality of life (Table 70). Data on treatment-related mortality was available from three studies (Table 72).114, 120, 471 There was no reported cases of treatment-related mortality in the two single HSCT series (N=22). For the CIBMTR cohort, cumulative incidence of treatment-related mortality was 10 percent (2-27 percent) at 5 years for the single HSCT group (n=20); none of the 12 patients in the tandem group had treatment-related mortality (Table 72). Relapse/progression incidence, on the other hand, was 64 percent (30–85 percent) for the tandem group up to five years after transplant compared to 41 percent (20–62 percent) for the single HSCT group.471 Other adverse events were reported in only two single HSCT studies. There were no secondary malignancies (Table 72). Veno-occlusive disease occurred in two (of 18) patients in the EBMT cohort by De Giorgi et al.114

Table 72 Adverse effects for tandem HSCT and comparison (single HSCT) groups: Germ cell tumor

Outcome | Intervention Tandem (%) | Comparator Single (%) | Study
Treatment related mortality | Not applicable | 0^a^ | De Giorgi, 2005 (77240); Agarwal, 2007 (72940)
Treatment related mortality | 0 | 10 | CIBMTR, 2010
Secondary malignancies | Not applicable | 0^b^ | De Giorgi, 2005 (77240); Agarwal, 2007 (72940)
Veno-occlusive disease | Not applicable | 11 | De Giorgi, 2005 (77240)
Veno-occlusive disease | Not applicable | 0 | Agarwal, 2007 (72940)

a No cases of treatment-related mortality reported in both studies.

b No cases of secondary malignancies reported in both studies.

#### Ongoing Research

Two U.S. nonrandomized studies are underway on tandem transplants. The first is a two-center (M.D. Anderson Cancer Center; Fred Hutchinson Cancer Research Center) Phase II study being undertaken to evaluate if bevacizumab, when given in combination with two cycles of HDC, can help to control GCTs in patients aged 12 to 65 years. The study is currently recruiting patients with an estimated enrollment of 25 participants. The primary outcome of interest is 2-year EFS. The estimated final data collection date for this trial is June 2014. (NCT00936936).

The second study (Phase I/II) is being undertaken at the Children's Memorial Hospital in Chicago to assess the feasibility and toxicity of tandem rescue with peripheral blood cells following HDC as consolidation in pediatric patients with high risk solid tumors, including relapsed GCT. The study is currently recruiting patients with an estimated enrollment of 12 participants. The estimated final data collection date is September 2012 (NCT00179816).

#### Conclusion

The body of evidence on overall survival with tandem HSCT compared to single HSCT for the treatment of relapsed pediatric germ cell tumors was insufficient to draw conclusions.

### Central Nervous System/Embryonal Tumors Systematic Review

#### Background and Setting

Classification of brain tumors is based on both histopathologic characteristics of the tumor and location in the brain.122 Central nervous system (CNS) embryonal tumors are the most common malignant brain tumor in childhood. Embryonal tumors of the CNS primarily include medulloblastoma (MB), supratentorial primitive neuroectodermal tumor (PNET), and atypical teratoid/rhabdoid tumor (AT/RT).122 MBs account for 20 percent of all childhood CNS tumors.123, 124 The other types of embryonal tumors are rare by comparison.122

PNETs are a heterogeneous group of highly malignant neoplasms comprising 3 to 5 percent of all childhood brain tumors, most commonly located in the cerebral cortex and pineal region.123, 125 AT/RT, on the other hand, comprise approximately 2-3 percent of these tumors with a peak incidence in children less than three years of age, and is associated with characteristic genetic abnormalities.123, 125, 126 The prognosis for these tumors is worse than for MB, despite identical therapies.122, 123, 125

Recurrence of all forms of CNS embryonal tumors is not uncommon, usually occurring within 18 months of treatment; however, recurrent tumors may develop many years after initial treatment.122 The treatment of these tumors continues to evolve especially in children less than three years of age because of the concern of the deleterious effects of craniospinal radiation on the immature nervous system. Therapeutic approaches have attempted to delay and sometimes avoid the use of radiation, and have included trials investigating different chemotherapy regimens to improve outcome.122 Many centers have used HDC with HSCT to improve further the outcome for children with CNS embryonal tumors.

#### Evidence Summary

The overall grade of strength of evidence for overall survival with tandem HSCT compared to single HSCT for the treatment of CNS embryonal tumors is shown in Table 73.

Table 73 Overall grade of strength of evidence for overall survival: CNS embryonal tumors

Key Question | Study Design | Risk of bias | Consistency | Directness | Precision | Strength of Association | Overall Grade/ Conclusion
For pediatric patients with CNS embryonal tumors, what is the comparative effectiveness and harms of tandem HSCT and single HSCT regarding overall survival? Outcome of interest is overall survival. The comparator is single HSCT. | There are three observational studies on tandem HSCT. There are seven observational studies on single HSCT. | The risk of bias in this evidence is high. There are differences in conditioning regimens and source of stem cell support across studies. | Results for overall survival are of unknown consistency. Studies consist of multiple tumor types. There is variability in prognostic features between studies. | The outcomes reported are direct. The comparisons are indirect as the evidence base utilizes two or more bodies of evidence to make comparisons. | The evidence is imprecise, effects are uncertain. There is uncertainty on whether tandem HSCT is inferior, equivalent or superior to single HSCT. | Not applicable due to lack of obvious effect size. | The body of evidence on tandem HSCT compared to single HSCT for the treatment of CNS embryonal tumors was insufficient to draw conclusions.
For pediatric patients with CNS embryonal tumors, what is the comparative effectiveness and harms of single HSCT and conventional therapy regarding overall survival? Outcome of interest is overall survival. The comparator is conventional therapy. | There are five observational studies on single HSCT. There are two RCTs and one observational study on conventional therapy. | The risk of bias in this evidence is high. One RCT was performed earlier in the mid-90s; There are differences in treatment regimens and supportive care across studies. | Results are of unknown consistency. Studies consist of multiple tumor types. There is variability in prognostic features between studies. | The outcomes reported are direct. The comparisons are indirect as the evidence base utilizes two or more bodies of evidence to make comparisons. | The evidence is imprecise, effects are uncertain. There is uncertainty on whether single HSCT is inferior, equivalent or superior to conventional chemotherapy. | Not applicable due to lack of obvious effect size. | The body of evidence on single HSCT compared to conventional therapy for the treatment of CNS embryonal tumors was insufficient to draw conclusions.

The evidence compiled for this review includes ten observational studies133, 472-480 and two randomized clinical trials (RCT).481, 482 Nine studies reported outcomes for HSCT,133, 473-477, 481 479, 480 and three studies (including two RCTs) were multi-institutional treatment protocols on CNS embryonal tumors.478, 481, 482 For HSCT studies, 15 patients received tandem transplant, whereas 132 patients received single HSCT.

Based on the currently available evidence, it is not possible to clarify the role of HSCT (single or tandem procedure), as studies are limited individually by low numbers of patients enrolled and collectively by inconsistencies in the patients' ages. The prognosis and treatment varies depending upon the age of the patient and type of embryonal tumor. Most studies to date have focused on children with newly diagnosed medulloblastoma. Comparison between studies, moreover, remains challenging, given the heterogeneity of these tumors and the varied therapies used across centers.

#### Results

Twelve reports were included in this review. Table 74 shows the criteria that were used to select studies for this section. For HSCT studies, 15 patients received tandem transplant (MB, n=13; PNET, n=1; AT/RT, n=1), whereas 132 patients received single HSCT (MB, n=61; PNET, n=52; AT/RT, n=19).

Table 74 Study selection criteria: CNS embryonal tumors

Study Design | Population | Intervention | Comparators | Outcomes | Time | Setting
Controlled trial, cohort, case-series | Pediatric patients (0-21-yr) with newly diagnosed disease | Tandem (Auto Auto) HSCT | Single (Auto) HSCT | OS; EFS (DFS; PFS); long-term adverse events; QOL | All durations of followup | In-patient and/or out-patient
Controlled trial, cohort, case-series | Pediatric patients (0-21-yr) with newly diagnosed disease | Single (Auto) HSCT | Conventional therapy | OS; EFS (DFS; PFS); long-term adverse events; QOL | All durations of followup | In-patient and/or out-patient

Auto = autologous; DFS = disease-free survival; EFS = event-free survival; HSCT = hematopoietic stem-cell transplant; OS = overall survival; PFS = progression-free survival; QOL = quality of life

Table 75 shows the study design and population. Ten publications were observational studies133, 472-480 and two were randomized clinical trials (RCTs).481, 482 Nine studies reported outcomes for HSCT, and three studies (including two RCTs) were multi-institutional treatment protocols on CNS embryonal tumors.478, 481, 482 Of the nine HSCT studies, tandem transplants were performed in three studies, one of which reported comparative data of tandem vs. single HSCT.133 Sixty percent of these patients were considered as average-risk (i.e., Chang stage M0 having no metastasis), and 40 percent as high-risk (i.e., Chang stage M1-M4 having metastasis).

Table 75 Study characteristics and population: CNS embryonal tumors

Study | Design | Median Age in Months (Range) | Sex (M%) | Histology [Tumor Type] (%) | Tandem HSCT | Single HSCT | CC | Rx Period
Sung, 2007^466^ | Case series | 31 (17-198) | 50 | M0 (64); M1 (7); M3 (29) [MB (79); PNET (21)] | 11 | 3 | NA | 1999-2005
Gidwani, 2008^472^ | Case report | 4 | 100 | M0 [AT/RT (100)] | 1 | NA | NA | NR
Fangusaro, 2008^473^ | Case series | 37 (0-120) | 51 | M0 (82); M1-M3 (18) [PNET (100)] | NA | 43 | NA | 1991-2002
Dhall, 2008^474^ | Case series | 21 (5-35) | 50 | M0 (100) [MB (100)] | NA | 21 | NA | 1991-2002
Chi, 2004^475^ | Case series | 38 (7-119) | 76 | M1 (19); M2 (9.5); M3 (71) [MB (100)] | NA | 21 | NA | 1997-2003
Gardner, 2008^476^ | Case series | 35 (4-52) | 54 | M0 (77); M1 (8); M3 (15) [AT/RT (100)] | NA | 13 | NA | 1992-2002
Perez-Martinez, 2005^477^ | Case series | 3 (1-14) years | 61.5 | M1-M4 (NR) [MB (69); PNET (31)] | NA | 13 | NA | 1995-2002
Packer, 2006^482^ | RCT | (36-228) | 59 | M0 (100) [MB (100)] | NA | NA | 379 | 1996-2000
Geyer, 2005^481^ | RCT | (0-36) | 53 | M0 (68); M1+ (32) [MB (44); PNET (22); AT/RT (13) Other (21)] | NA | 210 | 284 | 1993-1997
Taylor, 2005^478^ | Case series | 94 (34-197) | 29 | M2 (19); M3 (81) [MB (100)] | NA | NA | 68 | 1992-2000
Bandopadhayay, 2011 479 | case series | 20.5 (3-37) | 61 | M0 (91); M1 (6); M3 (3) [MB (50); AT/RT (33); PNET (17)] | NA | 18 | NA | 1999-2005
Aihara, 2010^480^ | case report | 144 (84-156) | 100 | M3 (100) [MB (100)] | 3 | NA | NA | NR

AT/RT = atypical teratoid/rhabdoid tumor; CC = conventional care; HSCT = hematopoietic stem-cell transplant; M0 = no evidence of metastasis; M1 = tumor cells found in cerebrospinal fluid (by lumbar puncture and cytology study); M2 = tumor beyond primary site but still in brain; M3 = tumor deposits (“seeds”) in spine area that are easily seen on MRI; M4 = tumor spread to areas outside the CNS (outside both brain and spine); M = male; MB = medulloblastoma; NR = not reported; PNET = supratentorial primitive neuroectodermal tumor; RCT = randomized controlled trial

All patients across the nine transplant studies received HSCT as consolidation of primary treatments. All studies used different induction regimens (i.e., different chemotherapeutic agents and different (cumulative) dosages). The induction regimen across studies primarily consisted of five cycles of chemotherapy followed by consolidation phase. Various conditioning regimens were used across studies. The conditioning regimen primarily consisted of carboplatin, thiotepa, etoposide, busulfan and/or melphalan. Approximately 30 percent of patients (29-37 percent) also received radiation therapy across these studies. Peripheral blood stem cells were used as the sole source of support in five studies (two on single HSCT and three on tandem HSCT); combination of peripheral blood and bone marrow was used across the remaining four studies.

Data on conventional care were based on results from three multi-institutional treatment protocols on CNS embryonal tumors (one on multiple tumor types which consisted of MB, PNET and AT/RT; and two on MB).478, 481, 482 The study by Geyer et al.481 was a RCT from the U.S. Children's Cancer Group (COG) of two multi-agent chemotherapy regimens (with deferred radiotherapy) for children younger than 3 years of age with various malignant brain tumors in a large cohort of patients. Maintenance therapy for all patients in the COG protocol comprised of eight cycles of vincristine, carboplatin and cyclophosphamide; over 40 percent of patients received radiotherapy.481 Two studies reported on outcomes for MB patients; the RCT by Packer et al.482 reported on outcomes with radiotherapy and adjuvant chemotherapy for children three years and older with nonmetastatic disease, and the European multicenter study by Taylor et al.478 reported on outcomes for ages three years and older with metastasis.

Table 76 shows the outcomes that were reported across the 12 studies.

Table 76 Outcomes reported: CNS embryonal tumors

Study | OS | EFS (DFS, PFS) | QOL | Treatment-related Mortality | Second Malignancies | Other Adverse Effects
Sung, 2007^466^ | ✓ | ✓ | NR | ✓ | NR | ✓
Gidwani, 2008^472^ | ✓ | ✓ | NR | NR | ✓ | ✓
Fangusaro, 2008^473^ | ✓ | ✓ | NR | ✓ | ✓ | ✓
Dhall, 2008^474^ | ✓ | ✓ | ✓ | ✓ | NR | ✓
Chi, 2004^475^ | ✓ | ✓ | NR | ✓ | NR | NR
Gardner, 2008^476^ | ✓ | ✓ | NR | ✓ | NR | ✓
Perez-Martinez, 2005^477^ | NR | ✓ | NR | ✓ | ✓ | ✓
Packer, 2006^482^ | ✓ | ✓ | NR | ✓ | ✓ | ✓
Geyer, 2005^481^ | ✓ | ✓ | NR | ✓ | ✓ | ✓
Taylor, 2005^478^ | ✓ | ✓ | NR | ✓ | NR | ✓
Bandopadhayay, 2011 479 | ✓ | NR | NR | ✓ | NR | ✓
Aihara, 2010^480^ | NR | ✓ | NR | ✓ | NR | ✓

DFS = disease-free survival; EFS = event-free survival; NR = not reported; PFS = progression-free survival; QOL = quality of life

##### Overall Survival

Data on OS were reported in ten (of 12) studies (Table 76). For comparisons between tandem vs. single HSCT, data were available to compute 2-year rates for two studies, 3-year rates for two studies, and 5-year rates for four studies (Table 77). For Sung et al.466 (n=14), 2-year survival probability was 82 percent (95 percent confidence interval (CI), 59-100 percent) in the tandem group (MB, n=10; PNET, n=1) compared to 67 percent (13-100 percent) in the single HSCT group (MB, n=1; PNET, n=2). The AT/RT patient reported in Gidwani et al.472 has remained disease free for two years following tandem HSCT. OS was defined across studies as the interval between diagnosis to death or last followup.

Table 77 Overall survival for tandem HSCT and comparison (single HSCT) groups: CNS embryonal tumors

Outcome | Tumor type | Intervention Tandem (%; ± 95% CI; SE) [N] | Comparator Single (%; ± 95% CI; SE) [N] | p Value | Study
2-year | MB-PNET | 82 (59-100) [11] | 67 (13-100) [3] | NR | Sung, 2007^466^
2-year | AT/RT | [One patient alive without disease] | Not applicable | NR | Gidwani, 2008^472^
2-year | MB AT/RT | Not applicable | 50 [4.5] 20 [1.2]^*^ | NR | Bandopadhayay, 2011^479^
3-year | MB | Not applicable | 60 (36-84) [21] | NR | Chi, 2004^475^
3-year | AT/RT | Not applicable | 23 (11) [13] | NR | Gardner, 2008^476^
5-year | MB-PNET | 82 (59-100) [11] | NA | NR | Sung, 2007^466^
5-year | PNET | Not applicable | 49 (33-62) [43] | NR | Fangusaro, 2008^473^
5-year | MB | Not applicable | 70 (10) [21] | NR | Dhall, 2008^474^
5-year | MB | 50 [4.5] | Not applicable | <.01 | Bandopadhayay, 2011^479^
OS range for 5 years for studies with >10 patients | All | 82 | 49-70 | Not applicable | Not applicable

AT/RT = atypical teratoid/rhabdoid tumor; CI = confidence interval; MB = medulloblastoma; N = number of patients; NA = not available; PNET = supratentorial primitive neuro-ectodermal tumors; SE = standard error

* 18-month OS.

For the conventional-care group of studies, data were available to compute 3-year rates for one study,478 and 5-year rates for three studies (Table 78).478, 481, 482 There were no comparative studies between single HSCT vs. conventional care. For Geyer et al.481 on multiple tumor types, five-year survival probability overall was 43 percent (3 percent) for children under three years of age; for MB, PNET and AT/RT, the corresponding rates were 43 percent (5 percent), 31 percent (7 percent), and 29 percent (9 percent), respectively. Similar rates were observed for MB patients with metastatic disease in the multicenter study by Taylor et al.478 Packer et al.482 reported higher survival rates in their cohort of MB patients without metastasis.

Table 78 Overall survival for single HSCT and comparison (conventional care) groups: CNS embryonal tumors

Outcome | Tumor type | Intervention Single (%; ± 95% CI; SE) [N] | Comparator CC (%; ± 95% CI; SE) [N] | p Value | Study
3-year | MB | 60 (36-84) [21] | Not applicable | NR | Chi, 2004^475^
3-year | AT/RT | 23 (11) [13] | Not applicable | NR | Gardner, 2008^476^
3-year | MB | Not applicable | 50 (38-62) [68] | NR | Taylor, 2005^478^
5-year | PNET | 49 (33-62) [43] | Not applicable | NR | Fangusaro, 2008^473^
5-year | MB | 70 (10) [21] | Not applicable | NR | Dhall, 2008^474^
5-year | MB | Not applicable | 86 (1.9) [379] | NR | Packer, 2006^482^
5-year | MB-PNET-AT/RT-Other | Not applicable | 43 (3) [284] all pts 43 (5) [92] MB 31 (7) [46] PNET 29 (9) [28] Rhabdoid | NR | Geyer, 2005^481^
5-year | MB | Not applicable | 44 (32-56) [68] | NR | Taylor, 2005^478^
OS range for 5 years for studies with > 10 patients | All | 49-70 | 43-86 | Not applicable | Not applicable

AT/RT = atypical teratoid/rhabdoid tumor; CC = conventional care; CI = confidence interval; MB = medulloblastoma; N = number of patients; NA = not available; PNET = supratentorial primitive neuro-ectodermal tumors; SE = standard error

##### Adverse Effects

Only one HSCT study on MB patients evaluated quality of life (Table 76).474 Dhall et al.474 reported that mean intellectual functioning and QOL for children less than three years of age surviving without radiotherapy (n=4 [of 21]) was within the average range at both followup periods of testing (using the Parent Form of the Child Health Questionnaire [which is a 50-item QOL measure]). Data on treatment-related mortality were reported in 11 studies (Table 79).133, 474-479, 481-483 There was one (of 15) case (7 percent) in the tandem group, nine (of 132) cases (8 percent) in the single HSCT group, and 71 (of 663) cases (11 percent) in the conventional care group.

Table 79 Adverse effects for treatment (tandem HSCT) and comparison (single HSCT) groups: CNS embryonal tumors

Outcome | Tumor Type | Intervention Tandem (%) | Comparator Single (%) | Study
Treatment-Related Mortality | MB-PNET | 18 | 33 | Sung, 2007^466^
Treatment-Related Mortality | AT/RT | 0^a^ | NA | Gidwani, 2008^472^
Treatment-Related Mortality | PNET | NA | 5 | Fangusaro, 2008^473^
Treatment-Related Mortality | MB | NA | 0 | Chi, 2004^475^
Treatment-Related Mortality | MB | NA | 19 | Dhall, 2008^474^
Treatment-Related Mortality | AT/RT | NA | 0 | Gardner, 2008^476^
Treatment-Related Mortality | MB-PNET | NA | 15 | Perez-Martinez, 2005^477^
Treatment-Related Mortality | AT/RT | 0^a^ | NA | Gidwani, 2008^472^
Treatment-Related Mortality | PNET | NA | 2 | Fangusaro, 2008^473^
Treatment-Related Mortality | MB-PNET-AT/RT | 3 | NA | Bandopadhayay, 2011 479
Secondary Malignancies | AT/RT | NA | 8 | Gardner, 2008^476^
Secondary Malignancies | MB-PNET | NA | 8 | Perez-Martinez, 2005^477^
Secondary Malignancies | MB-PNET | 9 | 0 | Sung, 2007^466^
Secondary Malignancies | AT/RT | 0 | NA | Gidwani, 2008^472^
Infectious Complications | PNET | NA | 5 | Fangusaro, 2008^473^
Infectious Complications | MB | NA | 9.5 | Dhall, 2008^474^
Infectious Complications | AT/RT | NA | 8 | Gardner, 2008^476^
Infectious Complications | MB-PNET | NA | 38 | Perez-Martinez, 2005^477^
Infectious Complications | AT/RT | NA | 8 | Gardner, 2008^476^
Infectious Complications | MB-PNET | NA | 15 | Perez-Martinez, 2005^477^
Infectious Complications | MB-PNET-AT/RT | 3 | NA | Bandopadhayay, 2011 479
Serious Hemorrhagic Events | MB-PNET | NA | 8 | Perez-Martinez, 2005^477^
Veno-Occlusive Disease | | Not reported | Not reported

AT/RT = atypical teratoid/rhabdoid tumor; MB = medulloblastoma; NA = not applicable; PNET = supratentorial primitive neuro-ectodermal tumors

a Case report.

Secondary malignancies were reported in three single HSCT studies476, 477, 483and three studies on conventional care (Table 79 and Table 80).478, 481, 482 Three (of 69) cases (4 percent) of secondary malignancies were reported in the single HSCT group, and 12 (663) cases (2 percent) in the conventional care group. Other adverse events across studies are reported in Table 79 and Table 80, respectively.

Table 80 Adverse effects for treatment (single HSCT) and comparison (conventional care) groups: CNS embryonal tumors

Outcome | Tumor Type | Intervention Single (%) | Comparator CC (%) | Study
Treatment-related Mortality | PNET | 5 | Not applicable | Fangusaro, 2008^473^
Treatment-related Mortality | MB | 0 | Not applicable | Chi, 2004^475^
Treatment-related Mortality | MB | 19 | Not applicable | Dhall, 2008^474^
Treatment-related Mortality | AT/RT | 0 | Not applicable | Gardner, 2008^476^
Treatment-related Mortality | MB-PNET | 15 | Not applicable | Perez-Martinez, 2005^477^
Treatment-related Mortality | MB | Not applicable | 14 | Packer, 2006^482^
Treatment-related Mortality | MB-PNET-AT/RT-Other | Not applicable | 6 | Geyer, 2005^481^
Treatment-related Mortality | MB | 0^a^ | Not applicable | Aihara, 2010^480^
Secondary Malignancies | PNET | 2 | Not applicable | Fangusaro, 2008^473^
Secondary Malignancies | AT/RT | 8 | Not applicable | Gardner, 2008^476^
Secondary Malignancies | MB-PNET | 8 | Not applicable | Perez-Martinez, 2005^477^
Secondary Malignancies | MB | Not applicable | 2 | Packer, 2006^482^
Secondary Malignancies | MB | Not applicable | 1 | Taylor, 2005^478^
Secondary Malignancies | MB-PNET-AT/RT-Other | Not applicable | 2 | Geyer, 2005^481^
Infectious Complications | PNET | 5 | Not applicable | Fangusaro, 2008^473^
Infectious Complications | MB | 9.5 | Not applicable | Dhall, 2008^474^
Infectious Complications | AT/RT | 8 | Not applicable | Gardner, 2008^476^
Infectious Complications | MB-PNET | 38 | Not applicable | Perez-Martinez, 2005^477^
Infectious Complications | MB | Not applicable | 24 | Packer, 2006^482^
Infectious Complications | MB-PNET-AT/RT-Other | Not applicable | 21 | Geyer, 2005^481^
Serious Hemorrhagic Events | AT/RT | 8 | Not applicable | Gardner, 2008^476^
Serious Hemorrhagic Events | MB-PNET | 15 | Not applicable | Perez-Martinez, 2005^477^
Serious Hemorrhagic Events | MB-PNET-AT/RT-Other | Not applicable | 4 | Geyer, 2005^481^
Veno-occlusive Disease | MB-PNET | 8 | Not applicable | Perez-Martinez, 2005^477^
Veno-occlusive Disease | MB | Not applicable | 1 | Taylor, 2005^478^
Veno-occlusive Disease | MB-PNET-AT/RT-Other | Not applicable | 2 | Geyer, 2005^481^

AT/RT = atypical teratoid/rhabdoid tumor; CC = conventional care; MB = medulloblastoma; N = number of patients; PNET = supratentorial primitive neuroectodermal tumors

a Case report.

#### Ongoing Research

In North America, the Children's Hospital of Los Angeles is leading a Phase III trial (“Head Start III”) studying combination chemotherapy with or without etoposide followed by single HSCT in treating patients (10 years or younger) with newly diagnosed brain tumors including MB, PNET, and AT/RT. This is an international trial (U.S., Canada, Australia, New Zealand, Switzerland) being undertaken across 37 centers and is currently recruiting patients with an expected enrollment of 120 patients. The primary outcomes of interest include time to tumor progression, disease recurrence or death of any cause, EFS at 2 years and toxicity. The projected completion of accrual is December 2010 (NCT00392886).

The St. Jude Children's Research Hospital is leading a Phase III trial studying two different regimens of radiation therapy when given together with chemotherapy and HSCT (1 to 3 procedures) to see how this regimen works in treating patients (3 years to 21 years) with newly diagnosed MB, PNET, or AT/RT. This is an international trial (U.S., Canada, Australia) being undertaken across nine centers and is currently recruiting patients with an expected enrollment of 342 patients. The primary outcomes of interest include the relationship of protein expression in tumors and PFS up to seven years of followup. The projected completion of accrual is April 2011 (NCT00085202).

In addition to the above studies, there are two trials underway by the Children's Oncology Group (COG). The first trial is open for children aged 3 years or younger at diagnosis with newly diagnosed PNET or high-risk medulloblastoma (NCT00336024). The second trial is a Phase III study for patients under 21 years of age with AT/RT. Both studies are using multi-agent chemotherapy, radiation, and high-dose chemotherapy with hematopoietic stem-cell rescue (NCT00653068).”

#### Conclusion

The body of evidence on overall survival with tandem HSCT compared to single HSCT for the treatment of CNS embryonal tumors was insufficient to draw conclusions.

The body of evidence on overall survival with single HSCT compared to conventional therapy for the treatment of CNS embryonal tumors was insufficient to draw conclusions.

### Glial Tumor Systematic Review

#### Background and Setting

Glial tumors comprise a heterogeneous group of neoplasms that are the largest single group of primary brain tumors in children and adolescents and contribute significant morbidity and mortality.484 The World Health Organization (WHO) classifies glial tumors into four major categories: astrocytic, ependymal, oligodendroglial or mixed gliomas, and choroid plexus tumors. According to SEER data, pediatric age-adjusted incidence rate of primary CNS glial tumors per 100,000 persons was:

- Astrocytoma (excluding pilocytic), 0.411
- Glioblastoma, 0.138
- Ependymoma/anaplastic ependymoma, 0.226
- Choroid plexus tumor, 0.025
- Oligodendroglioma, 0.083
- The age-adjusted mortality rate of brain and other nervous system tumors was 0.65 per 100,000 persons.

Data on glial tumors are primarily from case series, save one comparative study with an historic cohort485 with patients who received high-dose chemotherapy and HSCT. Case reports were also available. Differences in patient selection, accrual of small numbers of patients with patient data not stratified by tumor type, and differences in conditioning regimens make differences in overall survival between HSCT and conventional chemotherapy difficult to interpret. Although randomized evidence for gross total resection is lacking, retrospective analysis reaffirms the value of surgical resection in prolonging survival.

A greater than 90 percent surgical resection of newly diagnosed malignant gliomas, both anaplastic astrocytoma and glioblastoma multiforme, in childhood and adolescence confers a statistically significant survival advantage when followed by local field irradiation and conventional chemotherapy, or autologous stem-cell rescue.485 Evidence was evaluated in five groups: anaplastic astrocytoma and glioblastoma multiforme (astrocytic tumors), choroid plexus tumor, ependymoma, and other glial tumor patients. Data for other glial tumors was presented but separate analysis by type was not possible. Patients were classified into newly diagnosed or recurrent/progressive disease due to a poorer overall survival for recurrent/progressive patients.

##### High-Grade Glioma: Anaplastic Astrocytoma (AA)/Glioblastoma Multiforme (GBM)

The prognosis for patients diagnosed with high-grade glioma is poor. The median survival is less than 1 year, the majority die within two years despite some exceptional survivors.486 Patients with grade II astrocytoma may survive for 5 or more years while patients with AA often die within 2 or 3 years and frequently show progression to GBM with survival times substantially less than 2 years.487

##### Choroid Plexus Carcinomas

Choroid plexus carcinomas are rare typically occurring among children under 12 years of age with the greatest prevalence among children less than 2 years of age. 488 Choroid plexus tumors account for 1-4 percent of all childhood brain tumors with 25 percent of these patients developing progressive disease. 488 The role of surgery is well established in these tumors. Total resection of the tumor is often limited by tumor vascularity, large tumor size, and the tumor's tendency to invade the brain.488 The added benefits of radiation and chemotherapy on overall survival after total resection are unclear.488

##### Ependymomas

Ependymomas are significantly more prevalent in infants and young children, than in adults, and account for 6-10 percent of brain tumors in children.489 Sixty percent of ependymal tumors in children are infratentorial with 40 percent supratentorial. With conventional therapy the estimated 5-year OS and PFS are 50-64 percent and 23-45 percent, respectively.490 Factors significant in the prognosis of patients are extent of tumor resection and age.490 Patients with gross total resection have higher survival rates compared to incompletely resected gliomas (67-80 percent and 22-47 percent 5-year OS, respectively), and younger children tend to have a worse prognosis (more aggressive biological behavior of the tumor, avoidance of irradiation, and unacceptable neurotoxicity).490

#### Evidence Summary

The overall grade of strength of evidence for overall survival with HSCT for the treatment of high-risk glial tumors is shown in Table 81. The evidence compiled for this review includes one comparative cohort study of HSCT versus conventional therapy, one noncomparative cohort study, four randomized clinical trials, three Phase II trials, and 30 case series. The total number of patients abstracted was 1012: 215 patients received HSCT and 797 received conventional therapy.

Table 81 Overall grade of strength of evidence for overall survival and the use of HSCT for the treatment of high-risk glial tumors

Key Question | Study Design | Risk of Bias | Consistency | Directness | Precision | Strength of Association | Overall Grade/Conclusion
For pediatric patients with high-risk, newly diagnosed anaplastic astrocytoma what is the comparative effectiveness and harms of HSCT and conventional chemotherapy regarding overall survival? Outcome of interest is overall survival. The comparator was conventional therapy. | Three studies examined overall survival for newly diagnosed anaplastic astrocytoma tumors. All studies were case-series and no studies were comparative between HSCT and conventional therapy. Survival data was available for 30 conventional therapy patients and 11 autologous transplant patients. Patients from Bertolone491 (N=76) were not included due to grouping of AA and GBM patients and presence in an analysis by Finlay485 *Patients from Massimo included two oligoastrocytoma patients and nine anaplastic astrocytoma patients. | The risk of bias in this evidence is high. Patient characteristics such as newly diagnosed astrocytoma or recurrent/progressive tumors provide some prognostic information. Data for HSCT patients is limited to only 11 patients. | Results for overall survival are not applicable. One study with N ≥10 is available for HSCT and two for conventional therapy. Studies use several different time points to calculate overall survival. In additional different patient characteristics prohibit direct comparison of patients for all studies. | The outcomes reported are direct. The comparisons are indirect as the evidence base utilizes two or more bodies of evidence to make comparisons. | The evidence is imprecise. | Not applicable due to lack of obvious effect size. | The body of evidence on overall survival with HSCT compared to conventional therapy for the treatment of high-risk newly diagnosed anaplastic astrocytoma was insufficient to draw conclusions.
For pediatric patients with high-risk recurrent or progressive anaplastic astrocytoma what is the comparative effectiveness and harms of HSCT and conventional chemotherapy regarding overall survival? Outcome of interest is overall survival. The comparator was conventional therapy. | Ten studies examined overall survival for recurrent anaplastic astrocytoma tumors. One study was comparative with a historical cohort. The remaining studies were case-series. Survival data was available for 71 conventional therapy patients and 17 autologous transplant patients. *Patients from Bertolone (N=76)491 were not included due to grouping of AA and GBM patients and presence in an analysis by Finlay485 *Patients from Gilheeney included 1 anaplastic astrocytoma patient, 1 oligoastrocytoma patient, and 2 GBM patients.492 | The risk of bias in this evidence is high. Patient characteristics such as newly diagnosed astrocytoma or recurrent/progressive tumors provide some prognostic information. Data for HSCT patients is limited to only 17 patients. | Results for overall survival are consistent One study with N ≥10 is available for HSCT and one for conventional therapy. Studies use several different time points to calculate overall survival. In additional different patient characteristics prohibit direct comparison of patients for all studies. | The outcome reported, overall survival, is direct. The comparisons are indirect as the evidence base utilizes two or more bodies of evidence to make comparisons. The best evidence was comparative, but the comparison was made with historical controls entered in a previous protocol. | The evidence is precise. While the evidence is qualitative it is likely that an important superiority exists for HSCT compared to conventional therapy for these patients. The results from Finlay et al. with a historic conventional therapy comparison group give 5-year overall survival estimates of 40% for HSCT patients and 0% for conventional therapy . This information is limited due to the HSCT group's small sample size (N=10). | The strength of association is strong. The results from Finlay et al. with a historic conventional therapy comparison group give 5-year overall survival estimates of 40% for HSCT patients and 0% for conventional therapy . This information is limited due to the HSCT group's small sample size (N=10). | Low strength evidence on overall survival suggests a benefit with single HSCT compared to conventional therapy for the treatment of high-risk recurrent or progressive anaplastic astrocytoma.
For pediatric patients with high-risk newly diagnosed glioblastoma multiforme what is the comparative effectiveness and harms of HSCT and conventional chemotherapy regarding overall survival? Outcome of interest is overall survival. The comparator was conventional therapy. | Five studies examined overall survival for newly diagnosed glioblastoma multiforme. All studies were case-series and no studies were comparative between HSCT and conventional therapy. Survival data was available for 40 conventional therapy patients and 27 autologous transplant patients. *Patients from Bertolone (N=76)491 were not included due to grouping of AA and GBM patients and presence in an analysis by Finlay.485 | The risk of bias in this evidence is high. Patient characteristics such as newly diagnosed astrocytoma or recurrent/progressive tumors provide some prognostic information. | Results for overall survival are not applicable. Two studies with N ≥10 are available for HSCT and one for conventional therapy. Studies use several different time points to calculate overall survival. In additional different patient characteristics prohibit direct comparison of patients for all studies. However, newly diagnosed glioblastoma multiforme survival outcomes seem to be similar for both HSCT and conventional therapy. | The outcomes reported are direct. The comparisons are indirect as the evidence base utilizes two or more bodies of evidence to make comparisons. | The evidence is imprecise. Survival estimates between groups overlap. | Not applicable due to lack of obvious effect size. | The body of evidence on overall survival with HSCT compared to conventional therapy for the treatment of high-risk newly diagnosed glioblastoma multiforme was insufficient to draw conclusions.
For pediatric patients with high-risk recurrent or progressive glioblastoma multiforme what is the comparative effectiveness and harms of HSCT and conventional chemotherapy regarding overall survival? Outcome of interest is overall survival. The comparator was conventional therapy. | Nine studies examined overall survival for recurrent/progressive glioblastoma multiforme. One study was comparative with a historical cohort. The remaining studies were case-series. Survival data was available for 35 conventional therapy patients and 22 autologous transplant patients. Patients from Bertolone (N=76)491 were not included due to grouping of AA and GBM patients and presence in an analysis by Finlay485 Patients from Gilheeney included 1 anaplastic astrocytoma patient, 1 oligoastrocytoma patient, and 2 GBM patients492 | The risk of bias in this evidence is high. Patient characteristics such as newly diagnosed glioblastoma multiforme or recurrent/progressive tumors provide some prognostic information. | Results for overall survival are consistent One study with N ≥10 is available for HSCT and one for conventional therapy. Studies use several different time points to calculate overall survival. In additional different patient characteristics prohibit direct comparison of patients for all studies. | The outcomes reported are direct. The comparisons are indirect as the evidence base utilizes two or more bodies of evidence to make comparisons. The best evidence was comparative, but the comparison was made with historical controls entered in a previous protocol. | The evidence is imprecise. | Not applicable due to lack of obvious effect size. | The body of evidence on overall survival with single HSCT compared to conventional therapy for the treatment of high-risk recurrent glioblastoma multiforme is insufficient to draw conclusions.
For pediatric patients with newly diagnosed anaplastic, nonanaplastic, mixed, or unspecified ependymoma, what is the comparative effectiveness and harms of HSCT and conventional chemotherapy regarding overall survival? Outcome of interest is overall survival. The comparator was conventional therapy (CT). | Eight studies examined overall survival for newly diagnosed nonanaplastic, mixed, or unspecified ependymoma which includes WHO grade II tumors and WHO grade III tumors. Survival data was reported for 329 patients with ependymal tumors who underwent CT and 29 autologous transplant patients. Four studies examined anaplastic ependymoma exclusively. Survival data were reported for 39 patients with anaplastic ependymal tumors who underwent CT and 1 autologous HSCT patient. All were case-series, and no studies were comparative between HSCT and CT. | The risk of bias in this evidence is high. Patient characteristics such as newly diagnosed astrocytoma or recurrent/progressive tumors provide some prognostic information. Studies often mixed anaplastic with non-anaplastic tumors which has been found to be a predictor of patient prognosis in some studies. (Jaing, 2004) | Results for overall survival not applicable. One study with nonanaplastic, mixed, or unspecified ependymoma ≥10 is available for HSCT and 5 for CT. Two CT studies were available for anaplastic ependymoma alone. Studies use different timepoints to calculate OS. Different patient characteristics prohibit direct comparison of patients for all studies. Survival data for newly diagnosed ependymoma treated with HSCT suggest an advantage for CT over HSCT. No comparison can be made for anaplastic disease. | The outcomes reported are direct. The comparisons are indirect as the evidence base utilizes two or more bodies of evidence to make comparisons. | The evidence is imprecise for newly diagnosed ependymoma and imprecise for anaplastic ependymoma patients. | Not applicable due to lack of obvious effect size. | The body of evidence on overall survival with single HSCT compared to conventional therapy for the treatment of newly diagnosed anaplastic, nonanaplastic, mixed, or unspecified ependymoma was insufficient to draw conclusions.
For pediatric patients with recurrent/progressive ependymoma, what is the comparative effectiveness and harms of HSCT and conventional chemotherapy regarding overall survival? Outcome of interest is overall survival. The comparator was conventional therapy. | Four studies examined overall survival for recurrent/progressive non-anaplastic, mixed, or unspecified ependymoma which includes WHO grade II tumors and WHO grade III tumors. Survival data was reported for 23 patients with ependymal tumors who underwent autologous transplant. All studies were case-series, and no studies were comparative between HSCT and conventional therapy. | The risk of bias in this evidence is high. Patient characteristics such as newly diagnosed astrocytoma or recurrent/progressive tumors provide some prognostic information. There were no recurrent ependymoma patients available for comparison in the conventional therapy group. Studies often mixed anaplastic with non-anaplastic tumors which has been found to be a predictor of patient prognosis in some studies. (Jaing, 2004) | Results for overall survival are not applicable. Studies use several different time points to calculate overall survival. In additional different patient characteristics prohibit direct comparison of patients for all studies. No comparison can be made for recurrent disease. | The outcomes reported are direct. The comparisons are indirect as the evidence base utilizes two or more bodies of evidence to make comparisons. | The evidence is imprecise. | Not applicable due to lack of obvious effect size. | The body of evidence on overall survival with single HSCT compared to conventional therapy for the treatment of recurrent ependymoma was insufficient to draw conclusions.
For pediatric patients with choroid plexus carcinoma, what is the comparative effectiveness and harms of HSCT and conventional chemotherapy regarding overall survival? Outcome of interest is overall survival. The comparator was conventional therapy. | Five studies examined overall survival for choroid plexus tumors. Survival data were reported for 4 patients with choroid plexus carcinoma tumors who underwent autologous transplant and 64 conventional therapy patients. | The risk of bias in this evidence is high. Data is available for only four patients with this tumor type who underwent HSCT in either case reports or a component of a case-series. | Results for overall survival are consistent. Autologous stem cell transplant demonstrated no improvement on overall survival for the four transplanted patients with deaths between 5 and 25 months, and HSCT studies reported 21.5-36% five-year OS. | The outcomes reported are direct. The comparisons are indirect as the evidence base utilizes two or more bodies of evidence to make comparisons. | The evidence is imprecise. Survival data for HSCT patients is available only from case reports and does not permit a precise measure of this outcome. | Not applicable due to lack of obvious effect size. | The body of evidence on overall survival with single HSCT compared to conventional therapy for the treatment of choroid plexus carcinoma was insufficient to draw conclusions.
For pediatric patients with other gliomas (oligodendroglioma , pontine glioma, high-grade glioma, brainstem glioma, ganglioma, malignant glioma and other glioma [unspecified]), what is the comparative effectiveness and harms of HSCT and conventional chemotherapy regarding overall survival? Outcome of interest is overall survival. The comparator was conventional therapy. | Fifteen studies examined overall survival for other glial tumors. Survival data were reported for 2 oligodendroglioma, 40 pontine glioma, 1 ganglioma, and 10 other glioma [unspecified] patients who underwent autologous transplant and 33 brain stem glioma, 19 high-grade glioma, and 28 other glioma [unspecified] conventional therapy patients. | The risk of bias in this evidence is high. Tumors in the other glioma category were poorly characterized by histology and do not allow for direct comparison. | Results for overall survival are not applicable. Consistency cannot be assessed for these diseases as the data is limited to either a few case reports (oligodendroglioma) , have no comparative treatment (pontine glioma, ganglioma, brain stem glioma) or are not given a specific histology (other glioma) | Where outcomes were reported, the evidence is indirect. The evidence base utilizes two or more bodies of evidence to make comparisons or there. | The evidence is imprecise. There is uncertainty on whether HSCT is inferior, equivalent or superior to conventional chemotherapy for these conditions. | Not applicable due to lack of obvious effect size. | The body of evidence on overall survival with HSCT compared to conventional therapy for the treatment of other gliomas was insufficient to draw conclusions.

#### Results

Thirty-eight publications comprising 40 studies were included in this review. The total number of patients abstracted from the 39 studies was 1,012: 215 patients received HSCT, whereas 797 patients received conventional chemotherapy. Study selection criteria are shown in Table 82.

Table 82 Study selection criteria: Glial tumors

Study Design | Population | Intervention | Comparators | Outcomes | Followup | Setting
Any study design | Pediatric patients (0-21-yr) with high-risk or relapsed/refractory disease | Single Auto HSCT Tandem Auto HSCT | Chemotherapy +/- RT Chemotherapy +/- RT | OS; EFS (DFS; PFS); long-term adverse events; QOL | All durations of followup | Inpatient for HSCT; In or outpatient for conventional chemotherapy

Auto = autologous; DFS = disease-free survival; EFS = event-free survival; HSCT = hematopoietic stem-cell transplant; OS = overall survival; PFS = progression-free survival; QOL = quality of life

Table 83 shows the study design and population. Of the included publications for HSCT, sixteen were case series,367, 488, 492-504 two were cohort studies,485, 490 and one was a Phase II trial. 505 One study, by Finlay et al.485, compared myeloablative chemotherapy with autologous stem-cell transplant to conventional therapy and used a group of historic controls from a trial by the children's cancer group (CCG-945). All studies were published after 1995 with treatment periods ranging from 1986-2005. Four studies were conducted in France488, 493, 494, 497, two in Italy495, 502, one in the U.K.504, and twelve in the U.S.132, 367, 485, 490, 496, 498-501, 503, 506A total of 215 patients were treated with autologous bone marrow transplantation; Two-hundred and two of these were given single autologous stem-cell transplants while 11 patients received tandem or sequential transplant.367, 504 Due to the small number of patients in each tumor histology (AA 4, GBM 6, BSG 2, EPD 2, CPC 1), and similar survival outcomes to single autologous transplant, these patients were not analyzed separately. Stem cell source varied by study. Six studies treated patients with peripheral blood stem cells,367, 488, 490, 500, 502, 503 ten studies treated patients with bone marrow transplant, 132, 485, 493-496, 499, 501, 504, 506and two studies used multiple sources.497, 498 Eight studies investigated patients with newly diagnosed high-risk disease488, 490, 494, 495, 498, 500, 503, 504 and the remaining studies contained patients who had recurrent or relapsed disease.492

Table 83 Study characteristics and population: Glial tumors

Study | Design | Median Age (mo.) | Range | Male (%) | Disease Stage/Category | Histology [Site]% | HSCT (N) | Comparator (N) | Treatment Period
Finlay, 2008^485^ | Cohort | 133.3 | 2.4-250 | 56 | NR | GBM 17 (63) AA 10 (37) | 27 | Not applicable | NR
Shih, 2008^132^ | Case-Series | 89 | 5-199 | NR | NR | EPD 1(20) AA 2(40) GBM 2(40) | 5 | Not applicable | 1989-2004
Zacharoulis, 2007^490^ | Cohort | 25 | 8-107 | 62 | 24 M0 (83) 1 M1 (3) 0 M2 4 M3 (14) | EPD: Posterior fossa 22(76) supratentorial 7 (24) | 29 | Not applicable | 1991-1997 (Head Start 1) 1997 - 2002 (Head Start 2)
Thorarinsdottir, 2007^503^ | Case-Series | ODG 27 months, Ganglioma 25 months, Anaplastic glioma 18 months , EPD 6 months | Anaplastic glioma: 9-29 | ODG 100 Ganglioma 100 Anaplastic glioma 67 EPD 0 | All WHO grade III | ODG right frontal 1 (16) Ganglioma temporal 1 (16) Anaplastic glioma 1 c-spine 1 (16) BSG 1 (16) EPD IV ventricle 1 (16) | 6 | Not applicable | 1998 - 2005
Massimino, 2005^502^ | Case-Series | 120 | 42-228 | 33 | NR, All high-grade | GBM 10 (48), AA 9(42) Anaplastic ODG 2 (10) spine 2 (10) Posterior fossa 2(10) Supratentorial 17(80) | 21 | Not applicable | 1996- 2003
Ozkaynak, 2004^367^ | Case-Series | 132 | 54-216 | 50 | 3 progressive (50) 3 recurrent (50) | AA 2 (33) GBM 1 (17) BSG 2 (33) EPD 1 (17) | 6 | Not applicable | 1995-2002
Bouffet, 1997^493^ | Case-Series | 84 | 34-204 | 42 | Diffuse pontine glial tumor | At least 2/3rd of tumor had to be in the pons | 24 | Not applicable | March 1990-?
Grovas, 1999^498^ | Case-Series | 144 | 60-216 | 63 | NR, patients with neuraxis dissemination excluded | GBM 11 | 11 | Not applicable | 1993-1995
Jakacki, 1999^500^ | Case-Series | 86 | 37-151 | 36 | High grade glial tumor or a diffuse pontine tumor | GBM 3 (27), AA 2(18) Pons 6 (55) | 11 | Not applicable | 1997 - 1998
Mason, 1998^506^ | PII trial | 22 | 5-144 | 53 | 9 low-grade EPD (60) 6 anaplastic (40) | posterior fossa 13 (87) supratentorial 2 (13) | 15 | Not applicable | 1986 - 1993
Dunkel, 1998^496^ | Case-Series | 95 | 42-179 | 70 | 10 High-grade glial malignancies | PON 10 | 10 | Not applicable | NR
Gururangan 1998^499^ | Case-series | AA 23mo CPC 19mo EPD 18mo GBM 24, 4, 11, and 58mo | 4-58 | AA 0 CPC 100 EPD 0 GBM 50 | All tumors were recurrent | EPD 1 GBM 4 AA 1 CPC 1 | 7 | Not applicable | 1989-1996
Berger, 1998^488^ | Case-Series | 27.5 | 22-33 | 0 | Newly diagnosed 1 metastatic 1 unknown progression | CPC 2 | 2 | Not applicable | 1984-1995
Busca, 1997^495^ | Case-Series | 132 (36-192) years for total group of 11 patients, | NR | 46 | 1 GBM patient was newly diagnosed 5 patients were relapsed. | AA 1 (16) EPD 2 (33) GBM 2(33) ODG 1 (16) | 6 | Not applicable | 1991 - 1996
Bouffet, 1999^494^ 493 | Case-Series | 72 | 36-168 | 60 | All high-grade glioma | parieto-occipital 1 (20) BSG 3 (60) thalamus 1 (20) | 5 | Not applicable | NR
Yule, 1997^504^ | Case-Series | 120 | 12-168 | NR | NR | anaplastic EPD 1(20%) CPC 1 (20) recurrent GBM 1(20) GBM 1 (20) suprasellar GBM 1(20) | 5 | Not applicable | 1993-1995
Grill, 1996^497^ | Case-Series | 36 | 6-180 | 50 | EPD, 2 patients had tumor cells in CSF 3 WHO low-grade tumors 13 WHO high-grade tumors | EPD: Supratentorial 6 (38) Infratentorial 10(62) | 16 | Not applicable | 1988 - 1994
Mahoney, 1996^501^ | Case-Series | AA 144 EPD 60 GBM 186 BSG 60 | AA: 96-192 EPD: 36-90 GBM:186 BSG: 60 | AA 100 EP 33 GBM 100 BSG 0 | | AA 2 (29) EPD 3(43) GBM 1 (14) BSG 1 (14) | 6 | Not applicable | 1990 - 1993
Gilheeney, 2010^492^ | Case-Series | AA 98 GBM 139 | AA 89-107 GBM 53-226 | NR | NR | NR | 4 | Not applicable | 1999 - 2002
Finlay, 2008^485^ | Cohort | 133.3 | 1.2-232 | 52 | NR | GBM 27 (48) AA 29(52) | Not applicable | 56 | 1985-1990
Grundy, 2010^513^ | Case-Series | BSG 30 CPC 10 High Grade Glioma 22 | BSG: 8.2-36 CPC: 4-34 HGG 4-37 | Glioma 69, CPC 93 | HGG: AA 7 1 Astroblastoma 2 Anaplastic ODGODG 5 Glioblastoma 3 unknown Diffuse pontine glioma: 1 diffuse AST 1 glioblastoma 1 unclassified 4 Inoperable | HGG 18(45) PON 7 (18) CPC 15(38) HGG metastatic 2 (11) HGG in posterior fossa 2 (11) HGG in supratentorial 17 (89) BSG metastatic 0 BSG 7 (100) CPC metastatic 4 (27) CPC posterior fossa 5(33) CPC supratentorial 10(77) | Not applicable | 40 | 1993 - 2003
Conter, 2009^508^ | Case-Series | 103 | 60-204 | 67 | EPD, 13 Grade II (57) 10 Grade III (43) | Supratentorial 4 (17) Infratentorial 20 (83) | Not applicable | 24 | 1996 - 2002
Wrede, 2009^522^ | RCT | 27.6 | 4-205 | 50 | Histologically confirmed CPC | CPC 29 Metastatic 5 (17) Lateral Ventricle 30 (88) Fourth Ventricle 4(12) | Not applicable | 34 | 2000-2008
Grundy 2007^512^ | Case-series | Median Non-metastatic 23.16 Metastatic 16.32 | Non-Metastatic: .6-38 Metastatic: 2.88-27 | 65 | All Newly Diagnosed 9 metastatic (10) | 89 EPD Metastatic 9 (10) Nonmetastatic 80 (90) | Not applicable | 89 | 1992 - 2003
De Sio, 2006^509^ | Case-Series | 101 | 50-235 | 64 | Recurrent/progressive histologically confirmed (except BSG) | EPD 2 (14) AA 3 (21) BSG 8 (57) GBM 1 (7) | Not applicable | 14 | 1998 - 2004
Korones, 2006^518^ | Case-Series | 108 | 60-252 | 77 | NR | Glioblastoma 5 (56) AA 2 (22) BSG 2(22) | Not applicable | 9 | 2002 - 2003
Macdonald, 2005^521^ | RCT | 144 | 36- 240 | 48 | All patients had histologic verification of high-grade AST | AA 30 (39) GBM variant 40 (53) 6 Other 6 (8) Supratentorial tumor 66 (86.8) Infratentorial tumor 10 (13.2) patients had metastatic disease 5 (7) | Not applicable | 76 | 1993-1998
Jaing, 2004^516^ | Case-Series | 79 | 8 - 216 | 58 | EPD, 22 Grade II (47) 24 Grade III (53) | Supratentorial 15 (35) Infratentorial27 (65) | Not applicable | 46 | 1985-2002
Bertolone, 2003^491^ | RCT | 48 | <12 - 192 | 58 | NR | AA 11 (61) EPD 3 (17) GBM 2 (11) Anaplastic mixed glioma 1 (6) anaplastic ganglioglioma 1 (6) | Not applicable | 18 | 1985 - 1990
Merchant, 2002^505^ | PII trial | 36 | 13.2-275 | 50 | Histologically confirmed EPD w/ no current radio or chemotherapy | differentiated EPD 35(70) anaplastic EPD 19(30) | Not applicable | 54 | June 1997 - ?
Grill, 2001^511^ | Case-Series | 27 | 5-62 | 55 | 56 of patients had a high grade tumor (82) 12 had a low-grade tumor (18) | EPD 73 (100) | Not applicable | 73 | 1990 - 1998
Hurwitz, 2001^515^ | Case-Series | 92.4 | 4-228 | 56 | Recurrent or progressive disease | AST 4 (9) EPD 13 (29) Malignant Glioma 13 (29) BSG 15(33) | Not applicable | 45 | 1993 - 1998
Horn, 1999^514^ | Case-Series | 52 | 8-240 | 60 | EPD, 61 M0 (85) 11 M1-M3 (15) | EPD: WHO II grade 2 51 (61) WHO II grade 3 31 (37) 1 missing Infratentorial 64 (77) Supratentorial 19 (23) | Not applicable | 83 | 1987-1991
Kobrinsky, 1999^517^ | Case-Series | NR | NR | 55 | NR | High grade AST 20 (48) BSG 22 (52) | Not applicable | 42 | 1988 - 1992
Doireau, 1999^510^ | Case-Series | 63 | 3-132 | NR | Relapsed or unresectable intramedullar gliomas | Anaplastic oligo-AST 1 (17) OligoAST 3 (50) AA 1 (17) AST otherwise not specified 1 (17) | Not applicable | 6 | 1992-1998
Robertson, 1998^489^ | RCT | 84 | 24-208 | 53 | 12 Anaplastic EPD (38) | posterior fossa EPD 21 (66) supratentorial EPD 11 (34) | Not applicable | 32 | 1986 - 1992
Kuhl, 1998^520^ | PII trial | NR | 36-192 | 66 | 19 anaplastic (90) 29% of patients had microscopic tumor cells in CSF | EPD 21 | Not applicable | 21 | 1987 - 1991
Berger, 1998^488^ | Case-Series | 57.5 | 4-111 | 55 | Newly diagnosed CPC | metastatic 3 (15) nonmetastatic 4 (20) unknown 13 (65) | Not applicable | 20 | 1984-1995
White, 1998^519^ | Case-Series | 20 | 3-47 | NR | No documented disseminated disease at diagnosis | EPD 14 | Not applicable | 14 | 1991 - 1995
Ayan, 1995^507^ | Case-Series | 150 | 60 - 180 | 75 | 4 Anaplastic (100) | frontal lobe EPD 1(25) parietal-temporal-occipital lobe EPD1 (25) Multiple parenchymal meningeal lesion EPD 1 (25) Temporoparietal lobe EPD 1 (25) CSF cytology positive 1 (25) | Not applicable | 4 | 1990 - 1991

BMT = bone marrow transplant; BSG = brainstem glioma; CPC = choroid plexus carcinoma; EPD = ependymoma; GBM = glioblastoma multiforme; GLI = glioma; HGG = high-grade glioma; M = male; NR = not reported; OAST = oligoAST; ODG = oligodendroglioma; PBSCT = peripheral blood stem cell transplant; PON = Pontine glioma; RCT = randomized clinical trial

Conventional therapy included 14 case series,132, 488, 507-519 one cohort study,485 two Phase II trials,505, 520 and four clinical trials.489, 491, 521, 522 Case reports were excluded as comparators. All studies were published after 1995 with treatment periods ranging from 1986-2005. Four studies were conducted in France488, 508, 510, 511, two in Germany520, 522, Italy509, Taiwan516, Turkey507, and the U.K.512, and ten in the U.S.485, 489, 491, 505, 513-515, 517, 518, 521 A total of 797 patients were treated with conventional chemotherapy; the vast majority of these patients were given chemotherapy alone (N=458; 57 percent) in 16 studies. Patients received combination radiotherapy in seven studies (N=213; 27 percent), and in four studies patients received radiotherapy alone (N=126; 16 percent). Twelve studies investigated newly diagnosed high-risk patients (60 percent) and the remaining studies contained patients who had recurrent or relapsed disease. Previous treatments included a mix of excision, chemotherapy, and radiotherapy.

All studies were specific to the pediatric age group, with age primarily reported as age at diagnosis or transplant; only one study520 lacked information about participant's median age. Three studies495, 499, 517 did not provide information on patient age. Median ages ranged from under one year of age to 18 years of age. Five studies reported no patient gender132, 492, 504, 510, 520, but among the remaining studies with five or more patients gender was distributed equally. Studies included patients of diverse histology:

Nineteen HSCT studies (N=215):

- Astrocytoma 31 (14.4 percent)
- Choroid plexus tumor 4 (1.9 percent)
- Ependymoma 70 (32.6 percent)
- High-grade glioma 2 (0.93 percent)
- Glioblastoma multiforme 56 (26.0 percent)
- Oligodendroglioma 4 (1.9 percent)
- Glioma [unspecified] 1 (0.47 percent)
- Pontine glioma [unspecified] 40 (18.6 percent)
- Ganglioma 1 (0.47 percent)

Twenty-one conventional treatment studies (N=797):

- Astroblastoma 1 (0.1 percent)
- Astrocytoma 109 (13.7 percent)
- Brainstem glioma 54 (6.8 percent)
- Choroid plexus tumor 69 (8.6 percent)
- Ependymoma 435 (54.6 percent)
- Ganglioma 1 (0.1 percent)
- Glioblastoma multiforme 80 (10 percent)
- Glioma [unspecified] 14 (1.8 percent)
- Oligodendroglioma 2 (0.3 percent)
- Other 9 (1.1 percent)
- Pontine glioma [unspecified] 0 (0 percent)

Induction regimens varied across and within studies (i.e., different chemotherapeutic agents and different (cumulative) dosages) and consisted of multiple cycles of chemotherapy and/or radiation and/or surgery. Conditioning regimens also varied. The most common regimens included thiotepa, etoposide, carboplatin, cyclophosphamide (with or without mesna), busulfan and carmustine (either alone or in combination with radiation therapy or additional drugs). Table 84 shows the pediatric outcomes that were reported across the 39 included studies.

Table 84 Outcomes reported: Glial tumors

Author, Year | OS | EFS (DFS, PFS) | Quality of Life | Treatment-Related Mortality | Secondary Malignancies | Other Adverse Effects
Finlay, 2008^485^ | ✓ | ✓ | NR | ✓ | NR | NR
Shih, 2008^132^ | ✓ | ✓ | NR | NR | NR | NR
Zacharoulis, 2007^490^ | ✓ | ✓ | NR | ✓ | NR | ✓
Thorarinsdottir, 2007^503^ | ✓ | ✓ | NR | NR | NR | ✓
Massimino, 2005^502^ | ✓ | ✓ | NR | NR | NR | NR
Ozkaynak, 2004^367^ | ✓ | NR | NR | NR | NR | NR
Bouffet, 1997^493^ | ✓ | ✓ | NR | ✓ | NR | ✓
Grovas, 1999^498^ | ✓ | ✓ | NR | NR | ✓ | ✓
Jakacki, 1999^500^ | ✓ | ✓ | NR | NR | NR | ✓
Mason, 1998^506^ | ✓ | ✓ | NR | ✓ | NR | NR
Dunkel, 1998^496^ | ✓ | NR | NR | NR | NR | NR
Gururangan, 1998^499^ | ✓ | ✓ | NR | ✓ | NR | NR
Berger, 1998^488^ | ✓ | NR | NR | NR | NR | NR
Busca, 1997^495^ | ✓ | ✓ | NR | NR | NR | NR
Bouffet, 1999^494^ | ✓ | NR | NR | NR | NR | NR
Yule, 1997^504^ | ✓ | NR | NR | NR | NR | NR
Grill, 1996^497^ | ✓ | ✓ | NR | ✓ | NR | NR
Mahoney, 1996^501^ | ✓ | ✓ | NR | ✓ | NR | ✓
Grundy, 2010^513^ | ✓ | ✓ | NR | NR | NR | NR
Conter, 2009^508^ | ✓ | ✓ | NR | NR | NR | NR
Wrede, 2009^522^ | ✓ | ✓ | NR | NR | NR | NR
Grundy 2007^512^ | ✓ | ✓ | NR | ✓ | NR | ✓
De Sio, 2006^509^ | ✓ | ✓ | NR | NR | NR | NR
Korones, 2006^518^ | NR | NR | NR | NR | NR | NR
Macdonald, 2005^521^ | ✓ | ✓ | NR | NR | NR | ✓
Jaing, 2004^516^ | ✓ | ✓ | NR | NR | NR | NR
Bertolone, 2003^491^ | ✓ | ✓ | NR | NR | NR | ✓
Merchant, 2002^505^ | NR | ✓ | NR | NR | NR | NR
Grill, 2001^511^ | ✓ | ✓ | NR | NR | NR | NR
Hurwitz, 2001^515^ | NR | ✓ | NR | NR | NR | NR
Horn, 1999^514^ | ✓ | ✓ | NR | NR | NR | NR
Kobrinsky, 1999^517^ | ✓ | NR | NR | NR | NR | NR
Doireau, 1999^510^ | ✓ | ✓ | NR | NR | NR | NR
Robertson, 1998^489^ | ✓ | ✓ | NR | NR | NR | NR
Kuhl, 1998^520^ | ✓ | ✓ | NR | NR | NR | NR
Berger, 1998^488^ | ✓ | NR | NR | NR | NR | NR
White, 1998^519^ | ✓ | NR | NR | NR | NR | NR
Ayan, 1995^507^ | ✓ | ✓ | NR | NR | NR | NR
Gilheeney, 2010^492^ | ✓ | NR | NR | ✓ | NR | NR

##### Overall Survival

Data on overall survival were reported in all but three studies,505, 515, 518 and calculated from the raw data from the additional studies (Table 84). Survival data are presented by five histologic categories (Table 85). Individual studies varied in their method for calculating overall survival.

Table 85 Overall survival for single auto HSCT and comparison (conventional chemotherapy +/- radiation) groups: Glial tumors

Indication | Outcome | Intervention Single (%; ± 95% CI) | Comparator Chemo (%; ± 95% CI) | P Value | Study
Astrocytoma | 1 year | ∼41 (N=10) | ∼26 (N=29) | Chemo vs. ABMR unstratified comparison of survival p=.0018 HR 1.9 (1.1-3.1) Chemo versus ABMR comparison stratified by histology: p=.010 Chemo/nonbulky versus ABMR/non-bulky unstratified exact comparison: p=0.017 [hazard ratio=9.1 (95% confidence interval 1.7–47.2) Minimal residual disease status (<3 cm tumor diameter) at time of myeloablative chemotherapy p=.003 | Finlay, 2008^485^
Astrocytoma | 1 year | Not applicable | 2 AA patients dead at median 7.1 mo (n=2) | Not reported | Shih, 2008^132^
Astrocytoma | 1 year | Not applicable | 3 AA dead at median 5mo (4-10mo) (n=3) | Not reported | De Sio, 2006^509^
Astrocytoma | 1 year | Not applicable | 1 patient DOD at 4 mo (50%), one patient alive with disease progression at 10+ months (n=2) | Not reported | Korones, 2006^518^
Astrocytoma | 1 year | Not applicable | ∼46 (n=30) | Not reported | Macdonald, 2005^521^
Astrocytoma | 1 year | Other Glioma ∼91 (Anaplastic astrocytoma (N=9) and anaplastic oligodendroglioma (N=2)) (N=11) | Not applicable | OS for glioblastoma multiforme compared to other histotypes (AA and ODG) were significantly worse p=.004 | Massimino, 2005^502^
Astrocytoma | 1 year | Not applicable | ∼83 GBM and AA Non-Infants (n=16) ∼52 GBM and AA Infants (n=6) | Not reported | Bertolone, 2003^491^
Astrocytoma | 1 year | Not applicable | 28±10% (n=35) | Not reported | Kobrinsky, 1999^517^
Astrocytoma | 1 year | 2 AA patients dead at 7 and 9 mo (N=2) | Not applicable | Not reported | Jakacki, 1999^500^
Astrocytoma | 3 Year | 40±14% (N=10) | 7±4% (N=29) | Chemo vs. ABMR unstratified comparison of survival p=.0018 HR 1.9 (1.1-3.1) Chemo versus ABMR comparison stratified by histology: p=.010 Chemo/nonbulky versus ABMR/non-bulky unstratified exact comparison: p=0.017 [hazard ratio=9.1 (95% confidence interval 1.7–47.2) Minimal residual disease status (<3 cm tumor diameter) at time of myeloablative chemotherapy p=.003 | Finlay, 2008^485^
Astrocytoma | 3 Year | Not applicable | ∼25 (N=30) | Not reported | Macdonald, 2005^521^
Astrocytoma | 3 Year | Other Glioma ∼73 (Anaplastic astrocytoma (N=9) and anaplastic oligodendroglioma (N=2)) (N=11) | Not applicable | OS for glioblastoma multiforme compared to other histotypes (AA and ODG) were significantly worse P=.004 | Massimino, 2005^502^
Astrocytoma | 3 Year | Not applicable | ∼57 GBM and AA Non-Infants (N=16) ∼25 GBM and AA Infants (N=6) | Not reported | Bertolone, 2003^491^
Astrocytoma | 3 Year | Not applicable | ∼5 (N=35) | Not reported | Kobrinsky, 1999^517^
Astrocytoma | 3 Year | Not applicable | 3 OA patients alive median 3 yr. | Not reported | Doireau, 1999^510^
Astrocytoma | 3 Year | 1 patient died at 15 mo (N=1) | Not applicable | Not reported | Busca, 1997^495^
Astrocytoma | 5 Year | 40±14% (N=10) | 0-4% (N=29) | Chemo vs. ABMR unstratified comparison of survival p=.0018 HR 1.9 (1.1-3.1) Chemo versus ABMR comparison stratified by histology: p=.010 Chemo/nonbulky vs. ABMR/non-bulky unstratified exact comparison: p=0.017 [hazard ratio=9.1 (95% confidence interval 1.7–47.2) Minimal residual disease status (<3 cm tumor diameter) at time of myeloablative chemotherapy P=.003 | Finlay, 2008^485^
Astrocytoma | 5 Year | Not applicable | 25±8% (N=30) | Not reported | Macdonald, 2005^521^
Astrocytoma | 5 Year | Other glioma ∼73 (Anaplastic astrocytoma (N=9) and AOA (N=2)) (N=11) | Not applicable | OS for GBM compared to other histotypes (AA and ODG) were worse p=.004 | Massimino, 2005^502^
Astrocytoma | 5 Year | 2 Anaplastic astrocytoma pts. alive with stable disease at follow up of 41 and 80 mo (N=2) | Not applicable | Not reported | Ozkaynak, 2004^367^
Astrocytoma | 5 Year | Not applicable | 36±13 GBM and AA Non-Infants (N=11) 25±15 GBM and AA Infants (N=6) | Not reported | Bertolone, 2003^491^
Astrocytoma | 5 Year | Not applicable | 0% (N=35) | Not reported | Kobrinsky, 1999^517^
Astrocytoma | 5 Year | Not applicable | 1 AA patient died (car accident) before last FU. 1 AOA patient alive at 5.5 year. 1 Astrocytoma patient with unspecified disease alive at 5.5 years (N=6) | Not reported | Doireau, 1999^510^
Astrocytoma | 5 Year | 2 AA patients died at 1 mo and 4 mo (N=2) | Not applicable | Not reported | Mahoney, 1996^501^
Astrocytoma | 5 Year | 50 (N=2) 1 AA patient alive with residual disease at 7.7 years 1 oligoastrocytoma patient DOT at 1 mo | Not applicable | Not reported | Gilheeney, 2010^492^
Glioblastoma multiforme | 1 Year | ∼43% (N=17) | ∼22% (N=27) | Chemo vs. ABMR unstratified comparison of survival p=.0018 HR 1.9 (1.1-3.1) Chemo versus ABMR comparison stratified by histology: p=.010 Chemo/nonbulky versus ABMR/non-bulky unstratified exact comparison: p=0.017 [hazard ratio=9.1 (95% confidence interval 1.7–47.2) Minimal residual disease status (<3 cm tumor diameter) at time of myeloablative chemotherapy p=.003 | Finlay, 2008^485^
Glioblastoma multiforme | 1 Year | Not applicable | 1 patient dead at 4 mo (N=2) | Not reported | Shih, 2008^132^
Glioblastoma multiforme | 1 Year | Not applicable | 1 patient AWD at 12 mo (N=1) | Not reported | De Sio, 2006^509^
Glioblastoma multiforme | 1 Year | Not applicable | 57% (n=7) | Not reported | Korones, 2006^518^
Glioblastoma multiforme | 1 Year | Not applicable | ∼45 (N=40) | Not reported | Macdonald, 2005^521^
Glioblastoma multiforme | 1 Year | ∼90% (N=10) | Not applicable | OS for GBM compared to other histotypes (AA and ODG) were worse p=.004 | Massimino, 2005^502^
Glioblastoma multiforme | 1 Year | 1 progressive patient DOD at 1 mo (N=1) | Not applicable | Not reported | Ozkaynak, 2004^367^
Glioblastoma multiforme | 1 Year | Not applicable | ∼83 GBM and AA Non-Infants (N=16) ∼52 GBM and AA Infants (N=6) | Not reported | Bertolone, 2003^491^
Glioblastoma multiforme | 1 Year | 73±13% (N=11) | Not applicable | Not reported | Grovas, 1999^498^
Glioblastoma multiforme | 1 Year | 1 patient DOD at 6 months, 1 patient had stable disease at last 12 mo FU, 1 patient died of treatment toxicity (N=3) | Not applicable | Not reported | Yule, 1997^504^
Glioblastoma multiforme | 1 Year | 1 patient dead of disease at 7 mo (N=1) | Not applicable | Not reported | Mahoney, 1996^501^
Glioblastoma multiforme | 1 Year | 2 GBM patients DOD at 6 mo and 10 mo (N=2) | Not applicable | Not reported | Gilheeney, 2010^492^
Glioblastoma multiforme | 3 Year | 12±6% (N=17) | 0% (N=27) | Chemo vs. ABMR unstratified comparison of survival p=.0018 HR 1.9 (1.1-3.1) Chemo versus ABMR comparison stratified by histology: p=.010 Chemo/nonbulky versus ABMR/non-bulky unstratified exact comparison: p=0.017 [hazard ratio=9.1 (95% confidence interval 1.7–47.2) Minimal residual disease status (<3 cm tumor diameter) at time of myeloablative chemotherapy p=.003 | Finlay, 2008^485^
Glioblastoma multiforme | 3 Year | Not applicable | ∼25%(N=40) | Not reported | Macdonald, 2005^521^
Glioblastoma multiforme | 3 Year | ∼30% (N=10) | Not applicable | OS for glioblastoma multiforme compared to other histotypes (AA and ODG) were significantly worse p=.004 | Massimino, 2005^502^
Glioblastoma multiforme | 3 Year | Not applicable | ∼57 GBM and AA Non-Infants (N=16) ∼25 GBM and AA Infants (N=6) | Not reported | Bertolone, 2003^491^
Glioblastoma multiforme | 3 Year | ∼35% (N=11) | Not applicable | Not reported | Grovas, 1999^498^
Glioblastoma multiforme | 3 Year | 3 pts DOD at median 15 mo (6 – 19 mo) (N=3) | Not applicable | Not reported | Jakacki, 1999^500^
Glioblastoma multiforme | 3 Year | 1 pt alive and progression free at final FU (N=1) | Not applicable | Not reported | Busca, 1997^495^
Glioblastoma multiforme | 5 Year | 12±6% (N=17) | 0% (N=27) | Chemo vs. ABMR unstratified comparison of survival p=.0018 HR 1.9 (1.1-3.1) Chemo versus ABMR comparison stratified by histology: p=.010 Chemo/nonbulky versus ABMR/non-bulky unstratified exact comparison: p=0.017 [hazard ratio=9.1 (95% confidence interval 1.7–47.2) Minimal residual disease status (<3 cm tumor diameter) at time of myeloablative chemotherapy p=.003 | Finlay, 2008^485^
Glioblastoma multiforme | 5 Year | Not applicable | 1 patients dead at 104 mo (N=2) | Not reported | Shih, 2008^132^
Glioblastoma multiforme | 5 Year | Not applicable | 22±7 (N=40) | Not reported | Macdonald, 2005^521^
Glioblastoma multiforme | 5 Year | 0% (N=10) | Not applicable | OS for glioblastoma multiforme compared to other histotypes (AA and ODG) were significantly worse p=.004 | Massimino, 2005^502^
Glioblastoma multiforme | 5 Year | Not applicable | 36±13 GBM and AA Non-Infants (N=16) 25±15 GBM and AA Infants (N=6) | Not reported | Bertolone, 2003^491^
Glioblastoma multiforme | 5 Year | ∼25 (N=11) | Not applicable | Not reported | Grovas, 1999^498^
Anaplastic ependymoma | 1 Year | Not applicable | 100% (N=12) | Not reported | Robertson, 1998^489^
Anaplastic ependymoma | 1 Year | 1 anaplastic ependymoma patient with tandem autologous treatment DOD at 15 mo (N=1) | Not applicable | Not reported | Yule, 1997^504^
Anaplastic ependymoma | 3 Year | Not applicable | 82% (59-100%) (N=12) | Not reported | Robertson, 1998^489^
Anaplastic ependymoma | 3 Year | Not applicable | Median 33 months (16-35mo) (N=4) | Not reported | Ayan, 1995^507^
Anaplastic ependymoma | 5 Year | Not applicable | 35.2±11.0% (N=23) | Not reported | Jaing, 2004^516^
Anaplastic ependymoma | 5 Year | Not applicable | 64% (25-84%) (N=12) | Not reported | Robertson, 1998^489^
Non-anaplastic, mixed, or unspecified ependymoma | 1 Year | Not applicable | 3 patients dead at 1.4, 2.4, and 3.6 mo (N=3) | Not reported | Shih, 2008^132^
Non-anaplastic, mixed, or unspecified ependymoma | 1 Year | Not applicable | Metastatic ∼89% (N=9) Non-Metastatic ∼95% (N=80) | Age< 1 year, p=.18 Female sex, p=.18 Infratentorial, p=.12 WHO gr. III, p=.15 Partial resection (judged by neurosurgeon) p=.07 Partial resection (radiologic review) p=.28 Dose intensity <.8, p=.05 HR=1.6 (1.0-2.7) | Grundy, 2007^512^
Non-anaplastic, mixed, or unspecified ependymoma | 1 Year | ∼80% (N=29) | Not applicable | GTR vs. <GTR not significant | Zacharoulis, 2007^490^
Non-anaplastic, mixed, or unspecified ependymoma | 1 Year | Not applicable | DOD at 2 and 6 mo (N=2) | Not reported | De Sio, 2006^509^
Non-anaplastic, mixed, or unspecified ependymoma | 1 Year | Not applicable | ∼96% (N=73) | PF tumor RR 7.9 (1.8 to 35) p=.0004 Postoperative radiologic documented residuum: RR 3.6 (1.7-7.7) p=.0009 | Grill, 2001^511^
Non-anaplastic, mixed, or unspecified ependymoma | 1 Year | Not applicable | 95% (85-100%) (N=20) | Not reported | Robertson, 1998^489^
Non-anaplastic, mixed, or unspecified ependymoma | 1 Year | 75 (54-96 95% CI) (N=16) | Not applicable | Not reported | Grill, 1996^497^
Non-anaplastic, mixed, or unspecified ependymoma | 1 Year | 2 patients dead at 7 and 9 months (67%) and one patient alive with progression at 25+ months (N=3) | Not applicable | Not reported | Mahoney, 1996^501^
Non-anaplastic, mixed, or unspecified ependymoma | 3 Year | | 79% (63.9-95.4) (N=23) | Complete vs. partial resection not significant | Conter, 2009^508^
Non-anaplastic, mixed, or unspecified ependymoma | 3 Year | Not applicable | Metastatic ∼58% (N=9) Non-Metastatic ∼80% (N=80) | Age< 1 year, p=.18 Female sex, p=.18 Infratentorial, p=.12 WHO gr. III, p=.15 Partial resection (judged by neurosurgeon) p=.07 Partial resection (radiologic review) p=.28 Dose intensity <.8, p=.05 HR=1.6 (1.0-2.7) | Grundy, 2007^512^
Non-anaplastic, mixed, or unspecified ependymoma | 3 Year | ∼62% (N=29) | Not applicable | GTR vs. <GTR not significant | Zacharoulis, 2007^490^
Non-anaplastic, mixed, or unspecified ependymoma | 3 Year | Not applicable | ∼68% (N=73) | PF tumor RR 7.9 (1.8 to 35) p=.0004 Postoperative radiologic documented residuum: RR 3.6 (1.7-7.7) p=.0009 | Grill, 2001^511^
Non-anaplastic, mixed, or unspecified ependymoma | 3 Year | Not applicable | 65 (44-86%) (N=20) | Not reported | Robertson, 1998^489^
Non-anaplastic, mixed, or unspecified ependymoma | 3 Year | 31 (3-58 95% CI) (N=16) | Not applicable | Not reported | Grill, 1996^497^
Non-anaplastic, mixed, or unspecified ependymoma | 5 Year | Not applicable | 74% (57.3-92.3) (N=23) | Complete vs. partial resection NS | Conter, 2009^508^
Non-anaplastic, mixed, or unspecified ependymoma | 5 Year | Not applicable | Metastatic ∼28% (N=80) Nonmetastatic ∼ 63 (N=9) | Age< 1 year, p=.18 Female sex, p=.18 Infratentorial, p=.12 WHO gr. III, p=.15 Partial resection (neurosurgeon) p=.07 Partial resection (radiologic review) p=.28 Dose intensity <.8, p=.05 HR=1.6 (1.0-2.7) | Grundy, 2007^512^
Non-anaplastic, mixed, or unspecified ependymoma | 5 Year | 38±10 (N=29) | Not applicable | GTR vs. <GTR NS | Zacharoulis, 2007^490^
Non-anaplastic, mixed, or unspecified ependymoma | 5 Year | 2 patients alive NED at last FU 20 mo, 67 mo (N=2) | Not applicable | Not reported | Busca, 1997^495^
Non-anaplastic, mixed, or unspecified ependymoma | 5 Year | 10 (0-29 95% CI) (N=16) | Not applicable | Not reported | Grill, 1996^497^
Non-anaplastic, mixed, or unspecified ependymoma | 5 Year | Not applicable | 52±(38 to 65%) (N=73) | PF tumor RR 7.9 (1.8 to 35) p=.0004 Postoperative radiologic documented residuum: RR 3.6 (1.7-7.7) p=.0009 | Grill, 2001^511^
Non-anaplastic, mixed, or unspecified ependymoma | 5 Year | Not applicable | Grade II 73.7±10.2% (N=20) Complete resection (N=18): 82.1±9.5% Incomplete resection (N=19): 36.8±11.8% Biopsy (N=6): 33.3±19.3% Age <3 years (N=9): 41.7±17.3% Age >3 years (N=34): 57.4±9.1% | Anaplasia p<.001 Surgical Resection p<.001 Age p=.036 | Jaing, 2004^516^
Non-anaplastic, mixed, or unspecified ependymoma | 5 Year | 1 patient alive with stable disease at 62 months (N=1) | Not applicable | Not reported | Ozkaynak, 2004^367^
Non-anaplastic, mixed, or unspecified ependymoma | 5 Year | Not applicable | 57.2±5 (N=83) | Age (<=3yr at diagnosis vs. >3 yr) p=.005; HR .04 (.2-.8) Deg. resection (GTR vs. <GTR) p=.01; HR 2.4(1.2-4.9) Histology (grade II vs. III) p=.05; HR 1.9 (.99-3.4) | Horn, 1999^514^
Non-anaplastic, mixed, or unspecified ependymoma | 5 Year | Not applicable | 6 pts DOD at 4.5 mo (N=21) | Not reported | Kuhl, 1998^520^
Non-anaplastic, mixed, or unspecified ependymoma | 5 Year | Not applicable | 53% (31-76%) (N=20) | Not reported | Robertson, 1998^489^
Non-anaplastic, mixed, or unspecified ependymoma | 5 Year | Not applicable | 50.3 (23.1-72.4) (N=15) | Not reported | Grundy, 2010^513^
Choroid plexus carcinoma (CPC) | 1 Year | Not applicable | ∼82 (N=29) | Tumor Type (Choroid plexus carcinoma vs. choroid plexus paplioma and atypicalb choroid plexus paplioma) HR 26.4 p=.003 | Wrede, 2009^522^
Choroid plexus carcinoma (CPC) | 1 Year | 2 partially resected pts DOD at 21 and 25 mo (N=2) | 13 patients DOD at median time 9 mo (range 4-41 mo) (65%) 7 patients Alive and well at median follow up 25 mo (range 3-85 mo) (35%) 1 of 8 gross total resection patients died (12.5%) 11 of 12 partial resection patients died (92%) (N=20) | Not reported | Berger, 1998^488^
Choroid plexus carcinoma (CPC) | 1 Year | 1 patient DOD at 5 months (N=1) | Not applicable | Not reported | Gururangan, 1998^499^
Choroid plexus carcinoma (CPC) | 1 Year | 1 pt dead at 11 mo (N=1) | Not applicable | Not reported | Yule, 1997^504^
Choroid plexus carcinoma (CPC) | 1 Year | Not applicable | 50.3 (23.1-72.4) (N=15) | Not reported | Grundy, 2010^513^
Choroid plexus carcinoma (CPC) | 3 Year | Not applicable | ∼70 (N=29) | Tumor Type (Choroid plexus carcinoma vs. choroid plexus paplioma and atypical choroid plexus paplioma) HR 26.4 p=.003 | Wrede, 2009^522^
Choroid plexus carcinoma (CPC) | 3 Year | Not applicable | 21.5 (5.2-45.0) 3(N=15) | Not reported | Grundy, 2010^513^
Choroid plexus carcinoma (CPC) | 5 Year | Not applicable | 36 (9-100) (N=29) | Tumor Type (Choroid plexus carcinoma vs. choroid plexus paplioma and atypical choroid plexus paplioma) HR 26.4 p=.003 | Wrede, 2009^522^
Choroid plexus carcinoma (CPC) | 5 Year | Not applicable | 21.5 (5.2-45.6) (N=15) | Not reported | Grundy, 2010^513^
Other glioma | 1 Year | 1 Oligodendroglioma dead at 8 mo (N=1) | Not applicable | Not reported | Thorarinsdottir, 2007^503^
Other glioma | 1 Year | Not applicable | Median BSG OS 9mo (3-11) (33%) (N=8) | Not reported | De Sio, 2006^509^
Other glioma | 1 Year | Not applicable | 2 patients w/brainstem glioma DOD at 4 and 8 mo (N=2) | Not reported | Korones, 2006^518^
Other glioma | 1 Year | Other glioma ∼91 (Anaplastic astrocytoma (N=9) and anaplastic oligodendroglioma (N=2)) (N=11) | Not applicable | OS for glioblastoma multiforme compared to other histotypes (AA and ODG) were significantly worse P=.004 | Massimino, 2005^502^
Other glioma | 1 Year | Not applicable | Other Glioma ∼62 (N=6) | Not reported | Macdonald, 2005^521^
Other glioma | 1 Year | 2 recurrent BSG patient DOD at 4 and 9 mo (N=2) | Not applicable | Not reported | Ozkaynak, 2004^367^
Other glioma | 1 Year | Pontine ∼25 (N=24) | Not applicable | Not reported | Bouffet, 1997^493^
Other glioma | 1 Year | Not applicable | Brainstem Glioma 9±5 (N=22) | Not reported | Kobrinsky, 1999^517^
Other glioma | 1 Year | 1 Pons patient alive at last follow up. 5 patients DOD at median 8 mo (5-14 mo) (N=6) | Not applicable | Not reported | Jakacki, 1999^500^
Other glioma | 1 Year | Median survival of pontine glioma patients was 4 mo (N=10) | Not applicable | Not reported | Dunkel, 1998^496^
Other glioma | 1 Year | Median survival of HGG patients was 3 mo (12d-11 mo) (N=13) | Not applicable | Not reported | Bouffet, 1997^493^
Other glioma | 1 Year | 1 oligodendroglioma dead at 10 mo (N=1) | Not applicable | Not reported | Busca, 1997^495^
Other glioma | 1 Year | Not applicable | 1 BSG dead at 2 mo (N=1) | Not reported | Mahoney, 1996^501^
Other glioma | 1 Year | Not applicable | HGG 57.9 (33.2-76.3) (N=19) | Not reported | Grundy, 2010^513^
Other glioma | 3 Year | Other glioma ∼73 (Anaplastic astrocytoma (N=9) and anaplastic oligodendroglioma (N=2)) (N=11) | Not applicable | OS for glioblastoma multiforme compared to other histotypes (AA and ODG) were significantly worse p=.004 | Massimino, 2005^502^
Other glioma | 3 Year | Not applicable | 3 year OS: Other glioma ∼62 (N=6) | Not reported | Macdonald, 2005^521^
Other glioma | 3 Year | Pontine ∼0. (N=24) | Not applicable | Not reported | Bouffet, 1997^493^
Other glioma | 3 Year | Not applicable | Brainstem glioma 0 (N=22) | Not reported | Kobrinsky, 1999^517^
Other glioma | 3 Year | Not applicable | HGG 40.5 (18.7-61.5) (N=19) | Not reported | Grundy, 2010^513^
Other glioma | 5 Year | 1 ganglioma patient dead at 59 mo (N=1) | Not applicable | Not reported | Thorarinsdottir, 2007^503^
Other glioma | 5 Year | Other glioma ∼73 (Anaplastic astrocytoma (N=9) and anaplastic oligodendroglioma (N=2)) (N=11) | Not applicable | OS for glioblastoma multiforme compared to other histotypes (AA and ODG) were significantly worse p=.004 | Massimino, 2005^502^
Other glioma | 5 Year | Not applicable | Other glioma ∼38 (N=6) | Not reported | Macdonald, 2005^521^
Other glioma | 5 Year | Not applicable | Malignant glioma 36 ± 10 (N=22) | Not reported | Kuhl, 1998^520^
Other glioma | 5 Year | Not applicable | HGG 34.7 (14.6-56.0) (N=19) | Not reported | Grundy, 2010^513^
Astrocytoma (summary comparison) | OS Range for 5 years for studies with ≥10 patients | Newly Diagnosed: ∼73%* (Massimo, 2005 502) [*This study included 9 Anaplastic Astrocytoma patients and 2 lower-grade oligodendroglioma patients.] Massimo measured from time of diagnosis | Newly Diagnosed: 25% (Macdonald 521N=30) Macdonald measured from time of study entry to death | Not applicable | Bertolone 491 was not included in this estimate because the study did not differentiate between AA and GBM patients
Astrocytoma (summary comparison) | OS Range for 5 years for studies with ≥10 patients | Recurrent/Pro gressive: 40% (Finlay 485 N=17) Measured from time of myeloablative chemotherapy | Recurrent/Progressive: 0% (Finlay 485 N=27) Measured from time of recurrence | Not applicable | Bertolone 491 was not included in this estimate because the study did not differentiate between AA and GBM patients
Glioblastoma multiforme (summary comparison) | 5 year OS for all studies with N ≥10 patients | Newly Diagnosed: 0-22% (Grovas 498 N=11, Massimo 502 N=10) Grovas measured from time of stem cell rescue Massimo considered OS from date of chemotherapy | Newly Diagnosed: 22% (Macdonald 521 N=40) Macdonald measured from time of study entry to death | Not applicable | Bertolone 491 was not included in this estimate because the study did not differentiate between AA and GBM patients
Glioblastoma multiforme (summary comparison) | 5 year OS for all studies with N ≥10 patients | Recurrent/Progressive: 12% (Finlay 485 N=17) Measured from time of myeloablative chemotherapy | Recurrent/Progressive: 0% (Finlay 485 N=27) Measured from time of recurrence | Not applicable | Bertolone 491 was not included in this estimate because the study did not differentiate between AA and GBM patients
Ependymoma (summary comparison) | 5 year OS for studies with N ≥10 patients | Newly Diagnosed, unspecified anaplastic 38% (Zacharoulis 490 N=29) Zacharoulis estimated OS from date of diagnosis | Newly Diagnosed Nonanaplastic, mixed, or unspecified Ependymoma: 52-74% (Conter 508 N=23, Grill, 2001 511 N=14, Horn 514 N=83, Jaing 516 N=20, Robertson489 N=20) Conter and Jaing estimated OS from date of surgery, Grill measured from date of chemotherapy, Robertson measured from date of randomization, and Horn measured from date of diagnosis. Overall, these differing estimates of overall survival approximate date of surgery within 13 weeks. Newly Diagnosed Anaplastic Ependymoma: 35.2-64% (Jaing 516 N=23 and Robertson 489 N=12) Jaing used date of surgery for OS calculation and Robertson used date of randomization | Not applicable | Grundy et al. was not included in this estimate because the study stratified by metastasis finding a 5 year OS of 28% for metastatic ependymoma and 63% for nonmetastatic disease and measured the OS from date of surgery.
Ependymoma (summary comparison) | 5 year OS for studies with N ≥10 patients | No patients alive past 25 months. (Berger 488 N=2, Gururangan 499 N=1, Yule 504 N=1) | 21.5-36% (Grundy N=15 and Wrede 522 N=29) Wrede measured OS from date of diagnosis and Grundy used date of surgery | Not applicable | Not applicable
Choroid plexus carcinoma (summary comparison) | 5 Year OS All studies | No patients alive past 25 months. (Berger 488 N=2, Gururangan 499 N=1, Yule 504 N=1) | 21.5-36% (Grundy N=15 and Wrede 522 N=29) Wrede measured OS from date of diagnosis and Grundy used date of surgery | Not applicable | Not applicable

Fourteen studies examined overall survival for astrocytic gliomas.123, 132, 367, 485, 491, 492, 495, 500-502, 509, 510, 517, 518 Survival data were reported for 20 patients with astrocytic tumors who underwent autologous transplant and 106 conventional therapy patients. Fourteen studies examined overall survival for glioblastoma multiforme.123, 132, 367, 485, 491, 492, 495, 498, 500-502, 504, 509, 518 Survival data was reported for 45 patients with glioblastoma multiforme who underwent autologous transplant and 92 conventional therapy patients. Of the noncomparative studies reporting yearly OS, none had HSCT treatment. OS at 5 years ranged from 0 percent in recurrent patients to 25 percent for newly diagnosed patients. One study grouped OS of newly diagnosed AA and GBM patients and stratified by noninfant or infant status. These patients had a 5-year OS of 36±13 for noninfants and 25±15 for infants.

Finlay et al.485, compared a historic chemotherapy cohort (CCG-945) to astrocytoma and GBM patients receiving HSCT. This study provided 5-year recurrent HSCT and conventional therapy OS estimates of 40 percent and 4 percent for astrocytoma and 12 percent and 0 percent for glioblastoma multiforme respectively. The OS was statistically significantly better for HSCT compared to chemotherapy at p=0.010 and retained this significance when stratified by tumor histology. The authors also found evidence that degree of surgical debulking impacted survival. OS estimates stratified by treatment and degree of debulking minimized the treatment effect and yielding a nonsignificant survival difference of p=0.39 due to the poor prognosis of patients with bulky tumor in both treatment types. However, when the authors looked at HSCT versus chemotherapy treatment among only surgically debulked patients the HSCT patients had a better survival (p=0.017).

Three noncomparative studies reported yearly GBM OS with a 5-year OS estimate for autologous transplant of newly diagnosed GBM of 0-22 percent and newly diagnosed conventional therapy of 22 percent.498, 502, 521 Data comparing HSCT to conventional therapy was provided by Finlay et al.485 for recurrent/progressive GBM and AA showed an increase in survival for HSCT. No comparison was made for newly diagnosed AA due to a lack of HSCT studies. Data for newly diagnosed GBM seems to show a similarly poor prognosis for both HSCT and conventional therapy patients.

Seventeen studies examined overall survival for ependymoma132, 367, 489, 490, 495, 497, 501, 504, 507-509, 511-514, 516, 520 Survival data was reported for 71 patients with ependymal tumors who underwent transplant and 442 conventional therapy patients. No studies were comparative between HSCT and conventional therapy. Five studies reported overall survival with a 5 year overall survival estimates for autologous transplant of recurrent tumor of 10 percent and newly diagnosed of 38 percent.367, 490, 495, 497, 504 Conventional therapy did not include recurrent disease and found estimates of 35.2 percent to 64 percent for newly diagnosed anaplastic ependymoma with newly diagnosed nonanaplastic, mixed or unspecified ependymoma estimates of 52-74 percent.489, 508, 511, 513, 514, 516, 520 One study stratified by metastatic/nonmetastatic disease and obtained a 5-year OS of 33 percent and 59 percent respectively.512 For patients with newly diagnosed ependymoma, patients treated with HSCT appear to have inferior overall survival when compared to those treated with conventional therapy.

Sixty-four patients with choroid plexus carcinoma were in three conventional therapy studies and four patients with HSCT across three studies reported survival.488, 499, 504, 513, 522 All HSCT patients died between five and 25 months. A conventional therapy study of 29 patients had survival of 35 percent at last followup (median 25 months, range 3-85 months). Two studies reported 5-year OS of 21.5 and 36 percent.

##### Event-free Survival

Data on event-free survival can be found in Appendix D.

##### Adverse Effects

Nine HSCT studies reported adverse events in a patient population of 138 patients composed of 13 anaplastic astrocytoma, three anaplastic glioma, 49 ependymoma, one ganglioma, 30 glioblastoma multiforme, one oligodendroglioma, and 41 pontine tumors (Table 86).485, 490, 493, 497, 498, 500, 501, 503, 506 The conventional therapy studies reported adverse events for 113 ependymoma patients, 30 anaplastic astrocytoma patients, 40 glioblastoma multiforme patients, 18 high-grade glioma patients, seven pontine tumor patients and 15 choroid plexus tumor patients.508, 512, 513, 521 Overall, the level of adverse event reporting for both HSCT and conventional therapy may be underreported. Many studies included tumor types not relevant to this report in their design, and the authors in most instances did not give data on a tumor group or per patient basis when discussing adverse events.

Table 86 Adverse effects for single auto HSCT and comparison (conventional chemotherapy +/- radiation) group: Glial tumors

Outcome | HSCT (%) | Conventional Therapy (%) | Study
Treatment related mortality | 5 toxic deaths in HSCT group (19%) | Not applicable | Finlay, 2008^485^
Treatment related mortality | 3 toxic deaths (10%) | Not applicable | Zacharoulis, 2007^490^
Treatment related mortality | Not applicable | 1 patient died preoperatively (1%) | Grundy, 2007^512^
Treatment related mortality | Not applicable | 3 (4%) | Macdonald, 2005^521^
Treatment related mortality | 1 hVOD (3%) 1 toxic exfoliative dermatitis with acute renal failure (3%) S1 aspergillus fumigatus pneumonia (3%) | Not applicable | Bouffet, 1997^493^
Treatment related mortality | 2 (18%) | Not applicable | Grovas, 1999^498^
Treatment related mortality | 5 toxic mortality (33%) | Not applicable | Mason, 1998^506^
Treatment related mortality | 1 (6%) | Not applicable | Grill, 1996^497^
Treatment related mortality | 4 (21%) | Not applicable | Mahoney, 1996^501^
Secondary malignancies | 1 lymphoblastic non-Hodgkin's lymphoma at 3.5 yr (9%) | Not applicable | Grovas, 1999^498^
Infectious complications ≥ grade III | # Gram positive bacterium per patient: Oligodendroglimoma 2 Ganglioma 3 Anaplastic glioma 0, 1, 2 Ependymoma 4 | Not applicable | Thorarinsdottir, 2007^503^
Infectious complications ≥ grade III | 3 cases of sepsis leading to toxic morality (10%) | Not applicable | Zacharoulis, 2007^490^
Infectious complications ≥ grade III | Not applicable | 6 Grade 3 or 4 infectious complication (8.6%) 1 patient died due to infection (group not given) (1.4%) | Macdonald, 2005^521^
Infectious complications ≥ grade III | 1 Aspergillus fumigatus (6%) 1 cytomegalovirus (6%) | Not applicable | Bouffet, 1997^493^
Infectious complications ≥ grade III | gram-positive sepsis (9%) | Not applicable | Grovas, 1999^498^
Infectious complications ≥ grade III | 7 infection (37%) 1 fungal infection (5%) | Not applicable | Mahoney, 1996^501^
Infectious complications ≥ grade III | 2 patients had interstitial pneumonia which resolved with treatment (17%) | Not applicable | Jakacki, 1999^500^
Serious hemorrhagic event | Not applicable | 2 patients died of serious hemorrhagic events (group not given) | Macdonald, 2005^521^
Veno-occlusive disease | 4 mild-severe hVOD (11%) 1 fatal hVOD (3%) | Not applicable | Bouffet, 1997^493^
Veno-occlusive disease | 1 Fatal hVOD at 2.9 mo (9%) | Not applicable | Grovas, 1999^498^
Long-term complications | Not applicable | 5 children required special needs education | Grundy, 2010^513^
Long-term complications | Not applicable | 2 Mild retardation (13%) 2 Severe retardation (13%) Two patients were placed in a special school, and two were ≥ 2 years behind at school 5 Diplopia (32%) Severe decrease of visual acuity 1 (6%) | Conter, 2009^508^
Long-term complications | 1 ODG pt had decreased neurologic responsiveness/ blindness (100%) 1 GG pt had ADD (100%) 1 AG patient had Gr 2 L hemiparesis (33%) 1 AG pt had Ataxia (33%) 1 EPD pt had hypotonia/multiple neuropathies G 2-4 hearing loss/poor speech (100%) | Not applicable | Thorarinsdottir, 2007^503^
Long-term complications | 1 right atrial mural thrombosis leading to death at 3.4 mo (9%) | Not applicable | Grovas, 1999^498^

#### Ongoing Research

Six trials were identified with currently unpublished results (Table 87). One trial was completed, two were ongoing, and three were recruiting participants. Anaplastic astrocytoma was investigated in four studies, brainstem glioma in one study, choroid plexus carcinoma in two studies, ependymoma in three studies, and glioblastoma multiforme in four studies. The estimated total enrollment of these trials is 363 participants, but with the exception of two studies, nonpediatric patients will also be enrolled. All studies include overall survival or event-free survival as outcomes relevant to this report.

Table 87 Ongoing trials: Glial tumors

Trial Name (Estimated Enrollment) | Status | Indication Relevant Tumor Types | Patient Population
Chemotherapy Plus Peripheral Stem Cell Transplantation in Treating Infants With Malignant Brain or Spinal Cord Tumors (n=83) | Completed | Newly Diagnosed: EPD, AA, CPC | up to 2 years
Stem Cell Transplant for High Risk Central Nervous System (CNS) Tumors (n=50) | Ongoing | Newly Diagnosed: GBM, AA | 18 mo - 25 years
Chemotherapy Followed by Bone Marrow or Peripheral Stem Cell Transplantation in Treating Patients With Glioblastoma Multiforme or Brain Stem Tumors (n=60) | Ongoing, no recruitment | Nonprogressive: GBM | 6-60 years
Busulfan, Melphalan, Topotecan Hydrochloride, and a Stem Cell Transplant in Treating Patients With Newly Diagnosed or Relapsed Solid Tumor (n=20) | Recruiting | Progressive/ Recurrent CNS: EPD, AA, BSG | 6-40 years
Phase III Pilot Study of Induction Chemotherapy Followed by Consolidation Myeloablative Chemotherapy Comprising Thiotepa and Carboplatin With or Without Etoposide and Autologous Hematopoietic Stem Cell Rescue in Pediatric Patients With Previously Untreated Malignant Brain Tumors(n=120) | Recruiting | Newly diagnosed: CNS Tumors: GBM, HGG, CPC, EPD, AA | Less than 10 years
Temozolomide, Carmustine, O6-Benzylguanine, Radiation Therapy, and an Autologous Stem Cell Transplant in Treating Patients With Newly Diagnosed Glioblastoma Multiforme or Gliosarcoma (n=30) | Recruiting | Newly diagnosed: GBM | 18+ years

AA = anaplastic astrocytoma; BSG = brainstem glioma; CNS = central nervous system; CPC = choroid plexus carcinoma; EPD = ependymoma; GBM = glioblastoma multiforme; HGG = high-grade glioma; OAST = oligoastrocytoma; ODG = oligodendroglioma; REC = recurrent

#### Conclusions

Low strength evidence on overall survival suggests a benefit with single HSCT compared to conventional therapy for the treatment of:

- High-risk recurrent or progressive anaplastic astrocytoma
- High-risk recurrent glioblastoma multiforme.

Low strength evidence on overall survival suggests a harm due to higher treatment-related mortality with single HSCT compared to conventional chemotherapy for the treatment of nonanaplastic mixed or unspecified ependymoma.

The body of evidence on overall survival with single HSCT compared to conventional therapy was insufficient to draw conclusions for treatment of:

- High-risk newly diagnosed anaplastic astrocytoma
- High-risk newly diagnosed glioblastoma multiforme
- Newly diagnosed anaplastic, nonanaplastic, mixed, or unspecified ependymoma
- Recurrent ependymoma
- Choroid plexus carcinoma
- Other gliomas.

## Systematic Reviews: Nonmalignant Disease

### Inherited Metabolic Diseases Systematic Review

#### Background and Setting

Inherited metabolic diseases (IMD), also known as inborn errors of metabolism, are rare genetic diseases of biochemistry. IMDs are caused by defects of enzymes which result in the accumulation of substrates in tissues and organs. As substrates accumulate, progressive damage to the skeletal structure, connective tissues, organs, and in more severe disorders, the central nervous system occurs. Symptoms and the severity range widely among the IMDs. Many of the diseases are characterized by a rapid deterioration and have a life expectancy of a few years, while some of the IMDs have a slower course and patients may live into adulthood. While each condition is rare, the collection of these diseases has caused significant morbidity and mortality. Estimates of cumulative incidence for IMDs range from 1 in 1500 to 1 in 5,000 live births.270, 523, 524

In this report, IMDs will be discussed in three sections: 1) diseases with rapid progression of symptoms and life expectancies of 10 years or less, 2) diseases with slower progression of symptoms and life expectancies of more than 10 years, and 3) diseases with two different forms, one form which has a rapid progression of symptoms and one form which has a slow progression of symptoms. For diseases that have a rapid progression of symptoms, the expected outcome following HSCT is prolonged life expectancy. For diseases with a slow progression of symptoms, the expected outcomes following HSCT are improvements in neurocognitive and neurodevelopmental functioning.

The diseases with rapid progression of symptoms that were systematically reviewed include: Wolman disease, Gaucher disease Type II, Niemann-Pick Type A, mucolipidosis II (I-cell disease), cystinosis, and infantile free sialic acid disease. The diseases with slow progression of symptoms that were systematically reviewed are mucopolysaccharidosis II (Hunter's disease), mucopolysaccharidosis III (Sanfilippo disease), mucopolysaccharidosis IV (Morquio syndrome), Fabry's disease, Gaucher disease Type III, aspartylglucosaminuria, β-mannosidosis, mucolipidosis III, mucolipidosis IV, Niemann-Pick Type C, glycogen storage disease Type 2 (Pompe disease), Salla disease, and adrenomyeloneuropathy. Diseases with forms that progress rapidly and forms that progress slowly and that were systematically reviewed are Farber's disease, GM_1_ gangliosidosis, Tay-Sachs disease, Sandhoff's disease, ceroid lipofuscinosis, and galactosialidosis.

#### Evidence Summary

##### Diseases With Rapid Progression

The overall grade of strength of evidence for overall survival with the use of HSCT for the treatment of inherited metabolic diseases with rapid progression is shown in Table 88.

Table 88 Overall grade of strength of evidence for overall survival with the use of HSCT for the treatment of inherited metabolic diseases with rapid progression

Key Question | Study Design | Risk of Bias | Consistency | Directness | Precision | Strength of Association | Overall Grade/Conclusion
What is the comparative effectiveness and harms of HSCT in the treatment of Wolman's disease compared to symptom management and natural progression of disease? Key outcomes are overall survival. | 2 case reports and 2 case series | High | The evidence is consistent. | The outcomes reported are direct. | The evidence is precise suggesting an overall survival advantage for HSCT over conventional therapy. While the evidence is qualitative it is unlikely that the prognosis would change without HSCT treatment. | The strength of association is strong. | High strength evidence on overall survival suggests a benefit with single HSCT compared to conventional management of Wolman's disease. 4 survived treatment, with followups of 0.3-11 yrs; 3 long-term survivors (4-11 yrs) highly functional and attending school. 2 TRM deaths 1 death from disease progression
What is the comparative effectiveness and harms of HSCT in the treatment of Gaucher disease Type II compared to symptom management and natural progression of disease? Key outcomes are overall survival. | 0 studies found | Not applicable | Not applicable | Not applicable | Not applicable | Not applicable | Insufficient evidence
What is the comparative effectiveness and harms of HSCT in the treatment of Niemann-Pick Type A compared to symptom management and natural progression of disease? Key outcomes are overall survival. | 1 case report and 1 case series | High | The evidence is consistent. | The outcomes reported are direct. | The evidence is imprecise. | Not applicable due to lack of obvious effect size. | Low strength evidence on overall survival suggests no benefit with single HSCT compared to symptom management for Niemann-Pick Type A. 2 pts dead at 2 yrs followup from disease progression 1 pt alive at 2.7 yrs followup, with neurocognitive and neurodevelopmental decline.
What is the comparative effectiveness and harms of HSCT in the treatment of mucolipidosis II (I-cell disease) compared to symptom management and natural progression of disease? Key outcomes are overall survival. | 3 case reports | High | The evidence is inconsistent. | The outcomes reported are direct. | The evidence is imprecise. | Not applicable due to lack of obvious effect size. | The body of evidence on overall survival with single HSCT compared to symptom management for mucolipidosis II (I-cell disease) is insufficient to draw conclusions. 1 pt died of progressive disease 5.6 yrs post-transplant. 1 pt alive 5 yrs post-transplant, mildly to moderately impaired mentally and physically 1 pt alive 2 yrs post, with unknown mental and physical outcomes
What is the comparative effectiveness and harms of HSCT in the treatment of cystinosis compared to symptom management and natural progression of disease? Key outcomes are overall survival. | 0 studies found | Not applicable | Not applicable | Not applicable | Not applicable | Not applicable | Insufficient evidence
What is the comparative effectiveness and harms of HSCT in the treatment of infantile free sialic acid disease compared to symptom management and natural progression of disease? Key outcomes are overall survival. | 0 studies found | Not applicable | Not applicable | Not applicable | Not applicable | Not applicable | Insufficient evidence

TRM = treatment-related mortality

##### Diseases With Slow Progression

The overall grade of strength of evidence for stabilization of neurocognitive and neurodevelopmental symptoms with the use of HSCT for the treatment of inherited metabolic diseases with slow progression is shown in Table 89.

Table 89 Overall grade of strength of evidence for stabilization of neurocognitive and neurodevelopmental symptoms with the use of HSCT for the treatment of inherited metabolic diseases with slow progression

Key Question | Study Design | Risk of Bias | Consistency | Directness | Precision | Strength of Association | Overall Grade/Conclusion
What is the comparative effectiveness and harms of HSCT in the treatment of MPS II (Hunter's disease) compared to symptom management, ERT, and the natural history of disease? Key outcomes are neurocognitive and neurodevelopmental symptoms. | 8 case reports and 6 case series | High | The evidence is consistent for the severe form. Evidence is inconsistent for the attenuated form. | The outcomes reported are direct. The comparisons are indirect as the evidence base utilizes two or more bodies of evidence to make comparisons. | For neurodevelopmental symptoms, the evidence is precise for both the severe and attenuated form, suggesting outcomes with HSCT are equal to ERT. For neurocognitive symptoms, the evidence is precise for the severe form, suggesting HSCT does not provide a benefit. For neurocognitive symptoms, the evidence is imprecise for the attenuated form, suggesting an advantage of HSCT over ERT. | For neurodevelopmental symptoms, the strength of association is not applicable as no effect size is obvious compared to ERT. For neurocognitive symptoms in the severe form, this is not applicable due to lack of obvious effect size. For neurocognitive symptoms in the attenuated form, the strength of association is weak. | Low strength evidence on neurodevelopmental outcomes suggests equivalent benefit with single HSCT compared to ERT for severe and attenuated forms of MPS II (Hunter's disease). Low strength evidence on neurocognitive outcomes suggests no benefit with single HSCT compared to symptom management/natural history for the severe MPS II. Low strength evidence on neurocognitive outcomes suggests benefit with single HSCT compared to ERT for attenuated MPS II. 7 TRM deaths out of 32 pts undergoing HSCT. 7 of 8 with severe form showed neurocognitive decline. Among 6 with attenuated form, 4 stable neurocognitively, 2 declining. ERT* trials on pts with attenuated form only. No neurocognitive outcomes reported. Improvements in neurodevelopmental symptoms were reported.
What is the comparative effectiveness and harms of HSCT in the treatment of MPS III (Sanfilippo disease) compared to symptom management and natural history of the disease? Key outcomes are neurocognitive and neurodevelopmental symptoms. | 1 case reports and 4 case series | High | Evidence is inconsistent. | The outcomes reported are direct. | The evidence is imprecise. | Not applicable due to lack of obvious effect size. | Low strength evidence on neurocognitive and neurodevelopmental outcomes suggests no benefit with single HSCT compared to symptom management for MPS III (Sanfilippo disease). 1 pt died 5 mos post-HSCT of pneumonia 1 pt alive at unspecified followup, 7 pts alive at 2.4-14.0 yrs No followup details in 1 pt, 1 pt stable, 6 pts declining neurocognitively and neurodevelopmentally, though 2 of 6 are declining slower than untreated siblings.
What is the comparative effectiveness and harms of HSCT in the treatment of MPS IV (Morquio syndrome) compared to symptom management and natural history of the disease? Key outcomes are neurocognitive and neurodevelopmental symptoms. | 2 case reports | High | Not applicable | The outcomes reported are direct. | The evidence is imprecise. | Not applicable due to lack of obvious effect size. | The body of evidence on neurocognitive and neurodevelopmental outcomes with single HSCT compared to symptom management for MPS IV (Morquio syndrome) is insufficient to draw conclusions. No followup data provided for 1 pt who was transplanted at 15 yrs of age. Only cardiac followup on 2^nd^ pt, and no cardiac improvement reported.
What is the comparative effectiveness and harms of HSCT in the treatment of Fabry's disease compared to symptom management and the natural history of the disease? Key outcomes are neurocognitive and neurodevelopmental symptoms. | 0 studies found | Not applicable | Not applicable | Not applicable | Not applicable | Not applicable | Insufficient evidence
What is the comparative effectiveness and harms of HSCT in the treatment of Gaucher Type III compared to symptom management, ERT, substrate reduction therapy, and the natural history of the disease? Key outcomes are neurocognitive and neurodevelopmental symptoms. | 2 case reports and 2 case series | High | Evidence for neurocognitive outcomes with HSCT is consistent. | The outcomes reported are direct. The comparisons are indirect as the evidence base utilizes two or more bodies of evidence to make comparisons. | The evidence on neurocognitive score stabilization with HSCT is precise. | Not applicable due to lack of obvious effect size. | Low strength evidence on neurocognitive and neurodevelopmental outcomes suggests no benefit with single HSCT compared to ERT for Gaucher Type III disease. 1 TRM death out of 8 undergoing HSCT. 5 out of 8 pts treated with HSCT showed stable neurocognitive scores. All pts with HSCT had improved growth, but no improvement in skeletal symptoms. 2 pts treated with HSCT followed by ERT*, alive at 19-21 yrs, with borderline mental retardation. Among 23 pts treated with ERT alone, 1 died of liver biopsy, the remaining are alive at 0.4-5 yrs followup. Neurocognitive scores are stable in 7 of 9 pts. Growth improved, but no change in skeletal symptoms. In an RCT with 30 pts, comparing ERT alone and ERT with substrate reduction therapy, there was no difference between the 2 grps in neurocognitive scores.
What is the comparative effectiveness and harms of HSCT in the treatment of aspartylglucosaminuria compared to symptom management and natural history of the disease? Key outcomes are neurocognitive and neurodevelopmental symptoms. | 1 case report and 3 case series | High | Evidence is consistent. | The outcomes reported are direct. | The evidence is imprecise. | Not applicable due to lack of obvious effect size. | The body of evidence on neurocognitive and neurodevelopmental outcomes with single HSCT compared to symptom management of aspartylglucosaminuria is insufficient to draw conclusions. All 10 pts alive at followups from 0.3-7.6 yrs. Improved concentration reported in 2 pts, development stabilized at 5 yrs of age in 2 pts whose real ages were 15 and 11. Studies may not have long enough followups to see real effect of HSCT since rapid decline in this disease occurs during adolescence.
What is the comparative effectiveness and harms of HSCT in the treatment of ß-mannosidosis compared to symptom management and natural history of the disease? Key outcomes are neurocognitive and neurodevelopmental symptoms. | 0 studies found | Not applicable | Not applicable | Not applicable | Not applicable | Not applicable | Insufficient evidence
What is the comparative effectiveness and harms of HSCT in the treatment of mucolipidosis III compared to symptom management and natural history of the disease? Key outcomes are neurocognitive and neurodevelopmental symptoms. | 0 studies found | Not applicable | Not applicable | Not applicable | Not applicable | Not applicable | Insufficient evidence
What is the comparative effectiveness and harms of HSCT in the treatment of mucolipidosis IV compared to symptom management and natural history of the disease? Key outcomes are neurocognitive and neurodevelopmental symptoms. | 0 studies found | Not applicable | Not applicable | Not applicable | Not applicable | Not applicable | Insufficient evidence
What is the comparative effectiveness and harms of HSCT in the treatment of Niemann-Pick Type C compared to symptom management, substrate reduction therapy, and the natural history of the disease? Key outcomes are neurocognitive and neurodevelopmental symptoms. | 2 case reports | High | Not applicable | The comparisons are indirect as the evidence base utilizes two or more bodies of evidence to make comparisons. | The evidence is imprecise. | Not applicable due to lack of obvious effect size. | The body of evidence on neurocognitive and neurodevelopmental outcomes with single HSCT compared to symptom management or natural history of Niemann-Pick Type C disease is insufficient to draw conclusions. 1 pt alive at 0.8 yrs followup, with slowly decreasing developmental age measurements. Pt became bedridden during conditioning phase and never improved. 1 pt alive at 1.7 yrs followup, developing normally, except for delayed speech. Studies of substrate reduction therapy versus symptom management present combined adult and pediatric data. Substrate reduction therapy may stabilize ambulation in these pts.
What is the comparative effectiveness and harms of HSCT in the treatment of glycogen storage disease Type 2 (Pompe disease) compared to symptom management and natural history of the disease? Key outcomes are neurocognitive and neurodevelopmental symptoms. | 0 studies found | Not applicable | Not applicable | Not applicable | Not applicable | Not applicable | Insufficient evidence
What is the comparative effectiveness and harms of HSCT in the treatment of Salla disease compared to symptom management and natural history of the disease? Key outcomes are neurocognitive and neurodevelopmental symptoms. | 0 studies found | Not applicable | Not applicable | Not applicable | Not applicable | Not applicable | Insufficient evidence
What is the comparative effectiveness and harms of HSCT in the treatment of adrenomyeloneuropathy compared to symptom management and the natural history of the disease? Key outcomes are neurocognitive and neurodevelopmental symptoms. | 0 studies found | Not applicable | Not applicable | Not applicable | Not applicable | Not applicable | Insufficient evidence A single report of HSCT on an adrenomyeloneuropathy was found on an adult patient, but no pediatric cases were found.

ERT = enzyme replacement therapy; TRM = treatment-related mortality

##### Diseases With Forms That Progress Rapidly and Slowly

The overall grade of strength of evidence for overall survival and stabilization of neurocognitive and neurodevelopmental symptoms with the use of HSCT for the treatment of inherited metabolic diseases with rapid progression and slow progression forms is shown in Table 90.

Table 90 Overall grade of strength of evidence for overall survival and stabilization of neurocognitive and neurodevelopmental symptoms with the use of HSCT for the treatment of inherited metabolic diseases with rapid progression and slow progression form

Key Question | Study Design | Risk of Bias | Consistency | Directness | Precision | Strength of Association | Overall Grade/Conclusion
What is the comparative effectiveness and harms of HSCT in the treatment of Farber's disease compared to symptom management and the natural history of the disease? Key outcomes are overall survival for the rapidly progressive form and neurocognitive and neurodevelopmental outcomes for the slowly progressive form. | Rapid progression: Type 1: 1 case report and 1 case series Slow progression: Type 2/3: 2 case series | Rapid progression: High Slow progression: High | Rapid progression: The evidence is inconsistent Slow progression: The evidence is consistent. | The outcomes reported are direct. | Rapid progression: The evidence is imprecise. Slow progression: Precise | Rapid progression: Not applicable for Type I Farber's disease. Slow progression: The strength of association is strong for Type 2/3 Farber's disease. | The body of evidence on overall survival with single HSCT compared to symptom management or natural history of the Type 1 form of Farber's disease is insufficient to draw conclusions. High strength evidence on number of subcutaneous nodules and number of joints with limited range of motion suggests a benefit with single HSCT compared to symptom management and the natural history of the Type 2/3 form of Farber's disease. 1 pt with Type 1 alive at 2.3 yrs followup with neurocognitive and neurodevelopmental decline. 1 pt with Type 1 dead at 6 mos post-HSCT from disease progression. All 5 pts with Type 2/3 alive at 0.7-1.3 yrs followup, with reduction in number of subcutaneous nodules and number of joints with limited range of motion.
What is the comparative effectiveness and harms of HSCT in the treatment of GM_1_ gangliosidosis compared to symptom management and natural history of the disease? Key outcomes are overall survival for the rapidly progressive form and neurocognitive and neurodevelopmental outcomes for the slowly progressive form. | Rapid progression: infantile form: 0 studies found Slow progression: juvenile form: 1 case report | Rapid progression: Not applicable Slow progression: High | Rapid progression: Not applicable Slow progression: Not applicable | The outcomes reported are direct. | Rapid progression: Not applicable Slow progression: Not applicable | Rapid progression: Not applicable Slow progression: Not applicable | Insufficient evidence for the infantile form of this disease. Insufficient evidence for the juvenile form of this disease. 1 pt alive at 7 yrs followup. Pt is wheelchair bound and has lost all language skills.
What is the comparative effectiveness and harms of HSCT in the treatment of Tay-Sachs disease compared to symptom management, substrate reduction therapy, and the natural history of the disease? Key outcomes are overall survival for the rapidly progressive form and neurocognitive and neurodevelopmental outcomes for the slowly progressive form. | Rapid progression: infantile form: 0 studies found Slow progression: juvenile form: 1 case report Unspecified progression: 1 case report and 1 case series | Rapid progression: Not applicable Slow progression: High Unspecified progression: High | Rapid progression: Not applicable Slow progression: Not applicable Unspecified progression: Not applicable | The comparisons are indirect as the evidence base utilizes two or more bodies of evidence to make comparisons. | Rapid progression: Not applicable Slow progression: Not applicable Unspecified progression: Not applicable | Rapid progression: Not applicable Slow progression: Not applicable Unspecified progression: Not applicable | Insufficient evidence for the infantile form of this disease. Insufficient evidence for the juvenile form of this disease. Insufficient evidence for the unspecified progression form of this disease. 1 pt with the juvenile form is alive at 2 yrs followup. Neurocognitive and neurodevelopmental decline is similar to untreated sibling. 2 pts with the juvenile form received substrate reduction therapy and were alive at 2 yrs followup. Both have declined neurocognitively and neurodevelopmentally. 1 pt with unspecified progression died 4.6 yrs post-HSCT of disease progression and the 2nd pt with unspecified progression was alive at 1.7 yrs post-transplant, but had regressed to a vegetative state.
What is the comparative effectiveness and harms of HSCT in the treatment of ceroid lipofuscinosis compared to symptom management and the natural history of the disease? Key outcomes are overall survival for the rapidly progressive form and neurocognitive and neurodevelopmental outcomes for the slowly progressive form. | Rapid progression: infantile form: 1 case series Slow progression: juvenile form: 0 studies found | Rapid progression: High Slow progression: Not applicable | Rapid progression: Consistent Slow progression: Not applicable | The outcomes reported are direct. | Rapid progression: The evidence is precise. Slow progression: Not applicable | Rapid progression (infantile): Not applicable due to lack of obvious effect size. Slow progression: Not applicable | Low strength evidence on neurocognitive outcomes suggests no benefit with single HSCT compared to symptom management and the natural history of the disease for the infantile form of ceroid lipofuscinosis. Insufficient evidence for the juvenile form of this disease. All 3 pts in case series are alive at 2-4 yrs followup. All 3 pts have neurocognitive decline, and are hypotonic and spastic.
What is the comparative effectiveness and harms of HSCT in the treatment of galactosialidosis compared to symptom management and the natural history of the disease? Key outcomes are overall survival for the rapidly progressive form and neurocognitive and neurodevelopmental outcomes for the slowly progressive form. | Unspecified progression: 1 case report | High | Not applicable | The outcomes reported are direct. | The evidence is imprecise. | Not applicable | The body of evidence on overall survival, neurocognitive and neurodevelopmental outcomes with HSCT compared to symptom management for galactosialidosis is insufficient to draw conclusions. This single case was part of a case series with several different diseases. Results were cumulative across all diseases and no data was available for the single galactosialidosis case 525
What is the comparative effectiveness and harms of HSCT in the treatment of Sandhoff's disease compared to symptom management, substrate reduction therapy, and the natural history of the disease? Key outcomes are overall survival for the rapidly progressive form and neurocognitive and neurodevelopmental outcomes for the slowly progressive form. | Unspecified progression: 1 case report | High | Not applicable | The comparisons are indirect as the evidence base utilizes two or more bodies of evidence to make comparisons. | The evidence is imprecise. | Not applicable | The body of evidence on overall survival, neurocognitive and neurodevelopmental outcomes with HSCT compared to symptom management, substrate reduction therapy, and the natural history of the disease for Sandhoff's disease is insufficient to draw conclusions. The single case report was part of a case series with several diseases. The form of the disease was not specified and there were no neurocognitive or neurodevelopmental outcomes reported. 3 pts with the juvenile form received substrate reduction therapy and were alive at 2 yrs followup. They were stable neurocognitively, but 2 developed gait disturbance and 1 is wheelchair bound.

#### Results

Table 91 shows the criteria that were used to select studies for this section.

Table 91 Study selection criteria: Inherited metabolic diseases

Study Design | Population | Intervention | Comparators | Outcomes | Followup | Setting
Controlled trials, case series, case reports from 1992-present | Pediatric patients (0-21-yr) | HSCT | symptom management, ERT, substrate reduction therapy | enzyme activity, neuro-cognitive and neuro-developmental measurements | All durations of followup | In-patient, out-patient

ERT = enzyme replacement therapy; HSCT = hematopoietic stem cell transplant

#### Diseases With Rapid Progression

##### Wolman Disease

Wolman disease is a rare autosomal recessive disorder characterized by a deficiency of lysosomal acid lipase which causes an accumulation of cholesterol esters and triglycerides in the spleen, liver, adrenal glands, bone marrow, small intestines, and lymph nodes.261 Fewer than 80 cases have been identified. Symptoms appear immediately, within the first week of life, and include failure to thrive, jaundice, anemia, relentless vomiting, abdominal distention, steatorrhea, and hepatosplenomegaly. Because of the failure to absorb nutrients, severe malnutrition occurs and life expectancy is less than 6 months.526 Several patients with Wolman disease have undergone HSCT (Table 92).527-530

Table 92 Study characteristics and population for Wolman disease

Study | Design | Median Age in Years (Range) at Treatment | Sex (M%) | Treatment, Year | Followup Period (yrs) | Enzyme Activity | Neuro-cognitive Outcomes | Neuro-developmental Outcomes | Adverse Effects
Gramatges, US, 2009^527^ | case report | 0.2 | 0 | HSCT, NR | 0.2 | ✓ | NR | NR | ✓
Tolar, US, 2009^531^ | case series (n=4) | 4.5 (0.2-2.1) | 50 | HSCT, NR | (0.2-11.0) | ✓ | ✓ | ✓ | ✓
Stein, Israel, 2007^529^ | case report | 0.25 | 0 | HSCT, NR | 4.0 | ✓ | ✓ | ✓ | ✓
Styczynski, 2011^530^ | Case series (n=1) | 16 | 0 | HSCT, NR | 0.3 | NR | NR | NR | ✓

Refer to Appendix E Table E1 for details of neurocognitive and neurodevelopmental outcomes. In summary, two patients died of treatment-related mortality, one at 2.5 months post-transplant and one at 8 months post-transplant and one died from the natural progression of the disease.527 Three (of 4) patients who survived HSCT are long-term survivors, with followup from 4 to 11 years. They are highly functional in language skills, and social and behavioral skills. One attends regular school and two attend special schools.529, 531

The case report of the patient with Wolman disease who underwent HSCT reported growth in height, weight and head circumference.529 Of the three surviving Wolman disease patients in the case series, one showed improvement in motor skills and another is reported to have average gross motor skills and below average fine motor skills531

Evidence for this rapidly progressing disease which has a life expectancy of 6 months, consists of two case reports and two case series. A total of seven patients with Wolman disease have undergone HSCT. Two died from the procedure and 1 died from disease progression. Four have survived and have been followed for 0.3 to 11 years, with normal or near normal functioning. For three patients who have survived long-term followup from 4 to 11 years, HSCT altered the course of Wolman disease.

##### Gaucher Disease Type II

Gaucher disease is caused by a deficiency in the enzyme glucocerebrosidase, which leads to an accumulation of glucosylceramide in the spleen, liver, lungs, bone marrow, and sometimes the brain.261 There are three types of Gaucher disease. Gaucher Type I is discussed in the Narrative Review section of this report. Gaucher Type III is discussed in this Systematic Review section under diseases with slow progression.

Type II is the acute neuronopathic form, exhibiting hepatosplenomegaly as early as three months of age. There is severe central nervous system involvement and death occurs within two years of life. There is no effective treatment for Type II because of the rapid progression of symptoms and neurological involvement. No HSCT and Gaucher Type II studies were found in the literature.

##### Niemann-Pick Disease Type A

Niemann-Pick disease is characterized by the accumulation of lipids in the spleen, liver, lungs, bone marrow, and the brain. There are three types of this disease. Type A occurs most frequently in the Ashkenazi Jewish population (1 in 40,000), while the frequency of Type A and B in the general population is estimated to be 1 in 250,000.^532^ Type B is discussed in the Narrative Review section of this report. Type C is discussed under the heading “Other Lipidoses” within this Systematic Review.

Type A is the most severe form, occurring in infants and characterized by jaundice, an enlarged liver, and brain damage, with life expectancy of 3 years.261 Reports of HSCT on 3 Type A patients have been found in the literature (Table 93).

Table 93 Study characteristics and population for Niemann-Pick Type A

Study | Design | Median Age in Years (Range) at Treatment | Sex (M%) | Treatment, Year | Followup Period (yrs) | Enzyme Activity | Neuro-cognitive Outcomes | Neuro-developmental Outcomes | Adverse Effects
Morel, Canada, 2007^533^ | case report | 2.5 | 0 | HSCT, NR | 2.7 | ✓ | ✓ | ✓ | ✓
Bayever, US, 1995 534 | case series (n=2) | 7 mos (4-10 mos) | 100 | HSCT, NR | 2.0 | ✓ | ✓ | ✓ | ✓

Refer to Appendix E Table E1 for details of neurocognitive and neurodevelopmental outcomes. In summary, a case report of a patient with Niemann-Pick Type A who underwent HSCT at 3 months of age, showed initial normal neurocognitive and neurodevelopmental progress, followed by brain atrophy at 0.6 years post-transplant, and the onset of seizure disorders and developmental delays by 1.7 years post-transplant.533 At the time of the report, the patient was alive at 2.7 years' followup. Two patients receiving HSCT continued to decline neurocognitively and neurodevelopmentally, and died 2 years post-transplant, from natural progression of disease.534 Autopsy of one patient showed very little enzyme present in target tissues of brain and liver.534

Evidence for Niemann-Pick Type A, which has a life expectancy of 3 years, consists of 1 case report and 1 case series.533, 534 HSCT did not prevent neurocognitive and neurodevelopmental decline in these patients. Based on these reports, HSCT does not show a benefit for Niemann-Pick Type A.

##### Mucolipidosis II (I-cell Disease)

Mucolipidosis II is an autosomal recessive disorder caused by a defective enzyme, N-acetylglucosamine-1-phosphotransferase, which is instrumental in the transport of enzymes. This defect causes a deficiency of lysosomal enzymes in fibroblasts, and an excess of lysosomal enzymes in tissues and extracellular fluids.535 This is a rare, panethnic disorder with an estimated frequency of 1 in 640,000 live births.524

The skeletal system is most severely affected. Death from progressive psychomotor retardation, pneumonia, or congestive heart failure usually occurs in early childhood. Symptom management of this disease includes antibiotics for respiratory infections and nutritional supplements.

There are reports of four cases of mucolipidosis II undergoing HSCT (Table 94).536-538 One mucolipidosis II patient was included in the retrospective study of 81 patients in the Japan Marrow Donor Program. The patient failed to engraft and no further information on that case could be separated from the aggregate data in that study.525

Table 94 Study characteristics and population for mucolipidosis II

Study | Design | Median Age, Yrs (Range) at Treatment | Sex (M%) | Treatment, Year | Followup Period (yrs) | Enzyme Activity | Neuro-cognitive Outcomes | Neuro-developmental Outcomes | Adverse Effects
Li, China, 2004^536^ | case series (n=1)^*^ | 1.0 | 0 | HSCT, 1999-2003 (for series) | 2.0 (for series) | NR | NR | NR | ✓
Grewal, US, 2003^537^ | case report | 1.6 | 0 | HSCT, NR | 5.0 | ✓ | ✓ | ✓ | ✓
Imaizumi, Japan, 1994^538^ | case series (n=1)^*^ | 0.7 | 0 | HSCT, NR | 5.6 | ✓ | ✓ | ✓ | ✓

* This case series combined several diseases in one study and only 1 pt in the series had this disease.

Refer to Appendix E Table E1 for details of neurocognitive and neurodevelopmental outcomes. In summary, one patient in a case series of combined diseases, did not have neurocognitive or neurodevelopmental followup, only adverse events reported.536 The patient experienced infectious complications, grade 2 skin aGVHD, and skin cGVHD. The patient was alive at last followup, which had a median of 2 years for the case series.536 One patient with delayed language skills continued to develop neurocognitively after HSCT, although abilities remained below real age. The patient's gross motor skills remained at level of a 1.5 year-old and fine motor skills were slowly developing through 5-years of followup.537 At the time of the report, the patient was alive at 5 years' followup. One patient with severe psychomotor retardation prior to HSCT gained developmental milestones of a 4- to 8-month old. The patient had no change in joint contractures and skeletal symptoms and died of disease progression at 5.6 years post-transplant.538

There was mention in one of the discussion sections537 of a personal communication with another physician who reportedly used HSCT to treat a patient with mucolipidosis II and that at 1 year post-transplant, the patient showed improvement in development and growth retardation. To our knowledge, this case has not been published.

Evidence for this disease which has a life expectancy of less than 1 decade, consists of three case reports. One patient died at 5.6 years post-transplant of disease progression, one is alive at 2 years' followup but with unknown neurological status, and the other patient was reported as showing progress neurocognitively, although below real age levels, and attends a special school. Based on these three patients with differing outcomes, there is uncertainty as to the benefit of HSCT for I-cell disease.

##### Cystinosis

Cystinosis is a rare autosomal recessive disease caused by a defect in cystinosin, which is needed to transport cystine out of lysosomes, which then results in the accumulation of cystine crystals in most major organs of the body.539 The incidence is estimated at 1 in 100,000-200,000, although the incidence in French Canadians may be higher.540 There are three types of cystinosis: classic nephropathic cystinosis, a rare adolescent form, and a mild adult-onset form.

Symptoms in the classic form present in the first year of life. Progressive renal damage and end stage renal failure is the usual cause of death, commonly within the first decade of life.539 The adolescent form of the disease is milder with a slower progression to renal failure. The adult form is benign, with no renal involvement.540 Renal transplant, oral cysteamine therapy, cysteamine eyedrops, and dialysis have prolonged survival into adulthood for patients with the nephropathic form.539 No studies of HSCT to treat cystinosis were found in the literature.

##### Infantile Sialic Acid Storage Disease

Infantile free sialic acid storage disease (ISSD) is a rare autosomal disorder caused by the accumulation of free sialic acid in lysosomes, due to a defect in the lysosomal membrane transport system.541 More than 27 ISSD cases have been reported. Dysmyelination of the brain occurs in ISSD. Symptoms present at birth and life expectancy is about a year, with cause of death commonly from respiratory infections.542 Disease management is symptom specific. No studies of HSCT to treat ISSD were found in the literature.

#### Diseases With Slow Progression

##### Hunter Syndrome (Mucopolysaccharidosis Type II)

Hunter Syndrome is a rare X-linked recessive disorder caused by a deficiency of the enzyme iduronate sulfatase, needed to degrade heparin sulfate and dermatan sulfate. The disease is panethnic, with an estimated incidence in Europe between 1 in 110,000–300,000; a higher incidence of 1 in 34,000 has been noted in the Jewish population living in Israel.543

There are two clinical forms of the disease, severe and attenuated. Onset of symptoms in the severe form occur at age 2 to 4 years. Survival can be expected into the second decade of life. Cause of death is usually heart disease, from valvular, myocardial, and ischemic factors.263 In the attenuated form, symptoms begin later in life, with minimal to no CNS involvement. Survival can extend into the fifth to sixth decade of life.263

Treatment is symptom specific: developmental, occupational, and physical therapy; shunting for hydrocephalus; tonsillectomy and adenoidectomy; positive pressure ventilation; carpal tunnel release; cardiac valve replacement; inguinal hernia repair; and hip replacement.544 HSCT has been attempted in MPS II patients, with both the severe (n=8) and attenuated forms (n=10), in attempts to slow or stop the progression of the disease (Table 95). An enzyme replacement therapy, Elaprase®, was approved by the FDA in 2006 for treatment of MPS II, following clinical trials which proved efficacy in patients with the attenuated form of the disease, aged 5-31 years.

Table 95 Study characteristics and population for mucopolysaccharidosis II (Hunter disease)

Study | Design | Median Age in Years (Range) at Treatment | Sex (M%) | Treatment, Year | Followup Period (yrs) | Enzyme Activity | Neuro-cognitive Outcomes | Neuro-developmental Outcomes | Adverse Effects
Guffon, France, 2009^545^ | case series (N=8) | 4.6 (3.0-16.3) | 100 | HSCT, 1990-2000 | 5.0-14.0 | ✓ | ✓ | ✓ | ✓
Page, US, 2008^556^ | case series (n=2) | ≤0.25 | 100 | HSCT, 1998-2007 | NR | NR | NR | NR | ✓
Tokimasa, Japan, 2008^557^ | case series (n=1)^*^ | 5.8 | 100 | HSCT, 2005 | 0.8 | NR | NR | NR | ✓
Seto, Japan, 2001^558^ | case series (n=3) | 6.0 (2.0-9.0) | 100 | 3 HSCT, NR, 7 not treated | 7.0 | NR | ✓ | NR | NR
Takahashi, Japan, 2001^547^ | comparative study (n=1) | 4.7 | 100 | 1 HSCT, 2 not treated, NR | 1.1 | ✓ | ✓ | NR | NR
Mullen, US, 2000^559^ | case report | 0.8 | 100 | HSCT, NR | 2.2 | ✓ | ✓ | ✓ | ✓
Coppa, Italy, 1999^551^ | case report | 3.0 | 100 | HSCT, 1995 | 4.0 | ✓ | ✓ | ✓ | ✓
Vellodi, England, 1999^549^ | case series (N=9) | 1.7 (0.8-5.1) | 100 | HSCT, 1982-1991 | 7-14 | ✓ | ✓ | ✓ | ✓
Li, US, 1996^548^ | case report | 5.0 | 100 | HSCT, NR | 5.0 | ✓ | ✓ | ✓ | NR
McKinnis, US, 1996^546^ | case report | 2.4 | 100 | HSCT, 1988 | 5.6 | ✓ | ✓ | ✓ | ✓
Coppa, Italy, 1995, 550 | case report | 2.8 | 100 | HSCT, 1992 | 2 | ✓ | ✓ | ✓ | NR
Hooger-brugge, Netherlands, 1995^553^ | case series (n=1)^*^ | 5.5 | 100 | HSCT, NR | 1.4 | NR | NR | ✓ | NR
Bergstrom, US, 1994^552^ | case report | 14.0 | 100 | HSCT, NR | 3 | ✓ | ✓ | ✓ | ✓
Imaizumi, Japan, 1994^538^ | case series, (n=1)^*^ | 9.8 | 100 | HSCT, NR | 9.8 | ✓ | ✓ | ✓ | ✓
Muenzer, US, 2007^554^ | open label ex-tension (N=9) | 6.0-20.0 | 100 | ERT, NR | 1.0 | ✓ | NR | ✓ | ✓
Muenzer, US, 2006^555^ | RCT (N=64) | 5.4-30.9 | 100 | ERT, NR | 1.0 | ✓ | NR | ✓ | ✓

* This case series combined several diseases in one study and only 1 pt in the series had this disease.

Refer to Appendix E Table E2 for details of neurocognitive and neurodevelopmental outcomes. In summary, among 32 patients undergoing HSCT, seven died of the treatment. In eight MPS II patients with the severe form, five showed decreases in neurocognitive scores545-547 and one showed stable scores.548 In 10 MPS II patients with the attenuated form, there are neurocognitive test scores for 6 patients. Four showed stable scores and two showed slight decreases in their neurocognitive scores.538, 545, 549, 550 Among the three case series and two case reports that did not specify if patients had the severe or attenuated form, there was neurocognitive information on three patients549: two patients showed neurocognitive decline and one patient was stable and attends a special school.

Of 32 MPS II patients undergoing HSCT, there was followup neurodevelopmental information for 19 patients. Improvements in joint stiffness were reported in 14 of the 19 patients,538, 545, 548, 551-553 and one patient showed improvement in both fine and gross motor skills.548

The two clinical trials of enzyme-replacement therapy for MPS II patients reported pre- and post-treatment measurements for 6-minute walk tests.548, 554, 555 The 1-year followup in the Phase II/III trial (N=96) showed improvements in distance walked by the ERT weekly group (p=0.01) and the enzyme-replacement therapy every other week group (p=0.07) compared to the placebo group. The open label extension (n=12) reported that 8 patients improved and 4 experienced no change in walk test results after 1 year of followup.

Evidence for the attenuated form of this disease with a life expectancy into adulthood, consists of three case reports and three case series. HSCT showed stabilization of cognitive skills in four of six patients. Though the numbers are small, HSCT may benefit MPS II patients with the attenuated form.

Evidence for the severe form of this disease with life expectancy into the second decade of life, consists of three case reports and one case series. Neurocognitive decline continued in seven of eight patients. Though the numbers are small, HSCT does not appear to benefit MPS II patients with the severe form.

##### Sanfilippo Syndrome (Mucopolysaccharidosis Type III)

Sanfilippo Syndrome is an autosomal recessive disorder, with an incidence of 1 in 70,000 births.560 There are four types of Sanfilippo Syndrome, differentiated by the specific enzyme deficiency needed to break down heparan sulfate (Type A: heparan sulfate sulfatase, Type B: N-acetyl-o-glucosaminidase, Type C: Acetyl CoA: o-glucosaminide N-acetyltransferase, and Type D: N-acetyl-o-glucosamine-6-sulfate sulfatase).

Type A is the most severe form. Unlike most mucopolysaccharidoses, Sanfilippo disease has milder somatic symptoms, but severe progressive CNS involvement.263 Initial clinical symptoms occur slowly from 1-6 years of age. Mental deterioration is progressive and severe by ages 6 to 10 years.560 Life expectancy is from 12-20 years, with cause of death primarily caused by cardiopulmonary arrest due to airway obstruction and/or pulmonary infection.263 Symptom management of this disease includes anticonvulsants and sedative medications to improve sleep quality. HSCT has been attempted in several MPS III patients (Table 96).553, 561-564

Table 96 Study characteristics and population for mucopolysaccharidosis III (Sanfilippo disease)

Study | Design | Median Age, Yrs (Range) at Treatment | Sex (M%) | Treatment, Year | Followup Period (yrs) | Enzyme Activity | Neuro-cognitive Outcomes | Neuro-developmental Outcomes | Adverse Effects
Ringden, Sweden, 2006^561^ | case series (n=2) | NR | NR | HSCT, NR | 0.4-14.0 (whole series) | NR | NR | NR | ✓
Lange, Brazil, 2006^562^ | case series (n=1)^*^ | 6.0 | 0 | HSCT, 1988-2000 (whole series) | 3.3-14.2 (whole series) | NR | ✓ | NR | ✓
Sivakumar, England, 1999^563^ | comparative study (n=1) | 0.6 | 100 | 1 HSCT, 1 not treated, NR | 7.4 | ✓ | ✓ | ✓ | ✓
Hooger-brugge, Netherlands, 1995^553^ | case series (n=3) | 2.1 (1.7-4.7) | NR | HSCT, NR | 2.4-7.2 | NR | ✓ | NR | NR
Vellodi, England, 1992^564^ | case series (N=2) | 1.5 (twins) | 0 | HSCT, NR | 9.0 | ✓ | ✓ | ✓ | ✓

* This case series combined several diseases in one study and only 1 pt in the series had this disease.

Refer to Appendix E Table E2 for details of neurocognitive and neurodevelopmental outcomes. In summary, one patient died 5 months post-transplant of pneumonia.561 Of nine MPS III patients undergoing HSCT, there is neurocognitive followup information on six patients. There was a continuing deterioration in six patients553, 563, 564 and no significant improvement reported in one patient.562

There is neurodevelopmental information for three of the nine MPS III patients undergoing HSCT.563, 564 One patient experienced a slow and continuous decline in skeletal and muscular symptoms and was wheelchair-bound by 7.4 years after the transplant. This patient experienced the same physical deterioration as his untreated sibling.563 Twins experienced less neurodevelopmental decline compared to untreated brothers who were wheelchair-bound by the time they reached the age of the twins.564

Evidence for this disease with a life expectancy into the second decade consists of two case reports and two case series.553, 561, 562, 564 HSCT did not alter the neurocognitive decline but may have had some effect on the neurodevelopmental decline in two patients. Although the numbers are small, HSCT does not appear to benefit MPS III.

##### Morquio Syndrome (Mucopolysaccharidosis Type IV)

Morquio Syndrome is an autosomal recessive disorder with an estimated incidence of 1 in 200,000 births.565 There are two types, differentiated by which enzyme needed to degrade keratin sulfate is deficient (Type A: N-acetylgalactosamine 6-sulfatase, and Type B: β-galactosidase). Type A is the more severe form. Onset of symptoms occurs around 2 years of age. In most cases, normal intelligence is preserved.263 Life expectancy can extend into the third or fourth decade of life with the more severe form, while those with the milder form have been reported to live decades longer.264 Common causes of death include myelopathy, restrictive chest wall movement, and valvular heart disease.565 Spinal fusion to stabilize the upper cervical spine and prevent irreversible spinal cord injury can be a life-saving treatment for MPS IV patients. HSCT has been attempted on two MPS IV patients (Table 97).558, 566

Table 97 Study characteristics and population for mucopolysaccharidosis IV (Morquio syndrome)

Study | Design | Median Age, Yrs (Range) at Treatment | Sex (M%) | Treatment, Year | Followup Period (yrs) | Enzyme Activity | Neuro-cognitive Outcomes | Neuro-developmental Outcomes | Adverse Effects
Seto, Japan, 2001^558^ | case series (n=1)^*^ | 15.0 | 100 | HSCT, NR | 7.0 | NR | NR | NR | NR
Gatzoulis, England, 1995^566^ | case series (n=1)^*^ | 5.25 | 100 | HSCT, NR | 2.5 (mean for series) | NR | NR | NR | NR

* This case series combined several diseases in one study and only 1 pt in the series had this disease.

Refer to Appendix E Table E2 for details of neurocognitive and neurodevelopmental outcomes. In summary, one patient was 15 years old at the time of transplant and a pretransplant MRI showed no pathological findings in the brain or spinal cord. The patient had mild bone deformities at the time of transplant, and there was no followup for this patient.558 From echocardiograph, aortic stenosis and left ventricular dilatation were detected in one patient prior to HSCT. There was no change in cardiac symptoms after HSCT.566

Evidence for this disease with a life expectancy that varies from adolescence into adulthood, is based on two cases of HSCT found in the literature. The reports did not provide any post transplant neurocognitive or neurodevelopmental followup data.

##### Fabry Disease

Fabry disease is an X-linked recessive disorder characterized by decreased activity of α-galactosidase A. The prevalence is estimated at 1/40,000-60,000 males.526 The onset of symptoms and the severity of the disease vary widely. Males may exhibit symptoms in childhood or adolescence, or remain asymptomatic into adulthood. Female carriers may be asymptomatic or have symptoms as severe as affected males.526 Pain episodes, called Fabry pain crises, consist of burning, tingling, and numbness in the hands and feet, and can last several hours to days.261 Decline in kidney function in early adulthood is the main cause of premature death in Fabry disease. Cardiovascular disease is also a cause of premature death, with hypertension, mitral valve prolapse, or congestive heart failure occurring.261

Renal transplantation and long-term hemodialysis have prolonged life in Fabry's disease patients, and enzyme-replacement therapy using recombinant alpha-galatosidase has been shown to be safe and effective.261

##### Gaucher Disease Type III

Gaucher disease is caused by a deficiency in the enzyme glucocerebrosidase, which leads to an accumulation of glucosylceramide in the spleen, liver, lungs, bone marrow, and sometimes the brain.261 There are three types of Gaucher disease. Gaucher Type I is discussed in the Narrative Review section. Gaucher Type II is discussed in the Systematic Review under diseases with rapid progression.

Gaucher Type III is the subacute neuronopathic form, usually beginning later in childhood or adolescence, with loss of muscle coordination and cognitive deterioration progressing more slowly than in Type II.261 Gaucher Type III patients may live into adulthood. Enzyme replacement therapy can be used to alleviate severe visceral symptoms, but is not effective in altering the neurologic progression of the disease.261 Combinations of enzyme replacement therapy using recombinant imiglucerase or velaglucerase, substrate reduction therapy using miglustat, and HSCT have been attempted in Type III Gaucher patients (Table 98).

Table 98 Study characteristics and population for Gaucher Type III

Study | Design | Median Age in Years (range) at Treatment | Sex (M%) | Treatment, Year | Followup Period (yrs) | Enzyme Activity | Neuro-cognitive Outcomes | Neuro-developmental Outcomes | Adverse Effects
Goker-Alpan, US, 2008^567^ | case series, N=32 | 1.3^*^ | 53 | HSCT followed by ERT (n=2), NR; ERT only (n=30), NR | 3-33 | NR | ✓ | NR | NR
Chen, Taiwan, 2007^568^ | case report | 5.8 | 0 | HSCT, 2004 | 1.5 | ✓ | ✓ | ✓ | ✓
Ringden, Sweden, 1995^303^ | case series, N=6 | 2.5 | 67 | HSCT | 5-11 | ✓ | ✓ | ✓ | ✓
Tsai, US, 1992^569^ | case report | 2.0 | 0 | HSCT | 2 | ✓ | ✓ | ✓ | ✓
Schiffman, Netherlands 2008^570^ | Randomized control-led trial (N=30) | substrate reduction therapy (n=21), mean: 10.4 no treatment (n=9) mean: 9.9 | substrate reduction therapy (n=21): 48 no treatment (n=9): 22 | Substrate reduction therapy in combination with ERT, NR | 2.0 | NR | ✓ | ✓ | NR
El-Beshlawy, Egypt, 2006^571^ | case series (n=11) | mean: 6.14 range (1-16), this data is on the whole study population of 22 pts, which includes 11 with Gaucher Type I | NR | ERT, NR | 0.4-2.2 | ✓ | NR | ✓ | ✓
Chan, Malaysia, 2002^572^ | case report | 7.6 | 0 | ERT, 1996-1998 | 4.5 | NR | ✓ | ✓ | NR
Banjar, Saudi Arabia, 1998^573^ | case series (n=3) | 2.8 (2.0-3.0) | 33 | ERT, NR | 2.5-3.5 | NR | NR | ✓ | NR
Schiffmann, Netherlands, 1997^574^ | case series (N=5) | 7.5 (3.5-8.5) | 80 | ERT, NR | up to 5 yrs | ✓ | ✓ | NR | NR
Erikson, Sweden, 1995^575^ | case series (n=3) | 4.8 (3.8-13.7) | 33 | ERT, NR | 2.3 yrs | ✓ | ✓ | ✓ | NR

* Age at diagnosis.

Refer to Appendix E Table E2 for details of neurocognitive and neurodevelopmental outcomes. In summary, among eight patients undergoing HSCT (two case reports and one case series of 6 patients), five showed stable neurocognitive scores.561, 569 All eight patients showed improved growth, although skeletal symptoms persisted.561, 568, 569 A case series that included two patients that had HSCT followed by enzyme-replacement therapy, report only followup data.567 Both patients have borderline mental retardation at last followup, but the mental status prior to HSCT and enzyme-replacement therapy is not specified.

Of 23 Gaucher Type III patients treated with enzyme-replacement therapy, neurocognitive followup is available on nine patients. Seven of the nine patients showed stable neurocognitive function,574, 575 one deteriorated clinically,574 and one who was showing improvement following enzyme-replacement therapy, deteriorated when therapy was discontinued.572 Enzyme-replacement therapy improves growth, but cannot change skeletal deformities. In the enzyme-replacement therapy case series of 11 patients for which grading severity of marrow involvement was provided, one worsened, five remained constant, and five experienced complete improvement.571 In a 2-year randomized controlled trial of substrate reduction therapy (miglustat) with enzyme-replacement therapy (imiglucerase; n=21) compared to enzyme-replacement therapy alone (n=9), there was no significant difference between study groups using several neurocognitive measurements.570

Evidence for HSCT for the treatment of Gaucher Type III which has a life expectancy extending into adulthood, consists of two case reports and two case series. In one case series, HSCT was followed by enzyme-replacement therapy. Among the patients who were treated with HSCT only, five of eight had stable neurocognitive scores at last followup. Among patients treated with enzyme-replacement therapy only, seven of nine had stable neurocognitive scores at last followup. Patients undergoing HSCT and patients treated with enzyme-replacement therapy have shown improved growth, although skeletal symptoms persist. HSCT appears to have a similar benefit compared to enzyme-replacement therapy.

##### Aspartylglucosaminuria

Aspartylglucosaminuria is a rare autosomal recessive disease characterized by a deficiency in the enzyme aspartylglucosaminidase, leading to an accumulation of glycoproteins in the liver, spleen, and thyroid. There is a higher prevalence of this disease in Finland, where the carrier frequency is estimated to be 1 in 36^576^ and the estimated incidence of the disease is 1 in 35,000. The estimated incidence outside of Finland is 1 in 2,000,000 births.

In the first year of life, recurrent infections, diarrhea, and hernia may occur. During adolescence, the intellectual disabilities worsen. The central nervous system is affected. Survival to mid-adulthood is expected, with most deaths attributed to pneumonia or other pulmonary complications.576 Anticonvulsant medications have been used to control seizures. HSCT has been attempted as a potential treatment of this disease (Table 99).

Table 99 Study characteristics and population for aspartylglucosaminuria

Study | Design | Median Age in Years (Range) at Treatment | Sex (M%) | Treatment, Year | Followup Period (yrs) | Enzyme Activity | Neuro-cognitive Outcomes | Neuro-developmental Outcomes | Adverse Effects
Malm, Sweden, 2004^577^ | case series (N=2) | 8.1 (5.8-10.4) | 50 | HSCT, 1996 | 5.0 | ✓ | ✓ | ✓ | ✓
Arvio, Finland, 2001^578^ | comparative study (n=5) | 2.75 (1.6-5.5) | 40 | HSCT, 1991-1997 | 1.0-7.6 | NR | ✓ | ✓ | ✓
Autti, Finland, 1999^579^ | comparative study (n=2) | 2.3 (2.0-2.6) | 100 | HSCT, NR | 4.0-7.0 | ✓ | ✓ | NR | NR
Laitinen, Finland, 1997^580^ | case report | 1.5 | 100 | HSCT, NR | 0.33 | ✓ | NR | NR | NR

Refer to Appendix E Table E2 for details of neurocognitive and neurodevelopmental outcomes. In summary, there were no reports of treatment-related mortality in the 10 patients undergoing HSCT. Of 10 patients with aspartylglucosaminuria undergoing HSCT, there is neurocognitive followup on nine. Two patients have improved concentration and cooperation.579 Two patients have stabilized developmentally at 5 years of age (real ages 15 and 11 years), and can speak in sentences and understand words in two languages.577 Five patients had, on average, lower developmental ages compared to 12 untreated patients, but direct comparisons may not be appropriate because the severity of disease differs widely in this disease. Two of the five transplanted patients were more severely retarded than any of the nontransplanted patients, potentially skewing the average age differential higher in the transplanted group.578

Evidence for aspartylglucosaminuria which has a life expectancy into mid-adulthood, consists of one case report and three case series, with a total of 10 transplants. Neurocognitive and neurodevelopmental measurements did not show clear improvements following HSCT. Small numbers in studies, and differences in severity of disease make interpretations of results difficult.

##### ß-Mannosidosis

ß-mannosidosis is a rare autosomal recessive disorder caused by a deficiency in the enzyme ß-mannosidase, resulting in the accumulation of oligosaccarides in lysosomes. Twenty cases have been identified worldwide, but the incidence may be higher because people with milder symptoms may never be diagnosed.

The onset of symptoms varies from infancy to adolescence, and the severity of symptoms varies from relatively mild to moderately severe.581 Mental retardation is present in all individuals with this disease. There is no cure for ß-mannosidosis and treatment is symptom-specific.

No reports of HSCT for ß-mannosidosis patients have been found.

##### Mucolipidosis III (Pseudo-Hurler Polydystrophy)

Mucolipidosis III is a rare autosomal recessive disorder caused by a deficiency of the enzyme, N-acetylglucosamine-1-phosphotransferase. A defect of this enzyme affects the function of all lysosomal enzymes, which in turn causes the accumulation of a variety of substrates.535

Symptoms present between the ages of 4 to 5 years and include joint stiffness and short stature. Survival to adulthood is expected. There is no cure and treatment is symptom-specific, and may include: low-impact physical therapy for stiff joints, myringotomy tube placement for recurrent otitis media, tendon release for carpal tunnel syndrome, bilateral hip replacement for older adolescents with milder disease, and monthly bisphosphonate pamidronate IV for bone pain associated with osteoporosis.

No reports of HSCT for mucolipidosis III have been found.

##### Mucolipidosis IV

Mucolipidosis IV is a rare autosomal recessive disorder caused by a defect in the protein mucolipin-1, which is needed in the transport of lipids and proteins. This defect results in the build-up of lipids and proteins in lysosomes, affecting the development and maintenance of the brain and retinas.582 An estimated 1 in 40,000 have mucolipidosis IV, with 70 percent having Ashkenazi Jewish ancestry.

There is a severe and more common form called typical mucolipidosis IV (about 95 percent) and a milder form called atypical mucolipidosis IV. In the severe form, mental and motor developmental delays occur within the first year of life. Most are unable to walk independently. Those with the milder form have less severe psychomotor and ophthalmic symptoms, and may be ambulatory. Life expectancy extends to adulthood, though a shorter life span is expected.582

Treatment is symptom-specific and may include: physical therapy for spasticity and ataxia, antiepileptic drugs, topical lubricating eyedrops, artificial tears, gels, or ointments for ocular irritation, and surgery for strabismus.

There are no reports of HSCT attempted in patients with mucolipidosis IV.

##### Niemann-Pick Disease C

Niemann-Pick disease is characterized by the accumulation of lipids in the spleen, liver, lungs, bone marrow, and the brain. There are three types of this disease. Type A is discussed in the “Sphingolipidoses” section of this Systematic Review and Type B is discussed in the Narrative Review section. The incidence of Type C is estimated to be 1 in 150,000 and is most common in Nova Scotia among those of French-Acadian descent.523

Prolonged neonatal jaundice may occur, with no other symptoms until 1-2 years later or potentially until teen or adult years, when the disease develops a slow, progressive neurodegenerative course.261 Death may occur in the late second or third decade of life, commonly from aspiration pneumonia. Management of this disease is symptom-specific for seizures, dystonia, and cataplexy, and may include chest physical therapy with aggressive bronchodilation and antibiotics for recurrent infections and seizure management. A randomized controlled study using substrate reduction therapy versus standard care has been conducted, and there are two case reports of HSCT to treat this disease (Table 100).

Table 100 Study characteristics and population for Niemann-Pick Type C

Study | Design | Median Age in Years (Range) at Treatment | Sex (M%) | Treatment, Year | Followup Period (yrs) | Enzyme Activity | Neuro-cognitive Outcomes | Neuro-develop-mental Outcomes | Adverse Effects
Bonney, England, 2009^583^ | case report | 1.3 | 100 | HSCT, NR | 1.7 | NR | ✓ | ✓ | ✓
Hsu, Taiwan, 1999^584^ | case report | 2.5 | 0 | HSCT, NR | 0.8 | NR | ✓ | ✓ | ✓
Patterson, US, 2010^585^ | open label extension (n=12) | Mean: 7.2 (4-11) | 42 | substrate reduction therapy, 2002-2004 | 2.0 | NR | NR | NR | ✓
Pineda, Spain, 2009^586^ | retrospective cohort (n=66)^*^ | Mean: 12.8 (0.6-43.0) | 47 | substrate reduction therapy, NR | 5.0 | NR | ✓ | ✓ | NR
Paciorkowski, US, 2008^587^ | case report | 1.6 | 0 | substrate reduction therapy, NR | 1.0 | NR | ✓ | ✓ | ✓
Patterson, US, 2007^588^ | RCT (n=12)^*^ | Mean: 7.2 (4-11) | 42 | substrate reduction therapy, 2002-2004 | 1.0 | NR | ✓ | ✓ | ✓

* Cannot separate adult and pediatric data in these studies.

Refer to Appendix E Table E2 for details of neurocognitive and neurodevelopmental outcomes. In summary, results from one case report of a patient with Niemann-Pick Type C undergoing HSCT showed that the transplant did not stop a progressive decline in developmental age, and an MRI confirmed brain atrophy. The patient became bedridden during the conditioning phase of the treatment. She never recovered developmentally following the transplant.584 The second case of HSCT showed a resolution of lung disease in the patient, and normal neurocognitive and neurodevelopmental progress, except for delayed speech.583 An abstract referenced in the most recent report of HSCT583 describes the resolution of lung disease in a Niemann-Pick Type C transplanted patient at 2 months post-transplant, but the patient died 3 months post-transplant of an adenovirus pulmonary infection.

Results from the randomized, controlled trial comparing substrate reduction therapy to routine symptom management and the retrospective cohort of substrate reduction therapy for Niemann-Pick Type C combined data for pediatric and adult patients.586, 588 The randomized, controlled trial did not find a significant difference in the mini-mental status examination (p=0.165) but found significantly improved ambulatory indexes in the treated group588 and the cohort study reported majority stable or improved scores in ambulation.586 The open-label extension study, which focused on pediatric patients, reported that eight of ten patients were stable in ambulation.585

Evidence for HSCT and Niemann-Pick Type C which has a life expectancy into the second to third decade, consists of two case reports. HSCT for one patient was not successful in stopping the neurocognitive and neurodevelopmental decline. One HSCT patient is developing normally at 1.7 years post-transplant. Based on two case reports, it is unclear if HSCT provides a benefit in the treatment of Niemann-Pick Type C.

##### Glycogen Storage Disease Type 2 (Pompe Disease)

Pompe disease is an autosomal recessive disorder caused by a deficiency in acid maltase, which results in the accumulation of lysosomal glycogen in tissues and cells. Cardiac, skeletal, and smooth muscle cells are the most seriously affected.589 The incidence is estimated at 1 in 40,000 live births. Age of onset and severity of symptoms varies among patients.

In infantile-onset Pompe disease, symptoms begin within the first few months of life and life expectancy is less than one year, with cause of death usually from cardiorespiratory failure or respiratory infection. The juvenile and adult-onset forms of the disease have either no or less severe cardiac involvement. Life expectancy ranges from early childhood to late adulthood, depending on the rate of disease progression. Respiratory failure is the most common cause of death.589 Several clinical trials of enzyme-replacement therapy in patients with infantile-onset Pompe disease have shown promising cardiac responses and variable skeletal responses to the treatment.590, 591

There have been no reports of HSCT in the treatment of Pompe disease.

##### Salla Disease

Salla disease is a type of sialic acid storage disease, which is a rare autosomal disorder caused by the accumulation of free sialic acid in lysosomes, due to a defect in the lysosomal membrane transport system.541 Salla disease is autosomal recessive. One hundred twenty Salla disease cases have been reported. Patients appear normal at birth, then develop psychomotor delay and ataxia during infancy, as dysmyelination of the brain occurs. Life expectancy is slightly reduced.541 Disease management is symptom-specific.

There are no reports of HSCT used to treat Salla disease.

##### Adrenomyeloneuropathy

Adrenomyeloneuropathy is a variant of the X-linked recessive disorder, adrenoleukodystrophy, which is discussed in the Narrative Review section of this report. These disorders are caused by the accumulation of very long chain fatty acids in the brain and adrenal cortex, due to a deficiency in the enzyme that breaks down fatty acids.592 About 40 percent of males with adrenoleukodystrophy develop adrenomyeloneuropathy, which presents in their late twenties as a chronic disorder of the spinal cord and peripheral nerves.593 The severity of symptoms varies greatly, even within one family. Depending on the severity of symptoms, life expectancy can reach late adulthood, though ambulation with a cane or walker may be necessary. HSCT has been shown to prevent the progression of symptoms in adrenoleukodystrophy if performed prior to the development of neurological symptoms.

A single case of HSCT for a 39-year-old male with adrenomyeloneuropathy was found in the literature.561 No pediatric cases treated with HSCT have been reported.

#### Diseases With Forms That Progress Rapidly and Slowly

##### Farber Disease

Farber disease is an autosomal recessive disorder characterized by a deficiency in ceramidase, resulting in the accumulation of ceramide in various tissues, the central nervous system, and most notably the joints. Fifty cases of this disease have been reported in the literature.594

Symptoms can begin in the first few weeks of life.261 Nodules forming on the vocal cords cause hoarseness and breathing difficulties, which sometimes require the insertion of a breathing tube. Life expectancy in Type 1, the more severe form which has central nervous system involvement, is 2 years of age with progressive neurological deterioration as cause of death. Patients with the milder form, Type 2/3 with either no or mild central nervous system symptoms, can live to their teenage years with chronic respiratory failure as the most common cause of death.595

Physical therapy or surgery may provide relief of contractures, and surgery to remove nodules, granulomas, and possibly enlarged lymph nodes may be recommended. Hematopoietic stem-cell transplantation has been attempted in two patients with Type 1 Farber and in five patients with Type 2/3 Farber (Table 101).

Table 101 Study characteristics and population for Farber's disease

Study | Design | Median Age in Years (Range) at Treatment | Sex (M%) | Treatment, Year | Followup Period (yrs) | Enzyme Activity | Neuro-cognitive Outcomes | Neuro-developmental Outcomes | Adverse Effects
Ehlert, Germany, 2006^596^ | case series (n=3) | 3.8 (2.0-3.9) | 33 | HSCT, NR | 0.5-1.2 | NR | NR | ✓ | ✓
Vormoor, Germany, 2004^597^ | case series (n=2) | 3.9 (3.8-3.9) | 50 | HSCT, NR | 0.9-1.2 | NR | NR | ✓ | ✓
Yeager, US, 2000^598^ | case report | 0.8 | 0 | HSCT, NR | 2.3 | ✓ | ✓ | ✓ | ✓
Hoogerbrugge, Netherlands, 1995^553^ | case series (n=1)^*^ | 1.5 | NR | HSCT, NR | 0.5 | NR | ✓ | ✓ | NR

* This case series combined several diseases in one study and only 1 pt in the series had this disease.

Refer to Appendix E, Table E3 for details of neurocognitive and neurodevelopmental outcomes. In summary, no treatment-related mortality was reported in the seven patients with Farber disease undergoing HSCT. There is neurocognitive followup on the two patients with Type 1 Farber disease with CNS involvement. In one patient at the time of transplant, her developmental age was equivalent to her real age. After 1.4 years followup, at age 2.1 years, her developmental age had deteriorated to 0.6 years.598 The second Type I patient had mental regression prior to the transplant, which worsened following the transplant. This patient died 6 months post-transplant of disease progression.553 No neurocognitive followup was provided for the five Farber disease patients who had Type 2 disease, which has little or no CNS involvement.

The five patients reported in the case series on Farber Type 2/3 had nodule and joint inflammation. HSCT was successful in reducing the number of subcutaneous nodules and reducing the number of joints with limited range of motion in five of five patients.596, 597

Evidence for Type 1 Farber disease with CNS involvement and a life expectancy of 2 years, consists of one case report and one case series. HSCT did not stop the neurocognitive deterioration in these patients. Evidence for Type 2 Farber disease without CNS involvement and a life expectancy extending into the second decade, consists of two case series. In all five patients with Farber Type 2/3 undergoing HSCT, both the number of subcutaneous nodules and the number of joints with limited range of motion were reduced. Based on these five patients, HSCT appears to improve the quality of life of patients with Farber Type 2/3.

##### GM1 Gangliosidosis

GM_1_ gangliosidosis is an autosomal recessive disorder caused by a deficiency in ß-galactosidase. There are three subtypes, classified by age at presentation: infantile (type 1), juvenile (type 2), and adult (type 3). Estimated incidence is 1 in 100,000-200,000 live births.599 The infantile form, which can present as early as six months, is characterized by overall developmental retardation and generalized seizures. Survival is 2-4 years, with death most commonly due to aspiration pneumonia. Symptoms in the juvenile form begin around 1 year and are primarily neurological. Progression of this form of the disease is slow, and survival through the fourth decade of life is possible. The adult form is a slowly progressive disease characterized by spasticity, ataxia, dysarthria, and loss of cognitive function.600

Research in the areas of enzyme replacement therapy and gene therapy for this disease are ongoing, but have not advanced to human trials.599 A case report describes the use of HSCT to treat a patient with the juvenile form of the disease (Table 102).

Table 102 Study characteristics and population for GM_1_ gangliosidosis

Study | Design | Median Age in Years (Range) at Treatment | Sex (M%) | Treatment, Year | Followup Period (yrs) | Enzyme Activity | Neuro-cognitive Outcomes | Neuro-developmental Outcomes | Adverse Effects
Shield, England, 2005^601^ | case report | 0.6 | 100 | HSCT, NR | 7 | ✓ | ✓ | ✓ | NR

Refer to Appendix E, Table E3 for details of neurocognitive and neurodevelopmental outcomes. In summary, a case report of a patient with GM_1_ gangliosidosis juvenile form describes a slow deterioration in neurocognitive and neurodevelopmental measurements.601

There have been no reports of HSCT for the infantile form of GM_1_ gangliosidosis, which has a life expectancy of 2 to 4 years. Evidence for the juvenile form of GM_1_ gangliosidosis, which has a life expectancy extending into the second through fourth decade, consists of 1 case report. Based on this case report, HSCT did not alter the course of the disease.

##### Tay-Sachs Disease

Tay-Sachs disease is an autosomal recessive disorder caused by a deficiency in the isoenzyme hexosaminidase A, resulting in the accumulation of GM_2_ ganglioside in the brain. The Ashkenazi Jewish population is most at risk, with a carrier rate estimated at 1 in 30.^600^ There are infantile-, juvenile-, and adult-onset forms of the disease. In the infantile form, patients have no hexosaminidase A enzyme and in the juvenile and adult forms, patients have low levels of hexosaminidase A enzyme. The infantile form is the most severe, and other than a marked startle reaction to noise, infants appear normal until about 6 months of age when developmental delays begin. Life expectancy is 4 to 5 years, with aspiration or bronchopneumonia the most common causes of death.261 The juvenile and adult forms are rare and symptoms are less severe.

Anticonvulsant medication to control seizures, proper hydration to keep airways open, and feeding tubes to provide nutritional supplements have been recommended. HSCT, substrate reduction therapy, and a combination of both, have been attempted on several Tay-Sachs disease patients (Table 103).

Table 103 Study characteristics and population for Tay-Sachs disease

Study | Design | Median Age in Years (Range) at Treatment | Sex (M%) | Treatment, Year | Followup Period (yrs) | Enzyme Activity | Neuro-cognitive Outcomes | Neuro-developmental Outcomes | Adverse Effects
Page, US, 2008^556^ | case series (n=1)^*^ | 0.06 | NR | HSCT, 1998-2007 for whole series | 4.6 | NR | NR | NR | ✓
Hooger-brugge, Netherlands,1995^553^ | case series (n=1)^*^ | 1.1 | NR | HSCT, NR | 1.7 | NR | ✓ | ✓ | NR
Jacobs, Netherlands, 2005^602^ | case report | 3.8 | 0 | HSCT, with substrate reduction therapy added at 2 yrs post-HSCT, NR | 2.0 | ✓ | ✓ | ✓ | NR
Maegawa, Canada, 2009^603^ | single arm (n=2) | 13.1 (10.1-16.0) | 0 | substrate reduction therapy, NR | 2.0 | NR | ✓ | ✓ | ✓

* This case series combined several diseases in one study and only 1 pt in the series had this disease.

Refer to Appendix E, Table E3 for details of neurocognitive and neurodevelopmental outcomes. Two case series of HSCT to treat several different diseases included one patient with Tay-Sachs in each series (disease form not specified). One patient died at 4.6 years post-transplant of a possible infection.556 The other patient had psychomotor retardation at the time of transplant and further regressed to a vegetative state at 1.7 years' followup.553

The case report602 was of a patient with the juvenile form of Tay-Sachs. In the case report, brain MRI, EEG, and neuropsychological tests showed neurological deterioration at 1.5 years post-transplant. At that time, substrate reduction therapy was initiated, but was not successful in stopping the deterioration. Neurodevelopmental followup in this case report showed motor skills deteriorating by 0.5 years post-transplant in this patient; her deterioration was comparable to her untreated sister's.

Among the two patients with the juvenile form who were treated with substrate reduction therapy,603 one who had mild cognitive impairment pretreatment experienced an acute psychotic event at 1.3 years post-treatment, and one who had severe cognitive impairment pretreatment had increased spasticity and seizures post-treatment. The 2 Tay-Sachs disease patients with the juvenile form of the disease who were treated with substrate reduction therapy, continued to have neurodevelopmental decline following the treatment.

Evidence for the juvenile form of Tay-Sachs disease which has a life expectancy of 15 years, consists of one case report. The patient continued to show neurocognitive and neurodevelopmental decline similar to what was experienced in the untreated sibling. Based on this case report, HSCT does not show a benefit in the treatment of the juvenile form of Tay-Sachs disease.

##### Ceroid Lipofuscinosis

Neuronal ceroid lipofuscinoses are autosomal recessive disorders which are the most common class of neurodegenerative diseases in children.600 A defect in the enzyme that degrades fatty acylated proteins causes the storage of autofluorescent lipopigments in lysosomes.604 Worldwide incidence of this disease is estimated at 1 in 20,000-100,000, but the incidence is higher in Finland.600

Depending on which gene is affected, symptoms may begin during early infancy, late infancy, or during juvenile years. Symptoms develop by the end of age 1 in the early infantile form with life expectancy from 6 to 13 years. In the late infantile form, symptoms begin from 2 to 4 years of age, with a life expectancy extending from 6 to 40 years. In the juvenile form, symptoms begin between 5 to 10 years of age with a life expectancy from teens to thirties.600

There is no cure for these disorders and treatment is symptom-specific: antiepileptic drugs and benzodiazepines for seizures, anxiety, and spasticity, gastric tubes for swallowing problems, and antidepressants and antipsychotic agents for patients with the juvenile form. HSCT has been performed in several patients with the early infantile form of the disease (Table 104).

Table 104 Study characteristics and population for ceroid lipofucinosis

Study | Design | Median Age in Years (Range) at Treatment | Sex (M%) | Treatment, Year | Followup Period (yrs) | Enzyme Activity | Neuro-cognitive Outcomes | Neuro-developmental Outcomes | Adverse Effects
Lonnqvist, Finland, 2001^605^ | case series (n=3) | 0.3 (0.3-0.6) | 33.3 | HSCT, 1996-1998 | 2-4 | ✓ | ✓ | ✓ | NR

Refer to Appendix E, Table E3 for details of neurocognitive and neurodevelopmental outcomes. Neurocognitive decline continued in three of three patients with ceroid lipofuscinosis with the infantile form undergoing HSCT, as measured by cerebral cortical atrophy and periventricular white matter hyperintensity. HSCT did not prevent the neurodevelopmental decline in the three patients with infantile ceroid lipofuscinosis. By followup of 2 to 4 years, all three were hypotonic and spastic.

Evidence for this disease which has a life expectancy of 6-13 years, consists of one case series of three patients. The procedure was unable to stop the neurocognitive and neurodevelopmental decline in all three patients. Based on this case series, HSCT does not show a benefit of HSCT for the treatment of infantile ceroid lipofuscinosis.

##### Galactosialidosis

Galactosialidosis is a rare autosomal recessive condition in which there is a deficiency of two lysosomal enzymes, neuraminidase and β-galactosidase. This enzyme deficiency causes the accumulation of oligosaccharides in many tissues such as the liver, bone marrow, and brain.576 There are three forms which differ by age of onset of symptoms and symptom severity. One-hundred cases have been reported, with 60 percent of the juvenile/adult forms in patients of Japanese descent.606

In the early infantile form, fluid accumulation begins before birth. Life expectancy does not extend beyond late infancy, with kidney failure or cardiomegaly as common causes of death. Symptoms in the late infantile form of the disease are similar to those in the early infantile form, though less severe and the onset is later in the first year of life. Life expectancy can extend into the second decade of life, depending on severity of symptoms. The juvenile/adult form of the disease is least severe, with symptoms first occurring usually in the teen years. There is no cure for galactosialidosis and treatment is symptom specific.

A retrospective study of 81 patients in the Japan Marrow Donor Program who underwent unrelated bone marrow transplantations for immunodeficiency and metabolic diseases reported a single case of galactosialidosis within its study population.525 The form of galactosialidosis was not specified in the report. Outcomes were cumulative overall and event-free survival, and cumulative acute and chronic graft-versus-host disease. Engraftment occurred in the galactosialidosis case, but no other information on that case could be separated from the aggregate data.

##### Sandhoff's Disease

Sandhoff's disease is caused by a deficiency in both hexosaminidase A and B, resulting in the accumulation of GM_2_ ganglioside in lysosomes. Symptoms are similar to those in Tay-Sachs disease, presenting at about 6 months of age. Life expectancy is 3 years of age.600 Symptom management includes anticonvulsant medication to control seizures, and proper hydration and nutrition to keep airways open.

A case of a patient with Sandhoff's disease undergoing HSCT is reported in the literature, but the form of the disease is not specified (Table 105). There is also a single arm study reporting the use of substrate reduction therapy in 3 patients with Sandhoff's disease (juvenile form).

Table 105 Study characteristics and population for Sandhoff's disease

Study | Design | Median Age in Years (Range) at Treatment | Sex (M%) | Treatment, Year | Followup Period (yrs) | Enzyme Activity | Neuro-cognitive Outcomes | Neuro-developmental Outcomes | Adverse Effects
Ringden, Sweden, 2006^561^ | case series (n=1)^*^ | NR | NR | HSCT, NR | 0.4-14 (for whole series) | NR | NR | NR | ✓
Maegawa, Canada, 2009^603^ | single arm (n=3) | 18 (8.7-20.1) | 67 | Substrate reduction therapy, NR | 2.0 | NR | ✓ | ✓ | ✓

* This case series combined several diseases in one study and only 1 pt in the series had this disease.

Refer to Appendix E, Table E3 for details of neurocognitive and neurodevelopmental outcomes. In summary, there is no neurocognitive or neurodevelopmental information in the patient with Sandhoff's disease (form unspecified) who underwent HSCT. The three patients with Sandhoff's disease who were treated with substrate reduction therapy experienced stable neurocognitive scores, but neurodevelopmental decline occurred.603 One became wheelchair dependent by 1.8 years post-treatment, and two had gait disturbance.

Evidence for Sandhoff's disease consists of one case report. The report did not specify if the patient had the infantile form or the juvenile form of the disease. No neurocognitive or neurodevelopmental followup information on the single Sandhoff's disease patient was provided; no conclusions on effectiveness can be made.

##### Adverse Effects

Table 106 summarizes the adverse effects reported in patients undergoing HSCT for inherited metabolic disorders.

Table 106 Adverse effects for treatment (HSCT) in IMD patients

Progression of Disease | Adverse Effect | Description | Disease | Study
Rapid | Treatment-related mortality | - unknown cause, probable infection at 4.6 yrs post | Tay-Sachs | Page, 2008^556^
Rapid | Treatment-related mortality | 2 of 4 pts in study:; - pt 2: at 2.5 mos post, hepatorenal failure, pulmonary failure, coagulopathy, sepsis; - pt 3: at 8 mos post, sepsis and liver | Wolman disease | Tolar, 2009^531^
Rapid | aGVHD | - grade 3 skin and liver in 2 of 4 pts; - grade 3 skin in 1 of 4 pts | Wolman disease | Tolar, 2009^531^
Rapid | aGVHD | - grade 3 skin and gut in 1 of 1 pt | Wolman disease | Styczynski, 2011^530^
Rapid | aGVHD | - grade 2 in 1 of 1 pt | Tay-Sachs | Page, 2008^556^
Rapid | aGVHD | - skin rash in 1 of 1 pt | Niemann-Pick Type A | Morel, 2007^533^
Rapid | aGVHD | - mild skin rash in 1 of 1 pt | Wolman disease | Stein, 2007^529^
Rapid | aGVHD | - grade 2, skin in 1 of 1 pt | Mucolipidosis II | Li, 2004 536
Rapid | aGVHD | - grade 2, gastrointestinal | Mucolipidosis II | Grewal, 2003^537^
Rapid | aGVHD | - moderately severe diarrhea in 1 of 2 pts | Niemann-Pick Type A | Bayever,1995 534
Rapid | cGVHD | - skin, in 1 of 1 pt | Mucolipidosis II | Li, 2004^536^
Rapid | cGVHD | - gastrointestinal, in 1 of 2 pts | Niemann-Pick Type A | Bayever, 1995^534^
Rapid | Infectious complications | - candida parapsilosis sepsis in 1/1 pt | Wolman disease | Gramatges, 2009^527^
Rapid | Infectious complications | - sepsis in 2 of 4 pts | Wolman disease | Tolar, 2009^531^
Rapid | Infectious complications | - cytomegalovirus and anigenemia in 1 of 1 pt | Wolman disease | Stein, 2007^529^
Rapid | Infectious complications | - coagulase-negative staphylococcus septicemia in 1 of 1 pt | Mucolipidosis II | Li, 2004 536
Slow | Treatment-related mortality | - single pt had post-tx lymphoproliferative disease at 0.8 yrs post-HSCT | MPS II | Tokimasa 2008^557^
Slow | Treatment-related mortality | - 4 of 9 pts died <100 days post-HSCT, 2 from sepsis and 2 from aGVHD; - 1 pt died 4 yrs post-HSCT from tx-related obliterative bronchiolitis; - 1 pt died of GVHD, at an unknown followup time | MPS II | Vellodi 1999^549^
Slow | Treatment-related mortality | - 1 of 2 died mos post-HSCT of pneumonia | MPS III | Ringden, 2006^561^
Slow | Treatment-related mortality | - 1 of 1 pt died of S. pneumonia sepsis at 2 yrs post | Gaucher Type III | Tsai, 1992^569^
Slow | aGVHD | - grade 1 skin in 1 of 1 pt | Niemann-Pick Type C | Bonney, 2009^583^
Slow | aGVHD | - grade 1 in 1 of 1 pt | MPS II | Tokimasa 2008^557^
Slow | aGVHD | - Grade 3 skin and Grade 2 gastrointestinal aGVHD at 2 wks post-HSCT and a skin rash at 17 wks post-HSCT in 1 of 1 pt | MPS II | Mullen 2000^559^
Slow | aGVHD | - moderate aGVHD in 1 of 3 surviving pts | MPS II | Vellodi 1999^549^
Slow | aGVHD | - grade 1 in 1 of 2 pts; - grade 2 in 1 of 2 pts | Farber's disease, Type 2/3 | Vormoor, 2004^597^
Slow | aGVHD | - grade 1 in 1 of 3 pts; - grade 2 in 2 of 3 pts | Farber's disease, Type 2/3 | Ehlert, 2006^596^
Slow | aGVHD | - Gr 1 mild skin rash in 1 of 1 pt | Gaucher Type III | Chen, 2007^568^
Slow | aGVHD | - severe skin, gastrointestinal, and liver aGVHD in 1 of 2 pts; - grade 1 skin aGVHD in 1 of 2 pts | aspartylglucosa-minuria | Malm, 2004^577^
Slow | aGVHD | - grade 1 in 1 of 1 pt | Niemann-Pick Type C | Hsu, 1999^584^
Slow | aGVHD | - severe in 2 of 2 pts | MPS III | Vellodi, 1992^564^
Slow | cGVHD | - severe hemolytic anemia at 9 mos post in 1 of 1 pt | MPS II | Mullen 2000^559^
Slow | cGVHD | - severe in 2 of 2 pts | MPS III | Vellodi, 1992(564
Slow | Infectious complications | - septicemia (MRSA) in 1 of 1 pt | MPS II | Tokimasa 2008^557^
Slow | Infectious complications | - 2 episodes of gram-positive bacteremia, one of limited gastrointestinal bleeding while thrombocytopenic, and one mucositis requiring parenteral nutrition for several wks in 1 of 1 pt | MPS II | Mullen 2000^559^
Slow | Infectious complications | - rotavirus gastroenteritis leading to severe hypoalbuminanemia and cerebral edema in 1 of 3 surviving pts | MPS II | Vellodi 1999^549^
Slow | Infectious complications | - grade 2 mucositis in 1 of 2 pts; - grade 3 mucositis in 1 of 2 pts | Farber's disease, Type 2/3 | Vormoor, 2004^597^
Slow | Infectious complications | - cytomegalovirus in 2 of 3 pts; - mucositis in 2 of 3 pts; - clostridium difficile enteritis in 1 of 3 pts | Farber's disease, Type 2/3 | Ehlert, 2006^596^
Slow | Infectious complications | staphylococcus epidermis sepsis in 1 of 1 pt | Gaucher Type III | Chen, 2007^568^
Slow | Infectious complications | - herpetic keratitis in 1 of 5 pts; - pneumonia in 1 of 5 pts | aspartylglucosaminuria | Arvio, 2001^578^
Slow | Infectious complications | - sepsis in 2 of 2 pts | MPS III | Vellodi A, 1992^564^
Slow | Seizures | - generalized tonic-clonic seizure occurred 3 days prior to transplant, attributed to conditioning regimen (busulfan) | Niemann-Pick Type C | Hsu, 1999^584^

#### Ongoing Research

“Stem Cell Transplantation for Inborn Errors of Metabolism,” a study sponsored by the Masonic Cancer Center of the University of Minnesota, is ongoing and no longer recruiting. The study is comparing patients treated by bone marrow, peripheral blood, or umbilical cord blood transplantation after March 2001 with historical controls. Outcomes to be measured include: survival, change in neuropsychometric function, rate of donor cell engraftment, rate of graft-versus-host disease, and toxicity of HSCT therapy. Patients with the following diseases were eligible to participate in the study: adrenoleukodystrophy, metachromatic leukodystrophy, globoid cell leukodystrophy, Gaucher disease, fucosidosis, Wolman's disease, Niemann-Pick disease, Batten disease, GM_1_ gangliosidosis, Tay-Sachs disease, and Sandhoff disease. The study began in January 1995 and the estimated study completion date was June 2010.

#### Conclusions

##### Rapidly Progressive Diseases

- High strength evidence on overall survival suggests a benefit with single HSCT compared to conventional management for Wolman's disease.
- Low strength evidence on overall survival suggests no benefit with single HSCT compared to symptom management or disease natural history for Niemann-Pick Type A.
- The body of evidence on overall survival with single HSCT compared to symptom management is insufficient to draw conclusions for mucolipidosis II (I-cell disease), Gaucher disease type II, cystinosis and infantile free sialic acid disease.

##### Slowly Progressive Diseases

- Low strength evidence on neurodevelopmental outcomes suggests a benefit with single HSCT compared to enzyme replacement therapy for the attenuated and severe forms of MPS II (Hunter's disease).
- Low strength evidence on neurocognitive outcomes suggests a benefit with single HSCT compared to enzyme replacement therapy for the attenuated form of MPS II (Hunter's disease).
- Low strength evidence on neurocognitive outcomes suggests no benefit with single HSCT compared to enzyme replacement therapy for the severe form of MPS II (Hunter's disease).
- Low strength evidence on neurocognitive outcomes suggests no benefit with single HSCT compared to enzyme replacement therapy for Gaucher Type III.
- Low strength evidence on neurocognitive or neurodevelopmental outcomes suggests no benefit with single HSCT compared to symptom management, substrate reduction therapy or disease natural history for MPS III (Sanfilippo).
- The body of evidence on neurocognitive or neurodevelopmental outcomes with single HSCT compared to symptom management and/or disease natural history is insufficient to draw conclusions for Niemann-Pick type C, MPS IV (Morquio syndrome), aspartylglucosaminuria, Fabry's disease, β-mannosidosis, mucolipidosis III or IV, glycogen storage disease type II (Pompe disease), Salla disease, and adrenomyeloneuropathy.

##### Disease With Both Rapidly and Slowly Progressive Forms

- High strength evidence on number of subcutaneous nodules and number of joints with limited range of motion suggests a benefit with single HSCT compared to symptom management or disease natural history for Farber's disease Type 2/3.
- Low strength evidence on neurocognitive outcomes suggests no benefit with single HSCT compared to symptom management or disease natural history for infantile ceroid lipofuscinosis.
- The body of evidence on overall survival and/or neurocognitive and neurodevelopmental outcomes with single HSCT compared to symptom management and or disease natural history is insufficient to draw conclusions for galactosialidosis (type unspecified) and Sandhoff disease (type unspecified), Farber's disease type I, infantile and juvenile forms of GM_1_, infantile and juvenile forms of Tay-Sachs, infantile GM_1_ gangliosidosis, and juvenile ceroid lipofuscinosis.

### Autoimmune Diseases Systematic Review

#### Type 1 Diabetes Mellitus

##### Background and Setting

Type 1 diabetes mellitus (DM1) is a T-cell mediated autoimmune disease characterized by selective, relentless and irreversible destruction of insulin-producing pancreatic beta-cells.607 DM1 is the most common autoimmune disorder in childhood, with an estimated incidence of 15,000 newly diagnosed cases in the U.S. annually based on 2002-2003 data.608 The disease typically is clinically diagnosed after approximately 60 to 80 percent of beta-cell mass has been destroyed.609 At this stage of disease, exogenous insulin treatment is required to maintain glucose homeostasis and survival. While DM1 comprises 5-10 percent of all diabetic causes, it is ultimately associated with a high frequency of vascular-related complications, including heart disease, stroke, blindness, and renal disease, with highly compromised quality of life and life expectancy.610

According to the U.S. Centers for Disease Control and Prevention, diabetes was the seventh leading cause of death listed on U.S. death certificates in 2006. Intensive insulin therapy (IIT) represents the gold standard treatment for DM1, to maintain tight control of blood glucose levels, as reflected by levels of HbA1C. IIT is delivered by multiple daily injections or by continuous subcutaneous infusion. Both methods have been shown to decrease the risk of diabetic retinopathy, nephropathy, and neuropathy by 39 to 90 percent and reduce their rate of progression by 39 to 60 percent when compared to standard insulin therapy with 1 to 2 injections daily.611 However, IIT is complicated by lack of patient acceptance and compliance, cannot fully prevent diabetic complications, and is associated with increased risk of severe hypoglycemia compared to standard therapy.

While DM1 does not typically develop into a fulminant, life-threatening form, it is a relentlessly progressive disorder despite IIT. The natural history may be transiently altered, but not halted, by coadministration of IIT and immune modulating therapies that include cyclosporine, azathioprine, prednisone, etanercept, and antithymocyte globulin (ATG).607 These approaches may induce a slower decline or some initial improvement in C-peptide levels, which directly reflect beta-cell mass and endogenous insulin production. However, the majority of patients continue to require increasing amounts of exogenous insulin. Furthermore, the toxic effects of immune suppressants, concerns about potential risks associated with immune suppression, and the need for continuous treatment in an otherwise healthy young population limit the use of these agents in conjunction with IIT.

For these reasons, based on a theory of possible reconstitution of immune tolerance after “immunologic reset,” nonmyeloablative autologous HSCT has been investigated as a way to effect an intense, but brief, immune suppression and preserve islet cell mass in children with newly diagnosed DM1. It is hypothesized that early intervention with HSCT will prevent the development of DM1-associated complications, improve quality of life, and ultimately increase life expectancy in this population. The effects of HSCT on insulin use and C-peptide levels will be compared to those parameters in children treated with IIT, in the context of adverse events associated with HSCT and IIT.

##### Evidence Summary

The overall grade of the strength of evidence for insulin independence and the use of HSCT for the treatment of autoimmune type I juvenile diabetes mellitus is shown in Table 107.

Table 107 Overall grade of strength of evidence for insulin independence and the use of HSCT for the treatment of autoimmune Type I diabetes mellitus

Key Question | Study Design | Risk of Bias | Consistency | Directness | Precision | Strength of Association | Overall Grade/Conclusion
For pediatric patients with newly diagnosed (within 4 weeks) autoimmune type 1 diabetes mellitus (DM1) what are the comparative effectiveness and harms of autologous HSCT and intensive insulin therapy (IIT). Outcomes of interest include long-term insulin independence, metabolic control, treatment-related mortality, and other long-term benefits and harms. Insulin independence is the key outcome of interest. Nonmyeloablative autologous HSCT is compared to IIT. | One Phase I/II prospective observational study (n=18) is available on the benefits and harms associated autologous HSCT using nonmyeloablative conditioning. For IIT, evidence was derived from the arms of two studies that compared IIT to conventional therapy in similar populations. One was an RCT and one an observational study. | The risk of bias is high. | The consistency of the evidence on long-term benefits and harms is unknown. The evidence is consistent in showing that an extended insulin-free interval can be achieved with autologous HSCT in children with newly diagnosed DM1. | Insulin independence in the short term can be considered a health outcome in itself. There is direct evidence that a prolonged interval of insulin independence can be achieved with autologous HSCT. There is indirect evidence for comparison of long-term benefits and harms between HSCT and IIT. | The precision of the evidence for long-term benefits and harms of HSCT is unknown. The evidence that an extended interval of insulin independence can be achieved with autologous HSCT is precise. | Not applicable due to lack of obvious effect size for adverse events including TRM. Strong strength of association for achieving an extended period of insulin independence following HSCT (16 of 18, 89%), averaging 31 months (range 14-52 months) | The overall body of evidence is insufficient to draw conclusions on long-term benefits or harms with single autologous HSCT in patients with newly diagnosed type I juvenile diabetes. Although the overall body of evidence is insufficient to come to conclusions about the relative balance of benefits (e.g., increased overall survival) or harms (treatment-related mortality, secondary malignancies), moderate strength evidence suggests that an extended interval of insulin independence can be achieved with single autologous HSCT in patients with newly diagnosed type I juvenile diabetes.

Evidence compiled for this review includes one prospective Phase I/II study of autologous HSCT (n=18 pediatric patients) that reported pre- and post-HSCT data on C-peptide levels and daily insulin use. Comparator data were obtained from the IIT control arms of two studies (total n=35) in newly diagnosed pediatric DM1 patients.

In the HSCT study, among 18 pediatric patients, the majority (89 percent) became free from insulin, either continuously (63 percent) or transiently (37 percent). Insulin independence was maintained for 7 to 52 months at total followup that ranged from 9 to 56 months. Among the 6 patients who resumed insulin, daily doses were lower than prior to HSCT. There was no treatment-related mortality in the HSCT study.

##### Results

The electronic literature search identified 15 citations relevant to HSCT and DM1, from which seven were retrieved for full-text screening, including those found in examination of the bibliographies of retrieved articles. A total of three reports were included in this review.612-614

Table 108 shows the criteria that were used to select studies for this section.

Table 108 Study selection criteria: Type I DM

Study Design | Population | Intervention | Comparator | Outcomes | Followup | Setting
Any study design | Pediatric patients (0-21 yrs) with newly diagnosed DM1 (within 6 weeks prior to study entry) | Nonmyeloablative autologous HSCT | Intensive insulin therapy | Serum C-peptide levels, HbA1C and daily insulin requirement pre- and post-HSCT | All durations of followup | In- or out-patient

Table 109 shows the characteristics of one Phase I/II study of HSCT,612 and the IIT control arms of two randomized trials that compared IIT with IIT plus an immunosuppressant agent.613, 614 All three studies included pediatric patients with DM1 who had been clinically diagnosed within 6 weeks prior to study entry.

Table 109 Type 1 juvenile diabetes mellitus study characteristics and population

Study | Design | Age Range (yrs) | Mean Age (yrs) | Sex M (%) | Disease Stage | HSCT (N) | Comparator (N) | Treatment Period
Couri et al. 2009^612^ | Prospective phase I/II | 13-21 | 16 | 67 | Newly diagnosed | 18 | Not applicable | 11/2003-04/2008
Crino et al. 2005^613^ | Retrospective | NR | 14 | NR | Newly diagnosed | Not applicable | 27 | NR
Mastrandrea et al. 2009^614^ | Randomized, double-blind | 8-18 | 12 | 38 | Newly diagnosed | Not applicable | 8 | 10/2002-10/2007

In the HSCT study, peripheral blood hematopoietic stem cells were mobilized with cyclophosphamide (2 g/m^2^) and granulocyte colony-stimulating factor (10 μg/kg daily).612 Patients were conditioned with a nonmyeloablative regimen comprising cyclophosphamide (50 mg/kg daily for 4 days) and rabbit antithymocyte globulin (0.5 mg/kg daily for 1 day, then 1 mg/kg daily for 4 days) prior to stem cell infusion. The IIT studies utilized 3 to 4 injections of short- or intermediate-acting insulin, with blood glucose levels monitored and maintained as near to normal as possible.613, 614

Table 110 shows the outcomes that were reported across the studies included in this report.

Table 110 Outcomes reported: Type I DM

Study | Δ C-peptide Level^*^ | Δ Daily Insulin Requirement | Δ HbA1c^*^ | Treatment-Related Mortality | Other Adverse Effects
Couri et al. 2009^612^ | ✓ | ✓ | ✓ | ✓ | ✓
Crino et al. 2005^613^ | ✓ | ✓ | ✓ | NR | ✓
Mastrandrea et al. 2009^614^ | ✓ | ✓ | ✓ | NR | ✓

* See Appendix F for data

###### Insulin Requirements

Daily pretransplant insulin use ranged from 0.13 to 0.59 IU/kg in the HSCT study.612 Insulin was suspended in 16 of 18 (89 percent) pediatric patients following HSCT.612 Among the 16 who became insulin-independent, 10 were reported continuously free for an average of 31 months (range: 14-52 months) at followup times that ranged from 9 to 56 months. Patients who ultimately resumed insulin remained free from its use for about 15 months (range 7 to 47 months), at followup times that ranged from 9 to 58 months. However, daily insulin doses after exogenous treatment was resumed were relatively small, ranging from 0.1 to 0.3 IU/kg, compared to premobilization doses that ranged from 0.13 to 0.44 IU/kg, maintaining good glucose control.

In one IIT study, daily insulin use averaged 0.91 ± 0.28 IU/kg at study entry, with no significant change at 12 or 24 months (0.61 ± 0.28 and 0.70 ± 0.24 IU/kg, respectively).613 In the second IIT study, average daily insulin use at 6 months was reported to have increased by 23 percent from that at baseline (p<0.05) but the dose was not specified.614 No patients became insulin independent in either study.

###### Adverse Events

No treatment-related mortality was reported in the HSCT study.612 One post-conditioning case of bilateral pneumonia was reported that responded quickly to intravenous broad-spectrum antibiotics. With long-term followup, six cases of oligospermia were reported, and one case of leukopenia. The majority of adverse effects in the HSCT study were mild and included nausea, vomiting, fever, and alopecia.

No severe adverse effects were reported with IIT in either study.613, 614

##### Ongoing Research

According to the website ClinicalTrials.gov, five clinical studies are recruiting pediatric patients, as shown in Table 111. None of these originates in the U.S. Of the ongoing trials, only one offers a comparison between autologous mesenchymal stem cells and placebo (NCT01157403).

Table 111 Ongoing clinical trials of HSCT in DM1

Study Title | Phase | Intervention | NCT ID
Autologous Transplantation of Mesenchymal Stem Cells for Treatment of Patients with Inset of Type 1 Diabetes | II/III | Autologous | 01157403
Autologous Hematopoietic Stem Cell Transplantation for Early Onset Type 1 Diabetes | II | Autologous | 00807651
Hematopoietic Stem Cell Transplantation in Type 1 Diabetes Mellitus | I/II | Autologous | 01121029
Safety and Efficacy of Autologous Stem Cell Transplantation for Early Onset Type 1 Diabetes Mellitus | I/II | Autologous | 00315133
Safety and Efficacy of Autologous Adipose-Derived Stem Cell Transplantation in Patients with Type 1 Diabetes | I/II | Autologous | 00703599

##### Conclusion

The overall body of evidence is insufficient to draw conclusions on long-term benefits or harms with single autologous HSCT in patients with newly diagnosed type I juvenile diabetes.

Moderate strength evidence suggests that an extended interval of insulin independence can be achieved with single autologous HSCT in patients with newly diagnosed type I juvenile diabetes.

#### Systemic Lupus Erythematosus

##### Background and Setting

Systemic lupus erythematosus (SLE) is a chronic autoimmune disease that is associated with inflammation and eventual organ damage.607 It may involve any organ system, with a wide range of disease severity. The exact cause of SLE is unknown. Diagnosis of SLE is the same regardless of age at onset, and is based on a combination of laboratory and clinical criteria. SLE is likely if four of the 11 revised American College of Rheumatology (ACR) criteria are present in a patient simultaneously or over time.615

SLE is rare in childhood, with an estimated incidence of 10 to 20 per 100,000 children, with some variation depending on ethnicity. Juvenile-onset SLE (prior to age 18 years) accounts for 15 to 20 percent of cases,616 which in general have a more severe presentation, faster development of organ damage, and a higher disease burden over a lifetime. For all age groups, 5-year survival rates have improved with advances in management of organ damage and complications, from 59 to 93 percent in the 1980s to 94 to 100 percent by the late 1990s.617 Patients aged younger than 24 years have the highest rate of SLE-related all-cause mortality, about 8-fold greater than the average for all SLE cases.618

The clinical course of SLE is marked by the alternation of periods of active disease and quiescence. However, children and adolescents with SLE enter adult life with considerable morbidity, secondary to sequelae of disease activity, side effects of medications, and comorbid conditions. The most common symptoms of SLE include fever, rash, fatigue, weight loss, arthritis, and renal disease.619 Lupus nephritis is one of the main clinical presentations of pediatric SLE, and it determines the course of illness as the major threat to long-term survival. Other major manifestations include neuropsychiatric, cardiac, and lung.

SLE has no known cure. Depending on severity, it is often treated with high-dose corticosteroids and immune suppressants, which are responsible for much of the permanent organ damage observed in these patients. Other treatments include hydroxychloroquine, cyclophosphamide, cyclosporine A, mycophenolate mofetil, azathioprine, nonsteroidal anti-inflammatory drugs (NSAIDs), rituximab, and abatacept.607 Only three agents have received U.S. Food and Drug Administration marketing approval for SLE: corticosteroids, hydroxychloroquine, and aspirin.

Autologous HSCT has been used to treat a small number of pediatric SLE cases, all of which have been severe, life-threatening, and refractory to nearly all drug therapies, with a dismal prognosis. Accordingly, this systematic review will present only results from HSCT reports, with the comparison being usual care.

##### Evidence Summary

The overall grade of strength of evidence for drug-free clinical remission and the use of HSCT for the treatment of severe, refractory systemic lupus erythematosus is shown in Table 112.

Table 112 Overall grade of strength of evidence for drug-free clinical remission and the use of HSCT for the treatment of severe, refractory systemic lupus erythematosus

Key Question | Study Design | Risk of Bias | Consistency | Directness | Precision | Strength of Association | Overall Grade/Conclusion
For pediatric patients with severe, refractory systemic lupus erythematosus (SLE) what are the effectiveness and harms of autologous HSCT and drug therapies? Outcomes of interest include long-term drug-free clinical remission, TRM, and other long-term benefits and harms. All patients in these studies had severe, refractory disease, with dismal prognosis, so the comparator is usual care and natural history. | There are 7 reports on autologous HSCT (total n = 17); the largest, a phase I/II study, contains information on 9 pediatric patients. | The risk of bias is high. | The consistency of the evidence on long-term benefits and harms is unknown. The evidence is consistent in showing an extended drug-free interval and clinical remission can be achieved with autologous HSCT. | Drug-free clinical remission of severe, refractory SLE in the short-term is considered a health outcome. There is direct evidence that an extended drug-free clinical remission can be achieved with autologous HSCT. The evidence comparing usual care is indirect. | The precision of the evidence for long-term benefits and harms is unknown. The evidence that an extended drug-free clinical remission can be achieved with autologous HSCT is precise. The precision of the evidence comparing usual care is unknown. | Not applicable due to lack of obvious effect size for adverse events including TRM. Strong strength of association for achieving an extended period of drug-free clinical remission following HSCT (12 of 17, 71%), ranging in duration from 4 to 66 months. | The overall body of evidence is insufficient to draw conclusions on long-term benefits or harms with single autologous HSCT for the treatment of severe, refractory SLE in children. Although the overall body of evidence is insufficient to come to conclusions about the relative balance of benefits (e.g., increased overall survival) or harms (treatment-related mortality, secondary malignancies), moderate strength evidence suggests that an extended drug-free clinical remission can be achieved with single autologous HSCT for the treatment of severe, refractory SLE in children.

Overall, 12 of 17 (71 percent) SLE patients treated with autologous HSCT entered a state of complete drug-free remission, for periods that ranged from about 4 months620 to 66 months.621 The former reflects the followup time at preparation of the paper. In the largest series (n=9), patients experienced complete drug-free remission for a median 24 months, and a range of 12 to 66 months.621

Three studies reported SLE Disease Activity Index (DAI) score changes pre- and post-HSCT.621-624 Patients who underwent autologous HSCT and experienced a complete drug-free remission had substantial reduction in their SLEDAI scores. In one study, two of four patients succumbed to treatment-related mortality, one at 63 days from multiorgan failure, the other on day 15 due to multiple causes.623

##### Results

A total of seven reports were included in this review. Table 113 shows the criteria that were used to select studies for this section.

Table 113 Study selection criteria: SLE

Study Design | Population | Intervention | Comparator | Outcomes | Followup | Setting
Any study design | Pediatric patients (0-21 yrs) with severe, refractory systemic lupus erythematosus (SLE) | Autologous HSCT | None applicable | Survival, drug-free remission post-HSCT, HSCT-related adverse events | All durations of followup | In-patient

Table 114 shows the characteristics of studies of autologous HSCT in 17 patients (16 female) aged 13-21 years with SLE. All had severe, life-threatening SLE that was refractory to most first- and second-line drugs, variously including corticosteroids, pulsed cyclophosphamide, 6-mercaptopurine, azathioprine, plasmapheresis, and hydroxychloroquine. Although rituximab and abatacept have been studied in adults with SLE, we did not identify any studies of those agents in the pediatric setting. Outcomes reported are included in Table 115.

Table 114 Systemic lupus erythematosus study characteristics and population

Study | Design | Age Range (yrs) | Mean Age (yrs) | Sex F (%) | Disease Stage | HSCT (N) | Comparator (N) | Treatment Period
Statkute, 2005^621^ | Case series | 15-21 | 19 | 100 | Severe, refractory, including WHO class III/IV renal, cardiac, CNS, and pulmonary involvement | 9 | N/A | 04/1997-08/2004
Chen, 2005^622^ | Case reports | 13, 18 | NR | 100 | Severe, refractory, including WHO class III/IV nephritis | 2 | NA | 1996, 2001
Lisukov, 2004^623^ | Case series | 15-21 | 19 | 100 | Severe, refractory, with SLEDAI score ranging from 6-30, with WHO class III/IV nephritis, CNS, cardiac, pulmonary and life-threatening cytopenias | 4 | NA | 1998-2003
Brunner, 2002^625^ | Case report | 18 | NR | 100 | Severe, refractory, with WHO class IV nephritis, cutaneous vasculitis, pneumonitis, with mechanical ventilation | 1 | NA | 2000
Musso, 2001^620^ | Case reports | 17, 20 | NR | 100 | Severe, life-threatening, refractory | 2 | NA | NR
Wulffraat, 2001^624^ | Case reports | 14, 14 | NR | 50 | Severe, life-threatening, refractory, with WHO class IV nephritis, hemorrhagic pneumonitis, pancytopenia, vasculitis, polyarthritis | 2 | NA | NR
Trysberg, 2000^626^ | Case report | 18 | NR | 100 | Severe, progressive life-threatening, refractory CNS lupus | 1 | NA | 1998

Table 115 Outcomes reported: SLE

Study | Complete Drug-Free Remission (%) | SLEDAI Score (pre-post) | TRM | Other Adverse Effects
Statkute, 2005^621^ | ✓ | NR | ✓ | ✓
Chen, 2005^622^ | ✓ | ✓ | ✓ | ✓
Lisukov 2004^623^ | ✓ | ✓ | ✓ | NR
Brunner, 2002^625^ | ✓ | NR | NR | ✓
Musso, 2001^620^ | ✓ | NR | ✓ | ✓
Wulffraat, 2001^624^ | ✓ | ✓ | ✓ | ✓
Trysberg, 2000^626^ | NR | NR | ✓ | ✓

Five studies used only peripheral blood stem cells.620-622, 625, 626 One used bone marrow cells;624 and, one used both sources.623 Conditioning regimens typically included cyclophosphamide plus ATG; two studies included total-body irradiation,624, 626 and one used modified BEAM regimens with ATG.623

###### Complete Drug-Free Remission

Table 116 shows the proportions of patients with severe, refractory SLE who entered a state of complete drug-free remission following intense immune suppression and autologous HSCT. Overall, 12 of 17 (71 percent) entered a state of complete drug-free remission, for periods that ranged from about 4 months620 to 66 months.621 The former reflects the followup time at preparation of the paper. In the largest series, patients experienced complete drug-free remission for a median 24 months, and a range of 12 to 66 months.621

Table 116 Complete drug-free remission in patients with SLE undergoing autologous HSCT

Complete Drug-Free Remission (%) | Duration of Complete Drug-Free Remission (Months) | Study
78 (n=9) | Median 24 (rng 12-66) | Statkute, 2005^621^
2 of 2 | 9, 44 | Chen, 2005^622^
25 (n=4) | >60 | Lisukov, 2004^623^
1 of 1 | 21 | Brunner, 2002^625^
2 of 2 | >30, >3.8 | Musso, 2001^620^
2 of 2 | 12, 18 | Wulffraat, 2001^624^
NR | NR | Trysberg, 2000^626^

###### Systemic Lupus Erythematosus Disease Activity Index (SLEDAI) Score

Three studies reported SLEDAI score changes pre- and post-HSCT,622-624 as shown in Table 117. In studies that reported this outcome, patients who underwent autologous HSCT and experienced a complete drug-free remission had substantial reduction in their SLEDAI scores.

Table 117 Systemic Lupus Erythematosus Disease Activity Index (SLEDAI) Score

Pre-HSCT SLEDAI Score (Mean ± SD) | Post-HSCT SLEDAI Score | Study
NR | NR | Statkute, 2005^621^
6, 12 | 0, 0 | Chen, 2005^622^
19 ± 10 | <3 | Lisukov, 2004^623^
NR | NR | Brunner, 2002^625^
NR | NR | Musso, 2001^620^
20, 27 | 0, 8 | Wulffraat, 2001^624^
NR | NR | Trysberg, 2000^626^

###### Mortality and Other Serious Adverse Events Associated With Autologous HSCT

As shown in Table 115, six studies reported information on treatment-related mortality among autologous HSCT recipients.620-624, 626 In one study, 2 of 4 patients succumbed to treatment-related mortality, one at 63 days from multiorgan failure, the other on day 15 due to multiple causes.623 Other than those mentioned, all other adverse effects of the autologous HSCT conditioning regimens were reported by the authors to be mild to moderate and without clinical sequelae.

##### Ongoing Research

According to the Web site ClinicalTrials.gov, two clinical studies are recruiting pediatric patients, as shown in Table 118.

Table 118 Ongoing clinical trials of HSCT in SLE

Study Title | Phase | Intervention | NCT ID
Cyclophosphamide and rATG/Rituximab in Patients With Systemic Lupus Erythematosus | II | Autologous HSCT | NCT00278538
Mesenchymal Stem Cells Transplantation for Refractory Systemic Lupus Erythematosus (SLE) | I/II | Allogeneic HSCT | NCT00698191

##### Conclusion

The overall body of evidence is insufficient to draw conclusions on long-term benefits or harms with single autologous HSCT for the treatment of severe, refractory SLE in children.

Moderate strength evidence suggests that an extended drug-free clinical remission can be achieved with single autologous HSCT for the treatment of severe, refractory SLE in children.

#### Juvenile Idiopathic Arthritis (JIA)

##### Background and Setting

Juvenile idiopathic arthritis (JIA) is the most common chronic rheumatic condition in children, with a prevalence of between 16 and 150 per 100,000.^607^ It is defined as persistent arthritis in one or more joints in a child or adolescent less than 16 years old, after excluding other causes. According to the current International League of Association of Rheumatologists (ILAR) the term JIA refers to seven different disease categories: systemic, persistent oligoarticular, extended oligoarticular, polyarticular rheumatoid factor (RF) negative, polyarticular RF positive, enthesitis-related arthritis, and psoriatic.627

While the cause of JIA is not defined, evidence suggests altered immune system function, particularly T-cell regulation, has a major role in the pathogenesis of joint damage and disease progression.628, 629 JIA subtypes vary by the number of joints involved, and by age of onset. The most common form is the early onset (before age 6 years) oligo- or mono-articular JIA, with 1 to 4 asymmetrical joints affected, a high frequency of positive antinuclear antibodies (ANA), and high risk (30 percent) of chronic uveitis. These forms have generally good prognosis, and may be managed with intra-articular steroids and physiotherapy.627

At the other end of the spectrum, systemic-onset JIA is distinct from other JIA subtypes, with a systemic inflammatory component. While about 50 percent of cases will have a waxing and waning course, with favorable long-term prognosis, the other 50 percent will have an unremitting course with polyarthritis; prolongation of active systemic illness past 6 months is a particularly bad prognostic sign.607 Despite current treatment that includes methotrexate, corticosteroids, biological response modifiers (blocking agents of TNF-alpha, IL-1, IL-6) or blockers of costimulatory immune cell-surface molecules (e.g., CD28 or CD20),and other immune suppressants, most children with systemic polyarticular JIA do not achieve long-term clinical remission.607, 627 More than one-third will have ongoing active disease into adulthood, with sequelae secondary to chronic inflammation. Those who do not respond to early use of antirheumatic agents will experience considerable morbidity from joint damage, osteoporosis, growth retardation, psychosocial morbidity, reduced quality of life and educational and employment disadvantage.627

Autologous HSCT has been used to treat a small number of pediatric JIA cases, all of which have been severe, progressive and refractory to standard drug therapies. Accordingly, this systematic review will present only results from HSCT reports, compared to usual care and the disease course.

##### Evidence Summary

The overall grade of strength of evidence for drug-free clinical remission and the use of HSCT for the treatment of severe, refractory juvenile idiopathic arthritis is shown in Table 119.

Table 119 Overall grade of strength of evidence for drug-free clinical remission and the use of HSCT for the treatment of severe, refractory juvenile idiopathic arthritis

Key Question | Study Design | Risk of Bias | Consistency | Directness | Precision | Strength of Association | Overall Grade/Conclusion
For pediatric patients with severe, refractory juvenile idiopathic arthritis (JIA) what is the comparative effectiveness and harms of autologous HSCT and drug therapies? All patients in these studies had severe, refractory disease, with very poor prognosis, so the comparator is usual care and natural history. Outcomes of interest include extended, drug-free clinical remission, TRM, and other long-term benefits and harms. | There are 4 single-arm and case reports (total n = 43). The largest, a registry report, contains information on 34 pediatric patients. | The risk of bias is high. | The consistency of the evidence on long-term benefits and harms is unknown. The evidence is consistent in showing an extended drug-free interval and clinical remission can be achieved with autologous HSCT. | Drug-free clinical remission of severe, refractory JIA in the short-term is considered a health outcome. There is direct evidence that an extended drug-free clinical remission can be achieved with autologous HSCT. The evidence comparing usual care is indirect. | The precision of the evidence for long-term benefits and harms is unknown. The evidence that an extended drug-free clinical remission can be achieved with autologous HSCT is precise. The precision of the evidence comparing usual care is unknown. | Not applicable due to lack of obvious effect size for adverse events including TRM. Strong strength of association for achieving an extended period of drug-free clinical remission following HSCT (24 of 43, 56%),averaging 30 months duration (range 6 to 60 months). | The overall body of evidence is insufficient to draw conclusions on long-term benefits or harms with single autologous HSCT for the treatment of severe, refractory JIA in children. Although the overall body of evidence is insufficient to come to conclusions about the relative balance of benefits (e.g., increased overall survival) or harms (treatment-related mortality, secondary malignancies), moderate strength evidence suggests that an extended drug-free clinical remission can be achieved with single autologous HSCT for the treatment of severe, refractory JIA in children.

Overall the evidence signals that autologous HSCT following chemotherapy-induced immune suppression may be associated with prolonged resolution of JIA into a drug-free, much-improved state. Among all cases reported, 21 of 43 (56 percent) achieved extended drug-free remission for 3 to 60 months. In the largest series, drug-free remission was reported in 53 percent, with a median duration of 29 months. There were four cases of treatment-related mortality, with no other reports of long-term benefits and harms.

##### Results

A total of four reports were included in this review.630-633 Table 120 shows the criteria that were used to select studies for this section.

Table 120 Study selection criteria: JIA

Study Design | Population | Intervention | Comparator | Outcomes | Followup | Setting
Any study design | Pediatric patients (0-21 yrs) with severe, refractory progressive juvenile idiopathic arthritis (JIA) | Autologous HSCT | None applicable | Survival, drug-free remission post-HSCT, HSCT-related adverse events | All durations of followup | In-patient

Table 121 presents the study characteristics and populations of 4 reports on the use of autologous HSCT treatment in patients with JIA. All patients had severe, refractory illness, mostly systemic (79 percent) but also polyarticular (21 percent). The largest experience is from the registry of the EBMT, which reports on 34 of 41 total patients who had received autologous HSCT at nine European centers.630 Four cases were treated in Japan631, 632 and five were from Italy.633 Patients ranged in age from 3 to 21 years, with 49 percent females and 51 percent males.

Table 121 Juvenile idiopathic arthritis study characteristics and population

Study | Design | Age Range (yrs) | Mean Age (yrs) | Sex F (%) | Disease Stage | HSCT (N) | Comparator (N) | Treatment Period
De Kleer, 2004^630^ | Registry report | 4-18 | 9 | 44 | Severe, refractory systemic (n=29) or polyarticular (n=5) | 34 | NA | Since 1997
Kishimoto, 2003^631^ | Case reports | 3-21 | 12 | 67 | Severe, refractory systemic disease | 3 | NA | NR
Nakagawa, 2001^632^ | Case report | 15 | NA | Male | Severe, refractory systemic disease | 1 | NA | 1999
Rabusin, 2000^633^ | Case series | 9-20 | 15 | 80 | Severe, refractory systemic (n=1) and systemic polyarticular (n=4) | 5 | NA | NR

Among 43 cases, 26 (60 percent) used bone-marrow stem cells, 12 (28 percent) used peripheral-blood stem cells, and the stem-cell source was not identified for five.633 Various conditioning regimens were reported, typically involving cyclophosphamide and ATG.

Table 122 shows outcomes that were reported in the four studies in this systematic review. Complete drug-free remission is the key outcome, which is generally defined as disappearance of signs and symptoms of JIA and cessation of antirheumatic agents.

Table 122 Outcomes reported: JIA

Study | Complete Drug-Free Remission (%) | TRM and Other Adverse Events
De Kleer, 2004^630^ | ✓ | ✓
Kishimoto, 2003^631^ | ✓ | ✓
Nakagawa, 2001^632^ | ✓ | ✓
Rabusin, 2000^633^ | ✓ | ✓

###### Complete Drug-free Remission

Overall, 56 percent of patients in these reports achieved a complete drug-free remission following autologous HSCT (Table 123). In the largest study, a complete drug-free response was achieved in 53 percent of cases, for an average duration of about 2.5 years, although some patients maintained this response for 60 months.630 In the Rabusin series, four of five (80 percent) patients achieved a complete drug-free response at 3 months' followup, with a relapse in one at 6 months, and ultimately relapse in the other three at 8, 12, and 18 months.633 One patient in the Kishimoto study had disease flares at 11 and 23 months followup, but became medication-free and asymptomatic at 39 months followup.631

Table 123 Complete drug-free remission in patients with JIA undergoing autologous HSCT

Complete Drug-Free Remission (%) | Duration of Complete Drug-Free Remission (Months) | Study
53 (n=34) | 29 ± 12 (rng 21-60) | De Kleer, 2004^630^
67 (n=3) | 10, 35 | Kishimoto, 2003^631^
1 of 1 | 15 | Nakagawa, 2001^632^
80 (n=5) | 11 ± 5 (rng 6-18) | Rabusin, 2000^633^

###### Overall Survival

One study reported Kaplan-Meier overall survival of about 79 percent at 5 years' followup.630

###### Treatment-related Mortality and Other Adverse Events

Overall, treatment-related mortality was reported in 4 of 43 (9 percent) compiled cases in this review. In the EBMT experience, treatment-related mortality was reported in 3 of 34 cases (9 percent), attributed to macrophage-activation syndrome.630 In another study, one patient who had an uncontrollable disease flare after autologous HSCT underwent a subsequent cord-blood allogeneic HSCT, but developed a CMV infection and died 48 days after allogeneic HSCT.631 No treatment-related mortality was reported in the other two studies.632, 633

##### Ongoing Research

According to ClinicalTrials.gov, there are no clinical trials of HSCT actively recruiting patients with JIA.

##### Conclusion

The overall body of evidence is insufficient to draw conclusions on long-term benefits or harms with single autologous HSCT for the treatment of severe, refractory JIA in children.

Moderate strength evidence suggests that an extended drug-free clinical remission can be achieved with single autologous HSCT for the treatment of severe, refractory JIA in children.

#### Systemic Sclerosis

##### Background and Setting

Systemic sclerosis is a generalized, highly heterogeneous autoimmune disorder characterized by diffuse, disabling skin thickening combined with fibrotic changes in many organs, in particular the heart and lung, ultimately resulting in end-stage failure.634

Systemic sclerosis is a rare disease. It is diagnosed in approximately 67 male patients and 265 female patients per 100,000 people each year in the U.S. Systemic sclerosis usually appears in women aged 30 to 40 years, and it occurs in slightly older men. In approximately 85 percent of cases, systemic sclerosis develops in individuals aged 20 to 60 years. Cases also are observed in children and in the elderly population. Immunologic mechanisms and heredity (certain HLA subtypes) play a role in etiology. Systemic sclerosis-like syndromes can result from exposure to vinyl chloride, bleomycin, pentazocine, epoxy and aromatic hydrocarbons, contaminated rapeseed oil, or L-tryptophan.

Systemic sclerosis pathophysiology involves vascular damage and activation of fibroblasts; collagen and other extracellular proteins in various tissues are overproduced. The disease varies in severity and progression, ranging from generalized skin thickening with rapidly progressive and often fatal visceral involvement, primarily end-stage organ failure.635-637 The course depends on the type of systemic sclerosis but is often unpredictable. Typically, progression is slow. Overall, 5- and 10-year survival is about 20 to 80 percent and 15 to 65 percent, respectively, according to the major organ affected at diagnosis.638-640 Patients with diffuse skin disease eventually develop visceral complications, which are the usual causes of death. Prognosis is poor if cardiac, pulmonary, or renal manifestations are present early. Heart failure may be intractable. Acute renal insufficiency, if untreated, progresses rapidly and causes death within months.

Results from Phase II open studies suggest intravenous pulse cyclophosphamide therapy may improve skin score and pulmonary function.641-643 However, no treatment has been shown definitively to halt disease progression. Autologous HSCT has been used to treat a small number of pediatric systemic sclerosis cases, all of which have been severe, progressive and refractory. Accordingly, this systematic review will present only results from HSCT reports, compared to usual care and the disease course.

##### Evidence Summary

The overall grade of strength of evidence for drug-free clinical remission and the use of HSCT for the treatment of severe, refractory systemic sclerosis is shown in Table 124.

Table 124 Overall grade of strength of evidence for drug-free clinical remission and the use of HSCT for the treatment of severe, refractory systemic sclerosis

Key Question | Study Design | Risk of Bias | Consistency | Directness | Precision | Strength of Association | Overall Grade/Conclusion
For pediatric patients with severe, refractory systemic sclerosis (SSc) what is the comparative effectiveness and harms of autologous HSCT and drug therapies? All patients in these studies had severe, refractory disease, with very poor prognosis, so the comparator is usual care and natural history. Outcomes of interest include extended, drug-free clinical remission, TRM, and other long-term benefits and harms. | There is one report from the EBMT/EULAR registry, with a total of 5 pediatric patients. | The risk of bias is high. | The consistency of the evidence on long-term benefits and harms is unknown. The evidence is consistent in showing a drug-free clinical remission can be achieved with autologous HSCT. | Drug-free clinical remission of severe, progressive SSc in the short-term is considered a health outcome. There is direct evidence that a drug-free clinical remission can be achieved with autologous HSCT. The evidence comparing usual care is indirect. | The precision of the evidence on long-term benefits and harms is unknown. The evidence that a drug-free clinical remission can be achieved with autologous HSCT is precise. The precision of the evidence comparing usual care is unknown. | Not applicable due to lack of obvious effect size for adverse events including TRM. Strong strength of association for achieving an extended period of drug-free clinical remission following HSCT (4 of 5, 80%). The duration of remission was not reported. | The overall body of evidence is insufficient to draw conclusions on long-term benefits or harms with single autologous HSCT for the treatment of severe, refractory SSc in children. Although the overall body of evidence is insufficient to come to conclusions about the relative balance of benefits (e.g., increased overall survival) or harms (treatment-related mortality, secondary malignancies), moderate strength evidence suggests that a drug-free clinical remission can be achieved with single autologous HSCT for the treatment of severe, refractory SSc in children.

Systemic sclerosis is very rare in children, with one registry report comprising the sole source of published evidence on the use of autologous HSCT in this setting. There are no proven therapies for advanced, progressive systemic sclerosis with visceral involvement, which has a dismal prognosis. In this context, that four of five patients (80 percent) entered a state of complete clinical remission, with the other one in partial remission, signals that autologous HSCT following chemotherapy-induced immune suppression may be associated with these results.

##### Results

One report was included in this review. Table 125 shows the criteria that were used to select studies for this section.

Table 125 Study selection criteria: Systemic sclerosis

Study Design | Population | Intervention | Comparator | Outcomes | Followup | Setting
Any study design | Pediatric patients (0-21 yrs) with severe, progressive systemic sclerosis (SSc) | Autologous HSCT | None applicable | Survival, drug-free remission post-HSCT, HSCT-related adverse events | All durations of followup | In-patient

Table 126 shows the study and patient characteristics of one report on the use of autologous HSCT in pediatric systemic sclerosis patients.644 This registry report provides details on 5 children age 9 to 17 years, all of whom had lung disease at inclusion and systemic sclerosis (4 diffuse, 1 limited). Disease had been diagnosed within 62 months (range: 26-85 months) before HSCT. They all received the same mobilization regimen comprising cyclophosphamide and G-CSF plus cell selection before transplantation with either CD34+ selection alone (n=3) or CD34+/4+/8+ (n=2). Different conditioning regimens were used, comprising cyclophosphamide plus antiCD52 (CAMPATH 1) (n=3), cyclophosphamide plus TBI plus ATG (n=1), or cyclophosphamide alone (n=1).

Table 126 Systemic sclerosis study characteristics and population

Study | Design | Age Range (yrs) | Mean Age (yrs) | Sex F (%) | Disease Stage | HSCT (N) | Comparator (N) | Treatment Period
Farge, 2004^644^ | Registry report | 9-17 | 12 | 80 | Refractory, severe, with early visceral involvement | 5 | NA | 1996-2002

Only scant details on pediatric patients are available in the registry report. All five children were reported alive after a median duration of about 38 months (range: 14-68 months). Four (80 percent) entered complete remission, with one partial remission. Disease ultimately progressed in one patient, and one relapsed about 9 months after experiencing a complete remission. One 19-year-old patient, not included in the group of five reported above, succumbed to diffuse alveolar hemorrhage 11 days post-transplant.

##### Ongoing Research

According to ClinicalTrials.gov, one Phase I/II study in China is actively recruiting individuals with systemic sclerosis to undergo HSCT with allogeneic mesenchymal stem cells (NCT00962923). A pilot study of total body irradiation in combination with cyclophosphamide, antithymocyte globulin, and autologous CD34-selected peripheral blood stem cell transplantation in children with refractory autoimmune disorders is active but not recruiting (NCT00010335).

##### Conclusion

The overall body of evidence is insufficient to draw conclusions on long-term benefits or harms with single autologous HSCT for the treatment of severe, refractory systemic sclerosis in children.

Moderate strength evidence suggests that an extended drug-free clinical remission can be achieved with single autologous HSCT for the treatment of severe, refractory systemic sclerosis in children.

#### Multiple Sclerosis

##### Background and Setting

Multiple sclerosis (MS) is a CNS demyelinating disease with an autoimmune etiology.645 It is characterized by the presence of inflammatory, demyelinating lesions scattered throughout the CNS at different sites and at different times. Clinical features secondary to the CNS lesions include loss of sensation, muscle weakness, visual loss, incoordination, cognitive impairment, fatigue, pain, and bladder and bowel disturbance.645

Pediatric MS is diagnosed after two clinical episodes of CNS demyelination that are separated by at least 30 days.646 In adults, three of the following four features are required: nine or more white matter lesions or one gadolinium-enhancing lesion; three or more periventricular lesions; one juxtacortical lesion; one infratentorial lesion. These criteria may be applied to identify pediatric cases, but have not been clinically validated in this population.647

The worldwide prevalence of pediatric MS is unknown. Data from individual countries or MS centers reported prevalence rates of MS in childhood ranging from 3.1 to 4.4 percent of all MS cases.648-650 A Canadian study estimated the incidence of initial pediatric demyelinating events (including MS, neuromyelitis optica, acute disseminated encephalomyelitis, complete transverse myelitis, and recurrent optic neuritis) as 0.9 per 100,000 individuals.651

The natural history of MS is extremely variable, with a waxing and waning pattern that may gradually worsen over time.645 Four broad categories are recognized: relapsing remitting MS (RRMS), which accounts for about 85 percent of cases; secondary progressive MS (SPMS), which represents a progression of RRMS with accumulating irreversible neurological deficit and disability; primary progressive MS (PPMS), which is characterized by progressive disease from onset, and accounts for 10 to 15 percent of MS cases; and, progressive relapsing MS (PRMS), defined as progressive disease from onset with superimposed relapses.

Malignant MS is a poorly defined subset of MS that comprises a heterogeneous group of demyelinating disorders that is applied only to cases that succumb within 5 years of onset, accounting for less than 5 percent of all MS subjects.652

The therapeutic approach to MS has evolved over the past two decades. Four first-line disease modifying therapies have received U.S. Food and Drug Administration approval for use in adults with RRMS: glatiramer acetate, intramuscular and subcutaneous interferon-β1a, and subcutaneous interferon-β1b.647 Evidence supporting their use in children is very limited.

Most treatment decisions in children with MS are based in part on results achieved in adults. Corticosteroids are used to treat acute, symptomatic relapses, but are associated with serious adverse effects in children.645 Second-line agents in children have included cyclophosphamide, mitoxantrone, mycophenolate mofetil, daclizumab, rituximab or natalizumab, primarily described in retrospective case series and reports with limited follow-up.647

There is no consensus on how to treat malignant MS. Approaches have included plasmapheresis, aggressive immunosuppression with mitoxantrone, cladribine, and cyclophosphamide, with no documented effect in this setting. Given the extremely poor prognosis of malignant MS, and the lack of effective treatment, autologous HSCT has been used to treat a small number of pediatric malignant MS cases. Accordingly, this systematic review will present only results from HSCT reports compared to usual care and the disease course.

##### Evidence Summary

The overall grade of strength of evidence for drug-free clinical remission and the use of HSCT for the treatment of severe, refractory malignant multiple sclerosis is shown in Table 127.

Table 127 Overall grade of strength of evidence for drug-free clinical remission and the use of HSCT for the treatment of severe, refractory malignant multiple sclerosis

Key Question | Study Design | Risk of Bias | Consistency | Directness | Precision | Strength of Association | Overall Grade/Conclusion
For pediatric patients with severe, refractory malignant multiple sclerosis (MS) what is the comparative effectiveness and harms of autologous HSCT and drug therapies? All patients in these studies had severe, refractory disease, with very poor prognosis, so the comparator is usual care and natural history. Outcomes of interest include extended, drug-free clinical remission, TRM, and other long-term benefits and harms. | There are three case series or case reports with a total of 5 pediatric patients. | The risk of bias is high. | The consistency of the evidence on long-term benefits and harms is unknown. The evidence is consistent in showing an extended drug-free interval and clinical remission can be achieved with autologous HSCT. | Drug-free clinical remission of severe, refractory MS in the short-term is considered a health outcome. There is direct evidence that an extended drug-free clinical remission can be achieved with autologous HSCT. The evidence comparing usual care is indirect. | The precision of the evidence for long-term benefits and harms is unknown. The evidence that an extended drug-free clinical remission can be achieved with autologous HSCT is precise. The precision of the evidence comparing usual care is unknown. | Not applicable due to lack of obvious effect size for adverse events including TRM. Strong strength of association for achieving an extended period of drug-free clinical remission following HSCT (5 of 5, 100%), ranging from 14 to 66 months. | The overall body of evidence is insufficient to draw conclusions on long-term benefits or harms with single autologous HSCT for the treatment of severe, refractory MS in children. Although the overall body of evidence is insufficient to come to conclusions about the relative balance of benefits (e.g., increased overall survival) or harms (treatment-related mortality, secondary malignancies), moderate strength evidence suggests that an extended drug-free clinical remission can be achieved with single autologous HSCT for the treatment of severe, refractory MS in children.

Malignant MS is very rare in children, with three reports comprising the sole identified source of published evidence on the use of autologous HSCT in this setting. There are no proven therapies for malignant MS, which has a dismal prognosis. In this context, that five of five patients (100 percent) entered a state of clinical remission, with no relapses at followup, signals that autologous HSCT following chemotherapy-induced immune suppression may be associated with these results.

##### Results

A total of three reports were included in this review. Table 128 shows the criteria that were used to select studies for this section.

Table 128 Study selection criteria: MS

Study Design | Population | Intervention | Comparator | Outcomes | Followup | Setting
Any study design | Pediatric patients (0-21 yrs) with malignant MS | Autologous HSCT | None applicable | Survival, drug-free remission post-HSCT, HSCT-related adverse events | All durations of followup | In-patient

Table 129 shows the study and patient characteristics of three reports (total N=5) on the use of autologous HSCT in pediatric patients.653-655 They ranged in age from 9 to 18 years, with two females and three males.

Table 129 Multiple sclerosis study characteristics and population

Study | Design | Age Range (yrs) | Mean Age (yrs) | Sex F (%) | Disease Stage | HSCT (N) | Comparator (N) | Treatment Period
Fagius, 2009^653^ | Case series | 9, 16 | NA | 1 female, 1 male | Refractory malignant MS of short duration | 2 | NA | Since 2004
Kimiskidis, 2008^654^ | Case report | 18 | NA | male | Refractory malignant MS of short duration | 1 | NA | 2001
Mancardi, 2005^655^ | Case reports | 16, 18 | NA | 1 female, 1 male | Refractory malignant MS of short duration | 2 | NA | NR

In the first report, peripheral blood stem cells were mobilized using cyclophosphamide and G-CSF.653 One patient underwent conditioning using a BEAM regimen (BCNU, etoposide, cytosine-arabinoside, melphalan), the other (a young male) was conditioned using cyclophosphamide. Total body irradiation was not used in either case. ATG and methylprednisolone were administered 1 and 2 days after stem-cell infusion. In the second report, peripheral blood stem cells were mobilized using cyclophosphamide and G-CSF, and the patient was conditioned with busulfan and ATG.654 In the third report, peripheral blood stem cells were mobilized using cyclophosphamide and G-CSF, and conditioned using a BEAM regimen plus cyclophosphamide plus ATG.655

In the Fagius study, both patients experienced stabilization of their disease course.653 One was alive at 35 months followup, with expanded disability status scale (EDSS) score reduced from 4.0 at HSCT to 0 at last followup. The second patient in the Fagius study was alive at 28 months, with EDSS score reduced from 8.0 at HSCT to 1.0 at followup. Adverse effects of autologous HSCT were not reported individually, but were as expected with the conditioning regimen, comprising fever, mucositis, and alopecia.

Kimiskidis and colleagues reported their patient showed rapid neurological improvement that was sustained and gradually increased following HSCT.654 His EDSS score dropped from 5.0 at HSCT to 1.5 at 66 months' followup. The patient experienced no relapses since HSCT, with no immunomodulatory therapies, and at publication had graduated from college.

Mancardi and colleagues reported results for two pediatric cases.655 The first patient was alive at 29 months' followup, with EDSS score reduced from 7.5 to 4.0, the ability to walk 500 meters unaided, independent in activities of daily living, and no relapses. HSCT-related adverse effects were not reported. The second patient was alive at 14 months' followup, with dramatically improved neurological condition and EDSS score reduced from 9.0 to 4.5; information was not provided about the patient's mobility or capability to perform activities of daily living. This patient experienced fever for two weeks post-HSCT, but no pathogen was identified.

In total, five pediatric patients with malignant MS have been reported alive following intense immune suppression and autologous HSCT. All had durable remission of severe, disabling disease and life-threatening disease for 14 to 66 months followup, improved EDSS scores, and improvement in neurological function. Where reported, mobility improved, along with the ability to perform activities of daily living. No patient relapsed in the followup periods reported.

##### Ongoing Research

According to ClinicalTrials.gov, there are no active clinical studies involving HSCT recruiting patients with any type of multiple sclerosis.

##### Conclusion

The overall body of evidence is insufficient to draw conclusions on long-term benefits or harms with single autologous HSCT for the treatment of severe, refractory MS in children.

Moderate strength evidence suggests that an extended drug-free clinical remission can be achieved with single autologous HSCT for the treatment of severe, refractory MS in children.

#### Crohn's Disease

##### Background and Setting

Crohn's disease is an idiopathic, chronic inflammatory disease of the gastrointestinal tract that primarily affects the small intestine and colon.

There is wide discrepancy in the prevalence and incidence estimates of Crohn's disease in North America.656 Prevalence has been estimated between about 44 to nearly 200 per 100,000 persons, perhaps representing the effect of environmental or genetic factors in its development. Similarly, incidence estimates vary considerably, from about 3.1 to about 5 cases per 100,000 person-years; the incidence in children is estimated at about 5 per 100,000. With about 300 million people in the United States, approximately 9,000 to 44,000 cases are diagnosed with Crohn's disease annually.

The natural history of Crohn's disease is characterized by recurring flares with periods of inactive disease and remission.657 The waxing and waning nature dictates that patients require medication for a large period of their life, primarily to maintain remission but also to control flares. About 50 percent of cases will remain in a state of remission or mild intermittent disease, but about 5 percent will have severe, drug-refractory disease.656 Surgery is required in up to 80 percent of cases at some point.657

While Crohn's disease-related mortality is relatively low, the range and severity of symptoms varies from mild to disabling. The most common symptoms of Crohn's disease are abdominal pain, often in the lower right area, and diarrhea. Rectal bleeding, weight loss, arthritis, skin problems, and fever may also occur. Bleeding may be serious and persistent, leading to anemia. Children with Crohn's disease may suffer delayed development and stunted growth. The most common complication is blockage of the intestine. Nutritional complications are common in Crohn's disease, with deficiencies of proteins, calories, and vitamins. These deficiencies may be caused by inadequate dietary intake, intestinal loss of protein, or poor absorption, also referred to as malabsorption. Other complications associated with Crohn's disease include arthritis, skin problems, inflammation in the eyes or mouth, kidney stones, gallstones, or other diseases of the liver and biliary system. Some of these problems resolve during treatment for disease in the digestive system, but some must be treated separately.

Current therapy for Crohn's disease consists of corticosteroids, immunomodulators and biological therapy blocking TNF-alpha (e.g., infliximab).657 Corticosteroids efficiently suppress inflammation, but have not been shown definitively to alter the natural course of Crohn's disease. Immunomodulators and biologicals such as azathioprine, 6-mercaptopurine, methotrexate, etanercept, and infliximab can induce and maintain remission, but their overall effect on the long-term course of Crohn's disease and the ultimate need for surgery are not definitively established.657 Their postoperative role also is not defined. In general, the optimal timing of therapies relative to disease course is not clear.

Autologous HSCT has been used to treat a small number of pediatric Crohn's disease cases, all of which have been severe, progressive, disabling, and refractory to nearly all drug therapies. Accordingly, this systematic review will present only results from HSCT reports, with the comparison considered usual care and the disease course.

##### Evidence Summary

The overall grade of strength of evidence for drug-free clinical remission and the use of HSCT for the treatment of severe, refractory Crohn's Disease is shown in Table 130.

Table 130 Overall grade of strength of evidence for drug-free clinical remission and the use of HSCT for the treatment of severe, refractory Crohn's disease

Key Question | Study Design | Risk of Bias | Consistency | Directness | Precision | Strength of Association | Overall Grade/Conclusion
For pediatric patients with severe, refractory, disabling Crohn's disease (CD), what is the comparative effectiveness and harms of autologous HSCT and drug therapies? All patients in these studies had severe, refractory, disabling disease, with very poor prognosis, so the comparator is usual care and natural history. Outcomes of interest include extended, drug-free clinical remission, TRM, and other long-term benefits and harms. | There is one case series that reports a total of 4 pediatric patients and one long-term follow-up study that reports 3 new pediatric patients. | The risk of bias is high. | The consistency of the evidence on TRM and long-term benefits and harms is unknown. The evidence is consistent in showing an extended drug-free interval and clinical remission can be achieved with autologous HSCT. | Drug-free clinical remission of severe, refractory, disabling CD in the short-term is considered a health outcome. There is direct evidence that an extended drug-free clinical remission can be achieved with autologous HSCT. The evidence comparing usual care is indirect. | The precision of the evidence for long-term benefits and harms is unknown. The evidence that an extended drug-free clinical remission can be achieved with autologous HSCT is precise. The precision of the evidence comparing usual care is unknown. | Not applicable due to lack of obvious effect size for adverse events including TRM. Strong strength of association for achieving an extended period of drug-free clinical remission following HSCT (7 of 7, 100%), ranging from 7 to 60 months. | The overall body of evidence is insufficient to draw conclusions on long-term benefits and harms with single autologous HSCT in children with severe, refractory, disabling CD. Although the overall body of evidence is insufficient to come to conclusions about the relative balance of benefits (e.g., increased overall survival) or harms (treatment-related mortality, secondary malignancies), moderate strength evidence suggests that an extended clinical remission, free from immune suppressant therapy following taper and discontinuation of corticosteroids 3-6 months post-HSCT, can be achieved with single autologous HSCT in children with severe, refractory, disabling CD.

The evidence signals that autologous HSCT following chemotherapy-induced immune suppression may be associated with prolonged resolution of severe, refractory, disabling Crohn's disease into a drug-free, much-improved state, 3 to 6 months post-HSCT.

##### Results

Two reports were included in this review. Table 131 shows the criteria that were used to select studies for this section.

Table 131 Crohn's disease study selection criteria

Study Design | Population | Intervention | Comparator | Outcomes | Followup | Setting
Any study design | Pediatric patients (0-21 yrs) with severe, refractory Crohn's Disease | Autologous HSCT | None applicable | Survival, drug-free remission post-HSCT, HSCT-related adverse events | All durations of followup | In-patient

One pilot study658 and one long-term follow-up study659 (Table 132) reported results on the use of autologous HSCT utilizing a conditioning regimen of high-dose cyclophosphamide plus equine or rabbit ATG and T-cell depleted CD-34+ enriched peripheral blood stem cells mobilized with cyclophosphamide and G-CSF. Mesna, methylprednisolone, and G-CSF were started in conjunction with the conditioning regimen.

Table 132 Crohn's disease study characteristics and population

Study | Design | Age Range (yrs) | Mean Age (yrs) | Sex F (%) | Disease Stage | HSCT (N) | Comparator (N) | Treatment Period
Oyama, 2005^658^ | Phase I | 15-21 | 17 ± 3 | 25 | Severe, disabling refractory to all standard treatments | 4 | NA | NR
Burt, 2010^659^ | Phase I/II | 16-21 | 18 | 33 | Severe, disabling, refractory to all standard treatments | 3 | NA | NR

Patients were 5 males, ages 15-21 years, and 2 females, ages 18 and 21 years. Pretransplant CDAI scores averaged 288 ± 37 (range: 101-337), with mean Karnofsky performance score (KPS) of 48 ± 10 (range: 40-60). All were highly symptomatic, completely disabled, with a clinical history and histologic evidence of Crohn's disease, and had failed treatment with corticosteroids, mesalamine, metronidazole, azathioprine, 6-mercaptopurine, and infliximab. Failure was defined as a Crohn's Disease Activity Index (CDAI) of 250-400 despite those therapies. All immunosuppressive and disease-modifying agents were discontinued at stem-cell mobilization, except systemic corticosteroids, which were tapered over 2 to 6 months. The key outcome was clinical remission, defined as CDAI≤150, and freedom from immune suppressant therapy following taper and discontinuation of corticosteroids post-HSCT. Adverse effects of autologous HSCT were also reported.

In the Oyama pilot study, all patients were alive at mean followup of 24 ± 15 months (range: 7-36 months).658 They had a rapid and dramatic post-HSCT improvement, discontinued all immunosuppressive therapies, regained normal appetite and oral intake, with cessation of diarrhea and abdominal pain. The mean CDAI score improved by 77 percent, declining from 288 ± 37 (range: 250-337), to 66 ± 13 (range 51-78). The mean Karnofsky Performance Status improved by 92 percent, from 48 ± 10 (range: 40-60) to 92 ± 10 (range: 80-100). Adverse HSCT-related events were not individually documented, but the procedure was reported as well tolerated. One patient (not identified) developed Mallory-Weiss syndrome that responded to intravenous fluids. One patient (unidentified) relapsed at 15 months after achieving remission at 6 months. Among the total patient population (pediatric cases not reported separately), after a median follow-up of 18 months (range 7-37 months) 11 of 12 remained in drug-free clinical remission.

In the second report,659 all 3 patients not previously reported in the Oyama paper658 were alive at 60 months follow-up, in an immune suppressant drug-free state but still with active Crohn's disease. All had undergone colectomy with or without ileostomy at 18 to 44 months following HSCT.

##### Ongoing Research

According to ClinicalTrials.gov, two Phase I clinical trials in the U.S. are recruiting pediatric patients with severe Crohn's disease (CDAI>250) for autologous HSCT (NCT00692939, NCT00278577).

##### Conclusion

The overall body of evidence is insufficient to draw conclusions on long-term benefits and harms with single autologous HSCT in children with severe, refractory, disabling CD.

Moderate strength evidence suggests that an extended clinical remission, free from immune suppressant therapy following taper and discontinuation of corticosteroids 3-6 months post-HSCT, can be achieved with single autologous HSCT in children with severe, refractory, disabling CD.

#### Miscellaneous Nonhematologic Autoimmune Diseases

##### Background and Setting

###### Myasthenia Gravis

Myasthenia gravis is an autoimmune disease characterized by failure of neuromuscular transmission secondary to destruction of acetylcholine receptors at the neuromuscular junction synapse by anti-acetylcholine antibodies.660 The estimated incidence of Myasthenia gravis is about 1 per 30,000.^661^ It typically presents in adulthood, but has been diagnosed in children as young as one year of age. Myasthenia gravis affects women more than men (67 percent of cases), with a peak onset in the 20s. Spontaneous remissions occur in about 25 percent of patients, but rarely last more than two years and do not typically recur.

Myasthenia gravis is controlled in most cases by the use of acetylcholinesterase inhibitors, but more severe, progressive disease is treated with immunomodulating approaches, including IVIG, corticosteroids, azathioprine, thymectomy, and plasmapheresis.661 High-dose cyclophosphamide has been used to treat severe MG, with good initial response in 90 percent of cases, although 80 percent have recurrence and require continual immunosuppression by 5 years following treatment.662 High-dose chemotherapy with allogeneic HSCT has been reported in one case of severe, refractory disease.

###### Calcinosis Cutis

Calcinosis cutis is a term used to describe a group of disorders in which calcium deposits form in the skin, first described by Virchow in 1855. It occurs in four major types according to etiology: dystrophic, metastatic, iatrogenic, and idiopathic. It may be associated with autoimmune diseases such as dermatomyositis, systemic lupus, systemic sclerosis, and others.663, 664 The incidence and prevalence of calcinosis cutis in the U.S. is unknown.

Damage caused by calcium deposits may be localized or systemic. Lesions may become painful, limit mobility of an adjacent joint, or compress adjacent neural structures. Ulceration and secondary infection may occur. Vascular calcification may cause ischemia and necrosis of the affected organ. Medical therapy is limited and of unproven benefit. Intralesional corticosteroids, probenecid, colchicine, magnesium or aluminum antacids, sodium etidronate and diphophosphonates, myoinositol hexaphosphonate, warfarin, diltiazem, sodium thiosulfate may be effective. Pediatric use of most of these agents is unapproved.

High-dose immunoablation with allogeneic HSCT has been reported in one pediatric patient with diffuse, severe refractory calcinosis cutis.

###### Overlap Syndrome

An overlap syndrome is an autoimmune disease of connective tissue in which the patient presents with symptoms of two or more diseases. As many as 25 percent of all patients with connective tissue disease show signs of an overlap syndrome. Examples of overlap syndromes include mixed connective tissue disease and scleromyositis, but the exact diagnosis depends from which diseases the patient shows symptoms. In overlap syndromes, features of systemic lupus, systemic sclerosis, polymyositis, dermatomyositis, rheumatoid arthritis and Sjögren's syndrome are found often.665

The prevalence of mixed connective tissue disease is not known precisely, falling somewhere between that of systemic sclerosis and polymyositis and systemic lupus. It is found more often in females than males (8:1 ratio), and occurs in children. Morbidity is greater in children than adults, with higher prevalence of myocarditis, glomerulonephritis, thrombocytopenia, seizures, and aseptic meningitis.665

Mixed connective tissue disease is viewed as incurable, with variable prognosis. The presentation ranges from mild self-limited disease, to major organ involvement that requires aggressive treatment. No controlled clinical trials have been performed to evaluate therapy in mixed connective tissue disease. Treatment strategies generally involve conventional therapies that are used for other autoimmune diseases such as systemic lupus, systemic sclerosis, and polymyositis. Given the heterogeneous clinical course of mixed connective tissue disease, therapy is individualized according to specific organ involvement and the severity of underlying disease activity. Agents include corticosteroids, antimalarials, methotrexate, cytotoxics (most often cyclophosphamide), and vasodilators, with varying degrees of success.666

Nonmyeloablative allogeneic HSCT has been reported in one severe, refractory pediatric case.

##### Evidence Summary

The overall grade of strength of evidence for drug-free clinical remission and the use of HSCT for the treatment of severe, refractory myasthenia gravis, overlap syndrome, or diffuse calcinosis cutis is shown in Table 133.

Table 133 Overall grade of strength of evidence for drug-free clinical remission and the use of HSCT for the treatment of severe, refractory myasthenia gravis, overlap syndrome, or diffuse calcinosis cutis

Key Question | Study Design | Risk of Bias | Consistency | Directness | Precision | Strength of Association | Overall Grade/Conclusion
For pediatric patients with severe, refractory myasthenia gravis (MG), overlap syndrome (OS), and cutaneous cutis (CC), what are the comparative effectiveness and harms of HSCT and drug therapies? Patients in these reports had severe, refractory, disease, with very poor prognosis, so the comparator is usual care and natural history. Outcomes of interest include long-term drug-free clinical remission, TRM, and other long-term benefits and harms. | There are three case reports on a total of 3 pediatric patients. | The risk of bias is high. | The consistency of evidence cannot be determined for the use of allogeneic HSCT to treat MG or OS, and autologous HSCT to treat CC. The consistency of the evidence for TRM and other long-term benefits and harms of HSCT cannot be determined. | Drug-free clinical remission of severe, refractory autoimmune disease in the short-term is considered a health outcome. There is direct evidence that an extended drug-free clinical remission can be achieved with allogeneic HSCT in MG or OS. There is direct evidence that an extended drug-free clinical remission for at least 2 years can be achieved with autologous HSCT in CC. The evidence comparing usual care is indirect. | The precision of the evidence for HSCT in MG, OS, and CC cannot be determined. The precision of the evidence for TRM and other long-term benefits and harms cannot be determined. | Not applicable due to lack of obvious effect size. | The overall body of evidence is insufficient to draw conclusions on benefits and harms with allogeneic HSCT to treat severe, refractory MG or OS, and autologous HSCT for the treatment of severe, refractory CC is insufficient to draw conclusions. The overall body of evidence is insufficient to demonstrate that an extended drug-free remission can be achieved with allogeneic HSCT to treat severe, refractory MG or OS, and autologous HSCT for the treatment of severe, refractory CC.

One case report each showed prolonged resolution of myasthenia gravis or overlap syndrome into a drug-free, much-improved state following chemotherapy-induced immunosuppression with allogeneic HSCT. Similarly, immunosuppression and autologous HSCT was followed by complete resolution of disabling diffuse calcinosis cutis in one patient.

##### Results

A total of three reports for these miscellaneous diseases were included in this review. Table 134 shows the criteria that were used to select studies for this section.

Table 134 Study selection criteria: MG, OS, CC

Study Design | Population | Intervention | Comparator | Outcomes | Followup | Setting
Any study design | Pediatric patients (0-21 yrs) with severe, refractory myasthenia gravis, overlap syndrome, and cutaneous cutis | Autologous or allogeneic HSCT | None applicable | Survival, drug-free remission post-HSCT, HSCT-related adverse events | All durations of followup | In-patient

As shown in Table 135, three case reports are available, one each on the use of allogeneic HSCT to treat myasthenia gravis667 or overlap syndrome,668 and one on autologous HSCT to treat calcinosis cutis.669

Table 135 Miscellaneous nonhematologic autoimmune disease study characteristics and population

Study | Design | Age Range (yrs) | Mean Age (yrs) | Sex F (%) | Disease Stage | HSCT (N) | Comparator (N) | Treatment Period
Strober, 2009^667^ | Case report | 17 | NA | M | Intractable myasthenia gravis, previously treated with pyridostigmine, IVIG, corticosteroids, thymectomy, azathioprine, mycophenolate mofetil, rituximab, and cyclophosphamide | Matched sibling allogeneic | NA | NR
Elhasid, 2004^669^ | Case report | 16 | NA | F | Severe, disabling refractory diffuse calcinosis, previously treated with corticosteroids, cyclophosphamide, azathioprine, methotrexate, hydroxychloroquine, and thalidomide | Autologous | NA | NR
Jones, 2004^668^ | Case report | 15 | NA | F | Severe, refractory overlap syndrome and pulmonary small vasculitis, previously treated with corticosteroids, methotrexate, cyclophosphamide, IVIG, NSAIDs, aspirin | Related donor allogeneic | NA | 2002

The myasthenia gravis case report outlined the outcome of reduced-intensity, matched-sibling, peripheral blood allogeneic HSCT using busulfan, fludarabine, and alemtuzumab.667 The patient was severely affected 17-year-old male who had failed prior treatment with pyridostigmine, IVIG, corticosteroids, thymectomy, azathioprine, mycophenolate mofetil, plasmapheresis, rituximab, and high-dose cyclophosphamide.

The patient with overlap syndrome was a 15-year-old female with pulmonary vasculitis, severe Cushing's syndrome, stunted growth, profound adrenal steroid dependency, and iatrogenic liver toxicity secondary to failed treatment with methotrexate and cyclophosphamide.668 She underwent reduced-intensity allogeneic HSCT using fludarabine, cyclophosphamide, and total body irradiation, followed by infusion of HLA-matched bone marrow stem cells.

The third case report involved a 16-year-old female who had diffuse, severely disabling calcinosis cutis with arthritis, myalgia, anemia, recurrent pulmonary hemorrhage, CNS abnormalities, and painful skin ulcers.669 Her condition did not adequately respond to corticosteroids, cyclophosphamide, azathioprine, methotrexate, hydroxychloroquine, and thalidomide. She developed pulmonary hypertension and ischemic digital necrosis, at which time she was referred for high-dose immunosuppression and autologous HSCT. Peripheral blood stem cells were mobilized using cyclophosphamide and G-CSF, and reinfused following a conditioning regimen comprising BCNU, etoposide, cytarabine, and melphalan.

The patient with myasthenia gravis achieved T- and B-cell immune reconstitution within 7 months post-HSCT, and during the next 12 months was weaned off pyridostigmine, developed normal muscle strength and lost 60 pounds of weight.667 He experienced mucositis that required total parenteral nutrition and patient-controlled analgesia for 11 days, 1 episode of gram-positive bacteremia that resolved with vancomycin, and CMV reactivation that resolved with ganciclovir. His oropharyngeal muscles and speech normalized, although he still had ophthalmoplegia. At 40 months post-HSCT, despite the presence of elevated acetylcholine receptor antibody levels, he was free of all myasthenia gravis treatments, was able to play basketball, and was reported as completely independent.

The patient with overlap syndrome achieved greater than 90 percent donor chimerism at 12 months post-HSCT.668 She was weaned off methylprednisolone, IVIG, and asthma medications over the next year, her cushingoid features resolved, she grew approximately 7 inches over 3 years' followup and became a full-time student in a regular classroom. She had no evidence of clinical graft-versus-host disease or systemic infection over 36 months' followup, but continued to have occasional periods of fatigue and mild Gottron-like rash, which was reported to decrease in frequency at followup.

The patient with calcinosis cutis engrafted promptly, with no significant HSCT-related complications reported.669 She regained mobility and ability to perform unaided activities of daily living, such as sitting, standing, and walking. At 6 weeks post-HSCT, the subcutaneous calcinosis nodules began to liquefy and calcium salts extruded through her skin. Deep calcinosis plaques disappeared, all skin ulcers healed completely, and her pulmonary blood pressure normalized. At 24 months' followup, the patient was free from clinical and laboratory evidence of disease activity.

##### Ongoing Research

According to ClinicalTrials.gov, one Phase I study is recruiting patients with severe, refractory myasthenia gravis for autologous HSCT (NCT00424489). A Phase I study is recruiting patients with severe, refractory systemic vasculitis and overlap syndrome for autologous HSCT (NCT00278512). No studies are recruiting for HSCT in patients with calcinosis cutis.

##### Conclusion

The overall body of evidence is insufficient to draw conclusions on benefits and harms with allogeneic HSCT to treat severe, refractory MG or OS, and autologous HSCT for the treatment of severe, refractory CC is insufficient to draw conclusions.

The overall body of evidence is insufficient to demonstrate that an extended drug-free remission can be achieved with allogeneic HSCT to treat severe, refractory MG or OS, and autologous HSCT for the treatment of severe, refractory CC.

#### Hematologic Autoimmune Diseases

##### Background and Setting

###### Evans Syndrome

Evans syndrome is an uncommon autoimmune disease characterized by simultaneous or sequential development of autoimmune thrombocytopenia and autoimmune hemolytic anemia, with some patients also being neutropenic.670-672 While the etiology is unknown, evidence suggests this disease is secondary to a more generalized immune dysregulation, with several clinical and laboratory features in common with systemic lupus and autoimmune lymphoproliferative syndrome.671, 673

The exact frequency of Evans syndrome is unknown. Familial occurrence is rare. It has a chronic, relapsing course, with substantial morbidity and mortality. In a 1997 survey of North American pediatric hematologists, the median reported age at diagnosis was about 8 years (range: 0.2–27 years).674 This late presentation age may indicate the disease was undiagnosed until the second presentation of cytopenia, which was usually months to years after the first presentation. Evans syndrome in adults has been anecdotally reported. No randomized trials have been conducted in patients with Evans syndrome, and the evidence for treatment is based on case reports, case series, and retrospective studies.675 Corticosteroids, IVIG, danazol, cyclosporine, azathioprine, cyclophosphamide, vincristine, rituximab, alemtuzumab, and splenectomy have been used, but response to therapy varies even within the same individual.

###### Autoimmune Hemolytic Anemia

Autoimmune hemolytic anemia occurs when an individual develops anti-self antibodies that destroy red blood cells. The incidence of autoimmune hemolytic anemia has been reported in the range of 1 per 50,000 to 75,000, rising with age, mostly as secondary rather than idiopathic disease.676 In children, the onset of autoimmune hemolytic anemia is more likely to be sudden and severe compared to that in adults. It has a relatively good prognosis in most cases, with good response to corticosteroids, and often not requiring splenectomy. It can develop into a refractory state that does not respond well to steroids, IVIG, azathioprine, cyclophosphamide, plasmapheresis, or splenectomy.

###### Autoimmune Thrombocytopenia

Chronic autoimmune thrombocytopenia is a disorder of diminished platelet count, secondary to the development of anti-self antibodies directed against platelet surface glycoproteins, resulting in splenic platelet destruction.677 Acute idiopathic thrombocytopenia purpura has an annual incidence in the U.S. of about 1.6 per 10,000, but it is estimated that chronic idiopathic thrombocytopenia purpura develops in 7 to 28 percent of children who have acute disease. Chronic, refractory autoimmune thrombocytopenia has been reported to have a mortality rate of 4 to 16 percent, largely attributed to bleeding or infection 678. It may respond to corticosteroids and IVIG, but can become refractory and nonresponsive to immunosuppressants that include cyclophosphamide, azathioprine, vinblastine, mycophenolate mofetil, and rituximab.

Given the poor response among a proportion of patients with severe Evans syndrome, autoimmune hemolytic anemia, and autoimmune thrombocytopenia to immunosuppressant therapies, with attendant serious adverse effects, HSCT has been investigated in a small number of children with severe, refractory Evans syndrome, autoimmune hemolytic anemia, and autoimmune thrombocytopenia.

##### Evidence Summary

The overall grade of strength of evidence for drug-free clinical remission and the use of HSCT for the treatment of severe, refractory Evans syndrome, autoimmune hemolytic anemia, or autoimmune thrombocytopenia is shown in Table 136.

Table 136 Overall grade of strength of evidence for drug-free clinical remission and the use of HSCT for the treatment of severe, refractory Evans syndrome, autoimmune hemolytic anemia, or autoimmune thrombocytopenia

Key Question | Study Design | Risk of Bias | Consistency | Directness | Precision | Strength of Association | Overall Grade/Conclusion
For pediatric patients with severe, refractory Evans syndrome (ES), autoimmune hemolytic anemia (AIHA), or autoimmune thrombocytopenia (AITP), what are the comparative effectiveness and harms of HSCT and drug therapies? Outcomes of interest include long-term drug-free clinical remission, TRM, and other long-term benefits and harms. | There are six case reports and two case series, for a total of 18 pediatric patients, who underwent HSCT for severe, refractory ES (n=8), AIHA (n=9), and AITP (n=1). | The risk of bias is high for all diseases evaluated. | The consistency of evidence cannot be determined for the use of allogeneic HSCT to treat severe, refractory ES or AIHA, or autologous HSCT to treat severe, refractory AIHA or AITP. | Drug-free clinical remission of severe, refractory autoimmune disease in the short-term is considered a health outcome. There is direct evidence that an extended drug-free clinical remission can be achieved with allogeneic HSCT for severe, refractory ES or AIHA and autologous HSCT for severe, refractory AIHA. | The precision of the evidence for allogeneic or autologous HSCT in severe, refractory ES, AIHA, or AITP cannot be determined. The precision of evidence on TRM and other long-term benefits and harms of HSCT cannot be determined. | Not applicable due to lack of obvious effect size. | The overall body of evidence is insufficient to draw conclusions about the comparative benefits or harms of single autologous or allogeneic HSCT compared to conventional therapy or disease natural history pediatric patients with severe, refractory ES, AIHA, or AITP. The overall body of evidence is insufficient to conclude that an extended drug-free clinical remission can be achieved with allogeneic HSCT for severe, refractory ES or AIHA and autologous HSCT for severe, refractory AIHA.

One case report each showed resolution of Evans syndrome or autoimmune hemolytic anemia into a drug-free, much-improved state following chemotherapy-induced immune suppression with allogeneic HSCT. Similarly, one case report showed resolution of severe, refractory autoimmune hemolytic anemia following autologous HSCT. The single case report of autologous HSCT for autoimmune thrombocytopenia showed no response to the procedure.

##### Results

A total of seven publications comprising eight studies (six case reports and two case series) on autoimmune hematologic conditions were included in this review. Table 137 shows the criteria that were used to select studies for this section.

Table 137 Study selection criteria: Refractory Evans syndrome, autoimmune hemolytic anemia, or autoimmune thrombocytopenia

Study Design | Population | Intervention | Comparator | Outcomes | Followup | Setting
Any study design | Pediatric patients (0-21 yrs) with severe, refractory Evans syndrome, autoimmune hemolytic anemia, or autoimmune thrombocytopenia | Allogeneic or autologous HSCT | None applicable | Survival, drug-free remission post-HSCT, HSCT-related adverse events | All durations of followup | In-patient

###### Evans Syndrome

Four studies (three case reports and one case series) described results of allogeneic HSCT in eight patients with severe, refractory Evans syndrome (Table 138).

Table 138 Evans syndrome, autoimmune hemolytic anemia, and autoimmune thrombocytopenia study characteristics and population

Study | Design | Age Range (yrs) | Mean Age (yrs) | Sex F (%) | Disease Stage | HSCT (N) | Comparator (N) | Treatment Period
Connor, 2008^680^ | Case report | 7 | NA | 100 | Severe, refractory ES | 1 | NA | NR
Urban, 2006^681^ | Case report | 6 | NA | 0 | Severe, refractory ES | 1 | NA | 2003
Raetz, 1997^682^ | Case report | 5 | NA | 0 | Severe, refractory ES | 1 | NA | NR
Daikeler, 2009^679^ | Case series | 2-21 | 11 | 0 | Refractory ES | 5 | NA | unselected (1984-2007)
Paillard, 2000^683^ | Case report | 8 | NA | 0 | Severe, refractory AIHA | 1 | NA | 1998
De Stefano, 1999^684^ | Case report | 12 | NA | 0 | Severe, refractory AIHA | 1 | NA | NR
Daikeler, 2009^679^ | Case series | 2-14 | 7 | 29% | Refractory AIHA | 7 | NA | unselected (1984-2007)
Huhn, 2003^685^ | Case report | 17 | NA | 0 | Severe, refractory AITP | 1 | NA | NR

The case series described 5 cases of Evans syndrome reported to the European Group for Blood and Marrow Transplantation (EBMT) registry between 1984 and 2007^679^. After receiving unspecified standard therapy, patients (100% male, age range 2-21) were referred for allogeneic HSCT (3 bone marrow, 1 peripheral blood, and 1 cord blood) with various combination conditioning regimens including cyclophosphamide, fludarabine, busulfan, thiotepa, ATG, TBI and received immunosuppressive cyclosporine A with either methotrexate or mycophenolate mofetil therapy for GVHD. Three patients were alive at 36, 85 and 113 months following allogeneic HSCT; one was dead from disease at 59 months and one was dead from interstitial pneumonitis at 6 months following allogeneic HSCT.679 All five patients were reported to have aGVHD (grade 1 n=1, grade 2 n=1, grade 3 n=1, NR n=2) and cGVHD (extensive: n=1, limited: n=1, NR: n=3), but no other HSCT-related adverse events were reported.

In the Connor et al. report, the female subject presented at age 6 months with Evans syndrome.680 Over the next several years, she was treated with corticosteroids, IVIG, cyclosporine A, mycophenolate mofetil, rituximab alone and with other drugs, and underwent a splenectomy, without experiencing durable remission. Her condition worsened, she developed pulmonary hypertension with dilated right ventricle and tricuspid regurgitation. She was referred for an unrelated, single-antigen mismatched allogeneic HSCT, using a conditioning regimen of alemtuzumab, fludarabine, and melphalan, with cyclosporine A and mycophenolate mofetil as graft-versus-host disease prophylaxis. The patient developed full donor chimerism, was weaned off all immunosuppressants, developed normalized pulmonary pressures, and exhibited normal right ventricular size and function at 10 months following allogeneic HSCT.680 No HSCT-related adverse events were reported.

A second case report describes the results achieved with an unrelated cord blood HSCT in a 7-year old boy with severe, refractory Evans syndrome who failed a previous double autologous HSCT.681 His disease was poorly responsive to previous therapy, including corticosteroids, IVIG, cyclosporine A, mycophenolate mofetil, vincristine, vinblastine, cyclophosphamide, rituximab, and danazol. He became pancytopenic, with disfiguring hypercorticism and polyneuropathy, and underwent double high-dose chemotherapy with autologous HSCT, with temporary improvement. After suffering a massive intracranial bleed, he received a 7/10 HLA-matched female cord blood HSCT, with a conditioning regimen comprising busulfan, ATG, thiotepa and etoposide. The patient developed graft-versus-host disease with grade II skin, liver, and mucosa involvement that resolved after a short course of prednisone and cyclosporine A.681 At 1.5 years' followup, he was reported with 100 percent donor chimerism, normal blood counts, in good clinical condition, free of graft-versus-host disease and the need for immunosuppressant drugs.

The third case involved a nearly 5-year-old boy who presented with Evans syndrome at age 5 months.682 His disease responded poorly to courses of therapy with corticosteroids, IVIG, 6-mercaptopurine, danazol, cyclosporine, azathioprine, vincristine, and anti-D, with increasingly worse mucosal bleeding and intracranial hemorrhage. He was referred for a matched-sibling cord blood allogeneic HSCT, with a myeloablative conditioning regimen consisting of total body irradiation, followed by cyclophosphamide, and cyclosporine-A graft-versus-host disease prophylaxis. The patient engrafted with adequate absolute neutrophil count by day 16 post-HSCT.682 However, he developed graft-versus-host disease with severe pulmonary insufficiency that resolved promptly following high-dose corticosteroid treatment. He ultimately experienced fulminant hepatic failure of unknown origin 286 days after transplant, and died on day 289.

###### Autoimmune Hemolytic Anemia

One case series and two case reports describe results on the use of HSCT to treat severe, refractory autoimmune hemolytic anemia (Table 138). The first report involves a boy, 8 years of age, who had severe AIHA that was refractory to prednisone, IVIG, cyclophosphamide, plasmapheresis, and splenectomy.683 As a consequence of life-threatening anemia, he underwent initial high-dose immunosuppressive chemotherapy with cyclophosphamide plus ATG followed by infusion of peripheral blood stem cells that had been mobilized using G-CSF. Because his disease did not respond to the initial HSCT procedure, he was treated again with a high-dose BEAM regimen and infusion of autologous stem cells. The patient was considered to be in hematological remission at 35 days following autologous HSCT, with no infectious complications.683 Although he relapsed at 7 months; this resolved with a course of corticosteroids and he was reported in complete hematological remission at 20 months' followup.

The second autoimmune hemolytic anemia case was that of a 12-year-old male whose disease had failed to respond to prednisone, azathioprine, cyclosporine A, cyclophosphamide, and splenectomy.684 As his condition worsened, he underwent high-dose immunosuppression using thoraco-abdominal irradiation, cyclophosphamide, and CAMPATH-1G followed by infusion of autologous peripheral blood stem cells mobilized using cyclophosphamide. He relapsed 7 weeks after HSCT, and underwent allogeneic HSCT with HLA-compatible unrelated donor bone-marrow stem cells following conditioning using busulfan, thiotepa, and fludarabine. Graft-versus-host disease prophylaxis comprised cyclosporine A, methotrexate, and ALG. The patient experienced an uncomplicated post-HSCT course, donor cell engraftment, restoration of normal immune system function, beneficial effects on body growth and skeletal deformities, with normal hemoglobin levels at 18 months after allogeneic HSCT without the need for immunosuppressant therapy.684

The case series reported on 7 cases of AIHA reported to the European Group for Blood and Marrow Transplantation (EBMT) registry between 1984 and 2007.^679^ After receiving unspecified standard therapy, patients (100% male, age range 2-21) were referred for allogeneic HSCT with various combination conditioning regimens including cyclophosphamide, fludarabine, busulfan, thiotepa, ATG, TBI and received immunosuppressive cyclosporine A with either methotrexate or mycophenolate mofetil therapy for GVHD. Of the 7 patients treated, 4 were alive at 3.9, 86, 112, 124 months, respectively. Three patients died during the study, one from hepatic VOD at 0.7 months of followup, one from infectious complications at followup of 1.4 months, and one died from disease progression at 5.2 months followup.679

###### Autoimmune Thrombocytopenia

One pediatric case of autoimmune thrombocytopenia was reported in a nonrandomized Phase I/II study that included patients who had severe autoimmune thrombocytopenia that had not responded to prednisone, IVIG, azathioprine, danazol, plasmapheresis, interferon, or splenectomy.685 This 17-year-old male underwent high-dose immunosuppression using cyclophosphamide followed by infusion of peripheral blood stem cells that were mobilized by G-CSF treatment (Table 138). The patient did not respond to autologous HSCT.685

##### Ongoing Research

According to ClinicalTrials.gov, no clinical trials of HSCT are recruiting patients with severe, refractory Evans syndrome, autoimmune hemolytic anemia, or autoimmune thrombocytopenia.

##### Conclusion

The overall body of evidence is insufficient to draw conclusions about the comparative benefits or harms of single autologous or allogeneic HSCT compared to conventional therapy or disease natural history pediatric patients with severe, refractory ES, AIHA, or AITP.

The overall body of evidence is insufficient to conclude that an extended drug-free clinical remission can be achieved with allogeneic HSCT for severe, refractory ES or AIHA and autologous HSCT for severe, refractory AIHA.