# Peer Reviewers

Morton Cowan, M.D.

Director, Bone Marrow Transplant Program

University of California San Francisco

San Francisco, CA

Ira Dunkel, M.D.

Pediatric Oncologist, Pediatric Medical Oncology

Memorial Sloan-Kettering Cancer Center

New York, NY

Naynesh Kamani, M.D.

Faculty, Blood and Marrow Transplant and Immunology

Children’s National Medical Center

Washington, D.C.

Sharon Gardner, M.D.

Associate Professor, Department of Pediatrics (Oncology Division)

New York University Pediatric Hematology Oncology

New York, NY

Naynesh Kamani, M.D.

Faculty, Blood and Marrow Transplant and Immunology

Children’s National Medical Center

Washington, D.C.

Michael Pulsipher, M.D.

Associate Professor, Pediatrics

University of Utah School of Medicine

Salt Lake City, UT