# Narrative Reviews

## Narrative Reviews: Malignant, Hematopoietic Disease

### Acute Lymphoblastic Leukemia

#### Acute Lymphoblastic Leukemia Background

Acute lymphoblastic leukemia (ALL) is the most common cancer diagnosed in children, accounting for 23 percent of cancer diagnoses among children younger than 15 years.15 An estimated 2,400 children and adolescents younger than 20 years are diagnosed with ALL annually in the United States. Although acute lymphoblastic leukemia is more common in children than in adults, the incidence shows a slight bimodal distribution, with a very high peak early in life (age 1 to 4 years) and a much lower peak after age 70 years.16 The incidence of ALL in children younger than 19 years of age in the United States in the year 2000 was 3.0 cases per 100,000. ALL is more common in white children than black children, with highest incidence among Hispanic children.15

Most cases of ALL do not have an identifiable genetic or environmental cause; it likely develops as a result of a combination of an environmental trigger (e.g., prenatal exposure to ionizing radiation, high postnatal dose of radiation) in individuals who have genetic susceptibilities such as upregulation of oncogenes or loss of inherent tumor suppressor proteins.15, 16 A number of germline genetic defects or clinical syndromes (e.g., Down syndrome, neurofibromatosis, Schwachman syndrome, Bloom syndrome, ataxia telangiectasia) have been associated with higher risk for developing acute lymphoblastic leukemia, but these collectively account for a small proportion of cases.

ALL typically presents with nonspecific signs and symptoms that include fever, anemia, fatigue, shortness of breath, petechiae or purpura, and CNS findings such as headache, nausea and vomiting, lethargy, and cranial nerve dysfunction.16 Total white blood count can be very low, or very high, ranging as high as greater than 100,000 per microliter. Patients may have low levels of neutrophils, erythrocytes, and platelets due to excessive acute lymphoblastic leukemia invasion of the bone marrow.

Morphologic, immunologic, and genetic methods are used to establish the diagnosis of any leukemia, its subtype, and specific type. For ALL, an individual prognostic risk profile is established.17-23 Childhood acute cases are divided into three risk groups: low, intermediate, and high. These groups also are referred to as standard, high, and very high.24 The Children's Oncology Group has used a four-category system that identifies patients with a very low probability of relapse.18 Infants fall into a special ALL subgroup that requires different treatment.25 Prognostic risk factors18 used to direct ALL treatment are summarized in Table 4. Detailed discussion of risk factors is beyond the scope of this review.

Table 4 Prognostic factors in pediatric acute lymphoblastic leukemia

Factor | Favorable | Intermediate | Unfavorable
Age (yrs) | 1 to 9 | ≥10 | <1 and MLL+
WBC count (× 10^9^/L) | <50 | ≥50
Immunophenotype | Precursor B cell | T cell
Genetic factors | Hyperdiploidy >50 DNA index >1.16 Trisomy 4, 10, 17 t(12;21)/ETV6-CBFA2 | Diploid t(1;19)/TCF3-PBX1 | t(9;22)/BCR-ABL1 t(4:11)/MLL-AF4 Hypodiploid < 44
CNS status | CNS1 | CNS2 Traumatic with blasts | CNS3
Minimal residual disease (end of induction) | <0.01% | 0.01% to 0.99% | ≥1%

CNS = central nervous system; WBC = white blood cell

Current management adjusts the intensity of ALL protocols according to specific presenting clinical and biologic features, as well as early treatment response, and is evolving with additional investigation. Therapy for most forms of ALL consists of four general phases: induction, intensification/consolidation, maintenance and early CNS prophylaxis. Induction therapy is started immediately, with the goal of achieving a CR, defined as fewer than 5 percent blast cells on morphological examination. Intensification or consolidation treatment is used after the patient achieves CR1, with the goal of long-term disease control and cure. Maintenance therapy typically continues in boys for 3 years and in girls for 2 years, with the goal to kill residual tumor cells.

#### ALL Evidence Base

The evidence base on the use of HSCT for treatment of pediatric ALL is summarized in Table 5. Evidence comprises systematic reviews, narrative reviews, genetically randomized clinical trials, as well as observational studies. A large number of HSCT procedures have been performed since the late 1960s. Two organizations, the European Group for Blood and Marrow Transplantation (EBMT) and the Center for International Blood and Marrow Transplant Research (CIBMTR) maintain data registries on HSCT procedures.

Table 5 Evidence base for HSCT in pediatric leukemia

Disease | Year First HSCT Performed | No. of Transplants to Date | Existing Clinical Evidence | Registries
Acute lymphoblastic leukemia | late 1960s | 5,064 HLA-matched sibling and unrelated donor transplants in patients younger than 20 years of age reported to CIBMTR for the period 1998–2007^32^ | Systematic reviews, narrative reviews, observational studies | CIBMTR, EBMT
Acute lymphoblastic leukemia | late 1960s | More than 10,000 HSCT in patients younger than 18 years old reported to EBMT between 1994 and 2008, of whom 6,315 underwent allogeneic or autologous HSCT for ALL | Systematic reviews, narrative reviews, observational studies | CIBMTR, EBMT
Acute and chronic myelogenous leukemia, myelodysplasia, juvenile myelomonocytic leukemia | late 1960s | 9,577 HLA-matched sibling and unrelated donor transplants in patients younger than 20 years of age reported to CIBMTR for the period 1998–2007^32^ | Systematic reviews, narrative reviews, genetically randomized clinical trials, observational studies | CIBMTR, EBMT
Acute and chronic myelogenous leukemia, myelodysplasia, juvenile myelomonocytic leukemia | late 1960s | More than 30,000 HSCT in patients younger than 18 years of age reported to EBMT between 1970 and 2002, of whom about 10,000–11,000 underwent allogeneic HSCT for AML and myelodysplasia33 | Systematic reviews, narrative reviews, genetically randomized clinical trials, observational studies | CIBMTR, EBMT

AML = acute myelogenous leukemia; CIBMTR = Center for International Bone Marrow Transplant Research; EBMT = European Group for Blood and Marrow Transplantation; HSCT = hematopoietic stem cell transplant

#### ALL Guidelines

In 2005, the American Society for Blood and Marrow Transplantation (ASBMT) published a systematic review and expert consensus panel recommendations for the role of cytotoxic therapy and HSCT in children with ALL.26 These remain the most comprehensive recommendations for this indication and population, and are summarized in Table 6. It should be noted, however, that revised guidelines were in preparation at the time this CER was submitted to AHRQ in 2011, and were unavailable for use here.

Table 6 ASBMT treatment recommendations for therapy of pediatric acute lymphoblastic leukemia

Indication for SCT | Treatment Recommendation^*^ | Highest Level of Evidence^**^ | Comments
SCT vs. chemotherapy in CR1 | B | 2++ | Demonstrated benefit only for matched related allogeneic SCT in very high-risk (Ph+ only) ALL. Not recommended for standard or other high-risk (i.e., induction failure, hypodiploidy, etc.) patients except in the context of clinical trial.
SCT vs. chemotherapy in CR2 | B | 2++ | Recommended only for matched related allogeneic transplantation vs. chemotherapy; however, the recommendation is tempered because of one prospective trial that did not demonstrate a benefit for transplantation when analyzed by the presence vs. absence of a related donor in an intent-to-treat analysis. Evidence is insufficient to support a recommendation for an unrelated allogeneic transplantation vs. chemotherapy.
Autologous purged SCT | C | 2++ | Although a majority of patients with late relapses achieve extended leukemia-free survival (LFS) with an autologous purged SCT, the evidence is insufficient to determine that this is better than chemotherapy alone. For those with an early relapse, the outcomes with autologous purged SCT are even less promising.
Autologous unpurged SCT | N/A | N/A | Data are unavailable on outcomes of unpurged autologous SCT.
Related allogeneic SCT | C | 2++ | A substantial proportion of patients achieve extended LFS.
Unrelated allogeneic SCT | C | 2++ | A substantial proportion of patients achieve extended LFS.
Related vs. unrelated allogeneic SCT | None | 2++ | Outcomes of related vs. unrelated donor allogeneic SCT have not been adequately studied, especially in patients who have had high resolution typing. No recommendation can be made at this time.
Comparison of conditioning regimens | B | 1+ | TBI-containing regimens have better outcomes than non-TBI containing regimens.
Autologous vs. allogeneic SCT | None | 2+ | The outcomes of autologous vs. allogeneic SCT have not been adequately studied. No recommendation can be made at this time.

ALL = acute lymphoblastic leukemia; ASBMT = American Society for Blood and Marrow Transplantation; CR = complete remission; LFS = leukemia-free survival; SCT = stem cell transplant; TBI = total body irradiation

* Grades of recommendation:

A At least one meta-analysis, systematic review, or randomized controlled trial (RCT) rated as 1++, and directly applicable to the target population; or a systematic review of RCTs or a body of evidence consisting principally of studies rated as 1+, directly applicable to the target population, and demonstrating overall consistency of results

B A body of evidence including studies rated as 2++ directly applicable to the target population, and demonstrating overall consistency of results; or extrapolated evidence from studies rated as 1++ or 1+

C A body of evidence including studies rated as 2+ directly applicable to the target population and demonstrating overall consistency of results; or extrapolated evidence from studies rated as 2++

D Evidence level 3 or 4; or extrapolated evidence from studies rated as 2+

** Levels of evidence:

1++ High-quality meta analyses, systematic reviews of randomized controlled trials (RCTs), or RCTs with a very low risk of bias

1+ Well-conducted meta analyses, systematic reviews of RCTs, or RCTs with a low risk of bias

1 - Meta-analyses, systematic reviews of RCTs, or RCTs with a high risk of bias

2++ High-quality systematic reviews of case-control or cohort studies. High-quality case-control or cohort studies with a very low risk of confounding, bias, or chance and a high probability that the relation is causal

2+ Well-conducted case control or cohort studies with a low risk of confounding, bias, or chance and a moderate probability that the relation is causal

2- Case control or cohort studies with a high risk of confounding, bias, or chance and a significant risk that the relation is not causal

3 Nonanalytic studies, e.g., case reports, case series

4 Expert opinion

#### ALL Summary

Contemporary treatment for newly diagnosed pediatric ALL aims to achieve complete first remission (CR1), with restoration of normal hematopoiesis, in about 1 to 1.5 months using chemotherapy.23 In most study groups, this is achieved in approximately 98 percent of patients using three agents (a glucocorticoid, vincristine, and L-asparaginase) to which an anthracycline may be added.15, 18, 20 Long-term event-free survival can now be expected in some 80 percent of children overall who achieve CR1 with modern risk-adapted chemotherapy. However, outcomes vary, such that in children who meet good-risk criteria (e.g., age 1 to 9 years, white blood count less than 50,000 per μL), EFS rates exceed 85 percent, whereas in those with high-risk age and white blood count criteria EFS rates approximate 70 percent. Use of additional criteria to further stratify treatment can identify patient groups with expected EFS rates ranging from less than 40 percent to more than 95 percent.

Among children with standard or good-risk disease who are in CR1, physicians attempt to limit postremission use of alkylating agents or anthracyclines that are associated with increased risk of late toxic effects. HSCT is generally not indicated in these cases.21, 23, 26 High-risk cases require more intensive consolidation that may entail the use of higher cumulative doses of multiple agents, including anthracyclines or alkylating agents and combinations thereof. Some 10 to 20 percent of patients with ALL are classified as very high risk, including infants, those with adverse cytogenetic abnormalities (e.g., t[4;11]; t[9;22] or low hypodiploid) and those with poor response to induction therapy with high end-induction minimal residual disease or high absolute blast count. These patients receive multiple cycles of intensive induction and consolidation chemotherapy, often including agents not used upfront for standard and less high-risk cases.

Despite such intense regimens and reported long-term event-free survival rates in high-risk patients (Table 7), they may be considered for allogeneic HSCT in CR1.^15, 21^ Some patients with late bone marrow relapse and isolated extramedullary relapses may be successfully treated with chemotherapy.27 However, HSCT is indicated for pediatric patients with ALL beyond CR1.^21, 23, 26^

Table 7 Benefits and harms after treatment for pediatric leukemia

Disease | Source | Treatment | Indications | Benefits | Harms | Comment
Acute lymphoblastic leukemia | Narrative review34 | allogeneic HSCT | CR1 Ph+ | DFS: 65 ± 8% (n=276)^k^ OS: 72 ± 8% k | NR | DFS p<0.001 MRD vs. chemotherapy at 5 years OS p=0.002 MRD vs. chemotherapy at 5 years
Acute lymphoblastic leukemia | Narrative review34 | chemotherapy | CR1 Ph+ | DFS: 25 ± 4%^k^ OS: 42 ± 4% a | NR | DFS p<0.001 MRD vs. chemotherapy at 5 years OS p=0.002 MRD vs. chemotherapy at 5 years
Acute lymphoblastic leukemia | Narrative review19 | allogeneic HSCT | CR1 infants | DFS: 64-76%^l-n^ | Fully ablative conditioning plus TBI increases risk for late effects on growth and neurocognitive development | Related and unrelated donors
Acute lymphoblastic leukemia | Narrative review19 | chemotherapy | CR1 infants | DFS: 33%^o^ | Relapse risk is high | Related and unrelated donors
Acute lymphoblastic leukemia | Narrative review19 | allogeneic HSCT | CR1 other high-risk | DFS: 56-76%^p-r^ | NR | B- or T-cell ALL, marked leukocytosis, hypodipolid, inadequate response to induction therapy, persistent minimal residual disease
Acute lymphoblastic leukemia | Narrative review19 | chemotherapy | CR1 other high-risk | DFS: 40-45%^p-r^ | NR | B- or T-cell ALL, marked leukocytosis, hypodipolid, inadequate response to induction therapy, persistent minimal residual disease
Acute lymphoblastic leukemia | Narrative review19 | allogeneic HSCT | Relapsed or salvage | DFS: 40-60%^s-v^ | NR | It is likely that the response to salvage treatment is influenced by the intensity of primary therapy.19
Acute lymphoblastic leukemia | Narrative review19 | chemotherapy | Relapsed or salvage | DFS≤33-44%^u,v^ | NR | It is likely that the response to salvage treatment is influenced by the intensity of primary therapy.19
Acute myelogenous leukemia | Systematic review35 | allogeneic HSCT | CR1 | DFS RR: 0.71 (95% CI 0.58, 0.95, p=0.00007) versus patients with no MSD who received additional chemotherapy or no further therapy after induction OS RR: 0.68 (95% CI, 0.48, 0.95, p=0.02) vs. patients with no MSD who received additional chemotherapy or no further therapy after induction | TRM RR = 0.97 (95% CI, 0.40, 2.38, p = 0.28) versus patients with no MSD who received additional chemotherapy or no further therapy after induction | DFS analysis based on all 6 included studies in meta-analysis between 1986 and 1995 with 3-7 yrs followup^a-f^ DFS RR reduction with allogeneic HSCT corresponds to absolute decrease in risk of relapse of; - 18% (95% CI, -0.24, -0.12) versus chemotherapy; OS RR reduction with allogeneic HSCT corresponds to an absolute difference in risk of death of; - 15% (95% CI, -0.05, -0.25) versus chemotherapy; OS analysis based on 4 studies^c-f^
Acute myelogenous leukemia | Systematic review35 | autologous HSCT | CR1 | DFS RR: 0.70-1.10 versus patients with no MSD who received additional chemotherapy or no further therapy after induction (data not pooled due to heterogeneity) OS RR: 0.71-1.34 versus patients with no MSD who received additional chemotherapy or no further therapy after induction (data not pooled due to heterogeneity) | TRM≤6% - 10% (data not pooled due to heterogeneity, total n = 404) | DFS risk difference= -17% versus patients with no MSD who received additional chemotherapy or no further therapy after induction^g^ OS risk difference= -14% versus patients with no MSD who received additional chemotherapy or no further therapy after induction^f^ TRM≤6% in 2 studies^a,d^ and 10% in a third study^f^
Acute myelogenous leukemia | Systematic review36 | allogeneic HSCT | CR1 | DFS: 47 ± 5% OS: 54 ± 5% | TRM = 17 ± 4% | Analysis included 5 consecutive genetic randomization CCG studies^e,f,h-j^ between 1979 and 1996 DFS p=0.075, 0.004 versus autologous HSCT and chemotherapy, respectively at 8 years followup OS p=0.031, 0.064 versus autologous HSCT and chemotherapy, respectively at 8 years followup TRM p=0.297, <0.001 versus autologous HSCT and chemotherapy, respectively at 8 years followup No statistically significant differences were reported for any outcome between chemotherapy and autologous HSCT
Acute myelogenous leukemia | Systematic review36 | autologous HSCT | CR1 | DFS: 42 ± 7% OS: 49 ± 7% | TRM = 7 ± 4%
Acute myelogenous leukemia | Systematic review36 | chemotherapy | CR1 | DFS: 34 ± 4% OS: 42 ± 4% | TRM = 6 ± 3%
Acute myelogenous leukemia | Narrative review37 | allogeneic HSCT | CR1 | DFS: 51-52% OS: 47-70% | NR | 3-5 yrs followup for DFS^a,g^ 5-8 years' followup for OS^d-f,i^ DFS p=0.01, 0.007 allogeneic HSCT versus autologous HSCT and chemotherapy, respectively OS p=0.002 allogeneic HSCT versus autologous HSCT OS p≤0.05–0.13 allogeneic HSCT versus chemotherapy
Acute myelogenous leukemia | Narrative review37 | autologous HSCT | CR1 | DFS: 21-38% OS: 48% | NR
Acute myelogenous leukemia | Narrative review37 | chemotherapy | CR1 | DFS: 27-36% OS: 34-60% | NR
Chronic myelogenous leukemia | Narrative review38 | allogeneic HSCT | CP1 Ph+ | OS: 66%^w^ DFS: 55%^w^ | TRM: 20% (MSD) TRM: 35% (URD) Grades 2-4 GVHD = 20% with MRD, 35% with URD^w^ | Survival data for patients with matched related sibling donor
Myelodysplasia and JMML | Prospective studies | allogeneic HSCT | Upfront, primary or secondary | OS: 31% JMML^x^ OS: 50% MDS^x^ DFS: 49-55% JMML^y^ | TRM: 13%^y^ | Patients with JMML and refractory anemia (RA) or RA-excess blasts exhibited high induction failure rates^x^ Actuarial OS at 6 years^x^ DFS 55% at 5 years with MRD, 49% with matched URD^y^ TRM at 5 years^y^

ALL= acute lymphoblastic leukemia; CCG= Children's Cancer Study Group; CR1= complete remission; DFS= disease free survival; GVHD= graft vs. host disease; HSCT= hematopoietic stem-cell transplantation; JMML= Juvenile myelomonocytic leukemia; MDS= myelodysplastic syndromes; MRD=matched related donor; NR= not reported; OS= overall survival; RA= refractory anemia ; RR= relative risk; CI= confidence interval; TRM= treatment related mortality; URD= unrelated donor

a Amadori et al., 1993^39^; RCT, n=161

b Michel et al., 1996^40^; prospective cohort study, n=171

c Shaw et al., 1994^41^; prospective cohort study, n=43

d Stevens et al., 1998^42^; RCT, n=359

e Wells et al., 1994^43^; RCT, n=591

f Woods et al., 1996^44^; RCT, n=589

g Ravindranath et al., 1996^45^; RCT, n=649

h Lange et al., 2004^46^; prospective study; n=65

i Smith et al., 2005^47^; RCT, n=485

j Woods et al., 1993^48^; prospective cohort study, n=142

k Arico et al., 2000^49^; retrospective study, n=326

l Jacobsohn et al., 2005^50^; prospective study, n=16

m Kosaka et al., 2004^51^; prospective study, n=44

n Sanders et al., 2005^52^; retrospective study, n=40

o Hilden et al., 2006^53^; prospective study, n=115

p Ribera et al., 2007^54^; RCT, n=106

q Satwani et al., 2007^55^; prospective study, n=28

r Schrauder et al., 2006^56^; prospective cohort study, n=387

s Boulad et al., 1999^57^; retrospective study, n=75

t Eapen et al., 2008^58^; prospective cohort study, n=209

u Einsiedel et al., 2005^59^; prospective study, n=207

v Gaynon et al., 2006^60^; RCT, n=214

w Cwynarski et al., 2003^61^; prospective study, n=314

x Woods et al., 2002^62^; prospective study, n=90

y Locatelli et al., 2005^63^; prospective study, n=100

As more pediatric ALL patients become long-term survivors, a host of treatment-related adverse events have assumed growing importance. These include cardiac late effects such as anthracycline-associated cardiomyopathy, neuropsychologic effects associated with methotrexate, endocrine deficits, and secondary malignancies such as AML associated with topoisomerase II inhibitor treatment or brain tumors associated with the use of radiotherapy.23, 28-30 Thus, leukemia survivors require regular examinations by physicians who are familiar with leukemia treatment and its associated risks and who are able to recognize early signs of adverse therapeutic sequelae. The Children's Oncology Group has published risk-based, exposure-related clinical practice guidelines intended to promote earlier detection of and intervention for complications secondary to treatment for pediatric malignancies.31 However, with the exception of GVHD, it is difficult to separate adverse effects associated with induction therapy and the subsequent consolidation treatment including HSCT.

### Acute Myelogenous Leukemia

The myelogenous leukemias comprise a spectrum of hematological malignancies. The vast majority (90 percent) are defined as acute, with the rest including chronic or subacute myeloproliferative disorders such as chronic myelogenous leukemia (CML), juvenile myelomonocytic leukemia (JMML) and myelodysplastic syndromes (MDS).64

#### Acute Myelogenous Leukemia Background

Approximately 6,500 children younger than 20 years of age develop an acute leukemia annually in the U.S.; acute myelogenous leukemia (AML) represents about 15 percent, or about 1,000 cases per year. The incidence of AML is stable during childhood, except for a slight increase during adolescence and a peak in the neonatal period.65 Some variation in the incidence of AML in children has been reported; for example, black children have an incidence of 5.8 cases per million compared to 4.8 cases per million among white children. The mortality rate from AML is estimated at 0.5 per 100,000 children younger than 10 years, and increases with age.

AML is a clonal malignancy that results from a series of somatic mutations in a hematopoietic multipotential cell, most commonly secondary to chromosomal translocations.65 Rarely, it may stem from a more differentiated, lineage-restricted progenitor cell. It is characterized by accumulation of abnormal (leukemic) blast cells, principally in the bone marrow, and impaired production of normal blood cells. Classification of myeloid leukemia as acute requires greater than 20 percent leukemic blasts in the bone marrow. In general, the clinical presentation of AML varies as a function of the leukemic cell burden within the bone marrow, with anemia, thrombocytopenia, and a low or normal absolute neutrophil count depending on the total white blood cell count. Other signs and symptoms may stem from invasion of extramedullary sites such as soft tissues, skin, gingiva, orbit, and brain.

There is a high concordance rate of AML in identical twins, and an estimated 2- to 4-fold risk of fraternal twins both developing AML up to about 6 years of age, suggesting the disease has a genetic component. AML also has been associated with syndromes that predispose to its development secondary to chromosomal translocations or instabilities, DNA repair defects, altered cytokine receptor or signal transduction pathway activation, and altered protein synthesis.64

Treatment of AML consists of remission-induction, followed by a course of consolidation therapy and subsequent intensification, which may include autologous or allogeneic HSCT.65, 66 Because the AML stem cell is inherently drug resistant, improvements in outcomes have been achieved through escalation of induction regimens to maximally tolerated dose levels that necessitate intensive supportive care measures. Further escalation and improvements in outcomes in AML are thus limited on the therapeutic side.

The therapeutic approach to a newly diagnosed pediatric patient with AML is dictated by a number of prognostic risk factors, including cytogenetics, mutations of signal transduction pathways, response to induction therapy, and others that may be termed novel.66, 67 Detailed discussion of risk factors is beyond the scope of this review, but several are summarized in Table 8 and will be referred to in this discussion.

Table 8 Potential risk factors for pediatric acute myelogenous leukemia

Prognostic Factor Category | Poor Risk | Favorable Risk
Cytogenetics | Deletion of chromosome 5q | t(15;17)
Cytogenetics | Monosomy of chromosome 5 or 7 | inv(16)
Cytogenetics | t(6;9) | t(8;21)
Cytogenetics | Abnormal chromosome 3 | t(9;11)
Cytogenetics | Complex cytogenetics
Mutations of signal transduction pathways | FLT3/ITD, high ITD-AR | CEBP-α mutation
Mutations of signal transduction pathways | c-KIT | NPM mutation
Mutations of signal transduction pathways | c-Fms
Mutations of signal transduction pathways | VEGF receptor
Mutations of signal transduction pathways | N- and K-RAS
Response to therapy | Poor response | Rapid response
Response to therapy | Minimal residual disease
Novel markers | High WT1 expression | Gene expression profile
Novel markers | High VEGF expression | Proteomic signature
Novel markers | High BAALC expression
Novel markers | Telomerase activity
Novel markers | Gene expression profile
Novel markers | Proteomic signature

BAALC = brain and acute leukemia, cytoplasmic; CEBP-α = CCAAT/enhancer binding protein-alpha; FLT3/ITD = FLT3/internal tandem duplication; ITD-AR = internal tandem duplication allelic ratio; NPM = nucleophosmin; VEGF = vascular endothelial growth factor; WT1 = Wilms' tumor

#### AML Evidence Base

The evidence base available on the use of HSCT for treatment of AML is summarized in Table 5. Published evidence comprises systematic reviews, narrative reviews, genetically randomized clinical trials, as well as observational studies. Two systematic reviews and one narrative review provide the basis for this evaluation. Also shown in Table 5, a large number of allogeneic HSCT procedures have been performed since the late 1960s. Two organizations, the European Group for Blood and Marrow Transplantation (EBMT), and in the U.S., the Center for International Blood and Marrow Transplant Research (CIBMTR), maintain data registries on HSCT procedures.

#### AML Guidelines

In 2007, the American Society for Blood and Marrow Transplantation (ASBMT) published a systematic review and expert consensus panel recommendations for the role of cytotoxic therapy and HSCT in children with AML.68 These remain the most comprehensive recommendations for this indication and population, and are summarized in Table 9. It should be noted, however, that revised guidelines were in preparation at the time this CER was submitted to AHRQ in 2011, and were unavailable for use here.

Table 9 ASBMT treatment recommendations for therapy of pediatric acute myelogenous leukemia

Indication for HSCT | Treatment Recommendation Grade^*^ | Highest Level of Evidence^**^ | Comments
Auto-SCT vs. chemotherapy in CR1 | A | 1++ | Auto-SCT and chemotherapy have equivalent survival outcomes. Lacking data on QOL, secondary malignancies and other late effects of treatment prevents a recommendation of one therapy over the other.
Allo-SCT vs. chemotherapy in CR1 | B | 2++ | Allo-SCT has superior OS and LFS compared with chemotherapy and is recommended Additional prospective data regarding risk subgroups may alter this recommendation.
Allo-SCT vs. chemotherapy in CR2 | D | 2- | There is a lack of evidence comparing MRD allo-SCT compared to chemotherapy in CR2; however, the consensus recommendation of the expert panel is MRD allo-SCT if available.
Auto-SCT vs. allo-SCT in CR1 | A | 1++ | MRD allo-SCT has superior survival outcomes compared to auto-SCT in CR1. Additional prospective data regarding risk subgroups may alter this recommendation. The consensus recommendation of the expert panel is to use bone marrow as the stem cell source in the MRD allo-SCT setting based on scientific, ethical, regulatory, and practical issues.
Auto-SCT vs. allo-SCT in CR2 | C | 2+ | The consensus recommendation of the expert panel is to use any suitably matched related or unrelated allo- over auto-SCT; however, there is a lack of evidence that one has better outcomes than the other.
Auto-SCT | No recommendation | 2+ | Current practice is to use PBSCT; however, there are very few patients in the 2 studies that fulfill review criteria. A randomized trial of auto-BMT vs. PBSCT is not feasible due to the infrequent use of auto-SCT for pediatric patients with AML. With current technology, there is a preference for using MUD or alternative donors over auto-SCT if a MRD is not available. There are no effective purging agents currently available, but if one were developed, it would increase interest for a trial of purged vs. unpurged auto-SCT.
Related vs. unrelated allo-SCT | D | 2+ | There are no data indicating that using one type of suitably matched allo-SCT is better than another. There are differences between institutions with regard to transplantation technique; however, there are no apparent differences in outcomes across institutions.
Related allo-SCT | B | 2+ | MRD allo-SCT is preferred in CR1 or CR2; in CR2, alternative donors could be considered if MRD is not available.
Unrelated allo-SCT | No recommendation | 2+ | No evidence for one preferred technique for unrelated allo-SCT (i.e., T cell depletion, cord blood vs. PBSCT vs. BMT, etc).
Comparison of allo-SCT myeloablative conditioning regimens | C | 2+ | There is no difference or preference of one conditioning regimen over another with respect to survival, LFS, or late effects.
Comparison of auto-SCT myeloablative conditioning regimens | No recommendation | NA | No evidence comparing conditioning regimens in the auto-SCT setting.
APL in CR1 | Not recommended | 4 | No evidence of a need for SCT.
APL in CR2 | D | 3 | Standard practice is to use allo-SCT (preferred) or auto-SCT if there is no suitable MRD, MUD, or alternative donor, or a trial comparing haploidentical allo- vs. auto-SCT.

* See Table 6 above for key to recommendation grades.

** See Table 6 above for key to levels of evidence.

#### AML Summary

Survival rates in children with AML have increased with time as a result of numerous clinical trials conducted within pediatric cooperative cancer groups.30, 35-38, 69 About 50 to 60 percent of newly diagnosed pediatric AML patients experience long-term survival with modern treatment and supportive care, as shown in Table 7. Chemotherapy and autologous and allogeneic HSCT are established methods in this setting, but there is uncertainty about when to use each. Current practice in European groups limits use of allogeneic HSCT in CR1 to patients with poor risk prognostic factors; in the U.S., patients with a matched sibling donor typically receive allogeneic HSCT in CR1.^38^ In general, patients who relapse and can be brought into CR2 will receive an allogeneic HSCT if a matched sibling donor is available, or if at very high risk, with an unrelated matched donor.38

Although the data compiled in Table 7 were not stratified according to prognostic risk factors, the evidence generally supports use of allogeneic HSCT in children with poor- to intermediate-risk disease in CR1, and all who have refractory AML or who relapse. Substantial effort is being expended on identification of additional prognostic markers at the genetic level with the aim of personalizing AML therapy to improve survival rates. Risk stratification also has potential to reduce the burden of associated adverse effects of the procedure by targeting therapy intensification to appropriate groups, with less-intensive treatment for those who would not benefit.66, 67

Adverse effects with HSCT in any disease are referable to all major organ systems including cardiovascular, CNS, endocrine, digestive, urinary, and reproductive, and include secondary malignancies and graft-versus-host disease.28, 29

The Children's Oncology Group has published risk-based, exposure-related clinical practice guidelines intended to promote earlier detection of and intervention for complications secondary to treatment for pediatric malignancies.31 However, with the exception of GVHD and treatment-related mortality, it is difficult to separate adverse effects associated with induction therapy and the subsequent consolidation treatment including HSCT.

### Chronic Myelogenous Leukemia

#### Chronic Myelogenous Leukemia Background

Chronic myelogenous leukemia (CML) is the most common of the chronic myeloproliferative disorders in children, but accounts for only 5 percent of childhood myeloid leukemia.64 It occurs in very young children, but the majority is found in patients aged 6 years and older. CML is a clonal panmyelopathy that involves all hematopoietic cell lineages. The white blood count may be extremely elevated in CML without evidence of excess leukemic blasts in the bone marrow, and is often associated with thrombocytosis. The Philadelphia chromosome, which is a translocation between chromosomes 9 and 22 (t[9, 22]), is nearly always present in CML. Bone marrow is hypercellular, with relatively normal granulocytic maturation. Biologically, CML in children is very similar to that in adults, so adult data are often extrapolated to children.38 It is the malignancy for which a graft-versus-leukemia (GVL) effect has most clearly been shown.70

CML occurs in three clinical phases: chronic, accelerated, and blast crisis. The chronic phase, which may last for 3 years, is associated with effects secondary to hyperleukocytosis, such as weakness, fever, night sweats, bone pain, and respiratory distress. The accelerated phase is characterized by progressive splenomegaly, thrombocytopenia, and increased proportion of peripheral and bone marrow blasts. In blast crisis, the bone marrow shows more than 30 percent blasts, with a clinical picture indistinguishable from acute leukemia. Patients who enter blast crisis will succumb to the disease within several months.71 This narrative review focuses on patients with chronic phase CML.

#### CML Evidence Base

The evidence base available on the use of HSCT for treatment of CML is summarized in Table 5. Published evidence comprises narrative reviews as well as observational studies. Allogeneic HSCT remains the only known curative modality for CML.

#### CML Guidelines

We identified no clinical guidelines for the use of HSCT in children with CML.

#### CML Summary

The EBMT reported outcomes in 314 children who received allogeneic HSCT in the pre-imatinib era. As shown in Table 7, the best results were achieved among children in chronic phase who received a matched sibling donor transplant (75 percent 3-year OS, 63 percent leukemia-free survival).61 Among patients who received an unrelated donor HSCT, procedural mortality reached 35 percent versus 20 percent with a MSD. Severe graft-versus-host disease (grades 2-3) occurred in 52 percent of unrelated donor HSCT recipients compared to 37 percent of recipients with a matched sibling donor. Similar results were reported by other groups who used allogeneic HSCT to treat children with chronic phase CML.72, 73

The introduction of imatinib mesylate (and newer tyrosine kinase inhibitors dasatinib and nilotinib) altered the paradigm of CML treatment, particularly in adults.74 However, there is no consensus how to treat newly diagnosed children with CML if a matched sibling donor is available.38, 75 Allogeneic HSCT may be delayed until imatinib fails to produce a major cytogenetic or molecular response, or if secondary resistance develops. However, relapse occurs in previously responding patients who stop imatinib. Thus, children with CML who achieve molecular disease control are typically managed individually. The decision and timing to proceed to allogeneic HSCT given the necessity for life-long imatinib therapy and the prospect of resistance developing remain uncertain.30

### Myelodysplastic Syndrome/Juvenile Myelomonocytic Leukemia

#### Myelodysplastic Syndrome/Juvenile Myelomonocytic Leukemia Background

In children, the myelodysplastic syndromes (MDS) comprise a heterogeneous group of disorders characterized by a constellation of ineffective hematopoiesis, impaired maturation of myeloid precursors with dysplastic morphologic features, and cytopenias.64 Myelodysplastic disorders have been defined by their predilection to evolve into AML, yet not all cases terminate in leukemia. Mortality in myelodysplasia syndrome results from bleeding, recurrent infection, and leukemic transformation. In the absence of treatment, myelodysplasia syndrome can be rapidly fatal, with or without the transformation to AML.

The exact incidence of MDS in childhood has been difficult to estimate because of controversies regarding its classification, the heterogeneity of presentation, and the heterogeneity of risk factors in the population. MDS may occur either de novo or secondary to previous therapy for cancer. The annual incidence internationally is estimated at 0.5 to 4 per million population, and myelodysplasia syndrome accounts for about 2 to 5 percent of hematologic malignancies in children.76 Fewer than 100 new cases of myelodysplasia are reported in the U.S. each year in children. The male-to-female ratio varies from 1.7 to 4.8:1 in different series.77

The significance of this male predominance is unclear but is attributed, in part, to the increased prevalence of juvenile myelomonocytic leukemia (JMML), which was previously termed “juvenile chronic myelogenous leukemia” (JCML), in boys and monosomy 7 syndrome in children.78 JMML is very rare, accounting for less than 1 percent of all childhood leukemias.

#### MDS/JMML Evidence Base

Given the rarity of MDS in children, randomized trials have not been performed specifically for this disease. Children with MDS have been included in AML studies, with allogeneic HSCT representing the only curative therapy.38 JMML historically has been fatal in more than 90 percent of patients despite the use of chemotherapy.64 Allogeneic HSCT is the only intervention that can provide long-term disease control.30 As shown in Table 5, available evidence includes narrative reviews that include information on MDS and JMML, and observational studies.

Outcomes data abstracted from recent narrative review articles on the use of HSCT to treat children with high-risk leukemias are summarized in Table 7.

#### MDS/JMML Guidelines

We identified no clinical guidelines for the use of HSCT in children with MDS, or JMML.

#### MDS Summary

Given the rarity of MDS in children, randomized trials have not been performed specifically for this disease. However, allogeneic HSCT is the only curative therapy.38 Children with MDS have been included in AML studies.62 This trial enrolled 77 patients with MDS or AML with antecedent MDS, randomly allocated to standard or intensively timed induction and subsequently to allogeneic HSCT if there was a suitable matched related donor, or to autologous HSCT or chemotherapy in the absence of a donor.62 Patients with refractory anemia (RA) or RA with excess blasts (RAEB) had a 45 percent remission rate and 6-year OS rate of 28 percent. Those with RAEB in transformation had a 69 percent remission rate and 30 percent 6 year OS rate. Patients with AML and history of MDS experienced an 81 percent remission rate and 50 percent OS rate with allogeneic HSCT, which was marginally significant compared to chemotherapy (p=0.08). The Children's Cancer Study Group investigators conclude that children with a history of MDS who present with AML (excluding those with monosomy 7) and a proportion with RAEB in transformation will do as well with AML chemotherapy remission induction and HSCT consolidation as those with AML. Among MDS patients who achieve remission following induction, but for whom a suitable stem cell donor is not available, optimum therapy is not established.64

#### JMML Summary

JMML historically has been fatal in more than 90 percent of patients despite the use of chemotherapy.64 Allogeneic HSCT is the only intervention that can provide long-term disease control.30 In a study of 100 JMML patients, OS of 64 percent has been reported at 5 years.63 Among patients who had disease recurrence, 7 of 15 who underwent a second allogeneic HSCT survived free of disease. In a retrospective National Marrow Donor Program registry analysis, 46 JMML patients who underwent unrelated donor allogeneic HSCT achieved a 2-year DFS rate of 24 percent with relapse probability of 58 percent.79

### Childhood Hodgkin's Lymphoma

Lymphomas, which are broadly divided into Hodgkin's lymphoma (HL) and non-Hodgkin's lymphoma (NHL) constitute 15 percent of all childhood cancers, and are the third most common childhood malignancy.80

#### Hodgkin's Lymphoma Background

Hodgkin's lymphoma, which comprises 6 percent of childhood cancers, shows a bimodal age incidence with most patients diagnosed between the ages of 15 and 30, and a second peak in adults 55 years of age and older. In the pediatric population, the incidence is highest among 15 to 19 year olds (29 per million per year), with children ages 10 to 14 years, 5 to 9 years, and 0 to 4 years having threefold, eightfold, and thirtyfold lower rates, respectively.81

Hodgkin's lymphoma, a B-cell lymphoma, is divided into two distinct subcategories, classical (which is characterized by multinucleated tumor cells known as Reed-Sternberg cells) and nodular lymphocyte predominant type (with large mononuclear tumor cells known as lymphocytic and histiocytic, or “L & H” cells), both with a background of inflammatory cells. Subtypes of classical HL include lymphocytic rich, nodular sclerosis, mixed cellularity and lymphocytic depleted. The most common subtypes seen in the pediatric population are the mixed cellularity, nodular lymphocyte predominant and nodular sclerosis.80

Most patients with Hodgkin's lymphoma present with painless adenopathy, commonly in the supraclavicular or cervical area. Whereas mediastinal involvement is present in approximately 75 percent of adolescents and adults, only about 35 percent of young children with Hodgkin's lymphoma have mediastinal presentation, in part because of the tendency of these patients to have disease with mixed cellularity or lymphocyte-predominant histology.81 Approximately 80 to 85 percent of children and adolescents with Hodgkin's lymphoma have involvement of lymph nodes and/or the spleen only (stages I-III), with the remaining 15 to 20 percent having noncontiguous extranodal involvement (stage IV).81 The most common extranodal sites include the lung, liver, bone, and bone marrow.81

Contemporary treatment programs use a risk-adapted approach in which patients receive multi-agent chemotherapy with or without low-dose involved field radiation.81 Prognostic factors considered include stage, presence or absence of B symptoms, and/or bulky disease.81 With current therapy, the long-term disease-free survival (DFS) in children with newly diagnosed localized and advanced-stage Hodgkin's lymphoma ranges between 85 to 100 percent and 70 to 90 percent, respectively.80

However, high-risk patients with Hodgkin's lymphoma whose disease is refractory to initial therapy or relapse after primary initial chemotherapy (particularly with early relapse at 12 months or earlier) have a minimal chance for long-term survival with salvage chemotherapy alone (with 5-year OS rates of 20 to 25 percent).80 Approximately 10 to 15 percent of patients with HL fail to achieve a complete remission (CR) or relapse, and it is in this population that more aggressive treatment strategies like HSCT are utilized.

#### Hodgkin's Lymphoma Evidence Base

The evidence compiled includes one review article, which summarizes the experience with autologous HSCT and childhood Hodgkin's lymphoma.80 There have been no randomized trials in the pediatric population with Hodgkin's lymphoma using HSCT, and the data consist of several small, retrospective case series as summarized in Table 10. Outcomes with the use of autologous HSCT and pediatric Hodgkin's lymphoma show a wide range, with an overall survival (OS) from 43 to 95 percent and event-free survival (EFS) from 31 to 62 percent (Table 11).82-86

Table 10 Pediatric lymphomas and the evidence base

Disease | Year First Transplant Performed | No. of Transplants to Date | Existing Dlinical Data | Registries
Hodgkin's Lymphoma | Late 1970s | Not determined | Literature Review, case series, registry data | The Center for International Blood and Marrow Transplant Research (CIBMTR) registry describes the use and outcome of autologous and allogeneic hematopoietic cell transplantation in the more than 500 centers participating in the CIBMTR. It is estimated that data are collected on nearly all allogeneic transplants performed in the U.S., approximately 25% of allogeneic transplants performed outside of the U.S. and approximately 60% of autologous transplants performed in North and South America. Prior studies suggest that these data are representative of transplants worldwide. For Hodgkin's and non-Hodgkin's lymphomas, the registry reports separate survival statistics for patients ≤20 years and >20 years of age. www.cibmtr.org/ReferenceCenter/SlidesReports/StatReport/index.html The European Group for Blood and Marrow Transplantation (EBMT) has an international registry which includes NHL and HL, with separate data for the pediatric population. www.ebmt.org/4Registry/registry1.html
Non-Hodgkin's Lymphoma | Late 1970s | Not determined | Literature Review, case series, registry data

Table 11 Benefits and harms after treatment for childhood Hodgkin's lymphoma

Disease | Source | Evidence Type | Treatment | Indication | Benefits | Harms
Hodgkin's lymphoma | Bradley and Cairo 2008^80^ | Literature Review | Autologous HSCT | Relapsed or refractory^a,b,c,d,e^ First, second and third CR, PR^c,e^ | 5-year OS 43-95% 5-year EFS 31-62% 5-year PFS 63% 5-year FFS 31%^a,b,c,d,e^ 3-year PFS 39%^e^ | Transplant-related deaths (including early and late) ranging from 0%-11.1% Risk of MDS/sAML is 4-20% at 5 years after autologous HSCT.

CR = complete response; EFS = event-free survival; FFS = failure-free survival; HSCT = hematopoietic stem-cell transplantation; MDS = myelodysplastic syndrome; OS = overall survival; PFS = progression-free survival; PR = partial remission; sAML = secondary acute myelogenous leukemia

a Stoneham et al. 2004^84^; n=51 case series, retrospective review of data from 8 centers transplanted between 1982-2000

b Lieskovsky et al. 2004^83^; n=41 case series, retrospective review of consecutive patients at one medical center transplanted between 1989-2001

c Verdeguer et al. 2000^85^; n=20 case series, retrospective review of clinical records from 8 hospitals transplanted between 1986-1997

d Baker et al. 1999^82^; n=53 case series transplanted between 1984 and 1996

e Williams et al. 1993^86^; n=81 case series of registry data, cases reported up to 1992. Eighty-one pediatric patients were case matched to adult patients from European Bone Marrow Transplant registry. Conclusions drawn included that pediatric patients with HL have the same outcome as their adult counterparts after autologous HSCT.

National Comprehensive Cancer Network (NCCN) clinical practice guidelines exist.87 No health technology assessments were identified in the search.

A case-matched comparison of autologous HSCT in the pediatric population (n=81) versus adult patients (n=81) with Hodgkin's lymphoma suggested that pediatric and adult patients with HL have similar EFS and OS.86

There have been two randomized trials in adult patients with relapsed or refractory Hodgkin's lymphoma, comparing standard-dose salvage chemotherapy and high-dose chemotherapy with autologous HSCT.88, 89 Both trials demonstrated significantly improved EFS and longer time to treatment failure in the HSCT group, but no significant difference in OS was observed between the two groups. Whether survival data from the adult population with Hodgkin's lymphoma can be extrapolated to the pediatric population is somewhat controversial.

In patients with Hodgkin's lymphoma who undergo HSCT, harms include secondary malignancies, including breast cancer and myelodysplastic syndrome/secondary acute myelogenous leukemia (MDS/sAML). In patients with recurrent lymphoma who undergo high-dose chemotherapy and autologous HSCT, the incidence of MDS/sAML is 4 to 20 percent at 5 years.80

#### Hodgkin's Lymphoma Guidelines

NCCN guidelines87 for the treatment of Hodgkin's lymphoma with HSCT state the best option for patients with progressive disease or relapse is high-dose therapy with autologous stem-cell rescue and that allogeneic transplant may be an option in select patients with progressive or relapsed disease.

#### Hodgkin's Lymphoma Summary

Overall there appears to be a favorable risk-benefit profile for the treatment of Hodgkin's disease with HSCT in patients with progressive disease or relapse, with OS and EFS rates ranging from 43 to 95 percent and 31 to 62 percent, respectively.80 Patients who fail following autologous HSCT or for patients who cannot mobilize sufficient numbers of autologous stem cells, allogeneic HSCT is an option.

Current recommendations are based on small numbers from five case series. Future challenges in the treatment of Hodgkin's lymphoma include the development of risk-stratified treatment approaches for patients with high-risk disease and the possible use of allogeneic HSCT where graft versus lymphoma has been demonstrated.80

### Childhood Non-Hodgkin's Lymphoma

#### Non-Hodgkin's Lymphoma Background

Non-Hodgkin's lymphoma (NHL) accounts for approximately 7 percent of cancers in children younger than 20 years of age.90 Whereas NHL in adults is more commonly low or intermediate grade, in the pediatric population almost all non-Hodgkin's lymphomas are high grade, and differ from disease in adults with respect to disease types, staging system, biology, treatment, and outcome.91 NHLs are broadly classified as being of B-cell, T-cell, or natural killer (NK) cell origin and by differentiation (precursor versus mature cell). NHLs in children and adolescence fall into three therapeutically relevant categories: (1) mature B-cell NHL: Burkitt and Burkitt-like lymphoma/leukemia (BL, 50 percent of pediatric NHL) and diffuse large B-cell lymphoma (DLBCL, 10-20 percent of pediatric NHL); (2) lymphoblastic lymphoma (LBL) primarily precursor T-cell and less frequently precursor B-cell (20 to 30 percent of pediatric NHL); and (3) anaplastic large cell lymphoma (ALCL), mature T-cell or null-cell lymphoma (10 percent). The other 10 percent of NHL observed in the pediatric population are comprised of diseases commonly seen in adults, such as follicular lymphoma, mucosa-associated lymphoid tissue (MALT) lymphoma, cutaneous lymphoma, primary central nervous system lymphoma or mature T-cell or natural killer-cell lymphoma.91 Approximately 100 of the 1,000 cases of childhood NHL that occur annually in the U.S. occur in children or adolescents with a primary or secondary immunodeficiency, and the majority are associated with Epstein-Barr virus.91 The ultimate goal in treating these patients is improving immune function.

Burkitt and Burkitt-like lymphoma (BL) consistently exhibit very aggressive clinical behavior and show overlapping characteristics with acute lymphoblastic leukemia. BL exhibits rapid growth rate, and a tendency to involve extranodal sites and to disseminate to the bone marrow and meninges. Common primary sites include the abdomen and pelvis and the head and neck. The diagnosis of Burkitt-like lymphoma is somewhat controversial due to overlapping histologic features with DLBCL. Cytogenetic evidence of C-MYC rearrangement is the gold standard for the diagnosis of BL. BL can be sporadic or endemic, with endemic cases being Epstein-Barr virus-related and occurring commonly in equatorial Africa.

Diffuse large B-cell lymphoma (DLBCL) in the pediatric population occurs more commonly in the second decade of life than the first. DLBCL differs biologically in children and adolescents than in adults (except for those that present as primary mediastinal disease, which represents approximately 20 percent of pediatric DLBCL). The characteristic chromosomal translocation seen in adult DLBCL, t(14;18), is rarely observed in pediatric DLBCL. Outcomes for children with DCBCL are more favorable than those seen in adults.

Lymphoblastic lymphoma (LBL) occurs most commonly in young men as an anterior mediastinal mass. Chromosomal abnormalities in LBL are not well characterized. The disease course is aggressive with frequent involvement of the bone marrow and/or central nervous system. Patients with limited disease may fare well, but those with poor-risk disease (defined as bone marrow or central nervous system involvement or LDH greater than 300 IU/L) or recurrent disease have less favorable outcomes.92

Anaplastic large cell lymphoma (ALCL) has a broad range of clinical presentations, including involvement of lymph nodes and extranodal sites, particularly skin and bone. More than 90 percent of cases have a characteristic chromosomal translocation t(2;5) which leads to expression of a fusion protein NPM/ALK, although variant ALK translocations also occur. ALCL is classified as a peripheral T-cell lymphoma (PTCL); however, ALK-positive ALCL has a superior prognosis to other forms of PTCL.

The St. Jude (Murphy) staging system is the most widely used for pediatric NHL, and differs from the Ann Arbor staging system (used in adult NHL) in the classification of abdominal, intrathoracic, and paraspinal/epidural disease.91 The most important prognostic variable in pediatric NHL is tumor burden, evaluated by staging and serum lactate dehydrogenase (LDH) level. Patients with stage III/IV disease and serum LDH greater than 400 U/L have significantly worse outcomes than those with LDH less than 400 U/L.

Unlike adults with NHL, who usually present with lymph node disease, most pediatric patients present with extranodal disease. Approximately 70 percent of children with NHL present with advanced disease and/or have involvement of the bone marrow, central nervous system and/or bone.80 The primary therapy for childhood NHL is multi-agent chemotherapy, with the length and intensity of therapy determined by the subtype and stage of disease.80 Children with limited stage NHL have an excellent prognosis with conventional chemotherapy with or without radiation, with estimated event-free survival of 90 to 95 percent.80 Patients with advanced stage disease have a variable prognosis depending upon disease subtype, with 5-year event-free survival rates ranging from 60 to 90 percent.80

If remission can be achieved in children and adolescents with recurrent or refractory B-cell NHL, HSCT is usually pursued.91 Most pediatric transplant programs reserve the use of HSCT in children with NHL for after first relapse, with disease progression or induction failure.80

#### NHL Evidence Base

The evidence compiled includes one review article which summarizes the experience with autologous HSCT and childhood NHL.80 There have been no randomized trials in the pediatric population with NHL using HSCT, and the data consist of five small, retrospective case series93-97 and one nonrandomized, comparative study 98, as summarized in Table 12. Several of the studies report survival data combined for patients with different histologies, with median EFS of 50 percent (range: 27 to 59 percent).93-96, 98 Studies that report survival data for one histologic type of NHL include ALCL: EFS 75 percent at 3 years97 and OS 95 percent at 7 years;99 LL: EFS 39 percent and 5-year OS of 44 percent for autologous HSCT, EFS 36 percent and 5-year OS 39 percent for allogeneic HSCT;92 BL: EFS 57 percent.100

Table 12 Benefits and harms after treatment for childhood Non-Hodgkin's lymphoma

Histology (n) | Source | Evidence Type | Treatment | Indications | Benefits | Harms | Comment
BL (6), LL (14), DLBCL (6), ALCL (7) | Won 2006^98,f^ | Nonrandomized comparative | Autologous HSCT | Relapsed/refractory | 2-year EFS 59.1% +/-9.3% (BL 66.7% +/- 27.2% LL 50.5% +/- 14.8% DLBCL 55.6 +/- 24.9% ALCL 100 | TRM 2/33 (6.1%) | Median followup 2.4 yrs (0.1-7.6)
BL (6), LL (14), DLBCL (6), ALCL (7) | Won 2006^98,f^ | Nonrandomized comparative | Conventional chemotherapy | Relapsed/refractory | EFS 16.3% +/- 4.6%
ALCL | Woessmann 2006^97,g^ | Case series, retrospective | Allogeneic | Relapsed/refractory (included first relapse and multiple relapses) | EFS 75% +/- 10% at 3 years | TRM 3/20 (15%). Acute GVHD ≥2 in 8 patients; extensive chronic GVHD in 2 patients.
LL | Levine et al. 2003^92,h^ | Case series from IBMTR and ABMTR | Autologous HSCT Allogeneic HSCT | CR1, CR2 or subsequent CR, relapse, primary induction failure | DFS/EFS 39% OS 6 months 75% 1 year 60% 5 year 44% | TRM 3% at 6 months | p values for OS differences between the autologous and allogeneic groups .01, .09 and .47 for 6 months, 1 year and 5 year, respectively. Study included adult patients with age range for autologous HSCT 2-67 (median 31) years and 5-53 (median 27) for allogeneic HSCT.
LL | Levine et al. 2003^92,h^ | Case series from IBMTR and ABMTR | Autologous HSCT Allogeneic HSCT | CR1, CR2 or subsequent CR, relapse, primary induction failure | DFS/EFS 36% OS 6 months 59% 1 year 49% 5 year 39% | TRM 18% at 6 months
Mixed HL and NHL (including LL, LCL, BL and NOS) | Kobrinsky et al. 2001^94,i^ | Case series | Autologous or allogeneic | Recurrent | DFS/EFS 50% | TRM 5/50 (10%) | Median followup 44 months.
ALCL | Fanin et al. 1999^99,j^ | Case series from EBMT | Autologous HSCT | CR1, CR2, CR≥3, PR1, PR≥2, sensitive relapse, primary refractory | OS for pediatric patients only (≤20 years) ∼95% at 7 years. | | Median followup 43.3 months. Study included adult patients. Age range was 3.2-53 (median 25). Eighteen of the 64 patients in the study were < 20 years old.
BL | Ladenstein 1997^100,k^ | Case series from EBMT | Autologous HSCT | Poor initial response to first-line chemotherapy (i.e., PR), sensitive relapse (SR), resistant relapse (RR) | 5-year EFS 56.6% for patients in PR and 48.7% for patients in SR. All patients with RR died within one year. | TRM 11.1 % | Median followup 4.3 years (2-12)
LL (21), B-NHL (19), LCL (6) | Bureo et al. 1995^93,l^ | Case series | 32 autologous and 14 allogeneic HSCT | CR1, CR2, CR3, refractory | EFS 58% [95%CI 42-73%] | TRM 13% [3/32 auto and 3/14 allo] | Median followup 33 months.
BL (16), LL (8) | Loiseau 1991^95,m^ | Case series | Autologous HSCT | Relapsed/ refractory | DFS 33%
BL (10), LL (2), DLBCL (5) | Philip 1988^96,n^ | Case series | Autologous HSCT | PR after first-line induction therapy | OS at 2 yrs 75% DFS/EFS 27% | TRM 2/17 (11.8%) | Median followup 2 yrs. Study included 11 children and 6 adults.

ABMTR = Autologous blood and marrow transplant registry; ALCL = anaplastic large cell lymphoma; BL = Burkitt lymphoma; CS = case series; DLBCL = diffuse large B-cell lymphoma; EBMT = European Group for Blood and Marrow Transplantation; GVHD = graft versus host disease; IBMTR = International Bone Marrow Transplant Registry; LL = lymphoblastic lymphoma; LCL = large cell lymphoma; NOS = not otherwise specified; SR = sensitive relapse; TRM = transplant-related mortality

f Won et al. 2006;^98^ 33 patients underwent autologous HSCT and 73 received conventional chemotherapy; patients transplanted between 1997-2004.

g Woessmann et al. 2006;^97^ n=20; patients transplanted between 1991-2003.

h Levine et al. 2003;^92^ n=128 for autologous HSCT and n=76 for allogeneic HSCT; patients transplanted between 1989-1998.

i Kobrinsky et al. 2001;^94^ n=50; study opened for accrual 1991 and closed 1994- bone marrow transplant was not a formal part of the study, but 42 patients were transplanted after induction therapy at the discretion of the treating physician and the remaining 8 patients underwent transplant between 5 and 84 weeks (median 14 weeks) from study entry.

j Fanin et al. 1999;^99^ n=64; patients transplanted between 1983-1996.

k Ladenstein et al. 1997;^100^ n=89; patients transplanted between 1979-1991.

l Bureo et al. 1995;^93^ n=46;

m Loiseau et al. 1991;^95^ n=24

n Philip et al. 1988;^96^ n=17

NCCN clinical practice guidelines (for all subtypes of pediatric NHL) and guidelines from the American Society for Blood and Marrow Transplantation (for DLBCL only) exist. No health technology assessments were identified in the search.

Harms associated with HSCT include secondary malignancies, which are a well-recognized complication in patients with lymphoma who undergo chemotherapy and/or radiation treatment. In patients with recurrent lymphoma who undergo high-dose chemotherapy and autologous HSCT, the incidence of myelodysplastic syndrome/secondary acute myelogenous leukemia is 4 to 20 percent at 5 years.80

#### NHL Guidelines

The American Society for Blood and Marrow Transplantation (ASBMT) issued a position statement on the use of HSCT in the treatment of diffuse large cell B-cell non-Hodgkin's lymphoma recommending its use in first chemotherapy-sensitive relapse, first complete remission in high/intermediate-high risk international prognostic index (IPI) patients, and as high-dose sequential therapy in intermediate-high/high risk IPI untreated patients.101

Guidelines from the ASBMT specifically addressing NHL and HSCT in the pediatric population were not identified.

NCCN clinical practice guidelines102 for BL recommend that patients be considered for a clinical trial, which may include autologous or allogeneic stem-cell rescue. The recommendations for DLBCL are for autologous HSCT for relapsed or refractory disease in patients with either partial or complete response to second line therapy. Recommendations for LBL include consolidation of high-dose therapy with autologous or allogeneic stem-cell rescue in poor risk patients, allogeneic HSCT for patients with an initial CR who relapse and for patients with an initial partial response. Finally, recommendations for peripheral T-cell lymphomas, noncutaneous (including ALCL) include high-dose therapy and stem-cell rescue as first-line consolidation in all patients except those considered low risk (by age adjusted IPI), and autologous or allogeneic HSCT in patients with relapsed or refractory disease with a partial or complete response to additional therapy.

#### NHL Summary

Overall there appears to be a favorable risk-benefit profile for the treatment of NHL with HSCT in patients with primary refractory or chemosensitive relapse. EFS for the various subtypes of NHL (except for ALCL) range from 27 to 59 percent,92-94, 96, 98, 100 and for ALCL, EFS of 75 percent at 3 years97 and OS 95 percent at 7 years99 have been reported.

Current recommendations are based on small studies which have included heterogeneous patient populations with various tumor histologies and a mixture of adult and pediatric patients.

Future challenges in the treatment of NHL include the development of risk-stratified treatment approaches for patients with high-risk disease, defining the use of autologous HSCT as upfront consolidation for certain groups of high-risk NHL, and the possible use of allogeneic HSCT where graft versus lymphoma has been demonstrated.80

## Narrative Reviews: Malignant, Nonhematopoietic Disease

### Neuroblastoma

#### Background

Neuroblastoma is the most common extracranial solid tumor of childhood, and accounts for 8 to 10 percent of all childhood cancers and for approximately 15 percent of cancer deaths in children.103 At least 40 percent of all children with neuroblastoma are designated as high-risk patients, based on adverse features including age 18 months or older at presentation, the presence of disseminated disease, unfavorable histologic features, and amplification of the MYCN oncogene.103

Low-risk patients are managed with surgery alone because excellent cure rates are achieved even when some tumor is left behind.103 Intermediate-risk patients are still at low risk of succumbing to disease but require limited chemotherapy and/or surgery.103, 104 The amount of chemotherapy is determined in part by the biological features. High-risk patients receive treatment with an aggressive regimen of combination high-dose chemotherapy (HDC); long-term survival with current treatments is about 30 percent.104 Children with aggressively treated, high-risk disease may develop late recurrences, some more than 5 years after completion of therapy.103, 104 Many centers have used HDC with HSCT in the setting of high-risk or recurrent disease.103, 105-108 Survivors have an increased rate of second malignant neoplasms, relative to the age- and sex-comparable U.S. population, and of chronic health conditions, relative to their siblings, which underscores the need for long-term medical surveillance.109

#### Evidence Base

The evidence compiled for this narrative review includes one systematic review,110 of three randomized controlled trials (RCTs).105, 107, 108 A followup analysis of one RCT111 and reports from two European registries112, 113 were also found (Table 13). No health technology assessments or clinical practice guidelines for the treatment of childhood neuroblastoma with HSCT were identified in the literature search.

Table 13 Neuroblastoma evidence base

Year of First HSCT Performed | No. of Transplants to Date | Existing Clinical Evidence | Registries
Early 1980s | >4,100 | Systematic review, randomized controlled trials | European Group for Blood and Marrow Transplantation (EBMT) registry (Ladenstein, 2008^113^): 4,098 procedures were registered between 1978 and 2006. In 3,974 patients, autologous stem cells were reinfused, while 124 patients were allocated for an allogeneic HSCT. Over 90% of patients were under the age of 10 years at diagnosis. The identified cases came from 27 European countries and at least seven international countries. Italian Neuroblastoma Registry (Garaventa, 2009^112^): 1,924 children were registered between 1979 and 2004.

HSCT = hematopoietic stem cell transplant

The systematic review was a report published by the Cochrane Collaboration in May 2010, comparing the effectiveness of HDC with autologous HSCT versus conventional therapy in children with high-risk disease.110 A meta-analysis of the three RCTs including 739 patients, independently identified in our search, showed a significant difference in both event-free and overall survival in favor of the transplant group (Table 14). Overall, no significant differences in the occurrence of adverse effects between treatment groups were identified in the Cochrane review (Table 14). These findings were further validated in a subsequent analysis of one RCT (not included in the Cochrane Review) with an 8-year median followup period (Table 14).111

Table 14 Benefits and harms after treatment for neuroblastoma

Source (Evidence Type) | Treatment | Indications | Benefits | Harms | Comment
Yalçin, 2010^110^ (Systematic Review) | Myeloablative therapy (high-dose chemotherapy and autologous bone marrow or stem-cell rescue (n=370) | Consolidate high-risk (initial) | Meta-analysis of three RCTs including 739 children. EFS (HR 0.78; 95% CI 0.67 to 0.90, p=0.0006) and OS (HR 0.74; 95% CI 0.57 to 0.98, p=0.04), both in favor of myeloablative therapy.^a^ | No significant difference between groups in treatment-related death (RR 2.53; 95% CI 0.17 to 37.12, p=0.50),^b^ secondary malignant disease (RR 0.99; 95% CI 0.14 to 7.00, p=0.99),^c^ serious infections (RR 1.02; 95% CI 0.84 to 1.23, p=0.88), and sepsis (RR 0.93; 95% CI 0.67 to 1.30, p=0.67).^d^ | All RCTs were multicenter studies, two of which were based in Europe (Berthold 2005^105^; Pritchard 2005^108^) and one in North America (Matthay 1999^107^); All trials used different myeloablative treatments. Patients were recruited between 1982 and 2002; none of the studies mentioned the exact patient age; only the number of cases above and below one year of age was stated; Data on adverse effects were very limited. None of the studies evaluated quality of life.
Yalçin, 2010^110^ (Systematic Review) | Conventional therapy (conventional chemotherapy or no further treatment) (n=369) | Consolidate high-risk (initial) | Meta-analysis of three RCTs including 739 children. EFS (HR 0.78; 95% CI 0.67 to 0.90, p=0.0006) and OS (HR 0.74; 95% CI 0.57 to 0.98, p=0.04), both in favor of myeloablative therapy.^a^ | Significant difference in favor of conventional therapy for renal effects (RR 2.28; 95% CI 1.28 to 4.04, p=0.005), interstitial pneumonitis (RR 9.55; 95% CI 2.26 to 40.43, p=0.002), and veno-occlusive disease (RR 35.18; 95% CI 2.13 to 580.88, p=0.01) based on data from one RCT.^d^
Matthay, 2009^111^ (RCT) | Myeloablative therapy (chemotherapy, total body irradiation, and ABMT) | Consolidate high-risk (initial) | 5-year EFS was 30%; (compared to control group, p=0.04) | Treatment-related deaths occurred in 22 of 122 patients (compared to the control group, p=0.7408); AML in one patient at 2.7 years followup; Follicular carcinoma of the thyroid in one patient at 7 years followup. | This report was an 8-year median followup analysis of the RCT by Matthay 1999^107^; treatment-related toxicity data were unchanged from previous report.
Matthay, 2009^111^ (RCT) | Conventional therapy (3 cycles of intensive chemotherapy) | Consolidate high-risk (initial) | 5-year EFS was 19% | Treatment-related deaths occurred in 22 of 138 patients; T-cell ALL in one patient at 2 years followup; Clear-cell carcinoma in one patient at 2.5 years' followup | This report was an 8-year median followup analysis of the RCT by Matthay 1999^107^; treatment-related toxicity data were unchanged from previous report.

ABMT = autologous bone marrow transplant; ALL = acute lymphoblastic leukemia; AML = acute myeloblastic leukemia; CI = confidence interval; EFS = event-free survival; HR = hazard ratio; OS = overall survival; RCT = randomized controlled trial

a Results from two RCTs could be pooled for overall survival (Berthold 2005^105^; Pritchard 2005^108^). The RCT by Matthay 1999^107^ only provided descriptive results: overall survival was similar for both regimens (n = 379 patients).

b Data on treatment-related death could be extracted from two trials with a total of 574 patients (Berthold 2005^105^; Matthay 1999^107^). There were 12 cases among 278 patients randomized to the transplant group and five among 296 patients randomized to the control group.

c Data on secondary malignant disease could be extracted from two trials with a total of 674 patients (Berthold 2005^105^; Matthay 1999^107^).

d Data on serious infections, sepsis, renal effects, interstitial pneumonitis and veno-occlusive disease could be extracted from Matthay 1999^107^.

#### Guidelines

No guidelines for the treatment of neuroblastoma were identified in the search.

#### Summary

Overall there appears to be a favorable risk-benefit profile for the role of HDC with autologous HSCT in children with high-risk disease, although possible higher levels of adverse effects should be kept in mind. Interpretation of these data is subject to the clinical context of the complete therapy which includes the effect of the induction regimen, the sources of stem cells, and presence and type of consolidation chemotherapy.

### Germ-Cell Tumors

#### Background

Germ-cell tumors represent 3 percent of all childhood neoplasms.114, 115 In the U.S., approximately 900 children and adolescents younger than 20 years of age are diagnosed with these tumors each year.115, 116 Childhood germ-cell tumors are composed primarily of extragonadal neoplasms (e.g., mediastinal or retroperitoneal) whereas gonadal (ovarian and testicular) tumors are more common in adults.115-118 Prognosis and appropriate treatment depend on factors such as histology (e.g., seminomatous vs. nonseminomatous), age (young children vs. adolescents), stage of disease, and primary site.117, 118

Germ-cell tumors are highly sensitive to chemotherapy.114, 117, 118 Cisplatin-based combination chemotherapy, followed by appropriate surgical resection of residual disease, is curative in 80 percent of patients.114, 118, 119 Reports of salvage treatment strategies used in adult recurrent germ-cell tumors include larger numbers of patients, but the differences between children and adults regarding the location of the primary tumor site, pattern of relapse, and the biology of childhood disease may limit the applicability of adult salvage approaches to children. Many centers have used HDC with HSCT in the setting of recurrent disease.114, 119, 120

#### Evidence Base

The evidence compiled for this review (Table 15) includes one cohort study,120 two reports based on registry data,114, 119 and two NCCN guidelines.117, 118 A review of the NCI's PDQ® Cancer Clinical Trials Registry identified at least one ongoing trial involving HSCT in the setting of relapsed childhood germ-cell tumors.121 No RCTs, systematic reviews or health technology assessments for childhood germ-cell tumors were identified in the literature search.

Table 15 Germ-cell tumor evidence base

Year of First HSCT Performed | No. of Transplants to Date | Existing Clinical Evidence | Registries
Late 1980s | >150 (pediatric age-group) | Cohort studies | European Group for Blood and Marrow Transplantation – EBMT (De Giorgi, 2005^114^): 160 patients with a diagnosis of extragonadal GCT registered between 1987 and 1999; analysis was undertaken of 23 children who received HDC with HSCT. Center for International Blood and Marrow Transplant Research – CIBMTR (Lazarus, 2007^119^): 300 patients with testicular cancer registered between 1989 and 2001; 198 patients received single HSCT, and 102 patients received tandem auto-transplants. Approximately 10% of patients were in the pediatric age-group. The identified cases came from 76 centers across eight countries.

HDC = high-dose chemotherapy; HSCT = hematopoietic stem cell transplant

Agarwal and colleagues120 reported their experience at Stanford University Medical Center in treating 37 consecutive patients who received HDC and autologous HSCT between 1995 and 2005 for relapsed disease (Table 16). Only four patients (11 percent) in this cohort were in the pediatric age group. Twenty-nine patients had received prior standard salvage chemotherapy. Three-year overall and event-free survival was 57 and 49 percent, respectively. Treatment-related mortality was reported at 3 percent. In terms of ongoing trials, there is a pilot study underway to assess the feasibility of HDC followed by autologous HSCT in patients with newly diagnosed or relapsed solid tumors (including GCTs). Twenty patients (6 months to 40 years of age) are expected to be enrolled in this single-center U.S. study with the expected final data collection date of December 2010.^121^

Table 16 Benefits and harms after treatment for germ-cell tumors

Source (Evidence Type) | Treatment | Indications | Benefits | Harms | Comment
Agarwal, 2009^120^ (cohort) | HDC with autologous HSCT | Relapsed | 3-year overall survival of 57% (95% CI, 41-71%); 3-year event-free survival of 49% (95% CI, 33-64%). | The treatment-related mortality was 3%; four patients developed signs of mild VOD of liver. | 37 consecutive patients between 1995 and 2005 at Stanford. Median patient age of 28 years at transplant (range: 9-59 years; 92% male); four patients (11%) between 0-19 years. Primary tumor sites included 24 testes/adnexal, 10 chest/neck/ retroperitoneal, and 3 central nervous system.

CI = confidence interval; HDC = high-dose chemotherapy; HSCT = hematopoietic stem-cell transplant; VOD = veno-occlusive disease

#### Guidelines

Our search identified two guidelines for the treatment of GCT. Both guidelines were from NCCN and were not specific to childhood disease.117, 118 The NCCN testicular cancer guidelines118 recommend HDC with HSCT as the preferred third-line option for metastatic disease if the patient experiences an incomplete response or relapses after second-line conventional dose chemotherapy. This recommendation is based on lower-level evidence and uniform NCCN consensus (Category 2A) In addition, HDC with HSCT is recommended as one therapeutic option for patients with poor prognostic features including an incomplete response to first-line therapy, high levels of serum markers, high-volume disease and presence of extratesticular primary tumor. This recommendation is based on lower-level evidence, including clinical experience and nonuniform NCCN consensus, but no major disagreement (Category 2B) Alternatively, the patients may be put on best supportive care or salvage surgery if feasible.118 The NCCN ovarian cancer guidelines,117 on the other hand, recommend HDC with HSCT as one therapeutic option for patients having persistently elevated alpha-fetoprotein and/or beta-human chorionic gonadotropin levels after first-line chemotherapy. This recommendation is based on lower-level evidence and uniform NCCN consensus (Category 2A)

#### Summary

Although there is not sufficient literature to firmly establish the role of HDC with autologous HSCT for relapsed pediatric germ-cell tumor, studies in adult patients with similar tumors show efficacy in poorly responsive or relapsed disease. Further study is needed in young children and adolescents to determine whether the efficacy noted in adult studies can be extrapolated to pediatric patients.

### Central Nervous System Embryonal Tumors

#### Background

Classification of brain tumors is based on both histopathologic characteristics of the tumor and location in the brain.122 Central nervous system (CNS) embryonal tumors are the most common malignant brain tumor in childhood. Embryonal tumors of the CNS include medulloblastoma, ependymoblastoma, supratentorial primitive neuroectodermal tumors (PNETs), medulloepithelioma, and atypical teratoid/rhabdoid tumor (AT/RT).122

Medulloblastomas account for 20 percent of all childhood CNS tumors.123, 124 The other types of embryonal tumors are rare by comparison 122. Surgical resection is the mainstay of therapy with the goal being gross total resection with adjuvant radiation therapy, as medulloblastomas are very radiosensitive tumors.124, 125 Treatment protocols are based on risk stratification, as average or high risk. HSCT is used in high-risk disease, including metastatic, and recurrent or residual following surgery and chemotherapy. The average-risk group includes children older than 3 years, without metastatic disease, and with tumors that are totally or near totally resected (i.e., less than 1.5 cm^2^ of residual disease).124 In addition, patients with non-anaplastic medulloblastoma are considered to be at average (or standard) risk, and those with anaplastic disease at high risk. The high-risk group includes children aged 3 years or younger, or with metastatic disease, and/or subtotal resection (i.e., more than 1.5 cm^2^ of residual disease).124 The treatment of medulloblastoma continues to evolve, and, especially in children younger than 3 years because of the concern of the deleterious effects of craniospinal radiation on the immature nervous system, therapeutic approaches have attempted to delay and sometimes avoid the use of radiation, and have included trials investigating different chemotherapy regimens to improve outcome.122

PNETs are a heterogeneous group of highly malignant neoplasms comprising 3 to 5 percent of all childhood brain tumors, most commonly located in the cerebral cortex and pineal region.123, 125 AT/RT, on the other hand, is a tumor of early childhood, with nearly two-thirds of cases diagnosed before the age of 3 years.123, 125, 126 The prognosis for these tumors is worse than for medulloblastoma, despite identical therapies.122, 123, 125 Recurrence of all forms of CNS embryonal tumors is not uncommon, usually occurring within 18 months of treatment; however, recurrent tumors may develop many years after initial treatment.122 Many centers have used HDC with HSCT in the setting of high-risk disease.

#### Evidence Base

The evidence compiled for this review includes seven case series published since 2005.^127-133^ No RCTs, registry reports, or clinical practice guidelines for the treatment of childhood CNS embryonal tumors with HSCT were identified in the literature search. In addition, no systematic reviews or health technology assessments were found on CNS embryonal tumors (Table 17). Published information on outcome for children with CNS embryonal tumors is based on small series and is retrospective in nature (Table 18).

Table 17 CNS embryonal tumors evidence base

Year of First HSCT Performed | No. of Transplants to Date | Existing Clinical Evidence | Registries
Mid 1990s | >150 | Retrospective case series | None

HSCT = hematopoietic stem cell transplant

Table 18 Benefits and harms after treatment for CNS embryonal tumors

Source (Evidence Type) | Treatment | Indications | Benefits | Harms | Comment
Butturini et al. 2009^127^ (case series) | HDC with autologous HSCT | Relapsed or residual | 3-year OS of 83% (SE, 15%); EFS of 83% (SE, 15%) [in patients without prior radiotherapy, n=6]; 3-year OS of 29% (SE, 13%); EFS of 20% (SE, 12%) [in patients with prior radiotherapy, n=13] | Treatment-related deaths in one patient without prior radiotherapy, and in four patients with prior radiotherapy; Post-transplant recurrence in six patients with prior radiotherapy. | 19 patients recruited between 1992-2008; Median age at transplant, 4.5 years (range, 1.7-5.8) in patients with no prior radiotherapy; 9.9 years (4-18.2) in patients with prior radiotherapy; MB and PNET (supratentorial location at diagnosis, 17-30%)
Grodman et al. 2009^129^ (case series) | HDC with autologous HSCT | Relapsed or residual | 5-year OS of 50% (95% CI, 15-77%) | Neurotoxicity in two MB patients | 8 patients recruited between 1995-2002; Mean age at transplant, 12.9 years (range, 5.6-27.8); MB (n=7, 87.5%) and germinoma (n=1)
Cheuk et al. 2008^128^ (case series) | HDC with autologous HSCT | Relapsed or residual | 5-year OS of 51.9%; EFS of 53.9%; Subgroup analysis for MB patients (n=9): 5-year OS of 51.9%; EFS of 55.6% | Transplant-related death in one patient; Hepatic VOD in two patients; Grade 4 renal toxicity in one patient | 13 patients recruited between 1996-2006; Mean age at transplant, 8.5 years (range: 2.7-20); MB (n=9, 69%), PNET (n=1), ependymoma (n=1), germ-cell tumor (n=1), and cerebral rhabdoid (n=1)
Kadota et al. 2008^130^ (case series) | HDC with autologous HSCT | Relapsed or residual | 2-year OS of 59% (SE, 9%); PFS of 34% (9%). | No treatment-related deaths; Infections in 15 patients (52%); Stomatitis in 12 patients | 29 patients recruited between 1994-2003; median age of 9.8 years (range, 4.3-17.1); MB (n=22, 76%) and germinoma (n=7)
Shih et al. 2008^132^ (case series) | HDC with autologous HSCT | Relapsed or residual | 5-year OS of 28% (SE, 9.8%); PFS of 18.5% (SE, 8.4%); 5-year PFS for patients aged <3 years at diagnosis significantly better than older patients (57% vs. 5%, p = 0.02) | Transplant-related death in two patients; 44% of patients experienced grade 3/4 transplant-related toxicity | 27 children recruited between 1989-2004; Median age at transplant, 6.7 years (range, 1.1 – 18.5); Six patients aged ≤3 years at transplant) MB (n=13, 48%), PNET (n=5), AT/RT (n=2) and other CNS tumors (ependymoma, n=3; anaplastic astrocytoma, 2; glioblastoma, n=2)
Ridola et al. 2007^131^ (case series) | HDC with autologous HSCT | Relapsed or residual | 5-year OS of 77.2% (95%CI, 58.3-89.1%); EFS of 66.7% (47.8-81.4%) [in patients with local recurrence, n=27] 5-year OS of 50% (95% CI, 25.4-74.6%); EFS of 50% (25.4-74.6%) [in patients with residual disease, n=12] | Two toxic deaths (5) from infections; Severe infections in 28%; Hepatic VOD in 33% | 39 children with MB between 1988-2005; Median age at transplant, 3.25 years (range, 0.9-6.7); 64% (n=25) of patients received varied therapy prior to transplant
Sung et al. 2007^133^ (case series) | HDC with autologous HSCT | Relapsed or residual | 3-year OS of 25.6% (SE, 15%); EFS of 29.1 ± 15.7% | Transplant-related deaths in two patients | 11 patients recruited between 1999-2005; median age, 8.2 years (3.75-17.2); MB (n=7, 64%) and PNET (n=4) 3 (of 11) MB patients received tandem therapy

AT/RT = atypical teratoid/rhabdoid tumor; CI = confidence interval; EFS = event-free survival; HDC = high-dose chemotherapy; HSCT = hematopoietic stem-cell transplant; MB = medulloblastoma; PFS = progression-free survival; PNET = supratentorial primitive neuro-ectodermal tumor; SE = standard error; OS = overall survival; VOD = veno-occlusive disease

#### Guidelines

No guidelines on the treatment of CNS embryonal tumors were identified in the search.

#### Summary

Overall, there is a favorable risk-benefit profile for the role of HDC with HSCT in young children with high-risk or recurrent medulloblastoma supported by case series published in the past 5 years. Data is limited regarding the use of this therapy for other childhood CNS embryonal tumors. Comparison of the effects of HSCT between treatment trials remains challenging given the heterogeneity of these tumors, use of different combinations of chemotherapy as well as radiation therapies, and varied patient selection.

## Narrative Reviews: Nonmalignant Disease

### Hemoglobinopathies

Characterized by inherited lifelong anemia hemoglobinopathies are a class of diseases defined by the abnormal function or synthesis of the hemoglobin molecule.134 Within this disease class sickle-cell disease (SCD) and thalassemias are the most common (Table 19). The patients are faced with major morbidity and premature mortality. HSCT is the only treatment with a curative intent.

Table 19 Evidence base for HSCT in hemoglobinopathies

Disease | Year of First HSCT Performed | No. of Transplants to Date | Existing Clinical Data | Registries
Sickle cell disease | 1984 | Approximately 250 | Review, case series, case reports | The Registry and Surveillance System in Hemoglobinopathies (RuSH) is a new collaborative registry with the NHLBI, CDC and six US states (California, Florida, Georgia, Michigan, North Carolina, and Pennsylvania) to study Hemoglobinopathies in the U.S.145 EBMT has a hemoglobinopathies registry.
β-thalassemia | 1981 | >1600 | Review, case series, case reports | Registries are maintained in the United Kingdom (National Register of Inherited Disorders), Iran and Oman The Registry and Surveillance System in Hemoglobinopathies (RuSH) is a new collaborative registry, with the NHBIL, CDC and six US states (California, Florida, Georgia, Michigan, North Carolina, and Pennsylvania) to study Hemoglobinopathies in the U.S.145 (Under development, in pilot phase) EBMT has a hemoglobinopathies registry.

CDC = Centers for Disease Control and Prevention; EBMT = European Group for Blood and Marrow Transplantation; HSCT = hematopoietic stem cell transplant; NHLBI = National Heart, Lung and Blood Institute

#### Sickle-Cell Disease

##### Background

Sickle-cell disease is a genetic hemoglobin disease causing severe pain crisis and dysfunction across organ systems, ultimately leading to premature death. The disease is caused by amino acid substitutions that alter the structure and function of the hemoglobin molecule. Sickle-cell disease occurs when the hemoglobin S gene is inherited from both parents. Worldwide, approximately 275,000 sickle-cell-affected conceptions and births occur each year.135 Average life expectancy is estimated at between 42 and 53 years for men and between 48 and 58 years for women.136 At age 5, 95 percent of patients will be asplenic, leaving them highly susceptible to infection and sepsis, the leading cause of death among young patients with sickle-cell disease.134 Clinical management includes three major therapeutic options: chronic blood transfusion, hydroxyurea, or HSCT. While the long-term use of blood transfusion has been shown effective at preventing stroke and other sickle-cell complications, it may lead to iron overload, infection, and alloimmunization.137 HSCT is the only treatment with a curative intent, aiming to remove sickled red blood cells and progenitor stem cells and replace them with stem cells able to express total or at least partial correction of the abnormal hemoglobin phenotype.138

##### Evidence Base

The evidence compiled for this review includes two literature reviews139, 140 and one systematic review on the use of hydroxyurea containing data from one RCT and 22 observational studies.141 One clinical practice guideline for the treatment of sickle-cell disease with HSCT142 and no health technology assessments were identified in the literature search.

For patients in whom HSCT is indicated, the review of the literature (Table 20) shows for median followup ranging from 0.9 to 17.9 years overall survival of greater than 92 percent and event free survival of greater than 82 percent have been observed. Cord blood and marrow donations from family donations have been used with equal success; although current numbers are small.143, 144

Table 20 Benefits and harms after treatment for hemoglobinopathies

Disease | Source | Treatment | Indications | Benefits | Harms | Comment
Sickle cell disease | Inati, 2009^140^ (literature review) | Blood transfusion with leukoreduced red cells | Acute or episodic symptoms or long term management of SCD Primary stroke prevention | Risk of stroke was 92% lower in the group receiving transfusions compared to the non-transfusion group at 26 months. | Chronic blood transfusion leads to iron overload and organ damage. | Trial was halted at 26 months followup because of ethical concerns of withholding transfusion.
Sickle cell disease | Strouse et al. 2008^141^ (systematic evidence review) | Hydroxyurea (HU) | Primary treatment for patients experiencing recurrent pain crisis or acute chest syndrome Recurrent stroke prevention | Hemoglobin levels increased by a mean of 0.4 g/dl while on treatment. Both hospitalizations and hospitalized days were lower when on treatment 1.1 vs. 2.8 and 7.1 vs. 23.4 days respectively. Observed in 17 studies HbF% increased from 5-10% at baseline to 15-20% during treatment. Frequency of pain crisis decreased in three of four studies From an average of 3.4 to 1.3 per year,^k,l,m^ with one study showing no difference n. | Evidence was graded by the authors as Moderate to support an increased risk of reversible, usually mild, cytopenias and rash or nail changes in children treated with HU. | Systematic evidence review contained data from one RCT and 22 observational studies. Data from the observational studies were largely consistent with the RCT. We summarize the most relevant outcomes from the RCT and observational data. Evidence was graded 146 by the authors as insufficient to assess the risk of leukemia or other secondary malignancies, splenic sequestration, and leg ulcer development.
Sickle cell disease | Bhatia and Walters 2008^139^ (literature review) | Allogeneic HSCT | Severe SCD | - Overall survival 92-94% a,b,c; - Patients with asymptomatic disease do better OS 100 vs. 88% and EFS 93 vs. 76% b; - Event free survival 82-86.1% a,b,c | - 15-20% aGVHD ≥ grade 2; - cGVHD 12-20%; - Treatment related mortality 6-7%; - Graft rejection 7-10% (all data from a,b,c); - ovarian failure is common among SCD patients after HSCT, however the sample sizes are too limited to make inferences. 5/6 females who received Bu16/CY200 had primary amenorrhea,^b^ and in the Multicenter collaborative study six of the seven evaluable females had primary amenorrhea a.; In the three major series of HSCT among SCD, males receiving Bu16/CY200 had normal sexual development. | Age range at transplant (0.9-22 years)^a,b,c^ Median years of followup ranged from 0.9 to 17.9 years.^a,b,c^ Infections are the major cause of treatment related mortality. All patients in these series were conditioned with Bu 14-16 mg/kg or 485 mg/m^2^ with CY200; ATG was also used in the French and multicenter studies. Note, the intervention (allogeneic HSCT) refers to HLA-identical donors only.
β-thalassemia major | Bhatia and Walters 2008^139^ | Transfusion with leukoreduced red cells | Long term management | | Chronic blood transfusion leads to Iron overload and organ damage.
β-thalassemia major | Bhatia and Walters 2008^139^ | Allogeneic HSCT | | - Thalassemia free survival (TFS) 73% d; - TFS by class; 94, 77 and 53% for class 1,2 and 3 respectively^d^.; - Overall survival 65-100% e,f,g,h; - 2 year event free survival 79% f | 32-47.3% aGVHD ≥ grade 2 e,g,h 14-37.5% cGVHD e,g,h 10-34% Treatment related mortality^e, g,h^ Rates are unclear due to small numbers but a study of endocrine function after HSCT in 15 patients (10 male 5 female) followed for 12 years, 20% of boys (2/10) had gonadal failure, 100% of girls experienced ovarian failure, an additional five girls who had entered puberty prior to HSCT also experienced 100% ovarian failure after HSCT.^i^ | Overall survival estimate of 100 came from a mixed cohort of thalassemia and SCD^f^.; - 2 year EFS came from 33 thalassemia patients in the cohort.^f^; Rates for aGVHD and cGVHD include transplants with related and unrelated donors. One study reported aGVHD in 11% and cGVHD of 6% of patients but 25% of that cohort are patients with SCD.^f^ The largest study (886 patients) does not report on aGVHD.^d^

aGVHD = acute graft vs. host disease; ATG = antithymocyte globulin; cGVHD = chronic graft versus host disease; HSCT = hematopoietic stem cell transplant; RCT = randomized controlled trial; SCD = sickle-cell disease

a Walters et al. 2000^138^ multicenter study of 59 children with SCD treated with HSCT;

b Vermylen et al. 1998^147^ case series of first 50 patients with SCD transplanted in Belgium;

c Bernaudin et al. 2007^148^ results from 87 patients with SCD treated with HSCT;

d Lucarelli et al. 2002^149^ 886 patients with thalassemia;

e La Nasa et al. 2005^150^ 68 patients;

f Locatelli et al. 2003^144^ 33 thalassemia and 11 patients with SCD;

g Hongeng et al. 2006^151^ 49 thalassemia;

h Gaziev et al. 2000^152^ 29 thalassemia;

i Li et al. 2004^153^ study of endocrine function after HSCT for thalassemia;

j Ferster et al. 1996^154^ randomized cross-over trial of 25 patients receiving hydroxyurea for SCD at 2 sites;

k Olivieri and Vichinsky, 1998^155^;

l Santos et al. 2002^156^;

m Svarch et al. 2006^157^;

n Hankins et al. 2005^158^;

o Adams et al. 1998^159^ RCT on transfusion for SCD of 130 children

##### Guidelines

Guidelines for the treatment of sickle-cell disease with HSCT come from the criteria developed by Walters et al.142

Patients younger than 16 years old with sickle-cell disease who have an HLA-identical sibling bone marrow donor with one or more of the following are eligible for HSCT:

- Stroke, central nervous system (CNS) hemorrhage or a neurologic event lasting longer than 24 hours or abnormal cerebral magnetic resonance imaging (MRI) scan or cerebral arteriogram or MRI angiographic study and impaired neuropsychological testing
- Acute chest syndrome with a history of recurrent hospitalizations or exchange transfusions
- Recurrent vaso-occlusive pain three or more episodes per year for 3 or more years or recurrent priapism
- Impaired neuropsychological function and abnormal cerebral MRI scan
- Stage I or II sickle lung disease
- Sickle nephropathy (moderate or severe proteinuria or a glomerular filtration rate [GFR] 30–50 percent of the predicted normal value)
- Bilateral proliferative retinopathy and major visual impairment in at least one eye
- Osteonecrosis of multiple joints with documented destructive changes
- Requirement for chronic transfusions but with RBC alloimmunization of more than two antibodies during long-term transfusion therapy

##### Summary

Overall there appears to be a favorable risk-benefit profile for the treatment of severe sickle cell disease with HSCT for patients aged younger than 16 years who have an HLA-identical sibling donor and are candidates for transplant as indicated by the presence of one of the complications listed above. Approximately 14 to 18 percent of patients with sickle-cell disease have an HLA-identical matched sibling, and therefore the majority of patients rely on transfusion and/or hydroxyurea for their clinical management. The use of well-matched unrelated donors for HSCT for patients with severe sickle cell disease is currently under study (ClinicalTrials.gov record NCT00745420 BMT-CTN trial 0601).

#### β-Thalassemia Major

##### Background

Thalassemia is considered to be the most common genetic disorder in the world.160 Thalassemia is caused by mutations in the globin genes that either reduce or eliminate the production of one of the globin chains.161 Reduction or absence of the β-globin chain results in β-thalassemia. The most severe form is β-thalassemia major, where individuals have severe anemia and are dependent on transfusions for survival. Approximately 150 million people carry β-thalassemia genes. β-thalassemia major defines the most severe group of patients who have transfusion-dependent anemia with transfusions often beginning as early as 6 months of age. Signs of the disease usually appear within the first year of life and life expectancy is severely reduced among these patients. Prior to 1980, median survival was 17.1 years with 50 percent of patients dying before age 15 years.162-165 Among patients who are adherent with iron chelation therapy, there is a 30 to 60 percent chance of being alive at age 30 versus 10 percent for a those who are not.164, 166, 167 Clinical management for β-thalassemia major relies on life-long transfusion support, which when adequately provided can prevent much of the morbidity and mortality of the disease. However, the only potentially curative treatment for thalassemia is to correct the genetic defect through HSCT.

##### Evidence Base

The evidence compiled for this review was contained in a 2008 literature review by Bhatia and Walters.139 No clinical practice guidelines or health technology assessments on the use of HSCT for β-thalassemia major were identified in the search.

Patients with β-thalassemia major selected for transplant are placed into one of three risk categories based on clinical features of the disease:

- Adherence to a program of regular iron chelation therapy
- Presence or absence of hepatomegaly
- Presence or absence of portal fibrosis observed by liver biopsy

Patients placed in class 1 have none of the risk factors, class two patients have one or two, and patients in class three have all three risk factors. Outcomes after HSCT vary by class (Table 20)149

Review of the literature shows thalassemia-free survival after HSCT of 73 percent overall, and 94, 77, and 53 percent for classes 1, 2, and 3, respectively. Overall survival estimates range from 65 to 100 percent.

##### Guidelines

No guidelines for the treatment of β-thalassemia major with HSCT were identified in the search.

##### Summary

Overall there appears to be a favorable risk-benefit profile for the treatment of β-thalassemia major with HSCT for patients who have an HLA-identical family donor. Approximately 30 to 36 percent149 of patients has an HLA-identical family donor, the remainder rely on lifelong transfusion for the clinical management of the disease. For those patients with a suitable donor, avoidance of the complications of long-term transfusion may outweigh the risks of HSCT. However, prior to HSCT, adherence to iron chelation is essential, as rates of thalassemia-free survival are worse for those with complications due to iron overload.

### Bone Marrow Failure Syndromes

Bone marrow failure syndromes (BMF) comprise a broad number of diseases with varying etiologies (Table 21). The unifying factor is that hemopoiesis is abnormal or fully arrested in at least one cell line.168 BMF can either be acquired, as in acquired aplastic anemia, or congenital as is the case in patients with Fanconi anemia, Diamond Blackfan anemia, and Schwachman Diamond syndrome.

Table 21 Listing of bone marrow failure syndromes and their evidence base

Disease | Year of First HSCT Performed | No. of Transplants to Date | Existing Clinical Data | Registries
Acquired Aplastic Anemia | Early 1970s | Unclear | RCTs, review, case reports, case series | None
Fanconi Anemia | Early 1970s | Unclear | Review, case series, case reports | The International Fanconi Anemia Registry (est. 1982) to study the features of Fanconi anemia. The registry is housed at Rockefeller University, and contains data on more than 1000 patients with FA in the U.S. (www.rockefeller.edu)
Schwachman Diamond Syndrome | 1991 | Approximately 30 reported | Review, case series, case reports | The North American SDS Registry, Fred Hutchinson Cancer Research Center, seeks to register all SDS cases in the U.S. and Canada. (www.shwachman-diamond.org/)
Dyskeratosis Congenita | Unclear | 30 patients reported | Reviews, case series, case reports | The Dyskeratosis Congenita Registry established in 1995, Hammersmith Hospital, London, and includes data on the epidemiology pathophysiology, genetics and treatment of DC. Information from 200 families, in 40 countries and more than 350 affected individuals.171
Congenital Amegakaryocytic Thrombocytopenia | 1990 | 52 patients | Reviews, case series, case reports | None found
Diamond Blackfan Anemia | | Unclear | Reviews, case series, case reports | The Diamond Blackfan Anemia registry of North America, established in 1993 and housed at Schneider Children's Hospital, New York includes demographics, lab, and clinical data on over 500 patients with DBA in the U.S. and Canada. (Bagby et al. 2004^172^ and www.dbar.org)
Severe Congenital Neutropenia/Kostmann Syndrome | 1980 | 40 patients | Reviews, case series, case reports | The Severe Chronic Neutropenia International Registry, est.1994, University of Washington has the largest collection of SCN long-term data (depts.washington.edu/registry). As of 2003, the French Severe Chronic Neutropenia Registry, created in 1994 included 101 patients with SCN (Ferry et al. 2005^173^)

DC = Dyskeratosis congenita; DBA = Diamond Blackfan anemia; FA = Fanconi anemia; RCT = randomized controlled trial; SCN = severe congenital neutropenia; SDS = Schwachman Diamond syndrome

#### Acquired Bone Marrow Failure Syndrome

##### Acquired Aplastic Anemia

###### Background

Acquired aplastic anemia is a failure of the bone marrow to produce red and white blood cells, as well as platelets. Approximately 80 percent of all cases of aplastic anemia are acquired versus congenital. While disease onset can occur at any age, it preferentially occurs in young adults and individuals over 60 years of age.169 Patients with acquired aplastic anemia are classified according to the severity of marrow aplasia.170 The urgency of treatment is dictated by the patient's absolute neutrophil count and the duration of severe neutropenia, which is correlated to survival.

The standard of care for treatment of aplastic anemia is immunosuppression and/or HSCT. The patient's age, medical history (such as number of prior blood transfusions and infections) and the availability of a matched sibling donor guide treatment decisions.172

###### Evidence Base

The evidence compiled for this review includes one literature review.168 One clinical practice guideline172 but no health technology assessments for the treatment of childhood acquired aplastic anemia with HSCT were identified in the literature search. The evidence base on the use of HSCT for treatment of acquired aplastic anemia is summarized in Table 22.

Table 22 Benefits and harms after treatment for bone marrow failure syndromes

Disease | Source | Treatment | Indications | Benefits | Harms | Comment
Acquired Aplastic Anemia | Myers and Davies, 2008^168^ (Literature review) | Immunosuppressive therapy | - Front line therapy in those without a matched sibling donor | - 68%^a^-80%^b^ overall survival at 10 years.; - 89%^b^ overall survival if confined to responders to therapy.; - disease free survival 40% at 10 years c | - Patients left at higher risk for infection due to use of IST for 2-3 years.; - Higher rates of clonal evolution with repeat IS d.; - increased rates for MDS and AML ranging from 8%-25%^d, e, f^ | - 17-34% of SAA patients treated with IST will eventually require HSCT as salvage therapy g.; Not pediatric patients median age 32 (2-80) e.
Acquired Aplastic Anemia | Myers and Davies, 2008^168^ (Literature review) | Allogeneic HSCT | - Front line therapy for those with a matched sibling donor | - matched sibling donors overall survival ranges from 85-98%^c,g,h,i^.; - Survival for those with GVHD grade 0-1 98% versus 70% in recipients with grade II-IV i.; - Five year overall survival after transplant with matched sibling peripheral blood stem cells 73% versus 85% after matched sibling bone marrow transplant. | - relative risk for mortality of 2.04 (1.09-3.78) for those receiving PBSC versus bone marrow.; - relative risk of GVHD 2.82 (1.46-5.44) for PBSC vs. BMT^j^.; - Kaplan-Meier estimate of risk of secondary malignancy after myeloablative transplantation for SAA 14%^k^; - Development of GVHD; - restrictive or obstructive pulmonary disease 24%^l^ | Age range at transplant 4-46 (median ∼19) i. The type of conditioning regimen seems to have a greater association with adverse outcomes such as stunted growth, altered endocrine and pulmonary function, bone marrow density, and for those receiving radiation-containing regimens affects on fertility.
Acquired Aplastic Anemia | Myers and Davies, 2008^168^ (Literature review) | Allogeneic HSCT | - Treatment for those refractory to immunosuppressive therapy. (Unrelated donor) | - 84% 5 year failure free survival for unrelated matched donor HSCT vs. 11% for repeat course of immunotherapy after one failed course.; - 73% 2 year survival, and 84% for children 14 years or younger; - unrelated m. mismatched donor 34-40% survival n,o | - Development of GVHD; - restrictive or obstructive pulmonary disease 24%^l^ | Age range at transplant = 1.8-67, median 14 years k. Age range at transplant 1-42, median 18 years l. Five donors (13%) were HLA mismatched family members m. Median age of these patients is approximately 18 years with a range of (1-65), and all patients may not be refractory to suppressive therapy o.
Fanconi Anemia | Dufour and Svahn, 2008^174^ (Literature Review) | Androgen Therapy | - Front line therapy for those with no matched sibling donor | 75% of patients will respond to androgen therapy p within 2-12 months | - virilization; - hyperactivity; - renal toxicity; - hypertension; - Possible adverse effect on subsequent HSCT q, r | Response is incomplete and generally drug dependent, additionally the age of responders is not mentioned in this article. p Age range at transplant = 4-37.4, median 10.8 years q. Age range at transplant = 7-31, median 8 years r. Combining androgens with corticosteroids can help to minimize liver toxicity s, however, age of patients is not discussed in this article.
Fanconi Anemia | Myers and Davies, 2008^168^ (Literature Review) | Allogeneic HSCT | - Front line therapy for those with a matched sibling donor | - 10 year survival of 89% after transplant with peritransplantation ATG^qq^; - 88% sustained engraftment and 93% overall survival when Cyclophosphamide (Cy) is used alone as immunosuppressive agent^ff^ | - acute GVHD 23%; - chronic GVHD 12% q with peritransplantation ATG; - acute GVHD 57% for those receiving 80 mg/kg, 14% aGVHD for patients receiving 60 mg/kg of CY.; - chronic GVHD 33% for those receiving 80 mg/kg and 11% for those receiving a dose of 60 mg/kg v. | Age range at transplant = 5-29, median 9 u. Age at transplant 2.7-22.9 years, median 7.6 years q.
Fanconi Anemia | Myers and Davies, 2008^168^ (Literature Review) | Allogeneic HSCT | - Front line therapy in those using an unrelated donor | - survival rates 38%-96% when using Flu-based conditioning regimen^w,x,y,z,aa^; - decrease in treatment related mortality from 81% to 47%^w^; - 3 year overall survival 52% for fludarabine containing regimens vs. 13% for fludarabine-free regimens; - 42% overall survival (50% for those on fludarabine vs. 25% for those on fludarabine free regimens) when using umbilical cord blood transplant bb | - acute GVHD 21% with Flu-free^ww^; - acute GVHD 16% with Flu^vv^; - chronic GVHD 31%^dd^; - acute GVHD 32.5%; - chronic GVHD 16% when using umbilical cord blood transplant cc | Of total n=98, 39% (n = 38) ≤ 10 years, 44% (n = 43) 11-20 years, and 17% (n = 17) > 20 years at transplant. No age-group analysis of the flu group provided w. Age range at transplant 7-31, median age 8 years, and survival of 38% reported in a group with mixed conditioning regimens z. Age range at transplant = 5-24, median 11. Fourteen of 18 patients (78%) < 20 years aa. For the Flu vs. Flu free sub-group analysis age range 1-45, median age 8.6 years bb. This is using t-cell depleted stem cells. FA patients have heightened sensitivity to GVHD tissue damage and GVHD likely increases an already high rate of later malignancy
Schwachman-Diamond Syndrome | Myers and Davies, 2009 168 (Literature Review) | Allogeneic HSCT | SDS patients with marrow aplasia, MDS/AML | - 60% 5-year survival using a fully myeloablative regimen, with a matched or unmatched donor ee, f.; - 100% engraftment and 100% survival among 7 patients with marrow aplasia or MDS/AML who received a reduced intensity Flu-based conditioning regimen gg.; Overall survival 64.5% at 1.1 years hh. | - virilization; - hyperactivity; - renal toxicity; - hypertension | Transplants with matched related or unrelated donor. Case report of 3 patients, only one followed >5 years.^ee^. Survival >60% if one adult patient who died 32 days after transplant is excluded.^f^. Six of seven patients <13, one patient was age 29.^gg^
Schwachman-Diamond Syndrome | Burroughs, Woolfrey and Shimamura, 2009^175^ (Literature Review) | Allogeneic HSCT | SDS patients with marrow aplasia, MDS/AML | | - Grade III and Grade IV GVHD 24% and 29% ii.; Transplant related Mortality 35.5%, with higher rates 67% vs. 20% for those receiving a TBI containing regimen^ii^. 19% graft failure (5 patients) | Burroughs, Woolfrey and Shimamura, 2009^175^ (Literature Review)
Dyskeratosis Congenita | Myers and Davies, 2009^168^ (Literature Review) | Androgen therapy with oxymetholone | First line therapy for those in bone marrow failure without a matched donor. | Androgen therapy may produce some improvement in hemopoietic function in some patients for a variable amount of time. | - increased incidences of chronic pulmonary and vascular complications, particularly pulmonary fibrosis.; For patients with matched donor Mortality rates of; - 50% using CY and ATG conditioning; - 85% using CY alone.^jj^ (ages 2-33, 1/3 of patients were over 18) | No quantitative data were found. The mechanism of action is also not well understood, but it appears to promote direct growth of hemopoietic progenitors.^kk^ Long term toxicity and harm data is not available as followup has only reached two years on a few patients alive after transplant.
Dyskeratosis Congenita | Myers and Davies, 2009^168^ (Literature Review) | Allogeneic HSCT | First line therapy for those with bone marrow failure who have a matched related donor. | | | These are a mixture of matched related and matched unrelated donors. Long term outcomes do not exist due to the fact that survival from HSCT has historically been low.
Dyskeratosis Congenita | De la Fuente and Dokal, 2007^176^ (Literature Review) | Allogeneic HSCT | First line therapy for those with bone marrow failure who have a matched related donor. | - 86% survival among 7 patients transplanted using nonmyeloablative procedures u -^qq^. | | These are a mixture of matched related and matched unrelated donors. Long term outcomes do not exist due to the fact that survival from HSCT has historically been low.
Dyskeratosis Congenita | MacMillan et al. 1998^177^ (two case reports) | Allogeneic HSCT | First line therapy Matched Unrelated | | - Patient 1 developed grade 1 GVHD, hemorrhagic cystitis, three episodes of E. coli sepsis and hypertension; - Patient 2 developed grade 2 GVHD, hemorrhagic cystitis and hypertension.
Congenital Amegakaryocytic Thrombocytopenia | Kudo et al. 2002^178^ (Case Reports) | Allogeneic HSCT | First line therapy matched unrelated donor | - Patient 1 engrafted after 16 days and survived for one year post-transplant; - Patient 2 engrafted on day 14 and was alive at the time of publication
Congenital Amegakaryocytic Thrombocytopenia | MacMillan, et al. 1998^177^ (Case Reports) | Allogeneic HSCT | First line therapy matched unrelated donor | - Patient 1 was alive 16 months after a second transplant (failed engraftment on the first transplant); - Patient 2 failed two transplants (UCB, BM), then engrafted after the third transplant (UCB) and was alive 7 months after transplant
Congenital Amegakaryocytic Thrombocytopenia | Steele et al. 2005^179^ (Case Report) | Allogeneic HSCT | First line therapy matched unrelated donor | Patient was alive 21 months after transplant; - engraftment on day 10 | - Developed grade 1 GVHD, and alopecia; - had a severe allergic and febrile reaction to equine ATG so was switched to rabbit ATG.
Congenital Amegakaryocytic Thrombocytopenia | Al-Ahmari et al. 2004^180^ (Five Case Reports) | Allogeneic HSCT | First line therapy matched related | 80% of the patients were alive at a median followup of 30 months.; - one patient failed to engraft and subsequently died after another failed transplant. | aGVHD ≥ grade 2 was observed in three patients; - one patient has cGVHD but symptoms were under control.; - 80% developed transient hypertension; - one patient developed veno-occlusive disease, which resolved with conservative measures | Three donors were siblings and two were parents.
Congenital Amegakaryocytic Thrombocytopenia | Yesilipek et al. 2000 181 (Case Report) | Allogeneic HSCT | First line therapy matched related | - patient alive 20 months post transplant with PSC
Congenital Amegakaryocytic Thrombocytopenia | Lackner et al. 2000^182^ (Case Series of eight) | Allogeneic HSCT | First line therapy both matched related and unrelated | - 75% of patients were alive at a median of 17 months followup; - 88% (7) of patients engrafted | - three patients developed aGVHD grade 2 | Five bone marrow One cord blood Two peripheral stem cells
Diamond-Blackfan Anemia (DBA) | Lipton and Ellis, 2009^183^ (Literature Review) | Corticosteroids and/or red cell transfusion | First-line therapy corticosteroids | - ∼80% of patients respond. Of the 80%; 20% achieve Remission 40% require continued steroid therapy 40% remain transfusion and chelation dependent v. | - 22% develop pathologic fractures and 12% cataracts with the use of corticosteroids. 5/36 deaths reported to the DBAR were due to complications of iron overload from red cell transfusion. | - 17% are nonresponsive to corticosteroids.^v^; Steroid use has been modified since these estimates.
Diamond-Blackfan Anemia (DBA) | Lipton and Ellis, 2009^183^ (Literature Review) | Allogeneic HSCT | For patients who have become transfusion dependent or steroid intolerant | - overall actuarial survival at greater than 40 years is 75.1% (65.9-84.9) 100% for those in sustained remission 86.7%(73.0-100) for corticosteroid-maintained patients and 57.2 (39.7-74.7) for transfusion dependent patients.; 72.7% 5-year survival for matched sibling donor and 19.1% for alternative donor's ss. 76% 3-year survival after sibling versus 39% with alternative donor transplantation.^tt^. 90% survival for children under 10 transplanted with matched sibling donor. Unpublished data from the DBAR shows actuarial survival, since 2000, for all DBA patients transplanted using alternative donors to be 80%. Patients were carefully selected when they lacked a suitable matched-related donor. | 14 of 36 deaths reported to the DBAR were complications of HSCT
Severe Congenital Neutropenia/ Kostmann Syndrome | Elhasid and Rowe, 2010^184^ (Literature Review) | Human Granulocyte colony-stimulating factor (G-CSF) | First-line therapy | >90% of patients respond to G-CSF with an increase in total neutrophil count and ANC as well as a decrease in the incidence of infection^uu,vv^. | Incidence of MDS/Acute leukemia increases from 2.9% to 8% per year by 12 years of G-CSF therapy ww. Osteoporosis may develop in as many of 50% of patients on G-CSF therapy xx. Vasculitis has been reported in 3.3% (9/270) SNC patients xx. Incidence of splenomegaly increased from baseline 20.6% prior to treatment to 38.9% during the first year and remained (33.8-47.6%) over the course of 10 years of treatment xx. | It is unclear if the increased incidence is indeed a medication side effect or the natural history of disease as until G-CSF therapy life expectancy was too short to observe these effects.
Severe Congenital Neutropenia/ Kostmann Syndrome | Elhasid and Rowe, 2010^184^ (Literature Review) | Allogeneic HSCT | Refractory to G-CSF | 88% engraftment (7/8) among those receiving HLA-identical sibling donor. Three with alternate donors 1/3 survived with excessive cGVHD zz. | Grade 0-1 acute GVHD, one patient who received UCB had fatal acute grade IV GVHD. Additionally one case of extensive chronic GVHD was observed. Severe infection occurred in 4 pts, 3 were fatal yy. | Eight of nine patients engrafted after HSCT with 61% Five year survival among nine patients (four refractory, one BMF, four MDS/acute leukemia). The three deaths occurred at a median time of 0.7 years after transplant aaa.
Severe Congenital Neutropenia/ Kostmann Syndrome | Elhasid and Rowe, 2010^184^ (Literature Review) | Allogeneic HSCT | Occurrence of MDS and acute leukemia | Three of 18 patients survived after HSCT.

a Pongtanakul, et al. 2008^185^ retrospective study of immunosuppressive therapy in AA, n=42;

b Scheinberg et al. 2008^186^ retrospective study of immunosuppressive therapy in severe AA, n=77 ;

c Kojima et al. 2000^187^ retrospective study comparing HSCT and immunosuppressive therapy in AA, n=100;

d Kojima et al., 2002^187^ cohort study of immunosuppressive therapy and the subsequent development of MDS and AML, n=113 ;

e Frickhofen et al., 2003^188^;

f Kosaka et al., 2008^189^ cohort study of immunosuppressive therapy in severe and very severe AA, n=201;

g Locasciulli et al. 2007^190^ retrospective study comparing immunosuppressive therapy and HSCT in two sequential cohorts, n=2479;

h Bacigalupo et al. 2000^191^ outcomes for 1,759 patients treated with matched sibling transplant in Europe ;

i Locatelli et al. 2000^192^ randomized trial on the effect of GVHD on survival after matched sibling HSCT, n=71;

j Farzin et al. 2007^193^ cohort study of matched sibling donor HSCT in FA, n=18;

j Schrezenmeier et al., 2007^194^ retrospective analysis comparing survival after PBSC and BM in 692 (134 PBSC, 558 BM) patients with SAA.;

k Deeg et al. 1996^195^ analysis of secondary malignancies after myeloablative transplantation for SAA, n=700;

l Deeg et al. 1998^196^ cohort study of long-term survivors of HSCT for AA, n=212;

m Bacigalupo et al. 2005^197^ prospective cohort of 38 patients with SAA, reporting outcomes after HSCT;

n Deeg et al. 2006^198^ nonrandomized trial of conditioning regimens for unrelated donor HSCT; n=87;

o Viollier et al. 2008^199^ retrospective study of unrelated HSCT, n=498;

p Dufour and Svahn, 2008^174^ review;

q Guardiola et al. 2000^200^ retrospective analysis of 69 allogeneic stem-cell transplants for FA from EGBMT;

r de Medeiros et al. 2006^201^ retrospective analysis of FA patients from a single institution who underwent alternative HSCT, n=47;

s Dufour and Svahn 2008^174^ review;

u Zanis-Neto et al. 2005^202^ nonrandomized trial of low-dose cyclophosphamide conditioning for matched related HSCT, n=30;

v Zanis-Neto et al. 2005^202^ nonrandomized trial of low-dose cyclophosphamide conditioning for matched related HSCT, n=30;

w Wagner et al. 2007^203^ retrospective study of alternative donor transplants in FA, n=98;

x Locatelli et al. 2007^204^, cohort study of outcomes after HSCT, n=26 for those with an unrelated donor ;

y Yabe et al. 2006^205^ cohort study of alternative donor HSCT, n=27;

z de Medeiros et al. 2006^201^ retrospective analysis of FA patients from a single institution who underwent alternative HSCT, n=47;

aa Chaudhury et al. 2008^206^ retrospective study of fludarabine-based conditioning regimen for HSCT in high-risk FA, n=18;

bb Gluckman et al. 2007^207^ retrospective registry review of cord blood transplant in FA, n=93;

cc Gluckman et al. 2007^207^, retrospective registry review of cord blood transplant in FA, n=93;

dd Wagner et al. 2007^203^ retrospective study of alternative donor transplants for FA, n=98;

ee Vibhakar et al. 2005^208^ case report of umbilical cord blood HSCT for SDS, n=3;

ff Donadieu et al. 2005^209^ retrospective registry analysis of unrelated and identical sibling donor HSCT for SDS, n=10;

gg Bhatla et al. 2008^209, 210^ series of 7 SDS patients with marrow aplasia or MDS/AML;

hh Cesaro et al. 2005^211^ report on 26 patients with SDS;

ii Cesaro et al. 2005^211^ report on 26 patients with SDS;

jj de la Fuente and Dokal 2007^176^, review of 28 cases of HSCT for DC;

kk Beran et al. 1982^212^ in vitro study of the effects of testosterones on human erythroid progenitor cells;

ll Ayas et al. 2005^213^ case report;

mm Dror et al. 2003^214^ case report;

nn Brazzola et al. 2005^215^ case report;

oo Gungor et al. 2003^216^ case report;

pp Cossu et al. 2002^217^ case report;

qq Nobili et al. 2002^218^ case report;

rr Vlachos et al. 2008^219^ consensus document from the 2005 Diamond Blackfan Anemia International Consensus Conference;

ss Lipton et al. 2006^220^ series of 36 patients from the DBA registry;

tt Roy et al. 2005^221^ series of 61 patients with DBA who underwent HSCT;

uu Zeidler et al. 2000^222^ management of Kostman syndrome with G-CSF;

vv Rosenberg et al. 2006^223^ review of harms associated with long-term G-CSF treatment in 29 SCN patients;

ww Rosenberg et al. 2006^223^ harms associated with long term G-CSF treatment in 29 SCN patients;

xx Yakisan et al. 1997^224^ cohort of 30 patients with SCN;

yy Ferry et al. 2005^173^ HSCT among 9 patients in the French SCN registry;

zz Zeidler et al. 2000^225^ HSCT among 11 patients without malignant transformation;

aaa Ferry et al. 2005^173^ HSCT among 9 patients in the French SCN registry

The literature review168 reports for patients without a matched sibling donor immunosuppression can offer 89 percent 10-year survival among responders. Seventeen to 34 percent will eventually require HSCT as salvage therapy and the long term use of immunosuppressants leave the patient at higher risk for infection and an increased rate of MDS/AML of 8 to 25 percent. For patients with a matched sibling donor survival rates after transplant are far better reaching 98 percent in some series. A matched sibling bone marrow transplant may offer better survival 85 percent versus 73 percent with peripheral blood stem cells and a lower risk of graft versus host disease. Various conditioning regimens are available and are associated with varied rates of adverse events.

###### Guidelines

Guidelines for the treatment of acquired aplastic anemia with HSCT were published by Bagby et al.172

The treatment algorithm recommends:

- patients younger than 35 years with a matched sibling donor, HSCT as first-line therapy,
- patients older than 35 years or no matched sibling donor, immunosuppressive therapy as first-line therapy,
- HSCT as treatment for those refractory to immunosuppression.

###### Summary

Overall there appears to be a favorable risk-benefit profile for the treatment of acquired aplastic anemia with HSCT. Clinical management entails immunosuppression and HSCT. In general younger patients with a matched sibling donor are encouraged to pursue HSCT, while older patients who are less tolerant of transplant or those without a matched sibling donor are first put on immunosuppressive therapy. For those receiving transplant, control of graft-versus-host disease is essential in achieving high rates of survival. Selection of a conditioning regimen influences the harms associated with transplantation.

#### Inherited/Congenital Bone Marrow Failure Syndromes

##### Fanconi Anemia

###### Background

First described in 1927,^226, 227^ Fanconi anemia is an inherited chromosomal instability that affects all of the bone marrow elements. It is associated with various physical malformations, including pigmentary changes of the skin, and predisposes to malignancy. Fanconi anemia is the most common inherited bone marrow failure syndrome, with thirteen identified subtypes.172 With the exception of subtype B, all follow an autosomal recessive pattern of inheritance.228, 229 Among patients with Fanconi anemia, bone marrow failure, typically occurs between 5 and 10 years of age with a cumulative risk of 50 to 90 percent by age 40. Patients are highly susceptible to cancer, with a cumulative incidence of hematologic malignancy of 22 to 33 percent by age 40.^223, 230^ While malformations are common, approximately 25 to 40 percent of affected individuals have no visible anomalies.172

###### Evidence Base

The evidence compiled for this review includes two literature reviews.168, 174 One clinical practice guideline231 but no health technology assessments for the treatment of childhood Fanconi anemia with HSCT were identified in the literature search. The evidence base on the use of HSCT for treatment of Fanconi anemia is summarized in Table 22.

The literature review by Dufour and Svahn174 reports on androgen therapy, the frontline treatment choice for children without a matched sibling donor. According to the review, approximately 75 percent of such patients respond to androgen therapy within 2-12 months. Reported harms associated with androgen therapy include, but are not limited to, virilization, hyperactivity, renal toxicity, and possible adverse effects on subsequent HSCT. Myers and Davies168 report survival after HSCT using matched sibling donor of about 90 percent, but with a transplant comes the risk of peritransplant mortality of 10 to 15 percent and a risk of chronic graft-versus-host disease from 12 up to 28.5 percent, based on the conditioning regimen.

###### Guidelines

Guidelines for the treatment of Fanconi anemia with HSCT were developed at a conference held April 10-11, 2008 in Chicago, Illinois and are published by the Fanconi Anemia Research Fund.231 HSCT is currently the best therapy available to cure the patient of marrow aplasia, to prevent progression to myelodysplastic syndrome or AML, or to cure existing MDS or AML.

Among patients with a matched sibling donor, treatment with HSCT may proceed if there is:

- Platelet count of less than 50,000
- Hemoglobin less than 8 gm/dL
- Transfusion dependence
- Absolute neutrophil count less than 1,000
- Absolute neutrophil count greater than 1,000 with frequent infection

Among patients with no matched related donor and adequate organ function and controlled infection treatment with HSCT may be considered if:

- Persistent and severe cytopenia develops
  ○ Hemoglobin less than 8 g/dL
  ○ Absolute neutrophil count less than 500/mm^3^
  ○ And/or platelets less than 20,000/mm^3^
- There is evidence of myelodysplastic syndrome or leukemia

Other indications for transplant:

- Absolute indication
  - For patients with high-risk myelodysplastic syndrome or AML, HSCT is recommended
- Relative indication
  - For patients with moderate isolated cytopenias or moderate aplastic anemia with evidence toward progression towards transfusion dependence
  - For low-risk myelodysplastic syndrome

###### Summary

Overall there appears to be a favorable risk-benefit profile for the treatment of Fanconi anemia with HSCT. The vast majority of patients with Fanconi anemia will progress to aplastic anemia or myelodysplastic syndrome/AML without transplant. HSCT using matched sibling donor have survival rates of about 90 percent. In general, patients are transplanted prior to the development of myelodysplastic syndrome/AML, as the outcomes are better for patients with aplastic anemia. Age also is considered, as younger age is associated with better outcomes. Androgen therapy has a long history of use in patients with Fanconi anemia; however, due to adverse effects to liver function, other significant adverse effects, and its effect on later adverse effects after transplant, it is generally recommended this therapy be reserved for patients with no matched sibling donor, but not as a definitive long-term treatment.

##### Schwachman Diamond Syndrome

###### Background

Schwachman Diamond syndrome is a rare disorder characterized by pancreatic insufficiency, skeletal abnormalities, and bone marrow failure. The disease has an autosomal recessive pattern of inheritance, with almost all affected persons having a mutation in the SBDS gene on chromosome 7q11.^232^ Approximately 200 cases have been reported, with very few patients being treated with allogeneic HSCT.170, 233 These patients are at higher risk than the general population for myelodysplastic syndrome and leukemia, specifically AML.172 Approximately 20 percent will develop aplastic anemia, 20 to 33 percent develop myelodysplastic syndrome or cytogenetic abnormalities, and 12 to 25 percent will eventually develop acute leukemia.209, 234-236 Nonhematologic malignancies have not been associated with Schwachman Diamond syndrome.171 Median survival in Schwachman Diamond syndrome is more than 35 years, but less for those developing aplastic anemia or leukemia. Clinical management consists of symptom-specific treatments, close monitoring of peripheral blood counts, and annual marrow evaluation allowing for treatment prior to clinical complications. Infections and hemorrhage associated with hematologic abnormalities are the primary causes of Schwachman Diamond syndrome-associated death after infancy.175 HSCT may provide a cure233 but significant cardiac and other organ toxicities have been described.175 Most patients do not require transplantation. Those who develop marrow aplasia or MDS/AML are candidates for HSCT.

###### Evidence Base

The evidence compiled for this review includes two literature reviews.168, 174 No health technology assessments or clinical practice guidelines for the treatment of Schwachman Diamond syndrome with HSCT were identified in the literature search. The evidence base on the use of HSCT for treatment of Schwachman Diamond is summarized in Table 22.

In the review by Burroughs and colleagues,175 performance of HSCT is reported to be associated with improved outcomes when performed before the development of overt leukemia. Significant organ toxicities, specifically cardiac, have been reported and are thought to occur by the aggravation of underlying organ dysfunction caused by conditioning regimens. Fludarabine-based regimens appear to reduce the toxicity for these patients, although reported numbers are small.168 Survival among 7 patients transplanted with myelodysplastic syndrome and/or AML who received fludarabine-based conditioning was 100 percent, compared to 60 percent 5-year survival (n=10) using a fully myeloablative regimen, with matched or unmatched donor.168

###### Guidelines

No guidelines for the treatment of Schwachman-Diamond syndrome were identified in the search.

###### Summary

Overall there appears to be a favorable risk-benefit profile for the treatment of Schwachman-Diamond with HSCT. While supportive measures such as transfusions, pancreatic enzymes, antibiotics are used, the only curative therapy for marrow failure, myelodysplastic syndrome, or leukemia is HSCT. Performance of HSCT is associated with better outcomes when performed prior to the development of overt leukemia. Aggravation of underlying organ dysfunction can occur with various conditioning regimens. Children with Schwachman-Diamond undergoing HSCT may receive a preparative regimen not including high-dose total body irradiation or cyclophosphamide.

##### Dyskeratosis Congenita

###### Background

Dyskeratosis congenita is a rare disorder related to a defect in telomere maintenance237 that is characterized by abnormal skin pigmentation, nail dystrophy, and mucosal leucoplakia.238 Ninety percent of reported cases are male with observed linkage to Xq28. Autosomal recessive and dominant inheritance have been noted.239 While precise estimates of incidence are unknown, dyskeratosis congenita has been recognized across racial groups, with an estimated prevalence of 1 in 1,000,000 persons. This disease presents with both clinical and genetic heterogeneity, even within families, making diagnosis and treatment challenging. The dyskeratosis congenita registry includes approximately 350 cases to date,171 and through 2008, approximately 552 cases have been reported in the literature.240 Patients exhibit a predisposition to bone marrow failure, malignancy and pulmonary dysfunction. Eighty to 90 percent of patients develop bone marrow failure by age 30.^171^ Bone marrow failure accounts for the majority of deaths (approximately 60 to 70 percent), while pulmonary complications (approximately 10 to 15 percent) and malignancies (approximately 10 percent) account for the rest.241 Commonly, bone marrow failure and/or other complications present prior to diagnosis.242

Dyskeratosis congenita has highlighted the critical role of telomerase in human growth and development, the major complication of which is bone marrow failure. The only curative treatment for severe bone marrow failure is allogeneic HSCT; however, in patients with dyskeratosis congenita, this is not a cure for the underlying disease, as HSCT does not address the telomerase defect.176 The median survival for patients with dyskeratosis congenita is 44 years of age. For patients with severe subsets of disease, such as Hoyeraal-Hreidarsson syndrome (n=30 cases ever described) and Revesz syndrome (n=20 reported cases), median survival is dramatically reduced to 5 years and approximately 11 years, respectively. There are no cases of either of these severe disease subtypes in patients older than 20 years.243

###### Evidence Base

The evidence compiled for this review includes two literature reviews.168, 176 No health technology assessments or clinical practice guidelines for the treatment of dyskeratosis congenita with HSCT were identified in the literature search. One clinical practice guideline243 follows the model of Fanconi anemia to determine treatment for bone marrow failure from dyskeratosis congenita. The evidence base on the use of HSCT for treatment of dyskeratosis congenita is summarized in Table 22.

Survival estimates when using nonmyeloablative regimens are improved over the 50 to 85 percent mortality seen with prior regimens.168 However, as stated previously, HSCT is not a cure for this disorder as it does not remedy the underlying telomerase defect. Patients who survive transplant are at increased risk of pulmonary and vascular complications, although, due to the small number of patients, complication rates are not available.

###### Guidelines

No guidelines specific for the treatment of dyskeratosis congenita were identified in the search. However, in a recent publication by Savage and Alter,243 following the model of Fanconi anemia consensus guidelines, treatment for bone marrow failure is recommended if:

- Hemoglobin is consistently less than 8 g/dL, platelets less than 30,000/mm^3^, and neutrophils less than 1000/mm^3^.
- The first consideration for treatment for hematologic problems such as bone marrow failure may be HSCT, if there is a matched related donor.
- HSCT from an unrelated donor can be considered, although a trial of androgen therapy may be chosen.

###### Summary

Overall there appears to be a favorable risk-benefit profile for the treatment of dyskeratosis congenita with HSCT. For patients who have developed severe bone marrow failure with hemoglobin consistently less than 8 g/dL, platelets less than 30,000/mm^3^, and neutrophils less than 1000/mm^3^ and they have a matched related donor, HSCT is first-line treatment. HSCT is not a cure for dyskeratosis congenita as it does not address the underlying telomerase defect. Patients who survive transplant are at increased risk of pulmonary and vascular complications although due to the small numbers of patients, complication rates are not available.

##### Congenital Amegakaryocytic Thrombocytopenia

###### Background

Congenital amegakaryocytic thrombocytopenia is an extremely rare disorder characterized by isolated thrombocytopenia, reduction/absence of megakaryocytes in the bone marrow with in most cases no somatic abnormalities.171 It follows an autosomal recessive inheritance pattern and is caused by mutations in the thrombopoietin receptor MPL.244 While disease incidence is unknown, severe thrombocytopenia is observed in 0.12 to 0.24 percent of all newborns, and congenital amegakaryocytic thrombocytopenia represents a very small percentage of those. The diagnosis is made after excluding other acquired and inherited forms of thrombocytopenia.245 Affected individuals are identified shortly after birth.170 In the absence of HSCT, patients will develop severe aplastic anemia, leading to death. Median age of progression to severe aplastic anemia is 3.7 years.246

###### Evidence Base

The evidence compiled for this review includes one case report181 and five case series.177-180, 182 No health technology assessments or clinical practice guidelines for the treatment of congenital amegakaryocytic thrombocytopenia with HSCT were identified in the literature search.

Data from the case series are consistent in reporting high levels of engraftment and short-term survival data. The largest case series of eight patients reported 75 percent survival at a median followup of 17 months.182 In that same series, three patients developed grade 2 acute graft-versus-host disease.

###### Guidelines

No guidelines for the treatment of congenital amegakaryocytic thrombocytopenia were identified in the search.

###### Summary

Overall there appears to be a favorable risk-benefit profile for the treatment of congenital amegakaryocytic thrombocytopenia with HSCT. Clinical management utilizes platelet transfusions to prevent a patient from bleeding. HSCT from matched related donors have been encouraging but due to the lack of healthy matched related donors for these patients, often matched unrelated donors are needed, which carry a higher risk of graft failure and transplant-related toxicity. Without HSCT, these children will die at a median age of 3 years.

##### Diamond Blackfan Anemia

###### Background

Diamond Blackfan anemia, or congenital pure red cell aplasia, was reported in four children in 1938 by Diamond. It usually presents in infancy, although a subset of cases may present in adulthood, with symptoms of anemia such as pallor or failure to thrive. Most familial cases display an autosomal dominant pattern of inheritance.171 Based on an analysis by the Diamond Blackfan anemia registry of North America, the annual incidence is approximately 5 per million live births with 93 percent of patients presenting in the first year.220 Rates of cancer among patients with Diamond Blackfan are lower than rates among other hereditary bone marrow failure syndromes; however, with 4 percent of children with Diamond Blackfan diagnosed with cancer by age 15, the rate is much higher than the general population.219

###### Evidence Base

The evidence compiled for this review includes one literature review.183 One clinical practice guideline219, but no health technology assessments for the treatment of Diamond Blackfan anemia with HSCT were identified in the literature search. The evidence base on the use of HSCT for treatment of Diamond Blackfan is summarized in Table 22.

Data included in the literature review report that 80 percent of patients respond to first-line corticosteroids and that of those, 20 percent achieve remission. Twenty-two percent of patients develop pathologic fractures and 12 percent develop cataracts as a result of corticosteroid treatment.183 Survival after HSCT has been reported at longer than 40 years, 100 percent for those in remission prior to transplant, 87 percent for corticosteroid-maintained patients, and 57 percent for transfusion-dependent patients.183

###### Guidelines

Guidelines for the treatment of DBA with HSCT were published by Vlachos et al.219 Treatment with HSCT is recommended in patients with Diamond Blackfan whether corticosteroid responsive or transfusion dependent; patients typically are younger than 10 years of age, preferably between 2 and 5 years of age, if an HLA-matched donor is available.

###### Summary

Overall there appears to be a favorable risk-benefit profile for the treatment of DBA when an HLA-matched donor is available. HSCT is curative in DBA and deaths after HSCT appear to be attributed to toxicities rather than graft failure. Data on the effects of various conditioning regimens is too limited to draw conclusions.

##### Severe Congenital Neutropenia/Kostmann Syndrome

###### Background

First described in 1956 by Kostmann, severe congenital neutropenia is a rare genetic condition. Children with the disorder typically present with severe neutropenia, fever, and recurrent infections of the upper respiratory tract, lungs, and skin. Among the nine inbred families in which severe congenital neutropenia was first noted, the inheritance pattern is autosomal recessive;247 however, most other documented cases follow an autosomal dominant or sporadic pattern of inheritance.248 The incidence is approximately 3 to 4 per million births, with the majority of patients identified in the first three months of life. A subset of patients also has a mutation in the cytoplasmic component of the granulocyte colony-stimulating factor (G-CSF) receptor gene. These patients are at increased risk of developing acute myeloid leukemia.249

###### Evidence Base

The evidence compiled for this review includes one literature review.184 No health technology assessments for the treatment of severe congenital neutropenia with HSCT were identified in the literature search. The evidence base on the use of HSCT for treatment of severe congenital neutropenia is summarized in Table 22.

Ninety percent of patients are reported to respond after first-line treatment with G-CSF.184 However, long term treatment with G-CSF may lead to the development of myelodysplastic syndrome/acute leukemia, or osteoporosis. For patients refractory to G-CSF, Elhasid and Rowe184 reported 61 percent survival at 5 years, and for those who had developed myelodysplastic syndrome/acute leukemia, three of 18 survived.

###### Guidelines

Guidelines for treatment of severe congenital neutropenia with HSCT were published by Elhasid and Rowe.184 These recommendations are broken down into two groups, absolute and probable indications.

- Absolute indications:
  - Refractory to G-CSF therapy
  - Occurrence of MDS and acute leukemia
- Probable indications:
  - Gly185Arg missense mutation
  - Wild-type ELA2 not responding to standard doses of G-CSF

###### Summary

Overall there appears to be a favorable risk-benefit profile for the treatment of severe congenital neutropenia with HSCT. Development of MDS and acute leukemia are absolute indications for HSCT as this would be the only curative option. Patients with a matched donor are followed closely as outcomes are better if the transplant is completed prior to the development of MDS/acute leukemia. It is important to note that current recommendations are based on very small numbers of patients due to the rarity of this condition.

### Primary Immunodeficiencies

#### Background

The primary immunodeficiencies are a genetically heterogeneous group of diseases that affect distinct components of the immune system (Table 23). More than 120 gene defects have been described, causing more than 150 disease phenotypes.250 The most severe defects (collectively known as “severe combined immunodeficiency” or SCID) cause an absence or dysfunction of T lymphocytes, and sometimes B lymphocytes and natural killer cells.250

Table 23 Primary immunodeficiencies successfully treated with HSCT

Disease
[underlined: Lymphocyte immunodeficiencies] Adenosine deaminase deficiency Artemis deficiency Calcium channel deficiency CD 40 ligand deficiency Cernunnos-XLF immunodeficiency CHARGE syndrome with immune deficiency Common gamma chain deficiency Deficiencies in CD 45, CD3, CD8 DiGeorge syndrome DNA ligase IV Interleukin-7 receptor alpha deficiency Janus-associated kinase 3 (JAK3) deficiency Major histocompatibility class II deficiency Omenn syndrome Purine nucleoside phosphorylase deficiency Recombinase-activating gene (RAG) 1/2 deficiency Reticular dysgenesis Winged helix deficiency Wiskott-Aldrich syndrome X-linked lymphoproliferative disease Zeta-chain-associated protein-70 (ZAP-70) deficiency [underlined: Phagocytic deficiencies] Chediak-Higashi syndrome Chronic granulomatous disease Griscelli syndrome, type 2 Interferon-gamma receptor deficiencies Leukocyte adhesion deficiency Severe congenital neutropenias^*^ Shwachman-Diamond syndrome^*^ [underlined: Other immunodeficiencies] Autoimmune lymphoproliferative syndrome Cartilage hair hypoplasia CD25 deficiency Familial hemophagocytic lymphohistiocytosis Hyper IgD and IgE syndromes ICF syndrome IPEX syndrome NEMO deficiency NF-κB inhibitor, alpha (IκB-alpha) deficiency Nijmegen breakage syndrome

* While considered primary immunodeficiencies these conditions are described in the section dealing with bone marrow failure syndromes.

Without treatment, patients with severe combined immunodeficiency usually die by 12 to 18 months of age. With supportive care, including prophylactic medication, the lifespan of these patients can be prolonged, but long-term outlook is still poor, with many dying from infectious or inflammatory complications or malignancy by early adulthood.250

#### Evidence Base

The evidence compiled for this review (Table 24) includes three literature reviews (Table 25).250-252 No health technology assessments or clinical practice guidelines for the treatment of primary immunodeficiencies with HSCT were identified in the literature search.

Table 24 Evidence base for HSCT in primary immunodeficiencies

Disease | Year of First HSCT Performed | No. of Transplants to Date | Existing Clinical Data | Registries
Primary Immunodeficiencies | 1968 | >2000 | Reviews, Case series, Case reports | The Stem Cell Transplantation for Immunodeficiencies registry in France contains outcome data from many European centers. European Blood and Marrow Transplant network and the Center for International Blood and Marrow Transplantation both have registries covering people with Primary Immunodeficiencies. Specific registries exist for diseases such as; X-linked lymphoproliferative disease, chronic granulomatous disease, CD40 ligand deficiency, Wiskott-Aldrich syndrome.

Table 25 Benefits and harms after treatment for primary immunodeficiency

Disease | Source | Treatment | Indications | Benefits | Harms | Comment
Primary Immunodeficiency | Orange et al. 2006^252^ (Literature review) | IVIG (Intravenous immunoglobulin) SCIG (Subcutaneous immunoglobulin) | Primary treatment for those producing no antibodies, limited antibodies, and those with impaired specific antibody production | Reduction in both acute and chronic infections. | Up to 44% of patients may experience adverse reactions not related to rate of infusion ^¥^ | Additional harms are associated with the risks of placing a indwelling venous catheter for IVIG or the additional needed sticks for SCIG ^¥^ from a 2002 Immune Deficiency patient survey.
Primary Immunodeficiency | Ginnery and Cant, 2008^250^ (Literature review) | HSCT | Primary treatment for patients with Severe combined immune-deficiency and second line treatment for other PID | 5 year survival 90%*, after transplant from matched sibling donor and 69%* using matched unrelated donor. Other series report overall survival estimates ranging from 92-100% for related matched donors and 78-80% for matched unrelated donors a^l^b and 52% for mismatched unrelated donors. a | Acute GVHD developed in about 31-36% of children transplanted with related identical marrow, 50-73% in those receiving matched unrelated marrow a^l^b, and 45% in those transplanted with mismatched related donor marrow. a | * Survival rates were communicated as personal communication from P Landaus to the review papers authors.
Primary Immunodeficiency | Filipovich, 2008^251^ (Literature review) | HSCT | Primary treatment for patients with Severe combined immune-deficiency and second line therapy for other PID | 3 year survival of approximately 80%, 50% and 70% from matched sibling, haploidentical and unrelated donors.^c^

a Grunebaum et al. 2006^255^ retrospective cohort study of 94 SCID patients treated with HSCT

b Buckley et al. 1999^256^ report on 89 infants treated with HSCT for SCID

c Antoine et al. 2003^253^ registry report of 475 SCID and 512 non-SCID transplants

HSCT using HLA-identical sibling donors can provide correction of underlying primary immunodeficiencies such as SCID, Wiskott-Aldrich syndrome, and other prematurely lethal X-linked immunodeficiencies in approximately 90 percent of cases where a donor is available.251 According to a European series of 475 patients collected between 1968 and 1999, 3-year survival rates for SCID were 81 percent with a matched sibling donor, 50 percent with a haploidentical donor, and 70 percent with a transplant from an unrelated donor.253 Since 2000, overall survival for patients with SCID who have undergone HSCT is 71 percent.250 For non-SCID patients, 3 year survival rates were 71 percent, 42 percent, and 59 percent for genotypically HLA-matched, phenotypically HLA-matched and HLA-mismatched related, and HLA-mismatched unrelated, respectively.253

For Wiskott-Aldrich syndrome, which has a median survival of 15 years, an analysis of 170 patients transplanted between 1968 and 1996 demonstrated the impact of donor type on outcomes.254 Fifty-five transplants were from HLA-identical sibling donors, with a 5-year probability of survival of 87 percent (95 percent CI: 74–93 percent); 48 were from other relatives, with a 5-year probability of survival of 52 percent (37 to 65 percent); and 67 were from unrelated donors with a 5-year probability of survival of 71 percent (58 to 80 percent; p=0.0006). In patients with genetic immune/inflammatory disorders such as hemophagocytic lymphohistiocytosis the current results with allogeneic HSCT are 60 to 70 percent 5-year disease-free survival. Survival rates for patients with other immunodeficiencies are similar at 74 percent, with even better results (90 percent) when well-matched donors are used for defined conditions such as chronic granulomatous disease. Survival after HSCT for primary immunodeficiencies is good, and data show that patients surviving 12-24 months post-transplant generally have good long-term outcomes since relapse does not occur, as it may with hematologic malignancy.250

#### Guidelines

No guidelines for the treatment of primary immunodeficiencies were identified in the search.

#### Summary

Overall there appears to be a favorable risk-benefit profile for the treatment of SCID and other primary immunodeficiencies, including Wiskott-Aldrich syndrome and congenital defects of neutrophil function.257

While primary immunodeficiency diseases are heterogeneous, it is universally accepted that HSCT offers the only chance of cure. The best outcomes have been reported to occur when children are transplanted in infancy, prior to the development of organ damage.258, 259 Conventional therapies including treatment with IVIG may decrease morbidity and mortality but do not address the underlying problem or alter the long-term outcome.250 Gene therapy has been performed for over a decade now for ADA deficiency, X-linked SCID and WAS. It is, however, considered experimental.26

### Inherited Metabolic Diseases: Mucopolysaccharidoses

Mucopolysaccharidoses (MPS) are a group of disorders caused by single-gene defects leading to a deficiency in one of the 11 lysosomal enzymes needed to metabolize glycosaminoglycans (Table 26). As glycosaminoglycans accumulate in the cells, blood, and connective tissues, progressive damage to the skeletal structure and multiple organ systems occurs.261 Mucopolysaccharidoses are autosomal recessive disorders, with the exception of Hunter disease (MPS II), which is X-linked recessive. The severity of symptoms varies by subtype as well as within each subtype. The overall frequency of these disorders is estimated to be 3.5-4.5 per 100,000.^262-264^ MPS I, MPS VI, and MPS VII will be discussed in this section (Table 27) and MPS II, MPS III, and MPS IV will be discussed in the context of the Systematic Review.

Table 26 Evidence base for HSCT in MPS I, MPS VI and MPS VII

Disease | Treatment | Year of First Treatment | No. Patients Receiving Treatment to Date | Type of Research Available | Registries
MPS I | HSCT | 1980 | >500 | Case reports, case series, retrospective studies | Established in 2003: Genzyme Corporation and BioMarin Pharmaceutical initiated international observational database with treatment and outcome information; aggregate data available for research queries. Over 700 patients in registry.
MPS VI | HSCT | 1982 | >12 | Case reports, case series | BioMarin Pharmaceutical and the Women's and Children's Hospital in Adelaide, Australia have coordinated a registry; aggregate data available for research.
MPS VII | HSCT | 1994 | 2 | Case reports | None

Table 27 Treatment benefits and harms for Hurler Syndrome (MPS I), Maroteaux-Lamy Syndrome (MPS VI), and Sly Syndrome (MPS VII)

Disease | Treatment | Source and Evidence Type | Indications | Clinical Benefits | Clinical Harms
MPS I | ERT | Brady and Schiffman 2004,^265^ literature review | - all attenuated cases; - severe cases, dx ≤2 years, DQ^*^ <70 | - enzyme activity detected within 6-8 wks, with 50-80% reduction in excess glucosaminoglycans (GAG) secretion in urine; 63% mean reduction maintained following 1 year of ERT^a^; - liver volume decreased by 19% in ERT grp, increased by 1% in placebo grp^b^; - 1 year ERT: mean range of shoulder flexion increased 26-28 degrees, knee extension restriction decreased by 3-3.2 degrees, but skeletal abnormalities persist^a,c^; - 61% decrease in number of episodes of apnea and hypopnea after 1 year ERT^a^; - left ventricular hypertrophy resolves, but mitral and aortic valves remain thickened^c^; - 1 year on ERT: 25% mean reduction in liver size, 20% mean reduction in spleen size^a^; 6 years on ERT: liver volume in normal range for 100% pts, spleen volume near normal range in 50% pts^c^; - further coarsening of facial features did not progress as expected after 6 years of ERT in 100% of pts^c^; - worsening of pre-existing neurological symptoms can be expected^c^; - quality of life improvements include: increased energy and endurance, independence in normal daily activities, socializing, setting new goals for future such as college and marriage^c^ | - infusion-related reactions such as flushing, fever, headache, or rash experienced by 32% in ERT grp and 48% in placebo grp^b^; - IgG antibodies to enzyme develop in 100% of pts, but does not affect clinical efficacy of treatment^b^
MPS I | ERT | Wraith 2005,^266^ literature review | - all attenuated cases; - severe cases, dx ≤2 years, DQ^*^ <70
MPS I | ERT | Tolar and Orchard 2008,^267^ literature review | - all attenuated cases; - severe cases, dx ≤2 years, DQ^*^ <70
MPS I | Allogeneic HSCT | Prasad and Kurtzberg 2010,^268^ literature review | - severe cases with stable cardiopulmonary function, dx ≤2 yrs, DQ ≥70; - considered in rare attenuated cases, dx >2 yrs, DQ ≥70 | - 67% reach normal enzyme activity level^d^; - improves hearing in 30-40%, but does not reverse profound conductive and sensorineural abnormalities^e^; - improves joint mobility, but skeletal abnormalities persist in over 90% due to poor enzyme penetration of chondrocytes and failure to replace osteocytes^f,g^; - improves respiratory function relating to sleep apnea and persistent rhinorrhea within 3-6 months of transplant^h^; - improves myocardial muscle function and coronary artery patency within 1 year of transplant, but cardiac valvular deformities persist^i^; - resolves hepatosplenomegaly within 3 months of transplant^h^; - if transplant at ≤2 years, normal or near normal intellectual development reported in 64% of 12 cases; if transplant at >2 years, normal or near normal intellectual development in 25% of 12 cases^j^; - life expectancy prolonged^e,j^ | - acute graft vs. host disease 32% with HLA genotypically identical sibling donors and 55% for HLA haploidentical related donors^j^; - chronic graft vs. host disease 0% for HLA genotypically identical sibling donors and 24% for HLA haploidentical related donors^j^; - 8.3% pulmonary complications (hemorrhages and infections)^d^; - 10% viral, bacterial, and fungal infections^d^; - 15%^d^-42%^q^ treatment-related mortality reported (42% from transplants performed from 1980-1995; 15% from transplants performed 1994-2004 – improvements in donor matching and improved supportive care following transplant may be responsible for decrease in treatment-related mortality rate)
MPS I | Allogeneic HSCT | Boelens 2006,^269^ literature review | - severe cases with stable cardiopulmonary function, dx ≤2 yrs, DQ ≥70; - considered in rare attenuated cases, dx >2 yrs, DQ ≥70
MPS I | Allogeneic HSCT | Peters 2004,^270^ literature review | - severe cases with stable cardiopulmonary function, dx ≤2 yrs, DQ ≥70; - considered in rare attenuated cases, dx >2 yrs, DQ ≥70
MPS I | Allogeneic HSCT | Aldenhoven et al. 2008,^271^ literature review | - severe cases with stable cardiopulmonary function, dx ≤2 yrs, DQ ≥70; - considered in rare attenuated cases, dx >2 yrs, DQ ≥70
MPS VI | ERT | Brady and Schiffman 2004,^265^ literature review | - all cases as first-line therapy | - statistically significant difference in GAG secretion by week 24 between ERT group and placebo group in phase 3 trial (p<0.001) providing evidence of enzyme activity among ERT group^k^; - 5 of 9 experience improved joint mobility^l^; - hepatosplenomegaly improved in 5 of 9, worsened in 2 of 9, and remained stable in 2 of 9^l^; - sustained statistically significant improvement through phase 2 and phase 3 trials in 3-minute stair climb and 6- or 12-minute walk tests^m^ | - >50% experienced one or more infusion-related reactions such as flushing, fever, headache, or rash^m^; - one report of respiratory difficulty and anaphylaxis resulting in emergency tracheostomy (possibly exacerbated by underlying disease)^r^; - if central venous access port required for infusions, risk of infection and possibly endocarditis^r^
MPS VI | ERT | Harmatz et al. 2008^272^ (Phase III trial, N=56 age range 5-29) | - all cases as first-line therapy
MPS VI | Allogeneic HSCT | Peters 2004,^270^ literature review | - if ERT fails | - enzyme activity within normal range in 100% of pts^n,o^; - hepatosplenomegaly decreased^n^; - facial features became less coarse in 4 of 4 pts^o^; - dysphonia and hoarseness resolves in 2 of 2 pts^o^; - cardiac evaluation normal, but valve disease persists^n,o^; - sleep apnea resolved^n^; - significant improvement in posture, but dystosis multiplex persists^o^; - life expectancy prolonged^n,o^ | - acute graft vs. host disease in 3 of 4 pts^o^

* DQ=developmental quotient

a Kakkis et al. 2001,^273^ 10 MPS I pts on ERT weekly for one year

b Wraith et al. 2004,^274^ RCT of MPS I pts, 22 receiving ERT, 23 receiving placebo

c Sifuentes et al. 2007,^275^ 6-yr followup study of 5 pts in phase I/II trial for MPS I ERT

d Boelens et al. 2007,^276^ retrospective study of 146 MPS I pts in the European Blood and Marrow Transplantation registry

e Krivit et al. 1995,^277^ audiological evaluation on 12 MPS I pts following HSCT

f Field et al. 1994,^278^ followup of skeletal development in 11 MPS I pts up to 13 yrs post-HSCT

g Weisstein et al. 2004,^279^ musculoskeletal followup on 7 MPS I up to 7.6 yrs pts post-HSCT

h Souillet et al. 2003,^280^ report on 27 MPS I pts following HSCT

i Braunlin et al. 2003,^281^ report on cardiac ultrasound findings in 10 MPS I pts following HSCT

j Peters et al. 1998,^282^ 46 MPS I pts undergoing HSCT: 28 HLA-genotypically identical sibling donors, 26 HLA-haploidentical related donors

k Harmatz et al. 2006,^283^ Phase III trial of 39 MPS VI pts, 19 ERT and 20 placebo, treated for 48 wks

l Scarpa et al. 2009,^284^ followup from 6 months to 4.5 yrs of 9 MPS VI pts receiving ERT

m Harmatz et al. 2008,^272^ followup report of 56 MPS VI pts receiving ERT, from 3 clinical studies

n Krivit et al. 1984,^285^ case report, MPS VI following HSCT

o Herskhovitz et al. 1999,^286^ 1-9 yr followup of MPS VI pts after HSCT

p Yamada et al. 1998,^287^ case report MPS VII pt after HSCT

q Vellodi et al. 1997,^288^ 38 MPS I pts undergoing HSCT

r Giugliani et al. 2007,^289^ ERT guidelines for MPS VI

#### Hurler Syndrome (MPS I)

##### Background

Hurler Syndrome is caused by a deficiency of the lysosomal enzyme α-L-iduronidase, which is needed to break down heparan sulfate and dermatan sulfate. The disease is panethnic and has an estimated incidence of 1 per 100,000 live births. The disease is categorized into three types. The most severe form is Hurler (MPS IH), with two attenuated forms, Hurler-Scheie (MPS IH/S) and Scheie (MPS IS). Approximately 50-80 percent of cases are the severe form. In MPS IH, developmental delays are evident by 12 months of age.

Symptoms include respiratory insufficiency, hearing loss, joint movement restriction, distinct facial features such as a flat face and bulging forehead, and enlargement of the heart, spleen, and liver. Life expectancy is less than 10 years, with cause of death most commonly due to obstructive airway disease, upper respiratory infections, or cardiac complications. In MPS IH/S, symptoms begin between the ages of 3 and 8, and include moderate mental retardation, growth deficiencies, deafness, coarse facial features, clouded corneas, umbilical hernia, and heart disease. Life expectancy is the late teen years to early twenties. Children with MPS IS, the mildest form, have normal intelligence or mild learning disabilities and psychiatric problems. Other symptoms include nerve compression, aortic valve disease, sleep apnea, and impaired vision due to glaucoma, retinal degeneration, or clouded corneas. Affected individuals can live into adulthood, although with significant morbidity.263, 264

Clinical management requires coordination of a multidisciplinary team, to assess neurologic, ophthalmologic, auditory, cardiac, respiratory, gastrointestinal, and musculoskeletal symptoms at baseline prior to treatment designation, and subsequently at specified intervals following treatment.270, 290 Severity of neurologic symptoms and age at diagnosis are key elements in determining the treatment course for MPS I. Enzyme replacement therapy is available for MPS I, but the manufactured enzyme cannot cross the blood-brain barrier, so it cannot improve cognitive function or central nervous system function.

##### Evidence Base

The evidence compiled for this review includes seven literature reviews.265-271 Two clinical practice guidelines290, 291 but no health technology assessments for the treatment of MPS I with HSCT were identified in the literature search.

Treatment with enzyme replacement has been shown to be effective in increasing the enzyme activity level, reducing hepatosplenomegaly, and improving joint mobility and respiratory symptoms.273-275 Increased energy and endurance and improvement in the ability to perform normal activities of daily living have been reported following enzyme replacement.275 Because enzyme therapy does not cross the blood-brain barrier, neurologic symptoms persist.275 Like enzyme replacement, HSCT has also been shown to increase enzyme activity, reduce hepatosplenomegaly, improve joint mobility and improve respiratory symptoms.279, 280 The most beneficial outcome of HSCT is the potential to preserve intellectual development. Normal or near normal intellectual development has been reported if HSCT is performed prior to the onset of neurological symptoms.282 Disease management for MPS I also consists of a combination of palliative and symptom-specific treatments. Adaptive or supportive devices, physical and occupational therapy, symptom-based medications, and surgery may be necessary.

##### Guidelines

Guidelines for the treatment of MPS I with HSCT were published by The National Marrow Donor Program, International Bone Marrow Transplant Registry, and the Working Party on Inborn Errors of the European Bone Marrow Transplant Group in a collaborative 2003 publication of practice guidelines regarding HSCT for inherited metabolic diseases.291 A set of guidelines specific to MPS I was published in 2009 by a 12-member International Consensus Panel on the Management and Treatment of Mucopolysaccharidosis I.290

Enzyme-replacement therapy is recommended for all MPS I attenuated cases as first-line therapy. Enzyme replacement is also recommended for severe MPS I cases if the diagnosis was made at 2 years of age or younger and the developmental quotient (DQ) is less than 70.

HSCT is recommended for severe cases with stable cardiopulmonary function, if the disease is diagnosed at 2 years of age or younger and the DQ is 70 or greater. HSCT can also be considered in rare attenuated cases in which the diagnosis is made at older than 2 years of age and the DQ is 70 or greater.290

##### Summary

Overall there appears to be a favorable risk-benefit profile for the treatment of MPS I with HSCT for severe cases with stable cardiopulmonary function, if the disease is diagnosed at 2 years of age or younger and the DQ is 70 or greater. It is also recommended that overall there appears to be a favorable risk-benefit profile for the treatment of MPS I with HSCT for rare attenuated cases in which the diagnosis is made at older than 2 years of age and the DQ is 70 or greater.290

#### Maroteaux-Lamy Syndrome (MPS VI)

##### Background

There are three types of Maroteaux-Lamy Syndrome: severe, intermediate, and mild. A deficiency in the arylsufatase B enzyme results in the accumulation of dermatan sulfate. The clinical characteristics are similar to MPS I, except with a later onset and a slower progression of symptoms. Symptoms such as an enlarged head and deformed chest may be present at birth. Growth and development can be normal the first few years of life, but seem to decline around age 6. Other symptoms include coarseness of facial features, bone abnormalities in the hands and spine, corneal clouding, hepatomegaly, umbilical or inguinal hernias, pain from compressed nerves, and thickening and stenosis of the aortic and mitral valves. Mental development is usually normal, but psychomotor skills are affected by the physical and visual impairments of the disease. Life expectancy is less than 20 years.263, 264

Clinical management typically comprises a coordinated effort to address the diverse spectrum of respiratory, cardiac, skeletal, ophthalmologic, and central and peripheral nervous system symptoms.

##### Evidence Base

The evidence compiled for this review includes two literature reviews265, 270 and a Phase III clinical trial.272 Two clinical practice guidelines289, 291 but no health technology assessments were identified in the search.

Enzyme replacement therapy has proven to be a successful treatment for MPS VI, increasing enzyme activity level and improving joint mobility. A Phase III enzyme replacement trial showed sustained significant improvements in physical endurance tests such as stair climbing and walking.283 Because mental development in MPS VI patients is usually normal, there is no need for the manufactured enzyme to cross the blood-brain barrier. HSCT has been shown to increase enzyme activity levels, decrease hepatosplenomegaly, and improve visual acuity, and joint mobility.270

##### Guidelines

Guidelines for the treatment of MPS VI with HSCT were published by The National Marrow Donor Program, International Bone Marrow Transplant Registry, and the Working Party on Inborn Errors of the European Bone Marrow Transplant Group in a collaborative 2003 publication of practice guidelines regarding HSCT for inherited metabolic diseases.291 Guidelines specific to MPS VI were developed in 2004 at the International MPS Symposium and approved by an international consensus panel of specialists in medicine, genetics, and biochemistry.289

Enzyme-replacement therapy is recommended as first-line therapy for all cases of MPS VI. If enzyme replacement fails, then HSCT is recommended.

##### Summary

Overall there appears to be a favorable risk-benefit profile for the treatment of MPS VI with HSCT when enzyme replacement is not available or after failure of enzyme replacement. Supplemental treatment may include physical therapy, occupational therapy, and treatment-related surgery and medications.289

#### Sly Syndrome (MPS VII)

##### Background

Sly syndrome is a rare disease caused by a deficiency in the enzyme ß-glucuronidase. There have been fewer than 100 cases reported world-wide. As in the other mucopolysaccharidoses, a wide range in severity of symptoms exists. In most severe cases, neonatal jaundice and hydrops fetalis are present at birth, and survival is a few months. In less severe cases, growth retardation is evident in the first two years of life. Symptoms include coarse facial features, macrocephaly, hepatosplenomegaly, nerve entrapment, short stature, joint stiffness, inguinal and umbilical hernias, and corneal opacities. Respiratory insufficiency and frequent upper respiratory infections may occur. Mental retardation is moderate and nonprogressive. Life expectancy for the milder form is late teenage years through adulthood.263, 264

Clinical management for Sly syndrome is symptom specific. Surgery can relieve some of the respiratory problems and chronic ear infections and physical therapy can improve joint flexibility and range of motion.

##### Evidence Base

The evidence compiled for this review includes one literature review270 and one case report.287 One clinical practice guideline,291 but no health technology assessments were identified in the search.

HSCT has been performed in two patients with Sly syndrome. Enzyme activity levels have increased, upper respiratory infections have decreased, and motor function has improved.287

##### Guidelines

Guidelines for the treatment of MPS VII with HSCT were published by The National Marrow Donor Program, International Bone Marrow Transplant Registry, and the Working Party on Inborn Errors of the European Bone Marrow Transplant Group in a collaborative 2003 publication of practice guidelines regarding HSCT for inherited metabolic diseases.291

##### Summary

Overall there appears to be a favorable risk-benefit profile for the treatment of MPS VII with HSCT only in cases with severe physical disabilities, if the neuro-psychological and clinical status of the patient is good.291

### Inherited Metabolic Diseases: Sphingolipidoses

Sphingolipidoses are a group of autosomal recessive diseases characterized by a deficiency in one of several enzymes needed to metabolize lipids. The accumulation of lipids primarily affects the development and functioning of the central nervous system.292 The evidence base for these disorders is in Table 28 and the review of benefits and harms is in Table 29.

Table 28 Evidence base for HSCT in sphingolipidoses

Disease | Year of First HSCT | No. Transplants to Date | Type of Research Available | Registries
Gaucher Disease Type I | 1982 | unclear | Case reports, case series | Est. 1991: Genzyme Corporation sponsors the International Collaborative Gaucher Group (ICGG) to create an observational longitudinal database of clinical outcomes. Over 3,000 patients in registry.
Niemann-Pick Disease Type B | 1987 | 3 | Case reports | None
Globoid Cell Leukodys-trophy (Krabbe Disease) | 1998 | >34 | Case reports, case series | None
Meta-chromatic Leuko-dystrophy | 1982 | <100 | Case reports, case series | None

Table 29 Treatment benefits and harms for Gaucher Type I, Niemann-Pick Type B, Krabbe disease, and metachromatic leukodystrophy

Disease | Treatment | Source, Evidence Type | Indications | Clinical Benefits | Clinical Harms
Gaucher Disease Type I | ERT | Jmoudiak and Futerman 2005,^296^ literature review | - all cases, as first line therapy | - rapid and sustained improvements in anemia for about 90% of pts over 2 year period^a^ - among pts with bone pain, 52% pain free and 94% report no additional crises after 2 years^a^ - hepatomegaly decreased by 30-40% and splenectomy decreased by 50-60%, but liver and spleen remain larger than normal size^a^ | - intravenous catheterization in children can be difficult, causing pain and apprehension in pts^b^ - infusion-related adverse events can be expected, including nausea, headache, rash, malaise, chest pain, vomiting; most can be managed through slower infusion rates or pretreatment with antihistamines^c^
Gaucher Disease Type I | Allogeneic HSCT | Peters 2004,^270^ literature review | - recommended for more severe cases | - increase in enzyme activity level, though still below normal^d,e^ - decrease in liver size, though liver still enlarged, 3-6 months post HSCT^d,e,f,g^ - growth pattern returned to normal by 3 years post HSCT^e,f,g^ - psychological development normal^f^ | - 1 treatment-related mortality due to aspergillosis reported, out of 6 in case series^g^ - 5 of 6 had mild acute GVHD^g^ (- 2 of 2 had grade I acute GVHD^f^ - 1 of 2 developed septicemia^f^
Niemann-Pick Disease Type B | Allogeneic HSCT | Peters 2004,^270^ literature review | - recommended for pts with early severe liver disease or pulmonary symptoms; - considered experimental therapy for pts with neurological symptoms | - reduction in liver size, though liver still enlarged^h,i,j^ - enzyme level increased^i,j^ - interstitial lung disease resolved, though mild restrictive lung disease persists^i,j^ - 5.5 years post transplant, either stable or improved in cognitive function, verbal skills, performance skills, receptive vocabulary, and expressive vocabulary^i^ - 10 yrs post transplant, pt can perform majority of activities of daily living without assistance, though mild gross motor delay persists^j^ | - acute and chronic GVHD^h,I,j^ - septicemia and pneumonitis^h^ - veno-occlusive disease^i^ - mild to moderate respiratory distress^i^; - deficits in memory, but not known if underlying disease or transplant are responsible^i,j^ - engraftment decreasing with time, so disease progression continued several yrs post transplant; pt now severely mentally and physically disabled^k^
Niemann-Pick Disease Type B | Allogeneic HSCT | Schuchman 2007,^306^ literature review | - recommended for pts with early severe liver disease or pulmonary symptoms; - considered experimental therapy for pts with neurological symptoms
Globoid Cell Leukodyst rophy (Krabbe Disease) | Allogeneic HSCT | Peters 2004,^270^ literature review | - recommended for severe early onset form if disease is diagnosed antenatally, so that HSCT can be performed during neonatal period, prior to onset of symptoms; - recommended for late onset form of disease if symptoms are not severe | - enzyme activity levels in pts reached donor levels after 1 year post-transplant^l^ - 2 pts with late onset form and neurologic disability: tremors and ataxia resolved by 6 months, motor incoordination resolved by 1 year, and gait dysfunction resolved slowly over 7 years post-transplant^l^ - 3 late onset pts developed normally in: cognition, language, and memory^l^ - asymptomatic newborns survival better compared to untreated controls (p=0.001) and better than treated symptomatic patients (p=0.01)^m^ - early onset pts with no symptoms prior to transplantation maintained normal vision, hearing, and cognitive development; variable motor function was maintained^m^ - central nervous system deterioration reversed in 4 out of 4 pts^n^ | - 3 of 5 pts had graft-vs.-host disease, grade I-II^l^; - complications among 25 transplant pts: 17 graft-vs.-host disease grades I-IV, 3 brief episodes of autoimmune hemolytic anemia, 1 catheter-related silent brain infarct, 2 asymptomatic hypertrophic cardiomyopathies, 1 symptomatic hypertrophic cardiomyopathy^m^ - treatment-related mortality among 25 transplant pts: 1 GVHD, 1 aspiration pneumonia, 1 adenoviral infection, 1 complication from liver biopsy for GVHD^m^
Globoid Cell Leukodyst rophy (Krabbe Disease) | Allogeneic HSCT | Pastores 2009,^307^ literature review
Metachromatic Leukodystrophy | Allogeneic HSCT | Peters 2004^270^, literature review | - not recommended if neuro-psychologic and/or neurologic symptoms are advanced; - recommended in pre-symptomatic pts (usually diagnosed early post-natally or prenatally) or pts with good neuropsychologic function | - enzyme activity reaches donor levels^o,p^; - no further deterioration of white matter in the brain following transplant^o^ - some mental capabilities preserved (well-developed language, for example), but physical limitations persisted (difficulty with gross and fine motor skills)^o^; - nerve sensory velocities improved from abnormal to normal, 2 years post transplant^q^ - serial MR findings support neuropsychological and neurophysiological tests that show disease stabilization 2-6 years post-transplant^r^ - disease progression halted for over 11 years post-transplant, based on clinical, electrophysiological, and neuroradiological data: wheelchair bound, IQ stable at mild mental retardation, auditory evoked responses stable, nerve conduction velocities stable^s^ | - 3 of 4 pts experienced acute GVHD^p^; 1 of 2 pts experienced chronic GVHD^r^ - 4 pts with mild to moderate symptoms at time of transplant deteriorated mentally and physically post-HSCT^p^
Metachromatic Leukodystrophy | Allogeneic HSCT | Biffi et al. 2008,^308^ literature review | | | - 3 of 4 pts experienced acute GVHD^p^; 1 of 2 pts experienced chronic GVHD^r^ - 4 pts with mild to moderate symptoms at time of transplant deteriorated mentally and physically post-HSCT^p^

a Weinreb et al. 2002,^299^ 1028 Gaucher I pts, 2-5 yrs followup of ERT

b Charrow et al. 2003,^297^ ERT consensus recommendations for Gaucher type I

c Starzyk et al. 2007,^300^ review of adverse event reports from 1994-2004 for ERT

d Chan et al. 1994,^302^ Gaucher type I case report, 2.8 yrs post HSCT

e Yen et al. 1997,^304^ Gaucher I case report, 3 yrs post HSCT

f Ringden et al. 1995,^303^ case series of 2 Gaucher type I pts, 3-8 yrs post HSCT

g Hobbs et al. 1987,^305^ case series of 6 Gaucher type I pts, 1-3.3 yrs post HSCT

h Vellodi et al. 1987,^309^ Niemann-Pick Type B case report, 9 months post HSCT

i Shah et al. 2005,^310^ Niemann-Pick Type B case report, 5.5 yrs post HSCT

j Schneiderman et al. 2007,^311^ Niemann-Pick Type B case report, 10 yrs post HSCT

k Victor et al. 2003,^312^ Niemann-Pick Type B case report 16 yrs post HSCT

l Krivit et al. 1998,^313^ case series of 5 GLD pts, 1-9 yrs post HSCT

m Escolar et al. 2005,^314^ case series of 25 GLD pts, 11 asymptomatic and 14 symptomatic, 4 months - 6 yrs post HSCT

n Kurtzberg et al. 2002,^315^ case series of 5 GLD pts, 1-9 yrs post HSCT

o Krivit et al. 1990,^316^ MLD case report, 5 yrs post HSCT

p Malm et al. 1996,^317^ case series of 4 MLD pts, 2-3 yrs post HSCT

q Pierson et al. 2008,^318^ case series of 3 MLD siblings, 2 yrs post HSCT

r Stillman et al. 1994,^319^ case series of 2 MLD pts, 2-6 yrs post HSCT

s Gorg et al. 2007,^320^ case report of 1 MLD pt, 13-yrs post HSCT

#### Gaucher Disease Type I

##### Background

Gaucher disease, the most common lysosomal storage disorder, is caused by a deficiency in the enzyme ß-glucocerebrosidase, which leads to an accumulation of glucosylceramide in the spleen, liver, lungs, bone marrow, and sometimes the brain. There are three types of Gaucher disease, based on the absence or presence, and progression of neurologic involvement. Gaucher disease Type II and Type III, the neuronopathic forms, are discussed in the Systematic Review section. Type I is non-neuronopathic, and is the most common form of the disease (about 90 percent), with a prevalence of 1 in 100,000 in the general population.293 Those of Eastern and Central European (Ashkenazi) Jewish descent are at highest risk for this type (estimated at 1 in 450-1000).261, 293 Symptoms can develop from early childhood to late adulthood. Patients presenting in early childhood have a more severe course of the Type I disease; those presenting later in life are more likely of Jewish descent.261 Symptoms include anemia, hepatosplenomegaly, skeletal disorders, and lung and kidney impairment. The clinical course, disease progression, severity among the different organ systems, and life expectancy vary markedly among cases.294 There can be both central and peripheral nervous system involvement in this form of the disease, but the nervous system symptoms are distinct from Type II and Type III because there is no neuronal loss in Type I.295 Some developmental delays may occur as a consequence of the persistent clinical symptoms.261

##### Evidence Base

The evidence compiled for this review includes two literature reviews.270, 296 Three clinical practice guidelines,291, 297, 298 but no health technology assessments were identified in the literature search.

Enzyme-replacement therapy has been shown to be effective in increasing ß-glucocerebrosidase enzyme activity levels, resulting in improvements in visceral symptoms.296 Evidence from a retrospective analysis of 1,028 patients in the International Collaborative Gaucher Group has shown that enzyme-replacement therapy can provide rapid and sustained improvements in anemia, decrease bone pain, and decrease organomegaly.299 Adverse effects from enzyme replacement are primarily infusion related.300 Treatment of Gaucher Type I is life-long, in which enzyme-replacement therapy dosages may need to be adjusted,301 and ERT may need to be supplemented with medications or surgery to address issues of pain, pre-existing irreversible skeletal complications, and hypertension.

HSCT may be considered for Gaucher Type I if there is a persistence or progression of severe bone pain or if access to ERT is limited.270 HSCT is effective in alleviating most symptoms of Gaucher Type I, in particular, the skeletal symptoms in the early onset severe form of Type I. Cure of Gaucher Type I can be achieved with HSCT if engraftment is successful and complications from the procedure are minimal.302-304 Complications range in severity, including graft-versus-host disease and treatment-related mortality.303, 305

##### Guidelines

Guidelines for the treatment of Gaucher Type I with HSCT have been made by the National Marrow Donor Program, International Bone Marrow Transplant Registry, and the Working Party on Inborn Errors of the European Bone Marrow Transplant Group in a 2003 publication of practice guidelines regarding HSCT for inherited metabolic diseases,291 the Global Experts Meeting on Therapeutic Goals for the Treatment of Gaucher Disease,298 and the U.S. regional coordinators of the International Collaborative Gaucher Group (ICGG) Registry.298

Following a multisystem evaluation to assess the severity of symptoms, HSCT is recommended for Gaucher Type I patients if there is a persistence or progression of severe bone pain that is not resolved by enzyme-replacement therapy or if enzyme replacement is unavailable.

##### Summary

Overall there appears to be a favorable risk-benefit profile for the treatment of Gaucher Type I with HSCT if there is a persistence or progression of severe bone pain or if ERT is unavailable,270, HSCT is effective in alleviating most symptoms of Gaucher Type I, in particular, the skeletal symptoms in the early onset severe form of Type I.291

#### Niemann-Pick Disease Type B

##### Background

Niemann-Pick disease is characterized by a deficiency in acid sphingomyelinase activity, resulting in the accumulation of lipids in the spleen, liver, lungs, bone marrow, and the brain, causing lack of muscle coordination, brain degeneration, feeding and swallowing difficulties, and hepatosplenomegaly. There are three types of this disease, Type A, B, and C. Type B is discussed in this section and Types A and C are discussed in more detail in the Systematic Review. Type B is panethnic and is the least severe form of the disease. It is usually diagnosed during childhood or preteen years, because of the development of hepatosplenomegaly.261 Severity of symptoms varies in Type B, and as the disease progresses, the pulmonary system becomes compromised, and bronchopneumonias may occur. Liver complications develop in more severe cases, leading to cirrhosis or portal hypertension.261, 321 This form usually does not involve neurological symptoms, and cases can survive into adulthood.

##### Evidence Base

The evidence compiled for this review includes two literature reviews.270, 306 One clinical practice guideline,291 but no health technology assessments were identified in the literature search.

Three transplantations for Niemann-Pick Type B have been reported in the literature. Two have reported successful outcomes,310, 311 and one showed initial improvements followed by neurological and physical deterioration after several years post-transplant.312 HSCT can be expected to increase enzyme activity level, reduce liver size, stabilize or improve cognitive function, and improve lung function, resulting in the ability to perform activities of daily living without assistance. Adverse events reported from the three transplantations include acute and chronic graft versus host disease, veno-occlusive disease, and infections.

Enzyme-replacement therapy is currently not available for pediatric cases. A Phase I trial in adults is complete, and enrollment in a Phase II trial was begun in 2010.

##### Guidelines

Recommendations for HSCT for Niemann-Pick Type B can be found in a publication of practice guidelines regarding HSCT for inherited metabolic diseases by the National Marrow Donor Program, International Bone Marrow Transplant Registry, and the Working Party on Inborn Errors of the European Bone Marrow Transplant Group.291

HSCT is recommended for Niemann-Pick Type B patients with early severe liver disease or pulmonary symptoms. HSCT is considered experimental therapy for patients with neurologic symptoms.

##### Summary

Overall there appears to be a favorable risk-benefit profile for the treatment of patients with HSCT who have severe symptoms from Niemann-Pick Type B particularly those with severe liver disease or pulmonary disease. The procedure will ideally be performed as early in the disease process as possible for maximum benefit.291, 306

#### Globoid Cell Leukosystrophy (Krabbe Disease)

##### Background

Globoid cell leukodystrophy, is a disease caused by a deficiency of the enzyme galactocerebrosidase, resulting in progressive destruction of central and peripheral myelin. The estimated incidence is 1 to 2 per 100,000 live births. Symptoms in the most common and more severe form of the disease (90 percent), sometimes called Krabbe disease, begin early in life, between 2 and 10 months of age. In the initial stages of the disease, there is irritability, feeding problems, and a general failure to thrive. Subsequent symptoms include stiffness, seizures, and slow development. Progression of the disease is quick, leading to a chronic vegetative state and death usually by 2 years of age.261 In the late-onset form of this disease, the juvenile or adult form, symptoms may begin later in childhood or adulthood, beginning with optic atrophy and cortical blindness. Gait disturbances, such as spasticity and ataxia, develop and progress slowly for about a decade, prior to death.322

##### Evidence Base

The evidence compiled for this review includes two literature reviews.270, 306 One clinical practice guideline,291 but no health technology assessments were identified in the literature search.

Transplantation in the early onset form of the disease has only been successful if performed during the neonatal period, prior to the development of any symptoms. These cases have been diagnosed antenatally, screened for the disease because an older sibling had died from the disease.314

Patients with the late form of the disease have had more success with stem-cell transplantation because the symptoms are less severe and the disease progression is slower. Both improvements in neuromuscular symptoms and continued neurocognitive development have been reported among late-onset patients undergoing transplantation.313-315 Adverse events reported include acute and chronic graft-versus-host disease, hemolytic anemia, asymptomatic and symptomatic cardiomyopathies, and transplant-related mortality.313, 314

##### Guidelines

Guidelines for the treatment of globoid cell leukodystrophy with HSCT can be found in a publication of practice guidelines regarding HSCT for inherited metabolic diseases by the National Marrow Donor Program, International Bone Marrow Transplant Registry, and the Working Party on Inborn Errors of the European Bone Marrow Transplant Group.291

HSCT is recommended for the severe early onset form of the disease if the disease is diagnosed antenatally, so that HSCT can be performed during the neonatal period, prior to the onset of symptoms. Screening for the disease is recommended in particular for families who have had a child previously diagnosed with the disease, allowing for an antenatal diagnosis and an early transplantation.291

HSCT is recommended for patients with the late onset form of disease if symptoms have not become severe.291

##### Summary

Overall there appears to be a favorable risk-benefit profile for the treatment of severe early onset globoid cell leukodystrophy with HSCT, when the disease has been diagnosed antenatally, and the transplant is performed in the neonatal period prior to the development of symptoms. It is also recommended that there appears to be a favorable risk-benefit profile for the treatment of the late form of globoid cell leukodystrophy with HSCT.

#### Metachromatic Leukodystrophy

##### Background

Metachromatic leukodystrophy (MLD) is an autosomal recessive disease caused by either a deficiency in the enzyme arylsulfatase A or a deficiency in a sphingolipid activator protein needed to form the substrate-enzyme complex. Absence of either substance leads to a buildup of cerebroside sulfate in the central nervous system and in peripheral nerves, causing demyelination and a neurodegenerative course.261 The incidence is approximately 1 in 40,000 births. There are three forms of the disease: late infantile, juvenile, and adult. The late infantile form is the most common, with the following symptoms occurring in the second year of life: muscle weakness and wasting, muscle rigidity, developmental delays, convulsions, loss of vision, and paralysis. Life expectancy is 5 to 6 years, with death usually due to aspiration or bronchopneumonia.292 The juvenile form presents between the ages of 3 and 12 years, beginning with mental deterioration, dementia, and urinary incontinence, followed by the same symptoms as the late infantile form, but progressing at a slower pace. Life expectancy is through mid-adolescence.261 Dementia and behavioral disturbances are the most notable symptoms in the adult form, which may begin in the mid-teenage years through adulthood. Neurological symptoms progress slowly, leading to a bedridden state. Life expectancy can extend beyond a decade following the onset of symptoms.261

##### Evidence Base

The evidence compiled for this review includes two literature reviews.270, 308 In addition, one clinical practice guideline,291 but no health technology assessments were identified in the literature search.

A wide range of effectiveness of HSCT in the treatment of MLD has been reported. Severity of the disease, in particular, the extent of neurological symptoms at the time of transplant, may determine whether there is a stabilization of symptoms or continued degeneration.308 The most beneficial results occur when HSCT is performed prior to the onset of clinical symptoms and if the donor has homozygous normal arylsulfatase A enzyme activity.270 The benefits of HSCT are primarily to the central nervous system, so symptoms related to the peripheral nervous system remain unresolved.270

##### Guidelines

Guidelines for the treatment of metachromatic leukodystrophy with HSCT can be found in a publication of practice guidelines regarding HSCT for inherited metabolic diseases by the National Marrow Donor Program, International Bone Marrow Transplant Registry, and the Working Party on Inborn Errors of the European Bone Marrow Transplant Group.291

HSCT is recommended for early onset severe patients if they are presymptomatic, usually diagnosed in an early postnatal or prenatal screening, because of an older affected sibling.

HSCT is not recommended for patients with the early onset severe form of the disease if neurophysiologic and neurologic symptoms have already occurred, since stabilization of symptoms is expected to take 6 to 12 months following transplant.

For patients with the juvenile or adult onset form of the disease, HSCT is recommended if comprehensive neurologic, neuropsychologic, neuroradiologic, and neurophysiologic assessments demonstrate the existence of functional abilities.291

##### Summary

Overall there appears to be a favorable risk-benefit profile for the treatment of the late infantile form of MLD, HSCT is recommended for presymptomatic patients only, usually those diagnosed early in the postnatal or prenatal stages, because of an older affected sibling. It is also recommended that overall there appears to be a favorable risk-benefit profile for the treatment of the juvenile and adult forms of MLD with HSCT if comprehensive neurologic, neuropsychologic, neuroradiologic, and neurophysiologic assessments demonstrate the existence of functional abilities.

### Inherited Metabolic Diseases: Glycoproteinoses

Glycoproteinoses are a group of lysosomal storage diseases characterized by a deficiency in enzymes needed to break down glycoproteins (Table 30). The accumulation of glycoproteins in the organs and central nervous system causes progressive damage and a neurodegenerative course.261

Table 30 Evidence base for HSCT in glycoproteinoses

Disease | Year of First Treatment | No. Transplants to Date | Existing Clinical Evidence | Registries
Fucosidosis | 1995 | 3 | Case reports | None
α-Mannosidosis | 1987 | <20 | Case series | None

#### Fucosidosis

##### Background

Fucosidosis is a rare autosomal recessive disorder caused by a deficiency in the enzyme α-fucosidase, resulting in the accumulation of glycolipids and glycoproteins in the liver, spleen, skin, heart, pancreas, kidneys, and brain.323 While cases have been reported throughout the world, most cases have come from Italy, Cuba, and the southwestern portion of the U.S. There are no estimates of incidence of the disease, with less than 100 cases having been reported in the literature. The signs and symptoms of the disease range in severity, presenting in a wide continuous clinical spectrum.324 The most severe form of the disease presents in the first year of life, beginning with developmental delays and coarse facial features. Growth retardation and mental retardation occur in over 90 percent of cases.324 Other symptoms include hepatosplenomegaly, seizures, optical abnormalities, frequent upper respiratory infections, angiokeratomas, and visceromegaly. Both physical and mental deterioration progresses with age. In the most severe form, life expectancy is late childhood. The milder form becomes evident at 1 to 2 years of age and life expectancy extends to mid-adulthood.261 There is no cure for fucosidosis.

##### Evidence Base

The evidence compiled for this review (Table 31) includes two literature reviews,270, 325 which describe three patients with fucosidosis undergoing HSCT, two reports in the literature and one conference abstract.326, 327 No health technology assessments or clinical practice guidelines for the treatment of fucosidosis with HSCT were identified in the literature search.

Table 31 Treatment benefits and harms for fucosidosis and α-mannosidosis

Disease | Treatment | Source, Evidence Type | Indications | Clinical Benefits | Clinical Harms
Fucosidosis | Allogeneic HSCT | Peters 2004,^270^ literature review | - recommended only for pre-symptomatic pts with an early diagnosis, before central nervous system starts to deteriorate | - enzyme activity detected in cerebrospinal fluid 1 yr post HSCT, indicating enzyme has reached central nervous system^a^; - myelination proceeding, though delayed compared to expected for age of pt^a^; - able to function in slightly low average range, sociable, happy, engaged at 1 yr post^a^; - progressive rise in enzyme levels, peaking at 30 months post HSCT^b^; - slight improvement in white matter myelination at 13 months post, more evident improvement by 24 months post, good myelination by 32 months post, near normal by 38-46 months post^b^ | - complications: graft vs. host disease, transient episode of idiopathic thrombocytopenic purpura, and repeated sepsis from central venous catheter^b^; - moderately severe graft vs. host disease^b^
Fucosidosis | Allogeneic HSCT | Heese 2008,^325^ literature review | - recommended only for pre-symptomatic pts with an early diagnosis, before central nervous system starts to deteriorate | | - complications: graft vs. host disease, transient episode of idiopathic thrombocytopenic purpura, and repeated sepsis from central venous catheter^b^; - moderately severe graft vs. host disease^b^
α-Mannosidosis | Allogeneic HSCT | Peters 2004,^270^ literature review | - recommended for all pts with severe Type I form prior to onset of significant symptoms; - recommended for Type II pts if early neurocognitive deficits present | - hepatosplenomegaly resolved within 1 mo post^c,d^; - bony abnormalities improved significantly in skull, thoracolumbar spine, and hands^c^; - trabeculation of long and short bones normalized^c^; - 2 of 3 pts with hearing deficits improved to near normal frequency range, except high frequency difficulties persisted, by 2 yrs post^d^; - neuropsychologic testing shows stabilization^c^ or improvement^d^ of neuropsychologic symptoms; - improvement in expressive speech at 3 yrs post in symptomatic pt^e^; - overall normal development at 6 yrs post in asymptomatic pt; attends mainstream school^e^ | - acute GVHD^c,d^; - graft vs. host disease led to obliterative bronchiolitis^e^
α-Mannosidosis | Allogeneic HSCT | Heese 2008,^325^ literature review | - recommended for all pts with severe Type I form prior to onset of significant symptoms; - recommended for Type II pts if early neurocognitive deficits present | | - acute GVHD^c,d^; - graft vs. host disease led to obliterative bronchiolitis^e^

a Vellodi et al. 1995,^327^ case report, fucosidosis pt, 1 yr post HSCT

b Miano et al. 2001,^326^ case report, fucosidosis pt, 4 yrs post HSCT

c Wall et al. 1998,^328^ case report, α-mannosidosis pt, 15 months post HSCT

d Grewal et al. 2004^329^, case series, 3 pediatric 1 adult α-mannosidosis pts, 1-6 yrs post HSCT

e Broomfield et al. 2010,^330^ comparison of 2 α-mannosidosis siblings, 1 late transplant to relieve symptoms, 1 presymptomatic transplant, 3-6 yrs post HSC

Both cases reported in the literature were diagnosed early because of disease in an older sibling. Transplantations were performed prior to the onset of symptoms, and the success of the transplants is attributed to the timing of the procedures. Leukocyte enzyme levels rose quickly following engraftment, and remained in the normal range 1 to 3 years post-procedure. Most promising is the detection of enzyme activity in cerebrospinal fluid, indicating that the enzyme had reached the central nervous system.327 MRIs from 1 to 3 years post-procedure showed a consistent progression of myelination following the transplants. Both cases reported in the literature showed better mental and physical development and improved quality of life compared to their affected siblings. Complications included GVHD and infections.326, 327

##### Guidelines

No guidelines for the treatment of fucosidosis with HSCT were identified in the search.

##### Conclusions

Overall there appears to be a favorable risk-benefit profile for the treatment of fucosidosis with HSCT when performed on presymptomatic patients who have had an early diagnosis. HSCT is only recommended for patients who have not shown any signs of central nervous system deterioration.270, 325

#### α-Mannosidosis

##### Background

Alpha-mannosidosis is an autosomal recessive disease caused by a deficiency in the enzyme α-mannosidase, resulting in the accumulation of oligosaccharides in the liver, bone marrow, and central nervous system. The estimated incidence of the disease is 1 in 500,000 world-wide. This disease exhibits a wide spectrum of clinical symptoms. Symptoms include mental retardation, impaired hearing, degeneration of previously acquired developmental skills, coarse features, hepatosplenomegaly, immunodeficiency, ataxia, and metabolic myopathy. There is a severe infantile form (Type I), with an onset of symptoms occurring before 12 months of age. Progressive deterioration in this type leads to death between 3 to 12 years of age. Type II is the less severe form, with symptoms beginning in late childhood to adulthood. The symptoms are milder and progress more slowly in this form. Life expectancy can extend through the fifth decade of life.331

##### Evidence Summary

The evidence compiled for this review includes two literature reviews (Table 31).270, 325 One clinical practice guideline291 but no health technology assessments for the treatment of α-mannosidosis with HSCT were identified in the literature search. Included literature reviews contain all identified reports of HSCT for α-mannosidosis.

Results have shown favorable outcomes, with resolutions in organomegaly, bony disease, and either stabilization or improvement of neuropsychologic symptoms.328, 329 A comparison of two α-mannosidosis siblings, one undergoing a late transplant to relieve symptoms, and one receiving a presymptomatic transplant, shows clearly that transplants earlier in the course of the disease are more beneficial.330 For untreated patients with the severe form of the disease, there is rapid physical and mental degeneration and life expectancy is 3 to 12 years; following HSCT, patients have survived beyond the expected lifespan and several attend mainstream school and participate in sports.329, 330

##### Guidelines

Guidelines for HSCT in α-mannosidosis can be found in a publication of practice guidelines regarding HSCT for inherited metabolic diseases by the National Marrow Donor Program, International Bone Marrow Transplant Registry, and the Working Party on Inborn Errors of the European Bone Marrow Transplant Group.291

HSCT is recommended for all patients with severe Type I form prior to the onset of significant symptoms, and recommended for Type II patients if early neurocognitive deficits are present.

##### Conclusions

Overall there appears to be a favorable risk-benefit profile for the treatment of severe Type I α-mannosidosis with HSCT, if performed prior to the onset of significant symptoms. It is also recommended that overall there appears to be a favorable risk-benefit profile for the treatment of Type II α-mannosidosis is early neurocognitive deficits are present.

### Inherited Metabolic Diseases: Peroxisomal Storage Disorders

Peroxisomal storage disorders are a heterogeneous group of congenital diseases in which there is either a dysfunction of the peroxisomes or a deficiency in the enzymes which are necessary for the metabolism of very-long-chain-fatty-acids (VLCFA). The accumulation of VLCFA in the central nervous system leads to demyelination of the nerve fibers in the brain and nerves, resulting in slower conduction of nerve impulses. Developmental delays and mental retardation are common in all peroxisomal storage disorders.332 The combined incidence of peroxisomal disorders is estimated at over 1 in 20,000 in the U.S.

#### Adrenoleukodystrophy

##### Background

Adrenoleukodystrophy is a demyelinating disorder of the central nervous system caused by the accumulation of very long chain fatty acids in the brain and adrenal cortex, due to a deficiency in the enzyme that breaks down fatty acids. The estimated incidence is 1 in 100,000.^333^ Symptoms range in severity, from the X-linked form which is the most severe form, to the milder adult-onset form. Onset of symptoms in the severe form occurs between 4 to 8 years of age, and is characterized by adrenal insufficiency in 90 percent and neurological deterioration in 100 percent of the cases.334 Symptoms include behavioral changes such as withdrawal or aggression, poor memory, and learning disabilities. Physical manifestations of the disease progress quickly and include visual loss, seizures, difficulty swallowing, deafness, fatigue, an increase in skin pigmentation, weakness of the lower limbs, intermittent vomiting, and progressive dementia. This severe form is often referred to as “childhood onset of cerebral adrenoleukodystrophy” (COCALD). In the milder adult-onset form, symptoms begin between the ages of 21 to 35 and progress more slowly. Stiffness, limb weakness, and ataxia may occur, along with deterioration of brain function. Expected survival is 1 to 10 years following the onset of symptoms.335

The severity and extent of symptoms determines the course of treatment. Patients with adrenocortical insufficiency need steroid hormone replacement therapy. In patients without neurologic symptoms, dietary therapy consisting of fat restriction and an oral supplement called “Lorenzo's oil,” a mixture of oleic acid and erucic acid, is recommended. Dietary therapy alone is not effective once neurological symptoms have progressed because erucic acid cannot enter the CNS in significant amounts.336

The severity of symptoms in adrenoleukodystrophy varies widely from the early onset form through the milder adult onset form. The severity of symptoms determines which therapeutic options to consider. Studies have shown that an MRI severity score of 2-3 in boys younger than 10 years of age, will most likely develop progressive cerebral disease and are therefore candidates for HSCT.291

##### Evidence Base

The evidence compiled for this review (Table 32) includes two literature reviews.270, 337 One clinical practice guideline291 but no health technology assessments for the treatment of adrenoleukodystrophy with HSCT were identified in the literature search.

Table 32 Evidence base for HSCT in adrenoleukodystrophy

Disease | Year of First Treatment | No. Transplants to Date | Existing Clinical Evidence | Registries
Adrenoleukodystrophy | 1984 | >125 | Case series, case reports | None

Outcomes following HSCT have varied from complete resolution of symptoms to having no effect (Table 33). Disease status prior to the procedure is the best predictor of outcomes.338, 339 The most successful outcomes are when the HSCT has been performed prior to the onset of neurologic symptoms. In a report on 94 boys with X-linked adrenoleukodystrophy receiving HSCT, 5-year survival rates were 70 percent with no neurological deficits, 67 percent with one neurological deficit, and 35 percent with two or more neurological deficits. The 5-year survival rates of boys with X-linked adrenoleukodystrophy not receiving HSCT have been reported as less than 40 percent.339

Table 33 Treatment benefits and harms for adrenoleukodystrophy

Disease | Treatment | Source, Evidence Type | Indications | Benefits | Harms
Adrenoleukodystrophy | Allogeneic HSCT | Peters 2004,^270^ literature review | - recommended as soon as diagnosis for child onset of cerebral adrenoleukodystrophy is confirmed | - 18 months post HSCT, behavioral and cognitive functions improved^a^; - MRI showed complete disappearance of lesions in brain if demyelination moderate^a,b,c^; - MRI showed deterioration stabilized if demyelination more extensive^b,c^; - cognitive function stabilized or improved in 7 of 12 pts^b^; - 8 of 12 functioning normally in school with no additional support^b^; - 5 yr survival: 70% with 0 neurologic deficits, 67% with 1 neurological deficit, 35% with 2 or more neurological deficits^d^; - 31 of 58 had no further neurological progression of disease^d^ | - treatment-related mortality at 3 yrs: 10% with related donor, 18% with unrelated donor^d^; - severe acute GVHD: 17% with related donor, 8% with unrelated donor^d^
Adrenoleukodystrophy | Allogeneic HSCT | Krivit et al. 1999,^337^ literature review | - recommended as soon as diagnosis for child onset of cerebral adrenoleukodystrophy is confirmed | | - treatment-related mortality at 3 yrs: 10% with related donor, 18% with unrelated donor^d^; - severe acute GVHD: 17% with related donor, 8% with unrelated donor^d^

a Aubourg et al. 1990,^340^ case report, 18 months post HSCT

b Shapiro et al. 2000,^341^ case series of 12 pts, 5-10 yrs post HSCT

c Loes et al. 1994,^342^ case series of 7 pts, 1-2 yrs post HSCT

d Peters et al. 2004,^270^ case series of 94 pts, 0.4-11.2 yrs post HSCT

##### Guidelines

Guidelines for the treatment of adrenoleukodystrophy with HSCT can be found in a publication of practice guidelines regarding HSCT for inherited metabolic diseases by the National Marrow Donor Program, International Bone Marrow Transplant Registry, and the Working Party on Inborn Errors of the European Bone Marrow Transplant Group.291

HSCT is recommended only for the early onset severe form, once there is definitive evidence of cerebral disease, usually determined by MRI.291

##### Summary

Overall there appears to be a favorable risk-benefit profile for the treatment of severe adrenoleukodystrophy with HSCT. HSCT is indicated at the first signs of demyelination due to the rapid progression of mental deterioration once cerebral disease is detected.291

### Osteopetrosis

#### Background

Osteopetrosis is a group of rare inherited disorders of the skeleton characterized by a defect in the form or function of osteoclasts. Osteoclasts degrade bone in the bone remodeling process, so a decrease in osteoclast activity causes an increase in bone density, an impairment of longitudinal growth of the bone, and bone marrow failure.343 There is a wide spectrum of presentation and severity of symptoms, which have been classified into three primary clinical types: autosomal recessive infantile (“malignant”) osteopetrosis, autosomal recessive “intermediate” osteopetrosis, and autosomal dominant osteopetrosis. The estimated incidence of the autosomal recessive type is 1 in 250,000–300,000 births, though in Costa Rica the incidence is three times as high, and for the autosomal dominant type, the estimated incidence is 1 in 20,000 births.344 The autosomal recessive infantile form is the most severe and is characterized by hepatosplenomegaly, cranial-nerve dysfunction, hearing loss in about one-third of cases, and visual deficits in a majority of the cases, all of which are detected within the first several months of life.

Because of neutrophil defects, anemia, and complications of the ear, nose, and throat, patients with osteopetrosis are susceptible to frequent infections, usually affecting the respiratory tract.345 Life expectancy is less than 10 years, with cause of death most commonly thrombocytopenia, anemia, or infectious complications.343 There are rare variants of the autosomal recessive type, a neuronopathic form characterized by seizures and a milder form exhibiting renal tubular acidosis are two examples. There is also a rare X-linked form characterized by severe immunodeficiency. Symptoms of the more common, but less severe autosomal dominant form are primarily skeletal, such as fractures, scoliosis, and osteomyelitis, with onset in late childhood or adolescence and a normal life expectancy.344

Clinical management of osteopetrosis is supportive, with fractures and arthritis treated by experienced orthopedic surgeons due to the brittleness of the bone, hypocalcemic seizures treated with calcium and vitamin D supplements, and bone marrow failure treated with red blood cell and platelet transfusions.345

#### Evidence Base

The evidence compiled for this review (Table 34) includes four literature reviews345-348 of osteopetrosis and HSCT (Table 35). In a retrospective study of over 100 osteopetrosis patients undergoing HSCT, 5-year disease free survival rates ranged from 24 percent with a mismatched unrelated donor to 73 percent with a matched sibling donor.349 Some patients experienced improvements in visual symptoms and either stable or improved growth.349 Risks related to HSCT include hypercalcemia, graft versus host disease, and infections.349, 350

Table 34 Evidence base for HSCT in osteopetrosis

Disease | Year of First Transplant | No. Transplants to Date | Existing Clinical Evidence | Registries
Osteopetrosis | 1977 | > 125 | Case reports, case series, retrospective analyses | None

Table 35 Treatment benefits and harms for osteopetrosis

Disease | Treatment | Source, Evidence Type | Indications | Clinical Benefits | Clinical Harms
Osteopetrosis | Allogeneic HSCT | Steward 2010,^348^ literature review | - recommended only for the severe form of autosomal recessive osteopetrosis | - 5-yr disease free survival rates: 73% with HLA identical genotype sibling donor, 43% with HLA identical phenotype or one mismatch related donor, 40% with HLA matched unrelated donor, 24% with HLA mismatch related donor^a^; - 56 of 122 have normal osteoclast function following HSCT and 6 of 122 survived with persistent osteopetrosis^a^; - in 42 evaluable pts, 29 had no further visual deterioration, 3 improved vision, 10 had further deterioration; better conservation of vision if HSCT performed before 3 months of age^a^; - in 18 evaluable pts: 11 had same or better percentile growth, 7 had lower percentile growth at last followup^a^; - following HSCT, most children can attend regular school, those with visual disability need special education^a^; - if engraftment successful, no clinical evidence of progressive disease^b^ | - 58 of 122 deaths related to HSCT or osteopetrosis, most common causes: 14 septicemia, 13 pneumonia, 8 veno-occlusive disease, 7 aplasia/hemorrhage^a^; - hypercalcemia in 8 of 50 evaluable pts; significantly higher risk if HSCT after 2 yrs of age^a^; - 4 of 10 pts had acute GVHD grades I-III^b^; - 5 of 10 pts died of transplant complications: 4 of interstitial pneumonitis, 1 of which had chronic GVHD involving respiratory and gastrointestinal tract, and 1 from Aspergillus infection^b^
Osteopetrosis | Allogeneic HSCT | Askmyr et al. 2008,^346^ literature review | - recommended only for the severe form of autosomal recessive osteopetrosis
Osteopetrosis | Allogeneic HSCT | Or et al. 2004,^347^ literature review | - recommended only for the severe form of autosomal recessive osteopetrosis
Osteopetrosis | Allogeneic HSCT | Wilson and Vellodi 2000,^345^ literature review | - recommended only for the severe form of autosomal recessive osteopetrosis

a Driessen et al. 2003 349, retrospective analysis of 122 pts, up to 10 yrs post-HSCT, extended followup on patients reported in Gerritsen et al. 1994^351^

b Eapen et al. 1998 350, case series of 10 pts, 2-18 yrs post-HSCT

Age at transplantation and availability of a suitable HLA matched donor determine the quality and durability of engraftment, which in turn affects the extent of benefit of HSCT.345, 350 Engraftment can significantly alter the course of the disease, and prolong life expectancy from less than 10 years of age, to adulthood. Despite successful engraftment, some patients may still experience growth retardation, visual impairment, and damage to permanent teeth.346 Additionally, susceptibility to fractures is expected for some time after successful transplantation. Monitoring of symptoms continues, by a multidisciplinary team including a pediatrician, an ophthalmologist, an audiologist, and a dentist.345

#### Guidelines

No guidelines for the management of osteopetrosis were identified in the search.

#### Summary

Overall there appears to be a favorable risk-benefit profile for the use of HSCT in the severe autosomal recessive infantile malignant form of osteopetrosis. For this indication HSCT is the only curative treatment. HSCT is performed as early as possible, once symptoms clearly indicate the severe form, usually before 3 months of age.346, 348 Symptom-specific treatment is recommended for the milder autosomal recessive form and the autosomal dominant form.