# Methods

## Topic Development and Refinement

The topic of this report and preliminary Key Questions were developed through a public process involving the public, the Scientific Resource Center (available at: http://effectivehealthcare.ahrq.gov/index.cfm/who-is-involved-in-the-effective-health-care-program1/about-the-scientific-resource-center1/) for the Effective Health Care program of the Agency for Healthcare Research and Quality (AHRQ), and various stakeholder groups.

Recognizing that the scope was broad and that there were diseases for which 20 years of research had been codified into guidelines and reviews, as described in the Introduction, we took a “narrative review” approach to those diseases, reserving a systematic review approach for those indications for which the role of HSCT was not established by clinical study. This was done in consultation with a Key Informant panel and AHRQ personnel. The Key Informant panel comprised clinical experts in the various diseases covered in this report. The topic refinement process made us aware that the literature base for the systematic review was predominantly case series and case reports. This represents the circumstance that the diseases under consideration are rare diseases or in more common diseases, the subgroups of patients having poor prognosis or are refractory to therapy.

Topic refinement also outlined the frameworks and PICOTS which were also posted for public comment. In summary, the public comments addressed three main points. First, while successes have been seen with HSCT in many pediatric conditions, the measurement of comparative outcomes after HSCT is difficult due to the rarity of the conditions (e.g., retinoblastoma) and/or the number of transplants completed (e.g., autoimmune diseases). Second, comparative harms data are equally difficult to obtain, as separating out the harms associated with HSCT from the harms associated with other prior treatments or disease natural history is not possible in many cases. Third, it was suggested that we contact the Pediatric Blood and Marrow Transplant Consortium and Center for International Blood and Marrow Transplant Research (CIBMTR) to see if they could provide advice to guide the structure of the report. No major changes were made following the public comments. These points were taken into account in the CER.

## Technical Expert Panel and Peer Review

With completion of the topic refinement phase, a Technical Expert Panel (TEP) was formed. The TEP included original Key Informant panel members and clinical experts not previously involved. The TEP provided consultation on the development of the protocol and evidence tables for the review. Ad hoc clinical questions were also addressed to the TEP. The draft report was reviewed by five external reviewers, including invited clinical experts and stakeholders. Revisions were made to the draft report based on reviewers' comments.

## Narrative Reviews

The narrative review approach to a number of conditions presented in this report was based on recognition that there exists a substantial body of evidence from 20 years or more of transplantation research and experience that had been codified into published guidelines and reviews. Thus, systematic review of the evidence for these diseases would not be expected to offer new insights or information. By contrast, the EPC recognized there were a number of diseases for which evidence of benefits and harms was less clear or for which clinical practice was less established, so that systematic review of the literature would be more likely to provide new insight to inform the field.

The final categorization of indications for the narrative reviews was determined in an iterative process. Information sources were not identified by a systematic review of the literature. Rather, the EPC relied on recently published reviews of pediatric transplantation studies, and publicly available sources such as the National Guidelines Clearinghouse and the National Cancer Institute's Physician Data Query (PDQ) Web site, to develop an initial list of diseases for discussion with the Key Informant panel. The EPC subsequently reexamined the lists, compared them to existing evidence, in the context of the Key Informant discussions. A final list of indications for narrative reviews compiled by the EPC was posted for public comment.

## Systematic Reviews

The following methods apply only to the systematic reviews presented in this report.

### Literature Search

Electronic databases searched were MEDLINE®, Embase®, and the Cochrane Controlled Trials Register. Databases were initially searched without restriction on date, using the search strategy shown in Appendix A. However, during the Topic Refinement phase of this project, the Key Informants strongly recommended limiting study selection to the past 15 years to ensure we identify evidence that is comparable in terms of therapeutic regimens and management protocols. Thus, we reviewed the literature from January 1995 up to November 9, 2009. Literature searches were updated to August 17, 2011, prior to delivery of the final report to ensure the identification of new literature that potentially had an impact on the review.

All search results were compiled into an EndNote® reference manager database with exclusion of duplicates. Additional details on these materials and results of our review are provided in the Results chapter. Search strategies and results are detailed in Appendix A.

### Study Selection

Inclusion and exclusion criteria are for all Key Questions.

Inclusion criteria:

- Reports on pediatric patients (age ≤21 years) who have relevant diseases (malignant solid tumors, inherited metabolic diseases, or autoimmune disease).
- Reports on an outcome of interest.
- Reported on HSCT and/or a comparator of interest.
- Intervention and comparator used contemporary regimens with respect to chemotherapy, radiation therapy and supportive care.
- For Key Questions 3 and 4 (inherited metabolic diseases) studies reporting outcomes on the natural history of disease were included as comparators.

Exclusion criteria:

- Studies older than 15 years as they would not represent contemporary regimens except the natural history data for Key Questions 3 and 4.
- Studies where pediatric data could not be separated and abstracted from adult data.
- Duplicate studies or reports with duplicate patients were excluded except the study with the largest number of patients with the longest followup.

Abstract and study selection was performed by a single reviewer for each section of the report. If a reviewer was uncertain whether a study should be selected for inclusion, this was resolved through discussion at team meetings.

Figure 4 shows a PRISMA11 diagram of the studies included in the systematic review. A listing of excluded references with reasons for exclusions is available in Appendix B.

Figure 4 PRISMA diagram of articles included in the systematic review

Figure 4 is a PRISMA diagram illustrating the review of articles for this systematic review. 5,181 records were identified in the initial database search and screened; an additional 1,235 records were identified in an August 2011 search update (total 6,416 records screened). Of these, 5,203 were excluded. 1,234 unique, full-text articles were reviewed and 21 additional records were identified through other sources. 983 full-text articles were excluded and 251 articles were included in the final report.

Disease | Total INCL | Total EXCL | (Hand Searched INCL) | (Hand Searched EXCL) | Totals (Total INCL & Total EXCL)
Autoimmune Disease | 30 | 293 | 0 | 0 | 323
Embryonal Tumors | 12 | 54 | 2 | 4 | 66
ESFT | 36 | 88 | 0 | 0 | 124
GCT | 4 | 7 | 2 | 7 | 11
Glial Tumors | 38 | 90 | 2 | 1 | 128
IMD | 56 | 114 | 0 | 0 | 170
Neuroblastoma | 9 | 159 | 0 | 0 | 168
Retinoblastoma | 20 | 21 | 0 | 0 | 41
Rhabdomyosarcoma | 26 | 35 | 3 | 0 | 61
Wilm's Tumor | 20 | 17 | 0 | 0 | 37
Other | 0 | 105 | 0 | 0 | 105
Totals | 251 | 983 | 9 | 12 | 1,234

### Data Abstraction

Data were abstracted by a single reviewer, and fact checked by another reviewer. If there were disagreements, they were resolved through discussion among the review team. The following data elements of primary studies were abstracted from the articles meeting selection criteria:

- Critical features of the study design
  ○ Patient inclusion/exclusion criteria
  ○ Number of participants and flow of participants through steps of study
- Patient characteristics, including:
  ○ Age
  ○ Sex
  ○ Race/ethnicity
  ○ Disease and stage
  ○ Disease duration
  ○ Other prognostic characteristics
- Treatment characteristics, including
  ○ Stem-cell source
  ○ Chemotherapy versus chemo-radiotherapy
  ○ Immunosuppressive therapy as prophylaxis for graft versus host disease
  ○ Supportive care
- Outcome assessment details
  ○ Identified primary outcome
  ○ Secondary outcomes
  ○ Response criteria
  ○ Use of independent outcome assessor
  ○ Followup frequency and duration
- Data analysis details
  ○ Statistical analyses (statistical test/estimation results)
    – Test used
    – Summary measures
    – Sample variability measures
    – Precision of estimate
    – P values

Full data abstraction tables are available in Appendix C. Evidence tables were generated in Microsoft Excel® and Microsoft Word®.

### Study Quality

Evidence consisted largely of case series and case reports; therefore we did not attempt to assess the quality of individual studies. It is well recognized in the study of rare diseases that a common challenge is the preponderance of small, uncontrolled studies.12 Therefore, because studies tended to be homogenous in design, quality assessment would be unlikely to discriminate between higher and lesser quality studies.

### Data Synthesis

Data synthesis was qualitative. We attempted to identify subgroups based on prognostic factors such as tumor stage or location in solid tumors, or disease severity or rate of progression in the inborn metabolic disorders, to see if these subgroups showed patterns of treatment success or failure. The evidence base was considered insufficient and too heterogeneous to use quantitative pooling methods. Where possible we calculated confidence intervals for results and reported ranges of results for studies that addressed the same population and treatment.

### Grading the Evidence for Each Key Question

The strength of the body of evidence for each indication was assessed according to the process developed by the AHRQ EPC Program13 for the EPC Methods Guide, based on a system developed by the GRADE Working Group.14 This comprised an iterative, qualitative consensus-driven process among EPC team members familiar with the summarized literature, using the 4 required domains specified in the EPC Methods Guide: risk of bias, consistency, directness, and precision. There were no head-to-head comparative studies for most diseases; in those situations, directness was based on the outcome (e.g., overall survival or other clinically important health outcomes) rather than on the comparison. For small series or a compilation of case reports in which the prognosis absent HSCT is uniformly fatal (e.g., Wolman's disease), the known natural history was considered an indirect comparator. An optional domain, strength of association (SOA, magnitude of effect) was thus ascribed to the body of evidence when there was an apparent benefit or harm, increasing the overall strength beyond what may be normally considered appropriate for such evidence. SOA was deemed not applicable for diseases where there was no clear evidence of benefit or harm with HSCT versus comparators, or if results (e.g., overall survival rates) of individual studies within a body of literature were inconsistent or conflicted. No quantitative scoring method was applied.

Table 3 displays the EPC Methods Guide definitions and applications of GRADE and describes how we applied the domains in this review.

Table 3 Elements of evidence grading for Key Questions

Domain | Definitions and Elements From EPC Methods Guide | Score and Application by BCBSA in the HSCT Project
Risk of Bias | Risk of bias is the degree to which the included studies for a given outcome or comparison have a high likelihood of adequate protection against bias (i.e., good internal validity), assessed through two main elements:; - Study design (e.g., RCTs or observational studies); - Aggregate quality of the studies under consideration. Information for this determination comes from the rating of quality (good/fair/poor) done for individual studies. | In the application of this domain one of three levels of aggregate risk of bias is typically used:; - Low risk of bias was applied when evidence was available from randomized comparative trials.; - Medium risk of bias was applied when evidence was available from large, nonrandomized comparative studies.; - High risk of bias was applied to all other evidence.; Because evidence for the majority of indications considered in the systematic reviews comprised case series or case reports, we did not individually assess study quality. As a consequence, the risk of bias was presumed to be high.
Consistency | The principal definition of consistency is the degree to which reported effect sizes from included studies appear to have the same direction of effect. This can be assessed through two main elements:; - Effect sizes have the same sign (that is, are on the same side of “no effect”).; - The range of effect sizes is narrow.; Application Use one of three levels of consistency:; - Consistent (i.e., no inconsistency); - Inconsistent; - Unknown or not applicable (e.g., single study); As noted in the text, single-study evidence bases (even mega-trials) cannot be judged with respect to consistency. In that instance, use “consistency unknown (single study).” | In the application of this domain we used one of three levels of consistency:; - Consistent (results appear to have one direction of effect i.e. HSCT appears to be an improvement over conventional therapy, HSCT appears not to be an improvement over comparator, or HSCT and conventional therapy appear to have the same survival benefit.); - Inconsistent (Results have more than one direction of effect leading to more than one conclusion.); - Unknown or not applicable (Results may be of unknown consistency is the evidence based consists of a single study or a few case reports.)
Directness | The rating of directness relates to whether the evidence links the interventions directly to health outcomes. For a comparison of two treatments, directness implies that head-to-head trials measure the most important health or ultimate outcomes. Two types of directness, which can coexist, may be of concern: Evidence is indirect if:; - It uses intermediate or surrogate outcomes instead of health outcomes. In this case, one body of evidence links the intervention to intermediate outcomes and another body of evidence links the intermediate to most important (health or ultimate) outcomes.; - It uses two or more bodies of evidence to compare interventions A and B— e.g., studies of A vs. placebo and B vs. placebo, or studies of A vs. C and B vs. C but not A vs. B.; Indirectness always implies that more than one body of evidence is required to link interventions to the most important health outcomes. Directness may be contingent on the outcomes of interest. EPC authors are expected to make clear the outcomes involved when assessing this domain. Application Score dichotomously as one of two levels of directness:; - Direct; - Indirect; If indirect, specify which of the two types of indirectness accounts for the rating (or both, if that is the case)—namely, use of intermediate/surrogate outcomes rather than health outcomes and use of indirect comparisons. Comment on the potential weaknesses caused by, or inherent in, the indirect analysis. The EPC should note if both direct and indirect evidence was available, particularly when indirect evidence supports a small body of direct evidence. | In the application of this domain we addressed the outcome and comparison separately. For the outcome it was scored dichotomously as one of two levels of directness:; - Direct; - Indirect; It was considered direct if the measured outcome was a health outcome, and indirect if the outcome was measured by a surrogate or intermediate outcome. In general this literature commonly reported overall survival and toxicities which are direct health outcomes. For the comparison it was scored dichotomously as one of two levels of directness:; - Direct; - Indirect; It was a direct comparison if outcomes were measured in a head-to head trial and indirect where two or more bodies of evidence were used to compare interventions. Direct comparisons were rare in this literature. For this dimension most were indirect.
Precision | Precision is the degree of certainty surrounding an effect estimate with respect to a given outcome (i.e., for each outcome separately). If a meta-analysis was performed, this will be the confidence interval around the summary effect size. Application Score dichotomously as one of two levels of precision:; - Precise; - Imprecise; A precise estimate is an estimate that would allow a clinically useful conclusion. An imprecise estimate is one for which the confidence interval is wide enough to include clinically distinct conclusions. For example, results may be statistically compatible with both clinically important superiority and inferiority (i.e., the direction of effect is unknown), a circumstance that will preclude a valid conclusion. | In the application of this domain, we scored precision dichotomously as one of two levels of precision:; - Precise; An estimate was considered precise if one of three conditions were met:; 1. A beneficial effect, highly unlikely to be affected by confounding, was observed.; 2. A decrement was observed (e.g., no increase in survival, a decline in survival or high treatment related mortality) highly unlikely to be affected by confounding.; 3. Qualitative comparison of the range of results of HSCT and comparator was plausible.; - Imprecise; An estimate was considered imprecise if none of the above applied.
Strength of association (magnitude of effect) | Strength of association refers to the likelihood that the observed effect is large enough that it cannot have occurred solely as a result of bias from potential confounding factors. | This optional domain was applied for indications with very large effect sizes evident. This additional domain should be considered if the effect size is particularly large. Use one of two levels:; - Strong: large effect size that is unlikely to have occurred in the absence of a true effect of the intervention.; - Weak: small enough effect size that it could have occurred solely as a result of bias from confounding factors.

BCBSA = Blue Cross Blue Shield Association; EPC = Evidence-based Practice Center; HSCT = hematopoietic stem cell transplant; RCT = randomized controlled trial

The overall grade of evidence strength was classified into the following four categories:

- High: Further research is very unlikely to change our confidence in the estimate of effect
- Moderate: Further research is likely to have an important impact on our confidence in the estimate of effect and may change the estimate of effect
- Low: Further research is very likely to have an important impact on our confidence in the estimate of effect and is likely to change the estimate
- Insufficient: Any estimate of effect is very uncertain