# Key Informants

Mitchell Cairo, M.D.

Chief, Pediatric Blood/Bone Marrow Transplantation

Columbia University Medical Center

New York, NY

Laurence Cooper, M.D.

Professor of Pediatrics

M.D. Anderson Cancer Center

Houston, TX

Morton Cowan, M.D.

Director, Bone Marrow Transplant Program

University of California San Francisco

San Francisco, CA

Marc Leib, M.D., J.D.

Medical Director

Arizona Health Care Cost Containment System

Phoenix, AZ

Michael L. Nieder, M.D.

Medical Director, Blood & Marrow Transplant Program

All Children’s Hospital

St. Petersburg, FL