# Introduction

## Background

Hematopoietic stem-cell transplantation (HSCT) involves the infusion of pluripotent hematopoietic progenitor cells to an individual in the course of treatment of a variety of conditions, including certain malignancies, autoimmune diseases, anemias, immunodeficiencies and inborn metabolic disease.1-3 While the term HSCT is used throughout this report, it is important to note that graft preparations actually contain a mixture of hematopoietic progenitor cells at different stages of maturity, including cells with self-renewal capability (stem cells).4

Hematopoietic progenitor cells arise in the bone marrow. These cells may be isolated from marrow that is aspirated from long bones or the pelvis; alternatively, they can be obtained from the blood by apheresis, and are termed peripheral blood stem cells (PBSC). The proportion of PBSCs circulating in the blood is normally very low, but can be significantly increased by the administration of cyclophosphamide, growth factors such as G-CSF, antibodies (e.g., anti-VLA-4), polyanions (e.g., fucoidan), chemokines (e.g., GROβ), and some signaling pathway inhibitors (e.g., AMD3100).4 Target yields of PBSCs sufficient for transplantation (i.e., more than 2 × 10^6^ CD34+ cells/kg) are usually obtained with one to three aphereses, although this may vary in patients with different malignancies or other conditions (e.g., Fanconi's anemia). PBSCs generally result in faster hematopoietic reconstitution than progenitor cell concentrates isolated from aspirated bone marrow, and are the preferred preparation for autologous transplantation in modern clinical practice.4

Two fundamentally different types of HSCT are in clinical use, depending on the indication and the patient.1, 2 The first, autologous HSCT, involves infusion of hematopoietic progenitor cells obtained from the patient, with the sole intent to restore hematopoietic function following the administration of bone marrow ablative doses of cytotoxic agents. The effectiveness of autologous HSCT is derived entirely from the high-dose cytotoxic conditioning regimen, particularly for treatment of aggressive but chemosensitive malignancies, such as some Hodgkin's and non-Hodgkin's lymphomas. Tandem autologous HSCT refers to a planned treatment that involves administration of two cycles of myeloablative therapy, each followed by infusion of autologous HSCT.

The second type of HSCT, allogeneic HSCT, refers to the infusion of hematopoietic progenitor cells obtained from a donor, but has two purposes. It recreates a new immunohematopoietic system in patients who receive marrow ablative doses of cytotoxic agents. In addition, the nonself allogeneic immune effector cells contained in a donor stem cell preparation exert a therapeutic graft-versus-malignancy (GVM) effect, and in the case of autoimmune diseases, a possible graft-versus-autoimmune disease effect.

Allogeneic HSCT may involve the use of a fully marrow ablative, high-dose conditioning regimen, with accompanying tumor cytoreduction, or a nonmyeloablative regimen, that is referred to as reduced-intensity conditioning, with clinical benefit primarily secondary to the GVM effect.5, 6 Reduced-intensity conditioning regimens have been designed to extend the potential benefits of allogeneic HSCT to patients who for reasons of age, disease, or underlying comorbidities, would not be considered candidates for a high-dose, myeloablative procedure. In essence, autologous HSCT is a lifesaving rescue procedure to restore bone marrow function, whereas allogeneic HSCT may be both a rescue and therapeutic procedure.

Umbilical cord blood (UCB) also is a source of hematopoietic stem cells for transplantation.1 UCB is technically an allogeneic source of hematopoietic progenitor cells; it is hypothesized, however, that cord blood cells are more immunologically naïve than bone-marrow-derived progenitor cells. As a consequence, the incidence of acute and chronic graft-versus-host disease (GVHD) is lower with the use of UCB transplantation than with bone marrow-derived cell preparations. Human leukocyte antigen (HLA) matching requirements are thus less stringent than with marrow-derived progenitor cell preparations. However, the total number of progenitor cells that can be obtained from a single umbilical cord is relatively low, which has hampered the application of UCB transplantation in adults, even though outcomes are similar to those achieved with matched unrelated bone-marrow-derived cell preparations.1

HSCT of any type is associated with a number of adverse events, regardless of the conditioning regimen and type of transplant. Acute and chronic GVHD can be highly problematic in patients who undergo an allogeneic HSCT, and represent the major limitation to use of this procedure in older or otherwise debilitated patients.5 Short term (i.e., days 0-100 post-transplant) complications of HSCT of either type include mucositis, hemorrhage, infections (e.g., bacterial, fungal, viral), veno-occlusive disease of the liver, and pulmonary complications. Long-term complications include infertility, impaired growth and cognitive development, and secondary malignancies. The long-term complications assume greater importance in pediatric patients than in older recipients, in particular as post-HSCT survival rates have increased and treatment-related mortality has decreased with improved life support and management.7-10 Additional background information is presented in the discussion of each condition.

## Scope and Key Questions

This comparative effectiveness review consists of two major sections, which were determined through the Agency for Healthcare Research and Quality (AHRQ) topic refinement process with input from Key Informants and AHRQ personnel (see Methods chapter). The first section comprises a set of narrative reviews on the use of HSCT in pediatric malignant and nonmalignant diseases for which HSCT is considered a well-established treatment option. The second section contains a set of systematic reviews of the use of HSCT in malignant and nonmalignant diseases, including solid tumors, inherited metabolic diseases, and autoimmune diseases. The indications systematically reviewed were those for which the therapeutic role of HSCT has not been established by clinical study. Specific settings are outlined in the Methods chapter. For pediatric malignancies, key outcomes of interest included overall survival, treatment-related mortality, and other severe adverse events.

For the inherited metabolic diseases, outcomes of interest were overall survival, neurocognitive and neurodevelopmental measures, treatment-related mortality, and other severe adverse events. For the autoimmune diseases, the key outcomes were drug-free clinical remission, as well as treatment-related mortality and other severe adverse events. No effort was made to systematically review outcomes in the context of different induction chemotherapy or consolidation conditioning regimens, supportive care, or stem-cell preparations. Rather, the document is intended to show the level of evidence in the literature on the use of HSCT for each indication, supposing that treatment will be delivered according to protocols in place at individual clinical institutions. The EPC Methods Guide process was used to provide an overall evaluation of the strength of evidence for each key outcome and for the overall body of evidence for each indication.

Table 1 displays the indications to be approached as a narrative review, while Table 2 displays the indications to be addressed in the systematic review. It is important to note that neuroblastoma, germ cell tumors, and central nervous system embryonal tumors are covered in both the narrative and systematic reviews; however, they are distinguished in each by the specific indication and the type of transplant procedure.

Table 1 Pediatric HSCT indications to be addressed with narrative review

Type | Disease | Indication(s) | Transplant Type
MH | Acute lymphoblastic leukemia (ALL) | In first (high-risk patients), second, or subsequent complete remission (CR) | Allo
MH | Acute myelogenous leukemia (AML) | In first, second, or subsequent CR; early relapse; induction failure | Allo
MH | Juvenile myelomonocytic leukemia (JMML) | As upfront therapy | Allo
MH | Myelodysplastic syndrome (MDS) | As upfront therapy for primary or secondary MDS | Allo
MH | Chronic myelogenous leukemia (CML) | Chronic phase or refractory to tyrosine kinase inhibitor (TKI) | Allo
MH | Non-Hodgkin's lymphoma (NHL)/Hodgkin's lymphoma (HL) | Induction failure; first, second, third CR/partial remission | Auto/allo
MNH | Neuroblastoma (NB) | Consolidate high-risk (initial) | Auto
MNH | Neuroblastoma (NB) | Relapsed/refractory | Auto (allo in selected incidences)
MNH | Germ cell tumor (GCT) | Relapsed | Auto (allo if fail auto and in selected incidences)
MNH | Central nervous system embryonal tumors | Relapsed or residual | Auto
NM | Hemoglobinopathies | Variable | Allo
NM | Bone marrow failure syndromes (BMF) | Variable | Allo
NM | Primary immunodeficiencies, including: Lymphocyte immunodeficiencies Adenosine deaminase deficiency Artemis deficiency Calcium channel deficiency CD 40 ligand deficiency Cernunnos-XLF immune deficiency CHARGE syndrome with immune deficiency Common gamma chain deficiency Deficiencies in CD45, CD3, CD8 DiGeorge syndrome DNA ligase IV Interleukin-7 receptor alpha deficiency Janus-associated kinase 3 (JAK3) deficiency Major histocompatibility class II deficiency Omenn syndrome Purine nucleoside phosphorylase deficiency Recombinase-activating gene (RAG) 1/2 deficiency Reticular dysgenesis Winged helix deficiency Wiskott-Aldrich syndrome X-linked lymphoproliferative disease Zeta-chain-associated protein-70 (ZAP-70) deficiency Phagocytic deficiencies Chediak-Higashi syndrome Chronic granulomatous disease Griscelli syndrome type 2 Interferon-gamma receptor deficiencies Leukocyte adhesion deficiency Severe congenital neutropenias Shwachman-Diamond syndrome Other immunodeficiencies Autoimmune lymphoproliferative syndrome Cartilage hair hypoplasia CD25 deficiency Familial hemophagocytic lymphohistiocytosis Hyper IgE syndromes ICF syndrome IPEX syndrome NEMO deficiency NF-κB inhibitor, alpha (IκB-alpha) deficiency Nijmegen breakage syndrome | Variable | Allo
NM | Inherited metabolic diseases, including: Mucopolysaccharidosis (MPS) MPS I (Hurler), MPS VI (Maroteaux-Lamy), MPS VII (Sly syndrome) Sphingolipidosis Gaucher I, Niemann-Pick disease B, globoid leukodystrophy, metachromatic leukodystrophy Glycoproteinosis Fucosidosis, alpha-mannosidosis Peroxisomal storage disorders Adrenoleukodystrophy | Variable | Allo
NM | Osteopetrosis | Severe | Allo

ALL = acute lymphoblastic leukemia; allo = allogeneic; AML = acute myelogenous leukemia; auto = autologous; BMF = bone marrow failure; CML = chronic myelogenous leukemia; CR = complete remission; DM = diabetes mellitus; ESFT = Ewing sarcoma family of tumors; GCT = germ cell tumor; HL = Hodgkin's lymphoma; JRA = juvenile rheumatoid arthritis; MA = meta-analysis; MDS = myelodysplastic syndrome;MH = malignant, hematopoietic; MNH = malignant, nonhematopoietic; NB = neuroblastoma; NHL = non-Hodgkin's lymphoma (includes Burkitt/Burkitt-like, diffuse large B-cell lymphoma, lymphoblastic lymphoma and anaplastic large cell lymphoma); NM = nonmalignant; OS = osteosarcoma; PNET = primitive neuroectodermal tumor; SLE = systemic lupus erythematosus; TKI = tyrosine kinase inhibitor

Table 2 Pediatric HSCT indications to be addressed with systematic review

Type | Disease | Indication(s) | Transplant Type | Comparator
MNH | Ewing sarcoma family of tumors (ESFT) | Consolidate high risk (initial) | Auto | Conventional chemotherapy
MNH | Ewing sarcoma family of tumors (ESFT) | Relapsed/refractory | Auto | Conventional chemotherapy
MNH | Ewing sarcoma family of tumors (ESFT) | Relapsed/refractory | Tandem auto auto | Single auto
MNH | Wilms | Consolidate high risk | Auto | Conventional chemotherapy
MNH | Wilms | Relapsed/refractory | Auto | Conventional chemotherapy
MNH | Wilms | Relapsed/refractory | Tandem auto auto | Single auto
MNH | Rhabdomyosarcoma (RMS) | High-risk disease | Auto | Conventional chemotherapy
MNH | Rhabdomyosarcoma (RMS) | High-risk disease | Tandem auto auto | Single auto
MNH | Retinoblastoma | Extraocular spread | Auto | Conventional chemotherapy
MNH | Retinoblastoma | Extraocular spread | Tandem auto auto | Single auto
MNH | Neuroblastoma (NB) | Consolidate high risk (initial) Relapsed/refractory | Tandem auto auto | Single auto
MNH | Germ cell tumor (GCT) | Relapsed | Tandem auto auto | Single auto
MNH | Central nervous system embryonal tumors | Initial therapy | Auto | Conventional chemotherapy
MNH | Central nervous system embryonal tumors | Initial therapy | Tandem auto auto | Single auto
MNH | Central nervous system glial tumors | Consolidate high risk | Auto | Conventional chemotherapy
MNH | Central nervous system glial tumors | Relapsed/refractory | Auto | Conventional chemotherapy
[underlined: NM] | [underlined: Inherited metabolic diseases:] Mucopolysaccharidosis (MPS) MPS II (Hunter's), MPS III (Sanfilippo), MPS IV (Morquio) Sphingolipidosis Fabry's, Farber's, Gaucher's II-III, GM_1_ gangliosidosis, Niemann-Pick disease A, Tay-Sachs disease, Sandhoff's disease Glycoproteinosis Aspartylglucosaminuria, beta-mannosidosis, mucolipidosis III and IV [underlined: Other lipidoses] Niemann-Pick disease C, Wolman disease, ceroid lipofuscinosis Glycogen storage GSD type II Multiple enzyme deficiency Galactosialidosis, mucolipidosis type II [underlined: Lysosomal transport] defects Cystinosis, sialic acid storage disease, Salla disease Peroxisomal storage disorders Adrenomyeloneuropathy | Variable | Allo | Enzyme-replacement therapy, substrate reduction with iminosugars and chaperones
NM | Autoimmune, including juvenile rheumatoid arthritis (JRA), systemic lupus erythematosus (SLE), scleroderma, immune cytopenias, Crohn's | Upfront therapy for severe/ refractory or salvage | Auto/allo | Immunosuppressants, targeted biologic therapies and/or low-dose chemotherapy
NM | Autoimmune type 1 diabetes mellitus (DM) | Variable | Auto | Immunosuppressants, targeted biologic therapies and/or low-dose chemotherapy, conventional management (i.e., insulin injections)

allo = allogeneic; auto = autologous; DM = diabetes mellitus; ESFT = Ewing sarcoma family of tumors; GCT = germ cell tumor; HL = Hodgkin's lymphoma; JRA = juvenile rheumatoid arthritis; MDS = myelodysplastic syndrome; MNH = malignant, nonhematopoietic; NM = nonmalignant; OS = osteosarcoma; PNET = primitive neuroectodermal tumor; RMS = rhabdomyosarcoma; SLE = systemic lupus erythematosus; TKI = tyrosine kinase inhibitor

### Systematic Review Key Questions

- Key Question 1. For pediatric patients with malignant solid tumors, what is the comparative effectiveness of HSCT and conventional chemotherapy regarding overall survival, long-term consequences of HSCT, and quality of life?
- Key Question 2. For pediatric patients with malignant solid tumors, what are the comparative harms of HSCT and conventional chemotherapy regarding adverse effects of treatment, long-term consequences of HSCT, and impaired quality of life?
- Key Question 3. For pediatric patients with inherited metabolic diseases, what is the comparative effectiveness of HSCT, enzyme-replacement therapy (ERT), and substrate reduction with iminosugars regarding overall survival, cure, long-term consequences of HSCT, and quality of life?
- Key Question 4. For pediatric patients with inherited metabolic diseases, what are the comparative harms of HSCT, enzyme-replacement therapy (ERT), and substrate reduction with iminosugars regarding adverse effects of treatment, long-term consequences of HSCT, and impaired quality of life?
- Key Question 5. For pediatric patients with autoimmune diseases, what is the comparative effectiveness of HSCT, immunosuppressants, target biologic therapies, and low-dose chemotherapy regarding overall survival, cure, and remission?
- Key Question 6. For pediatric patients with autoimmune diseases, what are the comparative harms of HSCT, immunosuppressants, target biologic therapies, and low dose chemotherapy regarding adverse effects of treatment, long-term consequences of HSCT, and impaired quality of life?

The PICOTS (Patient, Intervention, Comparator, Outcome, Timing, and Setting) for the three indications addressed in the systematic review follow.

#### Indication 1 Malignant Solid Tumors (Key Questions 1 and 2)

P: | Pediatric patients with malignant solid tumors including rhabdomyosarcoma and retinoblastoma
I: | Hematopoietic stem-cell transplantation (HSCT)
C: | Conventional chemotherapy
O: | Overall survival (OS); long-term consequences of HSCT; quality of life (QOL)
T: | All durations of followup will be included
S: | Inpatient

#### Indication 2 Inherited Metabolic Disease (Key Questions 3 and 4)

P: | Pediatric patients with inherited metabolic diseases
I: | Hematopoietic stem-cell transplantation (HSCT)
C: | Enzyme-replacement therapy (ERT) for IMDs with products approved by the U.S. Food and Drug Administration (FDA), substrate reduction with iminosugars disease natural history
O: | OS; cure; long-term consequences of HSCT; QOL
T: | All durations of followup will be included
S: | Inpatient

#### Indication 3 Autoimmune Disease (Key Questions 5 and 6)

P: | Pediatric patients with autoimmune diseases
I: | Hematopoietic stem-cell transplantation (HSCT)
C: | Immunosuppressants, targeted biologic therapies, low-dose chemotherapy
O: | Remission, survival, cure
T: | All durations of followup will be included
S: | Inpatient

Analytic frameworks are detailed in Figure 1, Figure 2, and Figure 3.

Figure 1 Analytic framework for HSCT for pediatric malignant solid tumors

HSCT = hematopoietic stem-cell transplantation; KQ = Key Question; QOL = quality of life

Figure 1 shows an analytic framework, i.e., a graph that depicts key questions one and two. Briefly, patients with pediatric malignant solid tumor can be treated with HSCT or other therapies. The short term effectiveness and safety of the interventions is measured by intermediate outcomes (recurrence free survival and progression free survival) and adverse event data. The long term effectiveness and safety of the interventions is measured overall survival, long term consequences of HSCT, and quality of life.

Figure 2 Analytic framework for HSCT for pediatric inherited metabolic diseases

GVHD = graft-versus-host disease; HSCT = hematopoietic stem-cell transplantation; KQ = Key Question; QOL = quality of life

Figure 2 shows an analytic framework, i.e., a graph that depicts key questions three and four. Briefly, patients with pediatric inherited metabolic disease can be treated with HSCT or other therapies. The short term effectiveness and safety of the interventions is measured by intermediate outcomes stable source of endogenous enzyme, stabilization or slowed progression of neurocognitive decline) and adverse event data. The long term effectiveness and safety of the interventions is measured overall survival, cure, long term consequences of HSCT, and quality of life.

Figure 3 Analytic framework for HSCT for pediatric autoimmune diseases

GVHD = graft-versus-host disease; HSCT = hematopoietic stem-cell transplantation; KQ = Key Question; QOL = quality of life

Figure 3 shows an analytic framework, i.e., a graph that depicts key questions five and six. Briefly, patients with pediatric inherited metabolic disease can be treated with HSCT or other therapies. The short term effectiveness and safety of the interventions is measured by intermediate outcomes (slowed progression or improvement in organ damage secondary to the autoimmune disease) and adverse event data. The long term effectiveness and safety of the interventions is measured by remission, overall survival, cure, long term consequences of HSCT, and quality of life.