# C-Peptide and HbA1c Outcomes

In all studies, serum C-peptide levels were measured using radioimmunoassay. To accommodate differences in data presentation and analysis, they are presented in the tables as a percentage change from values at study entry.

## C-Peptide Level

Data on C-peptide levels were reported in all three studies included in this review, at follow-up times that range from 6 months in one IIT study (Crino et al, 2005, rec#23080) to more than 4 years in the HSCT study (Couri et al, 2009, rec#290) (Table F1). The proportional change in C-peptide levels in the HSCT study refer only to patients who remained continuously insulin free.

AppendixTable F1 C-peptide levels following autologous HSCT or IIT in pediatric patients

Outcome | Intervention % Δ in Mean Value | Comparator % Δ in Mean Value | p-value (vs Mean Baseline Value) | Study (rec#)
6 months | + ∼ 113 (n = 11) | | < 0.001 | Couri et al, 2009 (290)
1 year | + ∼ 100 (n = 12) | | 0.001 | Couri et al, 2009 (290)
2 year | + 249 (n = 8) | | < 0.001 | Couri et al, 2009 (290)
3 year | + 224 (n = 3) | | 0.001 | Couri et al, 2009 (290)
4 year | NR (n = 1) | | NR | Couri et al, 2009 (290)
1 year | | + 131 (n = 27) | NS | Crino et al, 2005 (23080)
2 year | | + 119 (n = 27) | NS | Crino et al, 2005 (23080)
6 months | | - 20 (n = 8) | 0.05 | Mastrandrea et al, 2009 (40050)

The data in Table F1 show that C-peptide levels following a mixed-meal tolerance test were significantly increased above baseline values in the HSCT study (Couri et al, 2009, rec#290) for more than two years in 8 of 12 patients who became continuously insulin free following the procedure. In one IIT study, mean fasting C-peptide levels were not changed significantly at 1 or 2 years following initiation of treatment from that at study entry (Crino et al, 2005, rec#23080). In the second IIT study, the mean C-peptide level following a Boost meal test was slightly lower at 6 months following initiation of treatment than that at study entry (Mastrandrea et al, 2009, rec#40050).

## Hemoglobin A1C Levels

Table F2 shows HbA1C levels in patients treated with nonmyeloablative autologous HSCT (Couri et al, 2009, rec#290) or IIT (Crino et al, 2005, rec#23080; Mastrandrea et al, 2009, rec#40050).

AppendixTable F2 HbA1C levels following autologous HSCT or IIT in pediatric patients

Outcome | Intervention % Δ in Mean Value | Comparator % Δ in Mean Value | p-value (vs Mean Baseline Value) | Study (rec#)
3 months | - 32 | | < 0.001 | Couri et al, 2009 (290)
1 year | - 29 | | < 0.001 | Couri et al, 2009 (290)
2 year | - 29 | | < 0.001 | Couri et al, 2009 (290)
3 year | - 31 | | < 0.001 | Couri et al, 2009 (290)
4 year | - 25 | | < 0.001 | Couri et al, 2009 (290)
1 year | | - 48 | NS | Crino et al, 2005 (23080)
2 year | | - 38 | NS | Crino et al, 2005 (23080)
6 months | | - 44 | NR | Mastrandrea et al, 2009 (40050)

Hemoglobin A1C (HbA1C) levels pretransplant ranged from 5.4% to 11.6% (mean 8.4 ± 1.6%) among 18 pediatric patients in the HSCT study (Couri et al, 2009, rec#290). Among those who became continuously insulin-free, HbA1C declined from a mean 8.0% to 5.7%, 5.7%, 5.5%, and 6.0%, respectively, at 12, 24, 36, and 48 months after transplantation (p < 0.001 at all time points versus pretreatment value).

In one IIT study, HbA1C did not change significantly from a mean 10.5 ± 2.2% at diagnosis to 5.4 ± 0.8% and 6.5 ± 0.9% at 12 and 24 months, respectively (Crino et al, 2005, rec# 23080). In the second IIT study, mean HbA1C at study entry (12.4 ± 2.5%) declined to an average 7.0 ± 1.2% (p-value NR) (Mastrandrea et al, 2009, rec#40050).