# Neurodevelopmental and Neurocognitive Outcomes

Appendix Table E1 Neurocognitive and neurodevelopmental outcomes for treatment (HSCT) of inherited metabolic diseases with rapid progression

Appendix Table E2 Neurocognitive and neurodevelopmental outcomes for treatment (HSCT) and comparators (ERT, substrate reduction therapy) of inherited metabolic diseases with slow progression

Appendix Table E3 Neurocognitive and neurodevelopmental outcomes for treatment (HSCT) and comparators (ERT, substrate reduction therapy) of inherited metabolic diseases with both rapid and slow progression