# Disease-Free/Event-Free Survival

## Ewing's Sarcoma Family of Tumors (ESFT)

EFS or DFS was reported or generated in 13 HSCT studies (Oberlin, 2008 #2020; Meyers, 2001, #13670; Drabko, 2005, #6680; Prete, 1998, #17210; Hawkins, 2000 ,#15360; Ozkaynak, 1998, #18540; Laws, 2003, #9450; Yaniv, 2004, #9100; Kushner, 2001, #14240; Lucas, 2008, #9450; Diaz, 2010 #1212; Ilari, 2010 #1208; Ladenstein, 2010 #1209) and 4 comparative studies (Bernstein, 2006, #6290; Sari, 2010 #42790; Kushner,1995, #44560; Milano, 2006,#5960;).

Appendix Table D1 Event-free survival (DFS; PFS) for treatment (single and tandem auto HSCT) and comparison (conventional chemotherapy +/- radiation) groups: ESFT

| Intervention Single (%; ± 95% CI) | Comparator Chemo (%; ± 95% CI) | Study
1 year | 54% (25-84)* | | Yaniv, Israel, 2004 (n=11) #9100
1 year | 20% (0-45)* | | Kushner, USA, 2001(n=10) #14240
1 year | 50% (0-100%)* | | Laws, Germany, 2003 (n=2) #9450
1 year | Stable disease 9 mos after HSCT | | Lucas, USA, 2008 (n=1) #2450
1 year | | 65% +/- 5% [isolated lung mets vs other and more than isolated lung mets 72% +/-7% and 62% +/-6%; p=.39] | Bernstein, USA/Canada 2006 (n=110) #6290
1 year | | 83% (67-98%) | Kushner, USA, 1995 (n=24) #44560
2 year | 20% | | Meyers, USA, 2001 (n=32) #13670
2 year | 63% | | Drabko, Poland, 2005 (n=21) #6680
2 year | 63% | | Prete, Italy, 1998 (n=17) #17210
2 year | 50% (0-100%)* | | Laws, Germany, 2003 (n=2) #9450
2 year | | 24% (+/-4%) [31% +/-7% for pts with isolated lung mets and 20% +/-5% for pts with more widespread dz; p=.39] | Bernstein, USA/Canada 2006 (n=110) #6290
3 year | 36% | | Hawkins, USA, 2000 (n=16) #15360
3 year | 51% for all pts 66% +/-19% for 1st remission 37% for 2nd remission | | Ozkaynak, USA, 1998 (n=15) #18540
3 year | 18% (0-41%)* | | Yaniv, Israel, 2004 (n=11) #9100
3 year | 20% (0-45)* | | Kushner, USA, 2001 (n=10) #14240
3 year | | 75% (55-95%) | Kushner, USA, 1995 (n=24) #44560
3 year | | 74% | Milano, Italy, 2006 (n=18) #5960
3 year | 40% (SD: 0.05) | | Ladenstein, Austria, France, UK, Switzerland, Netherlands, Germany, Sweden, 2010 #1209
4 year | A NED (ESFT) at 50 mos after HSCT^a^ | | Numata, Japan, 2006 (n=1) #12130
5 year | 46% | | Oberlin, France, 2008 (n=61) #2020
5 year | 32% (+/- 11%) in HyperME with median f/u 146 mos (98-190) and 40% (+/-13%) in TandemME with median f/u 68 mos (28-88 mos) | | Burdach, Germany and Austria, 2003 (n=32) #10030
5 year | 18% (0-41%)* | | Yaniv, Israel, 2004 (n=11) #9100
5 year | 20% (0-45)* | | Kushner, USA, 2001 (n=10) #14240
5 year | A NED 60 months after surgery | | Kogawa, Japan, 2004 (n=1) #8410
5 year | | 18% | Sari, Turkey, 2010 (n=36) #42790
5 year | | 75% (55-95%) | Kushner, USA, 1995 (n=24) #44560
5 year | PFS 56% (+/- 4%) with a median f/u of 92 months for survivors (range 6-168 months) by localized vs mets at dx PFS for pts with local dz:78% (+/- 8%); for mets: 27% (+/- 10%) | | Diaz, Spain, 2010 (n=47) #1212
5 year | 7 year f/u 61% (95%CI 36-79) | | Ilari, Italy, 2010 (n=24) #1208

a Numata (#12130)-pt dxd with CML, chronic phase at 50 mos

## Wilm's Tumor

### Event-free/disease-free survival

Sixteen studies reported event or disease-free survival (Spreafico, 2008, #2380; Malogolowkin, 2008, ##44950; Tucci, 2007, ##3910; Park, 2006, ##5450; Campbell, 2004, #8570; Valera, 2004, ##8620; Kremens, 2002, ##11240; Abu-Ghosh, 2002, #45610; Saarinen-Pihkala, 1998, ##17940; Pein,1998, ##17570; Dagher, 1998, #17840; Hempel, 1998, ##18100; Hempel, 1996, #20550; Kullendorff,1997, #19290; Brown, 2010, #1211; Lucas, 2010, #1210).

Appendix Table D2 Event-free survival (DFS; PFS) for treatment (single auto HSCT) and comparison (conventional chemotherapy +/- radiation) groups: Wilm's tumor

| Intervention Single (%; ± 95% CI) | Comparator Chemo (%; ± 95% CI) | Study
1 year | 1 yr 52% [32-73] (n=23) | | Kremens, 2002, #11240
1 year
1 year | | 1 yr ∼73% (n=11) | Abu-Ghosh, 2002, #45610
1 year | 1 yr 86% [60-100]* (n=7) | | Hempel, 1996, #20550
1 year | 1 yr 75% [33-100]* (n=4) | | Kullendorff, 1997, #19290
1 year | 1 yr 67% [13-100]* (n=3) | | Valera, 2004, #8620
1 year
1 year | .5 yrs (n=1) | | Dagher, 1998, #17840
1 year | DFS at 15 months after HSCT (n=1) | | Brown, 2010, #1211
1 year PFS range across studies | 52%-86% (Kremens, Spreafico, Hempel, Kullendorff, Valera) | ∼73% (Abu-Ghosh)
2 year | 2 yr 75% [33-100]* (n=4) | | Kullendorff, 1997, #19290
2 year
2 year | 2 yr 86% [60-100]* (n=7) | | Hempel,1996, #20550
2 year | alive at 32 months after HSCT (n=1) | | Hempel, 1998, #18100
2 year | EFS at 2.5 years (n=1) | | Lucas, 2010, #1210
3 year | 3 yr 50% +/- 17 (n=28) | | Pein, 1998, #17570
3 year | 3 yr 52% [32-73] (n=23) | | Kremens, 2002, #11240
3 year | 3 yr 56% +/-12% (n=20) | | Spreafico, 2008, #2380
3 year | | 3 year 66.6% (n=10) | Tucci, 2007, #3910
3 year | | 3 yr 64% (n=11) | Abu-Ghosh, 2002, #45610
3 year | 3 yr 67% [13-100]* (n=3) | | Valera, 2004, #8620
4 year | 4-year 60% (n=13) | | Campbell, 2004, #8570
4 year | median 51 months (40-53 months) (n=3) | | Saarinen-Pihkala, 1998, #17940
4 year | | 4 yr 48% (n=60) | Malogolowkin, 2008, #44950
5 year | 5 yr 52% [32-73]* (n=23) | | Kremens,2002, #11240
5 year | A NED at 7 yr (n=1) | 5 year 42.8% (n=10) | Tucci, 2007, #3910
5 year | | 5 yr 64% (n=11) | Abu-Ghosh, 2002, #45610

## Rhabdomyosarcoma

### Event-free survival

Data on intermediate outcomes were reported in eleven studies and calculated from the raw data from two additional studies (Hara, 1998 #17950; Lucidarme, 1998 #17610). Event free survival estimates are presented below.

Appendix Table D3 Event-free survival (DFS; PFS) for treatment (single auto HSCT) and comparison (conventional chemotherapy +/- radiation) groups: Rhabdomyosarcoma

Setting | Outcome | Intervention Single (%; ± 95% CI) | Comparator Chemo (%; ± 95% CI) | P-value | Study
Metastatic Auto | 1 year | ∼46% at 1 year (n=52) | ∼53% at 1 year (n=42) | | Carli, Italy, 1999 #16010
Metastatic Auto | 1 year | | ∼63% at 1 year (n=152) | | Sandler, USA, 2001 #12810
Metastatic Auto | 1 year | | ∼69% at 1 year (n=127) | | Breneman, USA, 2003 #75360
Mixed Tumor Stage Auto | 1 year | 12.5 (4,35) at 1 year (n=8) | | | Lucidarme, France, 1998± #17610
Mixed Tumor Stage Auto | 1 year | 66.7 (28.9,100) at 1 year (n=7) | | | Hara, Japan, 1998± #17950
Metastatic Auto | 3 year | 29.7 (15.6,43.8) at 3 years (n=52) | 19.2 (6.8-31.6)at 3 years (n=42) | 0.3 | Carli, Italy, 1999 #16010
Metastatic Auto | 3 year | 16.5 at 3 years (n=101) | 54.9 at 3 years (n=45) | | McDowell, UK, 2010 #75350
Metastatic Auto | 3 year | 75% (33-107) at 3 years (n=4) | 15% (-4-35) at 3 years (n=13) | | Williams, Canada, 2004 #9010
Metastatic Auto | 3 year | 35.3% (24.3-46.5) at 3 years (n=70) | | | Bisogno, Italy, 2009 #75340
Metastatic Auto | 3 year | | ∼28% at 3 years (n=152) | | Sandler, USA, 2001 #12810
Metastatic Auto | 3 year | | 25% (17-33) at 3 years (n=127) | | Breneman, USA, 2003 #75360
Mixed Tumor Stage Auto | 3 year | 66.7 (28.9,100) at 3 years (n=7) | | | Hara, Japan, 1998± #17950
Metastatic Auto | 5 year | 14.9 at 5 years (n=101) | 51.0% at 5 years (n=45) | | McDowell, UK, 2010 #75350
Metastatic Auto | 5 year | | ∼20% at 5 years (n=127) | | Breneman, USA, 2003 #75360
Metastatic Auto | 5 year | | ∼27% at 5 years (n=152) | | Sandler, USA, 2001 #12810
Mixed Tumor Stage | 5 year | 36% at 5 years (n=22) | | | Matsubara**, Japan, 2003 #10810
Cranial Parameningeal | 5 year | | 32% (22-42) at 10 years (n=91) | | Raney, USA, 2008 #2440
Metastatic (summary) | EFS range for 3 years for studies with > 20 patients | 29.7-35.3% (Carli #16010, Biosgno #75340) | 19.2-28% (Carli #16010, Sandler #12810, Breneman #75360) | | This range does not Include the McDowell #75350 study as the patients in the treatment arm are not comparable to other studies due to their higher risk category.
Mixed Tumor stage (summary) | EFS range for 3 years for studies with > 5 patients | 66.7% (Hara #17950) | No comparator

## Retinoblastoma

Four studies reported event free survival (Namouni, 1997 #18090; Kremens, 2003 #10860; Dunkel, 2010 #28560; Dunkel, 2010 #1204), and EFS was calculated from the raw data from two studies (Galindo, 2003; Matsubara, 2005 #7580). These studies were all single arm case series. At five years the event free survival for patients without CNS involvement ranges from 66.7 to 85.7.

Appendix Table D4 Event-free survival (DFS; PFS) for treatment (single auto HSCT) and comparison (conventional chemotherapy +/- radiation) groups: Retinoblastoma

Outcome | Intervention Single (%; ± 95% CI) | Comparator Chemo (%; ± 95% CI) | P-value | Study
Event Free no CNS | Isolated orbital disease (n=7) 85.7 (59.8-100) at 1-5 years | | | Namouni, 1997± #18090
Event Free no CNS | 100% at 1-3 years 75% at 4-5 years^b^ (n=4) | | | Galindo, 2003± #10420
Event Free no CNS | 100% at mean Follow-up of 38 months (n=3) | | | Matsubara, 2005 #7580
Event Free no CNS | 66.7% at mean follow-up of 8.9 years (n=5) | | | Kremens, 2003 # 10860
Event Free no CNS | 67% (38-85) at follow-up of 5 years (DFS) 59% (31-79) at follow-up of 10 years (PFS) | | | Dunkel, 2010, #1204
Event Free mixed | ∼88% at 1 year^a^ ∼ 62% at 2 years ∼57% at 3 years ∼53% at 4-5 years (n=34)^b^ | | | Namouni, 1997 #18090
Event Free mixed | Patients with Trilateral retinoblastoma (n=13) ∼68% at 1 year ∼38% at 2-5 years | | | Dunkel, 2010 #28560
EFS range for 5+ years for studies with >2 patients without CNS involvement not including trilateral retinoblastoma | 66.7-85.7% (Kremens 2003 # 10860,Galindo 2003 #10420, Namouni 1997 #18090) | NR
EFS range for 5+ years for studies with >2 trilateral retinoblastoma | ∼38% (Dunkel, 2010 #28560) | No comparator study identified

a estimated preceded by a ∼ were estimated from published Kaplan-Meier curves.

b this includes all patients including those who died prior to treatment.

± survival curves were constructed using the raw data published in the articles.

## Neuroblastoma

Data on intermediate outcomes were reported in all seven primary studies. Six studies reported data as event-free survival (EFS), one study as disease-free survival (DFS), and another as progression-free survival (PFS). No significant differences between treatment groups in either three-year DFS or five-year EFS were identified in the two comparative studies.(Kim, 2007 [2870]; Ladenstein, 2008 [1610]) Multivariate analysis of the Sung et al. (2007) data showed the application of total body radiation and local radiotherapy during the treatment regimen, and a longer interval (≥ 12 weeks) between the first and second transplant to be independent favorable predictors for EFS (HR, 9.66, 7.17, 5.73; 95% CI, 1.31-71.26, 1.69-30.38, 1.32-24.88; p = 0.026, 0.007, 0.020, respectively).(Sung, 2007 [3950]) It should be noted that five studies (71%) did not define a priori these outcomes.

Appendix Table D5 Event-free survival (DFS; PFS) for treatment (tandem HSCT) and comparison (single HSCT) groups: Neuroblastoma

Outcome | Intervention Tandem (%; ± 95% CI; SE) [N] | Comparator Single (%; ± 95% CI; SE) [N] | P-value | Study (record #)
3 year rate | 50 (20.4) [9] | 40.6 (14.7) [27] | 0.50 | Kim, 2007 (2870)
3 year rate | 61 (50-71) [82] | | | George, 2006 (5440)
3 year rate | | 47 (38-55) [149] | | Berthold, 2005 (6760)
5 year rate | 27 (2) [455] | 33 (1) [2,895] | 0.19 | Ladenstein, 2008 (1610)
5 year rate | 54 (42-64) [82] | | | George, 2006 (5440)
5 year rate | 62.1 (13.7) [52] | | | Sung, 2007 (3950)
5 year rate | | 38 (21-54) [32] | | Pritchard, 2005 (8030)
5 year rate | | 30 (4) [189] | | Matthay, 2009 (6210)
5 year rate | 51.2 (12.4) [71] | | 0.03 | Sung, 2010 (1206)
> 5 year rate | 52 (40-63) [82] | | | George, 2006 (5440)
EFS range for ≥5 years for studies with > 10 patients | 27-62 | 30-38

CI, confidence interval; DFS, disease-free survival; N, number of patients; PFS, progression-free survival; SE, standard error

## Germ-Cell Tumor

Data on intermediate outcomes were reported in all four studies. The CIBMTR cohort reported data as progression-free survival (PFS) and the remaining three studies either as disease-free survival (Einhorn 2007, De Giorgi 2005) or event-free survival (Agarwal). Data were available to compute three-year rates across all studies, and five-year rates for three studies. For the CIBMTR cohort, there was a trend toward a lower probability of PFS at one-year in the tandem group compared to the single HSCT group (36% vs. 60%), although no p-values were computed due to the small number of cases. PFS did not differ between treatment groups across studies. For the CIBMTR cohort, PFS at 5 years for the tandem group remained at 36% (11%-63%) compared to 49% (26%-69%) in the single HSCT group. PFS was defined as survival without recurrence (or cancer progression) as measured by exam, radiographs, and/or an increase in serum marker levels.(CIBMTR, 2010)

Appendix Table D6 Event-free survival (DFS; PFS) for treatment (tandem HSCT) and comparison (single HSCT) groups: Germ-cell tumor

Outcome | Intervention Tandem (%; ± 95% CI) [N] | Comparator Single (%; ± 95% CI) [N] | P-value | Study (record #)
1-year rate | 36 (11-63) | 60 (36-78) | NR | CIBMTR, 2010
| 59 (39.5-88) | | | Einhorn, 2007 (77230)
| | 50 (26-74.5) | | De Giorgi, 2005 (77240)
3 year rate | 36 (11-63) | 49 (26-69) | NR | CIBMTR, 2010
3 year rate | 59 (39.5-88) | | | Einhorn, 2007 (77230)
3 year rate | | 50 (7-93) | | Agarwal, 2009 (72940)
3 year rate | | 50 (26-74.5) | | De Giorgi, 2005 (77240)
5 year rate | 36 (11-63) | 49 (26-69) | NR | CIBMTR. 2010
5 year rate | 59 (39.5-88) | | | Einhorn, 2007 (77230)
5 year rate | | 50 (26-74.5) | | De Giorgi, 2005 (77240)
EFS range for 5 years for studies with > 10 patients | 36-59 | 49-50

a EFS for stage IV patients; CI, confidence interval; DFS, disease-free survival; N, number of patients; NR, not reported; PFS, progression-free survival

## CNS/Embryonal Tumors

Data on intermediate outcomes were reported in 11 (of 12) studies. For comparisons between tandem vs. single HSCT, data were available to compute two-year, three-year, and five-year rates for three studies. For Sung et al. (2007), EFS at 2 years for the tandem group was 73% (46%-99%) compared to 67% (13%-100%) in the single HSCT group [4770] The AT/RT patient reported in Gidwani et al. (2008) was disease free for two years following tandem HSCT.[71940] EFS was defined as the interval between diagnosis to progression/relapse or death from any cause.

For the conventional-care group of studies, data were available to compute three-year rates for one study and five-year rates for three studies. There were no comparative studies between single HSCT vs. conventional care. For Geyer et al. (2005) on multiple tumor types, overall five-year EFS was 27% (3%) for children under three years of age; for MB, PNET and AT/RT, the corresponding rates were 32% (5%), 17% (6%), and 14% (7%), respectively.[49990] Similar trends to OS above observed in EFS rates between studies.

Appendix Table D7 Event-free survival (DFS; PFS) for treatment (tandem HSCT) and comparison (single HSCT) groups: CNS/embryonal tumors

Outcome (Tumor type) | Intervention Tandem (%; ± 95% CI; SE) [N] | Comparator Single (%; ± 95% CI; SE) [N] | P-value | Study (record #)
2 year rate
(MB-PNET) | 73 (46-99) [11] | 67 (13-100) [3] | NR | Sung, 2007 (4770)
(AT/RT) | [One patient remained disease-free] | | | Gidwani, 2008 (71940)
(MB-PNET) | | 57 (15) [13] | | Perez-Martinez, 2005 (7650)
3 year rate
(MB-PNET) | 73 (46-99) [11] | NA | | Sung, 2007 (4770)
(MB) | | 49 (27-72) [21] | | Chi, 2004 (7900)
(AT/RT) | | 23 (11) [13] | | Gardner, 2008 (71930)
(MB) | 67 [2 of3 patients with complete remission] | | | Aihara, 2010, #1201
5 year rate
(MB-PNET) | 58 (25-91) [11] | NA | | Sung, 2007 (4770)
(PNET) | | 39 (24-53) [43] | | Fangusaro, 2008 (3420)
(MB) | | 52 (11) [21] | | Dhall, 2008 (52130)
EFS range for 5 years for studies with > 10 patients | 58 | 39-52

AT/RT, atypical teratoid/rhabdoid tumor; CC, conventional care; CI, confidence interval; DFS, disease-free survival; EFS, event-free survival; MB, medulloblastoma; N, number of patients; NA, not available; PFS, progression-free survival; PNET, supratentorial primitive Neuroectodermal tumors; SE, standard error

Appendix Table D8 Event-free survival (DFS; PFS) for treatment (single HSCT) and comparison (conventional care) groups: CNS/embryonal tumors

Outcome (Tumor type) | Intervention Single (%; ± 95% CI; SE) [N] | Comparator CC (%; ± 95% CI; SE) [N] | P-value | Study (record #)
3 year rate
(MB) | 49 (27-72) [21] | | | Chi, 2004 (7900)
(MB) | | 40 (28-51) [68] | | Taylor, 2005 (52760)
(AT/RT) | 23 (11) [13] | | | Gardner, 2008 (71930)
5 year rate
(MB) | 52 (11) [21] | | | Dhall, 2008 (52130)
PNET | 39 (24-53) [43] | | | Fangusaro, 2008 (3420)
(MB) | | 81 (2) [379] | | Packer, 2006 (77250)
(MB-PNET-AT/RT-Other) | | 27 (3) [284] | | Geyer, 2005 (49990)
(MB) | | 35 (23-46) [68] | | Taylor, 2005 (52760)
EFS range for 5 years for studies with >10 patients | 39-52 | 27-81

AT/RT, atypical teratoid/rhabdoid tumor; CC, conventional care; CI, confidence interval; DFS, disease-free survival; EFS, event-free survival; MB, medulloblastoma; N, number of patients; NA, not available; PFS, progression-free survival; PNET, supratentorial primitive neuro-ectodermal tumors; SE, standard error

## Glial Tumors

Data on intermediate outcomes were reported in twenty-nine studies and calculated from the raw data. Event free survival estimates are presented below.

Appendix Table D9 Event-free survival (DFS; PFS) for treatment (single auto HSCT) and comparison (conventional chemotherapy +/- radiation) groups: Glial tumors

Setting | Outcome | Intervention Single (%; ± 95% CI) | Comparator Chemo (%; ± 95% CI) | P-value | Study
Astrocytoma | 1 year | AA/GBM PFS: ∼30% (These HSCT and chemotherapy estimates are grouped EFS for astrocytoma and glioblastoma multiforme) (N=27) | AA/GBM year PFS ∼10% (N=56) | Chemo versus ABMR unstratified comparison of event-free survival: P=0.014 | Finlay, 2008
Astrocytoma | 1 year | | 2 patients progressed at 1.5 and 8.5 mo (N=2) | | Shih, 2008
Astrocytoma | 1 year | | 3 patients progressed at 3,3, and 8 mo (N=3) | | Sio, 2006
Astrocytoma | 1 year | | 1 astrocytoma patient progressed at 4 months, and one patient was progression free at 10 months (N=2) | | Koronoes, 2006
Astrocytoma | 1 year | Other Glioma ∼ 73 (9 AA and 2 Oligodendroglioma) (N=11) | | PFS for glioblastoma multiforme compared to other histotypes (AA and ODG) were significantly worse P=.008 | Massimino, 2005
Astrocytoma | 1 year | | Median AA PFS 21.2mo (1.2-49.3) (N=4) | | Hurwitz, 2001
Astrocytoma | 1 year | | 1 OA patient progressed shortly after chemotherapy and received irradiation (33% of OA) (N=6) | | Doireau, 1999
Astrocytoma | 1 year | 2 patients progressed at 4.5 and 5.5 months (N=2) | | | Jakacki, 1999
Astrocytoma | 1 year | 1 patient progressed at 11 mo (N=1) | | | Busca, 1997
Astrocytoma | 3 Year | AA/GBM PFS: 22±7% (These HSCT and chemotherapy estimates are grouped EFS for astrocytoma and glioblastoma multiforme) (N=27) | AA/GBM year PFS 0% (N=56) | Chemo versus ABMR unstratified comparison of event-free survival: P=0.014 | Finlay, 2008
Astrocytoma | 3 Year | Other Glioma ∼ 73 (9 AA and 2 Oligodendroglioma) (N=11) | | PFS for glioblastoma multiforme compared to other histotypes (AA and ODG) were significantly worse P=.008 | Massimino, 2005
Astrocytoma | 5 Year | AA/GBM PFS: 22±7% (These HSCT and chemotherapy estimates are grouped EFS for astrocytoma and glioblastoma multiforme) (N=27) | AA/GBM year PFS 0% (N=56) | Chemo versus ABMR unstratified comparison of event-free survival: P=0.014 | Finlay, 2008
Astrocytoma | 5 Year | Other Glioma ∼ 73 (9 AA and 2 Oligodendroglioma) (N=11) | | PFS for glioblastoma multiforme compared to other histotypes (AA and ODG) were significantly worse P=.008 | Massimino, 2005
Glioblastoma Multiforme | 1 Year | AA/GBM PFS: 22±7% (These HSCT and chemotherapy estimates are grouped EFS for astrocytoma and glioblastoma multiforme) This AA PFS remained constant up to 5-years follow up (N=27) | 1 AA/GBM year PFS 0% (N=56) | Chemo versus ABMR unstratified comparison of event-free survival: P=0.014 | Finlay, 2008
Glioblastoma Multiforme | 1 Year | | 2 patients progressed at 1 and 4.2 mo (N=2) | | Shih, 2008
Glioblastoma Multiforme | 1 Year | | Median 6 mo (5-12) (86) 1 patient is alive without progression at 15+ mo (N=5) | | Korones, 2006
Glioblastoma Multiforme | 1 Year | | 1 patient progressed at 11mo (N=1) | | Sio, 2006
Glioblastoma Multiforme | 1 Year | ∼40 (N=10) | | PFS for glioblastoma multiforme compared to other histotypes (AA and ODG) were significantly worse P=.008 | Massimino, 2005
Glioblastoma Multiforme | 1 Year | 64±14 (N=11) | | | Grovas, 1999
Glioblastoma Multiforme | 1 Year | 4 patients progressed at 2, 3, 4 and 7 months (N=4) | | | Jakacki, 1999
Glioblastoma Multiforme | 1 Year | 1 patient was alive with no progression at last FU (N=1) | | | Busca, 1997
Glioblastoma Multiforme | 3 Year | AA/GBM PFS: 22±7% (These HSCT and chemotherapy estimates are grouped EFS for astrocytoma and glioblastoma multiforme) This AA PFS remained constant up to 5-years follow up (N=27) | 1 AA/GBM year PFS 0% (N=56) | Chemo versus ABMR unstratified comparison of event-free survival: P=0.014 | Finlay, 2008
Glioblastoma Multiforme | 3 Year | ∼20 (N=10) | | PFS for glioblastoma multiforme compared to other histotypes (AA and ODG) were significantly worse P=.008 | Massimino, 2005
Glioblastoma Multiforme | 3 Year | 2 year PFS: 46±14 (N=11) | | | Grovas, 1999
Glioblastoma Multiforme | 3 Year | 1 patient progressed at 34months (N=1) | | | Mahoney, 1996
Glioblastoma Multiforme | 5 Year | AA/GBM PFS: 22±7% (These HSCT and chemotherapy estimates are grouped EFS for astrocytoma and glioblastoma multiforme) This AA PFS remained constant up to 5-years follow up (N=27) | 1 AA/GBM year PFS 0% (N=56) | Chemo versus ABMR unstratified comparison of event-free survival: P=0.014 | Finlay, 2008
Glioblastoma Multiforme | 5 Year | 0 (N=10) | | PFS for glioblastoma multiforme compared to other histotypes (AA and ODG) were significantly worse P=.008 | Massimino, 2005
Anaplastic Ependymoma | 1 Year | | 91% (76-100%) (N=12) | Neurosurgical estimate of GTR vs. < GTR, P=.0001 Post-op radiographic residual tumor 1.5cm^2^ vs < 1.5cm^2^, P<.0001 No difference found for anaplastic vs. non-anaplastic progression | Robertson, 1998
Anaplastic Ependymoma | 1 Year | 1 patient progressed at 27 mo (25) (N=4) | | | Ayan, 1995
Anaplastic Ependymoma | 3 Year | | 65% (38-93%) (N=12) | Neurosurgical estimate of GTR vs. < GTR, P=.0001 Post-op radiographic residual tumor 1.5cm^2^ vs < 1.5cm^2^, P<.0001 No difference found for anaplastic vs. non-anaplastic progression | Robertson, 1998
Anaplastic Ependymoma | 5 Year | | 35.2±11.0% (N=23) | Grade II vs. anaplastic P=.005 | Jaing, 2004
Anaplastic Ependymoma | 5 Year | | ∼14% (N=31) | | Horn, 1999
Anaplastic Ependymoma | 5 Year | | Complete resection 70% (± 14) (N=10) incomplete resection 36% (± 15) I (N=11) 52% (±11) all anaplastic ependymoma (N=21) | Resection: P=.09 | Kuhl, 1998
Anaplastic Ependymoma | 5 Year | | 47% (17-61%) (N=12) | Neurosurgical estimate of GTR vs. < GTR, P=.0001 Post-op radiographic residual tumor 1.5cm^2^ vs < 1.5cm^2^, P<.0001 No difference found for anaplastic vs. non-anaplastic progression | Robertson, 1998
Non-anaplastic, mixed, or unspecified Ependymoma | 1 Year | | ∼88 (N=23) | Complete vs. partial resection not significant | Conter, 2009
Non-anaplastic, mixed, or unspecified Ependymoma | 1 Year | | 2 patients progressed at 1 mo and 1 at 1.4 mo (N=2) | | Shih, 2008
Non-anaplastic, mixed, or unspecified Ependymoma | 1 Year | | Non-metastatic: ∼87% (N=80) Metastatic ∼62.5% (N=9) | | Grundy, 2007
Non-anaplastic, mixed, or unspecified Ependymoma | 1 Year | ∼63% (N=29) | | EFS across the three age groups: <18 months, 18–35 months and 36 months significant difference P=0.04 GTR vs <GTR not significant | Zacharoulis, 2007
Non-anaplastic, mixed, or unspecified Ependymoma | 1 Year | | 2 patients progressed at 2 and 3 mo (N=2) | | Sio, 2006
Non-anaplastic, mixed, or unspecified Ependymoma | 1 Year | | ∼92% (N=64) | | Merchant, 2002
Non-anaplastic, mixed, or unspecified Ependymoma | 1 Year | | | Median 2.1mo (.0-30.3) (N=13) | Hurwitz, 2001
Non-anaplastic, mixed, or unspecified Ependymoma | 1 Year | | 56% (N=73) | Posterior Fossa Tumor RR 2.1 (1-2.5) P=.05 Postoperative radiologic documented residuum RR 2.9 (1.6-5.1) P=.0004 | Grill, 2001
Non-anaplastic, mixed, or unspecified Ependymoma | 1 Year | ∼22 (N=15) | | | Mason, 1998
Non-anaplastic, mixed, or unspecified Ependymoma | 1 Year | 57 (31-83 95% CI) (N=14) | | | Grill, 1996
Non-anaplastic, mixed, or unspecified Ependymoma | 1 Year | 1 patient progressed at 12 mo (N=7) | | | Mahoney, 1996
Non-anaplastic, mixed, or unspecified Ependymoma | 1 Year | 75% (56-95%) (N=20) | | Neurosurgical estimate of GTR vs. < GTR, P=.0001 Post-op radiographic residual tumor 1.5cm^2^ vs < 1.5cm^2^, P<.0001 No difference found for anaplastic vs. non-anaplastic progression | Robertson, 1995
Non-anaplastic, mixed, or unspecified Ependymoma | 3 Year | | 3 year PFS: 62.5 54.2 (N=23) | Complete vs. partial resection not significant | Conter, 2009
Non-anaplastic, mixed, or unspecified Ependymoma | 3 Year | | metastatic: ∼46% (N=80) Metastatic 0% (N=9) | | Grundy, 2007
Non-anaplastic, mixed, or unspecified Ependymoma | 3 Year | ∼28% (N=29) | | EFS across the three age groups: <18 months, 18–35 months and 36 months significant difference P=0.04 GTR vs <GTR not significant | Zacharoulis, 2007
Non-anaplastic, mixed, or unspecified Ependymoma | 3 Year | | :∼71% (N=64) | | Merchant, 2002
Non-anaplastic, mixed, or unspecified Ependymoma | 3 Year | | 23% (N=73) | Posterior Fossa Tumor RR 2.1 (1-2.5) P=.05 Postoperative radiologic documented residuum RR 2.9 (1.6-5.1) P=.0004 | Grill, 2001
Non-anaplastic, mixed, or unspecified Ependymoma | 3 Year | 0% (N=15) | | | Mason, 1998
Non-anaplastic, mixed, or unspecified Ependymoma | 3 Year | 27 (0-55 95% CI) (N=14) | | | Grill, 1996
Non-anaplastic, mixed, or unspecified Ependymoma | 3 Year | 54% (31-76%) (N=20) | | Neurosurgical estimate of GTR vs. < GTR, P=.0001 Post-op radiographic residual tumor 1.5cm^2^ vs < 1.5cm^2^, P<.0001 No difference found for anaplastic vs. non-anaplastic progression | Robertson, 1995
Non-anaplastic, mixed, or unspecified Ependymoma | 5 Year | | 54.2% (N=23) | Complete vs. partial resection not significant | Conter, 2009
Non-anaplastic, mixed, or unspecified Ependymoma | 5 Year | | Non-metastatic: ∼39% (N=80) Metastatic 0% (N=9) | | Grundy, 2007
Non-anaplastic, mixed, or unspecified Ependymoma | 5 Year | | Grade II: 67.5±11.0% (N=20) Age<3 (N=9) 22.2±13.9 Age>3 (N=34): 52.2±9% GTR (N=18): 71.8±10.7% STR (N=19): 30.7±11.3 Biopsy (N=6): 16.7±15.2% RT involved field (N=31) 52.3±9.3% RT without involved field (N=12): 31.3±14% | Gr II vs. Anaplastic P=.002 Age: P=.005 Surgical Resection: P<.001 Radiotherapy: P=.029 | Jaing, 2004
Non-anaplastic, mixed, or unspecified Ependymoma | 5 Year | | 12% (N=73) | Posterior Fossa Tumor RR 2.1 (1-2.5) P=.05 Postoperative radiologic documented residuum RR 2.9 (1.6-5.1) P=.0004 | Grill, 2001
Non-anaplastic, mixed, or unspecified Ependymoma | 5 Year | | Overall: 42.2±5.5% (N=83) <3 years (N=29) ∼18 3 years (N=54): ∼56 <GTR (N=48): ∼23 GTR (N=35): ∼71 Grade II (N=51): ∼53 | Age<3, Age >3: P<.01 Gender: P<.01 GTR: P<.01 Residual Disease by scan: P<.01 Histology Gr II vs Gr III: P<.01 | Horn, 1999
Non-anaplastic, mixed, or unspecified Ependymoma | 5 Year | | 54% (31-76%) (N=20) | Neurosurgical estimate of GTR vs. < GTR, P=.0001 Post-op radiographic residual tumor 1.5cm^2^ vs < 1.5cm^2^, P<.0001 No difference found for anaplastic vs. non-anaplastic progression | Robertson, 1998
Non-anaplastic, mixed, or unspecified Ependymoma | 5 Year | 2 patients alive with no disease progression at last follow up (N=2) | | | Busca, 1997
Non-anaplastic, mixed, or unspecified Ependymoma | 5 Year | 14 (0-37 95% CI) (N=14) | | | Grill, 1996
CPC | 1 Year | | 28.9% (9.0-48.0)% (N=15) | | Grundy, 2010
CPC | 1 Year | | ∼56% (N=29) | CPC vs. CPP/APP HR=15.2, P<.0001 Chemotherapy yes vs. no, HR=6.4, P=.004 | Wrende, 2009
CPC | 1 Year | 1 patient progressed at 4 months (N=1) | | | Gururangan, 1998
CPC | 3 Year | | 28.9% (9.0-48.0)% (N=15) | | Grundy, 2010
CPC | 3 Year | | ∼56% (N=29) | CPC vs. CPP/APP HR=15.2, P<.0001 Chemotherapy yes vs. no, HR=6.4, P=.004 | Wrende, 2009
CPC | 5 Year | | 21.7(5.3-45.1)% (N=15) | CPC vs. CPP/APP HR=15.2, P<.0001 Chemotherapy yes vs. no, HR=6.4, P=.004 | Grundy, 2010
CPC | 5 Year | | ∼36% (N=29) | 28 (7-100)% (N=29) | Wrende, 2009
Other Glioma | 1 Year | | HGG: 52.6 (33.2-763) (N=19) | | Grundy, 2010
Other Glioma | 1 Year | 1 patient with oligodendroglioma progressed at 8 mo. (N=1) 1 patients with anaplastic glioma progressed at 3 mo(N=3) | | | Thorarinsdottir, 2007
Other Glioma | 1 Year | | BSG Median 1 mo (0-5 mo 95% CI) BSG 13 (0-35% 95% CI) (N=8) | | Sio, 2006
Other Glioma | 1 Year | | 1 BSG patient progressed at 4 months, one at 8 months (N=2) | | Korones, 2006
Other Glioma | 1 Year | 1 year PFS: Other Glioma ∼ 73 (9 AA and 2 Oligodendroglioma) (N=11) | | PFS for glioblastoma multiforme compared to other histotypes (AA and ODG) were significantly worse P=.008 | Massimino, 2005
Other Glioma | 1 Year | | BSG median 2.9mo (.1-19.8) (N=15) Malignant glioma Median 1.4mo (.4-7.2) (N=13) Miscellaneous glioma median 2.1mo (.6-12.9) (N=12) | | Hurwitz, 2001
Other Glioma | 1 Year | 1 year PFS Pontine glioma ∼3 (N=35) | | | Bouffet, 1999
Other Glioma | 1 Year | 5 Pontine glioma patients progressed Median 5 mo (3-12) (N=6) 1 patient was progression free at 12 months. (N=6) | | | Jakacki, 1999
Other Glioma | 1 Year | 1 ODG patient was alive and progression free at last follow up (N=1) | | | Busca, 1997
Other Glioma | 1 Year | 1 BSG patient progressed at 1 mo (N=1) | | | Mahoney, 1996
Other Glioma | 3 Year | | HGG: 24.1(7.8-45.1) (N=19) | | Grundy, 2010
Other Glioma | 3 Year | 2 patients with anaplastic glioma progressed at 17, and 33.5 mo (N=3) | | | Thorarinsdottir, 2007
Other Glioma | 3 Year | | BSG 0 | | Sio, 2006
Other Glioma | 3 Year | 3 year PFS: Other Glioma ∼ 73 (9 AA and 2 Oligodendroglioma) (N=11) | | PFS for glioblastoma multiforme compared to other histotypes (AA and ODG) were significantly worse P=.008 | Massimino, 2005
Other Glioma | 5 Year | | HGG: 18.1 (4.6-38.6) (N=19) | | Grundy, 2010
Other Glioma | 5 Year | 1 patient with ganglioma progressed at 59 mo (N=1) | | | Thorarinsdottir, 2007
Other Glioma | 5 Year | 5 year PFS: Other Glioma ∼ 73 (9 AA and 2 Oligodendroglioma) (N=11) | | PFS for glioblastoma multiforme compared to other histotypes (AA and ODG) were significantly worse P=.008 | Massimino, 2005
Other Glioma | 5 Year | | Malignant Glioma 36 ± 10 (N=22) | | Kuhl, 1998
Astrocytoma | 1 year PFS N ≥ 10 | Recurrent/Progressive: ∼30% (Finlay N=27) [This estimate includes glioblastoma multiforme tumor types] Measured from time of myeloablative chemotherapy | Recurrent/Progressive: ∼10 (Finlay N=56) [This estimate includes glioblastoma multiforme tumor types] Finlay et al measured from time of tumor recurrence
Astrocytoma | 1 year PFS N ≥ 10 | Newly Diagnosed: ∼73%* (Massimo, 2005) [*This study included 9 Anaplastic Astrocytoma patients and 2 lower-grade oligodendroglioma patients.] Massimo measured from time of diagnosis
Glioblastoma Multiforme | 1 year PFS N ≥ 10 | Recurrent/Progressive: ∼30% (Finlay N=27*) [*This estimate includes anaplastic astrocytoma tumor types] Measured from time of myeloablative chemotherapy | Recurrent/Progressive: ∼10-42% (Finlay* N=56, Korones** N=7) [*This estimate includes glioblastoma multiforme tumor types, ** 1 patient DOD before progression] Finlay et al measured from time of tumor recurrence Korones time measurement uncertain
Glioblastoma Multiforme | 1 year PFS N ≥ 10 | Newly Diagnosed: Grovas measured from time of stem cell rescue Massimo considered OS from date of chemotherapy 64 Grovas (N=11) ∼40 Massimo (N=10) | Recurrent/Progressive: (Korones N=7) 14%
Ependymoma | 5 year PFS for studies with N ≥10 patients | Newly Diagnosed 12% (Zacharoulis (N=29)) Zacharoulis estimated PFS from date of diagnosis | Newly Diagnosed Non-anaplastic, mixed, or unspecified Ependymoma: 12-67% (Conter (N=23), Grill,2001 (N=73), Horn (N=51), Jaing (N=20), Robertson (N=20)) Conter and Jaing estimated OS from date of surgery, Grill measured from date of chemotherapy, Robertson measured from date of randomization, and horn measured from date of diagnosis. Newly Diagnosed Anaplastic Ependymoma: 14-52% (Jaing (N=23) , Horn (N=31), Kuhl (N=21), Robertson (N=12)) Jaing used date of surgery for PFS calculation, Horn used date of diagnosis, Kuhl used date of chemotherapy, and Robertson used date of randomization | | Grundy et al. was not included in this estimate because the study stratified by metastasis finding a 5 year PFS of 0% for metastatic ependymoma and 46% for non-metastatic disease and measured the PFS from date of surgery.
Ependymoma | 5 year PFS for studies with N ≥10 patients | Recurrent/Progressive: 14% (Grill, 1996 (N=14)) Grill measured PFS from date of autologous bone marrow transplant | | | Grundy et al. was not included in this estimate because the study stratified by metastasis finding a 5 year PFS of 0% for metastatic ependymoma and 46% for non-metastatic disease and measured the PFS from date of surgery.
CPC | 5 Year PFS All studies: | 1 patient progressed at 4 mo (Gururangan (N=1)) Gururangan assessed EFS after myeloablative chemotherapy | 21.7-36% (Grundy (N=15) and Wrede (N=29)) Wrede measured EFS from date of diagnosis and Grundy used date of surgery

AA= anaplastic ependymoma, AWD= Alive with disease, BSG, Brain stem glioma; CPC, Choroid plexus carcinoma; DOD=Dead of disease, GBM=Glioblastoma multiforme; HGG, high-grade glioma