# Systematic Review Data Abstraction

Appendix Table C1 Design, participant selection and enrollment: Ewing's tumors

Appendix Table C2 Participant characteristics:Treatment, Ewing's tumors

Appendix Table C3 Participant characteristics: Comparator, Ewing's tumors

Appendix Table C4 Treatment characteristics: Ewing's tumors

Appendix Table C5 Outcome assessment: Treatment, Ewing's tumors

Appendix Table C6 Outcome assessment: Comparator, Ewing's tumors

Appendix Table C7 Time to event outcomes: Treatment, Ewing's tumors

Appendix Table C8 Time to event outcomes: Comparator, Ewing's tumors

Appendix Table C9 Adverse events: Treatment, Ewing's tumors

Appendix Table C10 Adverse events: Comparator, Ewing's tumors

Appendix Table C11 Design, participant selection and enrollment: Wilm's tumor

Appendix Table C12 Participant characteristics: Treatment, Wilm's tumor

Appendix Table C13 Participant characteristics: Comparator, Wilm's tumor

Appendix Table C14 Treatment characteristics: Wilm's tumor

Appendix Table C15 Outcome assessment: Treatment, Wilm's tumor

Appendix Table C16 Outcome assessment: Comparator, Wilm's tumor

Appendix Table C17 Time to event outcomes: Treatment, Wilm's tumor

Appendix Table C18 Time to event outcomes: Comparator, Wilm's tumor

Appendix Table C19 Adverse events: Treatment, Wilm's tumor

Appendix Table C20 Adverse events: Comparator, Wilm's tumor

Appendix Table C21 Design, participant selection and enrollment: Rhabdomyosarcoma

Appendix Table C22 Participant characteristics: Treatment, rhabdomyosarcoma

Appendix Table C23 Participant characteristics: Comparator, rhabdomyosarcoma

Appendix Table C24 Treatment characteristics: Rhabdomyosarcoma

Appendix Table C25 Outcome assessment: Treatment, rhabdomyosarcoma

Appendix Table C26 Outcome assessment: Comparator, rhabdomyosarcoma

Appendix Table C27 Time to event outcomes: Treatment, rhabdomyosarcoma

Appendix Table C28 Time to event outcomes: Comparator, rhabdomyosarcoma

Appendix Table C29 Adverse events: Treatment, rhabdomyosarcoma

Appendix Table C30 Adverse events: Comparator, rhabdomyosarcoma

Appendix Table C31 Design, participant selection and enrollment: Retinoblastoma

Appendix Table C32 Participant characteristics: Treatment, retinoblastoma

Appendix Table C33 Participant characteristics: Comparator, retinoblastoma

Appendix Table C34 Treatment characteristics: Retinoblastoma

Appendix Table C35 Outcome assessment: Treatment, retinoblastoma

Appendix Table C36 Outcome assessment: Comparator, retinoblastoma

Appendix Table C37 Time to event outcomes: Treatment, retinoblastoma

Appendix Table C38 Time to event outcomes: Comparator, retinoblastoma

Appendix Table C39 Adverse events: Treatment, retinoblastoma

Appendix Table C40 Adverse events: Comparator, retinoblastoma

Appendix Table C41 Design, participant selection and enrollment: Neuroblastoma

Appendix Table C42 Participant characteristics: Treatment, neuroblastoma

Appendix Table C43 Participant characteristics: Comparator, neuroblastoma

Appendix Table C44 Treatment characteristics: Neuroblastoma

Appendix Table C45 Outcome assessment: Treatment, neuroblastoma

Appendix Table C46 Outcome assessment: Comparator, neuroblastoma

Appendix Table C47 Time to event outcomes: Treatment, neuroblastoma

Appendix Table C48 Time to event outcomes: Comparator, neuroblastoma

Appendix Table C49 Time to event outcomes: Regression modeling, neuroblastoma

Appendix Table C50 Adverse events: Treatment, neuroblastoma

Appendix Table C51 Adverse events: Comparator, neuroblastoma

Appendix Table C52 Design, participant selection and enrollment: Germ cell tumor

Appendix Table C53 Participant characteristics: Treatment, germ cell tumor

Appendix Table C54 Participant characteristics: Comparator, germ cell tumor

Appendix Table C55 Treatment characteristics: Germ cell tumor

Appendix Table C56 Outcome assessment: Treatment, germ cell tumor

Appendix Table C57 Outcome assessment: Comparator, germ cell tumor

Appendix Table C58 Time to event outcomes: Treatment, germ cell tumor

Appendix Table C59 Time to event outcomes: Comparator, germ cell tumor

Appendix Table C60 Adverse events: Treatment, germ cell tumor

Appendix Table C61 Adverse events: Comparator, germ cell tumor

Appendix Table C62 Design, participant selection and enrollment: Embryonal tumors

Appendix Table C63 Participant characteristics: Treatment, embryonal tumors

Appendix Table C64 Participant characteristics: Comparator, embryonal tumors

Appendix Table C65 Treatment characteristics: Embryonal tumors

Appendix Table C66 Outcome assessment: Treatment, embryonal tumors

Appendix Table C67 Outcome assessment: Comparator, embryonal tumors

Appendix Table C68 Time to event outcomes: Treatment, embryonal tumors

Appendix Table C69 Time to event outcomes: Comparator, embryonal tumors

Appendix Table C70 Quality of life: Embryonal tumors

Appendix Table C71 Adverse events: Treatment, embryonal tumors

Appendix Table C72 Adverse events: Comparator, embryonal tumors

Appendix Table C73 Design, participant selection and enrollment: Glial tumors

Appendix Table C74 Participant characteristics: Treatment, glial tumors

Appendix Table C75 Participant characteristics: Comparator, glial tumors

Appendix Table C76 Treatment characteristics: Glial tumors

Appendix Table C77 Outcome assessment: Treatment, glial tumors

Appendix Table C78 Outcome assessment: Comparator, glial tumors

Appendix Table C79 Time to event outcomes: Treatment, glial tumors OS

Appendix Table C80 Time to event outcomes: Comparator, glial tumors OS

Appendix Table C81 Time to event outcomes: Comparator, glial tumors PFS

Appendix Table C82 Neurological outcomes : Glial tumors

Appendix Table C83 Adverse events: Treatment, glial tumors

Appendix Table C84 Adverse events: Comparator, glial tumors

Appendix Table C85 Design, participant selection and enrollment: Inherited metabolic diseases

Appendix Table C86 Participant characteristics: Treatment, inherited metabolic diseases

Appendix Table C87 Participant characteristics: Comparator, inherited metabolic diseases

Appendix Table C88 Treatment characteristics: Inherited metabolic diseases

Appendix Table C89 Outcome assessment: Treatment, inherited metabolic diseases

Appendix Table C90 Outcome assessment: Comparator, inherited metabolic diseases

Appendix Table C91 Time to event outcomes: Treatment, inherited metabolic diseases

Appendix Table C92 Time to event outcomes: Comparator, inherited metabolic diseases

Appendix Table C93 Neurocognitive/neuropsychological outcomes: Inherited metabolic diseases

Appendix Table C94 Adverse events: Treatment, inherited metabolic diseases

Appendix Table C95 Adverse events: Comparator, inherited metabolic diseases

Appendix Table C96 Design, participant selection and enrollment: Autoimmune disease

Appendix Table C97 Participant characteristics: Treatment, autoimmune disease

Appendix Table C98 Participant characteristics: Comparator, autoimmune disease

Appendix Table C99 Treatment characteristics: Autoimmune disease

Appendix Table C100 Outcome assessment: Treatment, autoimmune disease

Appendix Table C101 Outcome assessment: Comparator, autoimmune disease

Appendix Table C102 Time to event outcomes: Treatment, autoimmune disease

Appendix Table C103 Time to event outcomes: Comparator, autoimmune disease