# Excluded Studies

[underlined: Retrieval Code] (field 12)

DNG | do not retrieve full copy
GET | retrieve full copy
UNC | uncertain; needs check by second reviewer

[underlined: Two Arms of Study Code] (field 12)

NAR | narrative review portion
SYS | systematic review portion

[underlined: Selection Decision Code] (after reviewing retrieved article, enter into field 12)

INC | include
EXC | exclude (with codes for exclusion reasons)

[underlined: Full Review Codes] (field 42)

I Key Question Codes

NRQ | not relevant question (note if ANM, NDE, NRD, NRI, NRO)
Q1 | comparative benefits HSCT vs Ctx in solid tumors
Q2 | comparative harms HSCT vs Ctx in solid tumors
Q3 | comparative benefits HSCT vs other Tx in IMD
Q4 | comparative harms HSCT vs other Tx in IMD
Q5 | comparative benefits HSCT vs other Tx in autoimmune diseases
Q6 | comparative harms HSCT vs other Tx in autoimmune diseases
Q#? | unclear if relevant to any key question

II Study Design Codes

ADB | administrative database
ANM | animal study
CEA | cost/cost-effectiveness analysis
CCS | case-control study
COH | cohort study
COM | noteary
CR | case report (n≤5)
CS | case series
D? | design unclear/possibly relevant
DAC | diagnostic accuracy study
DUP | duplicated patient population
EDT | editorial
FLA | foreign language article
GUI | guideline
INV | in vitro
LTR | letter
MA | meta-analysis
NAB | no abstract
NPC | not relevant comparator
NPD | no primary data
NRD | not relevant disease
NR | not relevant disease b/c part of narrative review
NRE | not relevant design
NRI | not relevant intervention
NRO | not relevant outcome (or no follow-up)
NRP | not relevant population
NRS | not relevant study
PI | phase I trial
PII | phase II trial
PRG | prognostic study
PRO | prospective single-arm study
QEX | quasi-experimental study (nonrandomized comparative)
RAD | radiology study
RCT | randomized controlled trial
REG | registry
RET | retrospective study
REV | review article
SR | systematic review
STG | disease staging study
XSL | cross-sectional study

III Sample Size Code (single-arm only)

FEW | n < 10
N10 | 10 ≤ n < 25
N25 | 25 ≤ n < 50
N50 | 50 ≤ n < 100
N100 | n ≥ 100
N? | n unclear

IV Basic Disease Codes

AID | Autoimmune disease
ALD | adrenoleukodystrophy
ALL | acute lymphoblastic leukemia
AMA | alpha-mannosidosis
AML | acute myelogenous leukemia
AMN | adrenomyeloneuropathy
ASP | aspartylglucosaminuria
AST | astrocytoma
BMA | beta-mannosidosis
BMF | bone marrow failure
CLF | ceroid lipofuscinosis
CLL | chronic lymphocytic leukemia
CML | chronic myelogenous leukemia
CNS | CNS tumors, NOS
CRN | Crohn's
CYS | cystinosis
DME | Diabetes mellitus type 1
DNS | disease not specified
ESF | Ewing/Ewing sarcoma family of tumors
ENV | Evan's syndrome
FAB | Fabry disease
FAR | Farber disease
FUC | Fucosidosis
GAL | galactosialidosis
GAUI | Gaucher I
GAUII | Gaucher II
GAUIII | Gaucher III
GCT | germ cell tumor
GLD | globoid leukodystrophy
GM1 | GM_1_ gangliosidosis
GSDII | glycogen storage disease II
HGB | hemoglobinopathy
HL | Hodgkin lymphoma
IBD | inflammatory bowel disease
ICP | immune cytopenia
IMD | inherited metabolic disease
JML | juvenile myelomonocytic leukemia
JRA | juvenile rheumatoid arthritis
MDS | myelodysplasia
MED | medulloblastoma
MLII | mucolipidosis II
MLIII | mucolipidosis III
MLIV | mucolipidosis IV
MLD | metachromatic leukodystrophy
MPSI | Hurler syndrome
MPSII | Hunter syndrome
MPSIII | Sanfilippo syndrome
MPSIV | Morquio syndrome
MPSVI | Maroteaux-Lamy syndrome
MPSVII | Sly syndrome
NBL | neuroblastoma
NHL | non-Hodgkin lymphoma
NPA | Niemann-Pick A
NPB | Niemann-Pick B
NPC | Niemann-Pick C
OSC | osteosarcoma
OST | osteopetrosis
PID | primary immune deficiency
PNET | primitive neuroectodermal tumor
RBA | retinoblastoma
RMS | rhabdomyosarcoma
SAL | Salla disease
SAN | Sandhoff disease
SAS | sialic acid storage disease
SCL | scleroderma/SS
SLE | systemic lupus erythematosus
STG | stage of disease
STS | soft tissue sarcoma
TAY | Tay-Sachs disease
WIL | Wilms tumor
WOL | Wolman disease

IV Disease code modifiers

HR | high risk
LR | low risk
MET | metastatic
NEW | newly diagnosed
PRD | progressive disease
REC | recurrent disease
REF | refractory
REL | relapsed
REM | remission
SEV | severe
STG | stage of disease

V Disease Code Characteristics

GRW | growth
HRD | hearing defects
HSM | hepatosplenomegaly
IQ | intelligence quotient
JNT | joint
MR | mental retardation
NCD | neurocognitive development
NMD | neuromuscular development
ORT | orthopedic/skeletal
SOH | state of health
SPE | speech
SZS | seizures

V Intervention Codes

AUT | autologous HSCT
ALO | allogeneic HSCT
BSC | best supportive care
CHM | chemotherapy
CRT | chemoradiotherapy
ERT | enzyme replacement therapy
HSCT | hematopoietic stem cell transplantation
IMM | immune suppression
INS | insulin therapy
PAL | palliative
PRI | primary treatment (previously untreated)
SEQ | sequential high-dose chemotherapy with single autologous HSCT
SUR | surgery only
T? | treatment unclear
TAN | tandem autologous HSCT
TBI | total body irradiation
UMB | umbilical cord blood HSCT

VI Outcome Codes

CNR | continuous remission
CRM | complete remission
CVS | cardiovascular AE
DFR | drug free remission
DFS | disease-free survival
DSS | (cancer) disease-specific survival
EFS | event free survival
ENG | engraftment
ESO | esophagus AEs
FU? | follow-up uncertain
GVH | graft versus host disease
INF | infection
HEM | hematologic toxicities
HEP | hepatic AEs
HRT | heart AEs
LC | local control
LNG | lung AEs
LRC | locoregional control
MFS | (distant) metastasis-free survival
MIR | minor response
MUC | mucositis
NV | nausea/vomiting
OAE | other AE
OS | overall survival
OTE | other time-to-event outcome
OTO | otologic/auditory AEs
O? | outcome unclear
PFS | progression-free survival
PR | partial remission
PRD | progressive disease
QOL | quality of life
RFS | recurrence free survival
REN | renal toxicities
RET | retinopathy
RSP | tumor response
SEL | serum enzyme levels
SKN | skin AEs
STD | stable disease
TAE | toxicity/adverse events (not specified)
TRM | treatment-related mortality
TTR | time-to-recurrence
VPR | very good partial response

## Excluded Studies: Original Review

[No Author]. Effect of intensive diabetes treatment on the development and progression of long-term complications in adolescents with insulin-dependent diabetes mellitus: Diabetes Control and Complications Trial. Diabetes Control and Complications Trial Research Group. J Pediatr. 1994;125(2):177-88. [pmid: 8040759]. Rec#: 75370 Reprint: exc nrp
[No Author]. Adverse events and their association with treatment regimens in the diabetes control and complications trial. Diabetes Care. 1995;18(11):1415-27. [pmid: 8722064]. Rec#: 62830 Reprint: exc nrp
[No Author]. Early worsening of diabetic retinopathy in the Diabetes Control and Complications Trial. Arch Ophthalmol. 1998;116(7):874-86. [pmid: 9682700]. Rec#: 62640 Reprint: exc nrp
[No Author]. Effect of intensive therapy on residual beta-cell function in patients with type 1 diabetes in the diabetes control and complications trial. A randomized, controlled trial. The Diabetes Control and Complications Trial Research Group. Ann Intern Med. 1998;128(7):517-23. [pmid: 9518395]. Rec#: 62660 Reprint: exc nrp
[No Author]. Retinopathy and nephropathy in patients with type 1 diabetes four years after a trial of intensive therapy. The Diabetes Control and Complications Trial/Epidemiology of Diabetes Interventions and Complications Research Group. N Engl J Med. 2000;342(6):381-9. [pmid: 10666428]. Rec#: 62520 Reprint: exc nrp
Abbott IR, Gaskill SJ, Hayes TC, Menick BJ. 28-Month-Old girl with delayed ambulation and speech. Pediatr Neurosurg. 2000;33(3):162-6. [pmid: 11096364]. Rec#: 76430 Reprint: exc nro
Abd El-Aal H. Role of radio-iodinated meta-iodo benzyl guanidine in assessment of children with neuroblastoma at NEMROCK. J Egypt Natl Canc Inst. 2006;18(4):375-81. [pmid: 18301461]. Rec#: 2370 Reprint: exc nrp
Abdel-Haq N, Savasan S, Davis M, Asmar BI, Painter T, Salimnia H. Asaia lannaensis bloodstream infection in a child with cancer and bone marrow transplantation. 2009. Rec#: 110 Reprint: exc nro
Aberg L, Kirveskari E, Santavuori P. Lamotrigine therapy in juvenile neuronal ceroid lipofuscinosis. Epilepsia. 1999;40(6):796-9. [pmid: 10368082]. Rec#: 58000 Reprint: exc nri
Aberg LE, Backman M, Kirveskari E, Santavuori P. Epilepsy and antiepileptic drug therapy in juvenile neuronal ceroid lipofuscinosis. Epilepsia. 2000;41(10):1296-302. [pmid: 11051125]. Rec#: 57870 Reprint: exc nri
Adams C, August CS, Maguire H, Sladky JT. Neuromuscular complications of bone marrow transplantation. Pediatr Neurol. 1995;12(1):58-61. [pmid: 7748363]. Rec#: 22300 Reprint: EXC NRS
Adkins ES, Sawin R, Gerbing RB, London WB, Matthay KK, Haase GM. Efficacy of complete resection for high-risk neuroblastoma: a Children's Cancer Group study. J Pediatr Surg. 2004;39(6):931-6. [pmid: 15185228]. Rec#: 8730 Reprint: exc nri
Al Salloum AA. Cyclophosphamide therapy for lupus nephritis: poor renal survival in Arab children. Pediatr Nephrol. 2003;18(4):357-61. [pmid: 12700962]. Rec#: 41890 Reprint: exc nri
Albert MH, Schuster F, Peters C, Schulze S, Pontz BF, Muntau AC, Roschinger W, Stachel DK, Enders A, Haas RJ, Schmid I. T-cell-depleted peripheral blood stem cell transplantation for alpha-mannosidosis. Bone Marrow Transplant. 2003;32(4):443-6. [pmid: 12900784]. Rec#: 10090 Reprint: exc nr
Alex J, Bahl MJ, Schlueter AJ. Peripheral blood stem cell recovery following early termination of apheresis due to hypotension in a 4.8-kg infant. J Clin Apher. 2009;24(3):120-1. [pmid: 19253358]. Rec#: 470 Reprint: exc nri
Al-Fifi SH. Intensive insulin treatment versus conventional regimen for adolescents with type 1 diabetes, benefits and risks. Saudi Med J. 2003;24(5):485-7. [pmid: 12847622]. Rec#: 62320 Reprint: exc nrs
Allen JC, Donahue B, DaRosso R, Nirenberg A. Hyperfractionated craniospinal radiotherapy and adjuvant chemotherapy for children with newly diagnosed medulloblastoma and other primitive neuroectodermal tumors. Int J Radiat Oncol Biol Phys. 1996;36(5):1155-61. [pmid: 8985038]. Rec#: 20010 Reprint: exc nri
Allison JW, James CA, Arnold GL, Stine KC, Becton DL, Bell JM. Reconversion of bone marrow in Gaucher disease treated with enzyme therapy documented by MR. Pediatr Radiol. 1998;28(4):237-40. [pmid: 9545478]. Rec#: 18040 Reprint: exc dac
al-Sewairy W, al-Mazyed A, al-Dalaan, al-Balaa S, Bahabri S. Methotrexate therapy in systemic-onset juvenile rheumatoid arthritis in Saudi Arabia: a retrospective analysis. Clin Rheumatol. 1998;17(1):52-7. [pmid: 9586680]. Rec#: 42350 Reprint: exc nro
Amalfitano A, Bengur AR, Morse RP, Majure JM, Case LE, Veerling DL, Mackey J, Kishnani P, Smith W, McVie-Wylie A, Sullivan JA, Hoganson GE, Phillips JA 3rd, Schaefer GB, Charrow J, Ware RE, Bossen EH, Chen YT. Recombinant human acid alpha-glucosidase enzyme therapy for infantile glycogen storage disease type II: results of a phase I/II clinical trial. Genet Med. 2001;3(2):132-8. [pmid: 11286229]. Rec#: 57830 Reprint: exc nrc
Angeles-Han S, Flynn T, Lehman T. Abatacept for refractory juvenile idiopathic arthritis-associated uveitis- a case report. J Rheumatol. 2008;35(9):1897-8. [pmid: 18785302]. Rec#: 41020 Reprint: exc ltr
Ansong AK, Li JS, Nozik-Grayck E, Ing R, Kravitz RM, Idriss SF, Kanter RJ, Rice H, Chen YT, Kishnani PS. Electrocardiographic response to enzyme replacement therapy for Pompe disease. Genet Med. 2006;8(5):297-301. [pmid: 16702879]. Rec#: 57220 Reprint: exc nrc
Applebaum H, Feinfeld LE. Ultrasonic resection of neuroblastomas Long-term local tumor control. Arch Surg. 1995;130(8):905-8. [pmid: 7632154]. Rec#: 21650 Reprint: EXC NRS
Ara T, Khan WA, Ali SM. Histopathological variations among cases of Wilms' tumor in Bangladesh and its relationship with prognosis. Bangladesh Med Res Counc Bull. 1997;23(2):56-9. [pmid: 9465437]. Rec#: 46190 Reprint: exc nrc
Argani P, Lae M, Ballard ET, Amin M, Manivel C, Hutchinson B, Reuter VE, Ladanyi M. Translocation carcinomas of the kidney after chemotherapy in childhood. J Clin Oncol. 2006;24(10):1529-34. [pmid: 16575003]. Rec#: 5790 Reprint: EXC NRD
Atchaneeyasakul LO, Wongsiwaroj C, Uiprasertkul M, Sanpakit K, Thephamongkhol K, Trinavarat A. Prognostic factors and treatment outcomes of retinoblastoma in pediatric patients: a single-institution study. Jpn J Ophthalmol. 2009;53(1):35-9. [pmid: 19184307]. Rec#: 630 Reprint: exc nrd
Atra A, Whelan JS, Calvagna V, Shankar AG, Ashley S, Shepherd V, Souhami RL, Pinkerton CR. High-dose busulphan/melphalan with autologous stem cell rescue in Ewing's sarcoma. Bone Marrow Transplant. 1997;20(10):843-6. [pmid: 9404924]. Rec#: 18830 Reprint: exc nrp
Autti T, Lonnqvist T, Joensuu R. Bilateral pulvinar signal intensity decrease on T2-weighted images in patients with aspartylglucosaminuria. Acta Radiol. 2008;49(6):687-92. [pmid: 18568562]. Rec#: 1820 Reprint: exc nro
Autti T, Santavuori P, Raininko R, Renlund M, Rapola J, Saarinen-Pihkala U. Bone-marrow transplantation in aspartylglucosaminuria. Lancet. 1997;349(9062):1366-7. [pmid: 9149703]. Rec#: 19360 Reprint: exc dup
Avigad S, Feinberg-Gorenshtein G, Luria D, Jeison M, Stein J, Grunshpan A, Sverdlov Y, Ash S, Yaniv I. Minimal residual disease in peripheral blood stem cell harvests from high-risk neuroblastoma patients. J Pediatr Hematol Oncol. 2009;31(1):22-6. [pmid: 19125082]. Rec#: 770 Reprint: exc nri
Avramova B, Jordanova M, Michailov G, Konstantinov D, Christosova I, Bobev D. Myeloablative chemotherapy with autologous peripheral blood stem cell transplantation in patients with poor-prognosis solid tumors - Bulgarian experience. J BUON. 2006;11(4):433-8. [pmid: 17309174]. Rec#: 4290 Reprint: EXC NRI
Bader-Meunier B, Aladjidi N, Bellmann F, Monpoux F, Nelken B, Robert A, Armari-Alla C, Picard C, Ledeist F, Munzer M, Yacouben K, Bertrand Y, Pariente A, Chausse A, Perel Y, Leverger G. Rituximab therapy for childhood Evans syndrome. Haematologica. 2007;92(12):1691-4. [pmid: 18055994]. Rec#: 77590 Reprint: exc nrc
Baehner F, Kampmann C, Whybra C, Miebach E, Wiethoff CM, Beck M. Enzyme replacement therapy in heterozygous females with Fabry disease: results of a phase IIIB study. J Inherit Metab Dis. 2003;26(7):617-27. [pmid: 14707510]. Rec#: 57560 Reprint: exc nrc
Bagatell R, Beck-Popovic M, London WB, Zhang Y, Pearson AD, Matthay KK, Monclair T, Ambros PF, Cohn SL. Significance of MYCN amplification in international neuroblastoma staging system stage 1 and 2 neuroblastoma: a report from the International Neuroblastoma Risk Group database. J Clin Oncol. 2009;27(3):365-70. [pmid: 19047282]. Rec#: 940 Reprint: exc nri
Balmaceda C, Fetell MR, Hesdorffer C. Thiotepa and etoposide treatment of recurrent malignant gliomas: phase I study. Cancer Chemother Pharmacol. 1997;40(1):72-4. [pmid: 9137533]. Rec#: 19900 Reprint: exc nri
Ban H, Andoh A, Tanaka A, Tsujikawa T, Sasaki M, Saito Y, Fujiyama Y. Analysis of thiopurine S-methyltransferase genotypes in Japanese patients with inflammatory bowel disease. Intern Med. 2008;47(19):1645-8. [pmid: 18827410]. Rec#: 1200 Reprint: exc nrd
Barile-Fabris L, Ariza-Andraca R, Olguin-Ortega L, Jara LJ, Fraga-Mouret A, Miranda-Limon JM, Fuentes de la Mata J, Clark P, Vargas F, Alocer-Varela J. Controlled clinical trial of IV cyclophosphamide versus IV methylprednisolone in severe neurological manifestations in systemic lupus erythematosus. Ann Rheum Dis. 2005;64(4):620-5. [pmid: 15769918]. Rec#: 41660 Reprint: exc nrp
bas A, Awan S. Rhabdomyosarcoma of the middle ear and mastoid: a case report and review of the literature. Ear Nose Throat J. 2005;84(12):780. 782. 784. [pmid: 16408557]. Rec#: 47190 Reprint: exc nrs nrp
Bashey A, Owen I, Lucas GF, Amphlett NW, Jones MM, Lawal A, McMullin MF, Mahendra P, Tyfield LA, Hows JM. Late onset immune pancytopenia following bone marrow transplantation. Br J Haematol. 1991;78(2):268-74. [pmid: 2064966]. Rec#: 26160 Reprint: EXC YEAR
Basu D, Ferns S, Prasad MA, Nalini P. Failure to thrive in a 3 month old boy. Postgrad Med J. 2002;78(923):567. 569. [pmid: 12357024]. Rec#: 11600 Reprint: exc nrs
Bay JO, Linassier C, Biron P, Durando X, Verrelle P, Kwiatkowski F, Rosti G, Demirer T. Does high-dose carmustine increase overall survival in supratentorial high-grade malignant glioma? An EBMT retrospective study. Int J Cancer. 2007;120(8):1782-6. [pmid: 17230505]. Rec#: 72120 Reprint: exc nrp
Beard ME, Willis JA, Scott RS, Nesbit JW. Is type 1 diabetes transmissible by bone marrow allograft?. 2002. Rec#: 12440 Reprint: exc nrs
Belldina EB, Huang MY, Schneider JA, Brundage RC, Tracy TS. Steady-state pharmacokinetics and pharmacodynamics of cysteamine bitartrate in paediatric nephropathic cystinosis patients. Br J Clin Pharmacol. 2003;56(5):520-5. [pmid: 14651726]. Rec#: 57570 Reprint: exc nrc
Bembi B, Agosti E, Boehm P, Nassimbeni G, Zanatta M, Vidoni L. Aminohydroxypropylidene-biphosphonate in the treatment of bone lesions in a case of Gaucher's disease type 3. Acta Paediatr. 1994;83(1):122-4. [pmid: 8193463]. Rec#: 23300 Reprint: EXC NRP
Benesch M, Kerbl R, Lackner H, Berghold A, Schwinger W, Triebl-Roth K, Urban C. Low-dose versus high-dose immunoglobulin for primary treatment of acute immune thrombocytopenic purpura in children: results of a prospective, randomized single-center trial. J Pediatr Hematol Oncol. 2003;25(10):797-800. [pmid: 14528103]. Rec#: 78140 Reprint: exc nrd
Benesch M, Siegler N, Hoff K, Lassay L, Kropshofer G, Muller H, Sommer C, Rutkowski S, Fleischhack G, Urban C. Safety and toxicity of intrathecal liposomal cytarabine (Depocyte) in children and adolescents with recurrent or refractory brain tumors: a multi-institutional retrospective study. Anticancer Drugs. 2009;20(9):794-9. [pmid: 19617818]. Rec#: 49370 Reprint: exc nrd
Benkerrou M, Le Deist F, de Villartay JP, Caillat-Zucman S, Rieux-Laucat F, Jabado N, Cavazzana-Calvo M, Fischer A. Correction of Fas (CD95) deficiency by haploidentical bone marrow transplantation. Eur J Immunol. 1997;27(8):2043-7. [pmid: 9295043]. Rec#: 19060 Reprint: exc nre
Beresford MW, Baildam EM. New advances in the management of juvenile idiopathic arthritis--2: the era of biologicals. Arch Dis Child Educ Pract Ed. 2009;94(5):151-6. [pmid: 19770495]. Rec#: 77090 Reprint: exc nra
Berkovitch M, Dolinski G, Tauber T, Aladjem M, Kaplinsky C. Neutropenia as a complication of intravenous immunoglobulin (IVIG) therapy in children with immune thrombocytopenic purpura: common and non-alarming. Int J Immunopharmacol. 1999;21(6):411-5. [pmid: 10405875]. Rec#: 16620 Reprint: exc nrd
Berthold F, Hero B, Kremens B, Handgretinger R, Henze G, Schilling FH, Schrappe M, Simon T, Spix C. Long-term results and risk profiles of patients in five consecutive trials (1979-1997) with stage 4 neuroblastoma over 1 year of age. Cancer Lett. 2003;197(1-2):11-7. [pmid: 12880954]. Rec#: 10140 Reprint: exc nri
Bertuzzi A, Castagna L, Nozza A, Quagliuolo V, Siracusano L, Balzarotti M, Compasso S, Alloisio M, Soto Parra H, Santoro A. High-dose chemotherapy in poor-prognosis adult small round-cell tumors: clinical and molecular results from a prospective study. J Clin Oncol. 2002;20(8):2181-8. [pmid: 11956280]. Rec#: 12380 Reprint: exc nrp
Besalduch J, Bargay J, Buades J, Galmes A, Morey M, Sampol A. Autoimmune hemolityc anemia after treatment of severe systemic lupus erythematosus with high-dose chemotherapy and autotransplantation of selected peripheral hematopoietic progenitors. Haematologica. 2003;88(2):ECR01. [pmid: 12604425]. Rec#: 10900 Reprint: exc nro
Beyer J, Kramar A, Mandanas R, et al. High-dose chemotherapy as salvage treatment in germ cell tumors: a multivariate analysis of prognostic variables. J Clin Oncol. 1996;14:2638-2645. [pmid: 8874322]. Rec#: 78790 Reprint: EXC NPD
Beyer J, Rick O, Siegert W, Bokemeyer C. Salvage chemotherapy in relapsed germ cell tumors. World J Urol. 2001;19:90-93. [pmid: 11374323]. Rec#: 78840 Reprint: EXC NRP
Bhattacharya N. Placental umbilical cord whole blood transfusion to combat anemia in the background of advanced rheumatoid arthritis and emaciation and its potential role as immunoadjuvant therapy. Clin Exp Obstet Gynecol. 2006;33(1):28-33. [pmid: 16761535]. Rec#: 5500 Reprint: exc nro
Bhattacharya N, Mukherijee K, Chettri MK, Banerjee T, Mani U, Bhattacharya S. A study report of 174 units of placental umbilical cord whole blood transfusion in 62 patients as a rich source of fetal hemoglobin supply in different indications of blood transfusion. Clin Exp Obstet Gynecol. 2001;28(1):47-52. [pmid: 11332589]. Rec#: 13800 Reprint: EXC NRS
Bien E, Stachowicz-Stencel T, Sierota D, Polczynska K, Szolkiewicz A, Stefanowicz J, Adamkiewicz-Drozynska E, Czauderna P, Kosiak W, Dubaniewicz-Wybieralska M, Izycka-Swieszewska E, Balcerska A. Sarcomas in children with neurofibromatosis type 1-poor prognosis despite aggressive combined therapy in four patients treated in a single oncological institution. Childs Nerv Syst. 2007;23(10):1147-53. [pmid: 17628808]. Rec#: 3550 Reprint: exc nrs
Bierings M. The role of T-cell depletion of autografts for autoimmune diseases. Rheumatology (Oxford). 1999;38(8):755-6. [pmid: 10501427]. Rec#: 16310 Reprint: exc nro
Binks M, Passweg JR, Furst D, McSweeney P, Sullivan K, Besenthal C, Finke J, Peter HH, van Laar J, Breedveld FC, Fibbe WE, Farge D, Gluckman E, Locatelli F, Martini A, van den Hoogen F, van de Putte L, Schattenberg AV, Arnold R, Bacon PA, Emery P, Espigado I, Hertenstein B, Hiepe F, Kashyap A, Kotter I, Marmont A, Martinez A, Pascual MJ, Gratwohl A, Prentice HG, Black C, Tyndall A. Phase I/II trial of autologous stem cell transplantation in systemic sclerosis: procedure related mortality and impact on skin disease. Ann Rheum Dis. 2001;60(6):577-84. [pmid: 11350846]. Rec#: 13740 Reprint: “exc nrs, 1 patient reported in rec#16270”
Binstadt BA, Caldas AM, Turvey SE, Stone KD, Weinstein HJ, Jackson J, Fuhlbrigge RC, Sundel RP. Rituximab therapy for multisystem autoimmune diseases in pediatric patients. J Pediatr. 2003;143(5):598-604. [pmid: 14615729]. Rec#: 78130 Reprint: exc nrd
Bleesing JJ, Straus SE, Fleisher TA. Autoimmune lymphoproliferative syndrome. A human disorder of abnormal lymphocyte survival. Pediatr Clin North Am. 2000;47(6):1291-310. [pmid: 11130997]. Rec#: 14330 Reprint: exc nra
Bleggi-Torres LF, Gasparetto EL, Faoro LN, Hanel R, Grande CV, de Carvalho Neto A, de Noronh L. Pleomorphic xanthoastrocytoma: report of a case diagnosed by intraoperative cytopathological examination. Diagn Cytopathol. 2001;24(2):120-2. [pmid: 11169891]. Rec#: 55830 Reprint: exc nro
Boelens JJ, Lazo G, Gaiser JF, Wulffraat NM. Epstein-Barr virus-associated haemophagocytic lympho-histiocytosis after stem cell transplantation. 2006. Rec#: 4970 Reprint: exc nrs
Bohgaki T, Atsumi T, Koike T. Autoimmune disease after autologous hematopoietic stem cell transplantation. Autoimmun Rev. 2008;7(3):198-203. [pmid: 18190878]. Rec#: 2660 Reprint: exc nra
Boiardi A, Bartolomei M, Silvani A, Eoli M, Salmaggi A, Lamperti E, Milanesi I, Botturi A, Rocca P, Bodei L, Broggi G, Paganelli G. Intratumoral delivery of mitoxantrone in association with 90-Y radioimmunotherapy (RIT) in recurrent glioblastoma. J Neurooncol. 2005;72(2):125-31. [pmid: 15925992]. Rec#: 7210 Reprint: exc nri nrp
Boland EA, Grey M, Oesterle A, Fredrickson L, Tamborlane WV. Continuous subcutaneous insulin infusion. A new way to lower risk of severe hypoglycemia, improve metabolic control, and enhance coping in adolescents with type 1 diabetes. Diabetes Care. 1999;22(11):1779-84. [pmid: 10546007]. Rec#: 62540 Reprint: exc nro
Bomgaars L, Kerr J, Berg S, Kuttesch J, Klenke R, Blaney SM. A phase I study of irinotecan administered on a weekly schedule in pediatric patients. Pediatr Blood Cancer. 2006;46(1):50-5. [pmid: 15768380]. Rec#: 7560 Reprint: exc nro
Bordigoni P, Turello R, Clement L, Lascombes P, Leheup B, Galloy MA, Plenat F. Osteochondroma after pediatric hematopoietic stem cell transplantation: report of eight cases. Bone Marrow Transplant. 2002;29(7):611-4. [pmid: 11979312]. Rec#: 12310 Reprint: EXC NRI
Borrelli O, Bascietto C, Viola F, Bueno de Mesquita M, Barbato M, Mancini V, Bosco S, Cucchiara S. Infliximab heals intestinal inflammatory lesions and restores growth in children with Crohn's disease. Dig Liver Dis. 2004;36(5):342-7. [pmid: 15191204]. Rec#: 41770 Reprint: exc nri
Borsi JD, Csaki C, Ferencz T, Oster W. Administration of Ethyol (amifostine) to a child with medulloblastoma to ameliorate hematological toxicity of high dose carboplatin. Anticancer Drugs. 1996;7(1):121-6. [pmid: 8742109]. Rec#: 21220 Reprint: EXC NRI
Bouhnik Y, Lemann M, Mary JY, Scemama G, Tai R, Matuchansky C, Modigliani R, Rambaud JC. Long-term follow-up of patients with Crohn's disease treated with azathioprine or 6-mercaptopurine. Lancet. 1996;347(8996):215-9. [pmid: 8551879]. Rec#: 21110 Reprint: exc nrp
Boulad F, Kernan NA, LaQuaglia MP, Heller G, Lindsley KL, Rosenfield NS, Abramson SJ, Gerald WL, Small TN, Gillio AP, Gulati SC, O'Reilly RJ, Ghavimi F. High-dose induction chemoradiotherapy followed by autologous bone marrow transplantation as consolidation therapy in rhabdomyosarcoma, extraosseous Ewing's sarcoma, and undifferentiated sarcoma. J Clin Oncol. 1998;16(5):1697-706. [pmid: 9586881]. Rec#: 18240 Reprint: exc nro
Bousvaros A, Kirschner BS, Werlin SL, Parker-Hartigan L, Daum F, Freeman KB, Balint JP, Day AS, Griffiths AM, Zurakowski D, Ferry GD, Leichtner AM. Oral tacrolimus treatment of severe colitis in children. J Pediatr. 2000;137(6):794-9. [pmid: 11113835]. Rec#: 42180 Reprint: exc nrd
Bousvaros A, Leichtner AM, Book L, Shigeoka A, Bilodeau J, Semeao E, Ruchelli E, Mulberg AE. Treatment of pediatric autoimmune enteropathy with tacrolimus (FK506). Gastroenterology. 1996;111(1):237-43. [pmid: 8698205]. Rec#: 20590 Reprint: exc nri
Bove KE, Daugherty C, Grabowski GA. Pathological findings in Gaucher disease type 2 patients following enzyme therapy. Hum Pathol. 1995;26(9):1040-5. [pmid: 7672788]. Rec#: 21590 Reprint: EXC NRC
Bowers DC, Aquino VM, Leavey PJ, Bash RO, Journeycake JM, Tomlinson G, Mulne AF, Haynes HJ, Winick NJ. Phase I study of oral cyclophosphamide and oral topotecan for children with recurrent or refractory solid tumors. Pediatr Blood Cancer. 2004;42(1):93-8. [pmid: 14752800]. Rec#: 9330 Reprint: EXC NRI
Bowman LC, Hancock ML, Santana VM, Hayes FA, Kun L, Parham DM, Furman WL, Rao BN, Green AA, Crist WM. Impact of intensified therapy on clinical outcome in infants and children with neuroblastoma: the St Jude Children's Research Hospital experience, 1962 to 1988. J Clin Oncol. 1991;9(9):1599-608. [pmid: 1831494]. Rec#: 25970 Reprint: EXC YEAR
Bradfield SM, Douglas JG, Hawkins DS, Sanders JE, Park JR. Fractionated low-dose radiotherapy after myeloablative stem cell transplantation for local control in patients with high-risk neuroblastoma. Cancer. 2004;100(6):1268-75. [pmid: 15022296]. Rec#: 9160 Reprint: exc nri
Brandes AA, Ermani M, Turazzi S, Scelzi E, Berti F, Amista P, Rotilio A, Licata C, Fiorentino MV. Procarbazine and high-dose tamoxifen as a second-line regimen in recurrent high-grade gliomas: a phase II study. J Clin Oncol. 1999;17(2):645-50. [pmid: 10080610]. Rec#: 56070 Reprint: exc nrp
Brandes AA, Turazzi S, Basso U, Pasetto LM, Guglielmi B, Volpin L, Iuzzolino P, Amista P, Pinna G, Scienza R, Ermani M. A multidrug combination designed for reversing resistance to BCNU in glioblastoma multiforme. Neurology. 2002;58(12):1759-64. [pmid: 12084873]. Rec#: 55650 Reprint: exc nrp
Breier DV, Rendo P, Gonzalez J, Shilton G, Stivel M, Goldztein S. Massive plasmocytosis due to methimazole-induced bone marrow toxicity. Am J Hematol. 2001;67(4):259-61. [pmid: 11443640]. Rec#: 13510 Reprint: exc nrd
Breitfeld PP, Lyden E, Raney RB, Teot LA, Wharam M, Lobe T, Crist WM, Maurer HM, Donaldson SS, Ruymann FB. Ifosfamide and etoposide are superior to vincristine and melphalan for pediatric metastatic rhabdomyosarcoma when administered with irradiation and combination chemotherapy: a report from the Intergroup Rhabdomyosarcoma Study Group. J Pediatr Hematol Oncol. 2001;23(4):225-33. [pmid: 11846301]. Rec#: 12620 Reprint: exc in breneman 2003
Briceno E, Reyes S, Sotelo J. Therapy of glioblastoma multiforme improved by the antimutagenic chloroquine. Neurosurg Focus. 2003;14(2):e3. [pmid: 15727424]. Rec#: 55210 Reprint: exc nri
Brinkman DM, de Kleer IM, ten Cate R, van Rossum MA, Bekkering WP, Fasth A, van Tol MJ, Kuis W, Wulffraat NM, Vossen JM. Autologous stem cell transplantation in children with severe progressive systemic or polyarticular juvenile idiopathic arthritis: long-term follow-up of a prospective clinical trial. Arthritis Rheum. 2007;56(7):2410-21. [pmid: 17599770]. Rec#: 3650 Reprint: exc same pt as In 8350
Brinkman DM, Jol-van der Zijde CM, ten Dam MM, te Boekhorst PA, ten Cate R, Wulffraat NM, Hintzen RQ, Vossen JM, van To MJ. Resetting the adaptive immune system after autologous stem cell transplantation: lessons from responses to vaccines. J Clin Immunol. 2007;27(6):647-58. [pmid: 17690955]. Rec#: 3410 Reprint: exc nri
Brinkman DM, ten Cate R, Vossen JM, Smeets TJ, Kraan MC, Tak PP. Decrease in synovial cellularity and cytokine expression after autologous stem cell transplantation in patients with juvenile idiopathic arthritis. Arthritis Rheum. 2002;46(4):1121-3. [pmid: 11953992]. Rec#: 12400 Reprint: exc nrd
Brisse H, Servois V, Bouche B, Avni F, Petit P, Thibault F, Zucker JM, Devalck C, Neuenschwander S. Hepatic regenerating nodules: a mimic of recurrent cancer in children. Pediatr Radiol. 2000;30(6):386-93. [pmid: 10876822]. Rec#: 15220 Reprint: EXC NRI NRO
Brodeur GM. Commentary on Kaneko et al.: Intensified chemotherapy increases the survival rates in patients with stage 4 neuroblastoma with MYCN amplification. J Pediatr Hematol Oncol. 2002;24(8):608-9. [pmid: 12439030]. Rec#: 11390 Reprint: EXC COM
Broun ER, Nichols CR, Gize G, et al. Tandem high dose chemotherapy with autologous bone marrow transplantation for initial relapse of testicular germ cell cancer. Cancer. 1997;79:1605-1610. [pmid: 9118046]. Rec#: 78800 Reprint: EXC NRP
Browne H, Armstrong A, Decherney A, Babb R, Illei G, Segars J, Pavletic S. Assessment of ovarian function with anti-Mullerian hormone in systemic lupus erythematosus patients undergoing hematopoietic stem cell transplant. Fertil Steril. 2009;91(4 Suppl):1529-32. [pmid: 18930199]. Rec#: 1100 Reprint: exc nro
Browne M, Somers G, Savoia H, Kukuruzovic R. Wolman's disease in an infant. Br J Haematol. 2003;122(4):522. [pmid: 12899707]. Rec#: 10100 Reprint: exc nrs
Bryan CJ, Prichard MN, Daily S, Jefferson G, Hartline C, Cassady KA, Hilliard L, Shimamura M. Acyclovir-resistant chronic verrucous vaccine strain varicella in a patient with neuroblastoma. Pediatr Infect Dis J. 2008;27(10):946-8. [pmid: 18776818]. Rec#: 1380 Reprint: exc nri
Buckingham BA, Sandborg CI. A randomized trial of methotrexate in newly diagnosed patients with type 1 diabetes mellitus. Clin Immunol. 2000;96(2):86-90. [pmid: 10900154]. Rec#: 40580 Reprint: exc cr
Bulsara KR, Baron PW, Tuttle-Newhall JE, Clavien PA, Morgenlander J. Guillain-Barre syndrome in organ and bone marrow transplant patients. Transplantation. 2001;71(8):1169-72. [pmid: 11374420]. Rec#: 13690 Reprint: exc nrd
Buratti S, Szer IS, Spencer CH, Bartosh S, Reiff A. Mycophenolate mofetil treatment of severe renal disease in pediatric onset systemic lupus erythematosus. J Rheumatol. 2001;28(9):2103-8. [pmid: 11550982]. Rec#: 42120 Reprint: exc nro
Burchill SA, Kinsey SE, Picton S, Roberts P, Pinkerton CR, Selby P, Lewis IJ. Minimal residual disease at the time of peripheral blood stem cell harvest in patients with advanced neuroblastoma. Med Pediatr Oncol. 2001;36(1):213-9. [pmid: 11464888]. Rec#: 13390 Reprint: exc nri
Burdach S, Jurgens H, Peters C, Nurnberger W, Mauz-Korholz C, Korholz D, Paulussen M, Pape H, Dilloo D, Koscielniak E, et al. Myeloablative radiochemotherapy and hematopoietic stem-cell rescue in poor-prognosis Ewing's sarcoma. J Clin Oncol. 1993;11(8):1482-8. [pmid: 8101562]. Rec#: 23950 Reprint: EXC YEAR
Burt RK, Traynor A, Oyama Y, Craig R. High-dose immune suppression and autologous hematopoietic stem cell transplantation in refractory Crohn disease. Blood. 2003;101(5):2064-6. [pmid: 12393477]. Rec#: 11560 Reprint: exc same pts as in rec#7570
Burzynski SR, Janicki TJ, Weaver RA, Burzynski B. Targeted therapy with antineoplastons A10 and AS2-1 of high-grade, recurrent, and progressive brainstem glioma. Integr Cancer Ther. 2006;5(1):40-7. [pmid: 16484713]. Rec#: 54950 Reprint: exc nrt
Burzynski SR, Weaver RA, Lewy RI, Janicki TJ, Jurida GF, Szymkowski BG, Khan MI, Bestak M. Phase II study of antineoplaston A10 and AS2-1 in children with recurrent and progressive multicentric glioma : a preliminary report. Drugs R D. 2004;5(6):315-26. [pmid: 15563234]. Rec#: 55250 Reprint: exc nri
Busuttil DP, Liu Yin JA. The bone marrow in hereditary cystinosis. Br J Haematol. 2000;111(2):385. [pmid: 11122075]. Rec#: 14380 Reprint: exc nrs
Butani L, West DC, Taylor DS. End-stage renal disease after high-dose carboplatinum in preparation of autologous stem cell transplantation. Pediatr Transplant. 2003;7(5):408-12. [pmid: 14738305]. Rec#: 9370 Reprint: exc nro
Calogero J, Crafts DC, Wilson CB, Boldrey EB, Rosenberg A, Enot KJ. Long-term survival of patients treated with BCNU for brain tumors. J Neurosurg. 1975;43(2):191-6. [pmid: 1185250]. Rec#: 73370 Reprint: EXC nrs
Candy S, Wright J, Gerber M, Adams G, Gerig M, Goodman R. A controlled double blind study of azathioprine in the management of Crohn's disease. Gut. 1995;37(5):674-8. [pmid: 8549944]. Rec#: 21420 Reprint: EXC NRS
Canete A, Gerrard M, Rubie H, Castel V, Di Cataldo A, Munzer C, Ladenstein R, Brichard B, Bermudez JD, Couturier J, de Bernardi B, Pearson AJ, Michon J. Poor survival for infants with MYCN-amplified metastatic neuroblastoma despite intensified treatment: the International Society of Paediatric Oncology European Neuroblastoma Experience. J Clin Oncol. 2009;27(7):1014-9. [pmid: 19171715]. Rec#: 650 Reprint: exc nri
Carpenter PA, White L, McCowage GB, Nayanar V, Toogood I, Shaw PJ, Lockwood L, Tiedemann K. A dose-intensive, cyclophosphamide-based regimen for the treatment of recurrent/progressive or advanced solid tumors of childhood: a report from the Australia and New Zealand Children's Cancer Study Group. Cancer. 1997;80(3):489-96. [pmid: 9241083]. Rec#: 46200 Reprint: exc nro
Casey DA, Wexler LH, Merchant MS, Chou AJ, Merola PR, Price AP, Meyers PA. Irinotecan and temozolomide for Ewing sarcoma: the Memorial Sloan-Kettering experience. Pediatr Blood Cancer. 2009;53(6):1029-34. [pmid: 19637327]. Rec#: 42810 Reprint: exc nrp
Castagnola E, Conte M, Parodi S, Papio F, Caviglia I, Haupt R. Incidence of bacteremias and invasive mycoses in children with high risk neuroblastoma. Pediatr Blood Cancer. 2007;49(5):672-7. [pmid: 17039488]. Rec#: 4860 Reprint: exc nri
Castagnola E, Dallorso S, Rabagliati M, Sacco O, Kotitsa Z, Dini G. Survival after cytomegalovirus pneumonia in two children receiving autologous peripheral blood progenitor cell transplantation (PBPCT). Bone Marrow Transplant. 1998;21(5):529-31. [pmid: 9535048]. Rec#: 18430 Reprint: exc nri
Castel V, Canete A, Navarro S, Garcia-Miguel P, Melero C, Acha T, Navajas A, Badal MD. Outcome of high-risk neuroblastoma using a dose intensity approach: improvement in initial but not in long-term results. Med Pediatr Oncol. 2001;37(6):537-42. [pmid: 11745893]. Rec#: 12800 Reprint: exc nri
Castel V, Garcia-Miguel P, Melero C, Navajas A, Navarro S, Molina J, Badal MD, Ruiz-Jimenez JI. The treatment of advanced neuroblastoma. Results of the Spanish Neuroblastoma Study Group (SNSG) studies. Eur J Cancer. 1995;31A(4):642-5. [pmid: 7576986]. Rec#: 22400 Reprint: EXC NRI
Castel V, Tovar JA, Costa E, Cuadros J, Ruiz A, Rollan V, Ruiz-Jimenez JI, Perez-Hernandez R, Canete A. The role of surgery in stage IV neuroblastoma. J Pediatr Surg. 2002;37(11):1574-8. [pmid: 12407542]. Rec#: 11530 Reprint: exc nri
Cathcart S, Morrell D. Vitiligo as a post-bone marrow transplantation complication. J Pediatr Hematol Oncol. 2007;29(7):485-7. [pmid: 17609627]. Rec#: 3620 Reprint: exc nr
Cecen E, Uysal KM, Ozguven A, Gunes D, Irken G, Olgun N. Veno-occlusive disease in a child with rhabdomyosarcoma after conventional chemotherapy: report of a case and review of the literature. Pediatr Hematol Oncol. 2007;24(8):615-21. [pmid: 18092252]. Rec#: 2750 Reprint: exc nro
Ceschel S, Casotto V, Valsecchi MG, Tamaro P, Jankovic M, Hanau G, Fossati F, Pillon M, Rondelli R, Sandri A, Silvestri D, Haupt R, Cuttini M. Survival after relapse in children with solid tumors: a follow-up study from the Italian off-therapy registry. Pediatr Blood Cancer. 2006;47(5):560-6. [pmid: 16395684]. Rec#: 6260 Reprint: EXC NRI
Chamberlain RS, Quinones R, Dinndorf P, Movassaghi N, Goodstein M, Newman K. Complete surgical resection combined with aggressive adjuvant chemotherapy and bone marrow transplantation prolongs survival in children with advanced neuroblastoma. Ann Surg Oncol. 1995;2(2):93-100. [pmid: 7728576]. Rec#: 22070 Reprint: EXC NRI
Chan DT, Poon WS, Chan YL, Ng HK. Temozolomide in the treatment of recurrent malignant glioma in Chinese patients. Hong Kong Med J. 2005;11(6):452-6. [pmid: 16340021]. Rec#: 54990 Reprint: exc nrp
Chan GS, Lam MF, Au WY, Chim S, Tse KC, Lo SH, Fung SH, Lai KN, Chan KW. Clinicopathologic analysis of renal biopsies after haematopoietic stem cell transplantation. Nephrology (Carlton). 2008;13(4):322-30. [pmid: 18221254]. Rec#: 2560 Reprint: exc nro
Chan KW, Petropoulos D, Choroszy M, Herzog C, Jaffe N, Ater J, Korbling M. High-dose sequential chemotherapy and autologous stem cell reinfusion in advanced pediatric solid tumors. Bone Marrow Transplant. 1997;20(12):1039-43. [pmid: 9466276]. Rec#: 18680 Reprint: exc nro
Chan SC, Chan KL, Peh WC. Clinics in diagnostic imaging (31). Adrenal neuroblastoma. Singapore Med J. 1997;38(11):504-8. [pmid: 9550915]. Rec#: 18380 Reprint: exc nri
Chantada GL, Dunkel IJ, Antoneli CB, de Davila MT, Arias V, Beaverson K, Fandino AC, Chojniak M, Abramson DH. Risk factors for extraocular relapse following enucleation after failure of chemoreduction in retinoblastoma. Pediatr Blood Cancer. 2007;49(3):256-60. [pmid: 17029248]. Rec#: 48630 Reprint: exc nrd
Chen IL, Yang SN, Hsiao CC, Wu KS, Sheen JM. Treatment with high-dose methylprednisolone for hepatic veno-occlusive disease in a child with rhabdomyosarcoma. Pediatr Neonatol. 2008;49(4):141-4. [pmid: 19054920]. Rec#: 910 Reprint: exc nrs
Cheuk DK, Lee TL, Chiang AK, Ha SY, Chan GC. Autologous hematopoietic stem cell transplantation for high-risk brain tumors in children. J Neurooncol. 2008;86(3):337-47. [pmid: 17906911]. Rec#: 72990 Reprint: exc few nrp
Cheung NK, Guo HF, Heller G, Cheung IY. Induction of Ab3 and Ab3' antibody was associated with long-term survival after anti-G(D2) antibody therapy of stage 4 neuroblastoma. Clin Cancer Res. 2000;6(7):2653-60. [pmid: 10914706]. Rec#: 15120 Reprint: exc nri
Cheung NK, Kushner BH, Cheung IY, Kramer K, Canete A, Gerald W, Bonilla MA, Finn R, Yeh SJ, Larson SM. Anti-G(D2) antibody treatment of minimal residual stage 4 neuroblastoma diagnosed at more than 1 year of age. J Clin Oncol. 1998;16(9):3053-60. [pmid: 9738575]. Rec#: 17720 Reprint: exc nri
Cheung NK, Kushner BH, LaQuaglia M, Kramer K, Gollamudi S, Heller G, Gerald W, Yeh S, Finn R, Larson SM, Wuest D, Byrnes M, Dantis E, Mora J, Cheung IY, Rosenfield N, Abramson S, O'Reill RJ. N7: a novel multi-modality therapy of high risk neuroblastoma (NB) in children diagnosed over 1 year of age. Med Pediatr Oncol. 2001;36(1):227-30. [pmid: 11464891]. Rec#: 13380 Reprint: exc nri
Chintagumpala M, Hassall T, Palmer S, Ashley D, Wallace D, Kasow K, Merchant TE, Krasin MJ, Dauser R, Boop F, Krance R, Woo S, Cheuk R, Lau C, Gilbertson R, Gajjar A. A pilot study of risk-adapted radiotherapy and chemotherapy in patients with supratentorial PNET. Neuro Oncol. 2009;11(1):33-40. [pmid: 18796696]. Rec#: 71130 Reprint: EXC NRI
Chiu SJ, Ou LS, Tsai TL, Hung IJ, Huang JL. Sequential evaluation of clinical and laboratory changes amongst children suffering from lupus nephritis during intermittent intravenous cyclophosphamide therapy. Clin Rheumatol. 2006;25(4):515-9. [pmid: 16283418]. Rec#: 41600 Reprint: exc nrp
Cho HJ, Jung HK, Sung KW, Ku HH, Lee SH, Kim DW. Autologous peripheral blood stem cell collections in children weighing less than 10 Kg with solid tumors: experience of a single center. J Clin Apher. 2005;20(2):65-71. [pmid: 15892091]. Rec#: 7290 Reprint: exc nrs
Choi HS, Koh SH, Park ES, Shin HY, Ahn HS. CNS recurrence following CD34+ peripheral blood stem cell transplantation in stage 4 neuroblastoma. Pediatr Blood Cancer. 2005;45(1):68-71. [pmid: 15770641]. Rec#: 71590 Reprint: exc nro
Chosidow O, Bagot M, Vernant JP, Roujeau JC, Cordonnier C, Kuentz M, Wechsler J, Andre C, Touraine R, Revuz J. Sclerodermatous chronic graft-versus-host disease. Analysis of seven cases. J Am Acad Dermatol. 1992;26(1):49-55. [pmid: 1732335]. Rec#: 25370 Reprint: EXC YEAR
Choudhary DR, Naithani R, Mahapatra M, Kumar R, Mishra P, Saxena R. Efficacy of cyclosporine as a single agent therapy in chronic idiopathic thrombocytopenic purpura. Haematologica. 2008;93(10):e61-2. [pmid: 18827257]. discussion e63 Rec#: 77510 Reprint: exc nro
Citak EC, Kesik V, Atay AA, Sari E, Kismet E, Koseoglu V. Transfusion-related acute lung injury in a child with neuroblastoma during a late engraftment period of autologous stem cell transplantation. Pediatr Transplant. 2008;12(2):235-7. [pmid: 18307675]. Rec#: 2320 Reprint: exc nri
Clarke K, Basser RL, Underhill C, Mitchell P, Bartlett J, Cher L, Findlay M, Dalley D, Pell M, Byrne M, Geldard H, Hill JS, Maher D, Fox RM, Green MD, Kaye AH. KRN8602 (MX2-hydrochloride): an active new agent for the treatment of recurrent high-grade glioma. J Clin Oncol. 1999;17(8):2579-84. [pmid: 10561325]. Rec#: 55980 Reprint: exc nrp
Cohen A. Hematopoietic stem cell transplantation and diabetes mellitus: the paradox between treatment and cause of a disease. Pediatr Transplant. 2009;13(1):3-6. [pmid: 18785911]. Rec#: 1360 Reprint: exc edt
Cohen KJ. Autologous stem cell rescue in children with brain tumors: the questions mount. Pediatr Blood Cancer. 2008;50(2):191. [pmid: 17924551]. Rec#: 3060 Reprint: exc nri
Cohn SL, Moss TJ, Hoover M, Katzenstein HM, Haut PR, Morgan ER, Green AA, Kletzel M. Treatment of poor-risk neuroblastoma patients with high-dose chemotherapy and autologous peripheral stem cell rescue. Bone Marrow Transplant. 1997;20(7):543-51. [pmid: 9337055]. Rec#: 18950 Reprint: exc nri
Coleman JE, Watson AR. Gastrostomy buttons for nutritional support in children with cystinosis. Pediatr Nephrol. 2000;14(8-9):833-6. [pmid: 10955939]. Rec#: 57900 Reprint: exc nrc
Colombel JF, Ferrari N, Debuysere H, Marteau P, Gendre JP, Bonaz B, Soule JC, Modigliani R, Touze Y, Catala P, Libersa C, Broly F. Genotypic analysis of thiopurine S-methyltransferase in patients with Crohn's disease and severe myelosuppression during azathioprine therapy. Gastroenterology. 2000;118(6):1025-30. [pmid: 10833476]. Rec#: 15280 Reprint: exc nro
Combs SE, Bischof M, Welzel T, Hof H, Oertel S, Debus J, Schulz-Ertner D. Radiochemotherapy with temozolomide as re-irradiation using high precision fractionated stereotactic radiotherapy (FSRT) in patients with recurrent gliomas. J Neurooncol. 2008;89(2):205-10. [pmid: 18461281]. Rec#: 54560 Reprint: exc nrp
Combs SE, Thilmann C, Edler L, Debus J, Schulz-Ertner D. Efficacy of fractionated stereotactic reirradiation in recurrent gliomas: long-term results in 172 patients treated in a single institution. J Clin Oncol. 2005;23(34):8863-9. [pmid: 16314646]. Rec#: 55020 Reprint: exc nri
Connell WR, Kamm MA, Ritchie JK, Lennard-Jones JE. Bone marrow toxicity caused by azathioprine in inflammatory bowel disease: 27 years of experience. Gut. 1993;34(8):1081-5. [pmid: 8174958]. Rec#: 23940 Reprint: EXC YEAR
Corbett R, Pinkerton R, Pritchard J, Meller S, Lewis I, Kingston J, McElwain T. Pilot study of high-dose vincristine, etoposide, carboplatin and melphalan with autologous bone marrow rescue in advanced neuroblastoma. Eur J Cancer. 1992;28A(8-9):1324-8. [pmid: 1515243]. Rec#: 25470 Reprint: EXC YEAR
Correia CE, Bhattacharya K, Lee PJ, Shuster JJ, Theriaque DW, Shankar MN, Smit GP, Weinstein DA. Use of modified cornstarch therapy to extend fasting in glycogen storage disease types Ia and Ib. Am J Clin Nutr. 2008;88(5):1272-6. [pmid: 18996862]. Rec#: 56760 Reprint: exc nrs
Cortes-Hernandez J, Ordi-Ros J, Labrador M, Segarra A, Tovar JL, Balada E, Vilardell-Tarres M. Predictors of poor renal outcome in patients with lupus nephritis treated with combined pulses of cyclophosphamide and methylprednisolone. Lupus. 2003;12(4):287-96. [pmid: 12729052]. Rec#: 41880 Reprint: exc nrp
Corti P, Bonanomi S, Vallinoto C, Balduzzi A, Uderzo C, Cazzaniga G, Gaipa G, Dassi M, Perseghin P, Rovelli A. Rituximab for immune hemolytic anemia following T- and B-Cell-depleted hematopoietic stem cell transplantation. Acta Haematol. 2003;109(1):43-5. [pmid: 12486323]. Rec#: 11200 Reprint: exc nr
Corti P, Peters C, Balduzzi A, Bertagnolio B, Biondi A, Bugarin C, Dassi M, Furlan F, Gaipa G, Longoni D, Maglia O, Parini R, Perseghin P, Uderzo C, Uziel G, Masera G, Rovelli A. Reconstitution of lymphocyte subpopulations in children with inherited metabolic storage diseases after haematopoietic cell transplantation. Br J Haematol. 2005;130(2):249-55. [pmid: 16029453]. Rec#: 6970 Reprint: exc nr
Cortis E, Insalaco A. Macrophage activation syndrome in juvenile idiopathic arthritis. Acta Paediatr Suppl. 2006;95(452):38-41. [pmid: 16801165]. Rec#: 5370 Reprint: exc nro
Cortona L, D'Orazio T, Locatelli F, Guagnini R, Bonetti F, Vitali L, Lorini R. Pancreatic beta cell function in children and adolescents after bone marrow transplantation. Bone Marrow Transplant. Suppl 1. 1991;8:66-7. [pmid: 1760649]. Rec#: 26710 Reprint: EXC YEAR
Cosetti M, Wexler LH, Calleja E, Trippett T, LaQuaglia M, Huvos AG, Gerald W, Healey JH, Meyers PA, Gorlick R. Irinotecan for pediatric solid tumors: the Memorial Sloan-Kettering experience. J Pediatr Hematol Oncol. 2002;24(2):101-5. [pmid: 11990694]. Rec#: 12270 Reprint: exc nro
Couri CE, Voltarelli JC. Potential role of stem cell therapy in type 1 diabetes mellitus. Arq Bras Endocrinol Metabol. 2008;52(2):407-15. [pmid: 18438552]. Rec#: 2050 Reprint: exc nra
Craft A, Cotterill S, Malcolm A, Spooner D, Grimer R, Souhami R, Imeson J, Lewis I. Ifosfamide-containing chemotherapy in Ewing's sarcoma: The Second United Kingdom Children's Cancer Study Group and the Medical Research Council Ewing's Tumor Study. J Clin Oncol. 1998;16(11):3628-33. [pmid: 9817284]. Rec#: 44170 Reprint: exc nrp
Craft AW, Cotterill SJ, Bullimore JA, Pearson D. Long-term results from the first UKCCSG Ewing's Tumour Study (ET-1). United Kingdom Children's Cancer Study Group (UKCCSG) and the Medical Research Council Bone Sarcoma Working Party. Eur J Cancer. 1997;33(7):1061-9. [pmid: 9376188]. Rec#: 44340 Reprint: exc nrp
Crino A, Schiaffini R, Manfrini S, Mesturino C, Visalli N, Beretta Anguissola G, Suraci C, Pitocco D, Spera S, Corbi S, Matteoli MC, Patera IP, Manca Bitti ML, Bizzarri C, Pozzilli P. A randomized trial of nicotinamide and vitamin E in children with recent onset type 1 diabetes (IMDIAB IX). Eur J Endocrinol. 2004;150(5):719-24. [pmid: 15132730]. Rec#: 62270 Reprint: exc nrc
Csaki C, Ferencz T, Sipos G, Kopper L, Schuler D, Borsi JD. Diffuse plasmacytosis in a child with brainstem glioma following multiagent chemotherapy and intensive growth factor support. Med Pediatr Oncol. 1996;26(5):367-71. [pmid: 8614371]. Rec#: 20830 Reprint: exc nri
Cummins C, Connock M, Fry-Smith A, Burls A. A systematic review of effectiveness and economic evaluation of new drug treatments for juvenile idiopathic arthritis: etanercept. Health Technol Assess. 2002;6(17):1-43. [pmid: 12234456]. Rec#: 77210 Reprint: exc sr
Curbow B, Somerfield MR, Baker F, Wingard JR, Legro MW. Personal changes, dispositional optimism, and psychological adjustment to bone marrow transplantation. J Behav Med. 1993;16(5):423-43. [pmid: 8254649]. Rec#: 23810 Reprint: EXC YEAR
Currie DM, Ludvigsdottir GK, Diaz CA, Kamani N. Topical treatment of sclerodermoid chronic graft vs. host disease. Am J Phys Med Rehabil. 2002;81(2):143-9. [pmid: 11807351]. Rec#: 12680 Reprint: exc nrd
Cutting R, Ezaydi Y, Edbrooke D, El-Ghariani K, Stamps R, Snowden JA. Graft failure and severe autoimmune haemolysis following fludarabine-based reduced-intensity matched unrelated donor bone marrow transplantation for severe aplastic anaemia: salvage by second transplant with conventional dose conditioning. 2006. Rec#: 5350 Reprint: exc nrs
Cybulla M, Walter KN, Schwarting A, Divito R, Feriozzi S, Sunder-Plassmann G. Kidney transplantation in patients with Fabry disease. Transpl Int. 2009;22(4):475-81. [pmid: 19207191]. Rec#: 56710 Reprint: exc nrc
Czyzewski EA, Goldman S, Mundt AJ, Nachman J, Rubin C, Hallahan DE. Radiation therapy for consolidation of metastatic or recurrent sarcomas in children treated with intensive chemotherapy and stem cell rescue. A feasibility study. Int J Radiat Oncol Biol Phys. 1999;44(3):569-77. [pmid: 10348286]. Rec#: 16790 Reprint: EXC MIX
Dahlborg SA, Petrillo A, Crossen JR, Roman-Goldstein S, Doolittle ND, Fuller KH, Neuwelt EA. The potential for complete and durable response in nonglial primary brain tumors in children and young adults with enhanced chemotherapy delivery. Cancer J Sci Am. 1998;4(2):110-24. [pmid: 9532413]. Rec#: 71380 Reprint: EXC NRI
Dallorso S, Dini G, Faraci M, Spreafico F. SCT for Wilms' tumour. Bone Marrow Transplant. Suppl 2. 2008;41:S128-30. [pmid: 18545233]. Rec#: 1640 Reprint: EXC REV
Dallorso S, Dini G, Ladenstein R, Cama A, Milanaccio C, Barra S, Cappelli B, Garre ML. Evolving role of myeloablative chemotherapy in the treatment of childhood brain tumours. Bone Marrow Transplant. Suppl 1. 2005;35:S31-4. [pmid: 15812527]. Rec#: 7450 Reprint: EXC NRP
Dantonello TM, Int-Veen C, Winkler P, Leuschner I, Schuck A, Schmidt BF, Lochbuehler H, Kirsch S, Hallmen E, Veit-Friedrich I, Bielack SS, Niggli F, Kazanowska B, Ladenstein R, Wiebe T, Klingebiel T, Treuner J, Koscielniak E. Initial patient characteristics can predict pattern and risk of relapse in localized rhabdomyosarcoma. J Clin Oncol. 2008;26(3):406-13. [pmid: 18202417]. Rec#: 2640 Reprint: exc nrd
Day DL, Johnson RT, Odrezin GT, Woods WG, Alford BA. Renal atrophy or infarction in children with neuroblastoma. Radiology. 1991;180(2):493-5. [pmid: 2068318]. Rec#: 26010 Reprint: EXC YEAR
De Bernardi B, Carli M, Casale F, Corciulo P, Cordero di Montezemolo L, De Laurentis C, Bagnulo S, Brisigotti M, Marchese N, Garaventa A, et al. Standard-dose and high-dose peptichemio and cisplatin in children with disseminated poor-risk neuroblastoma: two studies by the Italian Cooperative Group for Neuroblastoma. J Clin Oncol. 1992;10(12):1870-8. [pmid: 1453202]. Rec#: 24650 Reprint: EXC YEAR
de Boer NK, van Bodegraven AA, de Graaf P, van der Hulst RW, Zoetekouw L, van Kuilenburg AB. Paradoxical elevated thiopurine S-methyltransferase activity after pancytopenia during azathioprine therapy: potential influence of red blood cell age. Ther Drug Monit. 2008;30(3):390-3. [pmid: 18520612]. Rec#: 1940 Reprint: exc nro
De Filippo G, Carel JC, Boitard C, Bougneres PF. Long-term results of early cyclosporin therapy in juvenile IDDM. Diabetes. 1996;45(1):101-4. [pmid: 8522052]. Rec#: 40790 Reprint: exc nrc
de Kraker J, Graf N, van Tinteren H, Pein F, Sandstedt B, Godzinski J, Tournade MF. Reduction of postoperative chemotherapy in children with stage I intermediate-risk and anaplastic Wilms' tumour (SIOP 93-01 trial): a randomised controlled trial. Lancet. 2004;364(9441):1229-35. [pmid: 15464183]. Rec#: 45310 Reprint: exc nrp
de Kraker J, Hoefnagel KA, Verschuur AC, van Eck B, van Santen HM, Caron HN. Iodine-131-metaiodobenzylguanidine as initial induction therapy in stage 4 neuroblastoma patients over 1 year of age. Eur J Cancer. 2008;44(4):551-6. [pmid: 18267358]. Rec#: 2430 Reprint: exc nri
de Ridder L, Benninga MA, Taminiau JA, Hommes DW. Infliximab as first-line therapy in severe pediatric Crohn disease. J Pediatr Gastroenterol Nutr. 2006;43(3):388-90. [pmid: 16954965]. Rec#: 41450 Reprint: exc cr
De Sio L, Milano GM, Castellano A, Jenkner A, Fidani P, Dominici C, Donfrancesco A. Temozolomide in resistant or relapsed pediatric solid tumors. Pediatr Blood Cancer. 2006;47(1):30-6. [pmid: 16047361]. Rec#: 73060 Reprint: exc duplicate
Degar BA, Harrington RD, Rappeport JM, Woolfrey AE. 13-cis-retinoic acid-induced eosinophilia following autologous bone marrow transplantation for neuroblastoma. Med Pediatr Oncol. 1999;32(4):308-10. [pmid: 10102029]. Rec#: 16970 Reprint: exc nri
Denis R, Wayemberg JL, Vermeulen M, Gorus F, Liebaers I, Vamos E. Hyperphosphatasemia in GM1 gangliosidosis. 1992. Rec#: 25380 Reprint: exc year
Desai TK, Maliakkal J, Kinzie JL, Ehrinpreis MN, Luk GD, Cejka J. Taurine deficiency after intensive chemotherapy and/or radiation. Am J Clin Nutr. 1992;55(3):708-11. [pmid: 1550047]. Rec#: 25300 Reprint: EXC YEAR
Di Caro A, Bostrom B, Moss TJ, Neglia J, Ramsay NK, Smith J, Sasky LC. Autologous peripheral blood cell transplantation in the treatment of advanced neuroblastoma. Am J Pediatr Hematol Oncol. 1994;16(3):200-6. [pmid: 7913588]. Rec#: 22830 Reprint: EXC Year
Diaz MA, Vicent MG, Madero L. High-dose busulfan/melphalan as conditioning for autologous PBPC transplantation in pediatric patients with solid tumors. Bone Marrow Transplant. 1999;24(11):1157-9. [pmid: 10642802]. Rec#: 15770 Reprint: exc nro
Dini G, Lanino E, Garaventa A, Paolucci P, Amici A, Locatelli F, Colleselli P, Boni L, Dallorso S, Abla O, et al. Unpurged autologous bone marrow transplantation for neuroblastoma: the AIEOP-BMT group experience. Bone Marrow Transplant. Suppl 3. 1991;7:109-11. [pmid: 1855071]. Rec#: 26640 Reprint: EXC YEAR
Dini G, Lanino E, Garaventa A, Rogers D, Dallorso S, Viscoli C, Castagnola E, Manno G, Brisigotti M, Rosanda C, et al. Myeloablative therapy and unpurged autologous bone marrow transplantation for poor-prognosis neuroblastoma: report of 34 cases. J Clin Oncol. 1991;9(6):962-9. [pmid: 2033431]. Rec#: 26180 Reprint: EXC YEAR
Dionisi-Vici C, De Felice L, el Hachem M, Bottero S, Rizzo C, Paoloni A, Goffredo B, Sabetta G, Caniglia M. Intravenous immune globulin in lysinuric protein intolerance. J Inherit Metab Dis. 1998;21(2):95-102. [pmid: 9584260]. Rec#: 18260 Reprint: exc nro
Ditschkowski M, Einsele H, Schwerdtfeger R, Bunjes D, Trenschel R, Beelen DW, Elmaagacli AH. Improvement of inflammatory bowel disease after allogeneic stem-cell transplantation. Transplantation. 2003;75(10):1745-7. [pmid: 12777867]. Rec#: 10480 Reprint: exc nrd nro
Dixit MP, Bracamonte E, Dixit N. Intravenous cyclophosphamide--resistant systemic lupus erythematosus in Arizona. Pediatr Nephrol. 2004;19(7):738-43. [pmid: 15141346]. Rec#: 8880 Reprint: exc nro
Djaldetti R, Achiron A, Ziv I, Djaldetti M, Melamed E, Fishman P. IL-3-LA production by mononuclear cells of patients with multiple sclerosis: effect of treatment with intravenous immunoglobulins. Immunol Invest. 1995;24(5):765-73. [pmid: 8543340]. Rec#: 21640 Reprint: EXC NRI
Dohil R, Fidler M, Barshop B, Newbury R, Sellers Z, Deutsch R, Schneider J. Esomeprazole therapy for gastric acid hypersecretion in children with cystinosis. Pediatr Nephrol. 2005;20(12):1786-93. [pmid: 16133039]. Rec#: 57360 Reprint: exc nrc
Dome JS, Liu T, Krasin M, Lott L, Shearer P, Daw NC, Billups CA, Wilimas JA. Improved survival for patients with recurrent Wilms tumor: the experience at St. Jude Children's Research Hospital. J Pediatr Hematol Oncol. 2002;24(3):192-8. [pmid: 11990305]. Rec#: 12280 Reprint: exc nrp
Don DM, Newman AN, Fu YS. Spindle cell variant of embryonal rhabdomyosarcoma. Otolaryngol Head Neck Surg. 1997;116(4):529-32. [pmid: 9141404]. Rec#: 48280 Reprint: exc nrs
Donaldson SS, Torrey M, Link MP, Glicksman A, Gilula L, Laurie F, Manning J, Neff J, Reinus W, Thompson E, Shuster JJ. A multidisciplinary study investigating radiotherapy in Ewing's sarcoma: end results of POG #8346. Pediatric Oncology Group. Int J Radiat Oncol Biol Phys. 1998;42(1):125-35. [pmid: 9747829]. Rec#: 44180 Reprint: exc nrp
Doolittle ND, Anderson CP, Bleyer WA, Cairncross JG, Cloughesy T, Eck SL, Guastadisegni P, Hall WA, Muldoon LL, Patel SJ, Peereboom D, Siegal T, Neuwelt EA. Importance of dose intensity in neuro-oncology clinical trials: summary report of the Sixth Annual Meeting of the Blood-Brain Barrier Disruption Consortium. Neuro Oncol. 2001;3(1):46-54. [pmid: 11305417]. Rec#: 13870 Reprint: exc nrs
Drabko K, Winnicka D, Gaworczyk A, Ben-Skowronek I, Skomra D, Kowalczyk JR. Donor origin of Graves disease in a BMT recipient: evidence from FISH studies of thyroid tissue. 2006. Rec#: 5980 Reprint: exc nrs
DuBois SG, Messina J, Maris JM, Huberty J, Glidden DV, Veatch J, Charron M, Hawkins R, Matthay KK. Hematologic toxicity of high-dose iodine-131-metaiodobenzylguanidine therapy for advanced neuroblastoma. J Clin Oncol. 2004;22(12):2452-60. [pmid: 15197208]. Rec#: 8700 Reprint: EXC NRI
Duffner PK, Caviness VS Jr, Erbe RW, Patterson MC, Schultz KR, Wenger DA, Whitley C. The long-term outcomes of presymptomatic infants transplanted for Krabbe disease: report of the workshop held on July 11 and 12, 2008, Holiday Valley, New York. Genet Med. 2009;11(6):450-4. [pmid: 19346954]. Rec#: 320 Reprint: exc nr
Duffner PK, Horowitz ME, Krischer JP, Burger PC, Cohen ME, Sanford RA, Friedman HS, Kun LE. The treatment of malignant brain tumors in infants and very young children: an update of the Pediatric Oncology Group experience. Neuro Oncol. 1999;1(2):152-61. [pmid: 11554387]. Rec#: 73120 Reprint: exc nrt
Dunn JC, West KW, Rescorla FJ, Tres Scherer LR, Engum SA, Rouse TM, Smith JW, Grosfeld JL. The utility of lung biopsy in recipients of stem cell transplantation. J Pediatr Surg. 2001;36(8):1302-3. [pmid: 11479881]. Rec#: 13300 Reprint: EXC MIX
Dupuis-Girod S, Hartmann O, Benhamou E, Doz F, Mechinaud F, Bouffet E, Coze C, Kalifa C. Will high dose chemotherapy followed by autologous bone marrow transplantation supplant cranio-spinal irradiation in young children treated for medulloblastoma?. J Neurooncol. 1996;27(1):87-98. [pmid: 8699230]. Rec#: 21250 Reprint: EXC NRP
Dupuis-Girod S, Hartmann O, Benhamou E, Doz F, Mechinaud F, Bouffet E, Coze C, Kalifa C. [High-dose chemotherapy in relapse of medulloblastoma in young children]. Bull Cancer. 1997;84(3):264-72. [pmid: 9207872]. Rec#: 70880 Reprint: EXC NRP
Durando X, Lemaire JJ, Tortochaux J, Van-Praagh I, Kwiatkowski F, Vincent C, Bailly C, Verrelle P, Irthum B, Chazal J, Bay JO. High-dose BCNU followed by autologous hematopoietic stem cell transplantation in supratentorial high-grade malignant gliomas: a retrospective analysis of 114 patients. Bone Marrow Transplant. 2003;31(7):559-64. [pmid: 12692621]. Rec#: 10650 Reprint: exc pts in jacques-oliver
Dureau P, Broyer M, Dufier JL. Evolution of ocular manifestations in nephropathic cystinosis: a long-term study of a population treated with cysteamine. J Pediatr Ophthalmol Strabismus. 2003;40(3):142-6. [pmid: 12795432]. Rec#: 57640 Reprint: exc nrc
Eden BV, Debo RF, Larner JM, Kelly MD, Levine PA, Stewart FM, Cantrell RW, Constable WC. Esthesioneuroblastoma. Long-term outcome and patterns of failure--the University of Virginia experience. Cancer. 1994;73(10):2556-62. [pmid: 8174053]. Rec#: 22970 Reprint: EXC Year
Eden OB, Lilleyman JS. Guidelines for management of idiopathic thrombocytopenic purpura. The British Paediatric Haematology Group. Arch Dis Child. 1992;67(8):1056-8. [pmid: 1520013]. Rec#: 24960 Reprint: EXC YEAR
Eguchi H, Takaue Y, Kawano Y, Watanabe A, Watanabe T, Kikuta A, Koizumi S, Matsumura T, Sawada A, Horikoshi Y, Sekine Y, Koyama T, Shimokawa T, Shimizu K, Kawasaki K, Mugishima H, Takayama J, Ohira M, Ogawa M. Peripheral blood stem cell autografts for the treatment of children over 1 year old with stage IV neuroblastoma: a long-term follow-up. Bone Marrow Transplant. 1998;21(10):1011-4. [pmid: 9632274]. Rec#: 18050 Reprint: exc nri
Eliashiv S, Brenner T, Abramsky O, Shahin R, Agai E, Naparstek E, Steiner I. Acute inflammatory demyelinating polyneuropathy following bone marrow transplantation. Bone Marrow Transplant. 1991;8(4):315-7. [pmid: 1756330]. Rec#: 25870 Reprint: EXC YEAR
Elleder M, Kraus J, Kodet R. Infantile sialic acid storage disease (ISSD). Report on first case in Czech Republic with biopsy and autopsy findings. Sb Lek. 1993;94(2):145-53. [pmid: 7992007]. Rec#: 24590 Reprint: EXC YEAR
Elli M, Pinarli FG, Dagdemir A, Acar S. Veno-occlusive disease of the liver in a child after chemotherapy for brain tumor. Pediatr Blood Cancer. 2006;46(4):521-3. [pmid: 16317738]. Rec#: 6430 Reprint: EXC NRI
Elomaa I, Blomqvist C, Saeter G, Nilbert M, Monge OR, Wiebe T, Alvegard TA. Chemotherapy in Ewing's sarcoma. The Scandinavian Sarcoma Group experience. Acta Orthop Scand Suppl. 1999;285:69-73. [pmid: 10429626]. Rec#: 44080 Reprint: exc nrp
Elomaa I, Blomqvist CP, Saeter G, Akerman M, Stenwig E, Wiebe T, Bjork O, Alvegard TA. Five-year results in Ewing's sarcoma. The Scandinavian Sarcoma Group experience with the SSG IX protocol. Eur J Cancer. 2000;36(7):875-80. [pmid: 10785592]. Rec#: 43980 Reprint: exc nrp
Elstein D, Steinberg A, Abrahamov A, Zimran A. Ethical guidelines for enzyme therapy in neuronopathic Gaucher disease. Am J Hum Genet. 1997;61(4):A354. [pmid: 11644969]. Rec#: 57770 Reprint: exc nrs
Emminger W, Emminger-Schmidmeier W, Peters C, Hawliczek R, Hocker P, Gadner H. Is treatment intensification by adding etoposide and carboplatin to fractionated total body irradiation and melphalan acceptable in children with solid tumors with respect to toxicity?. Bone Marrow Transplant. 1991;8(2):119-23. [pmid: 1933052]. Rec#: 26030 Reprint: EXC YEAR
Emminger W, Gadner H. Fractionated total body irradiation, high-dose melphalan, etoposide, and carboplatin (FTBI-MEC) for autologous stem cell transplantation in children with advanced neuroblastoma and primitive neuroectodermal tumor. 1992. Rec#: 25250 Reprint: exc year
Endo H, Kumabe T, Jokura H, Shirane R, Ariga H, Takai Y, Yoshimoto T. Leptomeningeal dissemination of cerebellar malignant astrocytomas. J Neurooncol. 2003;63(2):191-9. [pmid: 12825824]. Rec#: 55490 Reprint: exc nrs
Eng CM, Banikazemi M, Gordon RE, Goldman M, Phelps R, Kim L, Gass A, Winston J, Dikman S, Fallon JT, Brodie S, Stacy CB, Mehta D, Parsons R, Norton K, O'Callaghan M, Desnick RJ. A phase 1/2 clinical trial of enzyme replacement in fabry disease: pharmacokinetic, substrate clearance, and safety studies. Am J Hum Genet. 2001;68(3):711-22. [pmid: 11179018]. Rec#: 57840 Reprint: exc nrc
Eng CM, Guffon N, Wilcox WR, Germain DP, Lee P, Waldek S, Caplan L, Linthorst GE, Desnick RJ. Safety and efficacy of recombinant human alpha-galactosidase A--replacement therapy in Fabry's disease. N Engl J Med. 2001;345(1):9-16. [pmid: 11439963]. Rec#: 57800 Reprint: exc nrc
Erduran E, Mocan H, Gedik Y, Kamaci R, Okten A, Deger O. Hydrocephalus, corneal opacities, deafness, left ventricle hypertrophy, clinodactyly in an adolescent patient. A new syndrome associated with glucocerebrosidase deficiency. Genet Couns. 1995;6(3):211-5. [pmid: 8588848]. Rec#: 22210 Reprint: EXC NRI
Escobar MA, Grosfeld JL, Powell RL, West KW, Scherer LR 3rd, Fallon RJ, Rescorla FJ. Long-term outcomes in patients with stage IV neuroblastoma. J Pediatr Surg. 2006;41(2):377-81. [pmid: 16481255]. Rec#: 6010 Reprint: exc nri
Evans AE, August CS, Kamani N, Bunin N, Goldwein J, Ross AJ 3rd, D'Angio GJ. Bone marrow transplantation for high risk neuroblastoma at the Children's Hospital of Philadelphia: an update. Med Pediatr Oncol. 1994;23(4):323-7. [pmid: 8058002]. Rec#: 23380 Reprint: EXC YEAR
Fagioli F, Biasin E, Mastrodicasa L, Sandri A, Ferrero I, Berger M, Vassallo E, Madon E. High-dose thiotepa and etoposide in children with poor-prognosis brain tumors. Cancer. 2004;100(10):2215-21. [pmid: 15139067]. Rec#: 8890 Reprint: EXC NRI NRP
Falcini F, Capannini S, Martini G, La Torre F, Vitale A, Mangiantini F, Nacci F, Cerinic MM, Cimaz R, Zulian F. Mycophenolate mofetil for the treatment of juvenile onset SLE: a multicenter study. Lupus. 2009;18(2):139-43. [pmid: 19151115]. Rec#: 40960 Reprint: exc nro
Fangusaro J, Massimino M, Rutkowski S, Gururangan S. Non-cerebellar primitive neuroectodermal tumors (PNET): summary of the Milan consensus and state of the art workshop on marrow ablative chemotherapy with hematopoietic cell rescue for malignant brain tumors of childhood and adolescents. Pediatr Blood Cancer. 2010;54(4):638-40. [pmid: 20146218]. Rec#: 70050 Reprint: EXC REV
Fangusaro JR, Jubran RF, Allen J, Gardner S, Dunkel IJ, Rosenblum M, Atlas MP, Gonzalez-Gomez I, Miller D, Finlay JL. Brainstem primitive neuroectodermal tumors (bstPNET): results of treatment with intensive induction chemotherapy followed by consolidative chemotherapy with autologous hematopoietic cell rescue. Pediatr Blood Cancer. 2008;50(3):715-7. [pmid: 17009232]. Rec#: 5000 Reprint: exc nrs
Farge D, Henegar C, Carmagnat M, Daneshpouy M, Marjanovic Z, Rabian C, Ilie D, Douay C, Mounier N, Clave E, Bengoufa D, Cabane J, Marolleau JP, Gluckman E, Charron D, Toubert A. Analysis of immune reconstitution after autologous bone marrow transplantation in systemic sclerosis. Arthritis Rheum. 2005;52(5):1555-63. [pmid: 15880600]. Rec#: 7350 Reprint: exc nrd
Farge D, Marolleau JP, Zohar S, Marjanovic Z, Cabane J, Mounier N, Hachulla E, Philippe P, Sibilia J, Rabian C, Chevret S, Gluckman E. Autologous bone marrow transplantation in the treatment of refractory systemic sclerosis: early results from a French multicentre phase I-II study. Br J Haematol. 2002;119(3):726-39. [pmid: 12437652]. Rec#: 11400 Reprint: exc nrs
Fassas A, Passweg J, Angnostopoulos A, Kazis. Hematopoietic stem cell transplantation for multiple sclerosis. J Neurol. 2002;249:1088-1097. [pmid: 12195460]. Rec#: Reprint: exc nrp
Feito JG, Pereda CA. Rituximab therapy produced rapid and sustained clinical improvement in a patient with systemic onset juvenile idiopathic arthritis refractory to TNF alpha antagonists. J Clin Rheumatol. 2009;15(7):363-5. [pmid: 20009975]. Rec#: 40840 Reprint: exc cr
Felix CA. A safer regimen for high-risk neuroblastoma. Pediatr Blood Cancer. 2009;53(1):3-6. [pmid: 19431215]. Rec#: 240 Reprint: EXC COM
Ferrari C, Bohling T, Benassi MS, Ferraro A, Gamberi G, Bacci G, Del prever A, Sangiorgi L, Ragazzini P, Sollazzo MR, Balladelli A, Picci P. Secondary tumors in bone sarcomas after treatment with chemotherapy. Cancer Detect Prev. 1999;23(5):368-74. [pmid: 10468888]. Rec#: 44050 Reprint: exc nrp
Ferreira RA, Vastert JS, Abinun M, Foster HE, Modesto C, Olive T, Kuis W, Wulffraat NM. Hemophagocytosis during fludarabine-based SCT for systemic juvenile idiopathic arthritis. 2006. Rec#: 5480 Reprint: exc nro
Fesslova V, Corti P, Sersale G, Rovelli A, Russo P, Mannarino S, Butera G, Parini R. The natural course and the impact of therapies of cardiac involvement in the mucopolysaccharidoses. Cardiol Young. 2009;19(2):170-8. [pmid: 19195419]. Rec#: 580 Reprint: exc nro
Finger PT, Czechonska G, Demirci H, Rausen A. Chemotherapy for retinoblastoma: a current topic. Drugs. 1999;58(6):983-96. [pmid: 10651386]. Rec#: 15740 Reprint: exc rev
Finlay JL, Wisoff JH. The impact of extent of resection in the management of malignant gliomas of childhood. Childs Nerv Syst. 1999;15(11-12):786-8. [pmid: 10603023]. Rec#: 15820 Reprint: exc rev
Fish JD, Grupp SA. Stem cell transplantation for neuroblastoma. Bone Marrow Transplant. 2008;41(2):159-65. [pmid: 18037943]. Rec#: 2890 Reprint: exc npd
Flandin I, Hartmann O, Michon J, Pinkerton R, Coze C, Stephan JL, Fourquet B, Valteau-Couanet D, Bergeron C, Philip T, Carrie C. Impact of TBI on late effects in children treated by megatherapy for Stage IV neuroblastoma. A study of the French Society of Pediatric oncology. Int J Radiat Oncol Biol Phys. 2006;64(5):1424-31. [pmid: 16427213]. Rec#: 6180 Reprint: exc nri
Flentje M, Weirich A, Graf N, Potter R, Zimmerman H, Ludwig R. Abdominal irradiation in unilateral nephroblastoma and its impact on local control and survival. Int J Radiat Oncol Biol Phys. 1998;40(1):163-9. [pmid: 9422573]. Rec#: 46130 Reprint: EXC NRP
Foeldvari I, Nielsen S, Kummerle-Deschner J, Espada G, Horneff G, Bica B, Olivieri AN, Wierk A, Saurenmann RK. Tumor necrosis factor-alpha blocker in treatment of juvenile idiopathic arthritis-associated uveitis refractory to second-line agents: results of a multinational survey. J Rheumatol. 2007;34(5):1146-50. [pmid: 17343318]. Rec#: 41350 Reprint: exc nrs
Fogarty PF, Seggewiss R, McCloskey DJ, Boss CA, Dunbar CE, Rick ME. Anti-interleukin-2 receptor antibody (daclizumab) treatment of corticosteroid-refractory autoimmune thrombocytopenic purpura. Haematologica. 2006;91(2):277-8. [pmid: 16461323]. Rec#: 77840 Reprint: exc ltr
Fogh SE, Andrews DW, Glass J, Curran W, Glass C, Champ C, Evans JJ, Hyslop T, Pequignot E, Downes B, Comber E, Maltenfort M, Dicker AP, Werner-Wasik M. Hypofractionated stereotactic radiation therapy: an effective therapy for recurrent high-grade gliomas. J Clin Oncol. 2010;28(18):3048-53. [pmid: 20479391]. Rec#: 54220 Reprint: exc nrp
Foncillas MA, Diaz MA, Sevilla J, Gonzalez Vicent M, Fernandez-Plaza S, Perez A, Madero L. Engraftment syndrome emerges as the main cause of transplant-related mortality in pediatric patients receiving autologous peripheral blood progenitor cell transplantation. J Pediatr Hematol Oncol. 2004;26(8):492-6. [pmid: 15284586]. Rec#: 8540 Reprint: exc nrd nrp
Foreman NK, Schissel D, Le T, Strain J, Fleitz J, Quinones R, Giller R. A study of sequential high dose cyclophosphamide and high dose carboplatin with peripheral stem-cell rescue in resistant or recurrent pediatric brain tumors. J Neurooncol. 2005;71(2):181-7. [pmid: 15690136]. Rec#: 7750 Reprint: exc nro
Foster H, Davidson J, Baildam E, Abinun M, Wedderburn LR. Autologous haematopoeitic stem cell rescue (AHSCR) for severe rheumatic disease in children: guidance for BSPAR members--executive summary. Rheumatology (Oxford). 2006;45(12):1570-1. [pmid: 17077155]. Rec#: 4750 Reprint: exc nrd
Fouladi M, Chintagumpala M, Ashley D, Kellie S, Gururangan S, Hassall T, Gronewold L, Stewart CF, Wallace D, Broniscer A, Hale GA, Kasow KA, Merchant TE, Morris B, Krasin M, Kun LE, Boyett JM, Gajjar A. Amifostine protects against cisplatin-induced ototoxicity in children with average-risk medulloblastoma. J Clin Oncol. 2008;26(22):3749-55. [pmid: 18669462]. Rec#: 1550 Reprint: EXC NRI
Fouladi M, Chintagumpala M, Laningham FH, Ashley D, Kellie SJ, Langston JW, McCluggage CW, Woo S, Kocak M, Krull K, Kun LE, Mulhern RK, Gajjar A. White matter lesions detected by magnetic resonance imaging after radiotherapy and high-dose chemotherapy in children with medulloblastoma or primitive neuroectodermal tumor. J Clin Oncol. 2004;22(22):4551-60. [pmid: 15542806]. Rec#: 8050 Reprint: EXC NRO
Fox E, Citrin D, Balis FM. The legacy of cancer therapy in children. J Natl Cancer Inst. 2009;101(16):1105-7. [pmid: 19648512]. Rec#: 40 Reprint: exc npd
Frappaz D, Bouffet E, Thiesse P, Mottolese C, Artiges V, Grabois M, Combaret V, Desuzinges C, Favrot M, Brunat Mentigny M, et al. Isolated intraspinal relapse of neuroblastoma after autologous bone marrow transplantation. Pediatr Hematol Oncol. 1994;11(4):439-43. [pmid: 7947018]. Rec#: 22890 Reprint: EXC Year
Frappaz D, Perol D, Michon J, Berger C, Coze C, Bernard JL, Zucker JM, Philip T. The LMCE5 unselected cohort of 25 children consecutively diagnosed with untreated stage 4 neuroblastoma over 1 year at diagnosis. Br J Cancer. 2002;87(11):1197-203. [pmid: 12439705]. Rec#: 11340 Reprint: exc nri
Frascella E, Pritchard-Jones K, Modak S, Mancini AF, Carli M, Pinkerton CR. Response of previously untreated metastatic rhabdomyosarcoma to combination chemotherapy with carboplatin, epirubicin and vincristine. Eur J Cancer. 1996;32A(5):821-5. [pmid: 9081360]. Rec#: 48370 Reprint: exc nro
Fraser CJ, Weigel BJ, Perentesis JP, Dusenbery KE, DeFor TE, Baker KS, Verneris MR. Autologous stem cell transplantation for high-risk Ewing's sarcoma and other pediatric solid tumors. Bone Marrow Transplant. 2006;37(2):175-81. [pmid: 16273111]. Rec#: 6510 Reprint: exc nro
Froissart R, Moreira da Silva I, Guffon N, Bozon D, Maire I. Mucopolysaccharidosis type II--genotype/phenotype aspects. Acta Paediatr Suppl. 2002;91(439):82-7. [pmid: 12572848]. Rec#: 11010 Reprint: exc dup
Frost JD, Hank JA, Reaman GH, Frierdich S, Seeger RC, Gan J, Anderson PM, Ettinger LJ, Cairo MS, Blazar BR, Krailo MD, Matthay KK, Reisfeld RA, Sondel PM. A phase I/IB trial of murine monoclonal anti-GD2 antibody 14.G2a plus interleukin-2 in children with refractory neuroblastoma: a report of the Children's Cancer Group. Cancer. 1997;80(2):317-33. [pmid: 9217046]. Rec#: 19130 Reprint: exc nri
Fujita M, Sato M, Nakamura M, Kudo K, Nagasaka T, Mizuno M, Amano E, Okamoto Y, Hotta Y, Hatano H, Nakahara N, Wakabayashi T, Yoshida J. Multicentric atypical teratoid/rhabdoid tumors occurring in the eye and fourth ventricle of an infant: case report. J Neurosurg. 2005;102(3 Suppl):299-302. [pmid: 15881754]. Rec#: 71970 Reprint: EXC NRD
Fukuda M, Kojima S, Matsumoto K, Matsuyama T. Autotransplantation of peripheral blood stem cells mobilized by chemotherapy and recombinant human granulocyte colony-stimulating factor in childhood neuroblastoma and non-Hodgkin's lymphoma. Br J Haematol. 1992;80(3):327-31. [pmid: 1374627]. Rec#: 25320 Reprint: EXC YEAR
Fukuda M, Miyajima Y, Miyashita Y, Horibe K. Disease outcome may be predicted by molecular detection of minimal residual disease in bone marrow in advanced neuroblastoma: a pilot study. J Pediatr Hematol Oncol. 2001;23(1):10-3. [pmid: 11196262]. Rec#: 14150 Reprint: exc nri
Gadner H. Is there evidence-based benefit of autologous stem cell transplantation in children with solid tumors?. Onkologie. 2002;25(3):278-81. [pmid: 12119464]. Rec#: 11900 Reprint: EXC COM
Gaipa G, Dassi M, Perseghin P, Venturi N, Corti P, Bonanomi S, Balduzzi A, Longoni D, Uderzo C, Biondi A, Masera G, Parini R, Bertagnolio B, Uziel G, Peters C, Rovelli A. Allogeneic bone marrow stem cell transplantation following CD34+ immunomagnetic enrichment in patients with inherited metabolic storage diseases. Bone Marrow Transplant. 2003;31(10):857-60. [pmid: 12748661]. Rec#: 10540 Reprint: exc nr
Gajjar A, Chintagumpala M, Ashley D, Kellie S, Kun LE, Merchant TE, Woo S, Wheeler G, Ahern V, Krasin MJ, Fouladi M, Broniscer A, Krance R, Hale GA, Stewart CF, Dauser R, Sanford RA, Fuller C, Lau C, Boyett JM, Wallace D, Gilbertson RJ. Risk-adapted craniospinal radiotherapy followed by high-dose chemotherapy and stem-cell rescue in children with newly diagnosed medulloblastoma (St Jude Medulloblastoma-96): long-term results from a prospective, multicentre trial. Lancet Oncol. 2006;7(10):813-20. [pmid: 17012043]. Rec#: 70350 Reprint: EXC NRI
Galvin-Parton PA. Screening for GALC to make neonatal diagnosis and initial neonatal stem cell treatment with umbilical cord blood. Pediatr Transplant. 2003;7(2):83-5. [pmid: 12654046]. Rec#: 10740 Reprint: exc nr
Garaventa A, Hartmann O, Bernard JL, Zucker JM, Pardo N, Castel V, Dallorso S, Adelbost Z, Ladenstein R, Chauvin F, et al. Autologous bone marrow transplantation for pediatric Wilms' tumor: the experience of the European Bone Marrow Transplantation Solid Tumor Registry. Med Pediatr Oncol. 1994;22(1):11-4. [pmid: 8232074]. Rec#: 23280 Reprint: EXC Year
Garaventa A, Ladenstein R, Chauvin F, Lanino E, Philip I, Corciulo P, Brisigotti M, Favrot M, Dini G, Philip T. High-dose chemotherapy with autologous bone marrow rescue in advanced stage IV neuroblastoma. Eur J Cancer. 1993;29A(4):487-91. [pmid: 8435197]. Rec#: 24410 Reprint: EXC YEAR
Garaventa A, Rondelli R, Lanino E, Dallorso S, Dini G, Bonetti F, Arrighini A, Santoro N, Rossetti F, Miniero R, Andolina M, Amici A, Indolfi P, Lo Curto M, Favre C, Paolucci P, Pession A, De Bernard B. Myeloablative therapy and bone marrow rescue in advanced neuroblastoma. Report from the Italian Bone Marrow Transplant Registry. Italian Association of Pediatric Hematology-Oncology, BMT Group. Bone Marrow Transplant. 1996;18(1):125-30. [pmid: 8832005]. Rec#: 20510 Reprint: EXC NRI
Gardner SL, Carreras J, Boudreau C, Camitta BM, Adams RH, Chen AR, Davies SM, Edwards JR, Grovas AC, Hale GA, Lazarus HM, Arora M, Stiff PJ, Eapen M. Myeloablative therapy with autologous stem cell rescue for patients with Ewing sarcoma. Bone Marrow Transplant. 2008;41(10):867-72. [pmid: 18246113]. Rec#: 2480 Reprint: exc nrp
Gaze MN, Chang YC, Flux GD, Mairs RJ, Saran FH, Meller ST. Feasibility of dosimetry-based high-dose 131I-meta-iodobenzylguanidine with topotecan as a radiosensitizer in children with metastatic neuroblastoma. Cancer Biother Radiopharm. 2005;20(2):195-9. [pmid: 15869455]. Rec#: 7380 Reprint: exc nro
George JN, Woolf SH, Raskob GE, Wasser JS, Aledort LM, Ballem PJ, Blanchette VS, Bussel JB, Cines DB, Kelton JG, Lichtin AE, McMillan R, Okerbloom JA, Regan DH, Warrier I. Idiopathic thrombocytopenic purpura: a practice guideline developed by explicit methods for the American Society of Hematology. Blood. 1996;88(1):3-40. [pmid: 8704187]. Rec#: 20580 Reprint: exc gui nra
George RE, London WB, Cohn SL, Maris JM, Kretschmar C, Diller L, Brodeur GM, Castleberry RP, Look AT. Hyperdiploidy plus nonamplified MYCN confers a favorable prognosis in children 12 to 18 months old with disseminated neuroblastoma: a Pediatric Oncology Group study. J Clin Oncol. 2005;23(27):6466-73. [pmid: 16116152]. Rec#: 6830 Reprint: exc nri
Germain DP, Waldek S, Banikazemi M, Bushinsky DA, Charrow J, Desnick RJ, Lee P, Loew T, Vedder AC, Abichandani R, Wilcox WR, Guffon N. Sustained, long-term renal stabilization after 54 months of agalsidase beta therapy in patients with Fabry disease. J Am Soc Nephrol. 2007;18(5):1547-57. [pmid: 17409312]. Rec#: 57020 Reprint: exc nrc
Gesundheit B, Cividalli G, Freeman A, Yatziv S, Koren G, Baruchel S. Cyclosporin A in the treatment of refractory immune thrombocytopenia purpura in children. Eur J Haematol. 2001;66(5):347-51. [pmid: 11422416]. Rec#: 78420 Reprint: exc nrc
Geyer JR, Balis FM, Krailo MD, Heideman R, Broxson E, Sato JK, Poplack D, Bleyer WA. A phase II study of thioTEPA in children with recurrent solid tumor malignancies: a Children's Cancer Group study. Invest New Drugs. 1996;13(4):337-42. [pmid: 8824353]. Rec#: 44530 Reprint: exc few
Ghavamzadeh A, Alimoghaddam K, Jahani M, Mousavi SA, Iravani M, Bahar B, Khodabandeh A, Khatami F, Gaffari F, Jalali A. Stem cell transplantation; Iranian experience. Arch Iran Med. 2009;12(1):69-72. [pmid: 19111033]. Rec#: 790 Reprint: EXC NRO
Giannini EH, Ilowite NT, Lovell DJ, Wallace CA, Rabinovich CE, Reiff A, Higgins G, Gottlieb B, Singer NG, Chon Y, Lin SL, Baumgartner SW. Long-term safety and effectiveness of etanercept in children with selected categories of juvenile idiopathic arthritis. Arthritis Rheum. 2009;60(9):2794-804. [pmid: 19714630]. Rec#: 77100 Reprint: exc nrp
Giraldo P, Pocovi M, Perez-Calvo J, Rubio-Felix D, Giralt M. Report of the Spanish Gaucher's disease registry: clinical and genetic characteristics. Haematologica. 2000;85(8):792-9. [pmid: 10942924]. Rec#: 14960 Reprint: exc nrs
Gluckman E. Bone marrow transplantation in children with hereditary disorders. Curr Opin Pediatr. 1996;8(1):42-4. [pmid: 8680513]. Rec#: 21060 Reprint: EXC REV
Goiriz R, Penas PF, Delgado-Jimenez Y, Fernandez-Herrera J, Aragues-Montanes M, Fraga J, Garcia-Diez A. Cutaneous lichenoid graft-versus-host disease mimicking lupus erythematosus. Lupus. 2008;17(6):591-5. [pmid: 18539715]. Rec#: 1910 Reprint: exc nrs
Goldberg SS, DeSantes K, Huberty JP, Price D, Hasegawa BH, Reynolds CP, Seeger RC, Hattner R, Matthay KK. Engraftment after myeloablative doses of 131I-metaiodobenzylguanidine followed by autologous bone marrow transplantation for treatment of refractory neuroblastoma. Med Pediatr Oncol. 1998;30(6):339-46. [pmid: 9589082]. Rec#: 18210 Reprint: exc nri
Goldblatt J, Szer J, Fletcher JM, McGill J, Rowell JA, Wilson M. Enzyme replacement therapy for Gaucher disease in Australia. Intern Med J. 2005;35(3):156-61. [pmid: 15737135]. Rec#: 57460 Reprint: exc nrp
Goldsby R, Pulsipher M, Adams R, Coffin C, Albritton K, Wagner L. 2002. Rec#: 11360 Reprint: exc nrs
Gonzalez-Vicent M, Diaz MA, Garcia-Sanchez F, Molina J, Madero L. Early onset of evans syndrome following autologous peripheral blood progenitor cell transplantation in a child. Haematologica. 2002;87(5):ECR17. [pmid: 12010680]. Rec#: 12180 Reprint: exc nri
Gordon SJ, Pearson AD, Reid MM, Craft AW. Toxicity of single-day high-dose vincristine, melphalan, etoposide and carboplatin consolidation with autologous bone marrow rescue in advanced neuroblastoma. Eur J Cancer. 1992;28A(8-9):1319-23. [pmid: 1515242]. Rec#: 25480 Reprint: EXC YEAR
Gorelik M, Debski R, Frangoul H. Autoimmune hemolytic anemia with giant cell hepatitis: case report and review of the literature. J Pediatr Hematol Oncol. 2004;26(12):837-9. [pmid: 15591908]. Rec#: 78000 Reprint: exc nri cr
Goto H, Kousaka A, Takano S, Usui M. Recurrence of retinoblastoma 12 years after brachytherapy. Am J Ophthalmol. 2002;134(5):773-5. [pmid: 12429261]. Rec#: 48900 Reprint: exc nro
Goto S, Goto H, Tanoshima R, Kato H, Takahashi H, Sekiguchi O, Kai S. Serum sickness with an elevated level of human anti-chimeric antibody following treatment with rituximab in a child with chronic immune thrombocytopenic purpura. Int J Hematol. 2009;89(3):305-9. [pmid: 19308659]. Rec#: 77430 Reprint: exc nro
Gottardo NG, Baker DL, Willis FR. Successful induction and maintenance of long-term remission in a child with chronic relapsing autoimmune hemolytic anemia using rituximab. Pediatr Hematol Oncol. 2003;20(7):557-61. [pmid: 12959862]. Rec#: 78160 Reprint: exc nrc
Gottlieb PA, Quinlan S, Krause-Steinrauf H, Greenbaum CJ, Wilson DM, Rodriguez H, Schatz DA, Moran AM, Lachin JM, Skyler JS. Failure to preserve beta-cell function with mycophenolate mofetil and daclizumab combined therapy in patients with new- onset type 1 diabetes. Diabetes Care. 2010;33(4):826-32. [pmid: 20067954]. Rec#: 40000 Reprint: exc nrp
Gottlober P, Leiter U, Friedrich W, Bunjes D, Schulz A, Kerscher M, Peter RU. Chronic cutaneous sclerodermoid graft-versus-host disease: evaluation by 20-MHz sonography. J Eur Acad Dermatol Venereol. 2003;17(4):402-7. [pmid: 12834449]. Rec#: 10290 Reprint: exc nrs
Grabenbauer GG, Beck JD, Erhardt J, Seegenschmiedt MH, Seyer H, Thierauf P, Sauer R. Postoperative radiotherapy of medulloblastoma. Impact of radiation quality on treatment outcome. Am J Clin Oncol. 1996;19(1):73-7. [pmid: 8554041]. Rec#: 21090 Reprint: EXC NRI
Graham ML, Herndon JE 2nd, Casey JR, Chaffee S, Ciocci GH, Krischer JP, Kurtzberg J, Laughlin MJ, Longee DC, Olson JF, Paleologus N, Pennington CN, Friedman HS. High-dose chemotherapy with autologous stem-cell rescue in patients with recurrent and high-risk pediatric brain tumors. J Clin Oncol. 1997;15(5):1814-23. [pmid: 9164190]. Rec#: 73220 Reprint: exc nro
Green DM, Breslow NE, Beckwith JB, Finklestein JZ, Grundy PE, Thomas PR, Kim T, Shochat SJ, Haase GM, Ritchey ML, Kelalis PP, D'Angio GJ. Comparison between single-dose and divided-dose administration of dactinomycin and doxorubicin for patients with Wilms' tumor: a report from the National Wilms' Tumor Study Group. J Clin Oncol. 1998;16(1):237-45. [pmid: 9440748]. Rec#: 46120 Reprint: EXC NRP
Green DM, Cotton CA, Malogolowkin M, Breslow NE, Perlman E, Miser J, Ritchey ML, Thomas PR, Grundy PE, D'Angio GJ, Beckwith JB, Shamberger RC, Haase GM, Donaldson M, Weetman R, Coppes MJ, Shearer P, Coccia P, Kletzel M, Macklis R, Tomlinson G, Huff V, Newbury R, Weeks D. Treatment of Wilms tumor relapsing after initial treatment with vincristine and actinomycin D: a report from the National Wilms Tumor Study Group. Pediatr Blood Cancer. 2007;48(5):493-9. [pmid: 16547940]. Rec#: 45120 Reprint: exc nrp
Grier HE, Krailo MD, Tarbell NJ, Link MP, Fryer CJ, Pritchard DJ, Gebhardt MC, Dickman PS, Perlman EJ, Meyers PA, Donaldson SS, Moore S, Rausen AR, Vietti TJ, Miser JS. Addition of ifosfamide and etoposide to standard chemotherapy for Ewing's sarcoma and primitive neuroectodermal tumor of bone. N Engl J Med. 2003;348(8):694-701. [pmid: 12594313]. Rec#: 43720 Reprint: exc nrp
Grill J, Dufour C, Kalifa C. 2006. Rec#: 4990 Reprint: exc nrs
Grill J, Sainte-Rose C, Jouvet A, Gentet JC, Lejars O, Frappaz D, Doz F, Rialland X, Pichon F, Bertozzi AI, Chastagner P, Couanet D, Habrand JL, Raquin MA, Le Deley MC, Kalifa C. Treatment of medulloblastoma with postoperative chemotherapy alone: an SFOP prospective trial in young children. Lancet Oncol. 2005;6(8):573-80. [pmid: 16054568]. Rec#: 52660 Reprint: EXC NRP
Grodman H, Wolfe L, Kretschmar C. Outcome of patients with recurrent medulloblastoma or central nervous system germinoma treated with low dose continuous intravenous etoposide along with dose-intensive chemotherapy followed by autologous hematopoietic stem cell rescue. Pediatr Blood Cancer. 2009;53(1):33-6. [pmid: 19326417]. Rec#: 350 Reprint: EXC NRI NRP
Gruhn B, Meerbach A, Egerer R, Mentzel HJ, Hafer R, Ringelmann F, Sauer M, Hermann J, Zintl F. Successful treatment of Epstein-Barr virus-induced transverse myelitis with ganciclovir and cytomegalovirus hyperimmune globulin following unrelated bone marrow transplantation. Bone Marrow Transplant. 1999;24(12):1355-8. [pmid: 10627648]. Rec#: 15790 Reprint: exc nrs
Grygotis LA, Chew FS. Choroid plexus carcinoma of the lateral ventricle. AJR Am J Roentgenol. 1997;169(5):1400. [pmid: 9353468]. Rec#: 76630 Reprint: EXC NRI
Grzeskowiak-Melanowska J, Skoczen S, Armata J. What is the best method of prevention of therapeutic failures in CNS in high risk retinoblastoma?. Med Pediatr Oncol. 1997;28(1):79. [pmid: 8950344]. Rec#: 49190 Reprint: exc nrd
Guglielmi M, De Bernardi B, Rizzo A, Federici S, Boglino C, Siracusa F, Leggio A, Cozzi F, Cecchetto G, Musi L, Bardini T, Fagnani AM, Bartoli GC, Pampaloni A, Rogers D, Conte M, Milanaccio C, Bruzzi P. Resection of primary tumor at diagnosis in stage IV-S neuroblastoma: does it affect the clinical course?. J Clin Oncol. 1996;14(5):1537-44. [pmid: 8622069]. Rec#: 20820 Reprint: EXC NRI
Guinan EC, Kalish LA, Berry WS, McDaniel S, Lehmann LE, Diller LR. A novel pattern of transaminase elevation associated with autologous transplant for neuroblastoma. Pediatr Transplant. 2006;10(6):669-76. [pmid: 16911489]. Rec#: 5160 Reprint: exc nri
Gullingsrud EO, Krivit W, Summers CG. Ocular abnormalities in the mucopolysaccharidoses after bone marrow transplantation. Longer follow-up. Ophthalmology. 1998;105(6):1099-105. [pmid: 9627663]. Rec#: 18080 Reprint: exc nrp
Gur-Lavi M. Long-term remission with allogenic bone marrow transplantation in systemic lupus erythematosus. Arthritis Rheum. 1999;42(8):1777. [pmid: 10446881]. Rec#: 16510 Reprint: exc nrp
Gurney JG. Neuroblastoma, childhood cancer survivorship, and reducing the consequences of cure. Bone Marrow Transplant. 2007;40(8):721-2. [pmid: 17912265]. Rec#: 3100 Reprint: exc edt
Gururangan S, McLaughlin C, Quinn J, Rich J, Reardon D, Halperin EC, Herndon J 2nd, Fuchs H, George T, Provenzale J, Watral M, McLendon RE, Friedman A, Friedman HS, Kurtzberg J, Vredenbergh J, Martin PL. High-dose chemotherapy with autologous stem-cell rescue in children and adults with newly diagnosed pineoblastomas. J Clin Oncol. 2003;21(11):2187-91. [pmid: 12775745]. Rec#: 71520 Reprint: EXC NRD
Gutweiler JR, Yu DC, Kim HB, Kozakewich HP, Marcus KJ, Shamberger RC, Weldon CB. Hepatoblastoma presenting with focal nodular hyperplasia after treatment of neuroblastoma. J Pediatr Surg. 2008;43(12):2297-300. [pmid: 19040959]. Rec#: 950 Reprint: exc nro
Gwak HS, Youn SM, Kwon AH, Lee SH, Kim JH, Rhee CH. ACNU-cisplatin continuous infusion chemotherapy as salvage therapy for recurrent glioblastomas: phase II study. J Neurooncol. 2005;75(2):173-80. [pmid: 16132508]. Rec#: 6750 Reprint: exc nri nrp
Haas-Kogan DA, Swift PS, Selch M, Haase GM, Seeger RC, Gerbing RB, Stram DO, Matthay KK. Impact of radiotherapy for high-risk neuroblastoma: a Children's Cancer Group study. Int J Radiat Oncol Biol Phys. 2003;56(1):28-39. [pmid: 12694821]. Rec#: 10630 Reprint: exc nri
Hagglund H, Ringden O, Remberger M, Lonnqvist B, Sparrelid E, Tammik L, Kumlien G. Faster neutrophil and platelet engraftment, but no differences in acute GVHD or survival, using peripheral blood stem cells from related and unrelated donors, compared to bone marrow. Bone Marrow Transplant. 1998;22(2):131-6. [pmid: 9707019]. Rec#: 17820 Reprint: exc nrp
Hajioff D, Goodwin S, Quiney R, Zuckerman J, MacDermot KD, Mehta A. Hearing improvement in patients with Fabry disease treated with agalsidase alfa. Acta Paediatr Suppl. 2003;92(443):28-30. [pmid: 14989462]. discussion 27 Rec#: 57550 Reprint: exc nrc
Hajnzic TF, Marotti M, Vrsalovic R. Long-term survival after recurrent retinoblastoma and second malignancy with massive lung metastasis. Eur J Pediatr. 2004;163(11):685-6. [pmid: 15309622]. Rec#: 48760 Reprint: exc nrs
Halevi R, Davidovitz M, Mann S, Ben-Bassat M, Stark H, Eisenstein B. Gaucher's disease and mesangiocapillary glomerulonephritis in childhood--a coincidence?. Pediatr Nephrol. 1993;7(4):438-40. [pmid: 8398656]. Rec#: 23920 Reprint: EXC NRI
Hamilton J, Capell H. The treatment of juvenile arthritis. Expert Opin Pharmacother. 2001;2(7):1085-92. [pmid: 11583059]. Rec#: 13070 Reprint: exc nra
Han JW, Kwon SY, Won SC, Shin YJ, Ko JH, Lyu CJ. Comprehensive clinical follow-up of late effects in childhood cancer survivors shows the need for early and well-timed intervention. Ann Oncol. 2009;20(7):1170-7. [pmid: 19270031]. Rec#: 440 Reprint: exc nro
Handgretinger R, Lang P, Ihm K, Schumm M, Geiselhart A, Koscielniak E, Hero B, Klingebiel T, Niethammer D. Isolation and transplantation of highly purified autologous peripheral CD34(+) progenitor cells: purging efficacy, hematopoietic reconstitution and long-term outcome in children with high-risk neuroblastoma. Bone Marrow Transplant. 2002;29(9):731-6. [pmid: 12040469]. Rec#: 12090 Reprint: exc nri
Handgretinger R, Leung W, Ihm K, Lang P, Klingebiel T, Niethammer D. Tumour cell contamination of autologous stem cells grafts in high-risk neuroblastoma: the good news?. Br J Cancer. 2003;88(12):1874-7. [pmid: 12799629]. Rec#: 10410 Reprint: exc nri
Hanke CA, Roessler J, Stegmaier S, Koscielniak E, Niemeyer CM, Kontny U. Alveolar rhabdomyosarcoma mimicking lymphoma with bone marrow involvement. Eur J Pediatr. 2007;166(5):505-6. [pmid: 17008999]. Rec#: 47140 Reprint: exc nrs
Harbour JW. What is the best treatment for retinoblastoma?. Am J Ophthalmol. 2004;138(3):471-3. [pmid: 15364232]. Rec#: 48740 Reprint: exc rev
Hartmann O, Valteau-Couanet D, Benhamou E, Vassal G, Rubie H, Beaujean F, Lemerle J. Stage IV neuroblastoma in patients over 1 year of age at diagnosis: consolidation of poor responders with combined busulfan, cyclophosphamide and melphalan followed by in vitro mafosfamide-purged autologous bone marrow transplantation. Eur J Cancer. 1997;33(12):2126-9. [pmid: 9516867]. Rec#: 18480 Reprint: exc nri
Hartmann O, Valteau-Couanet D, Vassal G, Lapierre V, Brugieres L, Delgado R, Couanet D, Lumbroso J, Benhamou E. Prognostic factors in metastatic neuroblastoma in patients over 1 year of age treated with high-dose chemotherapy and stem cell transplantation: a multivariate analysis in 218 patients treated in a single institution. Bone Marrow Transplant. 1999;23(8):789-95. [pmid: 10231141]. Rec#: 16890 Reprint: exc nri
Hartsell WF, Gajjar A, Heideman RL, Langston JA, Sanford RA, Walter A, Jones D, Chen G, Kun LE. Patterns of failure in children with medulloblastoma: effects of preirradiation chemotherapy. Int J Radiat Oncol Biol Phys. 1997;39(1):15-24. [pmid: 9300735]. Rec#: 19040 Reprint: EXC NRI
Hashii Y, Kusafuka T, Ohta H, Yoneda A, Osugi Y, Kobayashi Y, Fukuzawa M, Hara J. A case series of children with high-risk metastatic neuroblastoma treated with a novel treatment strategy consisting of postponed primary surgery until the end of systemic chemotherapy including high-dose chemotherapy. Pediatr Hematol Oncol. 2008;25(5):439-50. [pmid: 18569846]. Rec#: 1800 Reprint: exc nri
Hathirat P, Numhom S, Chuansumrit A, Chantarojanasiri T, Sirinavin S, Isarangkura P. Hepatopathy-thrombocytopenia vs infection-induced hemophagocytic syndrome in Wilms' tumor: a case report. J Med Assoc Thai. Suppl 2. 1993;76:240-3. [pmid: 7823002]. Rec#: 23850 Reprint: EXC YEAR
Hawkins DS, Bradfield S, Whitlock JA, Krailo M, Franklin J, Blaney SM, Adamson PC, Reaman G. Topotecan by 21-day continuous infusion in children with relapsed or refractory solid tumors: a Children's Oncology Group study. Pediatr Blood Cancer. 2006;47(6):790-4. [pmid: 16435380]. Rec#: 43310 Reprint: exc nro
Hawkins DS, Felgenhauer J, Park J, Kreissman S, Thomson B, Douglas J, Rowley SD, Gooley T, Sanders JE, Pendergrass TW. Peripheral blood stem cell support reduces the toxicity of intensive chemotherapy for children and adolescents with metastatic sarcomas. Cancer. 2002;95(6):1354-65. [pmid: 12216105]. Rec#: 11660 Reprint: EXC NRI
Hayani A, Mahoney DH Jr, Steuber CP, Saleem A. Recombinant interferon alfa-2b therapy in children with immune thrombocytopenic purpura. 1993. Rec#: 24020 Reprint: exc year
Hayani A, Mahoney DH Jr, Taylor LD. Therapy-related myelodysplastic syndrome in children with medulloblastoma following MOPP chemotherapy. J Neurooncol. 1992;14(1):57-62. [pmid: 1469465]. Rec#: 24880 Reprint: EXC YEAR
Hayashi M, Matsuda O, Ishida Y, Kida K. Change of immunological parameters in the clinical course of a myasthenia gravis patient with chronic graft-versus-host disease. Acta Paediatr Jpn. 1996;38(2):151-5. [pmid: 8677793]. Rec#: 20900 Reprint: exc nrs
Hayes-Jordan A, Benaim E, Richardson S, Joglar J, Srivastava DK, Bowman L, Shochat SJ. Open lung biopsy in pediatric bone marrow transplant patients. J Pediatr Surg. 2002;37(3):446-52. [pmid: 11877664]. Rec#: 12520 Reprint: exc nrd nro
Haysom L, Ziegler DS, Cohn RJ, Rosenberg AR, Carroll SL, Kainer G. Retinoic acid may increase the risk of bone marrow transplant nephropathy. Pediatr Nephrol. 2005;20(4):534-8. [pmid: 15719254]. Rec#: 7660 Reprint: exc nri
Heath JA, Broxson EH Jr, Dole MG, Filippa DA, George D, Lyden D, Dunkel IJ. Epstein-Barr virus-associated lymphoma in a child undergoing an autologous stem cell rescue. J Pediatr Hematol Oncol. 2002;24(2):160-3. [pmid: 11998794]. Rec#: 12220 Reprint: exc nrd
Heath JA, Moore K, Spriggs M, Waters KD. When two worlds collide. J Clin Oncol. 2007;25(25):4015-7. [pmid: 17761988]. discussion 4018-9 Rec#: 3310 Reprint: EXC EDT
Heegaard ED, Rosthoj S, Petersen BL, Nielsen S, Karup Pedersen F, Hornsleth A. Role of parvovirus B19 infection in childhood idiopathic thrombocytopenic purpura. Acta Paediatr. 1999;88(6):614-7. [pmid: 10419244]. Rec#: 16580 Reprint: exc nro
Heesters M, Molenaar W, Go GK. Radiotherapy in supratentorial gliomas. A study of 821 cases. Strahlenther Onkol. 2003;179(9):606-14. [pmid: 14628126]. Rec#: 55440 Reprint: exc nrp
Heitger A, Kern H, Mayerl D, Maurer K, Nachbaur D, Fruhwirth M, Fink FM, Niederwieser D. Effective T cell regeneration following high-dose chemotherapy rescued with CD34+ cell enriched peripheral blood progenitor cells in children. Bone Marrow Transplant. 1999;23(4):347-53. [pmid: 10100578]. Rec#: 16990 Reprint: EXC NRO
Henrickson M, Reiff A. Prolonged efficacy of etanercept in refractory enthesitis-related arthritis. J Rheumatol. 2004;31(10):2055-61. [pmid: 15468375]. Rec#: 41730 Reprint: exc nrd
Hero B, Kremens B, Klingebiel T, Bender-Gotze C, Burdach S, Schrappe M, Berthold F. Does megatherapy contribute to survival in metastatic neuroblastoma? A retrospective analysis. German Cooperative Neuroblastoma Study Group. Klin Padiatr. 1997;209(4):196-200. [pmid: 9293450]. Rec#: 19170 Reprint: exc nri
Herold KC, Gitelman S, Greenbaum C, Puck J, Hagopian W, Gottlieb P, Sayre P, Bianchine P, Wong E, Seyfert-Margolis V, Bourcier K, Bluestone JA. Treatment of patients with new onset Type 1 diabetes with a single course of anti-CD3 mAb Teplizumab preserves insulin production for up to 5 years. Clin Immunol. 2009;132(2):166-73. [pmid: 19443276]. Rec#: 40020 Reprint: exc nri
Herold KC, Gitelman SE, Masharani U, Hagopian W, Bisikirska B, Donaldson D, Rother K, Diamond B, Harlan DM, Bluestone JA. A single course of anti-CD3 monoclonal antibody hOKT3gamma1(Ala-Ala) results in improvement in C-peptide responses and clinical parameters for at least 2 years after onset of type 1 diabetes. Diabetes. 2005;54(6):1763-9. [pmid: 15919798]. Rec#: 40310 Reprint: exc nrc
Herold KC, Hagopian W, Auger JA, Poumian-Ruiz E, Taylor L, Donaldson D, Gitelman SE, Harlan DM, Xu D, Zivin RA, Bluestone JA. Anti-CD3 monoclonal antibody in new-onset type 1 diabetes mellitus. N Engl J Med. 2002;346(22):1692-8. [pmid: 12037148]. Rec#: 40470 Reprint: exc nrc
Herr AL, Hatami A, Kokta V, Dalle JH, Champagne MA, Duval M. Successful anti-CD20 antibody treatment of pemphigus foliaceus after unrelated cord blood transplantation. 2005. Rec#: 7820 Reprint: exc nrd
Higman MA, Port JD, Beauchamp NJ Jr, Chen AR. Reversible leukoencephalopathy associated with re-infusion of DMSO preserved stem cells. Bone Marrow Transplant. 2000;26(7):797-800. [pmid: 11042664]. Rec#: 14680 Reprint: EXC NRO
Higuchi LM, Joffe S, Neufeld EJ, Weisdorf S, Rosh J, Murch S, Devenyi A, Thompson JF, Lewis JD, Bousvaros A. Inflammatory bowel disease associated with immune thrombocytopenic purpura in children. J Pediatr Gastroenterol Nutr. 2001;33(5):582-7. [pmid: 11740233]. Rec#: 12820 Reprint: exc nro
Hilden J, Meerbaum S, Burger P, Finlay J. Central Nervous System Atypical Tetroid/Rhabdoid Tumor: results of therapy in children enrolled in a registry. J Clin Oncol. 2004;22:2877-2884. [pmid: 15254056]. Rec#: Reprint: exc nri
Hilden JM, Watterson J, Longee DC, Moertel CL, Dunn ME, Kurtzberg J, Scheithauer BW. Central nervous system atypical teratoid tumor/rhabdoid tumor: response to intensive therapy and review of the literature. J Neurooncol. 1998;40(3):265-75. [pmid: 10066100]. Rec#: 17140 Reprint: EXC NR
Hilgendorf I, Wolff D, Wilhelm S, Steiner B, Kiefel V, Hickstein H, Junghanss C, Freund M, Casper J. T-cell-depleted stem cell boost for the treatment of autoimmune haemolytic anaemia after T-cell-depleted allogeneic bone marrow transplantation complicated by adenovirus infection. 2006. Rec#: 5830 Reprint: exc nrs
Hill G, Castellino S, Williams D. Cardiac myxoma after treatment for childhood neuroblastoma. Pediatr Cardiol. 2009;30(3):340-2. [pmid: 18716707]. Rec#: 1470 Reprint: exc nri
Hinterberger W, Hinterberger-Fischer M, Marmont A. Clinically demonstrable anti-autoimmunity mediated by allogeneic immune cells favorably affects outcome after stem cell transplantation in human autoimmune diseases. Bone Marrow Transplant. 2002;30(11):753-9. [pmid: 12439698]. Rec#: 11350 Reprint: exc nrs
Hirayama M, Azuma E, Araki M, Komada Y, Nakagawa A. Evidence of graft-versus-tumor effect in refractory metastatic neuroblastoma. 2006. Rec#: 5260 Reprint: exc nro
Hoffmann B, Schwarz M, Mehta A, Keshav S. Gastrointestinal symptoms in 342 patients with Fabry disease: prevalence and response to enzyme replacement therapy. Clin Gastroenterol Hepatol. 2007;5(12):1447-53. [pmid: 17919989]. Rec#: 56910 Reprint: exc nrc
Hoffmeister PA, Madtes DK, Storer BE, Sanders JE. Pulmonary function in long-term survivors of pediatric hematopoietic cell transplantation. Pediatr Blood Cancer. 2006;47(5):594-606. [pmid: 16086420]. Rec#: 6890 Reprint: exc nro
Hoffmeister PA, Storer BE, Sanders JE. Diabetes mellitus in long-term survivors of pediatric hematopoietic cell transplantation. J Pediatr Hematol Oncol. 2004;26(2):81-90. [pmid: 14767193]. Rec#: 9300 Reprint: exc nrd nri
Holcomb GW 3rd, Greene HL. Fatal hemorrhage caused by disease progression after partial splenectomy for type III Gaucher's disease. J Pediatr Surg. 1993;28(12):1572-4. [pmid: 8301495]. Rec#: 23580 Reprint: EXC NRI
Holland FJ, McConnon JK, Volpe R, Saunders EF. Concordant Graves' disease after bone marrow transplantation: implications for pathogenesis. J Clin Endocrinol Metab. 1991;72(4):837-40. [pmid: 2005210]. Rec#: 26250 Reprint: EXC YEAR
Holmberg LA, Boeckh M, Hooper H, Leisenring W, Rowley S, Heimfeld S, Press O, Maloney DG, McSweeney P, Corey L, Maziarz RT, Appelbaum FR, Bensinger W. Increased incidence of cytomegalovirus disease after autologous CD34-selected peripheral blood stem cell transplantation. Blood. 1999;94(12):4029-35. [pmid: 10590046]. Rec#: 15860 Reprint: EXC MIX
Holtta P, Alaluusua S, Saarinen-Pihkala UM, Wolf J, Nystrom M, Hovi L. Long-term adverse effects on dentition in children with poor-risk neuroblastoma treated with high-dose chemotherapy and autologous stem cell transplantation with or without total body irradiation. Bone Marrow Transplant. 2002;29(2):121-7. [pmid: 11850706]. Rec#: 12600 Reprint: exc nri
Hon C, Chan GC, Ha SY, Ma SK, Wong KF, Au WY. Bone marrow transplantation for therapy-related acute myeloid leukemia in congenital retinoblastoma associated with 13q deletion syndrome. Ann Hematol. 2004;83(7):481-3. [pmid: 15170522]. Rec#: 8770 Reprint: exc nro
Horibe K, Fukuda M, Miyajima Y, Matsumoto K, Kondo M, Inaba J, Miyashita Y. Outcome prediction by molecular detection of minimal residual disease in bone marrow for advanced neuroblastoma. Med Pediatr Oncol. 2001;36(1):203-4. [pmid: 11464885]. Rec#: 13400 Reprint: exc nri
Horn B, Reiss U, Matthay K, McMillan A, Cowan M. Veno-occlusive disease of the liver in children with solid tumors undergoing autologous hematopoietic progenitor cell transplantation: a high incidence in patients with neuroblastoma. Bone Marrow Transplant. 2002;29(5):409-15. [pmid: 11919731]. Rec#: 12420 Reprint: exc nri
Horneff G, De Bock F, Foeldvari I, Girschick HJ, Michels H, Moebius D, Schmeling H. Safety and efficacy of combination of etanercept and methotrexate compared to treatment with etanercept only in patients with juvenile idiopathic arthritis (JIA): preliminary data from the German JIA Registry. Ann Rheum Dis. 2009;68(4):519-25. [pmid: 18413440]. Rec#: 77190 Reprint: exc nri
Horowitz ME, Kinsella TJ, Wexler LH, Belasco J, Triche T, Tsokos M, Steinberg SM, McClure L, Longo DL, Steis RG, et al. Total-body irradiation and autologous bone marrow transplant in the treatment of high-risk Ewing's sarcoma and rhabdomyosarcoma. J Clin Oncol. 1993;11(10):1911-8. [pmid: 8410118]. Rec#: 23760 Reprint: EXC YEAR
Houssiau FA, Vasconcelos C, D'Cruz D, Sebastiani GD, Garrido Ed Ede R, Danieli MG, Abramovicz D, Blockmans D, Mathieu A, Direskeneli H, Galeazzi M, Gul A, Levy Y, Petera P, Popovic R, Petrovic R, Sinico RA, Cattaneo R, Font J, Depresseux G, Cosyns JP, Cervera R. Immunosuppressive therapy in lupus nephritis: the Euro-Lupus Nephritis Trial, a randomized trial of low-dose versus high-dose intravenous cyclophosphamide. Arthritis Rheum. 2002;46(8):2121-31. [pmid: 12209517]. Rec#: 42000 Reprint: exc nrp
Hovi L, Saarinen-Pihkala UM, Vettenranta K, Lipsanen M, Tapanainen P. Growth in children with poor-risk neuroblastoma after regimens with or without total body irradiation in preparation for autologous bone marrow transplantation. Bone Marrow Transplant. 1999;24(10):1131-6. [pmid: 10578163]. Rec#: 15940 Reprint: exc nri
Hoyles RK, Ellis RW, Wellsbury J, Lees B, Newlands P, Goh NS, Roberts C, Desai S, Herrick AL, McHugh NJ, Foley NM, Pearson SB, Emery P, Veale DJ, Denton CP, Wells AU, Black CM, du Bois RM. A multicenter, prospective, randomized, double-blind, placebo-controlled trial of corticosteroids and intravenous cyclophosphamide followed by oral azathioprine for the treatment of pulmonary fibrosis in scleroderma. Arthritis Rheum. 2006;54(12):3962-70. [pmid: 17133610]. Rec#: 4610 Reprint: exc nrp
Hsu TR, Wong TT, Chang FC, Ho DM, Tang RB, Thien PF, Chang KP. Responsiveness of progressive optic pathway tumors to cisplatin-based chemotherapy in children. Childs Nerv Syst. 2008;24(12):1457-61. [pmid: 18769928]. Rec#: 1400 Reprint: exc nro
Huang JL, Hung IJ, Chen LC, Lee WY, Hsueh C, Hsieh KH. Successfully treated sulphasalazine-induced fulminant hepatic failure, thrombocytopenia and erythroid hypoplasia with intravenous immunoglobulin. Clin Rheumatol. 1998;17(4):349-52. [pmid: 9776124]. Rec#: 17580 Reprint: exc nro
Hung JJ, Huang JL. Etanercept therapy in children with juvenile rheumatoid arthritis. J Microbiol Immunol Infect. 2005;38(6):444-6. [pmid: 16341346]. Rec#: 41590 Reprint: exc nro
Hung PL, Chang YC, Huang LT, Lui CC, Lin JW, Huang SC. A 2-year-old girl with failure to thrive, progressive hepatosplenomegaly and progressive encephalopathy. Acta Paediatr Taiwan. 2003;44(1):1-3. [pmid: 12800374]. Rec#: 10390 Reprint: exc nrs
Hunold A, Weddeling N, Paulussen M, Ranft A, Liebscher C, Jurgens H. Topotecan and cyclophosphamide in patients with refractory or relapsed Ewing tumors. Pediatr Blood Cancer. 2006;47(6):795-800. [pmid: 16411206]. Rec#: 43320 Reprint: exc nrp
Hyams JS, Wilson DC, Thomas A, Heuschkel R, Mitton S, Mitchell B, Daniels R, Libonati MA, Zanker S, Kugathasan S. Natalizumab therapy for moderate to severe Crohn disease in adolescents. J Pediatr Gastroenterol Nutr. 2007;44(2):185-91. [pmid: 17255829]. Rec#: 41380 Reprint: exc nrc
Ikeda H, August CS, Goldwein JW, Ross AJ 3rd, D'Angio GJ, Evans AE. Sites of relapse in patients with neuroblastoma following bone marrow transplantation in relation to preparatory ‘debulking’ treatments. J Pediatr Surg. 1992;27(11):1438-41. [pmid: 1479507]. Rec#: 24710 Reprint: EXC YEAR
Ilaslan H, Sundaram M, Unni KK, Dekutoski MB. Primary Ewing's sarcoma of the vertebral column. Skeletal Radiol. 2004;33(9):506-13. [pmid: 15232658]. Rec#: 8660 Reprint: EXC MIX
Ilowite NT. Update on biologics in juvenile idiopathic arthritis. Curr Opin Rheumatol. 2008;20(5):613-8. [pmid: 18698187]. Rec#: 77150 Reprint: exc nra
Imaizumi M, Watanabe A, Kikuta A, Takano T, Ito E, Shimizu T, Tsuchiya S, Iinuma K, Konno T, Ohi R, Hayashi Y. Improved survival of children with advanced neuroblastoma treated by intensified therapy including myeloablative chemotherapy with stem cell transplantation: a retrospective analysis from the Tohoku Neuroblastoma Study Group. Tohoku J Exp Med. 2001;195(2):73-83. [pmid: 11846211]. Rec#: 12640 Reprint: exc nri
Imashuku S, Hibi S, Kosaka K, Tabata Y, Naya M, Hohjo M, Todo S. Secondary lymphoid malignancy in two children with neuroblastoma. Med Pediatr Oncol. 1996;27(1):54-6. [pmid: 8614392]. Rec#: 20610 Reprint: exc nri
Inaba H, Hale G, Leung W, Woodard P, Burnette K, Handgretinger R, Barfield R. Diagnostic challenge in recurrent skin rash after autologous bone marrow transplantation. J Pediatr Hematol Oncol. 2006;28(8):525-8. [pmid: 16912592]. Rec#: 5150 Reprint: EXC NRO
Inamo Y, Suzuki T, Mugishima H. A case of growth failure caused by 13-CIS-retinoic acid administration after bone marrow transplantation for neuroblasoma. Endocr J. 1999;46(Suppl):S113-5. [pmid: 12054112]. Rec#: 12040 Reprint: exc nri
Indelicato DJ, Keole SR, Shahlaee AH, Shi W, Morris CG, Gibbs CP Jr, Scarborough MT, Marcus RB Jr. Impact of local management on long-term outcomes in Ewing tumors of the pelvis and sacral bones: the University of Florida experience. Int J Radiat Oncol Biol Phys. 2008;72(1):41-8. [pmid: 18234436]. Rec#: 2510 Reprint: exc nrp
Inoue M, Nakano T, Yoneda A, Nishikawa M, Nakayama M, Yumura-Yagi K, Sakata N, Yasui M, Okamura T, Kawa K. Graft-versus-tumor effect in a patient with advanced neuroblastoma who received HLA haplo-identical bone marrow transplantation. Bone Marrow Transplant. 2003;32(1):103-6. [pmid: 12815485]. Rec#: 10370 Reprint: exc nri
Ishii E, Matsuzaki A, Ohnishi Y, Kai T, Ueda K. Successful treatment with ranimustine and carboplatin for recurrent intraocular retinoblastoma with vitreous seeding. Am J Clin Oncol. 1996;19(6):562-5. [pmid: 8931671]. Rec#: 20060 Reprint: exc nrd
Isoyama K, Ohnuma K, Ikuta K, Toyoda Y, Nakajima F, Yamada K, Nishihira H. Unrelated cord blood transplantation for second hemopoietic stem cell transplantation. Pediatr Int. 2003;45(3):268-74. [pmid: 12828579]. Rec#: 10330 Reprint: exc nro
Ito K, Ochiai T, Suzuki H, Chin M, Shichino H, Mugishima H. The effect of haematopoietic stem cell transplant on papules with ‘pebbly’ appearance in Hunter's syndrome. Br J Dermatol. 2004;151(1):207-11. [pmid: 15270893]. Rec#: 8550 Reprint: exc nro
Iwafuchi M, Utsumi J, Tsuchida Y, Kaneko M, Matsuyama S, Ohnuma N, Taguchi N, Mugishima H, Yokoyama J, Sasaki S, Yoshioka A, Nagahara N, Fukuzawa M, Suita S. Evaluation of patients with advanced neuroblastoma surviving more than 5 years after initiation of an intensive Japanese protocol: a report from the Study Group of Japan for Treatment of Advanced Neuroblastoma. Med Pediatr Oncol. 1996;27(6):515-20. [pmid: 8888810]. Rec#: 20080 Reprint: EXC NRI
Iwata F, Kuehl EM, Reed GF, McCain LM, Gahl WA, Kaiser-Kupfer MI. A randomized clinical trial of topical cysteamine disulfide (cystamine) versus free thiol (cysteamine) in the treatment of corneal cystine crystals in cystinosis. Mol Genet Metab. 1998;64(4):237-42. [pmid: 9758713]. Rec#: 58070 Reprint: exc nrc
Jacobson P, Park JJ, DeFor TE, Thrall M, Abel S, Krivit W, Peters C. Oral busulfan pharmacokinetics and engraftment in children with Hurler syndrome and other inherited metabolic storage diseases undergoing hematopoietic cell transplantation. Bone Marrow Transplant. 2001;27(8):855-61. [pmid: 11477444]. Rec#: 13310 Reprint: exc nrp
Jakacki RI, Jamison C, Heifetz SA, Caldemeyer K, Hanna M, Sender L. Feasibility of sequential high-dose chemotherapy and peripheral blood stem cell support for pediatric central nervous system malignancies. Med Pediatr Oncol. 1997;29(6):553-9. [pmid: 9324343]. Rec#: 18940 Reprint: EXC NRI
Jakisch BI, Wagner VM, Heidtmann B, Lepler R, Holterhus PM, Kapellen TM, Vogel C, Rosenbauer J, Holl RW. Comparison of continuous subcutaneous insulin infusion (CSII) and multiple daily injections (MDI) in paediatric Type 1 diabetes: a multicentre matched-pair cohort analysis over 3 years. Diabet Med. 2008;25(1):80-5. [pmid: 18199134]. Rec#: 61850 Reprint: exc nro
Jaspers GJ, Verkade HJ, Escher JC, de Ridder L, Taminiau JA, Rings EH. Azathioprine maintains first remission in newly diagnosed pediatric Crohn's disease. Inflamm Bowel Dis. 2006;12(9):831-6. [pmid: 16954801]. Rec#: 41460 Reprint: exc nrp
Jayne D, Passweg J, Marmont A, Farge D, Zhao X, Arnold R, Hiepe F, Lisukov I, Musso M, Ou-Yang J, Marsh J, Wulffraat N, Besalduch J, Bingham SJ, Emery P, Brune M, Fassas A, Faulkner L, Ferster A, Fiehn C, Fouillard L, Geromin A, Greinix H, Rabusin M, Saccardi R, Schneider P, Zintl F, Gratwohl A, Tyndall A. Autologous stem cell transplantation for systemic lupus erythematosus. Lupus. 2004;13(3):168-76. [pmid: 15119545]. Rec#: 8970 Reprint: exc nrp
Jenkin RD, Al-Fawaz I, Al-Shabanah MO, Allam A, Ayas M, Memon M, Rifai S, Schultz HP. Metastatic Ewing sarcoma/PNET of bone at diagnosis: prognostic factors--a report from Saudi Arabia. Med Pediatr Oncol. 2001;37(4):383-9. [pmid: 11568903]. Rec#: 43840 Reprint: exc nrp
Jennings MT, Cmelak A, Johnson MD, Moots PL, Pais R, Shyr Y. Differential responsiveness among high risk pediatric brain tumors in a pilot study of dose-intensive induction chemotherapy. Pediatr Blood Cancer. 2004;43(1):46-54. [pmid: 15170889]. Rec#: 74070 Reprint: exc nrs
Jennings MT, Iyengar S. Pharmacotherapy of malignant astrocytomas of children and adults: current strategies and future trends. CNS Drugs. 2001;15(9):719-43. [pmid: 11580310]. Rec#: 13080 Reprint: exc rec
Jeon HJ, Kong DS, Park KB, Lee JI, Park K, Kim JH, Kim ST, Lim do H, Kim WS, Nam DH. Clinical outcome of concomitant chemoradiotherapy followed by adjuvant temozolomide therapy for glioblastaomas: single-center experience. Clin Neurol Neurosurg. 2009;111(8):679-82. [pmid: 19640635]. Rec#: 54340 Reprint: exc nrp
Jiang Y, Mishima H, Sakai S, Liu YK, Ohyabu Y, Uemura T. Gene expression analysis of major lineage-defining factors in human bone marrow cells: effect of aging, gender, and age-related disorders. J Orthop Res. 2008;26(7):910-7. [pmid: 18302252]. Rec#: 2360 Reprint: exc nro
Johnston DL, Keene D, Bartels U, Carret AS, Crooks B, Eisenstat DD, Fryer C, Lafay-Cousin L, Larouche V, Moghrabi A, Wilson B, Zelcer S, Silva M, Brossard J, Bouffet E. Medulloblastoma in children under the age of three years: a retrospective Canadian review. J Neurooncol. 2009;94(1):51-6. [pmid: 19184579]. Rec#: 620 Reprint: EXC NRI
Johnston DL, Keene DL, Lafay-Cousin L, Steinbok P, Sung L, Carret AS, Crooks B, Strother D, Wilson B, Odame I, Eisenstat DD, Mpofu C, Zelcer S, Huang A, Bouffet E. Supratentorial primitive neuroectodermal tumors: a Canadian pediatric brain tumor consortium report. J Neurooncol. 2008;86(1):101-8. [pmid: 17619825]. Rec#: 52270 Reprint: EXC NRI
Jones OY, Cahill RA. Nonmyeloablative allogeneic bone marrow transplantation of a child with systemic autoimmune disease and lung vasculitis. Immunol Res. 2008;41(1):26-33. [pmid: 18360745]. Rec#: 2230 Reprint: exc same pt as in rec 9110
Kadota RP, Mahoney DH, Doyle J, Duerst R, Friedman H, Holmes E, Kun L, Zhou T, Pollack IF. Dose intensive melphalan and cyclophosphamide with autologous hematopoietic stem cells for recurrent medulloblastoma or germinoma. Pediatr Blood Cancer. 2008;51(5):675-8. [pmid: 18623206]. Rec#: 1700 Reprint: EXC NRI NRP
Kadota RP, Stewart CF, Horn M, Kuttesch JF Jr, Burger PC, Kepner JL, Kun LE, Friedman HS, Heideman RL. Topotecan for the treatment of recurrent or progressive central nervous system tumors - a pediatric oncology group phase II study. J Neurooncol. 1999;43(1):43-7. [pmid: 10448870]. Rec#: 53690 Reprint: exc nro
Kageji T, Nagahiro S, Horiguchi H, Watanabe T, Suzuya H, Okamoto Y, Kuroda Y. Successful high-dose chemotherapy for widespread neuroaxis dissemination of an optico-hypothalamic juvenile pilocytic astrocytoma in an infant: a case report. J Neurooncol. 2003;62(3):281-7. [pmid: 12777080]. Rec#: 10490 Reprint: exc nrd
Kahwash SB, Fung B, Savelli S, Bleesing JJ, Qualman SJ. Autoimmune lymphoproliferative syndrome (ALPS): a case with congenital onset. Pediatr Dev Pathol. 2007;10(4):315-9. [pmid: 17638424]. Rec#: 3460 Reprint: exc nrs
Kai T, Ishii E, Matsuzaki A, Inaba S, Suita S, Ueda K. High-dose chemotherapy and autologous blood stem cell transplantation in children with metastatic neuroblastoma. Acta Paediatr Jpn. 1997;39(1):54-60. [pmid: 9124054]. Rec#: 19720 Reprint: exc nri
Kajiwara R, Goto H, Yokosuka T, Yanagimachi M, Kuroki F, Yokota S. Hepatic veno-occlusive disease followed by esophageal varix rupture after hematopoietic stem cell transplantation in a 4-year-old boy with stage 4 neuroblastoma. J Pediatr Hematol Oncol. 2008;30(1):63-5. [pmid: 18176184]. Rec#: 2690 Reprint: exc nri
Kalkan Ucar S, Ozbaran B, Demiral N, Yuncu Z, Erermis S, Coker M. Clinical overview of children with mucopolysaccharidosis type III A and effect of Risperidone treatment on children and their mothers psychological status. Brain Dev. 2010;32(2):156-61. [pmid: 19217229]. Rec#: 56700 Reprint: exc nro
Kalwak K, Gorczynska E, Wojcik D, Toporski J, Turkiewicz D, Slociak M, Latos-Grazynska E, Boguslawska-Jaworska J, Chybicka A. Late-onset idiopathic thrombocytopenic purpura correlates with rapid B-cell recovery after allogeneic T-cell-depleted peripheral blood progenitor cell transplantation in children. Transplant Proc. 2002;34(8):3374-7. [pmid: 12493477]. Rec#: 11190 Reprint: exc nrd
Kamali S, Cefle A, Sayarlioglu M, Gul A, Inanc M, Ocal L, Aral O, Konice M. Experience with monthly, high-dose, intravenous immunoglobulin therapy in patients with different connective tissue diseases. Rheumatol Int. 2005;25(3):211-4. [pmid: 14722731]. Rec#: 41840 Reprint: exc nrd
Kamani N, August CS, Bunin N, Leahey A, Bayever E, Goldwein J, Zusman J, Evans AE, Angio GD. A study of thiotepa, etoposide and fractionated total body irradiation as a preparative regimen prior to bone marrow transplantation for poor prognosis patients with neuroblastoma. Bone Marrow Transplant. 1996;17(6):911-6. [pmid: 8807093]. Rec#: 20660 Reprint: EXC NRI
Kamani N, Kattamis A, Carroll A, Campbell D, Bunin N. Immune reconstitution after autologous purged bone marrow transplantation in children. J Pediatr Hematol Oncol. 2000;22(1):13-9. [pmid: 10695816]. Rec#: 15610 Reprint: exc nri
Kaminski JM, Yang CC, Yagmai F, Movsas B, Lee M, Barrett JT. Intracranial fibrosarcoma arising 5 years after chemotherapy alone for glioblastoma multiforme in a child. Pediatr Neurosurg. 2000;33(5):257-260. [pmid: 11155063]. Rec#: 14260 Reprint: exc nri
Kaneko M, Ohakawa H, Iwakawa M. Is extensive surgery required for treatment of advanced neuroblastoma?. J Pediatr Surg. 1997;32(11):1616-9. [pmid: 9396539]. Rec#: 18850 Reprint: exc nri
Kaneko M, Tsuchida Y, Mugishima H, Ohnuma N, Yamamoto K, Kawa K, Iwafuchi M, Sawada T, Suita S. Intensified chemotherapy increases the survival rates in patients with stage 4 neuroblastoma with MYCN amplification. J Pediatr Hematol Oncol. 2002;24(8):613-21. [pmid: 12439032]. Rec#: 11380 Reprint: exc nri
Kaneko M, Tsuchida Y, Uchino J, Takeda T, Iwafuchi M, Ohnuma N, Mugishima H, Yokoyama J, Nishihira H, Nakada K, Sasaki S, Sawada T, Kawa K, Nagahara N, Suita S, Sawaguchi S. Treatment results of advanced neuroblastoma with the first Japanese study group protocol. Study Group of Japan for Treatment of Advanced Neuroblastoma. J Pediatr Hematol Oncol. 1999;21(3):190-7. [pmid: 10363851]. Rec#: 16710 Reprint: exc nri
Kanold J, Paillard C, Tchirkov A, Merlin E, Marabelle A, Lutz P, Rousseau R, Baldomero H, Demeocq F. Allogeneic or haploidentical HSCT for refractory or relapsed solid tumors in children: toward a neuroblastoma model. Bone Marrow Transplant. Suppl 2. 2008;42:S25-30. [pmid: 18978740]. Rec#: 1010 Reprint: EXC NPD
Kanold J, Yakouben K, Tchirkov A, Carret AS, Vannier JP, LeGall E, Bordigoni P, Demeocq F. Long-term results of CD34(+) cell transplantation in children with neuroblastoma. Med Pediatr Oncol. 2000;35(1):1-7. [pmid: 10881000]. Rec#: 15200 Reprint: exc nri
Kao LY, Su WW, Lin YW. Retinoblastoma in Taiwan: survival and clinical characteristics 1978-2000. Jpn J Ophthalmol. 2002;46(5):577-80. [pmid: 12457919]. Rec#: 11290 Reprint: exc nrt
Kao PC, Huang SC, Wu ET, Wang CC, Jou ST. Cardiac perforation -- a rare complication of femoral venous catheterization. 2008. Rec#: 2300 Reprint:
Kapelushnik J, Aker M, Pugatsch T, Samuel S, Slavin S. Bone marrow transplantation from a cadaveric donor. Bone Marrow Transplant. 1998;21(8):857-8. [pmid: 9603417]. Rec#: 18150 Reprint: exc nro
Kapelushnik J, Nagler A, Or R, Naparstek E, Cividalli G, Aker M, Mehta J, Mumcuoglu M, Slavin S. Autologous bone marrow transplantation for stage IV neuroblastoma: the role of soybean agglutinin purging. Transplant Proc. 1993;25(3):2375-6. [pmid: 8516934]. Rec#: 24060 Reprint: EXC YEAR
Kara IO, Gonlusen G, Sahin B, Ergin M, Erdogan S. A general aspect on soft-tissue sarcoma and c-kit expression in primitive neuroectodermal tumor and Ewing's sarcoma. Is there any role in disease process?. Saudi Med J. 2005;26(8):1190-6. [pmid: 16127511]. Rec#: 6780 Reprint: exc nri
Kasow KA, Sims-Poston L, Eldridge P, Hale GA. CD34(+) hematopoietic progenitor cell selection of bone marrow grafts for autologous transplantation in pediatric patients. Biol Blood Marrow Transplant. 2007;13(5):608-14. [pmid: 17448921]. Rec#: 4020 Reprint: EXC NRO
Kasper B, Lehnert T, Bernd L, Mechtersheimer G, Goldschmidt H, Ho AD, Egerer G. High-dose chemotherapy with autologous peripheral blood stem cell transplantation for bone and soft-tissue sarcomas. Bone Marrow Transplant. 2004;34(1):37-41. [pmid: 15170176]. Rec#: 8780 Reprint: EXC DUP
Kato S, Nishihira H, Sako M, Kato K, Azuma E, Kawano Y, Kawa K, Kinoshita A, Sugita K, Sugi Y, Okimoto Y, Inamitsu T. Cord blood transplantation from sibling donors in Japan. Report of the national survey. Int J Hematol. 1998;67(4):389-96. [pmid: 9695412]. Rec#: 17900 Reprint: exc nr
Kattan J, Culine S, Terrier-Lacombe MJ, Theodore C, Droz JP. Paratesticular rhabdomyosarcoma in adult patients: 16-year experience at Institut Gustave-Roussy. Ann Oncol. 1993;4(10):871-5. [pmid: 8117607]. Rec#: 23650 Reprint: EXC YEAR
Katzenstein HM, Cohn SL, Shore RM, Bardo DM, Haut PR, Olszewski M, Schmoldt J, Liu D, Rademaker AW, Kletzel M. Scintigraphic response by 123I-metaiodobenzylguanidine scan correlates with event-free survival in high-risk neuroblastoma. J Clin Oncol. 2004;22(19):3909-15. [pmid: 15459212]. Rec#: 8200 Reprint: exc nri
Kawa K, Ohnuma N, Kaneko M, Yamamoto K, Etoh T, Mugishima H, Ohhira M, Yokoyama J, Bessho F, Honna T, Yoshizawa J, Nakada K, Iwafuchi M, Nozaki T, Mimaya J, Sawada T, Nakamura T, Miyata H, Yamato K, Tsuchida Y. Long-term survivors of advanced neuroblastoma with MYCN amplification: A report of 19 patients surviving disease-free for more than 66 months. J Clin Oncol. 1999;17(10):3216-20. [pmid: 10506621]. Rec#: 16240 Reprint: exc nri
Kawa-Ha K, Yumura-Yagi K, Inoue M, Park DY, Okamura T, Yasui M, Oota H, Sakata N, Yoneda M, Imura K. Results of single and double autografts for high-risk neuroblastoma patients. Bone Marrow Transplant. 1996;17(6):957-62. [pmid: 8807100]. Rec#: 20650 Reprint: EXC NRI
Kawakami Y, Ohtsuka M, Kikuta A, Yamamoto T. Multiple morphea-like lesions associated with chronic graft-versus-host disease after cord blood transplantation. 2009. Rec#: 570 Reprint:
Kawakami Y, Oyama N, Nakamura K, Kaneko F, Kikuta A, Suzuki H. Psoriasiform eruption associated with graft-versus-host disease. 2007. Rec#: 3350 Reprint:
Kaye EM, Ullman MD, Kolodny EH, Krivit W, Rischert JC. Possible use of CSF glycosphingolipids for the diagnosis and therapeutic monitoring of lysosomal storage diseases. Neurology. 1992;42(12):2290-4. [pmid: 1461381]. Rec#: 24630 Reprint: EXC DAC
Kebudi R, Gorgun O, Ayan I. Oral etoposide for recurrent/progressive sarcomas of childhood. Pediatr Blood Cancer. 2004;42(4):320-4. [pmid: 14966827]. Rec#: 43660 Reprint: exc few
Kelly A, Ramanan AV. A case of macrophage activation syndrome successfully treated with anakinra. Nat Clin Pract Rheumatol. 2008;4(11):615-20. [pmid: 18825135]. Rec#: 1210 Reprint: exc nro
Kelly J, Damron T, Grant W, Anker C, Holdridge S, Shaw S, Horton J, Cherrick I, Spadaro J. Cross-sectional study of bone mineral density in adult survivors of solid pediatric cancers. J Pediatr Hematol Oncol. 2005;27(5):248-53. [pmid: 15891558]. Rec#: 7310 Reprint: exc nro
Kelman CG, Disler DG. Metaphyseal undertubulation in gaucher disease: resolution at MRI in a patient undergoing enzyme replacement therapy. J Comput Assist Tomogr. 2000;24(1):173-5. [pmid: 10667678]. Rec#: 15680 Reprint: exc nr
Khademi B, Derakhshandeh V, Vasei M, Torabi S. Metastasis of retinoblastoma to the parotid gland: diagnosis by fine needle aspiration cytology. Otolaryngol Head Neck Surg. 2003;128(2):296-7. [pmid: 12601333]. Rec#: 48760 Reprint: exc nrs
Kharbanda S, Panoskaltsis-Mortari A, Haddad IY, Blazar BR, Orchard PJ, Cornfield DN, Grewal SS, Peters C, Regelmann WE, Milla CE, Baker KS. Inflammatory cytokines and the development of pulmonary complications after allogeneic hematopoietic cell transplantation in patients with inherited metabolic storage disorders. Biol Blood Marrow Transplant. 2006;12(4):430-7. [pmid: 16545727]. Rec#: 5910 Reprint: exc nrp
Kimonis VE, Troendle J, Rose SR, Yang ML, Markello TC, Gahl WA. Effects of early cysteamine therapy on thyroid function and growth in nephropathic cystinosis. J Clin Endocrinol Metab. 1995;80(11):3257-61. [pmid: 7593434]. Rec#: 58210 Reprint: EXC NRC
Kishnani PS, Corzo D, Leslie ND, Gruskin D, Van der Ploeg A, Clancy JP, Parini R, Morin G, Beck M, Bauer MS, Jokic M, Tsai CE, Tsai BW, Morgan C, O'Meara T, Richards S, Tsao EC, Mandel H. Early treatment with alglucosidase alpha prolongs long-term survival of infants with Pompe disease. Pediatr Res. 2009;66(3):329-35. [pmid: 19542901]. Rec#: 56600 Reprint: exc nrc
Kishnani PS, Corzo D, Nicolino M, Byrne B, Mandel H, Hwu WL, Leslie N, Levine J, Spencer C, McDonald M, Li J, Dumontier J, Halberthal M, Chien YH, Hopkin R, Vijayaraghavan S, Gruskin D, Bartholomew D, van der Ploeg A, Clancy JP, Parini R, Morin G, Beck M, De la Gastine GS, Jokic M, Thurberg B, Richards S, Bali D, Davison M, Worden MA, Chen YT, Wraith JE. Recombinant human acid. Neurology. 2007;68(2):99-109. [pmid: 17151339]. Rec#: 57110 Reprint: exc nrc
Kishnani PS, Goldenberg PC, DeArmey SL, Heller J, Benjamin D, Young S, Bali D, Smith SA, Li JS, Mandel H, Koeberl D, Rosenberg A, Chen YT. Cross-reactive immunologic material status affects treatment outcomes in Pompe disease infants. Mol Genet Metab. 2010;99(1):26-33. [pmid: 19775921]. Rec#: 56520 Reprint: exc nrc
Kishnani PS, Hwu WL, Mandel H, Nicolino M, Yong F, Corzo D. A retrospective, multinational, multicenter study on the natural history of infantile-onset Pompe disease. J Pediatr. 2006;148(5):671-676. [pmid: 16737883]. Rec#: 57200 Reprint: exc nrc
Kishnani PS, Nicolino M, Voit T, Rogers RC, Tsai AC, Waterson J, Herman GE, Amalfitano A, Thurberg BL, Richards S, Davison M, Corzo D, Chen YT. Chinese hamster ovary cell-derived recombinant human acid alpha-glucosidase in infantile-onset Pompe disease. J Pediatr. 2006;149(1):89-97. [pmid: 16860134]. Rec#: 57170 Reprint: exc nrc
Kishnani PS, Steiner RD, Bali D, Berger K, Byrne BJ, Case LE, Crowley JF, Downs S, Howell RR, Kravitz RM, Mackey J, Marsden D, Martins AM, Millington DS, Nicolino M, O'Grady G, Patterson MC, Rapoport DM, Slonim A, Spencer CT, Tifft CJ, Watson MS. Pompe disease diagnosis and management guideline. Genet Med. 2006;8(5):267-88. [pmid: 16702877]. Rec#: 57230 Reprint: exc nrc
Klaassen RJ, Trebo MM, Koplewitz BZ, Weitzman SS, Calderwood S. High-risk neuroblastoma in Ontario: a report of experience from 1989 to 1995. J Pediatr Hematol Oncol. 2003;25(1):8-13. [pmid: 12544767]. Rec#: 11060 Reprint: exc nri
Kletzel M, Abella EM, Sandler ES, Williams LL, Ogden AK, Pollock BH, Wall DA. Thiotepa and cyclophosphamide with stem cell rescue for consolidation therapy for children with high-risk neuroblastoma: a phase I/II study of the Pediatric Blood and Marrow Transplant Consortium. J Pediatr Hematol Oncol. 1998;20(1):49-54. [pmid: 9482413]. Rec#: 18620 Reprint: exc nri
Kletzel M, Becton DL, Berry DH. Single institution experience with high-dose cyclophosphamide, continuous infusion vincristine, escalating doses of VP-16-213, and total body irradiation with unpurged bone marrow rescue in children with neuroblastoma. Med Pediatr Oncol. 1992;20(1):64-7. [pmid: 1530757]. Rec#: 25430 Reprint: EXC YEAR
Kletzel M, Katzenstein HM, Haut PR, Yu AL, Morgan E, Reynolds M, Geissler G, Marymount MH, Liu D, Kalapurakal JA, Shore RM, Bardo DM, Schmoldt J, Rademaker AW, Cohn SL. Treatment of high-risk neuroblastoma with triple-tandem high-dose therapy and stem-cell rescue: results of the Chicago Pilot II Study. J Clin Oncol. 2002;20(9):2284-92. [pmid: 11980999]. Rec#: 12300 Reprint: exc nri
Kletzel M, Longino R, Rademaker AW, Danner-Koptik KE, Olszewski M, Morgan ER. Peripheral blood stem cell transplantation in young children: experience with harvesting, mobilization and engraftment. Pediatr Transplant. 1998;2(3):191-6. [pmid: 10084741]. Rec#: 17070 Reprint: exc nri
Kline RM, Fennewald L, Vore M, Bertolone SJ, Hente ML. Oral contraceptives: a cause of hyperbilirubinemia in stem cell transplant patients. J Pediatr Hematol Oncol. 1999;21(5):436-40. [pmid: 10524461]. Rec#: 16150 Reprint: exc nro
Klinge L, Straub V, Neudorf U, Schaper J, Bosbach T, Gorlinger K, Wallot M, Richards S, Voit T. Safety and efficacy of recombinant acid alpha-glucosidase (rhGAA) in patients with classical infantile Pompe disease: results of a phase II clinical trial. Neuromuscul Disord. 2005;15(1):24-31. [pmid: 15639117]. Rec#: 57480 Reprint: exc nrc
Klinge L, Straub V, Neudorf U, Voit T. Enzyme replacement therapy in classical infantile pompe disease: results of a ten-month follow-up study. Neuropediatrics. 2005;36(1):6-11. [pmid: 15776317]. Rec#: 57450 Reprint: exc nrc
Klingebiel T, Bader P, Bares R, Beck J, Hero B, Jurgens H, Lang P, Niethammer D, Rath B, Handgretinger R. Treatment of neuroblastoma stage 4 with 131I-meta-iodo-benzylguanidine, high-dose chemotherapy and immunotherapy. A pilot study. Eur J Cancer. 1998;34(9):1398-402. [pmid: 9849423]. Rec#: 17390 Reprint: exc nri
Klingebiel T, Pertl U, Hess CF, Jurgens H, Koscielniak E, Potter R, van Heek-Romanowski R, Rossi R, Schott C, Spaar HJ, Willnow U, Treuner J. Treatment of children with relapsed soft tissue sarcoma: report of the German CESS/CWS REZ 91 trial. Med Pediatr Oncol. 1998;30(5):269-75. [pmid: 9544222]. Rec#: 48140 Reprint: exc nrs
Kodet R, Newton WA Jr, Hamoudi AB, Asmar L, Wharam MD, Maurer HM. Orbital rhabdomyosarcomas and related tumors in childhood: relationship of morphology to prognosis--an Intergroup Rhabdomyosarcoma study. Med Pediatr Oncol. 1997;29(1):51-60. [pmid: 9142207]. Rec#: 48250 Reprint: exc nri
Kohler JA, Ellershaw C, Machin D. Response to N7 induction chemotherapy in children more than one year of age diagnosed with metastatic neuroblastoma treated in UKCCSG centers. Pediatr Blood Cancer. 2007;49(3):234-9. [pmid: 17252561]. Rec#: 4420 Reprint: exc nri
Koka VN, Julieron M, Bourhis J, Janot F, Le Ridant AM, Marandas P, Luboinski B, Schwaab G. Aesthesioneuroblastoma. J Laryngol Otol. 1998;112(7):628-33. [pmid: 9775291]. Rec#: 17600 Reprint: exc nri
Kolb EA, Kushner BH, Gorlick R, Laverdiere C, Healey JH, LaQuaglia MP, Huvos AG, Qin J, Vu HT, Wexler L, Wolden S, Meyers PA. Long-term event-free survival after intensive chemotherapy for Ewing's family of tumors in children and young adults. J Clin Oncol. 2003;21(18):3423-30. [pmid: 12972518]. Rec#: 43680 Reprint: exc nrp
Kombogiorgas D, Sgouros S, Walsh AR, Hockley AD, Stevens M, Grundy R, Peet A, English M, Spooner D. Outcome of children with posterior fossa medulloblastoma: a single institution experience over the decade 1994-2003. Childs Nerv Syst. 2007;23(4):399-405. [pmid: 17119978]. Rec#: 52410 Reprint: EXC NRI
Komotar RJ, Burger PC, Carson BS, Brem H, Olivi A, Goldthwaite PT, Tihan T. Pilocytic and pilomyxoid hypothalamic/chiasmatic astrocytomas. Neurosurgery. 2004;54(1):72-9. [pmid: 14683543]. discussion 79-80 Rec#: 55410 Reprint: exc nrd
Konoplia NE, Strongin IuS, Talabaev MV, Aleinikova OV. [Effectiveness of intensive chemotherapy in the treatment of medulloblastoma/primitive neuroectodermal tumor in children]. Vopr Onkol. 2008;54(2):157-63. [pmid: 18522163]. Rec#: 70180 Reprint: EXC FLA
Kortmann RD, Kuhl J, Timmermann B, Mittler U, Urban C, Budach V, Richter E, Willich N, Flentje M, Berthold F, Slavc I, Wolff J, Meisner C, Wiestler O, Sorensen N, Warmuth-Metz M, Bamberg M. Postoperative neoadjuvant chemotherapy before radiotherapy as compared to immediate radiotherapy followed by maintenance chemotherapy in the treatment of medulloblastoma in childhood: results of the German prospective randomized trial HIT '91. Int J Radiat Oncol Biol Phys. 2000;46(2):269-79. [pmid: 10661332]. Rec#: 15700 Reprint: EXC NRI NRC
Kosrirukvongs P, Chirapapaisan N, Visuthisakchai S, Issaragrisil S, Gonggetyai V. Sjogren-like syndrome after bone marrow transplantation. J Med Assoc Thai. 2008;91(11):1739-47. [pmid: 19127798]. Rec#: 760 Reprint: exc nro nrd
Kossiva L, Theodoridou M, Mostrou G, Vrachnou E, Le Deist F, Rieux-Laucat F, Kanariou MG. Mycophenolate mofetil as an alternate immunosuppressor for autoimmune lymphoproliferative syndrome. J Pediatr Hematol Oncol. 2006;28(12):824-6. [pmid: 17164652]. Rec#: 4570 Reprint: exc nri
Kounami S, Aoyagi N, Nakayama K, Yoshiyama M, Boshi H, Sakiyama M, Takeuchi T, Yoshikawa N. Fatal pulmonary thromboembolism after a second course of high-dose chemotherapy with autologous peripheral blood stem cell transplantation. Pediatr Transplant. 2003;7(5):400-3. [pmid: 14738303]. Rec#: 9380 Reprint: EXC NRO
Kounami S, Douno S, Matsubara H, Takayama J, Ohira M. Olfactory neuroblastoma as a second malignant neoplasm in a patient previously treated for childhood acute leukemia. Pediatr Hematol Oncol. 2001;18(7):459-63. [pmid: 11594709]. Rec#: 13050 Reprint: exc nri
Kozak T, Havrdova E, Pit'ha J, Gregora E, Pytlik R, Maaloufova J, Mareckova H, Kobylka P, Vodvarkova S. High-dose immunosuppressive therapy with PBPC support in the treatment of poor risk multiple sclerosis. Bone Marrow Transplant. 2000;25(5):525-31. [pmid: 10713630]. Rec#: 15530 Reprint: exc nrp
Kramer JH, Crittenden MR, Halberg FE, Wara WM, Cowan MJ. A prospective study of cognitive functioning following low-dose cranial radiation for bone marrow transplantation. Pediatrics. 1992;90(3):447-50. [pmid: 1518705]. Rec#: 24890 Reprint: EXC YEAR
Kramer K, Cheung NK. Autologous bone marrow transplantation in children with advanced neuroblastoma. 1995. Rec#: 21470 Reprint: exc year
Kramer K, Gerald WL, Kushner BH, Larson SM, Hameed M, Cheung NK. Disialoganglioside G(D2) loss following monoclonal antibody therapy is rare in neuroblastoma. Clin Cancer Res. 1998;4(9):2135-9. [pmid: 9748131]. Rec#: 17640 Reprint: exc nri
Kremens B, Klingebiel T, Herrmann F, Bender-Gotze C, Burdach S, Ebell W, Friedrich W, Koscielniak E, Schmid H, Siegert W, et al. High-dose consolidation with local radiation and bone marrow rescue in patients with advanced neuroblastoma. Med Pediatr Oncol. 1994;23(6):470-5. [pmid: 7935172]. Rec#: 23490 Reprint: EXC Year
Kretschmar CS, Kletzel M, Murray K, Thorner P, Joshi V, Marcus R, Smith EI, London WB, Castleberry R. Response to paclitaxel, topotecan, and topotecan-cyclophosphamide in children with untreated disseminated neuroblastoma treated in an upfront phase II investigational window: a pediatric oncology group study. J Clin Oncol. 2004;22(20):4119-26. [pmid: 15483021]. Rec#: 8150 Reprint: exc nri
Kreuzpaintner G, Horstkotte D, Heyll A, Losse B, Strohmeyer G. Increased risk of bacterial endocarditis in inflammatory bowel disease. Am J Med. 1992;92(4):391-5. [pmid: 1307218]. Rec#: 25270 Reprint: EXC YEAR
Krishnakumar S, Mallikarjuna K, Desai N, Muthialu A, Venkatesan N, Sundaram A, Khetan V, Shanmugam MP. Multidrug resistant proteins: P-glycoprotein and lung resistance protein expression in retinoblastoma. Br J Ophthalmol. 2004;88(12):1521-6. [pmid: 15548804]. Rec#: 8000 Reprint: exc nro
Krivan G, Timar L, Goda V, Reti M, Remenyi P, Masszi T. Bone marrow transplantation in non-malignant disorders. Bone Marrow Transplant. Suppl 4. 1998;22:S80-3. [pmid: 9916644]. Rec#: 17260 Reprint: exc nr
Krivit W. Stem cell bone marrow transplantation in patients with metabolic storage diseases. Adv Pediatr. 2002;49:359-78. [pmid: 12214779]. Rec#: 11670 Reprint: exc rev
Krivit W, Freese D, Chan KW, Kulkarni R. Wolman's disease: a review of treatment with bone marrow transplantation and considerations for the future. Bone Marrow Transplant. Suppl 1. 1992;10:97-101. [pmid: 1521099]. Rec#: 25450 Reprint: EXC REV
Krivit W, Peters C, Dusenbery K, Ben-Yoseph Y, Ramsay NK, Wagner JE, Anderson R. Wolman disease successfully treated by bone marrow transplantation. Bone Marrow Transplant. 2000;26(5):567-70. [pmid: 11019848]. Rec#: 14770 Reprint: exc dup
Kuis W, Wulffraat NM, Petty RE. Autologous stem cell transplantation: an alternative for refractory juvenile chronic arthritis. Rheumatology (Oxford). 1999;38(8):737-8. [pmid: 10501422]. Rec#: 16330 Reprint: exc com
Kumar S, Benseler SM, Kirby-Allen M, Silverman ED. B-cell depletion for autoimmune thrombocytopenia and autoimmune hemolytic anemia in pediatric systemic lupus erythematosus. Pediatrics. 2009;123(1):e159-63. [pmid: 19074962]. Rec#: 77490 Reprint: exc nrc
Kurland G, Michelson P. Bronchiolitis obliterans in children. Pediatr Pulmonol. 2005;39(3):193-208. [pmid: 15635614]. Rec#: 7840 Reprint: exc nra
Kuroda T, Saeki M, Honna T, Masaki H, Tsunematsu Y. Clinical significance of intensive surgery with intraoperative radiation for advanced neuroblastoma: does it really make sense?. J Pediatr Surg. 2003;38(12):1735-8. [pmid: 14666455]. Rec#: 9580 Reprint: exc nri
Kuroda T, Saeki M, Nakano M, Mizutani S, Endo M, Akiyama H. Surgical treatment of neuroblastoma with micrometastasis. J Pediatr Surg. 2000;35(11):1638-42. [pmid: 11083442]. Rec#: 14550 Reprint: exc nri
Kushner BH, Cheung NK, Kramer K, Dunkel IJ, Calleja E, Boulad F. Topotecan combined with myeloablative doses of thiotepa and carboplatin for neuroblastoma, brain tumors, and other poor-risk solid tumors in children and young adults. Bone Marrow Transplant. 2001;28(6):551-6. [pmid: 11607767]. Rec#: 13020 Reprint: exc nri
Kushner BH, Gulati SC, Kwon JH, O'Reilly RJ, Exelby PR, Cheung NK. High-dose melphalan with 6-hydroxydopamine-purged autologous bone marrow transplantation for poor-risk neuroblastoma. Cancer. 1991;68(2):242-7. [pmid: 1906368]. Rec#: 26090 Reprint: EXC YEAR
Kushner BH, Kramer K, LaQuaglia MP, Cheung NK. Curability of recurrent disseminated disease after surgery alone for local-regional neuroblastoma using intensive chemotherapy and anti-G(D2) immunotherapy. J Pediatr Hematol Oncol. 2003;25(7):515-9. [pmid: 12847316]. Rec#: 10240 Reprint: exc nri
Kushner BH, Kramer K, Meyers PA, Wollner N, Cheung NK. Pilot study of topotecan and high-dose cyclophosphamide for resistant pediatric solid tumors. Med Pediatr Oncol. 2000;35(5):468-74. [pmid: 11070479]. Rec#: 14590 Reprint: exc nro
Kushner BH, Kramer K, Modak S, Qin LX, Yataghena K, Jhanwar SC, Cheung NK. Reduced risk of secondary leukemia with fewer cycles of dose-intensive induction chemotherapy in patients with neuroblastoma. Pediatr Blood Cancer. 2009;53(1):17-22. [pmid: 19148951]. Rec#: 710 Reprint: exc nri
Kushner BH, O'Reilly RJ, Mandell LR, Gulati SC, LaQuaglia M, Cheung NK. Myeloablative combination chemotherapy without total body irradiation for neuroblastoma. J Clin Oncol. 1991;9(2):274-9. [pmid: 1899111]. Rec#: 26410 Reprint: EXC YEAR
Kutluk T, Varan A, Buyukpamukcu N, Atahan L, Caglar M, Akyuz C, Buyukpamukcu M. Improved survival of children with wilms tumor. J Pediatr Hematol Oncol. 2006;28(7):423-6. [pmid: 16825987]. Rec#: 45070 Reprint: exc nrp
Kuttesch JF Jr, Krailo MD, Madden T, Johansen M, Bleyer A. Phase II evaluation of intravenous vinorelbine (Navelbine) in recurrent or refractory pediatric malignancies: a Children's Oncology Group study. Pediatr Blood Cancer. 2009;53(4):590-3. [pmid: 19533657]. Rec#: 46660 Reprint: exc nro
Kuttesch JF Jr, Wexler LH, Marcus RB, Fairclough D, Weaver-McClure L, White M, Mao L, Delaney TF, Pratt CB, Horowitz ME, Kun LE. Second malignancies after Ewing's sarcoma: radiation dose-dependency of secondary sarcomas. J Clin Oncol. 1996;14(10):2818-25. [pmid: 8874344]. Rec#: 44440 Reprint: exc nrp
Kyllerman M, Mansson JE, Westphal O, Conradi N, Nellstrom H. Infantile galactosialidosis presenting with congenital adrenal hyperplasia and renal hypertension. Pediatr Neurol. 1993;9(4):318-22. [pmid: 8216548]. Rec#: 24030 Reprint: EXC NRS
Ladenstein R, Favrot M, Lasset C, Bouffet E, Philip I, Combaret V, Chauvin F, Brunat-Mentigny M, Biron P, Philip T. Indication and limits of megatherapy and bone marrow transplantation in high-risk neuroblastoma: a single centre analysis of prognostic factors. Eur J Cancer. 1993;29A(7):947-56. [pmid: 8499148]. Rec#: 24380 Reprint: EXC YEAR
Ladenstein R, Lasset C, Bouffet E, Brunat-Mentigny M, Biron P, Philip I, Chauvin F, Philip T. A single center experience with bone marrow transplantation for high risk neuroblastoma. Bone Marrow Transplant. Suppl 2. 1991;7:93. [pmid: 1878741]. Rec#: 26590 Reprint: EXC YEAR
Ladenstein R, Lasset C, Hartmann O, Frappaz D, Garaventa A, Klingebiel T, Zucker JM, Coze C, Burdach S, Gadner H, et al. Impact of megatherapy on survival after relapse from stage 4 neuroblastoma in patients over 1 year of age at diagnosis: a report from the European Group for Bone Marrow Transplantation. J Clin Oncol. 1993;11(12):2330-41. [pmid: 8246022]. Rec#: 23620 Reprint: EXC YEAR
Ladenstein R, Lasset C, Hartmann O, Klingebiel T, Bouffet E, Gadner H, Paolucci P, Burdach S, Chauvin F, Pinkerton R, et al. Comparison of auto versus allografting as consolidation of primary treatments in advanced neuroblastoma over one year of age at diagnosis: report from the European Group for Bone Marrow Transplantation. Bone Marrow Transplant. 1994;14(1):37-46. [pmid: 7951119]. Rec#: 22880 Reprint: EXC Year
Ladenstein R, Lasset C, Philip T. Treatment duration before bone marrow transplantation in stage IV neuroblastoma. European Bone Marrow Transplant Group Solid Tumour Registry. 1992. Rec#: 24780 Reprint: exc year
Lafay-Cousin L, Strother D. Current treatment approaches for infants with malignant central nervous system tumors. Oncologist. 2009;14(4):433-44. [pmid: 19342475]. Rec#: 72970 Reprint: exc rev
Lageron A, Maziere JC, Gane P, Goossens D, Roy C. Niemann Pick c or storage by excessive blood cell destruction: a case presenting a diagnosis problem. Acta Histochem. 1992;92(1):39-45. [pmid: 1580140]. Rec#: 25410 Reprint: EXC YEAR
Lamireau T, Cezard JP, Dabadie A, Goulet O, Lachaux A, Turck D, Maurage C, Morali A, Sokal E, Belli D, Stoller J, Cadranel S, Ginies JL, Viola S, Huet F, Languepin J, Lenaerts C, Bury F, Sarles J. Efficacy and tolerance of infliximab in children and adolescents with Crohn's disease. Inflamm Bowel Dis. 2004;10(6):745-50. [pmid: 15626892]. Rec#: 41680 Reprint: exc nrc
Lapierre V, Mahe C, Auperin A, Stambouli F, Oubouzar N, Tramalloni D, Benhamou E, Tiberghien P, Hartmann O. Platelet transfusion containing ABO-incompatible plasma and hepatic veno-occlusive disease after hematopoietic transplantation in young children. Transplantation. 2005;80(3):314-9. [pmid: 16082325]. Rec#: 6900 Reprint: exc nri
Laprie A, Michon J, Hartmann O, Munzer C, Leclair MD, Coze C, Valteau-Couanet D, Plantaz D, Carrie C, Habrand JL, Bergeron C, Chastagner P, Defachelles AS, Delattre O, Combaret V, Benard J, Perel Y, Gandemer V, Rubie H. High-dose chemotherapy followed by locoregional irradiation improves the outcome of patients with international neuroblastoma staging system Stage II and III neuroblastoma with MYCN amplification. Cancer. 2004;101(5):1081-9. [pmid: 15329919]. Rec#: 8430 Reprint: exc nri
Larsen EC, Connolly SA, Rosenberg AE. Case records of the Massachusetts General Hospital. Weekly clinicopathological exercises. Case 20-2003. A nine-year-old girl with hepatosplenomegaly and pain in the thigh. N Engl J Med. 2003;348(26):2669-77. [pmid: 12826642]. Rec#: 10340 Reprint: exc nr
Lashner BA. Autologous hematopoietic stem cell transplantation for Crohn's disease: high risk for a high reward. Inflamm Bowel Dis. 2005;11(8):778-9. [pmid: 16043994]. Rec#: 6960 Reprint: exc com
Lau L, Tai D, Weitzman S, Grant R, Baruchel S, Malkin D. Factors influencing survival in children with recurrent neuroblastoma. J Pediatr Hematol Oncol. 2004;26(4):227-32. [pmid: 15087949]. Rec#: 9020 Reprint: exc nri
Launay D, Marjanovic Z, de Bazelaire C, Florea L, Zohar S, Keshtmand H, Deligny C, de Raigniac A, Wells AU, Farge D. Autologous hematopoietic stem cell transplant in systemic sclerosis: quantitative high resolution computed tomography of the chest scoring. J Rheumatol. 2009;36(7):1460-3. [pmid: 19531757]. Rec#: 80 Reprint: EXC NRO
Laurence V, Pierga JY, Barthier S, Babinet A, Alapetite C, Palangie T, de Pinieux G, Anract P, Pouillart P. Long-term follow up of high-dose chemotherapy with autologous stem cell rescue in adults with Ewing tumor. Am J Clin Oncol. 2005;28(3):301-9. [pmid: 15923805]. Rec#: 7220 Reprint: EXC NRP
Laverdiere C, Cheung NK, Kushner BH, Kramer K, Modak S, LaQuaglia MP, Wolden S, Ness KK, Gurney JG, Sklar CA. Long-term complications in survivors of advanced stage neuroblastoma. Pediatr Blood Cancer. 2005;45(3):324-32. [pmid: 15714447]. Rec#: 7670 Reprint: exc nri
Lawlor ER, Murphy JI, Sorensen PH, Fryer CJ. Metastatic primitive neuroectodermal tumour of the ovary: successful treatment with mega-dose chemotherapy followed by peripheral blood progenitor cell rescue. Med Pediatr Oncol. 1997;29(4):308-12. [pmid: 9251739]. Rec#: 19000 Reprint: EXC NRO
Laws HJ, Burdach S, van Kaick B, Engel B, Dirksen U, Korholz D, Pape H, Kahn T, Merck H, Schmitz M, Heyll A, Dockhorn-Dworniczak B, Jurgens H, Gobel U. Multimodality diagnostics and megatherapy in poor prognosis Ewing's tumor patients. A single-center report. Strahlenther Onkol. 1999;175(10):488-94. [pmid: 10554643]. Rec#: 16080 Reprint: exc nrp
Laws HJ, Janssen G, Borkhardt A. Reassessment of treatment modalities for paediatric patients with chronic immune thrombocytopenia. Hamostaseologie. 2009;29(2):171-6. [pmid: 19404521]. Rec#: 250 Reprint: exc nra
Lazzerini M, Martelossi S, Marchetti F, Scabar A, Bradaschia F, Ronfani L, Ventura A. Efficacy and safety of thalidomide in children and young adults with intractable inflammatory bowel disease: long-term results. Aliment Pharmacol Ther. 2007;25(4):419-27. [pmid: 17269997]. Rec#: 41370 Reprint: exc nrp
Leahey AM, Friedman DL, Bunin NJ. Bone marrow transplantation in pediatric patients with therapy-related myelodysplasia and leukemia. Bone Marrow Transplant. 1999;23(1):21-5. [pmid: 10037046]. Rec#: 17170 Reprint: exc nro
Lee SH, Yoo KH, Sung KW, Kim JY, Cho EJ, Koo HH, Chung SE, Kang SW, Oh SY, Ham DI, Kim YD. Tandem high-dose chemotherapy and autologous stem cell rescue in children with bilateral advanced retinoblastoma. Bone Marrow Transplant. 2008;42(6):385-91. [pmid: 18574441]. Rec#: 1780 Reprint: exc nrs
Lee V, Cheng PS, Chik KW, Wong GW, Shing MM, Li CK. Autoimmune hypothyroidism after unrelated haematopoietic stem cell transplantation in children. J Pediatr Hematol Oncol. 2006;28(5):293-5. [pmid: 16772879]. Rec#: 5460 Reprint: exc nrd
Lee WY, Oh ES, Min CK, Kim DW, Lee JW, Kang MI, Min WS, Cha BY, Lee KW, Son HY, Kang SK, Kim CC. Changes in autoimmune thyroid disease following allogeneic bone marrow transplantation. Bone Marrow Transplant. 2001;28(1):63-6. [pmid: 11498746]. Rec#: 13250 Reprint: exc nrd
Lehman TJ. Clinical trials for the treatment of systemic onset juvenile rheumatoid arthritis-juvenile idiopathic arthritis. Curr Rheumatol Rep. 2000;2(4):313-5. [pmid: 11123076]. Rec#: 14350 Reprint: exc nra
Lehman TJ, Schechter SJ, Sundel RP, Oliveira SK, Huttenlocher A, Onel KB. Thalidomide for severe systemic onset juvenile rheumatoid arthritis: A multicenter study. J Pediatr. 2004;145(6):856-7. [pmid: 15580219]. Rec#: 41710 Reprint: exc nrp
Leng XM, Zhao Y, Zhou DB, Situ H, Li TS, Shen T, Zhao YQ, Zeng XF, Zhang FC, Dong Y, Tang FL. A pilot trial for severe, refractory systemic autoimmune disease with stem cell transplantation. Chin Med Sci J. 2005;20(3):159-65. [pmid: 16261884]. Rec#: 6540 Reprint: exc nrp
Lesesve JF, Schneider P, Dolgopolov I, Bastard C, Lenormand B, Cambon-Michot E, Callat MP, Cavelier B, Tron PH, Vannier JP. Therapy-related acute myeloid leukemia with t(8;21) in a child with previous Ewing's sarcoma. Med Pediatr Oncol. 1997;29(2):132-4. [pmid: 9180915]. Rec#: 19110 Reprint: exc nrd
Lesnik JJ, Singh GK, Balfour IC, Wall DA. Steroid-induced hypertrophic cardiomyopathy following stem cell transplantation in a neonate: a case report. Bone Marrow Transplant. 2001;27(10):1105-8. [pmid: 11438829]. Rec#: 13520 Reprint: exc nr
Leung CK. Fifteen years' review of advanced childhood neuroblastoma from a single institution in Hong Kong. Chin Med J (Engl). 1998;111(5):466-9. [pmid: 10374361]. Rec#: 16680 Reprint: exc nri
Levin VA, Uhm JH, Jaeckle KA, Choucair A, Flynn PJ, Yung WKA, Prados MD, Bruner JM, Chang SM, Kyritsis AP, Gleason MJ, Hess KR. Phase III randomized study of postradiotherapy chemotherapy with alpha-difluoromethylornithine-procarbazine, N-(2-chloroethyl)-N'-cyclohexyl-N-nitrosurea, vincristine (DFMO-PCV) versus PCV for glioblastoma multiforme. Clin Cancer Res. 2000;6(10):3878-84. [pmid: 11051233]. Rec#: 55840 Reprint: exc nrp
Levine JC, Kishnani PS, Chen YT, Herlong JR, Li JS. Cardiac remodeling after enzyme replacement therapy with acid alpha-glucosidase for infants with Pompe disease. Pediatr Cardiol. 2008;29(6):1033-42. [pmid: 18661169]. Rec#: 56780 Reprint: exc nrc
Levtchenko EN, van Dael CM, de Graaf-Hess AC, Wilmer MJ, van den Heuvel LP, Monnens LA, Blom HJ. Strict cysteamine dose regimen is required to prevent nocturnal cystine accumulation in cystinosis. Pediatr Nephrol. 2006;21(1):110-3. [pmid: 16252107]. Rec#: 57320 Reprint: exc nrc
Levy AS, Meyers PA, Wexler LH, Jakacki R, Angiolillo A, Ringuette SN, Cohen MB, Gorlick R. Phase 1 and pharmacokinetic study of concurrent carboplatin and irinotecan in subjects aged 1 to 21 years with refractory solid tumors. Cancer. 2009;115(1):207-16. [pmid: 19090012]. Rec#: 810 Reprint: exc cr nri
Levy Y, Uziel Y, Zandman G, Rotman P, Amital H, Sherer Y, Langevitz P, Goldman B, Shoenfeld Y. Response of vasculitic peripheral neuropathy to intravenous immunoglobulin. Ann N Y Acad Sci. 2005;1051:779-86. [pmid: 16127015]. Rec#: 77910 Reprint: exc cr
Lewis LD, Benin A, Szumlanski CL, Otterness DM, Lennard L, Weinshilboum RM, Nierenberg DW. Olsalazine and 6-mercaptopurine-related bone marrow suppression: a possible drug-drug interaction. Clin Pharmacol Ther. 1997;62(4):464-75. [pmid: 9357398]. Rec#: 18870 Reprint: exc nro
Liem RI, Higman MA, Chen AR, Arceci RJ. Misinterpretation of a Calvert-derived formula leading to carboplatin overdose in two children. J Pediatr Hematol Oncol. 2003;25(10):818-21. [pmid: 14528109]. Rec#: 9820 Reprint: exc nri
Locatelli F, Perotti C, Torretta L, Maccario R, Montagna D, Ravelli A, Giorgiani G, De Benedetti F, Giraldi E, Magnani ML, De Stefano P, Martini A. Mobilization and selection of peripheral blood hematopoietic progenitors in children with systemic sclerosis. Haematologica. 1999;84(9):839-43. [pmid: 10477459]. Rec#: 16430 Reprint: exc nro
Lones MA, Kirov I, Said JW, Shintaku IP, Neudorf S. Post-transplant lymphoproliferative disorder after autologous peripheral stem cell transplantation in a pediatric patient. Bone Marrow Transplant. 2000;26(9):1021-4. [pmid: 11100284]. Rec#: 14510 Reprint: EXC NRI
Lopez-Cubero SO, Sullivan KM, McDonald GB. Course of Crohn's disease after allogeneic marrow transplantation. Gastroenterology. 1998;114(3):433-40. [pmid: 9496932]. Rec#: 18570 Reprint: exc nrp
Lorch A, Kollmannsberger C, Hartmann JT, Metzner B, Schmidt-Wolf IG, Berdel WE, Weissinger F, Schleicher J, Egerer G, Haas A, Schirren R, Beyer J, Bokemeyer C, Rick O. Single versus sequential high-dose chemotherapy in patients with relapsed or refractory germ cell tumors: a prospective randomized multicenter trial of the German Testicular Cancer Study Group. J Clin Oncol. 2007;25(19):2778-84. [pmid: 17602082]. Rec#: 49710 Reprint: EXC NRP
Lorenzoni PJ, Scola RH, Carsten AL, Trentin AP, Teive HA, Pasquini R, Werneck LC. Chronic inflammatory demyelinating polyradiculoneuropathy in chronic graft-versus-host disease following allogeneic hematopoietic stem cell transplantation: case report. Arq Neuropsiquiatr. 2007;65(3A):700-4. [pmid: 17876419]. Rec#: 3180 Reprint: EXC NRD
Lotz J, Bui B, Gomez F, Theodore C, Caty. Sequential high-dose chemotherapy protocol for relapsed poor prognosis germ cell tumors combining two mobilization and cytoreductive treatments followed by three high-dose chemotehrapy reimgens supported by autologous stem cell transplantation. Results o. Annals of Oncology. 2005;16:411-418. Rec#: Reprint: exc nrp
Lovell DJ, Giannini EH, Reiff A, Jones OY, Schneider R, Olson JC, Stein LD, Gedalia A, Ilowite NT, Wallace CA, Lange M, Finck BK, Burge DJ. Long-term efficacy and safety of etanercept in children with polyarticular-course juvenile rheumatoid arthritis: interim results from an ongoing multicenter, open-label, extended-treatment trial. Arthritis Rheum. 2003;48(1):218-26. [pmid: 12528122]. Rec#: 41940 Reprint: exc nrp
Lovell DJ, Reiff A, Ilowite NT, Wallace CA, Chon Y, Lin SL, Baumgartner SW, Giannini EH. Safety and efficacy of up to eight years of continuous etanercept therapy in patients with juvenile rheumatoid arthritis. Arthritis Rheum. 2008;58(5):1496-504. [pmid: 18438876]. Rec#: 77170 Reprint: exc nrp
Lucchini G, Masera N, Foti G, Assali G, Perseghin P, Biagi E. A life-threatening paediatric case of acute autoimmune haemolytic anaemia (AIHA) successfully cured by plasma-exchange and combined immunosuppressive treatment. Transfus Apher Sci. 2009;40(2):115-8. [pmid: 19237316]. Rec#: 77450 Reprint: exc nri cr
Ludvigsson J, Faresjo M, Hjorth M, Axelsson S, Cheramy M, Pihl M, Vaarala O, Forsander G, Ivarsson S, Johansson C, Lindh A, Nilsson NO, Aman J, Ortqvist E, Zerhouni P, Casas R. GAD treatment and insulin secretion in recent-onset type 1 diabetes. N Engl J Med. 2008;359(18):1909-20. [pmid: 18843118]. Rec#: 40070 Reprint: exc nrc
Ludvigsson J, Hanas R. Continuous subcutaneous glucose monitoring improved metabolic control in pediatric patients with type 1 diabetes: a controlled crossover study. Pediatrics. 2003;111(5 Pt 1):933-8. [pmid: 12728068]. Rec#: 62330 Reprint: exc nro
Ludvigsson J, Samuelsson U, Ernerudh J, Johansson C, Stenhammar L, Berlin G. Photopheresis at onset of type 1 diabetes: a randomised, double blind, placebo controlled trial. Arch Dis Child. 2001;85(2):149-54. [pmid: 11466190]. Rec#: 40510 Reprint: exc nrc
Lueder GT, Brandt JM, Smith ME. Pathological case of the month. Retinoblastoma with invasion of the optic nerve. Arch Pediatr Adolesc Med. 1997;151(10):1057-8. [pmid: 9343022]. Rec#: 49150 Reprint: exc nrd
Luksch R, Grignani G, Fagioli F, Brach del Prever A, Podda M, Aliberti S, Casanova M, Prete A, Hanau G, Tamburini A, Allione P, Tienghi A, Ferrari S, Collini P, Marchiano A, Gandola L, Aglietta M, Madon E, Picci P, Fossati-Bellani F. Response to melphalan in up-front investigational window therapy for patients with metastatic Ewing's family tumours. Eur J Cancer. 2007;43(5):885-90. [pmid: 17254770]. Rec#: 4400 Reprint: exc nrp
Luksch R, Massimino M, Cefalo G, Lombardi F, Ferrari A, Casanova M, Gandola L, Terenziani M, Spreafico F, Fossati-Bellani F. Effects of recombinant human granulocyte-macrophage colony-stimulating factor in an intensive treatment program for children with Ewing's sarcoma. Haematologica. 2001;86(7):753-60. [pmid: 11454532]. Rec#: 13480 Reprint: exc nri
Luksch R, Podda M, Gandola L, Polastri D, Piva L, Castellani R, Collini P, Massimino M, Cefalo G, Terenziani M, Ferrari A, Casanova M, Spreafico F, Meazza C, Bozzi F, Marchiano A, Ravagnani F, Fossati-Bellani F. Stage 4 neuroblastoma: sequential hemi-body irradiation or high-dose chemotherapy plus autologous haemopoietic stem cell transplantation to consolidate primary treatment. Br J Cancer. 2005;92(11):1984-8. [pmid: 15900298]. Rec#: 7280 Reprint: exc nri
Luo XQ, Mo Y, Ke ZY, Xu L, Jiang XY, Zhang TT, Chen SM. High-dose chemotherapy without stem cell transplantation for refractory childhood systemic lupus erythematosus. Chemotherapy. 2008;54(5):331-5. [pmid: 18714153]. Rec#: 1490 Reprint: exc nrc
Lyos AT, Goepfert H, Luna MA, Jaffe N, Malpica A. Soft tissue sarcoma of the head and neck in children and adolescents. Cancer. 1996;77(1):193-200. [pmid: 8630930]. Rec#: 48390 Reprint: exc nri
Lyu RK, Ko YM, Hung IJ, Lu CS. Type C Niemann-Pick disease: report of a Chinese case. J Formos Med Assoc. 1993;92(9):829-31. [pmid: 7904866]. Rec#: 23910 Reprint: EXC NRS
Mabbott DJ, Barnes M, Laperriere N, Landry SH, Bouffet E. Neurocognitive function in same-sex twins following focal radiation for medulloblastoma. Neuro Oncol. 2007;9(4):460-4. [pmid: 17704358]. Rec#: 3400 Reprint: EXC NRO
Mackall CL, Stein D, Fleisher TA, Brown MR, Hakim FT, Bare CV, Leitman SF, Read EJ, Carter CS, Wexler LH, Gress RE. Prolonged CD4 depletion after sequential autologous peripheral blood progenitor cell infusions in children and young adults. Blood. 2000;96(2):754-62. [pmid: 10887145]. Rec#: 15180 Reprint: exc nro
Maegawa GH, van Giersbergen PL, Yang S, Banwell B, Morgan CP, Dingemanse J, Tifft CJ, Clarke JT. Pharmacokinetics, safety and tolerability of miglustat in the treatment of pediatric patients with GM2 gangliosidosis. Mol Genet Metab. 2009;97(4):284-91. [pmid: 19447653]. Rec#: 56630 Reprint: exc nro
Magnaldi S, Longo R, Ukmar M, Zanatta M, Bottega M, Sottocasa GL. Bone marrow relaxation times in Gaucher disease before and after enzyme replacement therapy. Eur Radiol. 1997;7(4):486-91. [pmid: 9204325]. Rec#: 19890 Reprint: exc dac
Mahdi G, Israel DM, Hassall E. Cyclosporine and 6-mercaptopurine for active, refractory Crohn's colitis in children. Am J Gastroenterol. 1996;91(7):1355-9. [pmid: 8677994]. Rec#: 42560 Reprint: exc nrs
Mandelbrot DA, Santos PW, Burt RK, Oyama Y, Block GA, Ahya SN, Rosa RM, Traynor AE. Resolution of SLE-related soft-tissue calcification following haematopoietic stem cell transplantation. Nephrol Dial Transplant. 2008;23(8):2679-84. [pmid: 18326564]. Rec#: 2270 Reprint: exc nrp
Mansfield JC, Parkes M, Hawthorne AB, Forbes A, Probert CS, Perowne RC, Cooper A, Zeldis JB, Manning DC, Hawkey CJ. A randomized, double-blind, placebo-controlled trial of lenalidomide in the treatment of moderately severe active Crohn's disease. Aliment Pharmacol Ther. 2007;26(3):421-30. [pmid: 17635377]. Rec#: 41250 Reprint: exc nrp
Marabelle A, Campagne D, Dechelotte P, Chipponi J, Demeocq F, Kanold J. Focal nodular hyperplasia of the liver in patients previously treated for pediatric neoplastic diseases. J Pediatr Hematol Oncol. 2008;30(7):546-9. [pmid: 18797204]. Rec#: 1320 Reprint: exc nrd nrp
Marabelle A, Paillard C, Tchirkov A, Halle P, Chassagne J, Demeocq F, Kanold J. Graft-versus-tumour effect in refractory metastatic neuroblastoma. 2007. Rec#: 4010 Reprint: exc nrs
Marina N, Meyers PA. High-dose therapy and stem-cell rescue for Ewing's family of tumors in second remission. J Clin Oncol. 2005;23(19):4262-4. [pmid: 15781877]. Rec#: 7510 Reprint: EXC EDT
Marina NM, Pappo AS, Parham DM, Cain AM, Rao BN, Poquette CA, Pratt CB, Greenwald C, Meyer WH. Chemotherapy dose-intensification for pediatric patients with Ewing's family of tumors and desmoplastic small round-cell tumors: a feasibility study at St Jude Children's Research Hospital. J Clin Oncol. 1999;17(1):180-90. [pmid: 10458232]. Rec#: 44060 Reprint: exc nrp
Markowitz J, Grancher K, Kohn N, Lesser M, Daum F. A multicenter trial of 6-mercaptopurine and prednisone in children with newly diagnosed Crohn's disease. Gastroenterology. 2000;119(4):895-902. [pmid: 11040176]. Rec#: 42200 Reprint: exc nrc
Markowitz JF. Therapeutic efficacy and safety of 6-mercaptopurine and azathioprine in patients with Crohn's disease. Rev Gastroenterol Disord. Suppl 1. 2003;3:S23-9. [pmid: 12684586]. Rec#: 10700 Reprint: exc nra
Marmont AM, Gualandi F, Occhini D, Morandi F, Ferretti E, Pezzolo A, Strada P, Ravetti JL, Pistoia V, Falanga A, Bacigalupo A. Catastrophic relapse of Evans syndrome five years after allogeneic BMT notwithstanding full donor chimerism. Terminal hemolytic-uremic syndrome. Autoimmunity. 2006;39(6):505-11. [pmid: 17060030]. Rec#: 4790 Reprint: exc nrp
Martin PL, Carter SL, Kernan NA, Sahdev I, Wall D, Pietryga D, Wagner JE, Kurtzberg J. Results of the cord blood transplantation study (COBLT): outcomes of unrelated donor umbilical cord blood transplantation in pediatric patients with lysosomal and peroxisomal storage diseases. Biol Blood Marrow Transplant. 2006;12(2):184-94. [pmid: 16443516]. Rec#: 6110 Reprint: exc nrp
Martinez-Banos D, Crispin JC, Lazo-Langner A, Sanchez-Guerrero J. Moderate and severe neutropenia in patients with systemic lupus erythematosus. Rheumatology (Oxford). 2006;45(8):994-8. [pmid: 16484291]. Rec#: 6000 Reprint: exc nro
Martini A, Maccario R, Ravelli A, Montagna D, De Benedetti F, Bonetti F, Viola S, Zecca M, Perotti C, Locatelli F. Marked and sustained improvement two years after autologous stem cell transplantation in a girl with systemic sclerosis. Arthritis Rheum. 1999;42(4):807-11. [pmid: 10211898]. Rec#: 16930 Reprint: exc same as rec 16270
Marwaha RK, Aggarwal P, Trehan A. Immune thrombocytopenic purpura. Indian Pediatr. 1996;33(12):1019-26. [pmid: 9141802]. Rec#: 19970 Reprint: exc nra
Marymont MH, Geohas J, Tomita T, Strauss L, Brand WN, Mittal BB. Hyperfractionated craniospinal radiation in medulloblastoma. Pediatr Neurosurg. 1996;24(4):178-84. [pmid: 8873159]. Rec#: 21180 Reprint: EXC NRI
Massimino M, Gandola L, Spreafico F, Luksch R, Collini P, Giangaspero F, Simonetti F, Casanova M, Cefalo G, Pignoli E, Ferrari A, Terenziani M, Podda M, Meazza C, Polastri D, Poggi G, Ravagnani F, Fossati-Bellani F. Supratentorial primitive neuroectodermal tumors (S-PNET) in children: A prospective experience with adjuvant intensive chemotherapy and hyperfractionated accelerated radiotherapy. Int J Radiat Oncol Biol Phys. 2006;64(4):1031-7. [pmid: 16343801]. Rec#: 6330 Reprint: EXC NRI
Mathew S, Head D, Rodriguez-Galindo C, Raimondi SC. Trisomy of the long arm of chromosome 1 resulting in a dicentric derivative (6)t(1;6) chromosome in a child with myelodysplastic syndrome following treatment for a primitive neuroectodermal tumor. Leuk Lymphoma. 2000;37(1-2):213-8. [pmid: 10721789]. Rec#: 15510 Reprint: EXC NRI
Matsumoto M, Yagi H, Ishizashi H, Wada H, Fujimura Y. The Japanese experience with thrombotic thrombocytopenic purpura-hemolytic uremic syndrome. Semin Hematol. 2004;41(1):68-74. [pmid: 14727261]. Rec#: 9410 Reprint: exc nrd
Matthay KK. Impact of myeloablative therapy with bone marrow transplantation in advanced neuroblastoma. Bone Marrow Transplant. Suppl 3. 1996;18:S21-4. [pmid: 8971402]. Rec#: 20030 Reprint: EXC NRI
Matthay KK, Atkinson JB, Stram DO, Selch M, Reynolds CP, Seeger RC. Patterns of relapse after autologous purged bone marrow transplantation for neuroblastoma: a Childrens Cancer Group pilot study. J Clin Oncol. 1993;11(11):2226-33. [pmid: 8229138]. Rec#: 23710 Reprint: EXC YEAR
Matthay KK, DeSantes K, Hasegawa B, Huberty J, Hattner RS, Ablin A, Reynolds CP, Seeger RC, Weinberg VK, Price D. Phase I dose escalation of 131I-metaiodobenzylguanidine with autologous bone marrow support in refractory neuroblastoma. J Clin Oncol. 1998;16(1):229-36. [pmid: 9440747]. Rec#: 18780 Reprint: exc nri
Matthay KK, Edeline V, Lumbroso J, Tanguy ML, Asselain B, Zucker JM, Valteau-Couanet D, Hartmann O, Michon J. Correlation of early metastatic response by 123I-metaiodobenzylguanidine scintigraphy with overall response and event-free survival in stage IV neuroblastoma. J Clin Oncol. 2003;21(13):2486-91. [pmid: 12829667]. Rec#: 10310 Reprint: exc nri
Matthay KK, O'Leary MC, Ramsay NK, Villablanca J, Reynolds CP, Atkinson JB, Haase GM, Stram DO, Seeger RC. Role of myeloablative therapy in improved outcome for high risk neuroblastoma: review of recent Children's Cancer Group results. Eur J Cancer. 1995;31A(4):572-5. [pmid: 7576971]. Rec#: 22410 Reprint: EXC NRI NPD
Matthay KK, Perez C, Seeger RC, Brodeur GM, Shimada H, Atkinson JB, Black CT, Gerbing R, Haase GM, Stram DO, Swift P, Lukens JN. Successful treatment of stage III neuroblastoma based on prospective biologic staging: a Children's Cancer Group study. J Clin Oncol. 1998;16(4):1256-64. [pmid: 9552023]. Rec#: 18370 Reprint: exc nri
Matthay KK, Seeger RC, Reynolds CP, Stram DO, O'Leary M, Harris RE, Selch M, Atkinson JB, Haase G, Hammond GD, et al. Comparison of autologous and allogeneic bone marrow transplantation for neuroblastoma. Prog Clin Biol Res. 1994;385:301-7. [pmid: 7972225]. Rec#: 23440 Reprint: EXC Year
Matthay KK, Seeger RC, Reynolds CP, Stram DO, O'Leary MC, Harris RE, Selch M, Atkinson JB, Haase GM, Ramsay NK. Allogeneic versus autologous purged bone marrow transplantation for neuroblastoma: a report from the Childrens Cancer Group. J Clin Oncol. 1994;12(11):2382-9. [pmid: 7964954]. Rec#: 22540 Reprint: EXC Year
Matthay KK, Tan JC, Villablanca JG, Yanik GA, Veatch J, Franc B, Twomey E, Horn B, Reynolds CP, Groshen S, Seeger RC, Maris JM. Phase I dose escalation of iodine-131-metaiodobenzylguanidine with myeloablative chemotherapy and autologous stem-cell transplantation in refractory neuroblastoma: a new approaches to Neuroblastoma Therapy Consortium Study. J Clin Oncol. 2006;24(3):500-6. [pmid: 16421427]. Rec#: 6210 Reprint: exc nri
McBride SM, Daganzo SM, Banerjee A, Gupta N, Lamborn KR, Prados MD, Berger MS, Wara WM, Haas-Kogan DA. Radiation is an important component of multimodality therapy for pediatric non-pineal supratentorial primitive neuroectodermal tumors. Int J Radiat Oncol Biol Phys. 2008;72(5):1319-23. [pmid: 18485615]. Rec#: 1970 Reprint: EXC NRI
McCabe MA, Crowe H, Quinones R. Neurodevelopmental side effects of bone marrow transplantation: two case illustrations of identical twins. J Pediatr Hematol Oncol. 1997;19(2):145-50. [pmid: 9149746]. Rec#: 19610 Reprint: exc nri
McCowage GB, Vowels MR, Shaw PJ, Lockwood L, Mameghan H. Autologous bone marrow transplantation for advanced neuroblastoma using teniposide, doxorubicin, melphalan, cisplatin, and total-body irradiation. J Clin Oncol. 1995;13(11):2789-95. [pmid: 7595740]. Rec#: 21440 Reprint: EXC NRI
McDowell R, Li JS, Benjamin DK Jr, Morgan C, Becker A, Kishnani PS, Kanter RJ. Arrhythmias in patients receiving enzyme replacement therapy for infantile Pompe disease. Genet Med. 2008;10(10):758-62. [pmid: 18813140]. Rec#: 56770 Reprint: exc nrc
McMinn JR Jr, Cohen S, Moore J, Lilly S, Parkhurst J, Tarantino MD, Terrell DR, George JN. Complete recovery from refractory immune thrombocytopenic purpura in three patients treated with etanercept. Am J Hematol. 2003;73(2):135-40. [pmid: 12749017]. Rec#: 78200 Reprint: exc nrc
Meany HJ, Seibel NL, Sun J, Finklestein JZ, Sato J, Kelleher J, Sondel P, Reaman G. Phase 2 trial of recombinant tumor necrosis factor-alpha in combination with dactinomycin in children with recurrent Wilms tumor. J Immunother. 2008;31(7):679-83. [pmid: 18600176]. Rec#: 44810 Reprint: EXC NRO
Meignin V, Gluckman E, Gambaraelli D, Devergie A, Ramee MP, Janin A, Socie G. Meningioma in long-term survivors after allogeneic bone marrow transplantation. Bone Marrow Transplant. 1998;22(7):723-4. [pmid: 9818703]. Rec#: 72500 Reprint: EXC NRI
Melemed AS, Vance G, Kotylo PK, Smith FO. Potential role of hematopoietic stem cell transplantation in children with secondary acute lymphocytic leukemia. Bone Marrow Transplant. 2002;29(2):173-5. [pmid: 11850713]. Rec#: 12590 Reprint: exc nri
Mellouli F, Ksouri H, Torjmen L, Abdelkefi A, Ladeb S, Ben Othman T, Ben Hassen A, Bejaoui M. Transmission of type 1 diabetes by bone marrow transplantation: a case report. Pediatr Transplant. 2009;13(1):119-22. [pmid: 18208435]. Rec#: 2610 Reprint: exc nrs
Metzger ML, Stewart CF, Freeman BB 3rd, Billups CA, Hoffer FA, Wu J, Coppes MJ, Grant R, Chintagumpala M, Mullen EA, Alvarado C, Daw NC, Dome JS. Topotecan is active against Wilms' tumor: results of a multi-institutional phase II study. J Clin Oncol. 2007;25(21):3130-6. [pmid: 17634492]. Rec#: 44940 Reprint: exc nrs
Meyer A, Kossow K, Gal A, Muhlhausen C, Ullrich K, Braulke T, Muschol N. Scoring evaluation of the natural course of mucopolysaccharidosis type IIIA (Sanfilippo syndrome type A). Pediatrics. 2007;120(5):e1255-61. [pmid: 17938166]. Rec#: 56890 Reprint: exc nrs
Miano M, Garaventa A, Pizzitola MR, Piccolo MS, Dallorso S, Villavecchia GP, Bertolazzi C, Cabria M, De Bernardi B. Megatherapy combining I(131) metaiodobenzylguanidine and high-dose chemotherapy with haematopoietic progenitor cell rescue for neuroblastoma. Bone Marrow Transplant. 2001;27(6):571-4. [pmid: 11319584]. Rec#: 13820 Reprint: exc nri
Mikaeloff Y, Raquin MA, Lellouch-Tubiana A, Terrier-Lacombe MJ, Zerah M, Bulteau C, Habrand JL, Kalifa C. Primitive cerebral neuroectodermal tumors excluding medulloblastomas: a retrospective study of 30 cases. Pediatr Neurosurg. 1998;29(4):170-7. [pmid: 9876245]. Rec#: 71900 Reprint: EXC NRI
Miser JS, Goldsby RE, Chen Z, Krailo MD, Tarbell NJ, Link MP, Fryer CJ, Pritchard DJ, Gebhardt MC, Dickman PS, Perlman EJ, Meyers PA, Donaldson SS, Moore SG, Rausen AR, Vietti TJ, Grier HE. Treatment of metastatic Ewing sarcoma/primitive neuroectodermal tumor of bone: evaluation of increasing the dose intensity of chemotherapy--a report from the Children's Oncology Group. Pediatr Blood Cancer. 2007;49(7):894-900. [pmid: 17584910]. Rec#: 3680 Reprint: EXC DUP
Miser JS, Krailo MD, Tarbell NJ, Link MP, Fryer CJ, Pritchard DJ, Gebhardt MC, Dickman PS, Perlman EJ, Meyers PA, Donaldson SS, Moore S, Rausen AR, Vietti TJ, Grier HE. Treatment of metastatic Ewing's sarcoma or primitive neuroectodermal tumor of bone: evaluation of combination ifosfamide and etoposide--a Children's Cancer Group and Pediatric Oncology Group study. J Clin Oncol. 2004;22(14):2873-6. [pmid: 15254055]. Rec#: 8580 Reprint: exc nrp
Mishima Y, Nagasaki E, Terui Y, Irie T, Takahashi S, Ito Y, Oguchi M, Kawabata K, Kamata S, Hatake K. Combination chemotherapy (cyclophosphamide, doxorubicin, and vincristine with continuous-infusion cisplatin and etoposide) and radiotherapy with stem cell support can be beneficial for adolescents and adults with estheisoneuroblastoma. Cancer. 2004;101(6):1437-44. [pmid: 15368332]. Rec#: 8320 Reprint: exc nrd
Mitchell C, Jones PM, Kelsey A, Vujanic GM, Marsden B, Shannon R, Gornall P, Owens C, Taylor R, Imeson J, Middleton H, Pritchard J. The treatment of Wilms' tumour: results of the United Kingdom Children's cancer study group (UKCCSG) second Wilms' tumour study. Br J Cancer. 2000;83(5):602-8. [pmid: 10944599]. Rec#: 45830 Reprint: exc nrp
Mitchell C, Pritchard-Jones K, Shannon R, Hutton C, Stevens S, Machin D, Imeson J, Kelsey A, Vujanic GM, Gornall P, Walker J, Taylor R, Sartori P, Hale J, Levitt G, Messahel B, Middleton H, Grundy R, Pritchard J. Immediate nephrectomy versus preoperative chemotherapy in the management of non-metastatic Wilms' tumour: results of a randomised trial (UKW3) by the UK Children's Cancer Study Group. Eur J Cancer. 2006;42(15):2554-62. [pmid: 16904312]. Rec#: 45050 Reprint: exc nrp
Mittal R, Al Awadi S, Sahar O, Behbehani AM. Ewing's sarcoma as second malignant neoplasm after retinoblastoma: a case report. Med Princ Pract. 2008;17(1):84-5. [pmid: 18059108]. Rec#: 2820 Reprint: exc nrp
Mittal S, Milner BJ, Johnston PW, Culligan DJ. A case of hepatosplenic gamma-delta T-cell lymphoma with a transient response to fludarabine and alemtuzumab. Eur J Haematol. 2006;76(6):531-4. [pmid: 16548918]. Rec#: 5880 Reprint: EXC NRD NRI
Miyatake S, Kawabata S, Yokoyama K, Kuroiwa T, Michiue H, Sakurai Y, Kumada H, Suzuki M, Maruhashi A, Kirihata M, Onoc K. Survival benefit of boron neutron capture therapy for recurrent malignant gliomas. Appl Radiat Isot. 2009;67(7-8 Suppl):S22-4. [pmid: 19394240]. Rec#: 54380 Reprint: exc nrp
Moftakhar P, Fan X, Hurvitz CH, Black KL, Danielpour M. Long-term survival in a child with a central nervous system medulloepithelioma. J Neurosurg Pediatr. 2008;2(5):339-45. [pmid: 18976104]. Rec#: 71120 Reprint: EXC NRI
Mondria T, Lamers CH, te Boekhorst PA, Gratama JW, Hintzen RQ. Bone-marrow transplantation fails to halt intrathecal lymphocyte activation in multiple sclerosis. J Neurol Neurosurg Psychiatry. 2008;79(9):1013-5. [pmid: 18223013]. Rec#: 2550 Reprint: exc nro
Moore AS, Shaw PJ, Hallahan AR, Carter TL, Kilo T, Nivison-Smith I, O'Brien TA, Tapp H, Teague L, Wilson SR, Tiedemann K. Haemopoietic stem cell transplantation for children in Australia and New Zealand, 1998-2006: a report on behalf of the Australasian Bone Marrow Transplant Recipient Registry and the Australian and New Zealand Children's Haematology Oncology Group. Med J Aust. 2009;190(3):121-5. [pmid: 19203307]. Rec#: 70140 Reprint: EXC NRO
Moreno JC, Valverde F, Martinez F, Velez A, Torres A, Fanego J, Ocana MS. Bullous scleroderma-like changes in chronic graft-versus-host disease. J Eur Acad Dermatol Venereol. 2003;17(2):200-3. [pmid: 12705752]. Rec#: 10620 Reprint: exc nrs
Moser HW. New concepts in the diagnosis and treatment of lysosomal and peroxisomal disorders. Curr Opin Neurol Neurosurg. 1992;5(3):355-8. [pmid: 1623264]. Rec#: 25050 Reprint: EXC REV
Motto DG, Williams JA, Boxer LA. Rituximab for refractory childhood autoimmune hemolytic anemia. Isr Med Assoc J. 2002;4(11):1006-8. [pmid: 12489491]. Rec#: 78290 Reprint: exc nrc
Motzer R, Nichols C, Margolin K, Bacik J, Richardson P, Vogelzang N, et al. Phase III randomized trial of conventionaldose chemotherapy with or without high-dose chemotherapy and autologous hematopoietic stem-cell rescue as first-line treatment for patients with poor-prognosis metastatic germ cell tumors. J Clin Oncol. 2007;25:247-256. [pmid: 17235042]. Rec#: 78860 Reprint: EXC NRP
Motzer RJ, Mazumdar M, Bosl GJ, Bajorin DF, Amsterdam A, Vlamis V. High-dose carboplatin, etoposide, and cyclophosphamide for patients with refractory germ cell tumors: treatment results and prognostic factors for survival and toxicity. J Clin Oncol. 1996;14(4):1098-105. [pmid: 8648363]. Rec#: 51600 Reprint: exc nrp
Motzer RJ, Mazumdar M, Bosl GJ, et al. High-dose carboplatin, etoposide, and cyclophosphamide for patients with refractory germ cell tumors: treatment results and prognostic factors for survival and toxicity. J Clin Oncol. 1996;14:1098-1105. [pmid: 8648363]. Rec#: 78810 Reprint: EXC NRP
Motzer RJ, Sheinfeld S. Poor-risk testicular cancer and highdose chemotherapy. J Clin Oncol. 2003;21:4073-4074. [pmid: 14568986]. Rec#: 78830 Reprint: EXC EDT
Moyo VM, Smith D, Brodsky I, Crilley P, Jones RJ, Brodsky RA. High-dose cyclophosphamide for refractory autoimmune hemolytic anemia. Blood. 2002;100(2):704-6. [pmid: 12091370]. Rec#: 11960 Reprint: exc nrs
Mugishima H, Harada K, Suzuki T, Chin M, Shimada T, Takamura M, Shichino H, Fujisawa T, Ichikawa M, Iwata M, et al. Comprehensive treatment of advanced neuroblastoma involving autologous bone marrow transplant. Acta Paediatr Jpn. 1995;37(4):493-9. [pmid: 7572151]. Rec#: 21660 Reprint: EXC NRI
Mulhern RK, Palmer SL, Merchant TE, Wallace D, Kocak M, Brouwers P, Krull K, Chintagumpala M, Stargatt R, Ashley DM, Tyc VL, Kun L, Boyett J, Gajjar A. Neurocognitive consequences of risk-adapted therapy for childhood medulloblastoma. J Clin Oncol. 2005;23(24):5511-9. [pmid: 16110011]. Rec#: 6840 Reprint: EXC NRO
Mulne AF, Ducore JM, Elterman RD, Friedman HS, Krischer JP, Kun LE, Shuster JJ, Kadota RP. Oral methotrexate for recurrent brain tumors in children: a Pediatric Oncology Group study. J Pediatr Hematol Oncol. 2000;22(1):41-4. [pmid: 10695820]. Rec#: 53580 Reprint: exc nro
Musso M, Porretto F, Crescimanno A, Bondi F, Polizzi V, Scalone R, Mariani G. Autologous peripheral blood stem and progenitor (CD34+) cell transplantation for systemic lupus erythematosus complicated by Evans syndrome. Lupus. 1998;7(7):492-4. [pmid: 9796853]. Rec#: 17530 Reprint: exc nro
Mutafoglu Uysal K, Olgun N, Sarialioglu F, Kargi A, Cevik N. A case with extraosseous Ewing's sarcoma: a late effect related to bone marrow transplantation for thalassemia or a component of a familial cancer syndrome?. Pediatr Hematol Oncol. 2000;17(5):415-9. [pmid: 10914053]. Rec#: 15130 Reprint: EXC NRD
Muwakkit S, Rachid R, Bazarbachi A, Araysi T, Dbaibo GS. Treatment-resistant infantile Evans syndrome. Pediatr Int. 2001;43(5):502-4. [pmid: 11737713]. Rec#: 78390 Reprint: exc cr
Nabhan ZM, Kreher NC, Greene DM, Eugster EA, Kronenberger W, DiMeglio LA. A randomized prospective study of insulin pump vs. insulin injection therapy in very young children with type 1 diabetes: 12-month glycemic, BMI, and neurocognitive outcomes. Pediatr Diabetes. 2009;10(3):202-8. [pmid: 19140899]. Rec#: 61730 Reprint: exc nro
Nagane M, Kobayashi K, Ohnishi A, Shimizu S, Shiokawa Y. Prognostic significance of O6-methylguanine-DNA methyltransferase protein expression in patients with recurrent glioblastoma treated with temozolomide. Jpn J Clin Oncol. 2007;37(12):897-906. [pmid: 18156172]. Rec#: 54640 Reprint: exc nrp
Nakagawa Y, Kageji T, Mizobuchi Y, Kumada H, Nakagawa Y. Clinical results of BNCT for malignant brain tumors in children. Appl Radiat Isot. 2009;67(7-8 Suppl):S27-30. [pmid: 19406652]. Rec#: 54370 Reprint: exc nrt
Nakakura H, Ashida A, Matsumura H, Murata T, Nagatoya K, Shibahara N, Inoue T, Tamai H. A case report of successful treatment with plasma exchange for hemophagocytic syndrome associated with severe systemic juvenile idiopathic arthritis in an infant girl. Ther Apher Dial. 2009;13(1):71-6. [pmid: 19379173]. Rec#: 280 Reprint: exc nrd
Nasution R, Sutjipto A. Childhood retinoblastoma. Paediatr Indones. 1991;31(3-4):117-22. [pmid: 1956690]. Rec#: 26320 Reprint: EXC YEAR
Nathan DM, Cleary PA, Backlund JY, Genuth SM, Lachin JM, Orchard TJ, Raskin P, Zinman B. Intensive diabetes treatment and cardiovascular disease in patients with type 1 diabetes. N Engl J Med. 2005;353(25):2643-53. [pmid: 16371630]. Rec#: 62090 Reprint: exc nrp
Nathan DM, Zinman B, Cleary PA, Backlund JY, Genuth S, Miller R, Orchard TJ. Modern-day clinical course of type 1 diabetes mellitus after 30 years' duration: the diabetes control and complications trial/epidemiology of diabetes interventions and complications and Pittsburgh epidemiology of diabetes complications experience (1983-. Arch Intern Med. 2009;169(14):1307-16. [pmid: 19636033]. Rec#: 61680 Reprint: exc nrp
Nathan PC, Furlong W, De Pauw S, Horsman J, Van Schaik C, Rolland M, Weitzman S, Feeny D, Barr RD. Health status of young children during therapy for advanced neuroblastoma. Pediatr Blood Cancer. 2004;43(6):659-67. [pmid: 15390299]. Rec#: 8250 Reprint: exc nri
Navid F, Billups C, Liu T, Krasin MJ, Rodriguez-Galindo C. Second cancers in patients with the Ewing sarcoma family of tumours. Eur J Cancer. 2008;44(7):983-91. [pmid: 18353632]. Rec#: 43000 Reprint: exc nrp
Nelson JL, Torrez R, Louie FM, Choe OS, Storb R, Sullivan KM. Pre-existing autoimmune disease in patients with long-term survival after allogeneic bone marrow transplantation. J Rheumatol Suppl. 1997;48:23-9. [pmid: 9150114]. Rec#: 19500 Reprint: exc nrd
Nenadov Beck M, Meresse V, Hartmann O, Gaultier C. Long-term pulmonary sequelae after autologous bone marrow transplantation in children without total body irradiation. Bone Marrow Transplant. 1995;16(6):771-5. [pmid: 8750268]. Rec#: 21340 Reprint: EXC NRO
Nerome Y, Imanaka H, Nonaka Y, Takei S. Switching the therapy from etanercept to infliximab in a child with rheumatoid factor positive polyarticular juvenile idiopathic arthritis. Mod Rheumatol. 2007;17(6):526-8. [pmid: 18084710]. Rec#: 41150 Reprint: exc cr
Neuwelt CM. The role of plasmapheresis in the treatment of severe central nervous system neuropsychiatric systemic lupus erythematosus. Ther Apher Dial. 2003;7(2):173-82. [pmid: 12918940]. Rec#: 10020 Reprint: exc nri
Neve V, Foot AB, Michon J, Fourquet A, Zucker JM, Boule M. Longitudinal clinical and functional pulmonary follow-up after megatherapy, fractionated total body irradiation, and autologous bone marrow transplantation for metastatic neuroblastoma. Med Pediatr Oncol. 1999;32(3):170-6. [pmid: 10064183]. Rec#: 17160 Reprint: EXC NRI
Ng SM, Abdullah WA, Lin HP, Chan LL. Presenting features and treatment outcome of 78 Malaysian children with neuroblastoma. Southeast Asian J Trop Med Public Health. 1999;30(1):149-53. [pmid: 10695803]. Rec#: 15620 Reprint: exc nri
Nguyen QA, Villablanca JG, Siegel SE, Crockett DM. Esthesioneuroblastoma in the pediatric age-group: the role of chemotherapy and autologous bone marrow transplantation. Int J Pediatr Otorhinolaryngol. 1996;37(1):45-52. [pmid: 8884406]. Rec#: 20280 Reprint: exc nri
Nicholson HS, Kretschmar CS, Krailo M, Bernstein M, Kadota R, Fort D, Friedman H, Harris MB, Tedeschi-Blok N, Mazewski C, Sato J, Reaman GH. Phase 2 study of temozolomide in children and adolescents with recurrent central nervous system tumors: a report from the Children's Oncology Group. Cancer. 2007;110(7):1542-50. [pmid: 17705175]. Rec#: 52240 Reprint: exc nro
Nicolaides T, Tihan T, Horn B, Biegel J, Prados M, Banerjee A. High-dose chemotherapy and autologous stem cell rescue for atypical teratoid/rhabdoid tumor of the central nervous system. J Neurooncol. 2010;98(1):117-23. [pmid: 19936623]. Rec#: 71920 Reprint: EXC; NRI; one HSCT patient reported in Gardner (2008)
Nicolino M, Byrne B, Wraith JE, Leslie N, Mandel H, Freyer DR, Arnold GL, Pivnick EK, Ottinger CJ, Robinson PH, Loo JC, Smitka M, Jardine P, Tato L, Chabrol B, McCandless S, Kimura S, Mehta L, Bali D, Skrinar A, Morgan C, Rangachari L, Corzo D, Kishnani PS. Clinical outcomes after long-term treatment with alglucosidase alfa in infants and children with advanced Pompe disease. Genet Med. 2009;11(3):210-9. [pmid: 19287243]. Rec#: 56680 Reprint: exc nrc
Niebanck AE, Kwiatkowski JL, Raffini LJ. Neutropenia following IVIG therapy in pediatric patients with immune-mediated thrombocytopenia. J Pediatr Hematol Oncol. 2005;27(3):145-7. [pmid: 15750446]. Rec#: 7600 Reprint: exc nro
Niedzielska E, Wojcik D, Barg E, Pietras W, Sega-Pondel D, Doroszko A, Niedzielska M, Skarzynska M, Chybicka A. [Evaluation of selected endocrine complications in patients treated with auto- and allo-haematopoietic stem cell transplantation]. Med Wieku Rozwoj. 2008;12(3):761-6. [pmid: 19305027]. Rec#: 70240 Reprint: EXC FLA
Nitschke R, Parkhurst J, Sullivan J, Harris MB, Bernstein M, Pratt C. Topotecan in pediatric patients with recurrent and progressive solid tumors: a Pediatric Oncology Group phase II study. J Pediatr Hematol Oncol. 1998;20(4):315-8. [pmid: 9703003]. Rec#: 48130 Reprint: EXC NRI
Nitschke R, Smith EI, Altshuler G, Altmiller D, Shuster J, Green A, Castleberry R, Hayes FA, Golembe B, Ducos R. Postoperative treatment of nonmetastatic visible residual neuroblastoma: a Pediatric Oncology Group study. J Clin Oncol. 1991;9(7):1181-8. [pmid: 2045858]. Rec#: 26110 Reprint: EXC YEAR
Nordfeldt S, Ludvigsson J. Adverse events in intensively treated children and adolescents with type 1 diabetes. Acta Paediatr. 1999;88(11):1184-93. [pmid: 10591418]. Rec#: 62530 Reprint: exc nrs
Nordwall M, Hyllienmark L, Ludvigsson J. Early diabetic complications in a population of young patients with type 1 diabetes mellitus despite intensive treatment. J Pediatr Endocrinol Metab. 2006;19(1):45-54. [pmid: 16509528]. Rec#: 62060 Reprint: exc nrp
Notteghem P, Soler C, Dellatolas G, Kieffer-Renaux V, Valteau-Couanet D, Raimondo G, Hartmann O. Neuropsychological outcome in long-term survivors of a childhood extracranial solid tumor who have undergone autologous bone marrow transplantation. Bone Marrow Transplant. 2003;31(7):599-606. [pmid: 12692628]. Rec#: 10640 Reprint: exc nro
O, Bokemeyer C, Beyer J, Hartmann J, Schwella N, Kingreen D, et al. Salvage treatment with paclitaxel, ifosfamide, and cisplatin plus high-dose carboplatin, etoposide, and thiotepa followed by autologous stem-cell rescue in patients with relapsed or refractory germ cell cancer. J Clin Oncol. 2001;19:81-88. [pmid: 11134198]. Rec#: 78850 Reprint: EXC NRP
Obata H, Ueda T, Kawai A, Ishii T, Ozaki T, Abe S, Tanaka K, Tsuchiya H, Matsumine A, Yabe H. Clinical outcome of patients with Ewing sarcoma family of tumors of bone in Japan: the Japanese Musculoskeletal Oncology Group cooperative study. Cancer. 2007;109(4):767-75. [pmid: 17238190]. Rec#: 43180 Reprint: exc nrp
Oberlin O, Rey A, Desfachelles AS, Philip T, Plantaz D, Schmitt C, Plouvier E, Lejars O, Rubie H, Terrier P, Michon J. Impact of high-dose busulfan plus melphalan as consolidation in metastatic Ewing tumors: a study by the Societe Francaise des Cancers de l'Enfant. J Clin Oncol. 2006;24(24):3997-4002. [pmid: 16921053]. Rec#: 5130 Reprint: exc nrp
O'Brien TA, Eastlund T, Peters C, Neglia JP, Defor T, Ramsay NK, Scott Baker K. Autoimmune haemolytic anaemia complicating haematopoietic cell transplantation in paediatric patients: high incidence and significant mortality in unrelated donor transplants for non-malignant diseases. Br J Haematol. 2004;127(1):67-75. [pmid: 15384979]. Rec#: 8270 Reprint: exc nrd
Ochiai T, Ito K, Okada T, Chin M, Shichino H, Mugishima H. Significance of extensive Mongolian spots in Hunter's syndrome. Br J Dermatol. 2003;148(6):1173-8. [pmid: 12828746]. Rec#: 10320 Reprint: EXC DAC
Ochiai T, Ito K, Shichino H, Chin M, Mugishima H. Ultrastructural findings of cutaneous nerves in patients with Hunter's syndrome following hematopoietic stem cell transplant. Med Mol Morphol. 2005;38(2):118-22. [pmid: 15944819]. Rec#: 7140 Reprint: exc nro
Ogawa H, Kameda H, Amano K, Takeuchi T. Efficacy and safety of cyclosporine A in patients with refractory systemic lupus erythematosus in a daily clinical practice. Lupus. 2010;19(2):162-9. [pmid: 19952069]. Rec#: 40850 Reprint: exc nrp
Ogose T, Watanabe T, Suzuya H, Kaneko M, Onishi T, Watanabe H, Nakagawa R, Okamoto Y, Sano N, Kozan Y, Kuroda Y. Autoimmune hepatitis following allogeneic PBSCT from an HLA-matched sibling. Bone Marrow Transplant. 2003;31(9):829-32. [pmid: 12732893]. Rec#: 10590 Reprint: EXC NRS
Ohnuma K, Isoyama K, Nishihira H. Cord blood transplantation from HLA-mismatched unrelated donors. Leuk Lymphoma. 2002;43(5):1029-34. [pmid: 12148882]. Rec#: 11840 Reprint: exc nrp
Ohnuma N, Takahashi H, Kaneko M, Uchino J, Takeda T, Iwafuchi M, Ohhira M, Nishihira H, Mugishima H, Yokoyama J, et al. Treatment combined with bone marrow transplantation for advanced neuroblastoma: an analysis of patients who were pretreated intensively with the protocol of the Study Group of Japan. Med Pediatr Oncol. 1995;24(3):181-7. [pmid: 7838040]. Rec#: 22030 Reprint: EXC NRI
Okamoto Y, Takaue Y, Saito S, Shimizu T, Suzue T, Abe T, Sato J, Hirao A, Watanabe T, Kawano Y, et al. Toxicities associated with cryopreserved and thawed peripheral blood stem cell autografts in children with active cancer. Transfusion. 1993;33(7):578-81. [pmid: 8101399]. Rec#: 24040 Reprint: EXC YEAR
Olivares JL, Ramos FJ, Olive T, Fillat C, Bueno M. Autoimmune thyroiditis after bone marrow transplantation in a boy with Wiskott-Aldrich syndrome. J Pediatr Hematol Oncol. 2002;24(9):772-6. [pmid: 12468924]. Rec#: 11260 Reprint: exc nrd
Olowu WA. Lupus nephropathy and cardiopulmonary and hepatic dysfunctions in a child. Pediatr Nephrol. 2006;21(9):1318-22. [pmid: 16819645]. Rec#: 5340 Reprint: exc nrd
Olshan JS, Willi SM, Gruccio D, Moshang T Jr. Growth hormone function and treatment following bone marrow transplant for neuroblastoma. Bone Marrow Transplant. 1993;12(4):381-5. [pmid: 8275038]. Rec#: 23780 Reprint: EXC YEAR
Ortega JA, Donaldson SS, Ivy SP, Pappo A, Maurer HM. Venoocclusive disease of the liver after chemotherapy with vincristine, actinomycin D, and cyclophosphamide for the treatment of rhabdomyosarcoma. A report of the Intergroup Rhabdomyosarcoma Study Group. Childrens Cancer Group, the Pediatric Oncology Group, and the Pediatric Intergroup Statistical Center. Cancer. 1997;79(12):2435-9. [pmid: 9191535]. Rec#: 19250 Reprint: exc nro
Osunkwo I, Bessmertny O, Harrison L, Cheung YK, Van de Ven C, del Toro G, Garvin J, George D, Bradley MB, Wolownik K, Wischhover C, Levy J, Skerrett D, Cairo MS. A pilot study of tacrolimus and mycophenolate mofetil graft-versus-host disease prophylaxis in childhood and adolescent allogeneic stem cell transplant recipients. Biol Blood Marrow Transplant. 2004;10(4):246-58. [pmid: 15077223]. Rec#: 9040 Reprint: EXC NRD
Otten MH, Prince FH, Twilt M, van Rossum MA, Armbrust W, Hoppenreijs EP, Kamphuis S, Koopman-Keemink Y, Wulffraat NM, Gorter SL, Ten Cate R, van Suijlekom-Smit LW. Delayed clinical response in patients with juvenile idiopathic arthritis treated with etanercept. J Rheumatol. 2010;37(3):665-7. [pmid: 20080910]. Rec#: 77220 Reprint: exc nri
Oyama Y, Barr WG, Statkute L, Corbridge T, Gonda EA, Jovanovic B, Testori A, Burt RK. Autologous non-myeloablative hematopoietic stem cell transplantation in patients with systemic sclerosis. Bone Marrow Transplant. 2007;40(6):549-55. [pmid: 17646844]. Rec#: 3450 Reprint: exc nrp
Oyharcabal-Bourden V, Kalifa C, Genet JC. Standard-Risk Medulloblastoma Traeted by Adjuvant Chemotherapy Followed by Reduced-Dose Craniospinal Radiation Therapy: A French Society of Pediatric Oncology Study. J Clin Oncol. 2005;23(19). Rec#: Reprint: exc nri nrc
Ozkan A, Pazarli H, Celkan T, Karaman S, Apak H, Kaner G, Uzel O, Yildiz I. Retinoblastoma in Turkey: survival and clinical characteristics 1981-2004. Pediatr Int. 2006;48(4):369-73. [pmid: 16911081]. Rec#: 5170 Reprint: exc nro
Ozkaynak MF, Sondel PM, Krailo MD, Gan J, Javorsky B, Reisfeld RA, Matthay KK, Reaman GH, Seeger RC. Phase I study of chimeric human/murine anti-ganglioside G(D2) monoclonal antibody (ch14.18) with granulocyte-macrophage colony-stimulating factor in children with neuroblastoma immediately after hematopoietic stem-cell transplantation: a Children's Cancer Group Study. J Clin Oncol. 2000;18(24):4077-85. [pmid: 11118469]. Rec#: 14390 Reprint: exc nri
Ozsahin H, Le Deist F, Benkerrou M, Cavazzana-Calvo M, Gomez L, Griscelli C, Blanche S, Fischer A. Bone marrow transplantation in 26 patients with Wiskott-Aldrich syndrome from a single center. J Pediatr. 1996;129(2):238-44. [pmid: 8765621]. Rec#: 20380 Reprint: exc nrs
Padeh S, Sharon N, Schiby G, Rechavi G, Passwell JH. Hodgkin's lymphoma in systemic onset juvenile rheumatoid arthritis after treatment with low dose methotrexate. J Rheumatol. 1997;24(10):2035-7. [pmid: 9330950]. Rec#: 18970 Reprint: exc nro
Padula GD, McCormick B, Abramson DH. Brain necrosis after enucleation, external beam cobalt radiotherapy, and systemic chemotherapy for retinoblastoma. Arch Ophthalmol. 2002;120(1):98-9. [pmid: 11786070]. Rec#: 48990 Reprint: exc nrs
Pakakasama S, Eames GM, Morriss MC, Huls MH, Rooney CM, Heslop HE, Krance RA. Treatment of Epstein-Barr virus lymphoproliferative disease after hematopoietic stem-cell transplantation with hydroxyurea and cytotoxic T-cell lymphocytes. Transplantation. 2004;78(5):755-7. [pmid: 15371682]. Rec#: 8310 Reprint: exc nr
Palasis S, Egelhoff JC, Morris JD, Koch BL, Ball WS Jr. Central nervous system relapse of treated stage IV neuroblastoma. Pediatr Radiol. 1998;28(12):990-4. [pmid: 9880649]. Rec#: 17290 Reprint: exc nri
Palla A, Hegemann S, Widmer U, Straumann D. Vestibular and auditory deficits in Fabry disease and their response to enzyme replacement therapy. J Neurol. 2007;254(10):1433-42. [pmid: 17934877]. Rec#: 56900 Reprint: exc nrc
Panchagnula R, Britto C, Vinod J, Anuradha S, Damodar P. Wolman's disease--a case report. Indian J Pathol Microbiol. 2000;43(1):91-2. [pmid: 12583429]. Rec#: 10960 Reprint: exc nrs
Panigrahi S, Das M, Stagler D, Konstantini S, Gmori M, Slavin S, Nagler A. Development of secondary anaplastic oligoastrocytoma after matched unrelated bone marrow transplantation in a child with acute myeloid leukemia. Acta Haematol. 2003;109(4):196-8. [pmid: 12853693]. Rec#: 10200 Reprint: EXC NRS
Papadakis V, Dunkel IJ, Cramer LD, Kramer E, Papadopoulos E, Goldman S, Packer RJ, Willoughby M, Baker D, Garvin J, Strandjord S, Coccia P, Kaplan AM, Klemperer M, Finlay JL. High-dose carmustine, thiotepa and etoposide followed by autologous bone marrow rescue for the treatment of high risk central nervous system tumors. Bone Marrow Transplant. 2000;26(2):153-60. [pmid: 10918425]. Rec#: 70720 Reprint: EXC NRP
Pape H, Laws HJ, Burdach S, van Kaik B, Glag M, Gripp S, Wittkamp M, Jurgens H, Gobel U, Schmitt G. Radiotherapy and high-dose chemotherapy in advanced Ewing's tumors. Strahlenther Onkol. 1999;175(10):484-7. [pmid: 10554642]. Rec#: 16090 Reprint: exc nrp
Papsin BC, Vellodi A, Bailey CM, Ratcliffe PC, Leighton SE. Otologic and laryngologic manifestations of mucopolysaccharidoses after bone marrow transplantation. Otolaryngol Head Neck Surg. 1998;118(1):30-6. [pmid: 9450825]. Rec#: 18750 Reprint: exc nro
Paredes A. Can mycophenolate mofetil substitute cyclophosphamide treatment of pediatric lupus nephritis?. Pediatr Nephrol. 2007;22(8):1077-82. [pmid: 17370094]. Rec#: 41330 Reprint: exc nrs
Parini R, Rigoldi M, Santus F, Furlan F, De Lorenzo P, Valsecchi G, Concolino D, Strisciuglio P, Feriozzi S, Di Vito R, Ravaglia R, Ricci R, Morrone A. Enzyme replacement therapy with agalsidase alfa in a cohort of Italian patients with Anderson-Fabry disease: testing the effects with the Mainz Severity Score Index. Clin Genet. 2008;74(3):260-6. [pmid: 18445046]. Rec#: 56830 Reprint: exc nrd
Park JR, Slattery J, Gooley T, Hawkins D, Lindsley K, Villablanca JG, Matthay KK, Sanders JE. Phase I topotecan preparative regimen for high-risk neuroblastoma, high-grade glioma, and refractory/recurrent pediatric solid tumors. Med Pediatr Oncol. 2000;35(6):719-23. [pmid: 11107155]. Rec#: 14430 Reprint: exc nro
Park JR, Villablanca JG, London WB, Gerbing RB, Haas-Kogan D, Adkins ES, Attiyeh EF, Maris JM, Seeger RC, Reynolds CP, Matthay KK. Outcome of high-risk stage 3 neuroblastoma with myeloablative therapy and 13-cis-retinoic acid: a report from the Children's Oncology Group. Pediatr Blood Cancer. 2009;52(1):44-50. [pmid: 18937318]. Rec#: 1080 Reprint: exc nri
Parker RI, Barton NW, Read EJ, Brady RO. Hematologic improvement in a patient with Gaucher disease on long-term enzyme replacement therapy: evidence for decreased splenic sequestration and improved red blood cell survival. Am J Hematol. 1991;38(2):130-7. [pmid: 1951303]. Rec#: 25740 Reprint: EXC YEAR
Parodi E, Rivetti E, Amendola G, Bisogno G, Calabrese R, Farruggia P, Giordano P, Matarese SM, Nardi M, Nobili B, Notarangelo LD, Russo G, Vimercati C, Zecca M, De Mattia D, Ramenghi U. Long-term follow-up analysis after rituximab therapy in children with refractory symptomatic ITP: identification of factors predictive of a sustained response. Br J Haematol. 2009;144(4):552-8. [pmid: 19036077]. Rec#: 77500 Reprint: exc nrc
Parsons SK, Neault MW, Lehmann LE, Brennan LL, Eickhoff CE, Kretschmar CS, Diller LR. Severe ototoxicity following carboplatin-containing conditioning regimen for autologous marrow transplantation for neuroblastoma. Bone Marrow Transplant. 1998;22(7):669-74. [pmid: 9818694]. Rec#: 17450 Reprint: exc nri
Passweg JR, Rabusin M, Musso M, Beguin Y, Cesaro S, Ehninger G, Espigado I, Iriondo A, Jost L, Koza V, Lenhoff S, Lisukov I, Locatelli F, Marmont A, Philippe P, Pilatrino C, Quartier P, Stary J, Veys P, Vormoor J, Wahlin A, Zintl F, Bocelli-Tyndall C, Tyndall A, Gratwohl A. Haematopoetic stem cell transplantation for refractory autoimmune cytopenia. Br J Haematol. 2004;125(6):749-55. [pmid: 15180864]. Rec#: 8750 Reprint: exc nrp
Paulussen M, Ahrens S, Burdach S, Craft A, Dockhorn-Dworniczak B, Dunst J, Frohlich B, Winkelmann W, Zoubek A, Jurgens H. Primary metastatic (stage IV) Ewing tumor: survival analysis of 171 patients from the EICESS studies. European Intergroup Cooperative Ewing Sarcoma Studies. Ann Oncol. 1998;9(3):275-81. [pmid: 9602261]. Rec#: 18170 Reprint: exc nrp
Paulussen M, Craft AW, Lewis I, Hackshaw A, Douglas C, Dunst J, Schuck A, Winkelmann W, Kohler G, Poremba C, Zoubek A, Ladenstein R, van den Berg H, Hunold A, Cassoni A, Spooner D, Grimer R, Whelan J, McTiernan A, Jurgens H. Results of the EICESS-92 Study: two randomized trials of Ewing's sarcoma treatment--cyclophosphamide compared with ifosfamide in standard-risk patients and assessment of benefit of etoposide added to standard treatment in high-risk patients. J Clin Oncol. 2008;26(27):4385-93. [pmid: 18802150]. Rec#: 42900 Reprint: exc nrp
Pearson AD, Pinkerton CR, Lewis IJ, Imeson J, Ellershaw C, Machin D. High-dose rapid and standard induction chemotherapy for patients aged over 1 year with stage 4 neuroblastoma: a randomised trial. Lancet Oncol. 2008;9(3):247-56. [pmid: 18308250]. Rec#: 2310 Reprint: exc nri
Pechet TV, de le Morena M, Mendeloff EN, Sweet SC, Shapiro SD, Huddleston CB. Lung transplantation in children following treatment for malignancy. J Heart Lung Transplant. 2003;22(2):154-60. [pmid: 12581763]. Rec#: 10970 Reprint: EXC NRO
Perentesis J, Katsanis E, DeFor T, Neglia J, Ramsay N. Autologous stem cell transplantation for high-risk pediatric solid tumors. Bone Marrow Transplant. 1999;24(6):609-15. [pmid: 10490725]. Rec#: 16370 Reprint: exc nro
Perez-Martinez A, Leung W, Munoz E, Iyengar R, Ramirez M, Vicario JL, Lassaletta A, Sevilla J, Gonzalez-Vicent M, Madero L, Diaz-Perez MA. KIR-HLA receptor-ligand mismatch associated with a graft-versus-tumor effect in haploidentical stem cell transplantation for pediatric metastatic solid tumors. Pediatr Blood Cancer. 2009;53(1):120-4. [pmid: 19215002]. Rec#: 500 Reprint: EXC NRI
Perez-Martinez A, Quintero V, Vicent MG, Sevilla J, Diaz MA, Madero L. High-dose chemotherapy with autologous stem cell rescue as first line of treatment in young children with medulloblastoma and supratentorial primitive neuroectodermal tumors. J Neurooncol. 2004;67(1-2):101-6. [pmid: 15072454]. Rec#: 9080 Reprint: EXC; duplicate patients with Perez-Martinez (2005)- #7650
Perrotta S, Conte ML, La Manna A, Indolfi P, Rossi F, Locatelli F, Nobili B. Membranous glomerulopathy in children given allogeneic hematopoietic stem cell transplantation. Haematologica. 2005;90(Suppl):ECR31. [pmid: 16266922]. Rec#: 6520 Reprint: exc nrs
Pession A, Prete A, Locatelli F, Pierinelli S, Pession AL, Maccario R, Magrini E, De Bernardi B, Paolucci P, Paolucci G. Immunotherapy with low-dose recombinant interleukin 2 after high-dose chemotherapy and autologous stem cell transplantation in neuroblastoma. Br J Cancer. 1998;78(4):528-33. [pmid: 9716039]. Rec#: 17790 Reprint: exc nri
Peters C, Krivit W. Hematopoietic cell transplantation for mucopolysaccharidosis IIB (Hunter syndrome). Bone Marrow Transplant. 2000;25(10):1097-9. [pmid: 10828872]. Rec#: 15290 Reprint: exc com
Peters C, Shapiro EG, Anderson J, Henslee-Downey PJ, Klemperer MR, Cowan MJ, Saunders EF, deAlarcon PA, Twist C, Nachman JB, Hale GA, Harris RE, Rozans MK, Kurtzberg J, Grayson GH, Williams TE, Lenarsky C, Wagner JE, Krivit W. Hurler syndrome: II of HLA-genotypically identical sibling and HLA-haploidentical related donor bone marrow transplantation in fifty-four children. The Outcome Storage Disease Collaborative Study Group. Blood. 1998;91(7):2601-8. [pmid: 9516162]. Rec#: 18400 Reprint: exc nr
Peters C, Shapiro EG, Krivit W. Neuropsychological development in children with Hurler syndrome following hematopoietic stem cell transplantation. Pediatr Transplant. 1998;2(4):250-3. [pmid: 10084724]. Rec#: 17090 Reprint: exc nr
Petri M, Brodsky RA, Jones RJ, Gladstone D, Fillius M, Magder LS. High-dose cyclophosphamide versus monthly intravenous cyclophosphamide for systemic lupus erythematosus: a prospective randomized trial. Arthritis Rheum. 2010;62(5):1487-93. [pmid: 20131296]. Rec#: 40830 Reprint: exc nrp
Peyrl A, Azizi A, Czech T, Gruber-Olipitz M, Jones N, Haberler C, Prayer D, Autzinger E, Slavc I. Tumor stabilization under treatment with imatinib in progressive hypothalamic-chiasmatic glioma. Pediatr Blood Cancer. 2009;52(4):476-80. [pmid: 19061223]. Rec#: 54470 Reprint: exc nrd
Philip T, Ladenstein R, Lasset C, Hartmann O, Zucker JM, Pinkerton R, Pearson AD, Klingebiel T, Garaventa A, Kremens B, Bernard JL, Rosti G, Chauvin F. 1070 myeloablative megatherapy procedures followed by stem cell rescue for neuroblastoma: 17 years of European experience and conclusions. European Group for Blood and Marrow Transplant Registry Solid Tumour Working Party. Eur J Cancer. 1997;33(12):2130-5. [pmid: 9516868]. Rec#: 18470 Reprint: exc nri
Philip T, Ladenstein R, Zucker JM, Pinkerton R, Bouffet E, Louis D, Siegert W, Bernard JL, Frappaz D, Coze C, et al. Double megatherapy and autologous bone marrow transplantation for advanced neuroblastoma: the LMCE2 study. Br J Cancer. 1993;67(1):119-27. [pmid: 8427772]. Rec#: 24440 Reprint: EXC YEAR
Philip T, Zucker JM, Bernard JL, Lutz P, Bordigoni P, Plouvier E, Robert A, Roche H, Souillet G, Bouffet E, et al. Improved survival at 2 and 5 years in the LMCE1 unselected group of 72 children with stage IV neuroblastoma older than 1 year of age at diagnosis: is cure possible in a small subgroup?. J Clin Oncol. 1991;9(6):1037-44. [pmid: 2033417]. Rec#: 26200 Reprint: EXC YEAR
Philip T, Zucker JM, Bernard JL, Lutz P, Bordigoni P, Plouvier E, Robert A, Roche H, Souillet G, Bouffet E, et al. The LMCE1 unselected group of stage IV neuroblastoma revisited with a median follow up of 59 months after ABMT. Prog Clin Biol Res. 1991;366:517-25. [pmid: 2068168]. Rec#: 26450 Reprint: EXC YEAR
Pica A, Miller R, Villa S, Kadish SP, Anacak Y, Abusaris H, Ozyigit G, Baumert BG, Zaucha R, Haller G, Weber DC. The results of surgery, with or without radiotherapy, for primary spinal myxopapillary ependymoma: a retrospective study from the rare cancer network. Int J Radiat Oncol Biol Phys. 2009;74(4):1114-20. [pmid: 19250760]. Rec#: 73550 Reprint: exc nrp
Pico JL, Ibrahim A, Castagna L, Bourhis JH, Chazard M, Maraninchi D, Droz JP. Escalating high-dose carboplatin and autologous bone marrow transplantation in solid tumors. Oncology. Suppl 2. 1993;50:47-52. [pmid: 8233302]. Rec#: 23700 Reprint: EXC YEAR
Pihusch R, Salat C, Gohring P, Hentrich M, Wegner H, Pihusch M, Hiller E, Kolb HJ, Ostermann H. Factor XIII activity levels in patients with allogeneic haematopoietic stem cell transplantation and acute graft-versus-host disease of the gut. Br J Haematol. 2002;117(2):469-76. [pmid: 11972534]. Rec#: 12330 Reprint: exc nro
Pinkerton CR, Bataillard A, Guillo S, Oberlin O, Fervers B, Philip T. Treatment strategies for metastatic Ewing's sarcoma. Eur J Cancer. 2001;37(11):1338-44. [pmid: 11435062]. Rec#: 13530 Reprint: exc rev
Pinkerton CR, Groot-Loonen J, Barrett A, Meller ST, Tait D, Ashley S, McElwain TJ. Rapid VAC high dose melphalan regimen, a novel chemotherapy approach in childhood soft tissue sarcomas. Br J Cancer. 1991;64(2):381-5. [pmid: 1892770]. Rec#: 26040 Reprint: EXC YEAR
Pizer BL, Weston CL, Robinson KJ, Ellison DW, Ironside J, Saran F, Lashford LS, Tait D, Lucraft H, Walker DA, Bailey CC, Taylor RE. Analysis of patients with supratentorial primitive neuro-ectodermal tumours entered into the SIOP/UKCCSG PNET 3 study. Eur J Cancer. 2006;42(8):1120-8. [pmid: 16632346]. Rec#: 52500 Reprint: EXC NRI NPC
Plews DE, Turner ML, Wallace WH. Plasma exchange as successful treatment of thrombotic thrombocytopenic purpura post autologous bone marrow transplant in a child. Bone Marrow Transplant. 2000;25(6):679-80. [pmid: 10734305]. Rec#: 15460 Reprint: exc nri
Pole JG, Casper J, Elfenbein G, Gee A, Gross S, Janssen W, Koch P, Marcus R, Pick T, Shuster J, et al. High-dose chemoradiotherapy supported by marrow infusions for advanced neuroblastoma: a Pediatric Oncology Group study. J Clin Oncol. 1991;9(1):152-8. [pmid: 1985165]. Rec#: 26530 Reprint: EXC YEAR
Postovsky S, Ash S, Ramu IN, Yaniv Y, Zaizov R, Futerman B, Elhasid R, Ben Barak A, Halil A, Ben Arush MW. Central nervous system involvement in children with sarcoma. Oncology. 2003;65(2):118-24. [pmid: 12931017]. Rec#: 10000 Reprint: EXC NRI
Poustchi-Amin M, Leonidas JC, Elkowitz SS. Simultaneous occurrence of osteosarcoma and osteochondroma following treatment of neuroblastoma with chemotherapy, radiotherapy, and bone marrow transplantation. Pediatr Radiol. 1996;26(2):155-7. [pmid: 8587819]. Rec#: 21270 Reprint: exc nri
Pozzilli P, Pitocco D, Visalli N, Cavallo MG, Buzzetti R, Crino A, Spera S, Suraci C, Multari G, Cervoni M, Manca Bitti ML, Matteoli MC, Marietti G, Ferrazzoli F, Cassone Faldetta MR, Giordano C, Sbriglia M, Sarug. No effect of oral insulin on residual beta-cell function in recent-onset type I diabetes (the IMDIAB VII). IMDIAB Group. Diabetologia. 2000;43(8):1000-4. [pmid: 10990077]. Rec#: 62460 Reprint: exc nrs
Pozzilli P, Visalli N, Cavallo MG, Signore A, Baroni MG, Buzzetti R, Fioriti E, Mesturino C, Fiori R, Romiti A, Giovannini C, Lucentini L, Matteoli MC, Crino A, Teodonio C, Paci F, Amoretti R, Pisano L, Suraci C. Vitamin E and nicotinamide have similar effects in maintaining residual beta cell function in recent onset insulin-dependent diabetes (the IMDIAB IV study). Eur J Endocrinol. 1997;137(3):234-9. [pmid: 9330586]. Rec#: 62710 Reprint: exc nrd
Pradeep KE, Supriya NK. Niemann-Pick disease-type C: a case report. Indian J Pathol Microbiol. 2001;44(3):339-40. [pmid: 12024927]. Rec#: 12140 Reprint: exc nri
Pradhan DG, Sandridge AL, Mullaney P, Abboud E, Karcioglu ZA, Kandil A, Mustafa MM, Gray AJ. Radiation therapy for retinoblastoma: a retrospective review of 120 patients. Int J Radiat Oncol Biol Phys. 1997;39(1):3-13. [pmid: 9300734]. Rec#: 19050 Reprint: exc nrd
Pradhan KR, Johnson CS, Vik TA, Sender LS, Kreissman SG. A novel intensive induction therapy for high-risk neuroblastoma utilizing sequential peripheral blood stem cell collection and infusion as hematopoietic support. Pediatr Blood Cancer. 2006;46(7):793-802. [pmid: 16206215]. Rec#: 6620 Reprint: exc nri
Prados MD, Warnick RE, Mack EE, Chandler KL, Rabbitt J, Page M, Malec M. Intravenous carboplatin for recurrent gliomas. A dose-escalating phase II trial. Am J Clin Oncol. 1996;19(6):609-12. [pmid: 8931682]. Rec#: 56310 Reprint: exc nrp
Prahalad S, Bove KE, Dickens D, Lovell DJ, Grom AA. Etanercept in the treatment of macrophage activation syndrome. J Rheumatol. 2001;28(9):2120-4. [pmid: 11550985]. Rec#: 13150 Reprint: exc nro
Pratt G, Kinsey SE. Remission of severe, intractable autoimmune haemolytic anaemia following matched unrelated donor transplantation. Bone Marrow Transplant. 2001;28(8):791-3. [pmid: 11781633]. Rec#: 12720 Reprint: exc nrs
Preul MC, Caramanos Z, Villemure JG, Shenouda G, LeBlanc R, Langleben A, Arnold DL. Using proton magnetic resonance spectroscopic imaging to predict in vivo the response of recurrent malignant gliomas to tamoxifen chemotherapy. Neurosurgery. 2000;46(2):306-18. [pmid: 10690719]. Rec#: 15630 Reprint: exc nri
Price V, Barnes C, Canning P, Blanchette V, Greenberg M. Immune thrombocytopenia following successful treatment of cancer in children. Pediatr Blood Cancer. 2006;46(3):372-6. [pmid: 15700256]. Rec#: 7710 Reprint: exc nrd
Prince FH, Geerdink LM, Borsboom GJ, Twilt M, van Rossum MA, Hoppenreijs EP, Cate RT, Koopman-Keemink Y, van Santen-Hoeufft M, Raat H, van Suijlekom-Smit LW. Major improvements in health-related quality of life during the use of etanercept in patients with previously refractory juvenile idiopathic arthritis. Ann Rheum Dis. 2010;69(1):138-42. [pmid: 19581280]. Rec#: 77110 Reprint: exc nrp nro
Prince FH, Twilt M, ten Cate R, van Rossum MA, Armbrust W, Hoppenreijs EP, van Santen-Hoeufft M, Koopman-Keemink Y, Wulffraat NM, van Suijlekom-Smit LW. Long-term follow-up on effectiveness and safety of etanercept in juvenile idiopathic arthritis: the Dutch national register. Ann Rheum Dis. 2009;68(5):635-41. [pmid: 18413443]. Rec#: 77180 Reprint: exc nri
Provan D, Moss AJ, Newland AC, Bussel JB. Efficacy of mycophenolate mofetil as single-agent therapy for refractory immune thrombocytopenic purpura. Am J Hematol. 2006;81(1):19-25. [pmid: 16369979]. Rec#: 77860 Reprint: exc cr
Puchner MJ, Herrmann HD, Berger J, Cristante L. Surgery, tamoxifen, carboplatin, and radiotherapy in the treatment of newly diagnosed glioblastoma patients. J Neurooncol. 2000;49(2):147-55. [pmid: 11206010]. Rec#: 55820 Reprint: exc nrp
Punati J, Markowitz J, Lerer T, Hyams J, Kugathasan S, Griffiths A, Otley A, Rosh J, Pfefferkorn M, Mack D, Evans J, Bousvaros A, Moyer MS, Wyllie R, Oliva-Hemker M, Mezoff A, Leleiko N, Keljo D, Crandall W. Effect of early immunomodulator use in moderate to severe pediatric Crohn disease. Inflamm Bowel Dis. 2008;14(7):949-54. [pmid: 18306311]. Rec#: 41110 Reprint: exc nrc
Punnett A, Bliss B, Dupuis LL, Abdolell M, Doyle J, Sung L. Ototoxicity following pediatric hematopoietic stem cell transplantation: a prospective cohort study. Pediatr Blood Cancer. 2004;42(7):598-603. [pmid: 15127414]. Rec#: 8920 Reprint: exc nri
Quartier P, Taupin P, Bourdeaut F, Lemelle I, Pillet P, Bost M, Sibilia J, Kone-Paut I, Gandon-Laloum S, LeBideau M, Bader-Meunier B, Mouy R, Debre M, Landais P, Prieur AM. Efficacy of etanercept for the treatment of juvenile idiopathic arthritis according to the onset type. Arthritis Rheum. 2003;48(4):1093-101. [pmid: 12687553]. Rec#: 41900 Reprint: exc nro
Rabbone I, Bobbio A, Di Gianni V, Sacchetti C, Cerutti F. Intensive insulin therapy in preschool-aged diabetic children: from multiple daily injections to continuous subcutaneous insulin infusion through indwelling catheters. J Endocrinol Invest. 2008;31(3):193-5. [pmid: 18401199]. Rec#: 61830 Reprint: exc nro
Rabusin M, Andolina M, Maximova N. Haematopoietic SCT in autoimmune diseases in children: rationale and new perspectives. Bone Marrow Transplant. Suppl 2. 2008;41:S96-9. [pmid: 18545255]. Rec#: 1620 Reprint: EXC REV
Raj A, Bertolone S, Cheerva A. Successful treatment of refractory autoimmune hemolytic anemia with monthly rituximab following nonmyeloablative stem cell transplantation for sickle cell disease. J Pediatr Hematol Oncol. 2004;26(5):312-4. [pmid: 15111785]. Rec#: 8980 Reprint: exc nrs
Rajam L, Prasad V, Yatheesha BL. Reactive hemophagocytic syndrome. Indian J Pediatr. 2008;75(12):1261-3. [pmid: 18810357]. Rec#: 1260 Reprint: exc nro
Rakotoambinina B, Timsit J, Deschamps I, Laborde K, Jos J, Boitard C, Assan R, Robert JJ. Cyclosporin A does not delay insulin dependency in asymptomatic IDDM patients. Diabetes Care. 1995;18(11):1487-90. [pmid: 8722075]. Rec#: 40800 Reprint: exc nro
Ramaswami U, Wendt S, Pintos-Morell G, Parini R, Whybra C, Leon Leal JA, Santus F, Beck M. Enzyme replacement therapy with agalsidase alfa in children with Fabry disease. Acta Paediatr. 2007;96(1):122-7. [pmid: 17187618]. Rec#: 57060 Reprint: exc nrc
Ramsay SL, Meikle PJ, Hopwood JJ. Determination of monosaccharides and disaccharides in mucopolysaccharidoses patients by electrospray ionisation mass spectrometry. Mol Genet Metab. 2003;78(3):193-204. [pmid: 12649064]. Rec#: 10760 Reprint: exc dac
Raney RB, Asmar L, Newton WA Jr, Bagwell C, Breneman JC, Crist W, Gehan EA, Webber B, Wharam M, Wiener ES, Anderson JR, Maurer HM. Ewing's sarcoma of soft tissues in childhood: a report from the Intergroup Rhabdomyosarcoma Study, 1972 to 1991. J Clin Oncol. 1997;15(2):574-82. [pmid: 9053479]. Rec#: 19760 Reprint: exc nrp
Rao SP, Miller ST, Cohen BJ. B19 parvovirus infection in children with malignant solid tumors receiving chemotherapy. Med Pediatr Oncol. 1994;22(4):255-7. [pmid: 8107656]. Rec#: 23350 Reprint: EXC YEAR
Rao VK, Dugan F, Dale JK, Davis J, Tretler J, Hurley JK, Fleisher T, Puck J, Straus SE. Use of mycophenolate mofetil for chronic, refractory immune cytopenias in children with autoimmune lymphoproliferative syndrome. Br J Haematol. 2005;129(4):534-8. [pmid: 15877736]. Rec#: 77940 Reprint: exc nrd
Ravelli A, De Benedetti F, Viola S, Martini A. Macrophage activation syndrome in systemic juvenile rheumatoid arthritis successfully treated with cyclosporine. J Pediatr. 1996;128(2):275-8. [pmid: 8636829]. Rec#: 21070 Reprint: exc nro
Ravelli A, Moretti C, Temporini F, Rossi F, Magni-Manzoni S, Pistorio A, Martini A. Combination therapy with methotrexate and cyclosporine A in juvenile idiopathic arthritis. Clin Exp Rheumatol. 2002;20(4):569-72. [pmid: 12175118]. Rec#: 42010 Reprint: exc nro
Razzaq AA, Cohen AR. Neoadjuvant chemotherapy for hypervascular malignant brain tumors of childhood. Pediatr Neurosurg. 1997;27(6):296-303. [pmid: 9655144]. Rec#: 76560 Reprint: EXC NRS
Reardon DA, Dresemann G, Taillibert S, Campone M, van den Bent M, Clement P, Blomquist E, Gordower L, Schultz H, Raizer J, Hau P, Easaw J, Gil M, Tonn J, Gijtenbeek A, Schlegel U, Bergstrom P, Green S, Weir A, Nikolova Z. Multicentre phase II studies evaluating imatinib plus hydroxyurea in patients with progressive glioblastoma. Br J Cancer. 2009;101(12):1995-2004. [pmid: 19904263]. Rec#: 54290 Reprint: exc nro
Reiff A, Rawlings DJ, Shaham B, Franke E, Richardson L, Szer IS, Bernstein BH. Preliminary evidence for cyclosporin A as an alternative in the treatment of recalcitrant juvenile rheumatoid arthritis and juvenile dermatomyositis. J Rheumatol. 1997;24(12):2436-43. [pmid: 9415655]. Rec#: 18720 Reprint: exc nro
Reinhard H, Semler O, Burger D, Bode U, Flentje M, Gobel U, Gutjahr P, Leuschner I, Maass E, Niggli F, Scheel-Walter HG, Stockle M, Thuroff JW, Troger J, Weirich A, von Schweinitz D, Zoubek A, Graf N. Results of the SIOP 93-01/GPOH trial and study for the treatment of patients with unilateral nonmetastatic Wilms Tumor. Klin Padiatr. 2004;216(3):132-40. [pmid: 15175957]. Rec#: 45360 Reprint: exc nrp
Renner S, Krumpelmann S, Bruchelt G, Wiesinger H, Niethammer D, Klingebiel T. Effect of amifostine on neuroblastoma during high dose chemotherapy: in vivo and in vitro investigations. Anticancer Res. 2000;20(6B):4531-8. [pmid: 11205300]. Rec#: 14110 Reprint: exc nri
Reynolds CP. Detection and treatment of minimal residual disease in high-risk neuroblastoma. Pediatr Transplant. Suppl 5. 2004;8:56-66. [pmid: 15125707]. Rec#: 8950 Reprint: EXC NPD
Ricchetti ET, Erol B, Stern J, Russo P, States L, Dormans JP. Lower back pain and mass in a 13-year-old girl. Clin Orthop Relat Res. 2005;(430):248-57. [pmid: 15662332]. Rec#: 43520 Reprint: exc cr
Rick O, Beyer J, Kingreen D, Kuhl JS, Zingsem J, Huhn D, Siegert W, Schwella N. Successful autologous bone marrow rescue in patients who failed peripheral blood stem cell mobilization. Ann Hematol. 2000;79(12):681-6. [pmid: 11195005]. Rec#: 70680 Reprint: EXC NRO
Ries M, Clarke JT, Whybra C, Mehta A, Loveday KS, Brady RO, Beck M, Schiffmann R. Enzyme replacement in Fabry disease: pharmacokinetics and pharmacodynamics of agalsidase alpha in children and adolescents. J Clin Pharmacol. 2007;47(10):1222-30. [pmid: 17698592]. Rec#: 56950 Reprint: exc nrc
Ries M, Clarke JT, Whybra C, Timmons M, Robinson C, Schlaggar BL, Pastores G, Lien YH, Kampmann C, Brady RO, Beck M, Schiffmann R. Enzyme-replacement therapy with agalsidase alfa in children with Fabry disease. Pediatrics. 2006;118(3):924-32. [pmid: 16950982]. Rec#: 57130 Reprint: exc nrc
Ries M, Schiffmann R. Fabry disease: angiokeratoma, biomarker, and the effect of enzyme replacement therapy on kidney function. Arch Dermatol. 2005;141(7):904-5. author reply. 905. 6. [pmid: 16027312]. Rec#: 57380 Reprint: exc nrc
Ringold S, Chon Y, Singer NG. Associations between the American College of Rheumatology pediatric response measures and the continuous measures of disease activity used in adult rheumatoid arthritis: a secondary analysis of clinical trial data from children with polyarticular-course j. Arthritis Rheum. 2009;60(12):3776-83. [pmid: 19950286]. Rec#: 77080 Reprint: exc nrs
Robison LL, Green DM, Hudson M, Meadows AT, Mertens AC, Packer RJ, Sklar CA, Strong LC, Yasui Y, Zeltzer LK. Long-term outcomes of adult survivors of childhood cancer. Cancer. 2005;104(11 Suppl):2557-64. [pmid: 16247780]. Rec#: 45150 Reprint: exc nro
Rodeberg D, Arndt C, Breneman J, Lyden E, Donaldson S, Paidas C, Andrassy R, Meyer W, Wiener E. Characteristics and outcomes of rhabdomyosarcoma patients with isolated lung metastases from IRS-IV. J Pediatr Surg. 2005;40(1):256-62. [pmid: 15868594]. Rec#: 47290 Reprint exc in breneman 2003
Rodriguez V, Kuehnle I, Heslop HE, Khan S, Krance RA. Guillain-Barre syndrome after allogeneic hematopoietic stem cell transplantation. Bone Marrow Transplant. 2002;29(6):515-7. [pmid: 11960272]. Rec#: 12350 Reprint: EXC NRI
Rodriguez-Galindo C, Marina NM, Fletcher BD, Parham DM, Bodner SM, Meyer WH. Is primitive neuroectodermal tumor of the kidney a distinct entity?. Cancer. 1997;79(11):2243-50. [pmid: 9179073]. Rec#: 19330 Reprint: EXC NRI
Rodriguez-Galindo C, Poquette CA, Marina NM, Head DR, Cain A, Meyer WH, Santana VM, Pappo AS. Hematologic abnormalities and acute myeloid leukemia in children and adolescents administered intensified chemotherapy for the Ewing sarcoma family of tumors. J Pediatr Hematol Oncol. 2000;22(4):321-9. [pmid: 10959902]. Rec#: 14910 Reprint: EXC NRI
Roganovic J. Rituximab treatment in refractory idiopathic thrombocytopenic purpura in children. Eur J Pediatr. 2005;164(5):334. [pmid: 15711954]. Rec#: 77980 Reprint: exc cr
Rogers LR, Janakiraman N, Kasten-Sportes C, Rosenblum ML. Therapy-related myelodysplastic syndrome (t-MDS) in a patient with anaplastic astrocytoma: successful treatment with allogeneic bone marrow transplant. J Neurooncol. 2001;53(1):55-9. [pmid: 11678432]. Rec#: 12940 Reprint: exc rev nri
Rosenfeld A, Kletzel M, Duerst R, Jacobsohn D, Haut P, Weinstein J, Rademaker A, Schaefer C, Evans L, Fouts M, Goldman S. A phase II prospective study of sequential myeloablative chemotherapy with hematopoietic stem cell rescue for the treatment of selected high risk and recurrent central nervous system tumors. J Neurooncol. 2010;97(2):247-55. [pmid: 19768658]. Rec#: 70080 Reprint: exc few
Rosenkranz ME, Agle LM, Efthimiou P, Lehman TJ. Systemic and localized scleroderma in children: current and future treatment options. Paediatr Drugs. 2006;8(2):85-97. [pmid: 16608370]. Rec#: 5730 Reprint: exc nra
Rosenthal J, Bolotin E, Shakhnovits M, Pawlowska A, Falk P, Qian D, Oliver C, Sato J, Miser J, Forman S. High-dose therapy with hematopoietic stem cell rescue in patients with poor prognosis Ewing family tumors. Bone Marrow Transplant. 2008;42(5):311-8. [pmid: 18587438]. Rec#: 1760 Reprint: exc nrp
Ross LF, Philipson LH. Ethics of hematopoietic stem cell transplantation in type 1 diabetes mellitus. 2007. Rec#: 3490 Reprint: exc nrs
Rossi M, Parenti G, Della Casa R, Romano A, Mansi G, Agovino T, Rosapepe F, Vosa C, Del Giudice E, Andria G. Long-term enzyme replacement therapy for pompe disease with recombinant human alpha-glucosidase derived from chinese hamster ovary cells. J Child Neurol. 2007;22(5):565-73. [pmid: 17690063]. Rec#: 56960 Reprint: exc nrc
Rovelli AM. The controversial and changing role of haematopoietic cell transplantation for lysosomal storage disorders: an update. Bone Marrow Transplant. Suppl 2. 2008;41:S87-9. [pmid: 18545253]. Rec#: 1630 Reprint: exc rev
Roversi FM, Galdieri LC, Grego BH, Souza FG, Micheletti C, Martins AM, D'Almeida V. Blood oxidative stress markers in Gaucher disease patients. Clin Chim Acta. 2006;364(1-2):316-20. [pmid: 16125160]. Rec#: 57370 Reprint: exc nrp
Rubie H, Michon J, Plantaz D, Peyroulet MC, Coze C, Frappaz D, Chastagner P, Baranzelli MC, Mechinaud F, Boutard P, Lutz P, Perel Y, Leverger G, de Lumley L, Millot F, Stephan JL, Margueritte G, Hartmann O. Unresectable localized neuroblastoma: improved survival after primary chemotherapy including carboplatin-etoposide. Neuroblastoma Study Group of the Societe Francaise d'Oncologie Pediatrique (SFOP). Br J Cancer. 1998;77(12):2310-7. [pmid: 9649151]. Rec#: 18030 Reprint: exc nri
Ruperto N, Lovell DJ, Quartier P, Paz E, Rubio-Perez N, Silva CA, Abud-Mendoza C, Burgos-Vargas R, Gerloni V, Melo-Gomes JA, Saad-Magalhaes C, Chavez-Corrales J, Huemer C, Kivitz A, Blanco FJ, Foeldvari I, Hofer M. Long-term safety and efficacy of abatacept in children with juvenile idiopathic arthritis. Arthritis Rheum. 2010;62(6):1792-802. [pmid: 20191582]. Rec#: 77050 Reprint: exc nri
Ruperto N, Lovell DJ, Quartier P, Paz E, Rubio-Perez N, Silva CA, Abud-Mendoza C, Burgos-Vargas R, Gerloni V, Melo-Gomes JA, Saad-Magalhaes C, Sztajnbok F, Goldenstein-Schainberg C, Scheinberg M, Penades IC, Fischbach. Abatacept in children with juvenile idiopathic arthritis: a randomised, double-blind, placebo-controlled withdrawal trial. Lancet. 2008;372(9636):383-91. [pmid: 18632147]. Rec#: 77160 Reprint: exc nri
Ruperto N, Ravelli A, Castell E, Gerloni V, Haefner R, Malattia C, Kanakoudi-Tsakalidou F, Nielsen S, Bohnsack J, Gibbas D, Rennebohm R, Voygioyka O, Balogh Z, Lepore L, Macejkova E, Wulffraat N, Oliveira S, Russo R, Buoncompagni A, Hilario MO, Alpigiani MG, Passo M, Lovell DJ, Merino R, Martini A, Giannini EH. Cyclosporine A in juvenile idiopathic arthritis. Results of the PRCSG/PRINTO phase IV post marketing surveillance study. Clin Exp Rheumatol. 2006;24(5):599-605. [pmid: 17181934]. Rec#: 77200 Reprint: exc nri
Russo RA, Katsicas MM. Clinical remission in patients with systemic juvenile idiopathic arthritis treated with anti-tumor necrosis factor agents. J Rheumatol. 2009;36(5):1078-82. [pmid: 19435972]. Rec#: 77140 Reprint: exc nro nri
Rutkowski S, Bode U, Deinlein F, Ottensmeier H, Warmuth-Metz M, Soerensen N, Graf N, Emser A, Pietsch T, Wolff JE, Kortmann RD, Kuehl J. Treatment of early childhood medulloblastoma by postoperative chemotherapy alone. N Engl J Med. 2005;352(10):978-86. [pmid: 15758008]. Rec#: 52780 Reprint: EXC NRI
Ryu KH, Ahn HS, Koo HH, Kook H, Kim MK, Kim HK, Ghim T, Moon HN, Seo JJ, Sung KW, Shin HY, Yoo ES, Lyu CJ, Lee YH, Lee H, Cho B, Cho HS, Choi HS, Hah JO, Hwang TJ. Autologous stem cell transplantation for the treatment of neuroblastoma in Korea. J Korean Med Sci. 2003;18(2):242-7. [pmid: 12692423]. Rec#: 10660 Reprint: exc nri
Saarinen UM, Hovi L, Makipernaa A, Riikonen P. High-dose thiotepa with autologous bone marrow rescue in pediatric solid tumors. Bone Marrow Transplant. 1991;8(5):369-76. [pmid: 1768972]. Rec#: 25710 Reprint: EXC YEAR
Saarinen UM, Sariola H, Hovi L. Recurrent disseminated retinoblastoma treated by high-dose chemotherapy, total body irradiation, and autologous bone marrow rescue. Am J Pediatr Hematol Oncol. 1991;13(3):315-9. [pmid: 1793158]. Rec#: 26680 Reprint: EXC YEAR
Saarinen UM, Wikstrom S, Makipernaa A, Lanning M, Perkkio M, Hovi L, Rapola J, Sariola H. In vivo purging of bone marrow in children with poor-risk neuroblastoma for marrow collection and autologous bone marrow transplantation. J Clin Oncol. 1996;14(10):2791-802. [pmid: 8874341]. Rec#: 20250 Reprint: exc nri
Saavedra J, Garrido C, Folgueira D, Torres MJ, Ramos JT. Ochrobactrum anthropi bacteremia associated with a catheter in an immunocompromised child and review of the pediatric literature. Pediatr Infect Dis J. 1999;18(7):658-60. [pmid: 10440451]. Rec#: 16520 Reprint: exc nri
Saccardi R, Kozak T, Bocelli-Tyndall C, Fassas A, Kazis A, Havrdova E, Carreras E, Saiz A, Lowenberg B, te Boekhorst PA, Gualandio F, Openshaw H, Longo G, Pagliai F, Massacesi L, Deconink E, Ouyang J, Nagore FJ, Besalduch J, Lisukov IA, Bonini A, Merelli E, Slavino S, Gratwohl A, Passweg J, Tyndall A, Steck AJ, Andolina M, Capobianco M, Martin JL, Lugaresi A, Meucci G, Saez RA, Clark RE, Fernandez MN, Fouillard L, Herstenstein B, Koza V, Cocco E, Baurmann H, Mancardi GL. Autologous stem cell transplantation for progressive multiple sclerosis: update of the European Group for Blood and Marrow Transplantation autoimmune diseases working party database. Mult Scler. 2006;12(6):814-23. [pmid: 17263012]. Rec#: 4370 Reprint: exc nrp
Saeter G. Ewing's sarcoma of bone: ESMO clinical recommendations for diagnosis, treatment and follow-up. Ann Oncol. Suppl 2. 2007;18:ii79-80. [pmid: 17491059]. Rec#: 43140 Reprint: exc gui
Sakata N, Kawa K, Kato K, Yabe H, Yabe M, Nagasawa M, Mugishima H, Kigasawa H, Tsuchida M, Akiyama Y, Morisima Y, Kodera Y, Kato S. Unrelated donor marrow transplantation for congenital immunodeficiency and metabolic disease: an update of the experience of the Japan Marrow Donor Program. Int J Hematol. 2004;80(2):174-82. [pmid: 15481448]. Rec#: 8160 Reprint: exc nrp
Salawu L, Durosinmi MA. Immune thrombocytopaenic purpura: 11-year experience in Ile-Ife, Nigeria. Afr J Med Med Sci. 2001;30(1-2):99-103. [pmid: 14510161]. Rec#: 9890 Reprint: exc nro
Sampath S, Nitin G, Yasha TC, Chandramouli BA, Devi BI, Kovoor JM. Does choroid plexus tumour differ with age?. Br J Neurosurg. 2008;22(3):373-88. [pmid: 18568726]. Rec#: 75690 Reprint: exc nro
Sandoval C, Pui CH, Bowman LC, Heaton D, Hurwitz CA, Raimondi SC, Behm FG, Head DR. Secondary acute myeloid leukemia in children previously treated with alkylating agents, intercalating topoisomerase II inhibitors, and irradiation. J Clin Oncol. 1993;11(6):1039-45. [pmid: 8388919]. Rec#: 24090 Reprint: EXC YEAR
Sands SA, van Gorp WG, Finlay JL. Pilot neuropsychological findings from a treatment regimen consisting of intensive chemotherapy and bone marrow rescue for young children with newly diagnosed malignant brain tumors. Childs Nerv Syst. 1998;14(10):587-9. [pmid: 9840384]. Rec#: 17410 Reprint: EXC NRO
Sangthawan D, DesRosiers PM, Randall ME, Robertson K, Goebel S, Fallon R. Relapse in the skull after myeloablative therapy for high-risk neuroblastoma. Pediatr Hematol Oncol. 2003;20(1):23-30. [pmid: 12687750]. Rec#: 10680 Reprint: exc nri
Sansone R, Di Martino D, Lanino E, Dini G, Massimo L, Tonini GP. MYCN amplification does not affect survival of neuroblastoma patients treated with autologous bone marrow transplantation. Bone Marrow Transplant. Suppl 3. 1991;7:133-5. [pmid: 1855077]. Rec#: 26620 Reprint: EXC YEAR
Santana VM, Schell MJ, Williams R, Bowman LC, Thompson EI, Brenner MK, Mirro J Jr. Escalating sequential high-dose carboplatin and etoposide with autologous marrow support in children with relapsed solid tumors. Bone Marrow Transplant. 1992;10(5):457-62. [pmid: 1464010]. Rec#: 24690 Reprint: EXC YEAR
Sanz N, de Mingo L, Florez F, Rollan V. Rhabdomyosarcoma of the biliary tree. Pediatr Surg Int. 1997;12(2-3):200-1. Rec#: 19700 Reprint: exc nro
Sardi I, Cetica V, Massimino M, Buccoliero AM, Giunti L, Genitori L, Arico M. Promoter methylation and expression analysis of MGMT in advanced pediatric brain tumors. Oncol Rep. 2009;22(4):773-9. [pmid: 19724855]. Rec#: 73470 Reprint: exc nrs
Satman I, Ficicioglu C, Karsidag K, Yilmaz T, Dincdag N, Koca F, Odabasi F, Aydin A, Devrim S, Haktan M. Effects of methylprednisolone pulse therapy on insulin injections in patients with insulin-dependent diabetes mellitus. Turk J Pediatr. 1996;38(4):419-29. [pmid: 8993171]. Rec#: 40720 Reprint: EXC NRC
Savolainen HA, Kautiainen H, Isomaki H, Aho K, Verronen P. Azathioprine in patients with juvenile chronic arthritis: a longterm followup study. J Rheumatol. 1997;24(12):2444-50. [pmid: 9415656]. Rec#: 42400 Reprint: exc nrp
Sawamura Y, Ikeda J, Ishii N, Kato T, Tada M, Abe H, Shirato H. Combined irradiation and chemotherapy using ifosfamide, cisplatin, and etoposide for children with medulloblastoma/posterior fossa primitive neuroectodermal tumor--results of a pilot study. Neurol Med Chir (Tokyo). 1996;36(9):632-8. [pmid: 8913079]. Rec#: 20270 Reprint: EXC NRI
Sawhney S, Woo P, Murray KJ. Macrophage activation syndrome: a potentially fatal complication of rheumatic disorders. Arch Dis Child. 2001;85(5):421-6. [pmid: 11668110]. Rec#: 12990 Reprint: exc nre nri
Schachna L, Ryan PF, Schwarer AP. Malignancy-associated remission of systemic lupus erythematosus maintained by autologous peripheral blood stem cell transplantation. Arthritis Rheum. 1998;41(12):2271-2. [pmid: 9870885]. Rec#: 17320 Reprint: exc nrs
Scheurlen W, Ramasubbu K, Wachowski O, Hemauer A, Modrow S. Chronic autoimmune thrombopenia/neutropenia in a boy with persistent parvovirus B19 infection. J Clin Virol. 2001;20(3):173-8. [pmid: 11166667]. Rec#: 14220 Reprint: exc nro
Schiavetti A, Varrasso G, Maurizi P, Cappelli C, Clerico A, Properzi E, Castello MA. Ten-day schedule oral etoposide therapy in advanced childhood malignancies. J Pediatr Hematol Oncol. 2000;22(2):119-24. [pmid: 10779024]. Rec#: 74400 Reprint: exc nrs
Schiff M, Maire I, Bertrand Y, Cochat P, Guffon N. Long-term follow-up of metachronous marrow-kidney transplantation in severe type II sialidosis: what does success mean?. Nephrol Dial Transplant. 2005;20(11):2563-5. [pmid: 16091374]. Rec#: 6870 Reprint: exc nrd
Schiffmann R, Martin RA, Reimschisel T, Johnson K, Castaneda V, Lien YH, Pastores GM, Kampmann C, Ries M, Clarke JT. Four-year prospective clinical trial of agalsidase alfa in children with Fabry disease. J Pediatr. 2010;156(5):832-7. 837.e1. [pmid: 20097359]. Rec#: 56440 Reprint: exc nrc
Schmidt M, Simon T, Hero B, Eschner W, Dietlein M, Sudbrock F, Bongartz R, Berthold F, Schicha H. Is there a benefit of 131 I-MIBG therapy in the treatment of children with stage 4 neuroblastoma? A retrospective evaluation of The German Neuroblastoma Trial NB97 and implications for The German Neuroblastoma Trial NB2004. Nuklearmedizin. 2006;45(4):145-51. [pmid: 16964339]. quiz N39-40 Rec#: 5050 Reprint: exc nri
Schmidt ML, Joshi S, DeChristopher PJ, Mihalov M, Sosler SD. Successful management of concurrent congenital dyserythropoietic anaemia and autoimmune haemolytic anaemia with splenectomy. Br J Haematol. 1998;102(5):1182-6. [pmid: 9753043]. Rec#: 17620 Reprint: exc nrd
Schmidt ML, Lal A, Seeger RC, Maris JM, Shimada H, O'Leary M, Gerbing RB, Matthay KK. Favorable prognosis for patients 12 to 18 months of age with stage 4 nonamplified MYCN neuroblastoma: a Children's Cancer Group Study. J Clin Oncol. 2005;23(27):6474-80. [pmid: 16116154]. Rec#: 6820 Reprint: exc nri
Schmidt ML, Lukens JN, Seeger RC, Brodeur GM, Shimada H, Gerbing RB, Stram DO, Perez C, Haase GM, Matthay KK. Biologic factors determine prognosis in infants with stage IV neuroblastoma: A prospective Children's Cancer Group study. J Clin Oncol. 2000;18(6):1260-8. [pmid: 10715296]. Rec#: 15520 Reprint: exc nri
Schneider JA. Treatment of cystinosis: simple in principle, difficult in practice. J Pediatr. 2004;145(4):436-8. [pmid: 15480361]. Rec#: 57510 Reprint: exc com
Schroeder H, Wacher J, Larsson H, Rosthoej S, Rechnitzer C, Petersen BL, Carlsen NL. Unchanged incidence and increased survival in children with neuroblastoma in Denmark 1981-2000: a population-based study. Br J Cancer. 2009;100(5):853-7. [pmid: 19223904]. Rec#: 490 Reprint: exc nri
Schuening F, Longo WL, Atkinson ME, Zaboikin M, Kiem HP, Sanders J, Scott CR, Storb R, Miller AD, Reynolds T, Bensinger W, Rowley S, Gooley T, Darovsky B, Appelbaum F. Retrovirus-mediated transfer of the cDNA for human glucocerebrosidase into peripheral blood repopulating cells of patients with Gaucher's disease. Hum Gene Ther. 1997;8(17):2143-60. [pmid: 9414262]. Rec#: 18820 Reprint: exc nr
Schultze-Mosgau S, Thorwarth M, Wehrhan F, Holter W, Stachel KD, Grabenbauer G, Amann K, Beck JD. Ewing sarcoma of the mandible in a child: interdisciplinary treatment concepts and surgical reconstruction. J Craniofac Surg. 2005;16(6):1140-6. [pmid: 16327573]. Rec#: 6420 Reprint: EXC DUP
Schuster A, Apfelstedt-Sylla E, Pusch CM, Zrenner E, Thirkill CE. Autoimmune retinopathy with RPE hypersensitivity and ‘negative ERG’ in X-linked hyper-IgM syndrome. Ocul Immunol Inflamm. 2005;13(2-3):235-43. [pmid: 16019685]. Rec#: 6990 Reprint: exc nro
sDe Sio L, Milano GM, Castellano A, Jenkner A, Fidani P, Dominici C, Donfrancesco A. Temozolomide in resistant or relapsed pediatric solid tumors. Pediatr Blood Cancer. 2006;47(1):30-6. [pmid: 16047361]. Rec#: 43430 Reprint: EXC NRI
Seeger RC, Reynolds CP, Gallego R, Stram DO, Gerbing RB, Matthay KK. Quantitative tumor cell content of bone marrow and blood as a predictor of outcome in stage IV neuroblastoma: a Children's Cancer Group Study. J Clin Oncol. 2000;18(24):4067-76. [pmid: 11118468]. Rec#: 14400 Reprint: exc nri
Seeger RC, Villablanca JG, Matthay KK, Harris R, Moss TJ, Feig SA, Selch M, Ramsay N, Reynolds CP. Intensive chemoradiotherapy and autologous bone marrow transplantation for poor prognosis neuroblastoma. Prog Clin Biol Res. 1991;366:527-33. [pmid: 2068169]. Rec#: 26440 Reprint: EXC YEAR
Seeliger S, Baumann M, Mohr M, Jurgens H, Frosch M, Vormoor J. Autologous peripheral blood stem cell transplantation and anti-B-cell directed immunotherapy for refractory auto-immune haemolytic anaemia. Eur J Pediatr. 2001;160(8):492-6. [pmid: 11548187]. Rec#: 13170 Reprint: exc nri
Sfikakis PP. The first decade of biologic TNF antagonists in clinical practice: lessons learned, unresolved issues and future directions. Curr Dir Autoimmun. 2010;11:180-210. [pmid: 20173395]. Rec#: 77060 Reprint: exc nra
Shankar AG, Ashley S, Craft AW, Pinkerton CR. Outcome after relapse in an unselected cohort of children and adolescents with Ewing sarcoma. Med Pediatr Oncol. 2003;40(3):141-7. [pmid: 12518341]. Rec#: 11130 Reprint: exc nrp
Shao KD, Zhou YH, Shen YP, Ye BD, Gao RL, Zhang Y. Treatment of 37 patients with refractory idiopathic thrombocytopenic purpura by shengxueling. Chin J Integr Med. 2007;13(1):33-6. [pmid: 17578315]. Rec#: 3690 Reprint: exc nri
Shapiro B, Sisson JC, Shulkin BL, Gross MD, Zempel S. The current status of radioiodinated metaiodobenzylguanidine therapy of neuro-endocrine tumors. Q J Nucl Med. 1995;39(4 Suppl 1):55-7. [pmid: 9002750]. Rec#: 21300 Reprint: EXC NRS
Shen V, Woodbury C, Killen R, Van de Ven C, Sender L, Cairo MS. Collection and use of peripheral blood stem cells in young children with refractory solid tumors. Bone Marrow Transplant. 1997;19(3):197-204. [pmid: 9028545]. Rec#: 19810 Reprint: EXC NRO
Shen WP, Felsing N, Lang D, Goodman G, Cairo MS. Development of infant botulism in a 3-year-old female with neuroblastoma following autologous bone marrow transplantation: potential use of human botulism immune globulin. Bone Marrow Transplant. 1994;13(3):345-7. [pmid: 8199579]. Rec#: 23120 Reprint: EXC YEAR
Shevchenko YL, Novik AA, Kuznetsov AN, Afanasiev BV, Lisukov IA, Kozlov VA, Rykavicin OA, Ionova TI, Melnichenko VY, Fedorenko DA, Kulagin AD, Shamanski SV, Ivanov RA, Gorodokin G. High-dose immunosuppressive therapy with autologous hematopoietic stem cell transplantation as a treatment option in multiple sclerosis. Exp Hematol. 2008;36(8):922-8. [pmid: 18468768]. Rec#: 2010 Reprint: exc nrp
Shields CL, De Potter P, Himelstein BP, Shields JA, Meadows AT, Maris JM. Chemoreduction in the initial management of intraocular retinoblastoma. Arch Ophthalmol. 1996;114(11):1330-8. [pmid: 8906023]. Rec#: 20140 Reprint: exc nrd
Shuster JJ, Cantor AB, McWilliams N, Pole JG, Castleberry RP, Marcus R, Pick T, Smith EI, Hayes FA. The prognostic significance of autologous bone marrow transplant in advanced neuroblastoma. J Clin Oncol. 1991;9(6):1045-9. [pmid: 2033418]. Rec#: 26190 Reprint: EXC YEAR
Sibley GS, Mundt AJ, Goldman S, Nachman J, Reft C, Weichselbaum RR, Hallahan DE, Johnson L. Patterns of failure following total body irradiation and bone marrow transplantation with or without a radiotherapy boost for advanced neuroblastoma. Int J Radiat Oncol Biol Phys. 1995;32(4):1127-35. [pmid: 7607934]. Rec#: 71740 Reprint: EXC NRS
Silvani A, Gaviani P, Fiumani A, Scaioli V, Lamperti E, Eoli M, Botturi A, Salmaggi A. Systemic sagopilone (ZK-EPO) treatment of patients with recurrent malignant gliomas. J Neurooncol. 2009;95(1):61-4. [pmid: 19381446]. Rec#: 54390 Reprint: exc nrp
Simon T, Hero B, Dupuis W, Selle B, Berthold F. The incidence of hearing impairment after successful treatment of neuroblastoma. Klin Padiatr. 2002;214(4):149-52. [pmid: 12165893]. Rec#: 11820 Reprint: exc nri
Simon T, Hero B, Faldum A, Handgretinger R, Schrappe M, Niethammer D, Berthold F. Consolidation treatment with chimeric anti-GD2-antibody ch14.18 in children older than 1 year with metastatic neuroblastoma. J Clin Oncol. 2004;22(17):3549-57. [pmid: 15337804]. Rec#: 8420 Reprint: exc nri
Simpson JL, Alford MA, Carter KD, Keech RV. Metastatic rhabdomyosarcoma presenting as an isolated lateral rectus restriction. J Pediatr Ophthalmol Strabismus. 1999;36(2):90-1. [pmid: 10204136]. Rec#: 48090 Reprint: exc nro
Sims SA, Barker GJ, Gilman A. Oral complications associated with the treatment of pediatric neuroblastoma: a case study. J Clin Pediatr Dent. 2002;26(4):401-4. [pmid: 12175136]. Rec#: 11780 Reprint: exc nri
Singhal S, Birch JM, Kerr B, Lashford L, Evans DG. Neurofibromatosis type 1 and sporadic optic gliomas. Arch Dis Child. 2002;87(1):65-70. [pmid: 12089128]. Rec#: 55640 Reprint: exc nri
Sleight BJ, Prasad VS, DeLaat C, Steele P, Ballard E, Arceci RJ, Sidman CL. Correction of autoimmune lymphoproliferative syndrome by bone marrow transplantation. Bone Marrow Transplant. 1998;22(4):375-80. [pmid: 9722073]. Rec#: 17770 Reprint: exc nrs
Sluga M, Windhager R, Lang S, Heinzl H, Krepler P, Mittermayer F, Dominkus M, Zoubek A, Kotz R. A long-term review of the treatment of patients with Ewing's sarcoma in one institution. Eur J Surg Oncol. 2001;27(6):569-73. [pmid: 11520091]. Rec#: 43850 Reprint: exc nrp
Smart CE, Ross K, Edge JA, Collins CE, Colyvas K, King BR. Children and adolescents on intensive insulin therapy maintain postprandial glycaemic control without precise carbohydrate counting. Diabet Med. 2009;26(3):279-85. [pmid: 19317823]. Rec#: 61710 Reprint: exc nro
Smedler AC, Bolme P. Neuropsychological deficits in very young bone marrow transplant recipients. Acta Paediatr. 1995;84(4):429-33. [pmid: 7540899]. Rec#: 22010 Reprint: EXC NRS
Smith MA, Smith JG. Clinical experience with the use of rhG-CSF in secondary autoimmune neutropenia. Clin Lab Haematol. 2002;24(2):93-7. [pmid: 11985554]. Rec#: 12290 Reprint: exc nro
Snowden JA, Hill GR, Hunt P, Carnoutsos S, Spearing RL, Espiner E, Hart DN. Assessment of cardiotoxicity during haemopoietic stem cell transplantation with plasma brain natriuretic peptide. Bone Marrow Transplant. 2000;26(3):309-13. [pmid: 10967571]. Rec#: 14890 Reprint: exc nro
Snyder MJ, Bradford WD, Kishnani PS, Hale LP. Idiopathic hyperammonemia following an unrelated cord blood transplant for mucopolysaccharidosis I. Pediatr Dev Pathol. 2003;6(1):78-83. [pmid: 12481230]. Rec#: 11230 Reprint: exc nr
Spreafico F, Gandola L, Marchiano A, Simonetti F, Poggi G, Adduci A, Clerici CA, Luksch R, Biassoni V, Meazza C, Catania S, Terenziani M, Musumeci R, Fossati-Bellani F, Massimino M. Brain magnetic resonance imaging after high-dose chemotherapy and radiotherapy for childhood brain tumors. Int J Radiat Oncol Biol Phys. 2008;70(4):1011-9. [pmid: 17904307]. Rec#: 3130 Reprint: exc few
Spreafico F, Pritchard-Jones K, Bergeron C, de Kraker J, Dallorso S, Graf N. Value and difficulties of a common European strategy for recurrent Wilms' tumor. Expert Rev Anticancer Ther. 2009;9(6):693-6. [pmid: 19496704]. Rec#: 44650 Reprint: exc edt
Stalder MP, Rovo A, Halter J, Heim D, Silzle T, Passweg J, Rischewski J, Stern M, Arber C, Buser A, Meyer-Monard S, Tichelli A, Gratwohl A. Aplastic anemia and concomitant autoimmune diseases. Ann Hematol. 2009;88(7):659-65. [pmid: 19139895]. Rec#: 730 Reprint: exc nrs
Stary J, Sedlacek P, Vodvarkova S, Gasova Z, Bartunkova J. Development of common variable immunodeficiency in a patient with Evans syndrome treated by autologous stem cell transplantation. Pediatr Allergy Immunol. 2003;14(4):334-7. [pmid: 12911516]. Rec#: 10050 Reprint: exc nro
Statkute L, Verda L, Oyama Y, Traynor A, Villa M, Shook T, Clifton R, Jovanovic B, Satkus J, Loh Y, Quigley K, Yaung K, Gonda E, Krosnjar N, Spahovic D, Burt RK. Mobilization, harvesting and selection of peripheral blood stem cells in patients with autoimmune diseases undergoing autologous hematopoietic stem cell transplantation. Bone Marrow Transplant. 2007;39(6):317-29. [pmid: 17277794]. Rec#: 4340 Reprint: exc nro
Steinbach WJ, Sandborg CI. Development of systemic lupus erythematosus following autologous bone marrow transplant for acute lymphocytic leukemia. 2001. Rec#: 13600 Reprint:
Stephan JL, Kone-Paut I, Galambrun C, Mouy R, Bader-Meunier B, Prieur AM. Reactive haemophagocytic syndrome in children with inflammatory disorders. A retrospective study of 24 patients. Rheumatology (Oxford). 2001;40(11):1285-92. [pmid: 11709613]. Rec#: 12850 Reprint: exc nri
Stephan JL, Zeller J, Hubert P, Herbelin C, Dayer JM, Prieur AM. Macrophage activation syndrome and rheumatic disease in childhood: a report of four new cases. Clin Exp Rheumatol. 1993;11(4):451-6. [pmid: 8403593]. Rec#: 23980 Reprint: EXC YEAR
Sterba J, Pavelka Z, Slampa P. Concomitant radiotherapy and metronomic temozolomide in pediatric high-risk brain tumors. Neoplasma. 2002;49(2):117-20. [pmid: 12088104]. Rec#: 11990 Reprint: exc nri
Stewart DA, Gyonyor E, Paterson AH, Arthur K, Temple W, Schachar NS, Klassen J, Brown C, Russell JA. High-dose melphalan +/- total body irradiation and autologous hematopoietic stem cell rescue for adult patients with Ewing's sarcoma or peripheral neuroectodermal tumor. Bone Marrow Transplant. 1996;18(2):315-8. [pmid: 8864440]. Rec#: 20370 Reprint: EXC NRP
Stiefel M, Reiss T, Staege MS, Rengelshausen J, Burhenne J, Wawer A, Foell JL. Successful treatment with voriconazole of Aspergillus brain abscess in a boy with medulloblastoma. Pediatr Blood Cancer. 2007;49(2):203-7. [pmid: 16333861]. Rec#: 6360 Reprint: EXC NRI
Stram DO, Matthay KK, O'Leary M, Reynolds CP, Haase GM, Atkinson JB, Brodeur GM, Seeger RC. Consolidation chemoradiotherapy and autologous bone marrow transplantation versus continued chemotherapy for metastatic neuroblastoma: a report of two concurrent Children's Cancer Group studies. J Clin Oncol. 1996;14(9):2417-26. [pmid: 8823319]. Rec#: 20310 Reprint: exc nri
Stram DO, Matthay KK, O'Leary M, Reynolds CP, Seeger RC. Myeloablative chemoradiotherapy versus continued chemotherapy for high risk neuroblastoma. Prog Clin Biol Res. 1994;385:287-91. [pmid: 7972222]. Rec#: 23460 Reprint: EXC YEAR
Strauss SJ, McTiernan A, Driver D, Hall-Craggs M, Sandison A, Cassoni AM, Kilby A, Michelagnoli M, Pringle J, Cobb J, Briggs T, Cannon S, Witt J, Whelan JS. Single center experience of a new intensive induction therapy for ewing's family of tumors: feasibility, toxicity, and stem cell mobilization properties. J Clin Oncol. 2003;21(15):2974-81. [pmid: 12885818]. Rec#: 10120 Reprint: EXC NRO MIX
Streffer J, Schabet M, Bamberg M, Grote EH, Meyermann R, Voigt K, Dichgans J, Weller M. A role for preirradiation PCV chemotherapy for oligodendroglial brain tumors. J Neurol. 2000;247(4):297-302. [pmid: 10836623]. Rec#: 55940 Reprint: exc nrp
Strother D, Ashley D, Kellie SJ, Patel A, Jones-Wallace D, Thompson S, Heideman R, Benaim E, Krance R, Bowman L, Gajjar A. Feasibility of four consecutive high-dose chemotherapy cycles with stem-cell rescue for patients with newly diagnosed medulloblastoma or supratentorial primitive neuroectodermal tumor after craniospinal radiotherapy: results of a collaborative study. J Clin Oncol. 2001;19(10):2696-704. [pmid: 11352962]. Rec#: 70650 Reprint: EXC NRI
Stuber ML, Nader K, Yasuda P, Pynoos RS, Cohen S. Stress responses after pediatric bone marrow transplantation: preliminary results of a prospective longitudinal study. J Am Acad Child Adolesc Psychiatry. 1991;30(6):952-7. [pmid: 1757445]. Rec#: 25720 Reprint: EXC YEAR
Stylli SS, Kaye AH, MacGregor L, Howes M, Rajendra P. Photodynamic therapy of high grade glioma - long term survival. J Clin Neurosci. 2005;12(4):389-98. [pmid: 15925768]. Rec#: 55140 Reprint: exc nri
Su TI, Khanna D, Furst DE, Danovitch G, Burger C, Maranian P, Clements PJ. Rapamycin versus methotrexate in early diffuse systemic sclerosis: results from a randomized, single-blind pilot study. Arthritis Rheum. 2009;60(12):3821-30. [pmid: 19950289]. Rec#: 40860 Reprint: exc nrp
Suarez JC, Viano JC, Zunino S, Herrera EJ, Gomez J, Tramunt B, Marengo I, Hiramatzu E, Miras M, Pena M, Sonzini Astudillo B. Management of child optic pathway gliomas: new therapeutical option. Childs Nerv Syst. 2006;22(7):679-84. [pmid: 16389565]. Rec#: 54970 Reprint: exc nro
Sung KW, Yoo KH, Chung EH, Cho EJ, Jung HL, Koo HH, Lee SK, Lim DH, Kim DY, Kim DW, Kim HR, Kim SW. Double high-dose chemotherapy with autologous stem cell transplantation in patients with high-risk neuroblastoma: a pilot study in a single center. J Korean Med Sci. 2002;17(4):537-43. [pmid: 12172052]. Rec#: 11800 Reprint: exc nri
Svahn J, Fioredda F, Calvillo M, Molinari AC, Micalizzi C, Banov L, Schmidt M, Caprino D, Marinelli D, Gallisai D, Dufour C. Rituximab-based immunosuppression for autoimmune haemolytic anaemia in infants. Br J Haematol. 2009;145(1):96-100. [pmid: 19208098]. Rec#: 77460 Reprint: exc nrc
Svoren BM, Volkening LK, Butler DA, Moreland EC, Anderson BJ, Laffel LM. Temporal trends in the treatment of pediatric type 1 diabetes and impact on acute outcomes. J Pediatr. 2007;150(3):279-85. [pmid: 17307546]. Rec#: 61930 Reprint: exc nro
Tabori U, Sung L, Hukin J, Laperriere N, Crooks B, Carret AS, Silva M, Odame I, Mpofu C, Strother D, Wilson B, Samson Y, Bouffet E. Distinctive clinical course and pattern of relapse in adolescents with medulloblastoma. Int J Radiat Oncol Biol Phys. 2006;64(2):402-7. [pmid: 16198067]. Rec#: 52620 Reprint: EXC NRI NPC
Taga T, Okamoto N, Hisano T, Tanaka T, Shimada M, Okabe H, Shimada H, Ohta S. An infant with neuroblastoma and MYCN amplification found through mass screening. J Pediatr Hematol Oncol. 1998;20(5):486-8. [pmid: 9787326]. Rec#: 17560 Reprint: exc nri
Takahashi H, Manabe A, Aoyama C, Kamiya T, Kato I, Takusagawa A, Ogawa C, Ozawa M, Hosoya R, Yokoyama K. Iodine-131-metaiodobenzylguanidine therapy with reduced-intensity allogeneic stem cell transplantation in recurrent neuroblastoma. Pediatr Blood Cancer. 2008;50(3):676-8. [pmid: 17243128]. Rec#: 4430 Reprint: exc nri
Takken T, van den Beuken C, Wulffraat NM, Helders PJ, van der Net J. Exercise tolerance in children with juvenile idiopathic arthritis after autologous SCT. Bone Marrow Transplant. 2008;42(5):351-6. [pmid: 18587436]. Rec#: 1770 Reprint: exc nro
Tanaka H, Tsugawa K, Suzuki K, Oki ES, Nonaka K, Kimura S, Ito E. Treatment of difficult cases of systemic-onset juvenile idiopathic arthritis with tacrolimus. Eur J Pediatr. 2007;166(10):1053-5. [pmid: 17187256]. Rec#: 41400 Reprint: exc nrc
Tanphaichitr VS, Suvatte V, Mahasandana C, Sachapong P, Veerakul G, Kankirawatana S, Wasant P. Gaucher's disease;thirty-two years experience at Siriraj Hospital. Southeast Asian J Trop Med Public Health. Suppl 2. 1999;30:143-7. [pmid: 11400753]. Rec#: 13630 Reprint: exc nrs
Tarkowski A, Andersson-Gare B, Aurell M. Use of anti-thymocyte globulin in the management of refractory systemic autoimmune diseases. Scand J Rheumatol. 1993;22(6):261-6. [pmid: 8266027]. Rec#: 24540 Reprint: EXC YEAR
Tasdemiroglu E. Trilateral retinoblastoma. Acta Neurochir (Wien). 1999;141(8):893-4. [pmid: 10536729]. Rec#: 49070 Reprint: exc nrs
Tchirkov A, Paillard C, Halle P, Bernard F, Bordigoni P, Vago P, Demeocq F, Kanold J. Significance of molecular quantification of minimal residual disease in metastatic neuroblastoma. J Hematother Stem Cell Res. 2003;12(4):435-42. [pmid: 12965080]. Rec#: 9920 Reprint: exc nri
Teachey DT, Greiner R, Seif A, Attiyeh E, Bleesing J, Choi J, Manno C, Rappaport E, Schwabe D, Sheen C, Sullivan KE, Zhuang H, Wechsler DS, Grupp SA. Treatment with sirolimus results in complete responses in patients with autoimmune lymphoproliferative syndrome. Br J Haematol. 2009;145(1):101-6. [pmid: 19208097]. Rec#: 77470 Reprint: exc nrd
Tekautz TM, Fuller CE, Blaney S, Fouladi. Atypical Teratoid/Rhabid Tumors (ATRT): Improved Surivial in Children 3 years of Age and Older With Radiation Therapy and High-dose alkylator-based chemotehrapy. J Clin Oncol. 2005;23(7). Rec#: Reprint: exc nrc
ten Cate R, Brinkman DM, van Rossum MA, Lankester AC, Bredius RG, Egeler MR, van Tol MJ, Vossen JM. Macrophage activation syndrome after autologous stem cell transplantation for systemic juvenile idiopathic arthritis. Eur J Pediatr. 2002;161(12):686-6. [pmid: 12536993]. Rec#: 11070 Reprint: exc nro
Terasaki K, Kanekura T, Setoyama M, Kanzaki T. A pediatric case of sclerodermatous chronic graft-versus-host disease. Pediatr Dermatol. 2003;20(4):327-31. [pmid: 12869155]. Rec#: 10160 Reprint: exc nrs
Terasaki M, Bouffet E, Katsuki H, Fukushima S, Shigemori M. Pilot trial of the rate of response, safety, and tolerability of temozolomide and oral VP-16 in patients with recurrent or treatment-induced malignant central nervous system tumors. Surg Neurol. 2008;69(1):46-50. [pmid: 18054615]. Rec#: 54660 Reprint: exc nrs
Thurberg BL, Fallon JT, Mitchell R, Aretz T, Gordon RE, O'Callaghan MW. Cardiac microvascular pathology in Fabry disease: evaluation of endomyocardial biopsies before and after enzyme replacement therapy. Circulation. 2009;119(19):2561-7. [pmid: 19414635]. Rec#: 56640 Reprint: exc nrc
Thurberg BL, Rennke H, Colvin RB, Dikman S, Gordon RE, Collins AB, Desnick RJ, O'Callaghan M. Globotriaosylceramide accumulation in the Fabry kidney is cleared from multiple cell types after enzyme replacement therapy. Kidney Int. 2002;62(6):1933-46. [pmid: 12427118]. Rec#: 57670 Reprint: exc nrc
Timmermann B, Kortmann RD, Kuhl J, Rutkowski S, Meisner C, Pietsch T, Deinlein F, Urban C, Warmuth-Metz M, Bamberg M. Role of radiotherapy in supratentorial primitive neuroectodermal tumor in young children: results of the German HIT-SKK87 and HIT-SKK92 trials. J Clin Oncol. 2006;24(10):1554-60. [pmid: 16575007]. Rec#: 52510 Reprint: EXC NRI NRC
Ting SS, Ziegler JB, Vowels MR. Acquired autoimmune thrombocytopenia post-bone marrow transplantation for severe combined immunodeficiency. Bone Marrow Transplant. 1998;21(8):841-3. [pmid: 9603413]. Rec#: 18160 Reprint: exc nrs
Ting TV, Hashkes PJ. Methotrexate/naproxen-associated severe hepatitis in a child with juvenile idiopathic arthritis. Clin Exp Rheumatol. 2007;25(6):928-9. [pmid: 18173932]. Rec#: 41130 Reprint: exc cr
Tohyama J, Kato M, Koeda T, Ohno K. Type C Niemann-Pick disease. Detection and quantification of cholesterol-accumulating cells in bone marrow. 1993. Rec#: 24010 Reprint: exc nrs
Tolar J, Coad JE, Ramsay NK, Peters C, Davies SM. Lymphoproliferative disorder presenting as pulmonary nodules after bone marrow transplantation. 2001. Rec#: 12710 Reprint: exc nrs
Tolland JP, Devereux C, Jones FC, Bingham EA. Sclerodermatous chronic graft-versus-host disease--a report of four pediatric cases. Pediatr Dermatol. 2008;25(2):240-4. [pmid: 18429789]. Rec#: 2080 Reprint: exc nrd
Toren A, Nagler A, Rozenfeld-Granot G, Levanon M, Davidson J, Bielorai B, Kaplinsky C, Meitar D, Mandel M, Ackerstein A, Ballin A, Attias D, Biniaminov M, Rosenthal E, Brok-Simoni F, Rechavi G, Kaufmann Y. Amplification of immunological functions by subcutaneous injection of intermediate-high dose interleukin-2 for 2 years after autologous stem cell transplantation in children with stage IV neuroblastoma. Transplantation. 2000;70(7):1100-4. [pmid: 11045650]. Rec#: 14670 Reprint: exc nri
Touitou I, Dumont B, Pourtein M, Perelman S, Sirvent A, Soler C. Transmission of familial Mediterranean fever mutations following bone marrow transplantation. 2007. Rec#: 3430 Reprint: exc nrs
Trahair TN, Vowels MR, Johnston K, Cohn RJ, Russell SJ, Neville KA, Carroll S, Marshall GM. Long-term outcomes in children with high-risk neuroblastoma treated with autologous stem cell transplantation. Bone Marrow Transplant. 2007;40(8):741-6. [pmid: 17724446]. Rec#: 3320 Reprint: exc nri
Traynor AE, Barr WG, Rosa RM, Rodriguez J, Oyama Y, Baker S, Brush M, Burt RK. Hematopoietic stem cell transplantation for severe and refractory lupus. Analysis after five years and fifteen patients. Arthritis Rheum. 2002;46(11):2917-23. [pmid: 12428232]. Rec#: 11440 Reprint: exc nrp
Trebo MM, Thorner PS, Bowman WP, Weitzman S. Long-term survival of a stage 4 neuroblastoma patient despite persistent bone marrow disease following autologous bone marrow transplantation. Med Pediatr Oncol. 1999;33(6):585-7. [pmid: 10573586]. Rec#: 15960 Reprint: exc nri
Trivedi HL, Vanikar AV, Thakker U, Firoze A, Dave SD, Patel CN, Patel JV, Bhargava AB, Shankar V. Human adipose tissue-derived mesenchymal stem cells combined with hematopoietic stem cell transplantation synthesize insulin. Transplant Proc. 2008;40(4):1135-9. [pmid: 18555133]. Rec#: 1870 Reprint: exc nri
Trobaugh-Lotrario AD, Greffe B, Deterding R, Deutsch G, Quinones R. Pulmonary veno-occlusive disease after autologous bone marrow transplant in a child with stage IV neuroblastoma: case report and literature review. J Pediatr Hematol Oncol. 2003;25(5):405-9. [pmid: 12759629]. Rec#: 10520 Reprint: exc nri
Tse S, Saunders EF, Silverman E, Vajsar J, Becker L, Meaney B. Myasthenia gravis and polymyositis as manifestations of chronic graft-versus-host-disease. Bone Marrow Transplant. 1999;23(4):397-9. [pmid: 10100585]. Rec#: 16980 Reprint: exc nrs
Tsilou ET, Thompson D, Lindblad AS, Reed GF, Rubin B, Gahl W, Thoene J, Del Monte M, Schneider JA, Granet DB, Kaiser-Kupfer MI. A multicentre randomised double masked clinical trial of a new formulation of topical cysteamine for the treatment of corneal cystine crystals in cystinosis. Br J Ophthalmol. 2003;87(1):28-31. [pmid: 12488257]. Rec#: 57660 Reprint: exc nrc
Tsuchida Y, Kaneko M. Surgery in pediatric solid tumors with special reference to advanced neuroblastoma. Acta Paediatr Taiwan. 2002;43(2):67-71. [pmid: 12041619]. Rec#: 12080 Reprint: exc nri
Tsugu H, Oshiro S, Yanai F, Komatsu F, Abe H, Fukushima T, Nomura Y, Matsumoto S, Nabeshima K, Takano K, Utsunomiya H. Management of pilomyxoid astrocytomas: our experience. Anticancer Res. 2009;29(3):919-26. [pmid: 19414328]. Rec#: 54360 Reprint: exc nrd
Tsui E, Barnie A, Ross S, Parkes R, Zinman B. Intensive insulin therapy with insulin lispro: a randomized trial of continuous subcutaneous insulin infusion versus multiple daily insulin injection. Diabetes Care. 2001;24(10):1722-7. [pmid: 11574432]. Rec#: 62420 Reprint: exc nrp
Tsutsumi C, Miyazaki Y, Fukushima T, Yoshida S, Taguchi J, Miyake C, Miyazaki M, Kohno S, Jinnai I, Tomonaga M. Membranous nephropathy after allogeneic stem cell transplantation: report of 2 cases. Int J Hematol. 2004;79(2):193-7. [pmid: 15005351]. Rec#: 9180 Reprint: exc nro
Turner D, Grossman AB, Rosh J, Kugathasan S, Gilman AR, Baldassano R, Griffiths AM. Methotrexate following unsuccessful thiopurine therapy in pediatric Crohn's disease. Am J Gastroenterol. 2007;102(12):2804-12. quiz 2803, 2813. [pmid: 18042110]. Rec#: 41170 Reprint: exc nrc
Tuzun E, Baykan B, Gurses C, Gokyigit A. Longterm follow-up of electroencephalographic and clinical findings of a case with Gaucher's disease type 3a. Seizure. 2000;9(7):469-72. [pmid: 11034870]. Rec#: 14740 Reprint: exc nrp
Tyndall A, Fassas A, Passweg J, Ruiz de Elvira C, Attal M, Brooks P, Black C, Durez P, Finke J, Forman S, Fouillard L, Furst D, Holmes J, Joske D, Jouet J, Kotter I, Locatelli F, Prentice H, Marmont AM, McSweeney P, Musso M, Peter HH, Snowden JA, Sullivan K, Gratwohl A, et al. Autologous haematopoietic stem cell transplants for autoimmune disease--feasibility and transplant-related mortality. Autoimmune Disease and Lymphoma Working Parties of the European Group for Blood and Marrow Transplantation, the European League Against Rheumatism and the International Stem Cell Project for Autoimmune Disease. Bone Marrow Transplant. 1999;24(7):729-34. [pmid: 10516675]. Rec#: 16210 Reprint: exc nrp
Tyndall AJ, Joly F, Carbonne B, Deligny CN, Farge DC. Pregnancy and childbirth after treatment with autologous hematopoietic stem cell transplantation for severe systemic sclerosis requiring parenteral nutrition. Ethical issues. Clin Exp Rheumatol. 2008;26(6):1122-4. [pmid: 19210885]. Rec#: 540 Reprint: exc nro
Tynjala P, Lindahl P, Honkanen V, Lahdenne P, Kotaniemi K. Infliximab and etanercept in the treatment of chronic uveitis associated with refractory juvenile idiopathic arthritis. Ann Rheum Dis. 2007;66(4):548-50. [pmid: 17068061]. Rec#: 41440 Reprint: exc nro
Ucar B, Akgun N, Aydogdu SD, Kirel B, Idem S. Treatment of refractory Evans' syndrome with cyclosporine and prednisone. Pediatr Int. 1999;41(1):104-7. [pmid: 10200147]. Rec#: 78590 Reprint: exc nri cr
Ullrich NJ, Marcus K, Pomeroy SL, Turner CD, Zimmerman M, Lehmann LE, Scott RM, Goumnerova L, Gillan E, Kieran MW, Chi SN. Transverse myelitis after therapy for primitive neuroectodermal tumors. Pediatr Neurol. 2006;35(2):122-5. [pmid: 16876009]. Rec#: 71210 Reprint: EXC NRO
Urban C, Benesch M, Sovinz P, Schwinger W, Lackner H. Fatal Evans' syndrome after matched unrelated donor transplantation for hyper-IgM syndrome. Eur J Haematol. 2004;72(6):444-7. [pmid: 15128425]. Rec#: 8910 Reprint: exc nrd
Ushio Y, Kochi M, Kitamura I, Kuratsu J. Ventriculolumber perfusion of 3-[(4-amino-2-methyl-5-pyrimidinyl)-methyl]-1-(2-chloroethyl-1-nitrosou rea hydrochloride for subarachnoid dissemination of gliomas. J Neurooncol. 1998;38(2-3):207-12. [pmid: 9696373]. Rec#: 56130 Reprint: exc nrp
Vachvanichsanong P, Dissaneewate P, Winn T. Intravenous cyclophosphamide for lupus nephritis in Thai children. Scand J Rheumatol. 2004;33(5):339-42. [pmid: 15513684]. Rec#: 41720 Reprint: exc nri
Vaena DA, Abonour R, Einhorn LH. Long-term survival after high-dose salvage chemotherapy for germ cell malignancies with adverse prognostic variables. J Clin Oncol. 2003;21:4100-4104. [pmid: 14615439]. Rec#: 78820 Reprint: EXC NRP
Vaisbich MH, Koch VH. Report of a Brazilian multicenter study on nephropathic cystinosis. Nephron Clin Pract. 2010;114(1):c12-8. [pmid: 19816039]. Rec#: 56510 Reprint: exc nrc
Valteau-Couanet D, Benhamou E, Vassal G, Stambouli F, Lapierre V, Couanet D, Lumbroso J, Hartmann O. Consolidation with a busulfan-containing regimen followed by stem cell transplantation in infants with poor prognosis stage 4 neuroblastoma. Bone Marrow Transplant. 2000;25(9):937-42. [pmid: 10800060]. Rec#: 15330 Reprint: exc nri
Valteau-Couanet D, Rubie H, Meresse V, Farace F, Brandely M, Hartmann O. Phase I-II study of interleukin-2 after high-dose chemotherapy and autologous bone marrow transplantation in poorly responding neuroblastoma. Bone Marrow Transplant. 1995;16(4):515-20. [pmid: 8528166]. Rec#: 21500 Reprint: EXC NRI
Valteau-Couanet D, Vassal G, Pondarre C, Bonnay M, Benhamou E, Couanet D, Plantaz D, Hartmann O. Phase I study of high-dose continuous intravenous infusion of VP-16 in combination with high-dose melphalan followed by autologous bone marrow transplantation in children with stage IV neuroblastoma. Bone Marrow Transplant. 1996;17(4):485-9. [pmid: 8722343]. Rec#: 20880 Reprint: EXC NRI
van den Bent MJ, Brandes AA, Rampling R, Kouwenhoven MC, Kros JM, Carpentier AF, Clement PM, Frenay M, Campone M, Baurain JF, Armand JP, Taphoorn MJ, Tosoni A, Kletzl H, Klughammer B, Lacombe D, Gorlia T. Randomized phase II trial of erlotinib versus temozolomide or carmustine in recurrent glioblastoma: EORTC brain tumor group study 26034. J Clin Oncol. 2009;27(8):1268-74. [pmid: 19204207]. Rec#: 54440 Reprint: exc nrp
van den Berg H, Dirksen U, Ranft A, Jurgens H. Ewing tumors in infants. Pediatr Blood Cancer. 2008;50(4):761-4. [pmid: 17635001]. Rec#: 3510 Reprint: EXC MIX
Van den Hout JM, Reuser AJ, de Klerk JB, Arts WF, Smeitink JA, Van der Ploeg AT. Enzyme therapy for pompe disease with recombinant human alpha-glucosidase from rabbit milk. J Inherit Metab Dis. 2001;24(2):266-74. [pmid: 11405345]. Rec#: 57810 Reprint: exc nrc
van der Ploeg AT, Clemens PR, Corzo D, Escolar DM, Florence J, Groeneveld GJ, Herson S, Kishnani PS, Laforet P, Lake SL, Lange DJ, Leshner RT, Mayhew JE, Morgan C, Nozaki K, Park DJ, Pestronk A, Rosenbloom B, Skrinar A, van Capelle CI, van der Beek NA, Wasserstein M, Zivkovic SA. A randomized study of alglucosidase alfa in late-onset Pompe's disease. N Engl J Med. 2010;362(15):1396-406. [pmid: 20393176]. Rec#: 56430 Reprint: exc nrc
van Geel BM, Assies J, Haverkort EB, Koelman JH, Verbeeten B Jr, Wanders RJ, Barth PG. Progression of abnormalities in adrenomyeloneuropathy and neurologically asymptomatic X-linked adrenoleukodystrophy despite treatment with ‘Lorenzo's oil’. J Neurol Neurosurg Psychiatry. 1999;67(3):290-9. [pmid: 10449548]. Rec#: 57980 Reprint: exc nrc
van Laar JM, Farge D, Tyndall A. Stem cell transplantation: a treatment option for severe systemic sclerosis?. Ann Rheum Dis. 2008;67(Suppl 3):iii35-8. [pmid: 19022811]. Rec#: 850 Reprint: exc nra
Van Riet FA, Wessels G, Hesseling PB. Experience with high dose dexamethasone in the treatment of chronic symptomatic immune thrombocytopaenia. East Afr Med J. 1999;76(10):571-4. [pmid: 10734508]. Rec#: 15450 Reprint: exc nro
Vande Berg BC, Malghem J, Lecouvet FE, Devogelaer JP, Maldague B, Houssiau FA. Fat conversion of femoral marrow in glucocorticoid-treated patients: a cross-sectional and longitudinal study with magnetic resonance imaging. Arthritis Rheum. 1999;42(7):1405-11. [pmid: 10403268]. Rec#: 16630 Reprint: exc nro
Vanlemmens P, Plouvier E, Amsallem D, Racadot E, Deschaseaux ML, Schaal JP, Charbord P, Noir A, Herve P. Transplantation of umbilical cord blood in neuroblastoma. Nouv Rev Fr Hematol. 1992;34(3):243-6. [pmid: 1357627]. Rec#: 25550 Reprint: EXC YEAR
Varan A, Tuncer AM. The importance of the bone marrow examination in cystinosis. 1991. Rec#: 25850 Reprint: exc year
Vassal G, Couanet D, Stockdale E, Geoffray A, Geoerger B, Orbach D, Pichon F, Gentet JC, Picton S, Bergeron C, Cisar L, Assadourian S, Morland B. Phase II trial of irinotecan in children with relapsed or refractory rhabdomyosarcoma: a joint study of the French Society of Pediatric Oncology and the United Kingdom Children's Cancer Study Group. J Clin Oncol. 2007;25(4):356-61. [pmid: 17264330]. Rec#: 47070 Reprint: exc nro
Vassal G, Tranchand B, Valteau-Couanet D, Mahe C, Couanet D, Schoeppfer C, Grill J, Kalifa C, Hill C, Ardiet C, Hartmann O. Pharmacodynamics of tandem high-dose melphalan with peripheral blood stem cell transplantation in children with neuroblastoma and medulloblastoma. Bone Marrow Transplant. 2001;27(5):471-7. [pmid: 11313680]. Rec#: 70660 Reprint: EXC NRO
Vaughan WP. NCCN High-dose chemotherapy. Applications of high-dose chemotherapy with bone marrow/stem cell support in solid tumors. Cancer Control. 2001;8(6 Suppl 2):50-2. [pmid: 11760558]. Rec#: 70620 Reprint: EXC NRS
Vaux Z. Peripheral stem cell transplants in children. Paediatr Nurs. 1996;8(2):20-2. [pmid: 8715534]. Rec#: 20970 Reprint: EXC NRD NRI
Verdeguer A, Munoz A, Canete A, Pardo N, Martinez A, Donat J, Gomez P, Bureo E, Fernandez JM, Cubells J, Maldonado M, Sastre A. Long-term results of high-dose chemotherapy and autologous stem cell rescue for high-risk neuroblastoma patients: a report of the Spanish working party for BMT in children (Getmon). Pediatr Hematol Oncol. 2004;21(6):495-504. [pmid: 15552813]. Rec#: 7990 Reprint: exc nri
Vermeulen J, Ballet S, Oberlin O, Peter M, Pierron G, Longavenne E, Laurence V, Kanold J, Chastagner P, Lejars O, Blay JY, Marec-Berard P, Michon J, Delattre O, Schleiermacher G. Incidence and prognostic value of tumour cells detected by RT-PCR in peripheral blood stem cell collections from patients with Ewing tumour. Br J Cancer. 2006;95(10):1326-33. [pmid: 17088915]. Rec#: 4700 Reprint: exc nrp
Vettenranta K, Ukkonen P, Saarinen UM. RSV infection complicating the therapy of pediatric malignancies: report of six cases. Med Pediatr Oncol. 1996;26(4):261-3. [pmid: 8600339]. Rec#: 20930 Reprint: exc nri
Vialettes B, Maraninchi D, San Marco MP, Birg F, Stoppa AM, Mattei-Zevaco C, Thivolet C, Hermitte L, Vague P, Mercier P. Autoimmune polyendocrine failure--type 1 (insulin-dependent) diabetes mellitus and hypothyroidism--after allogeneic bone marrow transplantation in a patient with lymphoblastic leukaemia. Diabetologia. 1993;36(6):541-6. [pmid: 8101499]. Rec#: 24120 Reprint: EXC YEAR
Villas C, San Julian M. Ewing's tumor of the spine: report on seven cases including one with a 10-year follow-up. Eur Spine J. 1996;5(6):412-7. [pmid: 8988385]. Rec#: 21150 Reprint: exc cr (small)
Vinchon M, Leblond P, Noudel R, Dhellemmes P. Intracranial ependymomas in childhood: recurrence, reoperation, and outcome. Childs Nerv Syst. 2005;21(3):221-6. [pmid: 15599561]. Rec#: 74020 Reprint: exc nri
Vogelbaum MA, Berkey B, Peereboom D, Macdonald D, Giannini C, Suh JH, Jenkins R, Herman J, Brown P, Blumenthal DT, Biggs C, Schultz C, Mehta M. Phase II trial of preirradiation and concurrent temozolomide in patients with newly diagnosed anaplastic oligodendrogliomas and mixed anaplastic oligoastrocytomas: RTOG BR0131. Neuro Oncol. 2009;11(2):167-75. [pmid: 18779504]. Rec#: 54520 Reprint: exc nro
Voltarelli JC, Couri CE, Stracieri AB, Oliveira MC, Moraes DA, Pieroni F, Coutinho M, Malmegrim KC, Foss-Freitas MC, Simoes BP, Foss MC, Squiers E, Burt RK. Autologous nonmyeloablative hematopoietic stem cell transplantation in newly diagnosed type 1 diabetes mellitus. JAMA. 2007;297(14):1568-76. [pmid: 17426276]. Rec#: 4050 Reprint: exc all pts reported in couri rec 290
von Hoff K, Hinkes B, Gerber NU, Deinlein F, Mittler U, Urban C, Benesch M, Warmuth-Metz M, Soerensen N, Zwiener I, Goette H, Schlegel PG, Pietsch T, Kortmann RD, Kuehl J, Rutkowski S. Long-term outcome and clinical prognostic factors in children with medulloblastoma treated in the prospective randomised multicentre trial HIT'91. Eur J Cancer. 2009;45(7):1209-17. [pmid: 19250820]. Rec#: 51920 Reprint: EXC NRI
Vonk MC, Marjanovic Z, van den Hoogen FH, Zohar S, Schattenberg AV, Fibbe WE, Larghero J, Gluckman E, Preijers FW, van Dijk AP, Bax JJ, Roblot P, van Riel PL, van Laar JM, Farge D. Long-term follow-up results after autologous haematopoietic stem cell transplantation for severe systemic sclerosis. Ann Rheum Dis. 2008;67(1):98-104. [pmid: 17526554]. Rec#: 3820 Reprint: exc nrp
Vossen JM, Brinkman DM, Bakker B, Hoogerbrugge PM, ten Cate R. Rationale for high-dose cyclophosphamide and medium-dose total body irradiation in the conditioning of children with progressive systemic and polyarticular juvenile chronic arthritis before autologous stem cell transplantation. Rheumatology (Oxford). 1999;38(8):762-3. [pmid: 10501429]. Rec#: 16290 Reprint: exc npd
Vredenburgh JJ, Desjardins A, Herndon JE 2nd, Marcello J, Reardon DA, Quinn JA, Rich JN, Sathornsumetee S, Gururangan S, Sampson J, Wagner M, Bailey L, Bigner DD, Friedman AH, Friedman HS. Bevacizumab plus irinotecan in recurrent glioblastoma multiforme. J Clin Oncol. 2007;25(30):4722-9. [pmid: 17947719]. Rec#: 54680 Reprint: exc nrp
Wada RK, Seeger RC, Brodeur GM, Einhorn PA, Rayner SA, Tomayko MM, Reynolds CP. Human neuroblastoma cell lines that express N-myc without gene amplification. Cancer. 1993;72(11):3346-54. [pmid: 8242562]. Rec#: 23630 Reprint: exc nrp
Wagner JE, Kernan NA, Steinbuch M, Broxmeyer HE, Gluckman E. Allogeneic sibling umbilical-cord-blood transplantation in children with malignant and non-malignant disease. Lancet. 1995;346(8969):214-9. [pmid: 7616801]. Rec#: 21670 Reprint: EXC NRS
Wagner KR. Enzyme replacement for infantile Pompe disease: the first step toward a cure. Neurology. 2007;68(2):88-9. [pmid: 17210887]. Rec#: 57050 Reprint: exc nrc
Wagner LM, Crews KR, Iacono LC, Houghton PJ, Fuller CE, McCarville MB, Goldsby RE, Albritton K, Stewart CF, Santana VM. Phase I trial of temozolomide and protracted irinotecan in pediatric patients with refractory solid tumors. Clin Cancer Res. 2004;10(3):840-8. [pmid: 14871959]. Rec#: 9290 Reprint: EXC MIX
Wainwright MS, Martin PL, Morse RP, Lacaze M, Provenzale JM, Coleman RE, Morgan MA, Hulette C, Kurtzberg J, Bushnell C, Epstein L, Lewis DV. Human herpesvirus 6 limbic encephalitis after stem cell transplantation. Ann Neurol. 2001;50(5):612-9. [pmid: 11706967]. Rec#: 12880 Reprint: exc nrd
Waite L, Morrison E. Severe gastrointestinal involvement in systemic lupus erythematosus treated with rituximab and cyclophosphamide (B-cell depletion therapy). Lupus. 2007;16(10):841-2. [pmid: 17895311]. Rec#: 41200 Reprint: exc cr
Wang J, Hu W, Xie H, Zhang H, Chen H, Zeng C, Liu Z, Li L. Induction therapies for class IV lupus nephritis with non-inflammatory necrotizing vasculopathy: mycophenolate mofetil or intravenous cyclophosphamide. Lupus. 2007;16(9):707-12. [pmid: 17728363]. Rec#: 41230 Reprint: exc nrp
Watanabe K, Kanaya H, Fujiyama Y, Kim P. Combination chemotherapy using carboplatin (JM-8) and etoposide (JET therapy) for recurrent malignant gliomas: a phase II study. Acta Neurochir (Wien). 2002;144(12):1265-70. [pmid: 12478337]. discussion 1270 Rec#: 55580 Reprint: exc nrp
Watts RG. Idiopathic thrombocytopenic purpura: a 10-year natural history study at the childrens hospital of alabama. Clin Pediatr (Phila). 2004;43(8):691-702. [pmid: 15494875]. Rec#: 8110 Reprint: exc nro
Watts RG, Mroczek-Musulman E. Pulmonary interstitial disease mimicking idiopathic pneumonia syndrome as the initial site of relapse of neuroblastoma following autologous bone-marrow transplantation: a case report. Am J Hematol. 1996;53(2):137-40. [pmid: 8892741]. Rec#: 20240 Reprint: exc nri
Wedderburn LR, Abinun M, Palmer P, Foster HE. Autologous haematopoietic stem cell transplantation in juvenile idiopathic arthritis. Arch Dis Child. 2003;88(3):201-5. [pmid: 12598377]. Rec#: 10920 Reprint: exc nra
Wedrychowicz A, Gozdzik J, Krasowska-Kwiecien A, Kacinka E, Wiecha O, Kubiczek K, Ratajczak MZ. Manifestation of toxocariasis in children with neuroblastoma treated with autologous hematopoietic transplants. Pediatr Hematol Oncol. 2006;23(5):369-79. [pmid: 16728357]. Rec#: 5540 Reprint: exc nri
Weigel BJ, Breitfeld PP, Hawkins D, Crist WM, Baker KS. Role of high-dose chemotherapy with hematopoietic stem cell rescue in the treatment of metastatic or recurrent rhabdomyosarcoma. J Pediatr Hematol Oncol. 2001;23(5):272-6. [pmid: 11464981]. Rec#: 13340 Reprint: exc rev
Weintrob N, Benzaquen H, Galatzer A, Shalitin S, Lazar L, Fayman G, Lilos P, Dickerman Z, Phillip M. Comparison of continuous subcutaneous insulin infusion and multiple daily injection regimens in children with type 1 diabetes: a randomized open crossover trial. Pediatrics. 2003;112(3 Pt 1):559-64. [pmid: 12949284]. Rec#: 62310 Reprint: exc nro
Weiss B, Lerner A, Shapiro R, Broide E, Levine A, Fradkin A, Bujanover Y. Methotrexate treatment in pediatric Crohn disease patients intolerant or resistant to purine analogues. J Pediatr Gastroenterol Nutr. 2009;48(5):526-30. [pmid: 19412004]. Rec#: 40900 Reprint: exc nrc
Weitzman CC, Schlegel S, Murphy N, Antommaria AH, Brosco JP, Stein MT. When clinicians and a parent disagree on the extent of medical care. J Dev Behav Pediatr. 2009;30(3):242-3. [pmid: 19525718]. Rec#: 90 Reprint: exc nrd
Wells RJ, Reid JM, Ames MM, Mares WL, Krailo MD, Seibel NL, Mosher R, Reaman GH, Wiersma SR. Phase I trial of cisplatin and topotecan in children with recurrent solid tumors: Children's Cancer Group Study 0942. J Pediatr Hematol Oncol. 2002;24(2):89-93. [pmid: 11990712]. Rec#: 12260 Reprint: exc nro
Wen PY, Yung WK, Lamborn KR, Dahia PL, Wang Y, Peng B, Abrey LE, Raizer J, Cloughesy TF, Fink K, Gilbert M, Chang S, Junck L, Schiff D, Lieberman F, Fine HA, Mehta M, Robins HI, DeAngelis LM, Groves MD, Puduvalli VK, Levin V, Conrad C, Maher EA, Aldape K, Hayes M, Letvak L, Egorin MJ, Capdeville R, Kaplan R, Murgo AJ, Stiles C, Prados MD. Phase I/II study of imatinib mesylate for recurrent malignant gliomas: North American Brain Tumor Consortium Study 99-08. Clin Cancer Res. 2006;12(16):4899-907. [pmid: 16914578]. Rec#: 54860 Reprint: exc nro
Wenner WJ, Murphy JL. The effects of cysteamine on the upper gastrointestinal tract of children with cystinosis. Pediatr Nephrol. 1997;11(5):600-3. [pmid: 9323287]. Rec#: 58140 Reprint: exc nrc
Wexler LH, DeLaney TF, Tsokos M, Avila N, Steinberg SM, Weaver-McClure L, Jacobson J, Jarosinski P, Hijazi YM, Balis FM, Horowitz ME. Ifosfamide and etoposide plus vincristine, doxorubicin, and cyclophosphamide for newly diagnosed Ewing's sarcoma family of tumors. Cancer. 1996;78(4):901-11. [pmid: 8756388]. Rec#: 44450 Reprint: exc nrp
White L, Kellie S, Gray E, Toogood I, Waters K, Lockwood L, Macfarlane S, Johnston H. Postoperative chemotherapy in children less than 4 years of age with malignant brain tumors: promising initial response to a VETOPEC-based regimen. A Study of the Australian and New Zealand Children's Cancer Study Group (ANZCCSG). J Pediatr Hematol Oncol. 1998;20(2):125-30. [pmid: 9544162]. Rec#: 74620 Reprint: exc nrs
White NH, Sun W, Cleary PA, Danis RP, Davis MD, Hainsworth DP, Hubbard LD, Lachin JM, Nathan DM. Prolonged effect of intensive therapy on the risk of retinopathy complications in patients with type 1 diabetes mellitus: 10 years after the Diabetes Control and Complications Trial. Arch Ophthalmol. 2008;126(12):1707-15. [pmid: 19064853]. Rec#: 61750 Reprint: exc nrp
Wiegering V, Morbach H, Dick A, Girschick H. Crohn's disease during etanercept therapy in juvenile idiopathic arthritis: a case report and review of the literature. Rheumatol Int. 2010;30:801-804. [pmid: 19506877]. Rec#: Reprint: exc nro
Wiegering V, Morbach H, Dick A, Girschick HJ. Crohn's disease during etanercept therapy in juvenile idiopathic arthritis: a case report and review of the literature. Rheumatol Int. 2010;30(6):801-4. [pmid: 19506877]. Rec#: 77120 Reprint: exc nro
Willi SM. How low can we go…safely?: factors affecting intensive diabetes management. J Pediatr. 2006;149(2):154-6. [pmid: 16887424]. Rec#: 62020 Reprint: exc com
Willi SM, Cooke K, Goldwein J, August CS, Olshan JS, Moshang T Jr. Growth in children after bone marrow transplantation for advanced neuroblastoma compared with growth after transplantation for leukemia or aplastic anemia. J Pediatr. 1992;120(5):726-32. [pmid: 1578307]. Rec#: 25090 Reprint: EXC YEAR
Witt V, Fritsch G, Peters C, Matthes-Martin S, Ladenstein R, Gadner H. Resolution of early cytomegalovirus (CMV) infection after leukocyte transfusion therapy from a CMV seropositive donor. Bone Marrow Transplant. 1998;22(3):289-92. [pmid: 9720745]. Rec#: 17780 Reprint: exc nri
Wolden SL, Anderson JR, Crist WM, Breneman JC, Wharam MD Jr, Wiener ES, Qualman SJ, Donaldson SS. Indications for radiotherapy and chemotherapy after complete resection in rhabdomyosarcoma: A report from the Intergroup Rhabdomyosarcoma Studies I to III. J Clin Oncol. 1999;17(11):3468-75. [pmid: 10550144]. Rec#: 48010 Reprint: exc nrd
Wolden SL, Gollamudi SV, Kushner BH, LaQuaglia M, Kramer K, Rosen N, Abramson S, Cheung NV. Local control with multimodality therapy for stage 4 neuroblastoma. Int J Radiat Oncol Biol Phys. 2000;46(4):969-74. [pmid: 10705019]. Rec#: 15550 Reprint: exc nri
Wong KF, Hui PK, Chan JK, Chan YW, Ha SY. The acute lupus hemophagocytic syndrome. Ann Intern Med. 1991;114(5):387-90. [pmid: 1992881]. Rec#: 26310 Reprint: EXC YEAR
Wong MS, Chan GC, Ha SY, Lau YL. Clinical characteristics of chronic idiopathic thrombocytopenia in Chinese children. J Pediatr Hematol Oncol. 2002;24(8):648-52. [pmid: 12439037]. Rec#: 11370 Reprint: exc nro
Worcester HD, Vasef MA. Therapy-related acute myeloid leukemia with 11q23 abnormality coexisting with refractory metastatic Ewing sarcoma: report of a case and review of the literature. Pediatr Dev Pathol. 2010;13(1):50-4. [pmid: 19925255]. Rec#: 42710 Reprint: exc cr
Worgall S, Sondhi D, Hackett NR, Kosofsky B, Kekatpure MV, Neyzi N, Dyke JP, Ballon D, Heier L, Greenwald BM, Christos P, Mazumdar M, Souweidane MM, Kaplitt MG, Crystal RG. Treatment of late infantile neuronal ceroid lipofuscinosis by CNS administration of a serotype 2 adeno-associated virus expressing CLN2 cDNA. Hum Gene Ther. 2008;19(5):463-74. [pmid: 18473686]. Rec#: 56820 Reprint: exc nri
Wraith JE, Baumgartner MR, Bembi B, Covanis A, Levade T, Mengel E, Pineda M, Sedel F, Topcu M, Vanier MT, Widner H, Wijburg FA, Patterson MC. Recommendations on the diagnosis and management of Niemann-Pick disease type C. Mol Genet Metab. 2009;98(1-2):152-65. [pmid: 19647672]. Rec#: 56570 Reprint: exc gui
Wraith JE, Tylki-Szymanska A, Guffon N, Lien YH, Tsimaratos M, Vellodi A, Germain DP. Safety and efficacy of enzyme replacement therapy with agalsidase beta: an international, open-label study in pediatric patients with Fabry disease. J Pediatr. 2008;152(4):563-70. 570.e1. [pmid: 18346516]. Rec#: 56850 Reprint: exc nrc
Wraith JE, Vecchio D, Jacklin E, Abel L, Chadha-Boreham H, Luzy C, Giorgino R, Patterson MC. Miglustat in adult and juvenile patients with Niemann-Pick disease type C: long-term data from a clinical trial. Mol Genet Metab. 2010;99(4):351-7. [pmid: 20045366]. Rec#: 56450 Reprint: EXC DUP
Wrobel G, Dobaczewski G, Patkowski D, Sokol A, Grotthus E. Experiences with recombinant activated factor VII in the treatment of severe refractory thrombocytopenia. Pediatr Blood Cancer. 2006;47(5 Suppl):729-30. [pmid: 16933258]. Rec#: 5120 Reprint: exc nri
Wuhl E, Haffner D, Gretz N, Offner G, van't Hoff WG, Broyer M, Mehls O. Treatment with recombinant human growth hormone in short children with nephropathic cystinosis: no evidence for increased deterioration rate of renal function.The European Study Group on Growth Hormone Treatment in Short Children with Nephropathic Cystinosis. Pediatr Res. 1998;43(4 Pt 1):484-8. [pmid: 9545002]. Rec#: 58130 Reprint: exc nrc
Wuhl E, Haffner D, Offner G, Broyer M, van't Hoff W, Mehls O. Long-term treatment with growth hormone in short children with nephropathic cystinosis. J Pediatr. 2001;138(6):880-7. [pmid: 11391333]. Rec#: 57820 Reprint: exc nrc
Wulffraat M, de Kleer I, Brinkman D, ten Cate R, van der Net JJ, Rijkers GT, Kuis W. Autologous stem cell transplantation for refractory juvenile idiopathic artrhitis: current results and perspectives. Transplant Proc. 2002;34(7):2925-6. [pmid: 12431659]. Rec#: 11430 Reprint: exc data in rec 8350
Wulffraat N, van Royen A, Bierings M, Vossen J, Kuis W. Autologous haemopoietic stem-cell transplantation in four patients with refractory juvenile chronic arthritis. Lancet. 1999;353(9152):550-3. [pmid: 10028984]. Rec#: 17200 Reprint: exc same pt as in rec 8350
Wulffraat NM, Brinkman D, Ferster A, Opperman J, ten Cate R, Wedderburn L, Foster H, Abinun M, Prieur AM, Horneff G, Zintl F, de Kleer I, Kuis W. Long-term follow-up of autologous stem cell transplantation for refractory juvenile idiopathic arthritis. Bone Marrow Transplant. Suppl 1. 2003;32:S61-4. [pmid: 12931245]. Rec#: 9990 Reprint: exc nra
Wulffraat NM, de Kleer IM, Prakken BJ, Kuis W. Stem cell transplantation for autoimmune disorders. Refractory juvenile idiopathic arthritis. Best Pract Res Clin Haematol. 2004;17(2):277-89. [pmid: 15302340]. Rec#: 8510 Reprint: exc same pts as in rec 8350
Wulffraat NM, Haas PJ, Frosch M, De Kleer IM, Vogl T, Brinkman DM, Quartier P, Roth J, Kuis W. Myeloid related protein 8 and 14 secretion reflects phagocyte activation and correlates with disease activity in juvenile idiopathic arthritis treated with autologous stem cell transplantation. Ann Rheum Dis. 2003;62(3):236-41. [pmid: 12594109]. Rec#: 10940 Reprint: exc nro
Wulffraat NM, Kuis W. Autologous stem cell transplantation: a possible treatment for refractory juvenile chronic arthritis?. Rheumatology (Oxford). 1999;38(8):764-6. [pmid: 10501430]. Rec#: 16280 Reprint: exc same as rec 17200
Wulffraat NM, Kuis W, Petty R. Addendum: proposed guidelines for autologous stem cell transplantation in juvenile chronic arthritis. Paediatric Rheumatology Workshop. Rheumatology (Oxford). 1999;38(8):777-8. [pmid: 10501434]. Rec#: 16260 Reprint: exc npd
Wulffraat NM, Sanders LA, Kuis W. Autologous hemopoietic stem-cell transplantation for children with refractory autoimmune disease. Curr Rheumatol Rep. 2000;2(4):316-23. [pmid: 11123077]. Rec#: 14340 Reprint: exc pt reported in rec 8350
Yabe H, Inoue H, Matsumoto M, Hamanoue S, Hiroi A, Koike T, Sako M, Fujiwara M, Ueda Y, Maruya E, Saji H, Kato S, Yabe M. Unmanipulated HLA-haploidentical bone marrow transplantation for the treatment of fatal, nonmalignant diseases in children and adolescents. Int J Hematol. 2004;80(1):78-82. [pmid: 15293574]. Rec#: 8530 Reprint: exc cr nrs
Yamada K, Sugiura H, Takahashi M. Single center experience of treatment of Ewing's family of tumors in Japan. J Orthop Sci. 2006;11(1):34-41. [pmid: 16437346]. Rec#: 6120 Reprint: exc nrp
Yamada K, Takahashi M, Ogura M, Kagami Y, Taji H, Kamiya Y, Sugiura H, Morishima Y. High-dose chemotherapy and autologous peripheral blood stem cell transfusion for adult and adolescent patients with small round cell sarcomas. Bone Marrow Transplant. 2007;39(8):471-6. [pmid: 17334381]. Rec#: 4220 Reprint: exc nrp
Yamamori I, Kanie T, Maeda N, Kodera Y, Matsuyama T, Hasegawa H. Appearance of thyroid stimulating and blocking immunoglobulins after bone marrow transplantation: presentation of two contrasting cases. Endocr J. 2004;51(4):439-43. [pmid: 15351801]. Rec#: 8370 Reprint: EXC NRD NRO
Yanai T, Okazaki T, Yamataka A, Fujita H, Saito M, Lane G, Yamashiro Y, Miyano T. A rare case of bilateral stage IV adrenal neuroblastoma with multiple skin metastases in a neonate: diagnosis, management, and outcome. J Pediatr Surg. 2004;39(12):1782-3. [pmid: 15616928]. Rec#: 7870 Reprint: exc nri
Yang SH, Kim MK, Lee TK, Lee KS, Jeun SS, Park CK, Kang JK, Kim MC, Hong YK. Temozolomide chemotherapy in patients with recurrent malignant gliomas. J Korean Med Sci. 2006;21(4):739-44. [pmid: 16891823]. Rec#: 54880 Reprint: exc nrp
Yang WK, Fu LS, Lan JL, Shen GH, Chou G, Tseng CF, Chi CS. Mycobacterium avium complex-associated hemophagocytic syndrome in systemic lupus erythematosus patient: report of one case. Lupus. 2003;12(4):312-6. [pmid: 12729056]. Rec#: 10600 Reprint: exc nro
Yanik GA, Levine JE, Matthay KK, Sisson JC, Shulkin BL, Shapiro B, Hubers D, Spalding S, Braun T, Ferrara JL, Hutchinson RJ. Pilot study of iodine-131-metaiodobenzylguanidine in combination with myeloablative chemotherapy and autologous stem-cell support for the treatment of neuroblastoma. J Clin Oncol. 2002;20(8):2142-9. [pmid: 11956276]. Rec#: 12390 Reprint: exc nri
Yano S, Hida K, Kobayashi H, Iwasaki Y. Successful multimodal therapies for a primary atypical teratoid/rhabdoid tumor in the cervical spine. Pediatr Neurosurg. 2008;44(5):406-13. [pmid: 18703889]. Rec#: 52020 Reprint: EXC NRI
Yarali N, Fisgin T, Kara A, Duru F. Successful management of severe chronic autoimmune hemolytic anemia with low dose cyclosporine and prednisone in an infant. Turk J Pediatr. 2003;45(4):335-7. [pmid: 14768800]. Rec#: 78060 Reprint: exc nri
Yasuda K, Taguchi H, Sawamura Y, Ikeda J, Aoyama H, Fujieda K, Ishii N, Kashiwamura M, Iwasaki Y, Shirato H. Low-dose craniospinal irradiation and ifosfamide, cisplatin and etoposide for non-metastatic embryonal tumors in the central nervous system. Jpn J Clin Oncol. 2008;38(7):486-92. [pmid: 18573848]. Rec#: 52040 Reprint: EXC NRI
Yeung AH, Cowan MJ, Horn B, Rosbe KW. Airway management in children with mucopolysaccharidoses. Arch Otolaryngol Head Neck Surg. 2009;135(1):73-9. [pmid: 19153310]. Rec#: 700 Reprint: exc nrp
Yock TI, Krailo M, Fryer CJ, Donaldson SS, Miser JS, Chen Z, Bernstein M, Laurie F, Gebhardt MC, Grier HE, Tarbell NJ. Local control in pelvic Ewing sarcoma: analysis from INT-0091--a report from the Children's Oncology Group. J Clin Oncol. 2006;24(24):3838-43. [pmid: 16921035]. Rec#: 43240 Reprint: exc nrp
Yokota S, Mori M, Imagawa T, Murata T, Tomiita M, Itoh Y, Fujikawa S, Takei S. Guidelines on the use of etanercept for juvenile idiopathic arthritis in Japan. Mod Rheumatol. 2010;20(2):107-13. [pmid: 20087751]. Rec#: 77070 Reprint: exc gui
Yokoyama S, Hirakawa H, Soeda J, Ueno S, Tajima T, Mitomi T, Yabe H, Yabe M, Kato S. The strategy to treat disseminated neuroblastoma utilizing bone marrow transplantation: what is the surgeon's role?. Surg Today. 1994;24(10):895-9. [pmid: 7894187]. Rec#: 23510 Reprint: EXC YEAR
Yoo KH, Sohn WY, Sung KW, Jung HL, Koo HH, Oh SY, Kang SW. Chemoreduction followed by local therapy and adjuvant chemotherapy for advanced intraocular retinoblastoma: a pilot study in a single center. J Korean Med Sci. 2002;17(6):817-22. [pmid: 12483008]. Rec#: 11220 Reprint: exc nrd
Yoshida H, Kusuki S, Hashii Y, Ohta H, Morio T, Ozono K. Ex vivo-expanded donor CD4(+) lymphocyte infusion against relapsing neuroblastoma: A transient graft-versus-tumor effect. Pediatr Blood Cancer. 2009;52(7):895-7. [pmid: 19191346]. Rec#: 600 Reprint: exc nri
Young E, Chatterton C, Vellodi A, Winchester B. Plasma chitotriosidase activity in Gaucher disease patients who have been treated either by bone marrow transplantation or by enzyme replacement therapy with alglucerase. J Inherit Metab Dis. 1997;20(4):595-602. [pmid: 9266398]. Rec#: 19070 Reprint: exc nro
Yung WK, Kyritsis AP, Gleason MJ, Levin VA. Treatment of recurrent malignant gliomas with high-dose 13-cis-retinoic acid. Clin Cancer Res. 1996;2(12):1931-5. [pmid: 9816151]. Rec#: 56290 Reprint: exc nrp
Zacharoulis S, Ji L, Pollack IF, Duffner P, Geyer R, Grill J, Schild S, Jaing TH, Massimino M, Finlay J, Sposto R. Metastatic ependymoma: a multi-institutional retrospective analysis of prognostic factors. Pediatr Blood Cancer. 2008;50(2):231-5. [pmid: 17610266]. Rec#: 73780 Reprint: exc npd
Zage PE, Kletzel M, Murray K, Marcus R, Castleberry R, Zhang Y, London WB, Kretschmar C. Outcomes of the POG 9340/9341/9342 trials for children with high-risk neuroblastoma: a report from the Children's Oncology Group. Pediatr Blood Cancer. 2008;51(6):747-53. [pmid: 18704922]. Rec#: 1520 Reprint: exc nri
Zeng HS, Xiong XY, Wei YD, Wang HW, Luo XP. Macrophage activation syndrome in 13 children with systemic-onset juvenile idiopathic arthritis. World J Pediatr. 2008;4(2):97-101. [pmid: 18661762]. Rec#: 1580 Reprint: exc nro
Zhan H, Sinclair J, Adams S, Cale CM, Murch S, Perroni L, Davies G, Amrolia P, Qasim W. Immune reconstitution and recovery of FOXP3 (forkhead box P3)-expressing T cells after transplantation for IPEX (immune dysregulation, polyendocrinopathy, enteropathy, X-linked) syndrome. Pediatrics. 2008;121(4):e998-1002. [pmid: 18316354]. Rec#: 2290 Reprint: exc nrp
Zheng JJ, Chu XQ, Shi XH, Zhou CL, Seng BW. Efficacy and safety of azathioprine maintenance therapy in a group of Crohn's disease patients in China. J Dig Dis. 2008;9(2):84-8. [pmid: 18419641]. Rec#: 2120 Reprint: exc nrp
Zhou YM, Huang ZQ, Hu MH, Zhou SH, Huang T, Xu Y, Lu JH, Gan XF, Zhu WW. Clinical study on the effect of Shengxueling on idiopathic thrombocytopenic purpura. Chin J Integr Med. 2005;11(1):60-4. [pmid: 15975312]. Rec#: 7070 Reprint: exc nri
Ziegler DS, Cohn RJ, McCowage G, Alvaro F, Oswald C, Mrongovius R, White L. Efficacy of vincristine and etoposide with escalating cyclophosphamide in poor-prognosis pediatric brain tumors. Neuro Oncol. 2006;8(1):53-9. [pmid: 16443948]. Rec#: 52560 Reprint: exc few
Zimmerman MA, Goumnerova LC, Proctor M, Scott RM, Marcus K, Pomeroy SL, Turner CD, Chi SN, Chordas C, Kieran MW. Continuous remission of newly diagnosed and relapsed central nervous system atypical teratoid/rhabdoid tumor. J Neurooncol. 2005;72(1):77-84. [pmid: 15803379]. Rec#: 7460 Reprint: EXC NRI
Zoubek A, Holzinger B, Mann G, Peters C, Emminger W, Perneczky-Hintringer E, Gadner H, Mostbeck G, Horcher E, Dobrowsky W. High-dose cyclophosphamide, adriamycin, and vincristine (HD-CAV) in children with recurrent solid tumor. Pediatr Hematol Oncol. 1994;11(6):613-23. [pmid: 7857784]. Rec#: 22580 Reprint: EXC YEAR
Zucker JM, Philip T, Bernard JL, Michon J, Bouffet E, Gentet JC, Lopez M, Coze C, Philip I. Single or double consolidation treatment according to remission status after initial therapy in metastatic neuroblastoma: first results of LMCE 3 study in 40 patients. Bone Marrow Transplant. Suppl 2. 1991;7:91. [pmid: 1878739]. Rec#: 26610 Reprint: EXC YEAR
Zulian F, Balzarin M, Falcini F, Martini G, Alessio M, Cimaz R, Cimino L, Zannin ME. Abatacept for severe anti-tumor necrosis factor alpha refractory juvenile idiopathic arthritis-related uveitis. Arthritis Care Res (Hoboken). 2010;62(6):821-5. [pmid: 20191477]. Rec#: 40820 Reprint: exc nrc

## Excluded Studies: August 2011 Update

Abboud I, Porcher R, Robin M, de Latour RP, Glotz D, Socie G, Peraldi MN. Chronic kidney dysfunction in patients alive without relapse 2 years after allogeneic hematopoietic stem cell transplantation. Biol Blood Marrow Transplant. 2009;15:1251-7. [pmid: 19747632]. Reprint: exc nrp
Abdel-Haq N, Savasan S, Davis M, Asmar BI, Painter T, Salimnia H. Asaia lannaensis bloodstream infection in a child with cancer and bone marrow transplantation. J. Med. Microbiol. 2009;58:974-976. [pmid: 19502367]. Reprint: exc nro
Abinun M, Pieniazek P. Successful haematopoietic stem cell transplantation for osteopetrosis due to TCRIG1 mutation. Arch Dis Child. 2010;95:984. [pmid: 20870624]. Reprint: exc nrs
Abinun M, Flood TJ, Cant AJ, Veys P, Gennery AR, Foster HE, Friswell M, Baildam E, Davidson J, Southwood TR, Livermore P, Wedderburn LR. Autologous T cell depleted haematopoietic stem cell transplantation in children with severe juvenile idiopathic arthritis in the UK (2000-2007). Mol Immunol. 2009;47:46-51. [pmid: 19203795]. Reprint: exc nrp
Aliabadi H, Reynolds R, Powers CJ, Grant G, Fuchs H, Kurtzberg J. Clinical outcome of cerebrospinal fluid shunting for communicating hydrocephalus in mucopolysaccharidoses I, II, and III: a retrospective analysis of 13 patients. Neurosurgery. 2010;67:1476-81. [pmid: 21107178]. discussion 1481-2 Reprint: exc nro
Amend KL, Turnbull B, Foskett N, Napalkov P, Kurth T, Seeger J. Incidence of progressive multifocal leukoencephalopathy in patients without HIV. Neurology. 2010;75:1326-32. [pmid: 20938025]. Reprint: exc nrd
Andion M, Molina B, Gonzalez-Vicent M, Alonso L, Hernandez C, Lassaletta A, Lopez-Ibor B, Villa M, Diaz MA. High-dose busulfan and cyclophosphamide as a conditioning regimen for autologous peripheral blood stem cell transplantation in childhood non-Hodgkin lymphoma patients: a long-term follow-up study. J Pediatr Hematol Oncol. 2011;33:e89-91. [pmid: 21358341]. Reprint: exc nhl nro
Araki Y, Matsuyama Y, Kobayashi Y, Toyokawa S, Inoue K, Suzuki S, Makimoto A. Secondary neoplasms after retinoblastoma treatment: Retrospective cohort study of 754 patients in Japan. Japanese Journal of Clinical Oncology. 2011;41:373-379. [pmid: 21051531]. Reprint: exc nrt
Araya K, Sakai N, Mohri I, Kagitani-Shimono K, Okinaga T, Hashii Y, Ohta H, Nakamichi I, Aozasa K, Taniike M, Ozono K. Localized donor cells in brain of a Hunter disease patient after cord blood stem cell transplantation. Mol Genet Metab. 2009;98:255-63. [pmid: 19556155]. Reprint: exc nrs
Asano T, Kogawa K, Morimoto A, Ishida Y, Suzuki N, Ohga S, Kudo K, Ohta S, Wakiguchi H, Tabuchi K, Kato S, Ishii E. Hemophagocytic lymphohistiocytosis after hematopoietic stem cell transplantation in children: Nationwide survey of Japan. Pediatric Blood and Cancer. 2011;56:689. [pmid: 21298766]. Reprint: exc nrs
Bansal S, Ambulkar I, Karmarkar S, Shende M, Advani S. Prognostic factors responsible for outcome in Hodgkin lymphoma-analysis from a single centre in India. Pediatric Blood and Cance. 2011;56:885. Reprint: exc nrs
Bellaoui N, Lahsoune M, Nourichafi N, Majd A, Mifdal H, Benchemsi N. Stem cell transplantation in Morocco: Report of 87 cases: Greffe de cellules souches hematopoietiques au Maroc : a propos de 87 cas. Transfus. Clin. Biol. 2010;17:63-65. [pmid: 20674439]. Reprint: exc fla
Ben Turkia H, Riahi I, Azzouz H, Ladab S, Cherif W, Ben Chehida A, Abdelmoula MS, Caillaud C, Chemli J, Abdelhak S, Tebib N, Ben Dridi MF. [Phenotype and mutational spectrum in Tunisian pediatric gaucher disease]. Tunis Med. 2010;88:158-62. [pmid: 20415187]. Reprint: exc fla
Bensimhon P, Villablanca JG, Sender LS, Matthay KK, Park JR, Seeger R, London WB, Yap JS, Kreissman SG. Peripheral blood stem cell support for multiple cycles of dose intensive induction therapy is feasible with little risk of tumor contamination in advanced stage neuroblastoma: a report from the Childrens Oncology Group. Pediatr Blood Cancer. 2010;54:596-602. [pmid: 20049927]. Reprint: exc nrs
Bergeron A, Bengoufa D, Feuillet S, Meignin V, De Latour RP, Rybojad M, Gossot D, Azoulay E, Socie G, Tazi A. The spectrum of lung involvement in collagen vascular-like diseases following allogeneic hematopoietic stem cell transplantation: Report of 6 cases and review of the literature. Medicine. 2011;90:146-157. [pmid: 21358437]. Reprint: exc nrp
Bisogno G, Ferrari A, Prete A, Messina C, Basso E, Cecchetto G, Indolfi P, Scarzello G, D'Angelo P, De Sio L, Di Cataldo A, Carli M. Sequential high-dose chemotherapy for children with metastatic rhabdomyosarcoma. Eur J Cancer. 2009;45:3035-41. [pmid: 19783136]. Reprint: exc nrs
Blaes AH, Cavert WP, Morrison VA. Malassezia: Is it a pulmonary pathogen in the stem cell transplant population?. Transplant Infect Dis. 2009;11:313-317. Reprint: exc nrd
Bleich D. Umbilical cord blood and type 1 diabetes: A road ahead or dead end?. Diabetes Care. 2009;32:2138-9. [pmid: 19875610]. Reprint: exc edt
Bonney DK, O'Meara A, Shabani A, Imrie J, Bigger BW, Jones S, Wraith JE, Wynn RF. Successful allogeneic bone marrow transplant for Niemann-Pick disease type C2 is likely to be associated with a severe ‘graft versus substrate’ effect. J Inherit Metab Dis. 2010. #volume#:#pages# Reprint: exc nrs
Boztug K. Early-onset inflammatory bowel disease caused by loss-of-function mutations in the IL10 receptor genes. Hum. Gene Ther. 2009;20:1399. Reprint: exc nrd
Bunin N, Guzikowski V, Rand ER, Goldfarb S, Baluarte J, Meyers K, Olthoff KM. Solid organ transplants following hematopoietic stem cell transplant in children. Pediatr Transplant. 2010;14:1030-5. [pmid: 20846242]. Reprint: exc nrs
Butturini AM, Jacob M, Aguajo J, Vander-Walde NA, Villablanca J, Jubran R, Erdreich-Epstein A, Marachelian A, Dhall G, Finlay JL. High-dose chemotherapy and autologous hematopoietic progenitor cell rescue in children with recurrent medulloblastoma and supratentorial primitive neuroectodermal tumors: The impact of prior radiotherapy on outcome. Cancer. 2009;115:2956-2963. [pmid: 19402050]. Reprint: exc nrd
Cai JY, Tang JY, Pan C, Xu M, Xue HL, Zhou M, Dong L, Ye QD, Jiang H, Shen SH, Chen J. Results of RS-99 protocol for childhood solid tumors. World J Pediatr. 2010;6:43-9. [pmid: 20143210]. Reprint: exc nrs
Cakir FB, Ozulker T, Ozturk G. ASHAP: An effective salvage therapy for refractory Hodgkin lymphoma. Pediatric Blood and Cancer. 2011;56:890. Reprint: exc nrs
Capitini CM, Derdak J, Hughes MS, Love CP, Baird K, MacKall CL, Fry TJ. Unusual sites of extraskeletal metastases of ewing sarcoma after allogeneic hematopoietic stem cell transplantation. J. Pediatr. Hematol. Oncol. 2009;31:142-144. [pmid: 19194203]. Reprint: exc nrp
Capitini CM, Derdak J, Hughes MS, Love CP, Baird K, MacKall CL, Fry TJ. Unusual sites of extraskeletal metastases of ewing sarcoma after allogeneic hematopoietic stem cell transplantation. J. Pediatr. Hematol. Oncol. 2009;31:142-144. [pmid: 19194203]. Reprint: exc nrp
Cesaro S, Marsh J, Tridello G, Rovo A, Maury S, Montante B, Masszi T, Van Lint MT, Afanasyev B, Iriondo Atienza A, Bierings M, Carbone C, Doubek M, Lanino E, Sarhan M, Risitano A, Steinerova K, Wahlin A, Pegoraro A, Passweg J. Retrospective survey on the prevalence and outcome of prior autoimmune diseases in patients with aplastic anemia reported to the registry of the European group for blood and marrow transplantation. Acta Haematol. 2010;124:19-22. [pmid: 20606411]. Reprint: exc nrd
Chantada GL, Fandino AC, Guitter MR, Raslawski EC, Dominguez JL, Manzitti J, de Davila MT, Zubizarreta P, Scopinaro M. Results of a prospective study for the treatment of unilateral retinoblastoma. Pediatr Blood Cancer. 2010;55:60-6. [pmid: 20486172]. Reprint: exc nrs
Chen R, Palmer MJ, Popplewell L, Shen J, Smith E, Delioukina M, Kogut N, Rosenthal J, Forman S, Nademanee A. Reduced intensity allogeneic hematopoietic cell transplantation can induce durable remission in heavily pretreated relapsed Hodgkin lymphoma. Annals of Hematology. 2011;90:803-808. [pmid: 21210120]. Reprint: exc nri
Chintagumpala M, Hassall T, Palmer S, Ashley D, Wallace D, Kasow K, Merchant TE, Krasin MJ, Dauser R, Boop F, Krance R, Woo S, Cheuk R, Lau C, Gilbertson R, Gajjar A. A pilot study of risk-adapted radiotherapy and chemotherapy in patients with supratentorial PNET. Neuro-Oncology. 2009;11:33-40. [pmid: 18796696]. Repri/nt: exc nrs
Cho BS, Min CK, Kim HJ, Lee S, Kim YJ, Lim JY, Jeong DC, Cho B, Kim HK, Eom KS, Cho SG, Kim DW, Lee JW, Min WS, Kim CC, Chung NG. High levels of B cell activating factor during the peritransplantation period are associated with a reduced incidence of acute graft-versus-host disease following myeloablative allogeneic stem cell transplantation. Biol Blood Marrow Transplant. 2010;16:629-38. [pmid: 19963070]. Reprint: exc nrd
Citak EC, Oguz A, Karadeniz C, Okur A, Akyurek N. Primitive neuroectodermal tumor of the kidney in a child. Pediatr Hematol Oncol. 2009;26:481-6. [pmid: 19863203]. Reprint: exc nri
Ciurea SO, Mulanovich V, Jiang Y, Bassett R, Rondon G, McMannis J, de Lima M, Shpall EJ, Champlin RE. Lymphocyte Recovery Predicts Outcomes in Cord Blood and T Cell-Depleted Haploidentical Stem Cell Transplantation. Biology of Blood and Marrow Transplantation. 2011;17:1169-1175. [pmid: 21126598]. Reprint: exc nrd
Claviez A. Hematopoietic stem-cell transplantation for treatment of children and adolescents with recurring Hodgkin lymphoma. Pediatric Blood and Cancer. 2011;56:891. Reprint: exc nrs
Claviez A, Kluge R, Clauss D, Hasenclever D, Korholz D, Mauz-Korholz C. The impact of FDG-PET-based response assessment for outcome of children and adolescents with relapsed or progressive Hodgkin lymphoma undergoing autologous stem-cell transplantation. Pediatric Blood and Cancer. 2011;56:882. Reprint: exc nrs
Cohen A. Hematopoietic stem cell transplantation and diabetes mellitus: The paradox between treatment and cause of a disease. Pediatr Transplant. 2009;13:3-6. [pmid: 18785911]. Reprint: exc nrs
Cooper JD. Therapies for the neuronal ceroid lipofuscinoses. Int. J. Clin. Pharmacol. Ther. 2010;48:S31-S32.
Cyranoski D. Strange lesions after stem-cell therapy. Nature. 2010;465:997. [pmid: 20577182]. Reprint: exc nrs
Dahl D, Hahn A, Koenecke C, Heuft HG, Dammann E, Stadler M, Buchholz S, Krauter J, Eder M, Sykora KW, Klein C, Ganser A, Sauer M. Prolonged isolated red blood cell transfusion requirement after allogeneic blood stem cell transplantation: identification of patients at risk. Transfusion. 2010;50:649-55. [pmid: 19929861]. Reprint: exc nrd
Daugaard G, Skoneczna I, Aass N, De Wit R, De Santis M, Dumez H, Marreaud S, Collette L, Lluch JR, Bokemeyer C, Schmoll HJ. A randomized phase III study comparing standard dose BEP with sequential high-dose cisplatin, etoposide, and ifosfamide (VIP) plus stem-cell support in males with poor-prognosis germ-cell cancer. An intergroup study of EORTC, GTCSG, and Grupo Germinal (EORTC 30974). Ann Oncol. 2011;22:1054-61. [pmid: 21059637]. Reprint: exc nrp
De Ioris MA, Castellano A, Ilari I, Garganese MC, Natali G, Inserra A, De Vito R, Rava L, De Pasquale MD, Locatelli F, Donfrancesco A, Jenkner A. Short topotecan-based induction regimen in newly diagnosed high-risk neuroblastoma. Eur J Cancer. 2011;47:572-8. [pmid: 21112775]. Reprint: exc nrs
de Pagter PJ, Virgili A, Nacheva E, van Baarle D, Schuurman R, Boelens JJ. Chromosomally integrated human herpesvirus 6: transmission via cord blood-derived unrelated hematopoietic stem cell transplantation. Biol Blood Marrow Transplant. 2010;16:130-2. [pmid: 20053335]. Reprint: exc nrd
Dimaras H, Rushlow D, Halliday W, Doyle JJ, Babyn P, Abella EM, Williams J, Heon E, Gallie BL, Chan HS. Using RB1 mutations to assess minimal residual disease in metastatic retinoblastoma. Transla Res. 2010;156:91-7. Reprint: exc nrs
Dodero A, Crocchiolo R, Patriarca F, Miceli R, Castagna L, Ciceri F, Bramanti S, Frungillo N, Milani R, Crippa F, Fallanca F, Englaro E, Corradini P. Pretransplantation [18-F]fluorodeoxyglucose positron emission tomography scan predicts outcome in patients with recurrent Hodgkin lymphoma or aggressive non-Hodgkin lymphoma undergoing reduced-intensity conditioning followed by allogeneic stem cell transplantation. Cancer. 2010;116:5001-11. [pmid: 20665491]. Reprint: exc nri
Donker AE, Hoogerbrugge PM, Mavinkurve-Groothuis AMC, van de Kar NCAJ, Boetes C, Hulsbergen-van de Kaa CA, Groot-Loonen JJ. Metastatic rhabodmyosarcoma cured after chemotherapy and allogenic SCT. Bone Marrow Transplant. 2009;43:179-180. [pmid: 18762761]. Reprint: exc nri
Dunkel IJ, Gardner SL, Garvin JH Jr, Goldman S, Shi W, Finlay LJ. High-dose carboplatin, thiotepa, and etoposide with autologous stem cell rescue for patients with previously irradiated recurrent medulloblastoma. Neuro Oncol. 2010;12:297-303. [pmid: 20167818]. Reprint: exc nrd
Dunkel IJ, Jubran RF, Gururangan S, Chantada GL, Finlay JL, Goldman S, Khakoo Y, O'Brien JM, Orjuela M, Rodriguez-Galindo C, Souweidane MM, Abramson HD. Trilateral retinoblastoma: potentially curable with intensive chemotherapy. Pediatr Blood Cancer. 2010;54:384-7. [pmid: 19908299]. Reprint: exc nrs
Dutra AP, Lima ER, Fonseca KC. Childhood Hodgkin lymphoma: Experience in a single institution in Brazil. Pediatric Blood and Cancer. 2011;56:886. Reprint: exc nrs
Eleutherakis-Papaiakovou E, Kostis E, Migkou M, Christoulas D, Terpos E, Gavriatopoulou M, Roussou E, Bournakis E, Kastritis E, Efstathiou E, Dimopoulos MA, Papadimitriou CA. Prophylactic antibiotics for the prevention of neutropenic fever in patients undergoing autologous stem-cell transplantation: results of a single institution, randomized phase 2 trial. #journal#. 2010;85:863-7. Reprint: exc nrp
Farge D, Labopin M, Tyndall A, Fassas A, Mancardi GL, Van Laar J, Ouyang J, Kozak T, Moore J, Kotter I, Chesnel V, Marmont A, Gratwohl A, Saccardi R. Autologous hematopoietic stem cell transplantation for autoimmune diseases: an observational study on 12 years' experience from the European Group for Blood and Marrow Transplantation Working Party on Autoimmune Diseases. Haematologica. 2010;95:284-92. [pmid: 19773265]. Reprint: exc nrp
Ferrari S, Hall SK, Luksch R, Tienghi A, Wiebe T, Fagioli F, Alvegard TA, del Prever AB, Tamburini A, Alberghini M, Gandola L, Mercuri M, Capanna R, Mapelli S, Prete A, Carli M, Picci P, Barbieri E, Bacci G, Smeland S. Nonmetastatic Ewing family tumors: High-dose chemotherapy with stem cell rescue in poor responder patients. results of the Italian Sarcoma Group/Scandinavian Sarcoma Group III protocol. Annals of Oncology. 2011;22:1221-1227. [pmid: 21059639]. Reprint: exc nrp
Ferrari S, Sundby Hall K, Luksch R, Tienghi A, Wiebe T, Fagioli F, Alvegard TA, Brach Del Prever A, Tamburini A, Alberghini M, Gandola L, Mercuri M, Capanna R, Mapelli S, Prete A, Carli M, Picci P, Barbieri E, Bacci G, Smeland S. Nonmetastatic Ewing family tumors: high-dose chemotherapy with stem cell rescue in poor responder patients. Results of the Italian Sarcoma Group/Scandinavian Sarcoma Group III protocol. Ann Oncol. 2011;22:1221-7. [pmid: 21059639]. Reprint: exc nrs
Fesslova V, Corti P, Sersale G, Rovelli A, Russo P, Mannarino S, Butera G, Parini R. The natural course and the impact of therapies of cardiac involvement in the mucopolysaccharidoses Cardiol. Young. 2009;19:170-178. Reprint: exc nrd
Finkelstein-Shechter T, Gassas A, Mabbott D, Huang A, Bartels U, Tabori U, Laura J, Hawkins C, Taylor M, Bouffet E. Atypical teratoid or rhabdoid tumors: Improved outcome with high-dose chemotherapy. J. Pediatr. Hematol. Oncol. 2010;32:e182-e186. [pmid: 20495479]. Reprint: exc nrs
Flowers MED, Inamoto Y, Carpenter PA, Lee SJ, Kiem HP, Petersdorf EW, Pereira SE, Nash RA, Mielcarek M, Fero ML, Warren EH, Sanders JE, Storb RF, Appelbaum FR, Storer BE, Martin PJ. Comparative analysis of risk factors for acute graft-versus-host disease and for chronic graft-versus-host disease according to National Institutes of Health consensus criteria. Blood. 2011;117:3214-3219. [pmid: 21263156]. Reprint: exc nrp
Fukuoka K, Kaneko T, Akiyama M. Progressive multifocal leukoencephalopathy in a 16-year-old patient with pancytopenia after autologous bone marrow transplantation for relapsed Hodgkin lymphoma. Pediatr Blood Cancer. 2011;56:507-8. [pmid: 21154950]. Reprint: exc nrs
Gajjar A, Pizer B. Role of high-dose chemotherapy for recurrent medulloblastoma and other CNS primitive neuroectodermal tumors. Pediatr Blood Cancer. 2010;54:649-51. [pmid: 20146223]. Reprint: exc nrs
Gassas A, Raiman J, White L, Schechter T, Clarke J, Doyle J. Long-term adaptive functioning outcomes of children with inherited metabolic and genetic diseases treated with hematopoietic stem cell transplantation in a single large pediatric center: parents' perspective. J Pediatr Hematol Oncol. 2011;33:216-20. [pmid: 21336168]. Reprint: exc nrs
Gerber NU, von Hoff K, von Bueren AO, Treulieb W, Warmuth-Metz M, Pietsch T, Soerensen N, Faldum A, Emser A, Schlegel PG, Deinlein F, Kortmann RD, Rutkowski S. Outcome of 11 children with ependymoblastoma treated within the prospective HIT-trials between 1991 and 2006. J Neurooncol. 2011;102:459-69. [pmid: 21308398]. Reprint: exc nri
Ghavamzadeh A, Alimogaddam K, Jahani M, Mousavi SA, Iravani M, Bahar B, Khodabandeh A, Khatami F, Gaffari F, Jalali A. Stem cell transplantation; Iranian experience. Arch. Iran. Med. 2009;12:69-72. [pmid: 19111033]. Reprint: exc nrd
Gilman AL, Jacobsen C, Bunin N, Levine J, Goldman F, Bendel A, Joyce M, Anderson P, Rozans M, Wall DA, Macdonald TJ, Simon S, Kadota RP. Phase I study of tandem high-dose chemotherapy with autologous peripheral blood stem cell rescue for children with recurrent brain tumors: A pediatric blood and marrow transplant consortium study. Pediatric Blood and Cancer. 2011;57:506-513. [pmid: 21744474]. Reprint: exc nrs
Goi K, Inukai T, Honna H, Akahane K, Hirose K, Kuroda I, Hasuda N, Koshizuka K, Takano K, Sugita K. Successful tandem (autologous-cord blood) SCT in advanced neuroblastomas with highly amplified MYCN. Bone Marrow Transplantation. 2011;46:835-839. [pmid: 20697365]. Reprint: exc nri
Gramatges MM, Dvorak CC, Regula DP, Enns GM, Weinberg K, Agarwal R. Pathological evidence of Wolman's disease following hematopoietic stem cell transplantation despite correction of lysosomal acid lipase activity. Bone Marrow Transplant. 2009;44:449-450. [pmid: 19308038]. Reprint: exc nrs
Grodman H, Wolfe L, Kretschmar C. Outcome of patients with recurrent medulloblastoma or central nervous system germinoma treated with low dose continuous intravenous etoposide along with dose-intensive chemotherapy followed by autologous hematopoietic stem cell rescue. Pediatr Blood Cancer. 2009;53:33-36. [pmid: 19326417]. Reprint: exc nrp
Guffon N, Bertrand Y, Forest I, Fouilhoux A, Froissart R. Bone Marrow Transplantation in Children with Hunter Syndrome: Outcome after 7 to 17 Years. J. Pediatr. 2009;154:733-737. [pmid: 19167723]. Reprint: exc nrs
Guinan EC, Hewett EK, Domaney NM, Margossian R. Outcome of hematopoietic stem cell transplant in children with congenital heart disease. Pediatric Transplantation. 2011;15:75-80. [pmid: 20345610]. Reprint: exc nrp
Hackett M, Anover-Sombke S, Ochs HD, Torgerson TR. The short isoform of FOXP3 lacking exon 2 is insufficient to support regulatory T cell development and IPEX disease in humans. Clin Immunol. 2010;135:305. Reprint: exc nrs
Herr AL, Kabbara N, Bonfim CMS, Teira P, Locatelli F, Tiedemann K, Lankester A, Jouet JP, Messina C, Bertrand Y, De Heredia CD, Peters C, Chaves W, Nabhan SK, Ionescu I, Gluckman E, Rocha V. Long-term follow-up and factors influencing outcomes after related HLA-identical cord blood transplantation for patients with malignancies: An analysis on behalf of Eurocord-EBMT. Blood. 2010;116:1849-1856. [pmid: 20538797]. Reprint: exc nrp
Ho J, Lewis V, Guilcher GMT, Stephure DK, Pacaud DL. Endocrine complications following pediatric bone marrow transplantation. Journal of Pediatric Endocrinology and Metabolism. 2011;24:327-332. [pmid: 21823531]. Reprint: exc nrs
Hutton A, Bradwell M, English M, Chapple I. The oral health needs of children after treatment for a solid tumour or lymphoma. Int J Paediatr Dent. 2010;20:15-23. [pmid: 20059589]. Reprint: exc nrd
Inamoto Y, Flowers MED, Lee SJ, Carpenter PA, Warren EH, Deeg HJ, Storb RF, Appelbaum FR, Storer BE, Martin PJ. Influence of immunosuppressive treatment on risk of recurrent malignancy after allogeneic hematopoietic cell transplantation. Blood. 2011;118:456-463. [pmid: 21633087]. Reprint: exc nrp
Ishige-Wada M, Yagasaki H, Kato M, Shichino H, Chin M, Usui H, Owada M, Kitagawa T, Mugishima H. Allogenic hemaopotietic stem cell transplantation for patients with lysosomal and peroxisomal storage diseases: A single institute experiences (Nihon University). Journal of Inherited Metabolic Disease. 2011;34:S217. Reprint: exc nrd
Kahn S, Flowers C, Xu Z, Esiashvili N. Does the addition of involved field radiotherapy to high-dose chemotherapy and stem cell transplantation improve outcomes for patients with relapsed/refractory Hodgkin lymphoma?. International Journal of Radiation Oncology Biology Physics. 2011;81:175-180. Reprint: exc nrp
Kim YJ, Sung KW, Hwang HS, Jung SH, Kim JY, Cho EJ, Lim SJ, Choi YB, Cheuh HW, Lee SH, Yoo KH, Koo HH. Efficacy of itraconazole prophylaxis for autologous stem cell transplantation in children with high-risk solid tumors: A prospective double-blind randomized study. Yonsei Medical Journal. 2011;52:293-300. [pmid: 21319349]. Reprint: exc nro
Konja J, Rajic L, Femenic R, Bilic E, Anicic M. Management of pediatric Hodgkin lymphoma in Croatia. Pediatric Blood and Cancer. 2011;56:883. Reprint: exc nrs
Kopp HG, Wirths S, Faul C, Bethge W, Scheding S, Brugger W, Kanz L, Vogel W. Long-term results after transplantation of CD34+ selected (CellPro) versus unselected peripheral blood progenitor cells (PBPC) from related allogeneic donors. #journal#. 2010;136:1921-7. Reprint: exc nrp
Kubota M, Okuyama N, Hirayama Y, Asami K, Ogawa A, Watanabe A. Mortality and morbidity of patients with neuroblastoma who survived for more than 10 years after treatment--Niigata Tumor Board Study. J Pediatr Surg. 2010;45:673-7. [pmid: 20385269]. Reprint: exc nrs
Kushner BH, Kramer K, Modak S, Cheung NK. High-dose carboplatin-irinotecan-temozolomide: treatment option for neuroblastoma resistant to topotecan. Pediatr Blood Cancer. 2011;56:403-8. [pmid: 21049517]. Reprint: exc nrs
Ladenstein R, Potschger U, Siabalis D, Garaventa A, Bergeron C, Lewis IJ, Stein J, Kohler J, Shaw PJ, Holter W, Pistoia V, Michon J. Dose finding study for the use of subcutaneous recombinant interleukin-2 to augment natural killer cell numbers in an outpatient setting for stage 4 neuroblastoma after megatherapy and autologous stem-cell reinfusion. J Clin Oncol. 2011;29:441-8. [pmid: 21149662]. Reprint: exc nri
Laporte S, Couto-Silva AC, Trabado S, Lemaire P, Brailly-Tabard S, Esperou H, Michon J, Baruchel A, Fischer A, Trivin C, Brauner R. Inhibin B and anti-Mullerian hormone as markers of gonadal function after hematopoietic cell transplantation during childhood. BMC Pediatrics. 2011;11. #pages# Reprint: exc nrp
Laskin BL, Goebel J, Davies SM, Khoury JC, Bleesing JJ, Mehta PA, Filipovich AH, Paff ZN, Lawrence JM, Yin HL, Pinkard SL, Jodele S. Early clinical indicators of transplant-associated thrombotic microangiopathy in pediatric neuroblastoma patients undergoing auto-SCT. Bone Marrow Transplantation. 2011;46:682-689. [pmid: 20697372]. Reprint: exc nri
Lim YJ, Kim HJ, Lee YJ, Seol IJ, Lee YH. Clinical features of encephalopathy in children with cancer requiring cranial magnetic resonance imaging. Pediatric Neurology. 2011;44:433-438. [pmid: 21555054]. Reprint: exc nrp
Luisi FAV, Puty FCB, Alves MTS, Ladeia F, Lederman HM, Schettini ST. Descriptive analysis of the Hodgkin lymphoma patient's survival status after recurrence: A Brazilian experience. Pediatric Blood and Cancer. 2011;56:890. Reprint: exc nrs
Luo XD, Liu QF, Zhang Y, Sun J, Wang GB, Fan ZP, Yi ZS, Ling YW, Wei YQ, Liu XL, Xu B. Nephrotic syndrome after allogeneic hematopoietic stem cell transplantation: Etiology and pathogenesis. Blood Cells, Molecules, and Diseases. 2011;46:182-187. Reprint: exc nrp
Manjila S, Ray A, Hu Y, Cai DX, Cohen ML, Cohen AR. Embryonal tumors with abundant neuropil and true rosettes: 2 illustrative cases and a review of the literature. Neurosurg Focus. 2011;30:E2. [pmid: 21194275]. Reprint: exc nri
Marabelle A, Merlin E, Halle P, Paillard C, Berger M, Tchirkov A, Rousseau R, Leverger G, Piguet C, Stephan JL, Demeocq F, Kanold J. CD34+ immunoselection of autologous grafts for the treatment of high-risk neuroblastoma. Pediatr Blood Cancer. 2011;56:134-42. [pmid: 21058288]. Reprint: exc nri
Masetti R, Biagi C, Kleinschmidt K, Prete A, Baronio F, Colecchia A, Festi D, Pession A. Focal nodular hyperplasia of the liver after intensive treatment for pediatric cancer: Is hematopoietic stem cell transplantation a risk factor?. European Journal of Pediatrics. 2011;170:807-812. [pmid: 21225283]. Reprint: exc nrp
Masetti R, Cazzato S, Prete A, Rondelli R, Di Vincenzo AO, Pession A. Organizing pneumonia primed by high-dose chemotherapy and lung irradiation: Two pediatric cases. Journal of Pediatric Hematology/Oncology. 2011;33:e202-e204. [pmid: 21364470]. Reprint: exc nro
Massimino M, Gandola L, Spreafico F, Biassoni V, Luksch R, Collini P, Solero CN, Simonetti F, Pignoli E, Cefalo G, Poggi G, Modena P, Mariani L, Potepan P, Podda M, Casanova M, Pecori E, Acerno S, Ferrari A, Terenziani M, Meazza C, Polastri D, Ravagnani F, Fossati-Bellani F. No Salvage Using High-Dose Chemotherapy Plus/Minus Reirradiation for Relapsing Previously Irradiated Medulloblastoma. Int. J. Radiat. Oncol. Biol. Phys. 2009;73:1358-1363. [pmid: 19019566]. Reprint: exc nrp
Mazloom A, Zangeneh AH, Paulino AC. Prognostic factors after extraneural metastasis of medulloblastoma. Int J Radiat Oncol Biol Phys. 2010;78:72-8. [pmid: 20133080]. Reprint: exc nrs
Molina B, Alonso L, Gonzalez-Vicent M, Andion M, Hernandez C, Lassaletta A, Cormenzana M, Lopez-Ibor B, Villa M, Molina J, Diaz MA. High-dose busulfan and melphalan as conditioning regimen for autologous peripheral blood progenitor cell transplantation in high-risk neuroblastoma patients. Pediatr Hematol Oncol. 2011;28:115-23. [pmid: 21299340]. Reprint: exc nrs
Moskowitz AJ, Yahalom J, Kewalramani T, Maragulia JC, Vanak M, Zelenetz AD, Moskowitz CH. Pretransplantation functional imaging predicts outcome following autologous stem cell transplantation for relapsed and refractory Hodgkin lymphoma. Blood. 2010;116:4934-7. [pmid: 20733154]. Reprint: exc nrs
Munoz A, Gonzalez-Vicent M, Badell I, Diaz De Heredia C, Martinez A, Maldonado MS. Mycobacterial diseases in pediatric hematopoietic SCT recipients. Bone Marrow Transplantation. 2011;46:766-768. [pmid: 20697370]. Reprint: exc nrd
Naranjo A, Parisi MT, Shulkin BL, London WB, Matthay KK, Kreissman SG, Yanik GA. Comparison of (1)(2)(3)I-metaiodobenzylguanidine (MIBG) and (1)(3)(1)I-MIBG semi-quantitative scores in predicting survival in patients with stage 4 neuroblastoma: a report from the Children's Oncology Group. Pediatr Blood Cancer. 2011;56:1041-5. [pmid: 21328522]. Reprint: exc nri
Neier M, Jin Z, Kleinman C, Baldinger L, Bhatia M, Silver E, Van De Ven C, Morris E, Satwani P, George D, Garvin J, Bradley MB, Schwartz J, Cairo MS. Pericardial effusion post-SCT in pediatric recipients with signs and/or symptoms of cardiac disease. Bone Marrow Transplantation. 2011;46:529-538. [pmid: 20581882]. Reprint: exc nrp
Novik AA, Kuznetsov AN, Melnichenko VY, Fedorenko DA, Kartashov AV, Ionova TI, Kurbatova KA, Gorodokin GI. Reduced intensity conditioning regimen of autologous hematopoietic stem cell transplantation (+/−) mitoxantrone consolidation in multiple sclerosis Abstract No. 372. #journal#. 2010;116. #pages# Reprint: exc nrp
Palmer SL, Reddick WE, Glass JO, Ogg R, Patay Z, Wallace D, Gajjar A. Regional white matter anisotropy and reading ability in patients treated for pediatric embryonal tumors. Brain Imaging Behav. 2010;4:132-140. [pmid: 20502994]. Reprint: exc nrs
Park M, Koh KN, Kim BE, Im HJ, Seo JJ. Clinical features of late onset non-infectious pulmonary complications following pediatric allogeneic hematopoietic stem cell transplantation. Clinical Transplantation. 2011;25:E168-E176. [pmid: 21077955]. Reprint: exc nrp
Peinemann F, Kroger N, Bartel C, Grouven U, Pittler M, Erttmann R, Kulig M. High-dose chemotherapy followed by autologous stem cell transplantation for metastatic rhabdomyosarcoma-a systematic review. PLoS One. 2011;6. #pages# Reprint: exc sr
Polgreen LE, Chahla S, Miller W, Rothman S, Tolar J, Kivisto T, Nascene D, Orchard PJ, Petryk A. Early diagnosis of cerebral X-linked adrenoleukodystrophy in boys with Addison 's disease improves survival and neurological outcomes. European Journal of Pediatrics. 2011;170:1049-1054. [pmid: 21279382]. Reprint: exc nrd
Polgreen LE, Plog M, Schwender JD, Tolar J, Thomas W, Orchard PJ, Miller BS, Petryk A. Short-term growth hormone treatment in children with Hurler syndrome after hematopoietic cell transplantation. Bone Marrow Transplant. 2009;44:279-285. [pmid: 19252529]. Reprint: exc nrp
Reston JT, Uhl S, Treadwell JR, Nash RA, Schoelles K. Autologous hematopoietic cell transplantation for multiple sclerosis: a systematic review. Mult Scler. 2011;17:204-13. [pmid: 20921236]. Reprint: exc sr nrs
Rifkin R, Spitzer G, Orloff G, Mandanas R, McGaughey D, Zhan F, Boehm KA, Asmar L, Beveridge R. Pegfilgrastim appears equivalent to daily dosing of filgrastim to treat neutropenia after autologous peripheral blood stem cell transplantation in patients with non-Hodgkin lymphoma. #journal#. 2010;10:186-91. Reprint: exc nrp
Rodriguez R, Nademanee A, Palmer JM, Parker P, Nakamura R, Snyder D, Pullarkat V, Zain J, Smith E, Sahebi F, Patane K, Senitzer D, Chang k, Forman SJ. Thymoglobulin, CYA and mycophenolate mofetil as GVHD prophylaxis for reduced-intensity unrelated donor hematopoietic cell transplantation: beneficial effect seen on chronic GVHD. #journal#. 2010;45:205-7. Reprint: exc nrp
Rosenfeld A, Kletzel M, Duerst R, Jacobsohn D, Haut P, Weinstein J, Rademaker A, Schaefer C, Evans L, Fouts M, Goldman S. A phase II prospective study of sequential myeloablative chemotherapy with hematopoietic stem cell rescue for the treatment of selected high risk and recurrent central nervous system tumors. J Neurooncol. 2010;97:247-55. [pmid: 19768658]. Reprint: exc nro
Rubin J, Vettenranta K, Vettenranta J, Bierings M, Abrahamsson J, Bekassy AN, Hakansson Y, Frost BM, Arvidson J, Spendilow C, Winiarski J, Gustafsson B. Use of intrathecal chemoprophylaxis in children after SCT and the risk of central nervous system relapse. Bone Marrow Transplant. 2011;46:372-8. [pmid: 20498650]. Reprint: exc nrp
Safonova SA, Tsyearlina EV, Roschina NV, Punanov YA. Late endocrine complications in childhood Hodgkin Lymphoma (HL) survivors. Pediatric Blood and Cancer. 2011;56:893. Reprint: exc nrs
Satwani P, Harrison L, Bhatia M, Bradley MB, Garvin JH, George D, Martin P, Kurtzberg J, Schwartz J, Baxter-Lowe LA, Cairo MS. Myeloablative (MAC) Autologous Stem-Cell Transplantation (AUTOSCT) FOllowed by Reduced Intensity (RIC) Allogeneic Stem-Cell Transplantation (ALLOSCT) in Children, Adolescents, and Young Adults (CAYA) with poor risk Hodgkin Lymphoma (HL): Induction of long-term GVHL effect. Blood and Cancer. 2011;56:890-891. Reprint: exc nrs
Schmitz N, Trumper L, Ziepert M, Nickelsen M, Ho AD, Metzner B, Peter N, Loeffler M, Rosenwald A, Pfreundschuh M. Treatment and prognosis of mature T-cell and NK-cell lymphoma: an analysis of patients with T-cell lymphoma treated in studies of the German High-Grade Non-Hodgkin Lymphoma Study Group. Blood. 2010;116:3418-25. [pmid: 20660290]. Reprint: exc nrd
Seber A, Ginani VC, Gouveia RV, Zecchin VG, Marconcini JF, Villela N, Barros DP, Ribeiro LA, Da Rocha SL, Oliveira-Felix OMW, Simoes AG, Da Silva AG, De Seixas MT, Lederman HM, Petrilli AS, Luisi FAV. Hematopoietic stem-cell transplant for Hodgkin Lymphoma (HL). Pediatric Blood and Cancer. 2011;56:891. Reprint: exc nrs
Shaw PJ, Kan F, Woo Ahn K, Spellman SR, Aljurf M, Ayas M, Burke M, Cairo MS, Chen AR, Davies SM, Frangoul H, Gajewski J, Gale RP, Godder K, Hale GA, Heemskerk MB, Horan J, Kamani N, Kasow KA, Chan KW, Lee SJ, Leung WH, Lewis VA, Miklos D, Oudshoorn M, Petersdorf EW, Ringden O, Sanders J, Schultz KR, Seber A, Setterholm M, Wall DA, Yu L, Pulsipher MA. Outcomes of pediatric bone marrow transplantation for leukemia and myelodysplasia using matched sibling, mismatched related, or matched unrelated donors. Blood. 2010;116:4007-15. [pmid: 20671124]. Reprint: exc nrd
Shing MMK, Zhang Y, Gao Y, Tang J, Shi S, Zheng M, Duan Y, Chian KS, Lu F, Pan C, Jiang S, Ma L, Xu M, Liu A, He X, Tian HC, Lam HC. Multi-center study of childhood Hodgkin lymphoma in China. Pediatric Blood and Cancer. 2011;56:884. Reprint: exc nrs
Simon T, Berthold F, Borkhardt A, Kremens B, De Carolis B, Hero B. Treatment and outcomes of patients with relapsed, high-risk neuroblastoma: results of German trials. Pediatr Blood Cancer. 2011;56:578-83. [pmid: 21298742]. Reprint: exc nri
Stiff PJ, Agovi MA, Antman KH, Blaise D, Camitta BM, Cairo MS, Childs RW, Edwards JR, Gale RP, Hale GA, Lazarus HM, Arora M. High-dose chemotherapy with blood or bone marrow transplants for rhabdomyosarcoma. Biol Blood Marrow Transplant. 2010;16:525-32. [pmid: 19961947]. Reprint: exc nrp
Tang JY, Pan C, Xu M, Xue HL, Chen J, Dong L, Zhou M, Gu LJ, Chen QM. Effect of protocol RS-99 for childhood rhabdomysarcoma. Nat. Med. J.China. 2009;89:121-123. Reprint: exc nrs
Tarella C, Passera R, Magni M, Benedetti F, Rossi A, Gueli A, Patti C, Parvis G, Ciceri F, Gallamini A, Cortelazzo S, Zoli V, Corradini P, Carobbio A, Mule A, Bosa M, Barbui A, Di Nicola M, Sorio D, Caracciolo D, Gianni AM, Rambaldi A. Risk factors for the development of secondary malignancy after high-dose chemotherapy and autograft, with or without rituximab: a 20-year retrospective follow-up study in patients with lymphoma. J Clin Oncol. 2011;29:814-24. [pmid: 21189387]. Reprint: exc nri
Thepot S, Zhou J, Perrot A, Robin M, Xhaard A, de Latour RP, Ades L, Ribaud P, Petropoulou AD, Porcher R, Socie G. The graft-versus-leukemia effect is mainly restricted to NIH-defined chronic graft-versus-host disease after reduced intensity conditioning before allogeneic stem cell transplantation. Leukemia. 2010;24:1852-8. [pmid: 20827288]. Reprint: exc nrs
Tolar J, Eapen M, Orchard PJ, Blazar BR. Acid sphingomyelinase deficiency does not protect from graft-versus-host disease in transplant recipients with Niemann-Pick disease. Blood. 2010;115:434-435. [pmid: 20075175]. Reprint: exc nrs
Tolar J, Petryk A, Khan K, Bjoraker KJ, Jessurun J, Dolan M, Kivisto T, Charnas L, Shapiro EG, Orchard PJ. Long-term metabolic, endocrine, and neuropsychological outcome of hematopoietic cell transplantation for Wolman disease. Bone Marrow Transplant. 2009;43:21-27. [pmid: 18776925]. Reprint: exc nrs
Toledano H, Yahel A, Cohen IJ, Yaniv I, Stein J. Successful mobilization, harvest and transplant of peripheral blood stem cells using AMD3100 and G-CSF following high dose craniospinal irradiation for medulloblastoma in a young child. Pediatr Blood Cancer. 2010;54:613-5. [pmid: 19998469]. Reprint: exc nrd
Torrelo A, Patel S, Colmenero I, Gurbindo D, Lendinez F, Hernandez A, Lopez-Robledillo JC, Dadban A, Requena L, Paller AS. Chronic atypical neutrophilic dermatosis with lipodystrophy and elevated temperature (CANDLE) syndrome. J. Am. Acad. Dermatol. 2010;62:489-495. [pmid: 20159315]. Reprint: exc nrp
Tsuruta T, Aihara Y, Kanno H, Kiyotani C, Maebayashi K, Sakauchi M, Osawa M, Fujii H, Kubo O, Okada Y. High-dose chemotherapy followed by autologous and allogeneic peripheral blood stem cell transplantation for recurrent disseminated trilateral retinoblastoma. Child's Nervous System. 2011;27:1019-1024. Reprint: exc nrs
Turbeville S, Nicely H, Rizzo JD, Pedersen TL, Orchard PJ, Horwitz ME, Horwitz EM, Veys P, Bonfim C, Al-Seraihy A. Clinical outcomes following hematopoietic stem cell transplantation for the treatment of mucopolysaccharidosis VI. Molecular Genetics and Metabolism. 2011;102:111-115. [pmid: 20980181]. Reprint: exc nro
Tzaribachev N, Koetter I, Kuemmerle-Deschner JB, Schedel J. Rituximab for the treatment of refractory pediatric autoimmune diseases: a case series. Cases J. 2009;2:6609. [pmid: 20184679]. Reprint: exc nri
Valayannopoulos V, de Blic J, Mahlaoui N, Stos B, Jaubert F, Bonnet D, Fischer A, de Lonlay P. Laronidase for cardiopulmonary disease in Hurler syndrome 12 years after bone marrow transplantation. Pediatrics. 2010;126:e1242-7. [pmid: 20974778]. Reprint: exc nrd
Varlet P, Peyre M, Boddaert N, Miquel C, Sainte-Rose C, Puget S. Childhood gangliogliomas with ependymal differentiation. Neuropathol. Appl. Neurobiol. 2009;35:437-441. [pmid: 19220760]. Reprint: exc nro
Versluys A, Rossen JWA, van Ewijk B, Schuurman R, Bierings MB, Boelens JJ. Strong Association between Respiratory Viral Infection Early after Hematopoietic Stem Cell Transplantation and the Development of Life-Threatening Acute and Chronic Alloimmune Lung Syndromes. Biol. Blood Marrow Transplant. 2010;16:782-791. [pmid: 20060053]. Reprint: exc nrp
Vulcani-Freitas TM, Saba-Silva N, Cappellano A, Cavalheiro S, Marie SK, Oba-Shinjo SM, Malheiros SM, de Toledo SR. ASPM gene expression in medulloblastoma. Childs Nerv Syst. 2011;27:71-4. [pmid: 20694558]. Reprint: exc nrs
Wall DA, Chan KW, Nieder ML, Hayashi RJ, Yeager AM, Kadota R, Przepiorka D, Mezzi K, Kletzel M. Safety, efficacy, and pharmacokinetics of intravenous busulfan in children undergoing allogeneic hematopoietic stem cell transplantation. Pediatr. Blood Cancer. 2010;54:291-298. [pmid: 19743300]. Reprint: exc nrp
Wang JZ, Liu KY, Xu LP, Liu DH, Han W, Chen Y, Chen H, Zhang XH, Zhao T, Wang Y, Huang XJ. Basiliximab for the treatment of steroid-refractory acute graft-versus-host disease after unmanipulated HLA-mismatched/haploidentical hematopoietic stem cell transplantation. Transplantation Proceedings. 2011;43:1928-1933. [pmid: 21693302]. Reprint: exc nrp
Wang RY, Cambray-Forker EJ, Ohanian K, Karlin DS, Covault KK, Schwartz PH, Abdenur JE. Treatment reduces or stabilizes brain imaging abnormalities in patients with MPS I and II. Mol Genet Metab. 2009;98:406-11. [pmid: 19748810]. Reprint: exc nrt
Wiegering V, Eyrich M, Rutkowski S, Wolfl M, Schlegel PG, Winkler B. TH1 predominance is associated with improved survival in pediatric medulloblastoma patients. Cancer Immunol Immunother. 2011;60:693-703. [pmid: 21327638]. Reprint: exc nrd
Woolfrey A, Storek J, Bowyer S, Nelson R, Robertson M, Wallace C. Long-term response of juvenile idiopathic arthritis after conditioning with 8 Gy total body irradiation followed by autologous peripheral blood stem cells. Pediatr. Transplant. 2010;14:E65-E69. [pmid: 19254270]. Reprint: exc nrp
Worthey EA, Mayer AN, Syverson GD, Helbling D, Bonacci BB, Decker B, Serpe JM, Dasu T, Tschannen MR, Veith RL, Basehore MJ, Broeckel U, Tomita-Mitchell A, Arca MJ, Casper JT, Margolis DA, Bick DP, Hessner MJ, Routes JM, Verbsky JW, Jacob HJ, Dimmock DP. Making a definitive diagnosis: successful clinical application of whole exome sequencing in a child with intractable inflammatory bowel disease. Genet Med. 2011;13:255-62. [pmid: 21173700]. Reprint: exc nrs
Yeung AH, Cowan MJ, Horn B, Rosbe KW. Airway management in children with mucopolysaccharidoses. Arch. Otolaryngol. Head Neck Surg. 2009;135:73-79. [pmid: 19153310]. Reprint: exc nrs
Yoo KH, Lee SH, Sung KW, Koo HH, Chung NG, Cho B, Kim HK, Kang HJ, Shin HY, Ahn HS, Baek HJ, Han DK, Kook H, Hwang TJ, Kim SY, Lee YH, Hah JO, Im HJ, Seo JJ, Park SK, Jung HJ, Park JE, Lim YJ, Park SS, Lim YT, Yoo ES, Ryu KH, Park HJ, Park BK. Current status of pediatric umbilical cord blood transplantation in Korea: A multicenter retrospective analysis of 236 cases. American Journal of Hematology. 2011;86:12-17. [pmid: 21064135]. Reprint: exc t?
Zacharoulis S, Chi S, Kadota R, Kieran M. Biological modification strategies following marrow ablative, High-Dose Chemotherapy (HDCT) with Autologous Hematopoietic Stem Cell Rescue (AHSCR) for pediatric brain tumors. Pediatr. Blood Cancer. 2010;54:654-656. [pmid: 20146216]. Reprint: exc nrd
Zhang WL, Huang Y, Wang DS, Wang YZ, Zhu X, Hong L, Li P, Zhang PW, Zhou Y. [Therapeutic effects of high dose chemotherapy combined with autologous peripheral blood stem cell transplantation for neural ectodermal solid tumor originated from neural crest in children]. Zhongguo Dang Dai Er Ke Za Zhi. 2010;12:244-7. [pmid: 20416211]. Reprint: exc fla