# Search Strategies

Last search date: August 17, 2011

Search Strategy: PubMed/MEDLINE®

All Child: 0-18 years=3709
#107 Search #104 AND #106
#106 Search “Humans”[Mesh]
#104 Search #102 AND #103
#103 Search #55 OR #88 OR #90 OR #101
#102 Search #45 OR #47
#101 Search “Fabry Disease” OR “Fabry's disease” OR “Farber Lipogranulomatosis” OR “Fabry Disease” OR “Fabry's disease” OR “Farber Lipogranulomatosis” OR Gangliosidos* OR “Sandhoff Disease” OR “sandhoff's disease” OR “Gaucher Disease” OR “gaucher's disease” OR “Niemann-Pick Disease*” OR “Tay-Sachs Disease” OR Aspartylglucosaminuria OR “beta-Mannosidosis” OR Mucolipidos* OR “Wolman Disease” OR “Ceroid Lipofuscinos*” OR “Ceroid-Lipofuscinos*” OR galactosialidosis OR Cystinosis OR “Sialic Acid Storage Disease” OR “salla disease” OR “peroxisomal storage disorder*” OR adrenomyeloneuropath* OR “immune cytopenia*”
#90 Search “Ewing's Sarcoma” OR “Wilms Tumor” OR Rhabdomyosarcoma* OR Retinoblastoma* OR Medulloblastoma* OR PNET OR “Primitive Neuroectodermal Tumor*” OR Astrocytoma* OR Mucopolysaccharidos* OR Sphingolipidos* OR “Lysosomal Storage Disease*” OR “Glycogen Storage Disease*” OR “Niemann-Pick Disease*” OR Adrenoleukodystrophy OR “Juvenile Rheumatoid Arthritis” OR “Systemic Lupus Erythematosus” OR SLE OR Scleroderma OR “Crohn Disease” OR “Crohn's disease” OR “Autoimmune Disease*”
#88 Search (((((((((“Mucopolysaccharidoses”[Mesh] OR “Sphingolipidoses”[Mesh]) OR “Lysosomal Storage Diseases”[Mesh]) OR “Glycogen Storage Disease”[Mesh]) OR “Niemann-Pick Diseases”[Mesh]) OR “Adrenoleukodystrophy”[Mesh]) OR “Arthritis, Juvenile Rheumatoid”[Mesh]) OR “Lupus Erythematosus, Systemic”[Mesh]) OR “Scleroderma, Systemic”[Mesh]) OR “Crohn Disease”[Mesh]) OR “Autoimmune Diseases”[Mesh]
#55 Search (((((“Sarcoma, Ewing's”[Mesh] OR “Wilms Tumor”[Mesh]) OR “Rhabdomyosarcoma”[Mesh]) OR “Retinoblastoma”[Mesh]) OR “Medulloblastoma”[Mesh]) OR “Neuroectodermal Tumors, Primitive”[Mesh]) OR “Astrocytoma”[Mesh]
#47 Search “stem cell*” OR “bone marrow”
#45 Search “Bone Marrow Transplantation”[Mesh] OR (“Hematopoietic Stem Cell Transplantation”[Mesh] OR “Peripheral Blood Stem Cell Transplantation”[Mesh] OR “Cord Blood Stem Cell Transplantation”[Mesh] OR “Stem Cell Transplantation”[Mesh])

Additional searches were performed using

“stem cell*” OR “bone marrow”

Search “Bone Marrow Transplantation”[Mesh] OR (“Hematopoietic Stem Cell Transplantation”[Mesh] OR “Peripheral Blood Stem Cell Transplantation”[Mesh] OR “Cord Blood Stem Cell Transplantation”[Mesh] OR “Stem Cell Transplantation”[Mesh]) OR “stem cell*” OR “bone marrow”

AND

“Precursor Cell Lymphoblastic Leukemia-Lymphoma”[Mesh] OR “Leukemia, Myeloid, Acute”[Mesh] OR “acute lymphoblastic leukemia” OR acute myeloid leukemia”

“Lymphoma, Non-Hodgkin”[Mesh] OR “non-Hodgkin* lymphoma*”

“Hodgkin Disease”[Mesh] OR “hodgkin lymphoma”

“Leukemia, Myelomonocytic, Juvenile”[Mesh] OR “juvenile myelomonocytic leukemia”

“Leukemia, Myelogenous, Chronic, BCR-ABL Positive”[Mesh] OR “chronic myelogenous leukemia”

“Myelodysplastic-Myeloproliferative Diseases”[Mesh] OR “myelodysplastic disease*”

“Neuroblastoma”[Mesh] OR neuroblastoma*

“Leukodystrophy, Globoid Cell”[Mesh] OR “globoid leukodystrophy”

“Leukodystrophy, Metachromatic”[Mesh] OR “metachromatic leukodystrophy”

“Fucosidosis”[Mesh] OR fucosidosis

“alpha-Mannosidosis”[Mesh] OR “alpha-mannosidosis” OR “alpha-mannosidoses”

“Peroxisomal Disorders”[Mesh] OR “peroxisomal storage disorder*” OR adrenoleukodystroph*

“Osteopetrosis”[Mesh] OR osteopetrosis

“bone marrow failure” OR “Fanconi Anemia”[Mesh] OR “Fanconi* anemia” OR “Dyskeratosis Congenita”[Mesh] OR “dyskeratosis congenita” OR “Shwachman-Diamond” OR “Anemia, Diamond-Blackfan”[Mesh] OR “Diamond-Blackfan” OR “Diamond Blackfan”

“Ependymoma”[Mesh] OR ependymoma*

“Glioma”[Mesh] OR glioma*

“Choroid Plexus Neoplasms”[Mesh] OR (“choroid plexus” AND (tumor OR tumour OR tumors OR tumours OR neoplasm*))

medulloepithelioma* OR (supratentorial AND (PNET OR “primitive neuroectodermal”)) OR pineoblastoma* OR “cerebral neuroblastoma*” OR ganglioneuroblastoma* OR ependymoblastoma* OR “atypical teratoid/rhabdoid tumor*” OR “Pinealoma”[Mesh] OR (“Rhabdoid Tumor”[Mesh] AND atypical AND teratoid*) OR “Astrocytoma”[Mesh] OR “Oligodendroglioma”[Mesh] OR astrocytoma* OR oligodendroglioma* OR “glioblastoma multiforme”

“Diabetes Mellitus, Type 1”[Mesh] OR (“type 1” AND (diabetes OR diabetic OR DM)) OR “juvenile diabetes”

“Neoplasms, Germ Cell and Embryonal”[Mesh] AND germ) OR “germ cell tumor*”

Searches were also performed in EMBASE and the Cochrane Central Register of Controlled Trials for the above disease entities.

Additional searches were performed for the disease entities above and NOT the stem cell transplantation set to obtain literature on the therapeutic measures to be used as comparisons.

Diabetes
#15 Search (#10 AND #13) NOT #5 Limits: Humans, Clinical Trial, Editorial, Practice Guideline, Randomized Controlled Trial, Case Reports, Comparative Study, Controlled Clinical Trial, Guideline, English, All Infant: birth-23 months, All Child: 0-18 years, Publication Date from 1995/10/01 to 2010/07/12
#14 Search (#10 AND #13) NOT #5
#13 Search “Immunosuppression”[Mesh] OR immunomodulation OR immunosuppressant OR immunosuppressive OR “immune modulation” OR “immune suppression”
#10 Search “Diabetes Mellitus, Type 1”[Mesh] OR (“type 1” AND (diabetes OR diabetic OR DM)) OR “juvenile diabetes”
#5 Search “Bone Marrow Transplantation”[Mesh] OR (“Stem Cell Transplantation”[Mesh] OR “Peripheral Blood Stem Cell Transplantation”[Mesh] OR “Cord Blood Stem Cell Transplantation”[Mesh] OR “Hematopoietic Stem Cell Transplantation”[Mesh]) OR “bone marrow transplant*” OR “stem cell support” OR “stem cell transplant*”

Other Autoimmune Diseases
#23 Search (#20 AND #13) NOT #5 AND (severe OR refractory OR “poor prognosis”) Limits: Humans, Clinical Trial, Editorial, Practice Guideline, Randomized Controlled Trial, Case Reports, Comparative Study, Controlled Clinical Trial, Guideline, English, All Infant: birth-23 months, All Child: 0-18 years, Publication Date from 1995/10/01 to 2010/07/12
#22 Search (#20 AND #13) NOT #5 Limits: Humans, Clinical Trial, Editorial, Practice Guideline, Randomized Controlled Trial, Case Reports, Comparative Study, Controlled Clinical Trial, Guideline, English, All Infant: birth-23 months, All Child: 0-18 years, Publication Date from 1995/10/01 to 2010/07/12
#21 Search (#20 AND #13) NOT #5
#20 Search ((“Arthritis, Juvenile Rheumatoid”[Mesh] OR “Lupus Erythematosus, Systemic”[Mesh]) OR “Scleroderma, Systemic”[Mesh]) OR “Crohn Disease”[Mesh]
#13 Search “Immunosuppression”[Mesh] OR immunomodulation OR immunosuppressant OR immunosuppressive OR “immune modulation” OR “immune suppression”
#5 Search “Bone Marrow Transplantation”[Mesh] OR (“Stem Cell Transplantation”[Mesh] OR “Peripheral Blood Stem Cell Transplantation”[Mesh] OR “Cord Blood Stem Cell Transplantation”[Mesh] OR “Hematopoietic Stem Cell Transplantation”[Mesh]) OR “bone marrow transplant*” OR “stem cell support” OR “stem cell transplant*”

Ewing's Sarcoma
#42 Search #40 NOT #5 Limits: Humans, Clinical Trial, Editorial, Practice Guideline, Randomized Controlled Trial, Case Reports, Comparative Study, Controlled Clinical Trial, Guideline, English, All Infant: birth-23 months, All Child: 0-18 years, Publication Date from 1995/10/01 to 2010/07/12
#41 Search #40 NOT #5
#40 Search (#27 AND #39) AND #32
#39 Search ((“Recurrence”[Mesh] OR “Neoplasm Recurrence, Local”[Mesh])) OR “secondary “[Subheading] OR recurrent OR recurrence OR (stage AND IV) OR secondary OR metastatic OR metastas*
#32 Search “therapeutic use “[Subheading] OR “therapy “[Subheading] OR therapy OR treatment OR therapeutic*
#27 Search “Sarcoma, Ewing's”[Mesh] OR (Ewing* AND sarcoma)
#5 Search “Bone Marrow Transplantation”[Mesh] OR (“Stem Cell Transplantation”[Mesh] OR “Peripheral Blood Stem Cell Transplantation”[Mesh] OR “Cord Blood Stem Cell Transplantation”[Mesh] OR “Hematopoietic Stem Cell Transplantation”[Mesh]) OR “bone marrow transplant*” OR “stem cell support” OR “stem cell transplant*”

Wilms Tumor
#52 Search #50 NOT #5 Limits: Humans, Clinical Trial, Editorial, Practice Guideline, Randomized Controlled Trial, Case Reports, Comparative Study, Controlled Clinical Trial, Guideline, English, All Infant: birth-23 months, All Child: 0-18 years, Publication Date from 1995/10/01 to 2010/07/12
#51 Search #50 NOT #5
#50 Search (#48 AND #49) AND #32
#49 Search ((“Recurrence”[Mesh] OR “Neoplasm Recurrence, Local”[Mesh])) OR “secondary “[Subheading] OR recurrent OR recurrence OR (stage AND IV) OR secondary OR metastatic OR metastas* OR “unfavorable histology” OR relapse OR relapsed
#48 Search “Wilms Tumor”[Mesh] OR (wilm* AND (tumor OR tumors OR tumour*))
#32 Search “therapeutic use “[Subheading] OR “therapy “[Subheading] OR therapy OR treatment OR therapeutic*
#5 Search “Bone Marrow Transplantation”[Mesh] OR (“Stem Cell Transplantation”[Mesh] OR “Peripheral Blood Stem Cell Transplantation”[Mesh] OR “Cord Blood Stem Cell Transplantation”[Mesh] OR “Hematopoietic Stem Cell Transplantation”[Mesh]) OR “bone marrow transplant*” OR “stem cell support” OR “stem cell transplant*”

Rhabdomyosarcoma
#60 Search #58 NOT #5 Limits: Humans, Clinical Trial, Editorial, Practice Guideline, Randomized Controlled Trial, Case Reports, Comparative Study, Controlled Clinical Trial, Guideline, English, All Infant: birth-23 months, All Child: 0-18 years, Publication Date from 1995/10/01 to 2010/07/12
#59 Search #58 NOT #5
#58 Search (#56 AND #57) AND #32
#57 Search ((“Recurrence”[Mesh] OR “Neoplasm Recurrence, Local”[Mesh])) OR “secondary “[Subheading] OR relapse OR relapsed OR refractory OR “high-risk” OR extraocular OR recurrent OR recurrence
#56 Search “Rhabdomyosarcoma”[Mesh] OR rhabdomyosarcoma*
#32 Search “therapeutic use “[Subheading] OR “therapy “[Subheading] OR therapy OR treatment OR therapeutic*
#5 Search “Bone Marrow Transplantation”[Mesh] OR (“Stem Cell Transplantation”[Mesh] OR “Peripheral Blood Stem Cell Transplantation”[Mesh] OR “Cord Blood Stem Cell Transplantation”[Mesh] OR “Hematopoietic Stem Cell Transplantation”[Mesh]) OR “bone marrow transplant*” OR “stem cell support” OR “stem cell transplant*”

Retinoblastoma
#67 Search #65 NOT #5 Limits: Humans, Clinical Trial, Editorial, Practice Guideline, Randomized Controlled Trial, Case Reports, Comparative Study, Controlled Clinical Trial, Guideline, English, All Infant: birth-23 months, All Child: 0-18 years, Publication Date from 1995/10/01 to 2010/07/12
#66 Search #65 NOT #5
#65 Search (#64 AND #57) AND #32
#64 Search “Retinoblastoma”[Mesh] OR retinoblastoma*
#57 Search ((“Recurrence”[Mesh] OR “Neoplasm Recurrence, Local”[Mesh])) OR “secondary “[Subheading] OR relapse OR relapsed OR refractory OR “high-risk” OR extraocular OR recurrent OR recurrence
#32 Search “therapeutic use “[Subheading] OR “therapy “[Subheading] OR therapy OR treatment OR therapeutic*
#5 Search “Bone Marrow Transplantation”[Mesh] OR (“Stem Cell Transplantation”[Mesh] OR “Peripheral Blood Stem Cell Transplantation”[Mesh] OR “Cord Blood Stem Cell Transplantation”[Mesh] OR “Hematopoietic Stem Cell Transplantation”[Mesh]) OR “bone marrow transplant*” OR “stem cell support” OR “stem cell transplant*”

Germ Cell Tumors
#74 Search #72 NOT #5 Limits: Humans, Clinical Trial, Editorial, Practice Guideline, Randomized Controlled Trial, Case Reports, Comparative Study, Controlled Clinical Trial, Guideline, English, All Infant: birth-23 months, All Child: 0-18 years, Publication Date from 1995/10/01 to 2010/07/12
#73 Search #72 NOT #5
#72 Search (#70 AND #49) AND #32
#70 Search (“Neoplasms, Germ Cell and Embryonal”[Mesh] AND germ) OR “germ cell tumor*”
#49 Search ((“Recurrence”[Mesh] OR “Neoplasm Recurrence, Local”[Mesh])) OR “secondary “[Subheading] OR recurrent OR recurrence OR (stage AND IV) OR secondary OR metastatic OR metastas* OR “unfavorable histology” OR relapse OR relapsed
#32 Search “therapeutic use “[Subheading] OR “therapy “[Subheading] OR therapy OR treatment OR therapeutic*
#5 Search “Bone Marrow Transplantation”[Mesh] OR (“Stem Cell Transplantation”[Mesh] OR “Peripheral Blood Stem Cell Transplantation”[Mesh] OR “Cord Blood Stem Cell Transplantation”[Mesh] OR “Hematopoietic Stem Cell Transplantation”[Mesh]) OR “bone marrow transplant*” OR “stem cell support” OR “stem cell transplant*”

CNS Embryonal Tumors
#121 Search #120 NOT #117 Limits: Humans, Clinical Trial, Editorial, Practice Guideline, Randomized Controlled Trial, Case Reports, Comparative Study, Controlled Clinical Trial, Guideline, English, All Infant: birth-23 months, All Child: 0-18 years, Publication Date from 1995/10/01 to 2010/07/12
#120 Search (#110 AND #49) AND #32 Limits: Humans, Clinical Trial, Editorial, Practice Guideline, Randomized Controlled Trial, Case Reports, Comparative Study, Controlled Clinical Trial, Guideline, English, All Infant: birth-23 months, All Child: 0-18 years, Publication Date from 1995/10/01 to 2010/07/12
#117 Search “Bone Marrow Transplantation”[Mesh] OR (“Stem Cell Transplantation”[Mesh] OR “Peripheral Blood Stem Cell Transplantation”[Mesh] OR “Cord Blood Stem Cell Transplantation”[Mesh] OR “Hematopoietic Stem Cell Transplantation”[Mesh]) OR “bone marrow transplant*” OR “stem cell support” OR “stem cell transplant*”
#110 Search medulloblastoma* OR medulloepithelioma* OR (supratentorial AND (PNET OR “primitive neuroectodermal”)) OR pineoblastoma* OR “cerebral neuroblastoma*” OR ganglioneuroblastoma* OR ependymoblastoma* OR “atypical teratoid/rhabdoid tumor*”
#49 Search ((“Recurrence”[Mesh] OR “Neoplasm Recurrence, Local”[Mesh])) OR “secondary “[Subheading] OR recurrent OR recurrence OR (stage AND IV) OR secondary OR metastatic OR metastas* OR “unfavorable histology” OR relapse OR relapsed
#32 Search “therapeutic use “[Subheading] OR “therapy “[Subheading] OR therapy OR treatment OR therapeutic*

CNS Glial Tumors
#131 Search #129 NOT #117 Limits: Humans, Clinical Trial, Editorial, Practice Guideline, Randomized Controlled Trial, Case Reports, Comparative Study, Controlled Clinical Trial, Guideline, English, All Infant: birth-23 months, All Child: 0-18 years, Publication Date from 1995/10/01 to 2010/07/12
#129 Search (#126 AND #128) AND #32
#128 Search (“Recurrence”[Mesh] OR “Neoplasm Recurrence, Local”[Mesh]) OR relapse OR relapsed OR recurrent OR recurrence OR “high-risk”
#126 Search “Astrocytoma”[Mesh] OR “Oligodendroglioma”[Mesh] OR astrocytoma* OR oligodendroglioma* OR “glioblastoma multiforme”
#32 Search “therapeutic use “[Subheading] OR “therapy “[Subheading] OR therapy OR treatment OR therapeutic*
#117 Search “Bone Marrow Transplantation”[Mesh] OR (“Stem Cell Transplantation”[Mesh] OR “Peripheral Blood Stem Cell Transplantation”[Mesh] OR “Cord Blood Stem Cell Transplantation”[Mesh] OR “Hematopoietic Stem Cell Transplantation”[Mesh]) OR “bone marrow transplant*” OR “stem cell support” OR “stem cell transplant*”