# Appendixes

Appendix A Search Strategies

Appendix B Excluded Studies

Appendix C Systematic Review Data Abstraction

Appendix D Disease-Free/Event-Free Survival

Appendix E Neurodevelopmental and Neurocognitive Outcomes

Appendix F C-Peptide and HbA1c Outcomes