# Acronyms and Abbreviations

aGVHD: acute graft vs. host disease
AHRQ: Agency for Healthcare Research and Quality
AIHA: autoimmune hemolytic anemia
ALCL: anaplastic large cell lymphoma
ALL: acute lymphoblastic leukemia
Allo: allogeneic
AML: acute myelogenous leukemia
ASBMT: American Society for Blood and Marrow Transplantation
AT/ RT: atypical teratoid/rhabdoid tumor
ATG: antithymocyte globulin
Auto: autologous
BAALC: brain and acute leukemia, cytoplasmic
BL: Burkitt-like
BMF: bone-marrow failure
BMT: bone-marrow transplant
CAMT: congenital amegakaryocytic thrombocytopenia
CC: calcinosis cutis
C-CSF: granulocyte colony-stimulating factor
CD: Crohn's disease
CDAI: Crohn's disease activity index
CDC: Centers for Disease Control and Prevention
cGVHD: chronic graft vs. host disease
CI: confidence interval
CIBMTR: Center for International Bone Marrow Transplant Research
CML: chronic myelogenous leukemia
CNS: central nervous system
COCALD: childhood onset of cerebral adrenoleukodystrophy
COG: Children's Oncology Group
CR: complete remission
Cy: cyclophosphamide
DAI: disease activity index
DBA: Diamond Blackfan anemia
DFS: disease-free survival
DFS: disease-free survival
DLBCL: diffuse large B-cell lymphoma
DM: diabetes mellitus
DQ: developmental quotient
DOD: dead of disease
DOT: dead of treatment
EBMT: European Group for Blood and Marrow Transplantation
EDSS: expanded disability status scale
EFS: event-free survival
EPC: Evidence-based Practice Center
ERT: enzyme-replacement therapy
ES: Evans syndrome
ESFT: Ewing sarcoma family of tumors
F: female
FA: Fanconi anemia
FFS: failure-free survival
Flu: fludarabine
GCT: germ-cell tumor
GFR: glomerular filtration rate
GI: gastrointestinal
GVHD: graft versus host disease
GVM: graft versus malignancy
Hb: hemoglobin
HbF: fetal hemoglobin
HDC: high-dose chemotherapy
HL: Hodgkin's lymphoma
HLA: human leukocyte antigen
HR: hazard ratio
HSCT: hematopoietic stem-cell transplant
HU: hydroxyurea
ICGG: International Collaborative Gaucher Group
IIT: intensive insulin therapy
IPI: international prognostic index
IQ: intelligence quotient
IVIG: intravenous immune globulin
JIA: juvenile idiopathic arthritis
JCML: juvenile chronic myelogenous leukemia
JMML: juvenile myelomonocytic leukemia
JRA: juvenile rheumatoid arthritis
KQ: Key Question(s)
L&H: lymphocytic and histiocytic
LBL: lymphoblastic lymphoma
LCL: large-cell lymphoma
LDH: lactate dehydrogenase
LFS: leukemia-free survival
LL: lymphoblastic lymphoma
M: male
MA: meta analysis
MALT: mucosa-associated lymphoid tissue
MDS: myelodysplastic syndrome
MG: myasthenia gravis
MLD: metachromatic leukodystrophy
Mo(s).: month(s)
MPS: mucopolysaccharidosis
MRD: matched related donor
MRD: minimal residual disease
MRI: magnetic resonance imaging
MSC: mesenchymal stem cells
MS: multiple sclerosis
MSD: matched sibling donor
MUD: matched unrelated donor
N, n: number
NA: not applicable
NB: neuroblastoma
NCCN: National Comprehensive Cancer Network
NHL: non-Hodgkin's lymphoma
NHLBI: National Heart, Lung, and Blood Institute
NK: natural killer
NOS: not otherwise specified
NR: not reported
OS: osteosarcoma
OS: overall survival
OS: overlap syndrome
PBSC: peripheral blood stem cells
PBSCT: peripheral blood stem-cell transplant
PDQ®: Physician Data Query
PFS: progression-free survival
Ph+/-: Philadelphia chromosome positive/negative
PICOTS: patients, interventions, comparator, outcomes, timing, setting
PNET: primitive neuroectodermal tumor
PPMS: primary progressive multiple sclerosis
PR: partial remission
PRMS: progressive relapsing multiple sclerosis
Pt(s): patient(s)
PTCL: peripheral T-cell lymphoma
QOL: quality of life
RA: refractory anemia
RAEB: refractory anemia with excess blasts
RCT: randomized, controlled trial
RMS: rhabdomyosarcoma
RR: relative risk
RRMS: relapsing, remitting multiple sclerosis
RuSH: Registry and Surveillance System in Hemoglobinopathies
sAML: secondary acute myelogenous leukemia
SCD: sickle-cell disease
SCID: severe combined immunodeficiency
SCIG: subcutaneous immune globulin
SCN: severe congenital neutropenia
SCT: stem-cell transplant
SDS: Schwachman Diamond syndrome
SE: standard error
SLE: systemic lupus erythematosus
SLEDAI: Systemic Lupus Erythematosus Disease Activity Index
SPMS: secondary progressive multiple sclerosis
SS: systemic sclerosis
SSc: systemic sclerosis
TBI: total body irradiation
TEC: Technology Evaluation Center
TEP: Technical Expert Panel
TFS: thalassemia-free survival
TKI: tyrosine kinase inhibitor
TNF: tumor necrosis factor
TRM: treatment-related mortality
Tx: treatment/therapy
UCB: umbilical cord blood
URD: unrelated donor
VEGF: vascular endothelial growth factor
VLCFA: very long chain fatty acids
VOD: veno-occlusive disease
WBC: white blood cell
WT: Wilms tumor
Yr(s): year(s)