# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project: Joan Glacy, M.D., for abstract review; Lisa Sarsany, M.A., for government project management; Kimberly Della Fave for administrative support; and Sharon Flaherty, M.A., for contracts support.