# Technical Expert Panel

Joann Elmore, M.D., M.P.H.

Harborview Medical Center

Seattle, WA

Constantine Gatsonis, Ph.D.

Brown University

Providence, RI

Deborah Laxague, R.N.

National Breast Cancer Coalition

Grenada, CA

Carol Lee, M.D.

Memorial Sloan Kettering Cancer Center

New York, NY

Mark Robson, M.D.

Memorial Sloan Kettering Cancer Center

New York, NY

Robert Rosenberg, M.D.

University of New Mexico

Albuquerque, NM