# Summary and Discussion

After identification of a possible abnormality on screening mammography or physical examination, women typically undergo additional imaging studies (diagnostic mammography) and a physical examination. If these studies suggest the abnormality may be malignant, a biopsy of the suspicious area may be recommended. This evidence review focuses on the noninvasive imaging studies conducted after the discovery of a possible abnormality on screening mammography or physical examination - studies intended to guide patient management decisions. In other words, these studies are not intended to provide a final diagnosis as to the nature of the breast lesion; rather, they are intended to provide additional information about the nature of the lesion such that women can be appropriately triaged into “biopsy,” “watchful waiting,” or “return to normal screening intervals” care pathways.

According to the American College of Radiology, the threshold of suspicion at which management of women changes is 2 percent.92 After recall and workup, women with a suspicion of malignancy greater than 2 percent are generally advised to undergo tissue sampling of some kind (i.e., biopsy), and women with a lower suspicion of malignancy are triaged into imaging pathways. We used the 2 percent threshold to explore the clinical usefulness of the various noninvasive imaging technologies as add-ons to the current standard of care, namely, if a woman was recalled for evaluation after a screening mammography, and received standard of care workup vs. standard of care workup plus the noninvasive imaging technology, would the use of the noninvasive imaging technology be likely to alter the recommendations for care after the workup?

For all of the technologies evaluated in this assessment, only women with a low suspicion of malignancy after standard of care workup might be expected to experience a change in management decisions as a result of additional noninvasive imaging. A woman with a ≤12 percent suspicion of malignancy who has benign findings on MRI could have her suspicion of malignancy drop below the 2 percent threshold, and therefore she might be assigned to short-interval imaging followup management rather than tissue sampling management; a woman with a 1 percent suspicion of malignancy who has benign findings on MRI could have her suspicion of malignancy drop to near 0 percent and therefore she might be assigned to return to normal screening rather than short-interval followup imaging; a woman with a 1 percent suspicion of malignancy who has malignant findings on MRI could have her suspicion of malignancy increase to 4 percent and therefore she might be assigned to tissue sampling management rather than short-interval followup. The equivalent thresholds of pretest suspicion of malignancy at which additional imaging may change management are: for B-mode grayscale ultrasound, 1 to 10 percent; for scintimammography, 1 to 5 percent; and for PET, 1 to 5 percent.

Only women with a low suspicion of malignancy on standard of care workup might be expected to experience a change in management decisions as a result of additional noninvasive imaging. Clinicians can estimate the risk of malignancy by using patient age, family and personal history details, details of the mammographic images, and results of physical examination.261,262 Current standard practice already requires clinicians to estimate patient risk of malignancy. BI-RADS scores, for example, are estimates of patient risk of malignancy. Information is available that can be used to generate more precise estimates. For example, Wiratkapun et al. recently reported that a large cohort of women classified as BI-RADS 4 after diagnostic mammography were subsequently found to have a 20 percent prevalence of breast cancer, indicating that the methods used by this center to assign women as BI-RADS 4 were estimating that these women had a 20 percent probability of malignancy. Wiratkapun et al. performed a retrospective analysis of clinical risk factors and details of the mammographic images and found that these women could be classified into sub-categories that had cancer prevalences that ranged from as low as 9 percent to as high as 57 percent.261

Therefore, if the 2 percent threshold is chosen, the use of noninvasive imaging in addition to standard workup may be clinically useful for diagnostic purposes only for women with a low (generally, less than 12%) suspicion of malignancy. When choosing which noninvasive imaging technology to use for this purpose, diagnostic B-mode grayscale ultrasound and MRI appear to more accurate than PET, scintimammography, or the other types of ultrasound (Doppler) that were evaluated in this comparative effectiveness review.

Noninvasive imaging appears to be an acceptable option for many women. Liang et al. invited a series of women referred for breast biopsy to undergo an additional mammographic exam, MRI, and scintimammography before the biopsy.263 The women reported that MRI and scintimammography were much more comfortable than mammography, and that they would rather have additional noninvasive tests, even if they had to pay extra money out of pocket, instead of proceeding to immediate biopsy (assuming the results of the noninvasive tests were very accurate).

Several of our expert peer reviewers did not think that it is currently feasible for clinicians to estimate pre-test probability with sufficient precision to identify women with >0 but <5, 10 or 12 percent suspicion of malignancy after standard work-up. If it is not possible, then it is unlikely that these findings can be applied in practice. Furthermore, there are possible harms from noninvasive imaging, such as radiation exposure, that also need to be considered during decision-making.

## Changes Since 2006

This CER is an update of a CER finalized in 2006. The updated results are, in general, very similar to the findings of the 2006 report. For MRI, in 2006 we found that the sensitivity was 92.5 percent and the specificity was 75.5 percent; the updated evidence base supported estimates of 91.7 percent sensitivity and 77.5 percent specificity. In both reports, MRI was found to be less sensitive (approximately 85%) for evaluation of microcalcifications than for evaluation of lesions in general. For PET, in 2006 we found that the sensitivity was 82.2 percent and the specificity was 78.3 percent; the updated evidence base supported estimates of 83.0 percent sensitivity and 74.0 percent specificity. In the updated report we attempted to evaluate the accuracy of PET/CT, but only one study that met the inclusion criteria was identified.

For scintimammography, the updated evidence base identified a sensitivity of 84.7 percent, much higher than the sensitivity estimate from 2006 of 68.7 percent. Specificity was estimated at 84.8 percent in 2006, and at 77.0 percent in the update; however, the confidence intervals around the updated estimate of specificity are wide. It is possible that improvements in the technology in the last few years improved the sensitivity of the technique.

For ultrasound, in 2006 we only evaluated a relatively small subset of studies of B-mode grayscale ultrasound, and estimated a sensitivity of 86.1 percent and a specificity of 66.4 percent. The update included a significantly expanded evidence base on B-mode grayscale ultrasound, and identified a sensitivity of 92.4 percent and specificity of 75.8 percent. In the update we included numerous other types of ultrasound, including power and color Doppler ultrasound, that were not studied in the 2006 report.

## Limitations of the Evidence Base

The majority of conclusions about accuracy were rated as supported by “Low” strength of evidence. The evidence bases were rated as Low rather than Moderate or High due primarily to the heterogeneity of the results (inconsistency). All of the evidence bases were found to contain significant heterogeneity, and exploratory meta-regressions did not identify satisfactory explanations for the heterogeneity.

Another limitation of the evidence base is that most of the studies included only patients who had been referred for biopsy or surgery. Therefore the patient population under study does not contain a good representation of patients thought to be at sufficiently low risk of malignancy that additional imaging would be considered rather than immediate biopsy. The studies also did not distinguish between patients diagnosed with DCIS vs. invasive cancer; this point is important in addressing the consequences of delayed diagnoses of cancer, because a delay in diagnosis of DCIS may not be as harmful as a delay in diagnosis of invasive cancer. In addition, little information was reported about different patient subgroups, making it difficult to address Key Questions 2 and 3.

## Applicability

We used inclusion criteria intended to restrict the evidence base to only those studies that included the population of interest: women of average baseline risk after discovery of a suspicious lesion on routine screening who had already undergone standard recall and workup (diagnostic x-ray mammography). “Women of average baseline risk” refers to women who do not have a strong family history of breast cancer, do not carry a known genetic susceptibility mutation, do not have a prior personal history of breast cancer, and are not presenting for examination because of an overt symptom such as nipple discharge. However, the patient populations studied had much higher prevalences of cancers than would be expected if the populations were actually representative of the patient population of interest. The prevalence of cancers in the general population sent for breast biopsy (in the U.S.) has been reported to be approximately 20 to 30 percent percent.103 The population of interest includes not only those women who will be referred for biopsy, but should also include women who will be referred for short interval followup, and therefore the expected prevalence of cancers in the population of interest should be lower than 20 percent. However, the prevalence of cancers in the included studies was 25.8 percent for ultrasound, 54.5 percent for MRI, 56 percent for scintimammography, and 75.9 percent for PET. One reason for the elevated prevalence is that the studies generally attempted to use the “gold standard” reference to verify diagnoses (histopathology), and therefore many of the studies only enrolled patients who subsequently underwent biopsy or surgery. An additional possible reason for the elevated prevalence of disease is the fact that many of the studies were conducted in non-U.S. locations, where the prevalence of cancers in populations sent for biopsy has been reported to be 60 to 70 percent.264

The patient populations studied are therefore not truly representative of the patient population of interest. It is possible that the accuracy estimates we derived from these studies do not apply to women thought to be at sufficiently low risk of malignancy that additional imaging would be considered rather than immediate biopsy.

## Possible Impact of Key Assumptions on the Conclusions

The key assumption made was that the “reference standard,” a combination of biopsy, open surgery, and patient followup, was 100 percent accurate. Open surgery has been reported to have a false-negative rate of approximately 1 to 2 percent.265 Biopsy and patient followup have error rates higher than open surgery. Therefore some of the reference standard diagnoses were almost certainly incorrect. However, the errors should consist of a low rate of both false-negatives and false-positives, which should not systematically bias the results in any one direction. It seems unlikely that our estimates of diagnostic accuracy are significantly different from the “true” accuracy solely due to errors made by the reference standard diagnoses.

In addition, we have assumed the ACR’s suggested threshold of “change of management” of 2 percent is applicable and valid. It is possible that some patients or physicians may wish to use a different threshold. For example, a patient who has a strong desire to avoid biopsy may prefer the use of a higher threshold, whereas a patient who has a strong desire to avoid any uncertainty about breast cancer at all may prefer the use of a lower threshold. However, our results can be directly applied to such situations. Our post-test probability calculations can simply have a different threshold of “change in management” applied in order to derive theoretical models of the impact of the use of the different threshold on management decisions.

## Future Research

The strength of the evidence supporting the conclusions about accuracy in this assessment was in general rated as “low” primarily due to imprecise estimates of accuracy (wide confidence intervals) and/or inconsistencies across studies (heterogeneity). While further studies on the diagnostic accuracy of the noninvasive technologies evaluated are unlikely to substantially change the conclusions, the publication of additional diagnostic accuracy studies may increase the precision of the estimates of accuracy, and provide enough additional information to allow productive exploration into the causes of the heterogeneity. An additional limitation of the evidence base that could be explored in future research is inclusion of women thought to be at low risk of malignancy - the majority of the published studies only included women thought to be at moderate to high risk of malignancy.

One primary shortcoming in the current evidence base is the lack of evidence for specific subgroups of lesion types. For example, while we were able to determine the accuracy of MRI for patients presenting with microcalcifications, we were unable to determine the accuracy of PET, ultrasound, or scintimammography for patients presenting with microcalcifications due to lack of evidence. We had also hoped to be able to study the impact of variations in MRI methodology on the accuracy, but the many variations of imaging methods in use and the inconsistency in reporting across studies precluded any such analysis. Also, due to lack of evidence we were unable to determine the impact of patient characteristics such as age on the accuracy of the various imaging methods. Future diagnostic accuracy studies that report data for specific subgroups of patients or directly compare different imaging methods would be helpful in addressing these unanswered questions.

Studies of new technologies, and improvements in current technologies, are of course essential. For example, the use of computer-aided diagnosis software (CADx) to help interpret MRI images is a technology that appears to be rapidly diffusing, yet there is little clinical evidence available at this time on the impact of CADx on MRI accuracy.

A number of expert reviewers of this report commented that, based on the current state of knowledge, it is impossible to predict the pre-test probability of malignancy with sufficient accuracy to allow the findings of this technology report to be directly used in clinical practice. Therefore, continued research to improve clinicians’ ability to accurately estimate a woman’s probability of malignancy prior to diagnostic tests could also help to avoid missing cancers and to avoid unnecessary biopsies.

Future research efforts should also be turned to studies that report the impact of the use of noninvasive imaging on management decisions and patient-oriented outcomes. The ideal design for such a study would be a randomized controlled trial in which one group undergoes noninvasive imaging and one does not; the noninvasive imaging results are then used in management decisions; and the patients are followed up for long periods of time to determine the downstream impact of the use of noninvasive imaging on survival and quality of life. Admittedly such studies may be logistically difficult to conduct. When randomized trials are difficult to perform for logistical reasons, modeling studies are often considered acceptable methods of providing information about links between diagnostic testing strategies and patient outcomes.

The diagnostic thresholds that trigger invasive diagnostic testing should also be studied in the context of the addition of noninvasive imaging to standard protocols. Current standard of care results in large numbers of healthy women undergoing invasive diagnostic procedures, and many women may be undergoing treatment for small early-stage breast cancers that will never become clinically relevant even if not diagnosed and treated.5,103,266,267 The diagnostic thresholds in current use are intended to reduce the rate of missed cancers, which by necessity causes a loss of specificity. The low thresholds are also intended to partially compensate for diagnostic inaccuracy of tests in current use. The hope is that the addition of new kinds of noninvasive imaging to standard protocols may be able to reduce the number of false-positives without increasing the number of false-negatives. The thresholds used in clinical practice to trigger implementation of invasive diagnostic testing and treatment should be based on solid evidence about patient benefit-to-harm ratios derived from controlled trials and modeling studies.