# Results

Our literature searches identified a total of 4,511 possible articles. After review of the abstracts, we selected 384 for further review as full-length articles to determine whether they met the inclusion criteria. The study selection process is summarized in Figure 2. Full details of excluded articles and reasons for exclusion are shown in the Appendixes. The included articles are described throughout this Results section. We have organized the Results section by type of noninvasive test rather than by Key Question.

Figure 2 Study selection process

Figure 2 depicts the study selection process in a flowchart. At the top of the chart the 4,511 possible articles identified by our literature searches are depicted; after review of the abstracts, 384 articles were selected for further review. Moving down the chart, after applying the inclusion/exclusion criteria, 91 clinical trials were excluded. At the bottom of the chart the technologies the included studies addressed are listed: 41 studies of MRI, 7 studies of PET, 1 study of PET/CT, 10 studies of scintimammography, one study of breast-specific gamma imaging, and 31 studies of ultrasound.

## Magnetic Resonance Imaging

### Background

#### Technology

Magnetic resonance imaging (MRI) systems use strong magnetic fields and radiofrequency energy to translate hydrogen nuclei distribution in tissues into computer-generated images of the structure of the interior of the breast. MRI does not expose patients to radiation. However, the procedure is not completely noninvasive because often contrast agents are infused to improve the resolution of the images.

MRI systems are usually described primarily in terms of strength of the magnet, in the unit Tesla (T). Systems in commercial use for breast imaging usually vary from 0.5T to 3.0T. In general, increasing the strength of the magnet increases the spatial resolution of the images. MRI systems that use field strengths below 1.0T are usually open gantries and are primarily used for patients who cannot be accommodated inside the bore of a higher field strength magnet due to claustrophobia. An additional reason for the use of open gantry systems is that MRI-guided invasive procedures, such as biopsies, are much easier to perform than in closed systems.128

Surface coils are routinely used in MRI to increase the efficiency of signal detection and, by extension, the image quality. Dedicated breast coils have been available for some time and are considered a prerequisite for breast imaging.129 The dedicated breast coils allow the patient to lie prone with her breasts in close proximity to the coils. Some coils are designed to immobilize the breasts with compression. The compression reduces the volume to be imaged (and therefore reduces image acquisition time) and moves the coils closer to the tissue and helps prevent patient movement (so image quality is improved).130,131 Coils are described by the number of channels they contain. In general, increasing the number of channels improves the signal to noise ratio.130,132,133 Eight-channel breast coils are considered standard equipment for breast MRI examinations.

While all suppliers of MRI equipment provide suggested protocols for different examination types, it is common for users to customize these. The degree of protocol customization largely depends on the clinical users, both radiologists and technologists. Even in tightly controlled studies with a limited number of institutions all using equipment supplied by the same manufacturer, differences in technique have been observed.134

MR images are susceptible to a number of artifacts that could cause image distortion and false interpretations. In particular, breast MR images are prone to artifacts caused by sternal wires and prosthetic cardiac valves.135 Also, respiratory motion can be a problem, although when the patient is prone the effect is reduced.135 Interpretation of the images is a subjective procedure that requires specialized training.136,137 Computer-based tools to partially automate the interpretation procedure are available and may reduce subjectivity and decrease time required for image interpretation.138

The use of contrast agents for MRI breast examinations is considered standard procedure. Gadolinium-based paramagnetic contrast agents accumulate in the vascular system and can aid in visualizing tumors by highlighting areas containing a dense blood vessel network. There are currently five slightly different gadolinium-based contrast agents in common clinical use: gadobenate dimeglumine, gadopentetate dimeglumine, gadodiamide, gadoteridol, and gadoversetamide.139 These agents differ slightly in molecular structure; all, however, consist of the heavy metal gadolinium bound to a chelating molecule.140 Different agents may have different imaging properties.141,142 When using conventional gadolinium contrast agents, the exact dose used does not appear to be particularly relevant to image quality when used in the normal range (0.1 to 0.2 mmol/kg). When contrast is taken up by a lesion, one of three characteristic enhancement and wash-out curves are usually observed: continuous enhancement, rapid enhancement followed by a plateau, or rapid enhancement followed by rapid wash-out. Rapid wash-out is considered indicative of malignancy.136 In premenopausal women, the normal parenchyma can demonstrate enhancement that can decrease the specificity of breast MRI studies.143,144 The amount of enhancement depends on the stage in the menstrual cycle. Therefore, in order to ensure accurate results, an MRI study should if possible be performed during the second week of the menstrual cycle when proliferative changes are at their lowest level.

For the purposes of this assessment, only MRI conducted on a 0.5 to 3T system using dedicated breast coils and gadolinium-based contrast agents has been considered. These requirements were selected because they describe the systems and methods currently considered to be “standard practice” for breast imaging; other systems and methods would be unlikely to produce results that would be applicable to current clinical practice.145

#### Patient Safety and Comfort

A number of well-known safety hazards exist when a patient is undergoing an MRI exam. Examples include: patient heating, pacemaker malfunction, dislodgment of metallic implants, peripheral nerve stimulation, acoustic noise, and radio frequency induced burns.146–151 Precautions are taken at MRI facilities to routinely screen patients for possible contraindications. Patients are routinely asked to wear earplugs and are given an emergency call button. No adverse effects have been conclusively identified in association with the magnetic fields to which patients are exposed during routine MRI scanning.152–155 Therefore, so long as routine precautions are followed, breast MRI can be considered a safe exam for most patients.

A search for reports of patient discomfort did not find any reports of severe discomfort. In fact, in order to decrease patient motion, it is important that the patient be as comfortable as possible.135 Breast compression does increase the level of discomfort, but the amount is not significant, particularly when compared to the compression that is exerted during x-ray mammography exams.

Gadolinium-based contrast agents are generally considered to be very safe for most patients; some patients may experience allergic reactions which are generally mild.156,157 However, in 2007, FDA requested that manufacturers include a new warning on the labeling of all gadolinium-based contrast agents which are used to enhance MRI.139 The new labeling warns that the use of these agents increases the risk of development of nephrogenic systemic fibrosis (NSF) in patients with pre-existing acute or chronic severe renal insufficiency or renal dysfunction due to recent liver transplantation or hepatorenal syndrome.158–160 NSF is a progressive, disabling, and potentially fatal disorder that leads to deposition of excessive connective tissue in the skin and internal organs. The condition was previously unknown; the typical patient is a middle-aged individual with severe renal disease who first exhibits skin changes 2 to 4 weeks after undergoing an MRI examination that used gadolinium-based contrast agents.160

#### Accreditation Factors

General-purpose MRI systems are cleared for marketing by United States Food and Drug Administration (FDA) under the 510(k) process. Accessories such as breast coils are cleared separately, also under the 510(k) process. Imaging devices are usually not cleared for specific indications; they are cleared for marketing for all indications in the entire body or in specified parts of the body.

There is no nationwide compulsory accreditation for MRI facilities. The American College of Radiology does administer a voluntary accreditation program.161

### Findings From 2006 Review

Our CER from 2006 included 19 prospective diagnostic cohort studies of MRI (published between 1991 and 2004) that studied a total of 2181 suspicious breast lesions.30–32,34,35,40–42,44–46,141,162–168

We found that for suspicious lesions in general, at a fixed 95 percent sensitivity, the specificity of MRI was 62.8 percent. At the mean threshold of the studies, the sensitivity was 92.5 percent and the specificity was 72.4 percent. For lesions with microcalcifications, our analysis found that the sensitivity of MRI was 85.9 percent and the specificity was 75.5 percent.

### Evidence Base

Our literature searches identified 41 diagnostic cohort studies of MRI (published 2000 through 2009) that studied a total of 3882 patients with 4,202 suspicious breast lesions.11–51 The majority of the studies used 1.5T magnets (33 studies) and gadopentetic acid enhancement (26 studies). The studies and patients are described in detail in the Appendixes, and listed at the end of this subsection on MRI in Table 4.

Table 4 Included studies: magnetic resonance imaging (MRI)

Study | MRI Methods Studied | Design^*^ | N Patients
Akita et al. 2009^11^ | 1.5T gadodiamide | Diagnostic cohort study | 50
Baltzer et al. 2009^12^ | 1.5T gadopentetic acid CAD assistance vs. not | Prospective diagnostic cohort | 329
Hara et al. 2009^13^ | 1.5T gadodiamide | Diagnostic cohort study | 103
Kim et al. 2009^14^ | 1.5T gadopentetic acid | Diagnostic cohort study | 249
Lo et al. 2009^15^ | 3T gadopentetic acid | Prospective diagnostic cohort | 31
Imbracio et al. 2008^16^ | 1.5T gadopentetic acid | Prospective diagnostic cohort | 44
Pediconi et al. 2008^17^ | 1.5T gadopentetic acid vs. gadobenic acid | Prospective diagnostic cohort | 47
Vassiou et al. 2009^18^ | 1.5T gadopentetic acid | Prospective diagnostic cohort | 69
Brem et al. 2007^19^ | 1.5T gadopentetic acid | Diagnostic cohort study | 23
Cilotti et al. 2007^20^ | 1.5T gadoteridol | Retrospective | 55
Pediconi et al. 2007^21^ | 1.5T gadobenic acid | Prospective diagnostic cohort | 164
Zhu et al. 2007^22^ | 1.5T gadodiamide | Retrospective | 52
Bazzocchi et al. 2006^23^ | 1.0 or 1.5 T gadoteridol | Prospective diagnostic cohort | 174
Gokalp and Topal 2006^24^ | 1.5T gadopentetic acid | Prospective diagnostic cohort | 43
Kneeshaw et al. 2006^25^ | 1.5T gadopentetic acid | Prospective diagnostic cohort | 88
Ricci et al. 2006^26^ | 1.5T gadobenic acid | Prospective diagnostic cohort | 48
Pediconi et al. 2005^27^ | 1.5T gadobenic acid | Prospective diagnostic cohort | 36
Pediconi et al. 2005^28^ | 1.5T gadopentetic acid vs. gadobenic acid | Prospective diagnostic cohort | 26
Wiener et al. 2005^29^ | 1.5 T gadopentetic acid | Prospective diagnostic cohort | 65
Bluemke et al. 2004^30^ | 1.5T gadopentetic acid | Prospective diagnostic cohort | 821
Huang et al. 2004^31^ | 1.5T gadodiamide | Prospective diagnostic cohort | 50
Bone et al. 2003^32^ | 1.5T gadopentetic acid | Prospective diagnostic cohort | 97
Daldrup-Link et al. 2003^33^ | 1.5T gadopentetic acid | Prospective diagnostic cohort | 14
Heinisch et al. 2003^34^ | 1.0T gadopentetic acid | Prospective diagnostic cohort | 36
Walter et al. 2003^35^ | 1.0T gadopentetic acid | Prospective diagnostic cohort | 40
Guo et al. 2002^36^ | 1.5T gadopentetic acid | Retrospective diagnostic cohort | 52
Kelcz et al. 2002^37^ | 1.5T gadodiamide | Prospective diagnostic cohort | 62
Schedel et al. 2002^38^ | 1.5T gadopentetic acid | Diagnostic cohort study | 65
Trecate et al. 2002^39^ | 1.5T gadopentetic acid | Prospective diagnostic cohort | 28
Wiberg et al. 2002^40^ | 1.5T gadopentetic acid | Prospective diagnostic cohort | 93
Brix et al. 2001^41^ | 1.5T gadopentetic acid | Prospective diagnostic cohort | 14
Cecil et al. 2001^42^ | 1.5T gadopentetic acid | Diagnostic cohort study | 37
Furman-Haran et al. 2001^43^ | 1.5T gadodiamide | Prospective diagnostic cohort | 40
Imbriaco et al. 2001^44^ | 0.5T gadopentetic acid | Prospective diagnostic cohort | 49
Malich et al. 2001^45^ | 1.5T gadopentetic acid | Diagnostic cohort study | 94
Nakahara et al. 2001^46^ | 0.5T gadopentetic acid | Retrospective review of patients with microcalcifications on mammogram | 40
Torheim et al. 2001^47^ | 1.5T gadodiamide | Prospective diagnostic cohort | 127
Wedegartner et al. 2001^48^ | 1.0T gadopentetic acid | Prospective diagnostic cohort | 53
Yeung et al. 2001^49^ | 1.5T gadopentetic acid | Diagnostic cohort study | 30
Kvistad et al. 2000^50^ | 1.5T gadodiamide | Prospective diagnostic cohort | 130
Van Goethem et al. 2000^51^ | NR T gadopentetic acid | Retrospective review of patients with microcalcifications or a problem after clinical examination/mammogram/US | 75

* At times it was difficult to determine if a study was prospective or retrospective, and in those cases we defaulted to simply calling it a “diagnostic cohort study.”

#### Key Question 1 What is the accuracy of MRI for diagnosis of breast cancer in women referred for further evaluation after identification of a possible breast abnormality on routine screening (mammography and/or clinical or self-detection of a palpable lesion)?

We combined the data reported by all 41 studies into a bivariate binomial mixed model. The data were extremely heterogeneous (I^2^ = 98.4%). The summary sensitivity of MRI for all lesions was 91.7 percent (95% CI: 88.5 to 94.1%) and the summary specificity was 77.5 percent (95% CI: 71.0 to 82.9%). These summary estimates are fairly similar to our 2006 estimates of the accuracy of MRI (at the mean threshold the sensitivity was 92.5%, and the specificity was 72.4%).

We investigated the heterogeneity with meta-regression. The variables investigated were: the strength of the magnet, the type of contrast agent used, whether the study enrolled all/consecutive patients or not, whether the study was prospective in design or not, whether all diagnoses were verified by histopathology or not, whether any financial conflicts of interest from the funding source existed or not, whether the study was multi- or single-centered, whether readers were blinded to clinical information or not, whether the study accounted for inter-reader differences or not, the geographical setting of the study, whether the study was clearly affected by spectrum bias or not, and the prevalence of disease. The prevalence of disease in the study population and whether or not readers were blinded to clinical information were both found to be statistically significantly correlated with the accuracy data reported by the studies (p = 0.02 and 0.03, respectively). However, in subgroup analyses there was a statistical correlation between blinding of readers and prevalence of disease. Graphical analysis of prevalence of disease by accuracy failed to reveal any consistent pattern; therefore it is possible that the correlation between prevalence of disease and accuracy is an artifact caused by the correlation between blinding and enrollment of a population with a higher prevalence of disease. Studies that reported they had blinded readers to clinical information had a lower sensitivity than non-blinded studies (86.8% vs. 93.9%) but approximately the same specificity (74.7% vs. 78.0%).

#### Key Question 2 Are there demographic (e.g., age) and clinical risk factors (e.g., morphologic characteristics of the lesion) that affect the accuracy of the tests considered in Key Question 1?

Two studies reported the accuracy of MRI by patient age.30,44 One of these two studies (Bluemke et al.30) investigated the relative accuracy by premenopausal status vs. post-menopausal status of the patients, and reported virtually no difference in either sensitivity or specificity between groups. The other study (Imbriaco et al.44) reported the accuracy of MRI for women 50 years of age and older vs. younger women, and found that MRI was more sensitive (100% vs. 92.9%) in younger women, but had virtually the same specificity (75.0%) in both age groups.

Eight of the studies enrolled patients who had been referred for further investigation after identification of microcalcifications on mammography.20,22,23,25,30,39,46,51 When combined in a bivariate mixed-effects model the data from these eight studies had very low heterogeneity (I^2^ = 3.86%). The summary sensitivity of MRI for microcalcifications was 84.0 percent (79.5 to 88.3%) and the summary specificity was 79.4 percent (71.5 to 85.6%). The summary sensitivity of MRI for evaluation of microcalcifications is considerably lower than the sensitivity of MRI for evaluation of any/all lesions (84.0% vs. 91.7%). The specificity for microcalcifications is approximately the same (79.4% vs. 77.5%). Two studies also directly compared the sensitivity of MRI for evaluation of microcalcifications vs. other types or all types of lesions (Bluemke et al.30 and Van Goethem et al.51) and reported similar results: the sensitivity of MRI for evaluation of microcalcifications is approximately 85 percent, which is considerably lower than the sensitivity of MRI for evaluation of all/other types of lesions; whereas the specificity of MRI for evaluation of microcalcifications is approximately 77 percent, which may be slightly higher than the specificity of MRI for evaluation of all/other types of lesions.

Two studies evaluated the accuracy of MRI for dense breasts vs. all or non-dense breasts (Bluemke et al.30 and Wiberg et al.40), and reported virtually no difference in the accuracy of MRI for evaluation of these different categories of breast tissue.

One study enrolled only patients with lesions classified as BIRADS 3 before investigation by MRI (Gokalp and Topal24); however, only one enrolled patient (out of 43 total) was found to have a malignancy and therefore the patient population is too small to draw conclusions about the accuracy of MRI for probably benign lesions.

One study each investigated the accuracy of MRI for lesions broken down by palpable vs. non-palpable (Bluemke et al.30) and large lesion vs. small lesion (Imbracio et al.44).

#### Key Question 3 Are there other factors and considerations that may affect the accuracy or acceptability of MRI?

One study reported the accuracy of MRI images interpreted with and without a Computer Aided Diagnosis (CAD) software system.12 The study reported virtually no difference in either sensitivity (77.4% vs. 78.9%) or specificity (73.2% vs. 73.2%) with or without CAD assistance.

### Previously Published Systematic Reviews

We identified three systematic reviews of the use of MRI to evaluate women with prior clinical findings that suggest the possibility of breast cancer; two were published prior to the release of the 2006 version of this report. The methods and conclusions of these reviews are summarized in Table 3. The authors of two of the systematic reviews concluded that the negative predictive value of MRI is too low for this indication, and therefore patients did not benefit from being examined by MRI after mammography; the authors of the third review (Peters et al.) did not speculate on the clinical utility of MRI.169

Table 3 Other published technology assessments of MRI

Study | Methods | Conclusions
Peters et al. 2008^169^ | Systematic review of the literature on the diagnostic performance of contrast-enhanced MRI for breast lesions. The review included studies published 1985 through 2005, and identified 44 studies of 3101 women who had both MRI and breast biopsies. Summary ROC was fitted, and bivariate analyses were performed. | The summary sensitivity of MRI was 90% (95% CI: 88 to 92%), and the specificity was 72% (95% CI: 67% to 77%). Meta-regressions found that the prevalence of cancer in the population being studied affected the accuracy, as did the criteria used to identify lesions as malignant.
The Blue Cross/Blue Shield Technology Evaluation Program, published in 2002^170^ and then updated in 2004^171^ | Systematic review of the literature on the use of MRI to evaluate suspicious breast lesions in order to avoid biopsies. The review included 25 prospective studies and 14 retrospective studies. Reported data were described and a small, informal cost-benefit analysis was performed. | Reported sensitivity for MRI ranged from 91% to 99%; specificity ranged from 31% to 91%; and negative predictive value ranged from 56% to 99%. The authors of the review pointed out that in many of the populations studied, small breast lesions had been specifically excluded, and therefore the diagnostic performance of MRI in the clinic, where smaller lesions are often encountered, may be less accurate than predicted from these studies. The authors of the review performed a small, informal cost-benefit analysis and concluded that the negative predictive value of MRI was too low, even under the best possible conditions, to recommend the use of MRI for this indication. The potential benefit of sparing patients from unnecessary biopsy was not found to outweigh the potential harm of missed or delayed diagnosis of breast cancer.
Hrung et al. 1999^172^ | A systematic review focused on women presenting with either a lesion that was palpably abnormal, or a BIRADS category 4 lesion detected by mammography. The review included 16 studies published between 1994 and 1997. Quality of the studies was rated on a 10-point scale (1 = highest quality, 10 = poorest quality). The data from the included studies were combined meta-analytically using the method of Littenburg and Moses.173 The authors then conducted a cost-effectiveness analysis. | The mean quality score of the included studies was 3.0, indicating low quality. The optimal operating point of MRI, chosen to have a sensitivity of 95%, was found to have a specificity of 67%. Breast MRI is cost-effective relative to needle core biopsy only if MRI performance achieves a sensitivity and specificity of 93%, and needle core biopsy performance is less than the best available estimates. Therefore, the authors concluded that choosing needle core biopsy instead of MRI both increased patients QALYs and lowered the average cost per patient.

### Conclusion

We found that the summary sensitivity of MRI for all lesions is 91.7 percent (95% CI: 88.5 to 94.1%) and the summary specificity is 77.5 percent (95% CI: 71.0 to 82.9%) (Table 5). The data are inconsistent (namely, demonstrated significant heterogeneity in our statistical model), but the estimate of sensitivity is precise, therefore the strength of evidence supporting the estimate of the sensitivity of MRI is moderate. The estimate of specificity is imprecise, and therefore the strength of evidence supporting the estimate of specificity of MRI is low.

Table 5 Magnetic resonance imaging (MRI) accuracy

| N Studies | N Lesions | Summary Sensitivity (95% CI) | Summary Specificity (95% CI) | Strength of Evidence
MRI, overall | 41 | 3,882 | 91.7% (88.5 to 94.1%) | 77.5% (71.0 to 82.9%) | Moderate (sensitivity)/Low (specificity)
MRI, lesions with microcalcifications | 8 | 692 | 84.3% (79.5 to 88.3%) | 79.4% (71.5 to 85.6%) | High (sensitivity), Moderate (specificity)
MRI, dense breasts vs. others | 2 | 935 | Results were inconsistent | Results were inconsistent | Insufficient
MRI, lesions classified as BIRADS 3 before MRI imaging | 1 | 56 | 100.0% (20.8 to 99.2%) | 96.4% (87.5 to 98.9%) | Insufficient
MRI, palpable lesions vs. non-nonpalpable lesions | 1 | 821 | MRI is more sensitive for palpable lesions | MRI is more specific for non- palpable lesions | Insufficient
MRI, small lesions vs. larger lesions | 1 | 53 | MRI is more sensitive for larger lesions | MRI is more specific for larger lesions | Insufficient
MRI, readers blinded vs. not | 41 | 3,882 | Sensitivity is lower if readers are blinded to patient clinical information | Specificity is not affected | Moderate
MRI, CAD assistance vs. not | 1 | 451 | Sensitivity is not affected | Specificity is not affected | Insufficient
MRI, patient age | 2 | 874 | Results were inconsistent | Specificity is not affected | Insufficient

The only patient or lesion “factor” that was found to affect the accuracy of MRI and that had sufficient evidence to support a conclusion was the consistent finding that the sensitivity of MRI for evaluation of microcalcifications is considerably lower than the sensitivity of MRI for evaluation of any/all lesions. The strength of evidence supporting this conclusion was rated as high.

To aid in interpretation of these findings, we used Bayes’ theorem and the summary likelihood ratios for MRI used to evaluate lesions in general and to evaluate lesions with microcalcifications (see Table 6 and Table 7). These calculations suggest that MRI examinations of women thought to have a higher than 12 percent pre-MRI probability of cancer will not be very clinically useful for diagnostic purposes because the input provided by the MRI examinations would probably not affect the suspicion of malignancy sufficiently to alter clinical decisions about management of the patient (e.g., recommendations for biopsy vs. followup). For many women an MRI examination will probably not result in a change in management or affect patient outcomes. In Figure 3, we illustrate models of theoretical changes in management that could be made after the use of MRI. Figure 3 demonstrates that the majority of women referred for biopsy after standard work-up (the left-most pathway) would probably experience no change in management after the addition of MRI to the work-up. The middle and right-most pathways in Figure 3 indicate that women with low (12% and 1%) suspicion of malignancy after standard work-up might have their risk of malignancy shift across the “change in management” thresholds after the addition of an MRI. Note that a “change in management” does not necessarily mean that the patient will benefit from the change. For example, a woman thought to have a 1 percent suspicion of malignancy may be referred for a biopsy instead of short-interval followup after an MRI; but in most cases this biopsy will return a “benign” finding, suggesting the primary clinical impact of the addition of an MRI exam to the work-up of this particular patient population may be to increase the rate of unnecessary biopsies.

Table 6 Clinical interpretations of magnetic resonance accuracy: benign finding on MRI

Pretest Probability of the Lesion Being Malignant | Post-test Probability of the Lesion Being Malignant Despite a Finding of “Benign” on the MRI Exam
Pretest Probability of the Lesion Being Malignant | Lesions in General^a^ | Lesions with Microcalcifications
1% | 0% (0 to 0%) | 0% (0 to 0%)
5% | 1% (0 to 1%) | 1% (0% to 1%)
10% | 1% (1 to 2%) | 2% (2 to 3%)
12% | 1% (1 to 2%) | Not calculated
20% | 3% (2 to 4%) | 5% (4 to 6%)
30% | 5% (3 to 6%) | 8% (6 to 10%)
40% | 7% (5 to 9%) | 12% (9 to 15%)
50% | 10% (7 to 13%) | 16% (13 to 21%)
60% | 14% (11 to 18%) | 23% (18 to 28%)
70% | 20% (16 to 26%) | 31% (26 to 38%)
80% | 31% (24 to 38%) | 44% (37 to 51%)
90% | 50% (42 to 57%) | 64% (57 to 70%)

a The summary negative likelihood ratio is 0.11 (95% CI: 0.079 to 0.15).

Table 7 Clinical interpretations of MRI accuracy: malignant finding on MRI

Pretest Probability of the Lesion Being Malignant | Post-test Probability of the Lesion Being Malignant After a Finding of “Malignant” on the MRI Exam
Pretest Probability of the Lesion Being Malignant | Lesions in General^a^ | Lesions with Microcalcifications
1% | 4% (3 to 5%) | 4% (3 to 5%)
5% | 18% (14 to 22%) | 18% (13 to 23%)
10% | 31% (26 to 37%) | 31% (25 to 39%)
20% | 50% (44 to 57%) | 51% (42 to 59%)
30% | 64% (57 to 69%) | 64% (56 to 71%)
40% | 73% (67 to 78%) | 73% (66 to 79%)
50% | 80% (76 to 84%) | 80% (75 to 85%)
60% | 86% (82 to 89%) | 86% (81 to 90%)
70% | 90% (88 to 93%) | 91% (87 to 93%)
80% | 94% (93 to 95%) | 94% (92 to 96%)
90% | 97% (97 to 98%) | 97% (96 to 98%)

a The summary positive likelihood ratio is 4.1 (95% CI: 3.1 to 5.3).

Figure 3 Possible clinical scenarios for MRI: theoretical changes in management

Figure 3 graphically demonstrates the possible impact of an MRI exam on patient management. Three flowcharts are placed side-by-side: on the left are women thought to be at high risk of breast cancer; after either a positive or negative MRI examination, the recommendation for “biopsy” remains unchanged. The middle flowchart is of women thought be at approximately 12% risk of malignancy; after a negative finding on MRI it is possible these women would have their management changed from “biopsy” to short-interval followup. At the right side of the figure is a flowchart of women thought be at low risk of malignancy; after a positive finding on MRI these women might find their management recommendation to change from short-interval followup to biopsy.

A critical question for the application of this finding is whether it is feasible for clinicians to precisely estimate pretest probability in this range. Many of our expert reviewers did not think it is possible using currently available risk assessment methods.

## Positron Emission Tomography

### Background

#### Technology

Positron emission tomography (PET) is a nuclear imaging modality that uses radioactive tracers to provide images of metabolic processes. Several different radiopharmaceuticals can be used in PET imaging. The tracer most commonly used is ^18^F-fluorodeoxyglucose (FDG). Fluorine-18 (^18^F) is a positron-emitting radionuclide, and this assessment will focus exclusively on PET scans that used FDG as a tracer. Fluorodeoxyglucose is a glucose analog that accumulates in tissue in proportion to the tissue’s metabolic activity. Rapidly dividing tumor cells metabolize large amounts of glucose. The uptake of the radioactive tracer FDG can be monitored by PET and provide images of regional glucose metabolism. Areas of elevated metabolism, which may be tumor cells, can be visualized on the PET images.

When performing a PET scan, a small amount of FDG is injected into the bloodstream, and a gamma camera, dedicated breast scanner, or whole-body scanner is used to generate images that highlight areas of high tracer uptake. Whole-body scanners have a ring of detectors that surround the patient and image the entire body. Gamma cameras have only two detectors, one at each side of the patient, and image only a restricted portion of the body. Dedicated breast scanners have two detectors designed to image only the breasts. The performance of the different cameras may vary. However, it is not clear how clinically relevant these differences are with respect to the accuracy of breast imaging.174

Other factors may also affect the quality of the breast image acquired through a PET scan. In general, longer image acquisition times will improve the image quality of any PET scan.174 However, other factors such as patient movement, comfort, and workflow suggest that acquisition times be kept to minimum. The optimum time depends on the characteristics of the detector, with dedicated breast cameras requiring the least amount of time (four to five minutes) and whole body scanners requiring the most time (45 to 60 minutes) to acquire the full image.174

In whole-body PET studies, it is standard practice to acquire a second set of images so that the reconstructed images can be corrected to account for differences in the attenuation of the gamma photons in different areas of the body (“attenuation correction”). In breast imaging some operators believe that attenuation correction is essential for tumor localization and quantification of uptake.175

The standardized uptake value (SUV), which is the mean tracer activity detected normalized for the injected dose of tracer and body weight, is dependent on the image reconstruction algorithm.174 The reconstruction algorithm is manufacturer dependent. Therefore, diagnostic performance of breast PET imaging may vary across manufacturers. Diagnostic performance may also vary depending on study-specific factors such as FDG uptake time, patient motion, size of the lesion, histology of lesion, patient weight, blood glucose level, patient position, spatial resolution, and interpretation of the breast image.175–177

According to Rosen et al., stand-alone whole-body PET scanners for oncology indications are rapidly becoming obsolete.178 Combined computed tomography (CT)/PET systems are increasingly available and currently account for almost all of the new whole-body PET installations. These systems allow images of metabolism and anatomy to be obtained at the same time. The combined machine uses x-rays to generate 3D anatomical images (CT scanning) upon which the PET images of metabolism can be overlaid on a computer workstation. In this report, whole-body scanners that combine PET with CT and stand-alone PET scanners will be considered as separate technologies.

#### Patient Safety and Comfort

Using a typical dose for a whole-body scan, the effective radiation dose delivered during a typical PET study is 19 μSv/MBq (the value depends on how often the patient voids). This translates to 7.6 mSv for a typical 400 MBq whole-body PET exam. The use of a combined CT/PET scanner also exposes the patient to x-rays. A typical abdominal CT scan exposes the body to approximately 10 mSv, for a total of around 18 mSv for a single PET/CT study.179 For comparison, a typical x-ray mammogram exposes women to 0.36 mSV.180 Studies of atomic-bomb survivors and radiation workers have found a significant increase in the risk of cancer after exposure to as little as 20 mSv.179 Therefore, radiation dose from PET/CT scans may be a health concern. Following the exam, the short half-life of ^18^F means that additional precautions, such as avoiding public transportation, are not necessary.181

The intravenous administration of any pharmaceutical could lead to an adverse reaction. In a retrospective analysis of 81,801 administrations of PET radiopharmaceuticals, the number of serious adverse reactions reported was zero.182 Therefore, PET radiopharmaceuticals can be considered safe. All PET studies require the patient to relax for about an hour before image acquisition begins. In a whole-body PET camera, the patient must lie prone for 15 minutes to an hour, depending on the coverage of the study. No significant patient comfort issues have been reported.

#### Accreditation Factors

The Intersocietal Commission for the Accreditation of Nuclear Medicine Laboratories (ICANL) offers voluntary accreditation to facilities based on a peer review of their staff’s qualifications, education, equipment, quality control, and volume of clinical procedures.183

All medical and technical staff are required to meet specific minimum experience and education requirements in order for their facility to be accredited by ICANL. Options available to a facility’s medical staff range from board certification in nuclear medicine to board certification in a specialty area with a minimum number of years’ practice and volume of studies interpreted.

The accreditation program requires the technical director and all technologists working in the facility to hold the RT(N) credential from the American Registry of Radiologic Technologists (ARRT) or the CNMT credential from the Nuclear Medicine Technology Certification Board (NMTCB). In all situations, the physician is ultimately responsible to see that the appropriate images are obtained.

### Findings From 2006 Review

In the 2006 version of this CER, we included eight prospective diagnostic cohort studies of 226 breast lesions that were examined by whole-body PET scanning34,35,41,55,184–187 and one study of 50 patients that compared whole-body PET scanning to PET imaging with a gamma camera.188 We found that for suspicious lesions in general, at a fixed sensitivity of 95 percent, the specificity of whole-body PET scanning was only 46.7 percent. At the mean threshold of the included studies, the sensitivity of PET scanning was 82.2 percent and the specificity was 78.3 percent. There were no or insufficient data to come to any conclusions about the use of PET to evaluate any sub-populations of patients. Finally, we found that whole-body PET scanning was more accurate than gamma camera PET imaging for ruling out breast cancer. No studies of dedicated breast PET scanners met the inclusion criteria.

### Evidence Base

Our literature searches identified seven diagnostic cohort studies of 18-fluorodeoxyglucose PET that met our inclusion criteria34,35,41,52–55 and one study of the diagnostic value of dual-time point FDG-PET/CT.16 All of the studies used a whole-body PET scanner. We did not identify any studies that used PEM devices and met the inclusion criteria.

The included studies enrolled 398 patients who were all women with suspicious lesions detected by physical exam, mammography, or ultrasound. Overall, a total of 403 lesions were detected. One of the studies excluded patients with lesions smaller than 1.0 cm (Brix et al.41). Patients ranged in age from 21 to 91, and reported mean ages ranged from 48.3 to 58.0, suggesting that the patient populations studied are younger than the typical breast cancer population. In all seven studies, final diagnosis was established through biopsy or surgery. One study also clinically followed patients who were diagnosed as benign at biopsy (Kaida et al. 2008^52^). The included studies are listed in Table 8 at the end of this subsection on PET, and are described in detail in the Appendixes.

Table 8 Included studies: PET and PET/CT

Study | PET Methods Studied | Study Design^*^ | Number of Patients
Imbriaco et al. 2008^16^ | PET/CT | Diagnostic cohort study | 44
Kaida et al. 2008^52^ | Whole body PET | Prospective cohort study | 118
Buchmann et al. 2007^53^ | Whole body PET | Prospective cohort study | 29
Hienisch et al. 2003^34^ | Whole body PET | Prospective cohort study | 36
Walter et al. 2003^35^ | Whole body PET | Prospective cohort study | 44
Brix et al. 2001^41^ | Whole body PET | Prospective cohort study | 14
Schirrmeister et al. 2001^54^ | Whole body PET | Prospective cohort study | 117
Yutani et al. 2000^55^ | Whole body PET | Prospective cohort study | 40

* At times it was difficult to determine if a study was prospective or retrospective, and in those cases we defaulted to simply calling it a “diagnostic cohort study.”

The single included study of PET/CT enrolled a total of 44 patients with 55 suspicious breast lesions detected by physical examination, mammography, or ultrasound.16 No studies of dedicated breast PET scanners met the inclusion criteria.

#### Key Question 1 What is the accuracy of PET for diagnosis of breast cancer in women referred for further evaluation after identification of a possible breast abnormality on routine screening (mammography and/or clinical or self-detection of a palpable lesion)?

Seven studies reported results for 403 lesions in patients referred for further evaluation by whole-body PET scanning for suspicious breast lesions (abnormal mammogram and/or physical examination and/or ultrasound examination), summarized in Table 8. When combined in a mixed-effects bivariate model, the summary sensitivity of PET for all lesions was 83.0 percent (95% CI: 73.0 to 89.0%), and the summary specificity was 74.0 percent (95% CI: 58 to 86%), findings that are virtually identical to our estimates in the 2006 CER (Table 9). However, the data were found to contain significant heterogeneity (I^2^ = 64.0%), indicating substantial variability across the study results. The observed heterogeneity could not be explained through meta-regression using the following covariates: position (prone versus supine), enrolled mostly patients with palpable lesions (>75% vs. <75% or not reported), and blinded to patient clinical information (versus not blinded or not reported).

Table 9 PET accuracy

Category | N Studies | N Lesions | Summary Sensitivity (95% CI) | Summary Specificity (95% CI) | Strength of Evidence
PET | 7 | 403 | 83.0% (73.0 to 89.0%) | 74.0% (58.0 to 86%) | Low
PET/CT | 1 | 55 | 80% (63 to 89%) | 100% (63 to 100%) | Insufficient
PET, palpable lesions | 3 | 275 | 86.5% (81.4 to 90.7%) | 64.2% (49.8 to 76.9%) | Low
PET, prone vs. supine | 1 | 122 | PET performed in the prone position is more sensitive | Patient position did not affect specificity of PET | Insufficient
PET, BIRADS 5 lesions | 1 | 26 | 93% (76.5% to 99.1%) | 100.0% (15.7% to 84.3%) | Insufficient
PET, large lesions | 1 | 27 | 79.4% (62.1% to 91.3%) | 100.0% (2.5% to 100.0%) | Insufficient
PET, patients younger than age 65 | 1 | 25 | 78.1% (60.0% to 90.7%) | 100.0% (15.8% to 100.0%) | Insufficient

Because the PET data are inconsistent and imprecise, we rated the strength of evidence supporting the estimate of accuracy as “low.”

The study of PET/CT was a single-center study that enrolled a total of 44 patients with 55 suspicious breast lesions detected by physical examination, mammography, or ultrasound.16 PET scanning was performed at two time points. The first acquisition (Time 1) occurred immediately after an initial whole-body PET scan, and the second one (Time 2) occurred three hours after the first. At both time points, the images of the breast were acquired in the prone position. The CT data were used for attenuation correction, and images were reconstructed using a standard iterative algorithm.

The authors reported that dual-time point PET/CT (Time 2) demonstrated a sensitivity of 80 percent and specificity of 100 percent compared to a sensitivity of 62 percent and specificity of 100 percent for single time-point PET/CT. The authors concluded that malignant lesions showed a significant increase in FDG over time compared to benign lesions.

#### Key Question 2 Are there demographic (e.g., age) and clinical risk factors (e.g., morphologic characteristics of the lesion) that affect the accuracy of the tests considered in Key Question 1?

In three of the seven studies that addressed Key Question 1, the majority (>75.0%) of the women presented with palpable breast lesions— Kiada et al.52: 88.0 percent palpable, Schirrmeister et al.54: 76.0 percent, and Yutani et al.55: 93.0 percent palpable. Because there were only three studies, we could not fit the data in a bivariate model. Instead, we pooled the reported sensitivities and specificities in random-effects meta-analyses. However, the data were heterogeneous (I^2^ = 68.0% and I^2^ = 54.6% for sensitivity and specificity, respectively), indicating substantial variability among the study results. With only three studies, we did not attempt to explore possible reason(s) for the heterogeneity. The overall sensitivity for primarily palpable lesions is higher than that for all seven studies considered under Key 1 (86.5% vs. 83.0%), but the specificity is lower (64.2% vs. 74.0%).

One study directly compared images acquired when patients were in prone position to images of the same patients in supine position.52 In this study by Kaida et al. 2008, 118 women with 122 lesions suspected of having breast cancer underwent whole-body PET in the supine position immediately followed by prone breast PET imaging. According to the results reported in the study, the sensitivity and specificity of images in the supine position were 83.0 percent and 50.0 percent, respectively. The sensitivity and specificity of images in the prone position were 96.0 percent and 50.0 percent, respectively.

One study, Yutani et al. 2000, reported results separately for patients with BIRADS 5, lesions 1.5 cm or larger, and who were younger than 65.^55^ The authors reported that PET was more sensitive for larger lesions, but the specificity was unchanged; and for the other factors, the accuracy of PET was virtually the same as for PET for all patients.

#### Key Question 3 Are there other factors and considerations that may affect the accuracy or acceptability of the tests considered in Key Questions 1 and 2?

None of the seven studies on stand-alone PET scanning or the one study on PET with CT reported information that addressed this question.

### Previously Published Systematic Reviews

We identified two systematic reviews of PET for differential diagnosis of breast lesions. The review published by Sampson et al. in 2002 assessed the performance of PET in the differential diagnosis of benign and malignant lesions among patients with abnormal mammograms or a palpable breast mass.189,190 The review included 13 articles published before March 2001. A more recent review was written by Escalona et al. and published in 2010.^191^ This review included 16 studies of PET for diagnosis of breast lesions published before February 2007.

Sampson et al. performed a meta-analysis using a random-effects model, and selected a point on the summary ROC that reflected test performance, with a sensitivity of 89 percent and a specificity of 80 percent. When the prevalence of malignancy was 50 percent, 40 percent of all patients would benefit by avoiding the harm of a biopsy with negative biopsy results. However, the negative predictive value was found to only be 88 percent. For a patient with a negative PET scan, the authors concluded that a 12 percent chance of a missed or delayed diagnosis of breast cancer is too high to make it worth the 88 percent chance of avoiding biopsy of a benign lesion.189,190

Escalona et al. conducted a narrative discussion of the included studies and their findings. The authors concluded that “FDG-PET does not appear to be sufficiently accurate to be used in isolation for ruling out the presence of a primary tumour.”191

### Conclusion

We found that the summary sensitivity of PET for all lesions is 83.0 percent (95% CI: 73.0 to 89.0%) and the summary specificity is 74.0 percent (95% CI: 58.0 to 86.0%). The data are, however, inconsistent and imprecise, therefore the strength of evidence supporting the estimate of the accuracy of PET is low.

There was insufficient data reported by the studies to conclude much about the impact of various factors on the accuracy of PET. PET may be equally accurate for evaluation of palpable lesions as for evaluation of lesions in general, but only three studies reported information about palpable lesions only.

To aid in interpretation of these findings, we used Bayes’ theorem and the summary likelihood ratios for PET used to evaluate lesions in general (see Table 10 and Table 11). These calculations suggest that PET examinations of women thought to have a higher than 5 percent chance of malignancy will not be very clinically useful for diagnostic purposes because the input provided by the PET examination would probably not affect the suspicion of malignancy sufficiently to alter clinical decisions about management of the patient (e.g., recommendations for biopsy vs. followup). A critical question for the application of this finding is whether it is feasible for clinicians to precisely estimate pretest probability in this range. Several of our expert reviewers did not think it is possible using currently available risk assessment methods. For many women a PET examination will probably not result in a change in management or affect patient outcomes. This is further illustrated in Figure 4, where models of theoretical changes in management that could be made after the use of PET are shown graphically.

Figure 4 Possible clinical scenarios for positron emission tomography (PET): theoretical changes in management

Figure 4 graphically demonstrates the possible impact of a PET exam on patient management. Three flowcharts are placed side-by-side: on the left are women thought to be at high risk of breast cancer; after either a positive or negative PET examination, the recommendation for “biopsy” remains unchanged. The middle flowchart is of women thought be at approximately 5% risk of malignancy; after a negative finding on PET it is possible these women would have their management changed from “biopsy” to short-interval followup. At the right side of the figure is a flowchart of women thought be at low risk of malignancy; after a positive finding on PET these women might find their management recommendation to change from short-interval followup to biopsy.

Table 10 Clinical interpretations of PET accuracy: benign finding on PET

Pre-test Probability of the Lesion Being Malignant | Post-test Probability of the Lesion Being Malignant Despite a Finding of “Benign” on the PET Exam
Pre-test Probability of the Lesion Being Malignant | Lesions in General^a^
1% | 0% (0 to 0%)
5% | 1% (1 to 2%)
10% | 3% (2 to 4%)
20% | 6% (4 to 8%)
30% | 9% (6 to 14%)
40% | 14% (9 to 20%)
50% | 19% (13 to 27%)
60% | 26% (18 to 36%)
70% | 36% (26 to 46%)
80% | 49% (38 to 60%)
90% | 68% (57 to 77%)

a The summary negative likelihood ratio is 0.24 (95% CI: 0.15 to 0.37).

Table 11 Clinical interpretations of PET accuracy: malignant finding on PET

Pre-test Probability of the Lesion Being Malignant | Post-test Probability of the Lesion Being Malignant After a Finding of “Malignant” on the PET Exam
Pre-test Probability of the Lesion Being Malignant | Lesions in General^a^
1% | 3% (2 to 5%)
5% | 14% (9 to 22%)
10% | 26% (17 to 38%)
20% | 44% (32 to 57%)
30% | 58% (45 to 70%)
40% | 68% (56 to 78%)
50% | 76% (66 to 84%)
60% | 83% (74 to 89%)
70% | 88% (82 to 93%)
80% | 93% (88 to 96%)
90% | 97% (94 to 98%)

a The positive likelihood ratio is 3.2 (95% CI: 1.9 to 5.4).

## Scintimammography

### Background

#### Technology

Scintimammography (SMM) is similar to PET scanning in that it detects tissues that accumulate higher levels of a radioactive tracer. The tracer most commonly used for breast examination is ^99m^technetium-sestamibi (MIBI), and this assessment will only evaluate studies that used MIBI as the tracer. MIBI has a strong affinity for breast tumors, but may also accumulate in areas of inflammation or infection.192 A method of improving visualization of tumor tissue specifically is “double phase” SMM, in which two sets of images, one acquired immediately after administration of the tracer, and one approximately 30 minutes later, are acquired and compared. Gamma cameras used for scintimammography are designed to perform either planar imaging or single photon emission tomography (SPECT). In planar imaging, each imaged point represents the superimposition of all materials in front and behind it over-laid into a two-dimensional image. This causes objects that are perpendicular to the image to appear shortened.193 SPECT is a technique that uses multiple camera heads and computer processing to create a three-dimensional representation of the administered radiopharmaceutical taken up by tissue.

Scintimammography with MIBI may have limited spatial resolution for demonstrating cancers with diameters smaller than 10 mm.194–196 The sensitivity of scintimammography has also been reported to be affected by type of tumor, size of tumor, and the phase of the menstrual cycle.197 Scintimammography has been reported to be unaffected by the presence of a breast implant or by the density of the breast tissue.197

Breast specific gamma imaging (BSGI) is an offshoot of scintimammography. In 1999, Dilon Technologies received FDA 510(k) clearance for a BSGI camera. Their current product, the Dilon 6800®, is purported to overcome the obstacles of traditional scintimammography by providing a high resolution image with a small field of view. Specifically, the manufacturer claims it can identify very early stage cancers, about 1 mm in size; is not affected by breast density; can differentiate benign from malignant lesions; and is smaller than traditional gamma imaging systems, allowing for easy portability from site to site.198

#### Patient Safety and Comfort

A typical scintimammography study exposes the patient to approximately 9 mSv.199 For comparison, a typical x-ray mammogram exposes the patient to 0.36 mSv.180

Intravenous injection of MIBI has been associated with very few reported adverse reactions.200 A case of a patient without a past history of allergies, who developed a rash following administration of MIBI, has been reported in the literature.201 Another study reports, in addition to rash development, patients experiencing a strange taste following injection of MIBI.202

Other than removal of all clothing and jewelry above the waist, no special preparation is required of patients undergoing a scintimammography imaging study. Compared to other breast imaging procedures, scintimammography imaging takes longer to perform – forty minutes or more.203 During a typical study, the patient is placed in a prone position with the breast to be imaged hanging down.204 Although taut compression of the breast to be imaged is not required, prevention of cross-talk may require compression of the opposite breast.195,205

#### Accreditation Factors

The Intersocietal Commission for the Accreditation of Nuclear Medicine Laboratories (ICANL) offers voluntary accreditation to facilities based on a peer review of their staff’s qualifications, education, equipment, quality control, and volume of clinical procedures.183

All medical and technical staff are required to meet specific minimum experience and education requirements in order for their facility to be accredited by ICANL. Options available to a facility’s medical staff range from board certification in nuclear medicine to board certification in a specialty area with a minimum number of years’ practice and volume of studies interpreted.

The accreditation program requires the technical director and all technologists working in the facility to hold the RT(N) credential from the American Registry of Radiologic Technologists (ARRT) or the CNMT credential from the Nuclear Medicine Technology Certification Board (NMTCB). In all situations, the physician is ultimately responsible to see that the appropriate images are obtained.

### Findings From 2006 Review

Forty-four diagnostic cohort studies published in 45 manuscripts met our inclusion criteria.32,36,44,55,85,163,166,167,185,206–241 Our analysis found that for non-palpable lesions, at a fixed 95 percent sensitivity, the specificity of scintimammography was only 39.2 percent. At the mean threshold of the included studies, the sensitivity was 68.7 percent and the specificity was 84.8 percent. For palpable lesions and suspicious breast lesions in general, there was unexplained heterogeneity in the data, and therefore summary diagnostic test characteristics were not calculated.

### Evidence Base

Our literature searches identified a total of 11 studies of 1,064 patients that met the inclusion criteria for Key Question 1. One study evaluated BSGI;19 another tested planar and SPECT imaging combined;56 five studies assessed double-phase scintimammography;14,57–60 and the remaining four studies assessed planar imaging.61–64 These studies are described in detail in the Appendixes, and are listed at the end of this subsection on scintimammography in Table 13.

Table 13 Included studies: scintimammography

Study | Scintimammography Methods Studied | Design^*^ | N Patients
Grosso et al. 2009^61^ | Planar scintimammography with patient supine and prone | Prospective diagnostic cohort | 283
Habib et al. 2009^57^ | Double-phase scintimammography with patients supine and prone | Prospective diagnostic cohort | 22
Kim et al. 2009^14^ | Double-phase scintimammography | Prospective diagnostic cohort | 249
Kim et al. 2008^58^ | Double-phase scintimammography | Prospective diagnostic cohort | 75
Wang et al. 2008^62^ | Planar scintimammography | Prospective diagnostic cohort | 55
Brem et al. 2007^19^ | BSGI | Diagnostic cohort | 33
Gommans et al. 2007^63^ | Planar scintimammography | Prospective diagnostic cohort | 101
Kim et al. 2007^59^ | Double-phase scintimammography | Prospective diagnostic cohort | 78
Schillaci et al. 2007^64^ | Planar scintimammography | Prospective diagnostic cohort | 53
Pinero et al. 2006^60^ | Double phase scintimammography | Prospective diagnostic cohort | 88
Mathieu et al. 2005^56^ | SPECT | Retrospective chart review | 37

* At times it was difficult to determine if a study was prospective or retrospective, and in those cases we defaulted to simply calling it a “diagnostic cohort study.”

#### Key Question 1 What is the accuracy of scintimammography for diagnosis of breast cancer in women referred for further evaluation after identification of a possible breast abnormality on routine screening (mammography and/or clinical or self-detection of a palpable lesion)?

When all 11 studies were combined in the analysis, regardless of imaging technique(s) used, the summary sensitivity of SMM for all lesions was 84.7 percent (78.0 to 89.7%) and the summary specificity was 77.0 percent (95% CI: 64.7 to 85.9%). We also meta-analyzed the data reported by the nine included studies that used standard SMM (planar and double-phase imaging) by fitting a bivariate mixed-effects model. The summary sensitivity of standard SMM for all lesions was 84 percent (95% CI: 76% to 89%) and the summary specificity was 79 percent (95% CI: 63% to 89%), approximately the same as for the full dataset. In 2006, we found that the sensitivity of scintimammography was 68.7 percent and the specificity was 84.8 percent. Improvements in technology and techniques since then, such as the development of double-phase imaging, may explain the improved accuracy in the more recent studies.

There was a great deal of heterogeneity (I^2^ = 93%) in the reported data. We were unable to identify with meta-regression any study-related characteristics that explained this heterogeneity, such as consecutive enrollment of patients, blinding of the diagnostic test reader to patient history/other clinical information, and use of the gold standard (biopsy) as the reference standard.

#### Key Question 2 Are there demographic (e.g., age) and clinical risk factors (e.g., morphologic characteristics of the lesion) that affect the accuracy of the tests considered in Key Question 1?

Two studies evaluated only patients with palpable breast masses,57,62 one study evaluated only patients with non-palpable breast masses,63 and one study evaluated only patients with microcalcifications detected on x-ray mammography.61 With so few studies reporting on each category, evidence-based conclusions are difficult to support.

None of the studies reported outcomes by patient demographics or any other clinical risk factors that may have affected the accuracy of SMM.

#### Key Question 3 Are there other factors and considerations that may affect the accuracy or acceptability of the tests considered in Key Questions 1 and 2?

None were identified.

### Previously Published Systematic Reviews

We identified two decision/cost effectiveness analyses and four systematic reviews of the use of scintimammography to evaluate women after a positive mammography exam. The majority of these analyses were published prior to publication of most of the studies included in the present report. The findings of these reports are briefly summarized in Table 12. The accuracy of scintimammography reported by all four systematic reviews is very similar to our findings—a summary sensitivity of approximately 85 percent. Most of the systematic reviews reported a slightly higher (approximately 85%) specificity than our finding of approximately 80 percent specificity, but the confidence interval around our estimate of 80 percent is wide (imprecise estimate).

Table 12 Other published technology assessments of scintimammography

Study | Methods | Conclusions
Hussain and Buscombe 2006^242^ | A meta-analysis of trials of scintimammography for diagnosis of breast cancer was performed. Studies that included more than 100 patients published since 1997 were identified and included. | The overall sensitivity was 85% and the specificity was 84%.
Liu et al. 2005^243^ | A systematic review and meta-analysis intended to determine the value of scintimammography in diagnosing primary breast cancer. The authors of the review excluded the bulk of the published literature on the basis of “poor quality.” | The overall sensitivity was 86% and specificity was 80% for diagnosis of breast cancer by scintimammography; these numbers dropped to 69% for diagnosis of non-palpable lesions
Medical Advisory Secretariat, Ontario Ministry of Health 2003^200^ | A systematic review of the literature on the effectiveness of scintimammography in breast cancer detection. Studies published between 1992 and 2002 were eligible for inclusion. Seven studies directly comparing ultrasound to scintimammography, and 49 studies assessing the accuracy of scintimammography, were included. The data from the included studies were combined meta-analytically using the method of Littenburg and Moses.173 | The authors concluded that scintimammography is an effective imaging technique that can improve the ability to classify patients correctly. Summary receiver operating curves were shown, but no summary test characteristics were derived.
Liberman et al. 2003^244^ | A systematic review of the literature on the accuracy of scintimammography in the diagnosis of breast cancer. The review included 64 papers published between January 1967 and December 1999. The diagnostic test characteristics were individually combined meta-analytically in a fixed-effects model. Quality of the studies was formally assessed and used to weight the studies in the meta-analysis. | The aggregated summary test characteristics for scintimammography were 85.2% sensitivity and 86.6% specificity. For patients with a palpable mass, sensitivity was 87.8% and specificity was 87.5%. For patients without a palpable mass, lesions detected by mammography, sensitivity was 66.8% and specificity was 86.9%. The authors of the review concluded that scintimammography may be used effectively as an adjunct to mammography and physical examination in the diagnosis of breast cancer.
Allen et al. 2000^245^ | A decision tree sensitivity analysis comparing three patient management strategies: core needle biopsy after indeterminate or positive mammograms; core needle biopsy after positive mammograms, but patients with indeterminate mammograms were examined by scintimammography, and sent for core biopsy only if positive by scintimammography; all patients with indeterminate or positive mammograms were examined by scintimammography, and sent for core biopsy only if positive by scintimammography. Values used in the analysis were derived from the general literature. | The model predicted that the use of scintimammography would save money by reducing the number of biopsies, but at a cost of lost life expectancy. The use of scintimammography after indeterminate mammograms would save $189 million per year (assuming 21 million women undergo mammographic screening per year) at a cost of a loss of 0.000178 years of mean life expectancy. The use of scintimammography after positive and indeterminate mammograms would save $420 million per year, at a cost of a loss of 0.000222 years of life expectancy.
Hillner 1997^246^ | A decision analysis model comparing scintimammography to core biopsy and open surgical biopsy for hypothetical cohorts of women with nonpalpable breast lesions detected by mammography. The performances of scintimammography and biopsy were estimated from the general literature. | The model predicted that per 1,000 women, core biopsy would miss seven invasive and 10 in situ cancers, as compared to open surgery. Scintimammography would miss an additional 16 invasive cancers and 12 in situ cancers, as compared to core biopsy. However, most missed cancers would be detected if all women with negative findings received a 6-month followup mammography, and 65% of women undergoing scintimammography would be able to avoid any type of biopsy. Compared to undergoing immediate surgery, costs would be reduced by 20% with core biopsy, and by 39% with scintimammography. For each cancer diagnosis that was delayed by six months, the authors concluded that scintimammography would save $77,500.

### Conclusion

The estimates of the accuracy of various types of scintimammography, along with a rating of the strength of evidence supporting the accuracy estimate, are summarized in Table 14. We found that the summary sensitivity of scintimammography for all lesions was 84.7 percent (95% CI: 78.0 to 89.7%) and the summary specificity was 77.0 percent (64.7 to 85.9%). The data are, however, inconsistent and imprecise, therefore the strength of evidence supporting the estimate of the accuracy of scintimammography is low.

Table 14 Scintimammography accuracy

Category | N Studies | N Lesions | Summary Sensitivity (95% CI) | Summary Specificity (95% CI) | Strength of Evidence
Scintimammography, any | 11 | 1,064 | 84.7% (78.0 to 89.7%) | 77.0% (64.7 to 85.9%) | Low
Scintimammography, double-phase planar | 5 | 502 | 84.6% (73.2 to 91.7%) | 72.8% (59.2 to 83.1%) | Low
Scintimammography, planar | 4 | 492 | 81.5% (74.3 to 87.3%) | 82.1% (77.6 to 86.0%) | Low
Scintimammography, BSGI | 1 | 33 | 88.9% (51.8 to 99.7%) | 70.8% (48.9 to 87.4%) | Insufficient
Scintimammography, SPECT | 1 | 37 | 95.0% (75.1 to 99.9%) | 70.6% (44.0 to 89.7%) | Insufficient
Scintimammography, palpable lesions | 2 | 77 | 85.0% (73.4 to 92.9%) | 90.5% (80.4 to 96.4%) | Insufficient
Scintimammography, nonpalpable lesions | 1 | 101 | 82.2% (67.9 to 92.0%) | 92.9% (82.7 to 98.0%) | Insufficient
Scintimammography, microcalcifications | 1 | 283 | 78.1% (60.0 to 90.7%) | 82.5% (77.2 to 87.0%) | Insufficient

There was insufficient data reported by the studies to conclude much about the impact of patient demographics, clinical risk factors, lesion types, or other various factors on the accuracy of scintimammography.

To aid in interpretation of these findings, we used Bayes’ theorem and the summary likelihood ratios for scintimammography used to evaluate lesions in general (see Table 15 and Table 16). These calculations suggest that SC examinations of women thought to have a higher than 5 percent pre-SC probability of cancer will not be very clinically useful for diagnostic purposes because the input provided by the SC examinations would probably not affect the suspicion of malignancy sufficiently to alter clinical decisions about management of the patient (e.g., recommendations for biopsy vs. followup). Whether it is feasible for clinicians to estimate prior probability in this range is unclear; several of our expert reviewers did not think estimates could be this precise using currently available methods. For many women a SC examination will probably not result in a change in management or affect patient outcomes. In Figure 5 we illustrate models of theoretical changes in management that could be made after the use of scintimammography.

Figure 5 Possible clinical scenarios for scintimammography (SC): theoretical changes in management

SC = scintimammography

Figure 5 graphically demonstrates the possible impact of a SMM exam on patient management. Three flowcharts are placed side-by-side: on the left are women thought to be at high risk of breast cancer; after either a positive or negative SMM examination, the recommendation for “biopsy” remains unchanged. The middle flowchart is of women thought be at approximately 5% risk of malignancy; after a negative finding on SMM it is possible these women would have their management changed from “biopsy” to short-interval followup. At the right side of the figure is a flowchart of women thought be at low risk of malignancy; after a positive finding on SMM these women might find their management recommendation to change from short-interval followup to biopsy.

Table 15 Clinical interpretations of scintimammography accuracy: benign finding on scintimammography

Pre-test Probability of the Lesion Being Malignant | Post-test Probability of the Lesion Being Malignant Despite a Finding of “Benign” on the SC Exam
Pre-test Probability of the Lesion Being Malignant | Lesions in General^a^
1% | 0% (0 to 0%)
5% | 1% (1 to 2%)
10% | 2% (2 to 3%)
20% | 5% (3 to 6%)
30% | 8% (6 to 11%)
40% | 12% (9 to 16%)
50% | 17% (13 to 22%)
60% | 23% (18 to 29%)
70% | 32% (25 to 39%)
80% | 44% (36 to 52%)
90% | 64% (56 to 71%)

a The summary negative likelihood ratio is 0.21 (95% CI: 0.15 to 0.29).

Table 16 Clinical interpretations of scintimammography accuracy: malignant finding on scintimammography

Pre-test Probability of the Lesion Being Malignant | Post-test Probability of the Lesion Being Malignant After a Finding of “Malignant” on the Scintimammography Exam
Pre-test Probability of the Lesion Being Malignant | Lesions in General^a^
1% | 4% (2 to 5%)
5% | 17% (10 to 26%)
10% | 29% (21 to 39%)
20% | 48% (37 to 59%)
30% | 61% (51 to 71%)
40% | 71% (61 to 79%)
50% | 79% (71 to 85%)
60% | 85% (78 to 89%)
70% | 90% (85 to 93%)
80% | 94% (91 to 96%)
90% | 97% (96 to 98%)

a The summary positive likelihood ratio is 3.9 (95% CI: 2.2 to 6.8).

## Ultrasound

### Background

#### Technology

Ultrasound waves are high-frequency sound waves that reflect at boundaries between tissues with different acoustic properties. Ultrasound is commonly used to distinguish between solid breast lesions and cysts, and to guide biopsy needles.247

The most commonly used type of ultrasound (conventional, or regular, ultrasound) may be referred to as B-mode gray-scale ultrasound.248 The contrast resolution of conventional ultrasound depends on the transducer’s frequency. All modern breast imaging applications employ high frequency transducers (7 MHz or higher). Ultrasound images obtained by B-mode gray-scale imaging use differences in the brightness of the image (caused by different ways the ultrasound waves reflect and absorb off tissue interfaces) to examine the internal anatomy of the breast.248 The echoes of the sound waves are combined to form two-dimensional images of the structure of the interior of the breast. Malignant breast lesions generally appear darker on the images than the surrounding normal tissues, and often have ill-defined borders.249–251

One of the known problems with B-mode ultrasound is that interpretation of the images is primarily done by visually inspecting the image. Differences in human perception and utilization of different features for use in diagnosis cause variability in diagnosis and reader-dependent variations in the accuracy of diagnosis.249 Computer-aided diagnosis (CAD) systems are under development to address this problem. CAD systems are designed to detect patterns in images that are suggestive of malignancy, and to draw the readers’ attention to the areas of suspicion.

Compound imaging is a variant on B-mode imaging that is intended to reduce the “noise” in the image and thus improve the image quality.249 Compound imaging takes multiple ultrasound views from different angles and combines the many views into a single two-dimensional image.

Another variant on B-mode ultrasound is harmonic imaging. B-mode ultrasound waves develop harmonics (multiples of the transmission frequency) as they pass through breast tissue. Digital encoding can be used by computers to construct images from the harmonic frequencies.248 Harmonic images generally have improved resolution and fewer artifacts than regular B-mode ultrasound.249

Doppler ultrasound uses ultrasound to evaluate blood flow through vessels. The speed of blood flow can be evaluated by observing changes in the pitch of the reflected sound waves (the Doppler effect). Malignant masses often exhibit increased rates and amounts of blood flow (increased vascularity) in comparison to benign tissues.249 Doppler imaging can also be performed with microbubble contrast agents that enhance imaging of blood vessels.249 Two primary types of Doppler imaging exist, color and power. Color Doppler imaging encodes the mean Doppler frequency shifts at particular locations in various colors, whereas power Doppler imaging encodes the power of the signal (extent of the Doppler effect) at particular locations in various colors.252 Color Doppler therefore detects the velocity of the blood cells while power Doppler detects the amount of blood present.252

Ultrasound tomography uses ultrasound to acquire multiple images of the breast from different angles, and uses a computer to develop a 3D image of the structure of the interior of the breast. We intended to include ultrasound tomography in this systematic review, but did not identify any studies that met the inclusion criteria.

#### Patient Safety and Comfort

Ultrasound is generally considered to be extremely safe. Ultrasound examinations that use microbubble contrast agents have the potential for patients to react to the agents, but most reactions appear to be transient and mild, and consist of alteration of taste, facial flushing, and pain at the injection site.253

During a typical ultrasound breast imaging study, the patient is placed in a supine oblique position, with a pillow under the shoulder and the arm extended behind the head.254 Because taut compression is not required, ultrasound is generally painless. As long as routine practices are followed, ultrasound breast imaging can be considered a safe exam for most patients.

#### Accreditation Factors

The American College of Radiology (ACR) has instituted a voluntary breast ultrasound accreditation program that offers facilities the opportunity for peer review of their staff’s qualifications, equipment, and quality control and quality assurance programs.255

A physician supervising and interpreting breast ultrasound examinations is required to meet specific minimum experience and education requirements in order for their facility to be accredited by the ACR.

The accreditation program requires sonographers/mammographers to be certified by the American Registry of Diagnostic Medical Sonography (ARDMS), or post-primary certification (“advanced registry”) in breast sonography by the American Registry of Radiologic Technologists (ARRT), or certification by the ARRT or unrestricted state license and qualified to do mammography under Mammography Quality Standards Act (MQSA). The physician is not required to be present during breast ultrasound examinations performed by ARDMS sonographers or ARRT technologists with certification in breast sonography. However, the physician must be in the department during breast ultrasound examinations performed by ARRT technologists without an advanced registry in breast sonography. In all situations, the physician is ultimately responsible to see that the appropriate images are obtained.

### Findings From 2006 Review

In the 2006 version of this CER, we included eight prospective diagnostic cohort studies of 5,348 breast lesions that were examined by B-mode gray-scale ultrasound.45,73,79,83,162,256–258 We found that for suspicious lesions in general, the sensitivity of ultrasound examination was 86.1 percent, the specificity was 66.4 percent, and the negative predictive value was 93.3 percent (for a population with a prevalence of disease of 25.7%). The stability of these estimates was judged to be moderate, indicating a small chance that publication of new evidence could substantially change these estimates.

### Evidence Base

Our literature searches identified 31 diagnostic cohort studies of various types of ultrasound published between 1994 and 2009.^18,26,45,60,65–91^ These studies included a total of 8,642 patients with 9,044 breast lesions. The included studies are listed in Table 17 at the end of this subsection on ultrasound, and are described in detail in the Appendixes. A complexity in interpreting the evidence base is that some of the women enrolled in the included studies may have undergone a prior B-mode grayscale ultrasound examination before being enrolled in the study. In many cases, the studies reported that only women with “solid” lesions were included in the study, suggesting that women found to have simple cysts by ultrasound were not part of the study population. Other studies reported that women found to “clearly benign” (probably fibroadenomas and simple cysts) lesions on ultrasound were not included in the study. We believe the use of these study inclusion criteria improves the applicability of the evidence base. In standard clinical practice a woman recalled for further evaluation would, under most circumstances, undergo an ultrasound examination to rule out cysts and obviously benign lesions before being examined more thoroughly for signs of malignancy (although in standard practice the diagnostic portion of the US exam and identification of simple cysts with US would probably be conducted during the same ultrasound session).

Table 17 Included studies: ultrasound

Study | US Methods Studied | Design^*^ | N Patients
Gokalp et al. 2009^65^ | B-mode 2D grayscale, power Doppler, and combination of both methods | Prospective diagnostic cohort | 49
Vassiou et al. 2009^18^ | B-mode 2D grayscale | Prospective diagnostic cohort | 69
Liu et al. 2008^66^ | B-mode 2D grayscale, with and without contrast (with Sono Vue [Bracco, Italy]), and combination of both methods | Diagnostic cohort study | 108
Vade et al. 2008^67^ | B-mode 2D grayscale | Retrospective chart review | 20
Cha et al. 2007^68^ | B-mode 2D grayscale and tissue harmonic imaging | Prospective diagnostic cohort | 88
Chala et al. 2007^69^ | B-mode 2D grayscale | Retrospective chart review | 203
Zhi et al. 2007^70^ | B-mode 2D grayscale | Diagnostic cohort study | 232
Cho et al. 2006^71^ | B-mode 2D and 3D grayscale | Prospective diagnostic cohort | 141
Pinero et al. 2006^60^ | Combination power Doppler and color Doppler using a contrast agent (Levovist [Schering AG, Berlin, Germany]) | Prospective diagnostic cohort | 88
Ricci et al. 2006^26^ | B-mode grayscale with and without contrast (with Sono Vue [Bracco, Italy]); also compared US to MRI | Prospective diagnostic cohort | 48
Forsberg et al. 2004^72^ | B-mode 2D grayscale and power Doppler, with and without contrast (Levovist or Optison) | Diagnostic cohort study | 55
Meyberg-Solomayer et al. 2004^73^ | B-mode 2D gray-scale | Prospective diagnostic cohort | 65
Ozdemir et al. 2004^88^ | Power Doppler, with or without contrast (Levovist) | Prospective diagnostic cohort | 80
Chen et al. 2003^74^ | B-mode 2D gray scale | Prospective diagnostic cohort | 32
Kook and Kwag 2003^75^ | B-mode US and power Doppler, with and without contrast (Levovist) | Prospective diagnostic cohort | 36
Marini et al. 2003^76^ | B-mode 2D grayscale | Diagnostic cohort study | 238
Caruso et al. 2002^84^ | Color Doppler with and without contrast (Levovist) | Prospective diagnostic cohort | 36
Koukouraki et al. 2001^85^ | Color Doppler | Prospective diagnostic cohort | 116
Malich et al. 2001^45^ | Combination of B-mode, power Doppler, and color Doppler; also compared US to MRI | Diagnostic cohort study | 94
Milz et al. 2001^89^ | Power Doppler | Prospective diagnostic cohort | 102
Reinikainen et al. 2001^77^ | B-mode US and power Doppler, with and without contrast (Levovist) | Prospective diagnostic cohort | 63
Moon et al. 2000^90^ | Power Doppler, with and without contrast (Levovist) | Prospective diagnostic cohort | 69
Blohmer et al. 1999^78^ | B-mode 2D gray-scale and color Doppler | Prospective diagnostic cohort | 200
Chao et al. 1999^79^ | B-mode 2D gray-scale | Prospective diagnostic cohort | 3,050
Schroeder et al. 1999^86^ | Power and color Doppler, with and without contrast (Levovist) | Prospective diagnostic cohort | 92
Albrecht et al. 1998^91^ | Power Doppler, with or without contrast (EchoGen) | Prospective diagnostic cohort | 20
Wilkens et al. 1998^80^ | B-mode 2D gray-scale and color Doppler | Diagnostic cohort study | 53
Buadu et al. 1997^87^ | Color Doppler | Diagnostic cohort study | 114
Stavros et al. 1995^81^ | B-mode 2D gray-scale | Prospective diagnostic cohort | 622
Ciatto et al. 1994^82^ | B-mode 2D gray scale | Prospective diagnostic cohort | 2,079
Perre et al. 1994^83^ | B-mode 2D gray-scale | Prospective diagnostic cohort | 380

* At times it was difficult to determine if a study was prospective or retrospective, and in those cases we defaulted to simply calling it a “diagnostic cohort study.”

#### Key Question 1 What is the accuracy of ultrasound for diagnosis of breast cancer in women referred for further evaluation after identification of a possible breast abnormality on routine screening (mammography and/or clinical or self-detection of a palpable lesion)?

##### B-mode 2D Grayscale

Twenty-one studies of 8,199 lesions addressed the accuracy of B-mode 2D grayscale.18,26,65–83 We combined the reported data in a bivariate binomial model. The summary sensitivity of B-mode 2D grayscale ultrasound for all lesions was 92.4 percent (95% CI: 84.6 to 96.4%) and the summary specificity was 75.8 percent (60.8 to 86.3%); there was, however, considerable heterogeneity in the data (I^2^ = 99.6%). In our 2006 assessment, we found that for suspicious lesions in general, the sensitivity of B-mode ultrasound examination was 86.1 percent, considerably lower than the findings of the current update; and we also found in 2006 that the specificity was 66.4 percent, lower than the 75.8 percent specificity of the current update. The 2006 version of the report included only a small subset of the evidence base included in the current update.

We conducted meta-regressions to explore the heterogeneity in the data. The variables we investigated were: whether the studies accounted for inter-reader differences; whether the studies blinded image readers to clinical information or not; whether all diagnoses were verified by histopathology or not; whether a prospective design was used; whether the study was funded by a source without a financial interest in the results or not; whether the study enrolled consecutive/all patients; the geographical location of the study; what type(s) of breast lesions were enrolled in the study; and the prevalence of disease in the study. Two of these variables, whether the studies accounted for inter-reader differences, and whether the studies blinded image readers to clinical information or not, were statistically significantly associated with the results (p = 0.01 and 0.03, respectively). Subgroup analyses found that studies that had blinded image readers to clinical information had a higher sensitivity (96.6% vs. 87.0%) but a much lower specificity (59.5% vs. 85.1%) than unblinded studies. Studies that had accounted for inter-reader differences had a similar sensitivity (93.4% vs. 93.0%) but a much lower specificity (52.7% vs. 90.1%) than studies that did not account for inter-reader differences.

##### B-mode 2D Grayscale, Contrast Enhanced

Only two studies of a total of 154 breast lesions reported on the accuracy of B-mode 2D grayscale contrast-enhanced ultrasound compared to non-contrast enhanced.26,66 Contrast enhancement was reported to increase the sensitivity (97.5% vs. 82.7%) but to not dramatically affect the specificity (76.7% vs. 74.0%).

##### B-mode 3D Grayscale

Only one study of 150 breast lesions, Cho et al., reported on the accuracy of B-mode 3D grayscale ultrasound.71

##### Color Doppler Ultrasound

Six studies of a total of 718 lesions reported on the accuracy of color Doppler ultrasound.78,80,84–87 We combined the data reported by these studies in a bivariate binomial model. The summary sensitivity of color Doppler ultrasound for all lesions was 88.5 percent (95% CI: 74.4 to 95.4%) and the summary specificity was 76.4 percent (95% CI: 61.7 to 86.7%). There was considerable heterogeneity in the data (I^2^ = 95.2%). Exclusion of data from two studies that enrolled only patients with palpable lesions80,85 from the bivariate model did not affect the results. There were too few studies of color Doppler to perform full meta-regressions.

##### Color Doppler Ultrasound, Contrast Enhanced

Two studies of 146 lesions compared the accuracy of contrast-enhanced color Doppler to non-enhanced color Doppler.84,86 Contrast-enhancement was found to slightly increase the sensitivity (97.8% vs. 95.7%) and to dramatically increase the specificity (90.7% vs. 55.6%).

##### Color Doppler Ultrasound Directly Compared With B-mode Grayscale Ultrasound

Two studies directly compared the accuracy of color Doppler ultrasound to B-mode grayscale ultrasound.78,80 Color Doppler was found to have a higher sensitivity (74.0% vs. 53.1%) but a lower specificity than B-mode ultrasound (84.0% vs. 96.3%).

##### Power Doppler Ultrasound

Nine studies of a total of 614 lesions reported on the accuracy of power Doppler ultrasound.65,72,75,77,86,88–91 We combined the data in a bivariate binomial model. The summary sensitivity of power Doppler ultrasound for all lesions was 70.8 percent (95% CI: 47.5 to 86.6%) and the summary specificity was 72.6 percent (95% CI: 59.9 to 82.5%). There was considerable heterogeneity in the data (I^2^ = 97.4%).

##### Power Doppler Ultrasound, Contrast Enhanced

Seven studies of 403 lesions reported on the accuracy of contrast-enhanced power Doppler ultrasound.72,75,77,86,88,90,91 When we combined the data in a bivariate binomial model, the summary sensitivity for all lesions was 89.3 percent (95% CI: 52.4 to 98.4%) and the summary specificity was 70.4 percent (95% CI: 55.4 to 82.0%). There was considerable heterogeneity in the data (I^2^ = 87.5%).

##### Power Doppler Ultrasound Directly Compared With B-mode Grayscale Ultrasound

Four studies of 248 lesions directly compared the accuracy of power Doppler ultrasound to B-mode grayscale ultrasound.65,72,75,77 Power Doppler was found to have a lower sensitivity (54.7% vs. 87.7%) but a higher specificity (79.4% vs. 50.7%) than B-mode grayscale ultrasound in these four direct comparisons.

##### Power Doppler Ultrasound Directly Compared With Color Doppler Ultrasound

One study directly compared the accuracy of power Doppler, with and without contrast-enhancement, to color Doppler, with and without contrast-enhancement.86 This study reported that all four methods had a 100 percent sensitivity, but specificity for contrast-enhanced methods was much higher than for non-contrast-enhanced methods.

##### Tissue Harmonics

Only one study of 91 lesions reported on the accuracy of tissue harmonic ultrasound methods.68

#### Key Question 2 Are there demographic (e.g., age) and clinical risk factors (e.g., morphologic characteristics of the lesion) that affect the accuracy of the tests considered in Key Question 1?

None were identified.

#### Key Question 3 Are there other factors and considerations that may affect the accuracy or acceptability of the tests considered in Key Questions 1 and 2?

None were identified.

### Previously Published Systematic Reviews

Flobbe et al. published a decision analysis model comparing different strategies for managing patients presenting with palpable breast masses in 2004.^259^ Their decision model was based entirely on data from a single clinical study they previously authored (Flobbe et al.260). This particular clinical study by Flobbe et al. was excluded from the current report because it was confounded. Findings from the ultrasound exams influenced the way each patient was managed, including whether the patient was evaluated by biopsy. Therefore the data from Flobbe et al. cannot be used to accurately estimate the diagnostic characteristics of ultrasound because the study is strongly affected by verification bias. Because the decision model developed by Flobbe et al. was based entirely upon this confounded study, the results of the decision model are also suspect and will not be discussed here.

### Conclusion

The estimates of the accuracy of the various types of ultrasound, along with a rating of the strength of evidence supporting the accuracy estimate, are summarized in Table 18. We intended to evaluate ultrasound tomography, but did not identify any relevant studies that met the inclusion criteria.

Table 18 Ultrasound accuracy: accuracy of different types of ultrasound

Type of Ultrasound | N Studies | N Lesions | Summary Sensitivity (95% CI) | Summary Specificity (95% CI) | Strength of Evidence
B-mode grayscale 2D | 21 | 8,199 | 92.4% (84.6 to 96.4%) | 75.8% (60.8 to 86.3%) | Low
B-mode grayscale 2D contrast enhanced | 2 | 154 | 97.5% (91.4 to 99.7%) | 76.7% (65.4 to 85.8%) | Low
B-mode grayscale 3D | 1 | 150 | 98.3% (91.1 to 100.0%) | 70.0% (59.4 to 79.2%) | Insufficient
Color Doppler | 6 | 718 | 88.5% (74.4 to 95.4%) | 76.4% (61.7 to 86.7%) | Low
Color Doppler contrast enhanced | 2 | 146 | 97.8% (92.4 to 99.7%) | 90.7% (79.7 to 96.9%) | Low
Power Doppler | 9 | 614 | 70.8% (47.5 to 86.6%) | 72.6% (59.9 to 82.5%) | Low
Power Doppler contrast enhanced | 7 | 403 | 89.3% (52.4 to 98.4%) | 70.4% (55.4 to 82.0%) | Low
Tissue harmonics | 1 | 91 | 96.7% (82.8 to 99.9%) | 62.3% (49.0 to 74.4%) | Insufficient

Qualitative indirect and direct comparisons between different types of ultrasound imaging were also performed. B-mode grayscale ultrasound was found to be more sensitive than either power or color Doppler imaging (conclusion supported by a Low strength of evidence). Color Doppler imaging was more accurate (both more sensitive and more specific) than power Doppler imaging (conclusion supported by a Low strength of evidence). In general, contrast-enhancement was found to improve the accuracy of all types of ultrasound imaging (conclusion supported by a Low strength of evidence). However, in actual clinical practice, it is unlikely that Doppler imaging would be used in isolation; most likely Doppler imaging and B-mode imaging would be performed by the same operator during the same procedure, and the image reader would incorporate information from all of the types of imaging into the diagnosis. There is insufficient data available to reach conclusions about the accuracy of combined ultrasound modalities.

We were unable to identify any patient demographics, clinical risk factors, or other factors that affected the accuracy of the various types of ultrasound imaging. Most of the studies did not enroll women found to have obvious cysts, and therefore our findings do not apply to women who clearly have cystic lesions on ultrasound imaging.

To aid in interpretation of these findings, we used Bayes’ theorem and the summary likelihood ratios for the three primary types of ultrasound imaging (see Table 19 and Table 20). These calculations suggest that diagnostic ultrasound examinations of women thought to have a higher than 10 percent pre-ultrasound probability of cancer will not be very clinically useful for diagnostic purposes because the input provided by the ultrasound examinations would probably not affect the suspicion of malignancy sufficiently to alter clinical decisions about management of the patient (e.g., recommendations for biopsy vs. followup). These calculations suggest that ultrasound examinations may be clinically useful for diagnostic purposes for only a small subgroup of women, but clinicians would need to be able to identify women with a >0 percent but <10 percent suspicion of malignancy following standard workup. Several of our expert reviewers did not think this was currently feasible. For many women an ultrasound examination will probably not result in a change in management or affect patient outcomes. This is further illustrated in Figure 6, where models of theoretical changes in management that could be made after the use of diagnostic grayscale B-mode ultrasound are shown graphically.

Table 19 Clinical interpretations of ultrasound accuracy: benign finding on ultrasound

Pre-test Probability of the Lesion Being Malignant | Post-test Probability of the Lesion Being Malignant Despite a Finding of “Benign” on the Ultrasound Exam
Pre-test Probability of the Lesion Being Malignant | B-mode Grayscale 2D Ultrasound^a^ | Power Doppler Ultrasound | Color Doppler Ultrasound
1% | 0% (0 to 0%) | 0% (0 to 1%) | 0% (0 to 0%)
5% | 1% (0 to 1%) | 2% (1 to 4%) | 1% (0 to 2%)
10% | 1% (1 to 2%) | 4% (2 to 8%) | 2% (1 to 3%)
20% | 2% (1 to 5%) | 9% (5 to 16%) | 4% (2 to 7%)
30% | 4% (2 to 8%) | 15% (9 to 24%) | 6% (3 to 12%)
40% | 6% (3 to 12%) | 21% (13 to 33%) | 9% (5 to 17%)
50% | 9% (5 to 17%) | 29% (18 to 43%) | 13% (7 to 24%)
60% | 13% (7 to 23%) | 38% (25 to 53%) | 18% (10 to 32%)
70% | 19% (10 to 32%) | 48% (34 to 63%) | 26% (14 to 42%)
80% | 29% (16 to 45%) | 62% (47 to 75%) | 38% (22 to 56%)
90% | 47% (31 to 65%) | 78% (66 to 87%) | 57% (39 to 74%)

a The summary negative likelihood ratio is 0.10 (95% CI: 0.049 to 0.20).

Table 20 Clinical interpretations of ultrasound accuracy: malignant finding on ultrasound

Pre-test Probability of the Lesion Being Malignant | Post-test Probability of the Lesion Being Malignant After a Finding of “Malignant” on the Ultrasound Exam
Pre-test Probability of the Lesion Being Malignant | B-mode Grayscale 2D Ultrasound^a^ | Power Doppler Ultrasound | Color Doppler Ultrasound
1% | 4% (2 to 7%) | 3% (2 to 4%) | 4% (2 to 6%)
5% | 17% (5 to 11%) | 12% (9 to 16%) | 17% (11 to 24%)
10% | 30% (20 to 42%) | 22% (17 to 29%) | 29% (21 to 40%)
20% | 49% (36 to 62%) | 39% (32 to 47%) | 48% (38 to 62%)
30% | 62% (49 to 73%) | 53% (45 to 61%) | 62% (51 to 72%)
40% | 72% (60 to 81%) | 63% (56 to 71%) | 71% (62 to 80%)
50% | 79% (69 to 86%) | 72% (66 to 78%) | 79% (71 to 86%)
60% | 85% (77 to 91%) | 80% (74 to 84%) | 85% (78 to 90%)
70% | 90% (84 to 94%) | 86% (82 to 89%) | 90% (85 to 93%)
80% | 94% (90 to 96%) | 91% (88 to 94%) | 94% (91 to 96%)
90% | 97% (95 to 98%) | 96% (94 to 97%) | 97% (96 to 98%)

a The summary positive likelihood ratio is 3.8 (95% CI: 2.3 to 0.96).

Figure 6 Possible clinical scenarios for B-mode grayscale ultrasound (US): theoretical changes in management

Figure 6 graphically demonstrates the possible impact of an US exam on patient management. Three flowcharts are placed side-by-side: on the left are women thought to be at high risk of breast cancer; after either a positive or negative US examination, the recommendation for “biopsy” remains unchanged. The middle flowchart is of women thought be at approximately 10% risk of malignancy; after a negative finding on US it is possible these women would have their management changed from “biopsy” to short-interval followup. At the right side of the figure is a flowchart of women thought be at low risk of malignancy; after a positive finding on US these women might find their management recommendation to change from short-interval followup to biopsy.

Because most of the included studies did not enroll women found to have simple cysts or obviously benign lesions, our results did not measure the accuracy of ultrasound for identification of cysts or obviously benign lesions, and should not be applied to the use of ultrasound for these purposes. Ultrasound is generally accepted to have been well-established for accurately identifying simple cysts and certain types of “obviously benign” lesions.

## Comparative Accuracy and Safety

We identified three studies that directly compared PET and MRI34,35,41 and one study that directly compared PET/CT and MRI.16 There was no consistent pattern of relative accuracy across the three studies that directly compared PET and MRI. Imbracio et al. directly compared the diagnostic accuracy of PET/CT and MRI in the same set of patients.16 MRI was more sensitive but less specific than PET/CT in diagnosing breast lesions in this study.16 A qualitative indirect comparison of the summary accuracy estimates from the other sections of this report suggests that MRI is more sensitive than PET, but the two imaging methods have approximately the same specificity. Indirect comparisons may be inaccurate and should be used with extreme caution.

We identified two studies that directly compared B-mode grayscale ultrasound to MRI,18,26 and one study that compared a combination of several Doppler ultrasound methods to MRI.45 All three studies found that MRI was more sensitive than ultrasound for diagnosing breast lesions (results for specificity were inconsistent across studies). A qualitative indirect comparison of the summary accuracy estimates from the other sections of this report suggest that the two imaging methods are of approximately equal accuracy. As mentioned above, indirect comparisons should only be used with extreme skepticism about their accuracy.

We identified one study that directly compared scintimammography to a combination of several Doppler ultrasound methods60 that found the two methods were approximately equally accurate, with a slightly higher sensitivity for scintimammography. Qualitative indirect comparisons of the summary accuracy estimates from the other sections of this report suggest that ultrasound may be slightly more sensitive than scintimammography, but this finding should not be considered to be supported by solid evidence (see comments above about indirect comparisons).

We identified one study14 that directly compared scintimammography and MRI, and found MRI to be more sensitive but less specific than scintimammography. A qualitative indirect comparison of the summary accuracy estimates from the other sections of this report concurs with the direct comparison conclusion. We also identified one study19 that directly compared MRI to a variant of scintimammography (BSGI) with similar findings (MRI more sensitive but less specific than BSGI).

The summary estimates of accuracy of each modality are shown in Table 21, and comparative safety concerns are shown in Table 22. The data suggest, but do not prove, that ultrasound and MRI are more accurate than PET or scintimammography for evaluation of suspicious breast lesions. Because the evidence supporting these comparisons is, for the most part, indirect in nature, and not reported in sufficient detail to support statistical testing, we have refrained from drawing any solid evidence-based conclusions about comparisons across technologies.

Table 21 Summary accuracy results

Technology | N Studies | N Lesions | Summary Sensitivity (95% CI) | Summary Specificity (95% CI) | Post-test Probability of “Malignancy”^a^ | Strength of Evidence
B-mode grayscale 2D | 21 | 8,199 | 92.4% (84.6 to 96.4%) | 75.8% (60.8 to 86.3%) | 2% (1 to 5%) | Low
MRI | 41 | 3,882 | 91.7% (88.5 to 94.1%) | 77.5% (71.0 to 82.9%) | 3% (2 to 4%) | Moderate (sensitivity)/Low (specificity)
Scintimammography | 11 | 1,064 | 84.7% (78.0 to 89.7%) | 77.0% (64.7 to 85.9%) | 5% (3 to 6%) | Low
PET | 7 | 403 | 83.0% (73.0 to 89.0%) | 74.0% (58.0 to 86%) | 6% (4 to 8%) | Low

a Post-test probability of a lesion being “malignant” after a benign finding on the test for a typical woman with an estimated 20% chance of having a malignant lesion.

Table 22 Comparative safety concerns

Technology | Radiation Exposure | Possible Contrast Agent Reactions | Other Concerns
B-mode grayscale 2D | None | None | None
MRI | None | Rare cases of nephrotoxicity and rare cases of severe allergic reactions | Accidental injury from the magnetic field
Scintimammography | 9.0 mSv | Rare cases of severe allergic reactions | None
PET | 7.6 mSv | Rare cases of severe allergic reactions | None
X-ray mammography^a^ | 0.36 mSv | None | None

a Provided for comparison purposes.