# References

1 American Cancer Society (ACS). Cancer facts & figures 2010. Atlanta (GA). American Cancer Society (ACS). 2010. 68 p. www.cancer.org/acs/groups/content/@epidemiologysurveilance/documents/document/acspc-026238.pdf.
2 US Preventive Services Task Force (USPSTF). Screening for breast cancer: recommendations and rationale. Washington (DC). Agency for Healthcare Research and Quality (AHRQ). 2002. Feb. 10. (AHRQ Pub.; no. 02-507A). www.ahrq.gov/clinic/3rduspstf/breastcancer.
3 Humphrey LL, Helfand M, Chan BK, et al. Breast cancer screening: a summary of the evidence for the U.S Preventive Services Task Force. Ann Intern Med. Sep. 3. 2002;137(5 Part 1):347-67. [pmid: 12204020].
4 U.S. Preventive Services Task Force. Screening for breast cancer: U.S. Preventive Services Task Force recommendation statement. Ann Intern Med. Nov. 17. 2009;151(10):716-26. W-236. [pmid: 19920272].
5 Elmore JG, Barton MB, Moceri VM, et al. Ten-year risk of false positive screening mammograms and clinical breast examinations. N Engl J Med. Apr. 16. 1998;338(16):1089-96. [pmid: 9545356].
6 Rosenberg RD, Yankaskas BC, Abraham LA, et al. Performance benchmarks for screening mammography. Radiology. Oct. 2006;241(1):55-66. [pmid: 16990671].
7 Bruening W, Launders J, Pinkney N, et al. Effectiveness of noninvasive diagnostic tests for breast abnormalities. (Prepared by ECRI Evidence-based Practice center under Contract No 290-02-0019). Rockville (MD). Agency for Healthcare Research and Quality (AHRQ). 2006:130. Comparative effectiveness review; no. 2. http://effectivehealthcare.ahrq.gov/repFiles/BrCADx%20Final%20Report.pdf.
8 Harbord RM, Deeks JJ, Egger M, et al. A unification of models for meta-analysis of diagnostic accuracy studies. Biostatistics. Apr. 2007;8(2):239-51. [pmid: 16698768].
9 STATA statistics/data analysis. MP parallel edition. College Station (TX). StataCorp. 1984–2007. Single user Stata for Windows. www.stata.com.
10 Zamora J, Abraira V, Muriel A, et al. Meta-DiSc: a software for meta-analysis of test accuracy data. BMC Med Res Methodol. 2006;6:31. [pmid: 16836745].
11 Akita A, Tanimoto A, Jinno H, et al. The clinical value of bilateral breast MR imaging: is it worth performing on patients showing suspicious microcalcifications on mammography. Eur Radiol. Sep. 2009;19(9):2089-96. [pmid: 19350244].
12 Baltzer PA, Freiberg C, Beger S, et al. Clinical MR-mammography: are computer-assisted methods superior to visual or manual measurements for curve type analysis? A systematic approach. Acad Radiol. Sep. 2009;16(9):1070-6. [pmid: 19523854].
13 Hara M, Watanabe T, Okumura A, et al. Angle between 1 and 4 min gives the most significant difference in time-intensity curves between benign disease and breast cancer: analysis of dynamic magnetic resonance imaging in 103 patients with breast lesions. Clin Imaging. Sep–Oct. 2009;33(5):335-42. [pmid: 19712811].
14 Kim IJ, Kim YK, Kim SJ. Detection and prediction of breast cancer using couble phase Tc-99m MIBI scintimammography in comparison with MRI. Onkologie. Oct. 2009;32(10):556-60. [pmid: 19816071].
15 Lo GG, Ai V, Chan JK, et al. Diffusion-weighted magnetic resonance imaging of breast lesions: first experiences at 3 T. J Comput Assist Tomogr. Jan–Feb. 2009;33(1):63-9. [pmid: 19188787].
16 Imbriaco M, Caprio MG, Limite G, et al. Dual-time-point 18F-FDG PET/CT versus dynamic breast MRI of suspicious breast lesions. AJR Am J Roentgenol. Nov. 2008;191(5):1323-30. [pmid: 18941064].
17 Pediconi F, Catalano C, Padula S, et al. Contrast-enhanced MR mammography: improved lesion detection and differentiation with gadobenate dimeglumine. AJR Am J Roentgenol. Nov. 2008;191(5):1339-46. [pmid: 18941066].
18 Vassiou K, Kanavou T, Vlychou M, et al. Characterization of breast lesions with CE-MR multimodal morphological and kinetic analysis: comparison with conventional mammography and high-resolution ultrasound. Eur J Radiol. Apr. 2009;70(1):69-76. [pmid: 18295425].
19 Brem RF, Petrovitch I, et al. Breast-specific gamma imaging with 99mTc-Sestamibi and magnetic resonance imaging in the diagnosis of breast cancer--a comparative study. Breast J. Sep–Oct. 2007;13(5):465-9. [pmid: 17760667].
20 Cilotti A, Iacconi C, Marini C, et al. Contrast-enhanced MR imaging in patients with BI-RADS 3–5 microcalcifications. Radiol Med. Mar. 2007;112(2):272-86. [pmid: 17361370].
21 Pediconi F, Catalano C, Padula S, et al. Contrast-enhanced magnetic resonance mammography: does it affect surgical decision-making in patients with breast cancer. Breast Cancer Res Treat. Nov. 2007;106(1):65-74. [pmid: 17203383].
22 Zhu J, Kurihara Y, Kanemaki Y, et al. Diagnostic accuracy of high-resolution MRI using a microscopy coil for patients with presumed DCIS following mammography screening. J Magn Reson Imaging. Jan. 2007;25(1):96-103. [pmid: 17154376].
23 Bazzocchi M, Zuiani C, Panizza P, et al. Contrast-enhanced breast MRI in patients with suspicious microcalcifications on mammography: results of a multicenter trial. AJR Am J Roentgenol. Jun. 2006;186(6):1723-32. [pmid: 16714666].
24 Gokalp G, Topal U. MR imaging in probably benign lesions (BI-RADS category 3) of the breast. Eur J Radiol. Mar. 2006;57(3):436-44. [pmid: 16316732].
25 Kneeshaw PJ, Lowry M, Manton D, et al. Differentiation of benign from malignant breast disease associated with screening detected microcalcifications using dynamic contrast enhanced magnetic resonance imaging. Breast. Feb. 2006;15(1):29-38. [pmid: 16002292].
26 Ricci P, Cantisani V, Ballesio L, et al. Benign and malignant breast lesions: efficacy of real time contrast-enhanced ultrasound vs. magnetic resonance imaging. Ultraschall Med. Feb. 2007;28(1):57-62. [pmid: 17304413].
27 Pediconi F, Catalano C, Venditti F, et al. Color-coded automated signal intensity curves for detection and characterization of breast lesions: preliminary evaluation of a new software package for integrated magnetic resonance-based breast imaging. Invest Radiol. Jul. 2005;40(7):448-57. [pmid: 15973137].
28 Pediconi F, Catalano C, Occhiato R, et al. Breast lesion detection and characterization at contrast-enhanced MR mammography: gadobenate dimeglumine versus gadopentetate dimeglumine. Radiology. Oct. 2005;237(1):45-56. [pmid: 16126926].
29 Wiener JI, Schilling KJ, Adami C, et al. Assessment of suspected breast cancer by MRI: a prospective clinical trial using a combined kinetic and morphologic analysis. AJR Am J Roentgenol. Mar. 2005;184(3):878-86. [pmid: 15728612].
30 Bluemke DA, Gatsonis CA, Chen MH, et al. Magnetic resonance imaging of the breast prior to biopsy. JAMA. Dec. 8. 2004;292(22):2735-42. [pmid: 15585733].
31 Huang W, Fisher PR, Dulaimy K, et al. Detection of breast malignancy: diagnostic MR protocol for improved specificity. Radiology. Aug. 2004;232(2):585-91. [pmid: 15205478].
32 Bone B, Wiberg MK, Szabo BK, et al. Comparison of 99mTc-sestamibi scintimammography and dynamic MR imaging as adjuncts to mammography in the diagnosis of breast cancer. Acta Radiol. Jan. 2003;44(1):28-34. [pmid: 12630995].
33 Daldrup-Link HE, Kaiser A, Helbich T, et al. Macromolecular contrast medium (feruglose) versus small molecular contrast medium (gadopentetate) enhanced magnetic resonance imaging: differentiation of benign and malignant breast lesions. Acad Radiol. Nov. 2003;10(11):1237-46. [pmid: 14626298].
34 Heinisch M, Gallowitsch HJ, Mikosch P, et al. Comparison of FDG-PET and dynamic contrast-enhanced MRI in the evaluation of suggestive breast lesions. Breast. Feb. 2003;12(1):17-22. [pmid: 14659351].
35 Walter C, Scheidhauer K, Scharl A, et al. Clinical and diagnostic value of preoperative MR mammography and FDG-PET in suspicious breast lesions. Eur Radiol. Jul. 2003;13(7):1651-6. [pmid: 12835981].
36 Guo Y, Cai YQ, Cai ZL, et al. Differentiation of clinically benign and malignant breast lesions using diffusion-weighted imaging. J Magn Reson Imaging. Aug. 2002;16(2):172-8. [pmid: 12203765].
37 Kelcz F, Furman-Haran E, Grobgeld D, et al. Clinical testing of high-spatial-resolution parametric contrast-enhanced MR imaging of the breast. AJR Am J Roentgenol. Dec. 2002;179(6):1485-92. [pmid: 12438042].
38 Schedel H, Oellinger H, Kohlschein P, et al. Magnetic Resonance Female Breast Imaging (MRFBI) - evaluation of the changes in signal intensity over time pre- and post-administration of 0.2 mmol/kg Gd-DTPA. Zentralbl Gynakol. Feb. 2002;124(2):104-10. [pmid: 11935495].
39 Trecate G, Tess JD, Vergnaghi D, et al. Breast microcalcifications studied with 3D contrast-enhanced high-field magnetic resonance imaging: more accuracy in the diagnosis of breast cancer. Tumori. May–Jun. 2002;88(3):224-33. [pmid: 12195761].
40 Kristoffersen Wiberg M, Aspelin P, Perbeck L, et al. Value of MR imaging in clinical evaluation of breast lesions. Acta Radiol. May. 2002;43(3):275-81. [pmid: 12100324].
41 Brix G, Henze M, et al. Comparison of pharmacokinetic MRI and [18F] fluorodeoxyglucose PET in the diagnosis of breast cancer: initial experience. Eur Radiol. 2001;11(10):2058-70. [pmid: 11702142].
42 Cecil KM, Schnall MD, Siegelman ES, et al. The evaluation of human breast lesions with magnetic resonance imaging and proton magnetic resonance spectroscopy. Breast Cancer Res Treat. Jul. 2001;68(1):45-54. [pmid: 11678308].
43 Furman-Haran E, Grobgeld D, Kelcz F, et al. Critical role of spatial resolution in dynamic contrast-enhanced breast MRI. J Magn Reson Imaging. Jun. 2001;13(6):862-7. [pmid: 11382945].
44 Imbriaco M, Del Vecchio S, Riccardi A, et al. Scintimammography with 99mTc-MIBI versus dynamic MRI for non-invasive characterization of breast masses. Eur J Nucl Med. Jan. 2001;28(1):56-63. [pmid: 11202453].
45 Malich A, Boehm T, Facius M, et al. Differentiation of mammographically suspicious lesions: evaluation of breast ultrasound, MRI mammography and electrical impedance scanning as adjunctive technologies in breast cancer detection. Clin Radiol. Apr. 2001;56(4):278-83. [pmid: 11286578].
46 Nakahara H, Namba K, Fukami A, et al. Three-dimensional MR imaging of mammographically detected suspicious microcalcifications. Breast Cancer. 2001;8(2):116-24. [pmid: 11342984].
47 Torheim G, Godtliebsen F, Axelson D, et al. Feature extraction and classification of dynamic contrast-enhanced T2*-weighted breast image data. IEEE Trans Med Imaging. Dec. 2001;20(12):1293-301. [pmid: 11811829].
48 Wedegartner U, Bick U, Wortler K, et al. Differentiation between benign and malignant findings on MR-mammography: usefulness of morphological criteria. Eur Radiol. 2001;11(9):1645-50. [pmid: 11511885].
49 Yeung DK, Cheung HS, Tse GM. Human breast lesions: characterization with contrast-enhanced in vivo proton MR spectroscopy--initial results. Radiology. Jul. 2001;220(1):40-6. [pmid: 11425970].
50 Kvistad KA, Rydland J, Vainio J, et al. Breast lesions: evaluation with dynamic contrast-enhanced T1-weighted MR imaging and with T2*-weighted first-pass perfusion MR imaging. Radiology. Aug. 2000;216(2):545-53. [pmid: 10924584].
51 Van Goethem M, Biltjes IG, De Schepper AM. Indications for MR mammography. A Belgian study. JBR-BTR. Jun. 2000;83(3):126-9. [pmid: 11025925].
52 Kaida H, Ishibashi M, Fuji T, et al. Improved breast cancer detection of prone breast fluorodeoxyglucose-PET in 118 patients. Nucl Med Commun. Oct. 2008;29(10):885-93. [pmid: 18769306].
53 Buchmann I, Riedmuller K, Hoffner S, et al. Comparison of 99mtechnetium-pertechnetate and 123iodide SPECT with FDG-PET in patients suspicious for breast cancer. Cancer Biother Radiopharm. Dec. 2007;22(6):779-89. [pmid: 18158769].
54 Schirrmeister H, Kuhn T, Guhlmann A, et al. Fluorine-18 2-deoxy-2-fluoro-D-glucose PET in the preoperative staging of breast cancer: comparison with the standard staging procedures. Eur J Nucl Med. Mar. 2001;28(3):351-8. [pmid: 11315604].
55 Yutani K, Shiba E, Kusuoka H, et al. Comparison of FDG-PET with MIBI-SPECT in the detection of breast cancer and axillary lymph node metastasis. J Comput Assist Tomogr. Mar–Apr. 2000;24(2):274-80. [pmid: 10752892].
56 Mathieu I, Mazy S, Willemart B, et al. Inconclusive triple diagnosis in breast cancer imaging: is there a place for scintimammography. J Nucl Med. Oct. 2005;46(10):1574-81. [pmid: 16204705].
57 Habib S, Maseeh-uz-Zaman, Hameed A, et al. Diagnostic accuracy of Tc-99m-MIBI for breast carcinoma in correlation with mammography and sonography. J Coll Physicians Surg Pak. Oct. 2009;19(10):622-6. [pmid: 19811712].
58 Kim IJ, Kim SJ, Kim YK. Comparison of double phase Tc-99m MIBI and Tc-99m tetrofosmin scintimammography for characterization of breast lesions: Visual and quantitative analyses. Neoplasma. 2008;55(6):526-31. [pmid: 18999882].
59 Kim SJ, Bae YT, Lee JS, et al. Diagnostic performances of double-phase tc-99m MIBI scintimammography in patients with indeterminate ultrasound findings: visual and quantitative analyses. Ann Nucl Med. Jun. 2007;21(3):145-50. [pmid: 17561585].
60 Pinero A, Galindo PJ, Illana J, et al. Diagnostic efficiency of sestamibi gammagraphy and Doppler sonography in the preoperative assessment of breast lesions. Clin Transl Oncol. Feb. 2006;8(2):103-7. [pmid: 16632424].
61 Grosso M, Chiacchio S, Bianchi F, et al. Comparison between 99mTc-sestamibi scintimammography and X-ray mammography in the characterization of clusters of microcalcifications: a prospective long-term study. Anticancer Res. Oct. 2009;29(10):4251-7. [pmid: 19846982].
62 Wang F, Wang Z, Wu J, et al. The role of technetium-99m-labeled octreotide acetate scintigraphy in suspected breast cancer and correlates with expression of SSTR. Nucl Med Biol. Aug. 2008;35(6):665-71. [pmid: 18678351].
63 Gommans GM, van der Zant FM, van Dongen A, et al. (99M)Technetium-sestamibi scintimammography in non-palpable breast lesions found on screening X-ray mammography. Eur J Surg Oncol. Feb. 2007;33(1):23-7. [pmid: 17126524].
64 Schillaci O, Danieli R, Filippi L, et al. Scintimammography with a hybrid SPECT/CT imaging system. Anticancer Res. Jan. 2007;27(1B):557-62. [pmid: 17348441].
65 Gokalp G, Topal U, Kizilkaya E. Power Doppler sonography: anything to add to BI-RADS US in solid breast masses. Eur J Radiol. Apr. 2009;70(1):77-85. [pmid: 18243623].
66 Liu H, Jiang YX, Liu JB, et al. Evaluation of breast lesions with contrast-enhanced ultrasound using the microvascular imaging technique: initial observations. Breast. Oct. 2008;17(5):532-9. [pmid: 18534851].
67 Vade A, Lafita VS, Ward KA, et al. Role of breast sonography in imaging of adolescents with palpable solid breast masses. AJR Am J Roentgenol. Sep. 2008;191(3):659-63. [pmid: 18716091].
68 Cha JH, Moon WK, Cho N, et al. Characterization of benign and malignant solid breast masses: comparison of conventional US and tissue harmonic imaging. Radiology. Jan. 2007;242(1):63-9. [pmid: 17090709].
69 Chala L, Endo E, Kim S, et al. Gray-scale sonography of solid breast masses: diagnosis of probably benign masses and reduction of the number of biopsies. J Clin Ultrasound. Jan. 2007;35(1):9-19. [pmid: 17149763].
70 Zhi H, Ou B, Luo BM, et al. Comparison of ultrasound elastography, mammography, and sonography in the diagnosis of solid breast lesions. J Ultrasound Med. Jun. 2007;26(6):807-15. [pmid: 17526612].
71 Cho N, Moon WK, Cha JH, et al. Differentiating benign from malignant solid breast masses: comparison of two-dimensional and three-dimensional US. Radiology. Jul. 2006;240(1):26-32. [pmid: 16684920].
72 Forsberg F, Goldberg BB, Merritt CR, et al. Diagnosing breast lesions with contrast-enhanced 3-dimensional power Doppler imaging. J Ultrasound Med. Feb. 2004;23(2):173-82. [pmid: 14992354].
73 Meyberg-Solomayer GC, Kraemer B, Bergmann A, et al. Does 3-D sonography bring any advantage to noninvasive breast diagnostics. Ultrasound Med Biol. May. 2004;30(5):583-9. [pmid: 15183222].
74 Chen DR, Jeng LB, Kao A, et al. Comparing thallium-201 spect mammoscintigraphy and ultrasonography to detect breast cancer in mammographical dense breasts. Neoplasma. 2003;50(3):222-6. [pmid: 12937857].
75 Kook SH, Kwag HJ. Value of contrast-enhanced power Doppler sonography using a microbubble echo-enhancing agent in evaluation of small breast lesions. J Clin Ultrasound. Jun. 2003;31(5):227-38. [pmid: 12767017].
76 Marini C, Traino C, Cilotti A, et al. Differentiation of benign and malignant breast microcalcifications: mammography versus mammography-sonography combination. Radiol Med. Jan–Feb. 2003;105(1–2):17-26. [pmid: 12700541].
77 Reinikainen H, Rissanen T, Paivansalo M, et al. B-mode, power Doppler and contrast-enhanced power Doppler ultrasonography in the diagnosis of breast tumors. Acta Radiol. Jan. 2001;42(1):106-13. [pmid: 11167342].
78 Blohmer JU, Oellinger H, Schmidt C, et al. Comparison of various imaging methods with particular evaluation of color Doppler sonography for planning surgery for breast tumors. Arch Gynecol Obstet. 1999;262(3–4):159-71. [pmid: 10326635].
79 Chao TC, Lo YF, Chen SC, et al. Prospective sonographic study of 3093 breast tumors. J Ultrasound Med. May. 1999;18(5):363-70. [pmid: 10327015].
80 Wilkens TH, Burke BJ, Cancelada DA, et al. Evaluation of palpable breast masses with color Doppler sonography and gray scale imaging. J Ultrasound Med. Feb. 1998;17(2):109-15. [pmid: 9527570].
81 Stavros AT, Thickman D, Rapp CL, et al. Solid breast nodules: use of sonography to distinguish between benign and malignant lesions. Radiology. Jul. 1995;196(1):123-34. [pmid: 7784555].
82 Ciatto S, Rosselli del Turco M, Catarzi S, et al. The contribution of ultrasonography to the differential diagnosis of breast cancer. Neoplasma. 1994;41(6):341-5. [pmid: 7870218].
83 Perre CI, Koot VC, de Hooge P, et al. The value of ultrasound in the evaluation of palpable breast tumours: a prospective study of 400 cases. Eur J Surg Oncol. Dec. 1994;20(6):637-40. [pmid: 7995413].
84 Caruso G, Ienzi R, Cirino A, et al. Breast lesion characterization with contrast-enhanced US Work in progress. Radiol Med. Nov–Dec. 2002;104(5–6):443-50. [pmid: 12589266].
85 Koukouraki S, Koukourakis MI, Vagios E, et al. The role of 99mTc-sestamibi scintimammography and colour Doppler ultrasonography in the evaluation of breast lesions. Nucl Med Commun. Nov. 2001;22(11):1243-8. [pmid: 11606891].
86 Schroeder RJ, Maeurer J, Vogl TJ, et al. D-galactose-based signal-enhanced color Doppler sonography of breast tumors and tumorlike lesions. Invest Radiol. Feb. 1999;34(2):109-15. [pmid: 9951790].
87 Buadu LD, Murakami J, Murayama S, et al. Colour Doppler sonography of breast masses: a multiparameter analysis. Clin Radiol. 1997;52:917-23. [pmid: 9413965].
88 Zdemir A, Kilic K, Ozdemir H, et al. Contrast-enhanced power Doppler sonography in breast lesions: effect on differential diagnosis after mammography and gray scale sonography. J Ultrasound Med. Feb. 2004;23(2):183-95. quiz 196–7. [pmid: 14992355].
89 Milz P, Lienemann A, Kessler M, et al. Evaluation of breast lesions by power Doppler sonography. Eur Radiol. 2001;11(4):547-54. [pmid: 11354745].
90 Moon WK, Im JG, Noh DY, et al. Nonpalpable breast lesions: evaluation with power Doppler US and a microbubble contrast agent-initial experience. Radiology. Oct. 2000;217(1):240-6. [pmid: 11012451].
91 Albrecht T, Patel N, Cosgrove DO, et al. Enhancement of power Doppler signals from breast lesions with the ultrasound contrast agent EchoGen emulsion: subjective and quantitative assessment. Acad Radiol. Apr. 1998;5(Suppl 1):S195-8. discussion S199. [pmid: 9561080].
92 Guidance chapter. Breast Imaging Reporting and Data System Atlas (BI-RADS Atlas) BI-RADS - Mammography. 4th ed. Reston (VA). American College of Radiology (ACR). 2003:253-60. www.acr.org/SecondaryMainMenuCategories/quality_safety/BIRADSAtlas/BIRADSAtlasexcerptedtext/BIRADSMammographyFourthEdition/FollowUpandOutcomeMonitoringDoc4.aspx.
93 Surveillance Epidemiology and End Results. SEER stat fact sheets - cancer of the breast [internet]. Bethesda (MD). National Cancer Institute (NCI). accessed 2007 Feb 5. 3. Available: http://seer.cancer.gov/statfacts/html/breast_print.html.
94 Feuer EJ, Wun LM. DEVCAN: probability of developing or dying of cancer software, version 4.1 [internet]. Bethesda (MD). National Cancer Institute (NCI). accessed 2002 May 28. 1999:1. Available: http://canques.seer.cancer.gov/cgi-bin/cq_submit?dir-devcan1999&AMP;db=1&AMP;rpt=TAB&AMP;sel=.
95 Harvey JA. Unusual breast cancers: useful clues to expanding the differential diagnosis. Radiology. Mar. 2007;242(3):683-94. [pmid: 17325062].
96 Levine P, Simsir A, Cangiarella J. Management issues in breast lesions diagnosed by fine-needle aspiration and percutaneous core breast biopsy. Am J Clin Pathol. Jun. 2006;125(Suppl):S124-34. [pmid: 16830962].
97 Nelson HD, Tyne K, Naik A, et al. Screening for Breast Cancer: Systematic Evidence Review Update for the US Preventive Services Task Force. Ann Intern Med. 2009. Nov. [pmid: 20722173].
98 Gotzsche PC, Nielsen M. Screening for breast cancer with mammography. Cochrane Database of Systematic Reviews [internet]. Hoboken (NJ). John Wiley & Sons, Ltd. 2009;(4). accessed 2010 Oct 8. [Art. No.: CD001877]. Available:. [doi: 10.1002/14651858.CD001877.pub3]. [pmid: 19821284].
99 Liberman L, Menell JH. Breast imaging reporting and data system (BI-RADS). Radiol Clin North Am. May. 2002;40(3):409-30. [pmid: 12117184].
100 Diagnostic and Interventional Radiology Department. Mammography. Omaha (NE). Creighton University School of Medicine. 22 p. http://radiology.creighton.edu/mammo.html.
101 Obenauer S, Hermann KP, Grabbe E. Applications and literature review of the BI-RADS classification. Eur Radiol. May. 2005;15(5):1027-36. [pmid: 15856253].
102 Ng EY, Sree SV, Ng KH, et al. The use of tissue electrical characteristics for breast cancer detection: a perspective review. Technol Cancer Res Treat. Aug. 2008;7(4):295-308. [pmid: 18642968].
103 Lacquement MA, Mitchell D, Hollingsworth AB. Positive predictive value of the Breast Imaging Reporting and Data System. J Am Coll Surg. Jul. 1999;189(1):34-40. [pmid: 10401738].
104 Fryback DG, Thornbury JR. The efficacy of diagnostic imaging. Med Decis Making. Apr–Jun. 1991;11(2):88-94. [pmid: 1907710].
105 Counsell C. Formulating questions and locating primary studies for inclusion in systematic reviews. Ann Intern Med. Sep. 1. 1997;127(5):380-7. [pmid: 9273830].
106 Lijmer JG, Mol BW, Heisterkamp S, et al. Empirical evidence of design-related bias in studies of diagnostic tests. JAMA. Sep. 15. 1999;282(11):1061-6. [pmid: 10493205].
107 Deeks JJ. Systematic reviews of evaluations of diagnostic and screening tests. Egger M, Smith GD, Altman DG, editors. Systematic reviews in health care: meta-analysis in context. 2nd ed. London, England. BMJ Books. 2001:248-82.
108 Bojia F, Demisse M, Dejane A, et al. Comparison of fine-needle aspiration cytology and excisional biopsy of breast lesions. East Afr Med J. May. 2001;78(5):226-8. [pmid: 12002079].
109 Vetrani A, Fulciniti F, Di Benedetto G, et al. Fine-needle aspiration biopsies of breast masses. An additional experience with 1153 cases (1985 to 1988) and a meta-analysis. Cancer. Feb. 1. 1992;69(3):736-40. [pmid: 1530911].
110 Abu-Salem OT. Fine needle aspiration biopsy (FNAB) of breast lumps: comparison study between pre- and post-operative histological diagnosis. Arch Inst Pasteur Tunis. 2002;79(1–4):59-63. [pmid: 15072246].
111 Ljung BM, Drejet A, Chiampi N, et al. Diagnostic accuracy of fine-needle aspiration biopsy is determined by physician training in sampling technique. Cancer. Aug. 25. 2001;93(4):263-8. [pmid: 11507700].
112 Moher D, Pham B, Klassen TP, et al. What contributions do languages other than English make on the results of meta-analyses. J Clin Epidemiol. Sep. 2000;53(9):964-72. [pmid: 11004423].
113 Juni P, Holenstein F, Sterne J, et al. Direction and impact of language bias in meta-analyses of controlled trials: empirical study. Int J Epidemiol. Feb. 2002;31(1):115-23. [pmid: 11914306].
114 Chalmers I, Adams M, Dickersin K, et al. A cohort study of summary reports of controlled trials. JAMA. Mar. 9. 1990;263(10):1401-5. [pmid: 2304219].
115 Neinstein LS. A review of Society for Adolescent Medicine abstracts and Journal of Adolescent Health Care articles. J Adolesc Health Care. Mar. 1987;8(2):198-203. [pmid: 3818406].
116 Dundar Y, Dodd S, Williamson P, et al. Case study of the comparison of data from conference abstracts and full-text articles in health technology assessment of rapidly evolving technologies: does it make a difference?. Int J Technol Assess Health Care. Jul. 2006;22(3):288-94. [pmid: 16984055].
117 De Bellefeuille C, Morrison CA, Tannock IF. The fate of abstracts submitted to a cancer meeting: factors which influence presentation and subsequent publication. Ann Oncol. Mar. 1992;3(3):187-91. [pmid: 1586615].
118 Scherer RW, Langenberg P. Full publication of results initially presented in abstracts. Cochrane Library [Cochrane methodology review]. Oxford. Update Software. 2001;(2). accessed 2001 Apr 23. 35 p. Available: www.cochrane.org/index.htm.
119 Marx WF, Cloft HJ, Do HM, et al. The fate of neuroradiologic abstracts presented at national meetings in 1993: rate of subsequent publication in peer-reviewed, indexed journals. AJNR Am J Neuroradiol. Jun–Jul. 1999;20(6):1173-7. [pmid: 10445467].
120 Yentis SM, Campbell FA, Lerman J. Publication of abstracts presented at anaesthesia meetings. Can J Anaesth. Jul. 1993;40(7):632-4. [pmid: 8403137].
121 Whiting P, Rutjes AW, Reitsma JB, et al. The development of QUADAS: a tool for the quality assessment of studies of diagnostic accuracy included in systematic reviews. BMC Med Res Methodol. Nov. 10. 2003;3(1):25. www.biomedcentral.com/content/pdf/1471-2288-3-25.pdf. [pmid: 14606960].
122 Owens DK, Lohr KN, Atkins D, et al. Grading the strength of a body of evidence when comparing medical interventions-Agency for Healthcare Research and Quality and the Effective Health Care Program. J Clin Epidemiol. May. 2010;63(5):513-23. [pmid: 19595577].
123 Owens D, Lohr K, Atkins D, et al. Grading the strength of a body of evidence when comparing medical interventions. Methods guide for comparative effectiveness reviews. Rockville (MD). Agency for Healthcare Research and Quality (AHRQ). Jul. 2009:19. http://effectivehealthcare.ahrq.gov/ehc/products/122/328/2009_0805_grading.pdf.
124 Higgins JP, Thompson SG. Quantifying heterogeneity in a meta-analysis. Stat Med. Jun. 15. 2002;21(11):1539-58. [pmid: 12111919].
125 Higgins JP, Thompson SG, Deeks JJ, et al. Measuring inconsistency in meta-analyses. BMJ. Sep. 6. 2003;327(7414):557-60. [pmid: 12958120].
126 Deeks J, Macaskill P, Irwig L. Detecting publication bias in systematic reviews of diagnostic test accuracy [abstract O-009], Cochrane Collaboration [database online]. Oxford (UK). Cochrane Collaboration. accessed 2005 May 25. 2004:1. Available: www.cochrane.org/colloquia/abstracts/ottawa/O-009.htm.
127 Deeks J, Macaskill P, Irwig L. By how much does publication bias affect the results of systematic reviews of diagnostic test accuracy? (abstract O-010) Cochrane Collaboration [database online]. Oxford (UK). Cochrane Collaboration. accessed 2005 May 25. 2004:2. Available: www.cochrane.org/colloquia/abstracts/ottawa/O-010.htm.
128 Paakko E, Reinikainen H, Lindholm EL, et al. Low-field versus high-field MRI in diagnosing breast disorders. Eur Radiol. Jul. 2005;15(7):1361-8. [pmid: 15711841].
129 American College of Radiology (ACR). ACR Breast Imaging and Reporting Data System, Breast Imaging Atlas. Reston (VA). American College of Radiology (ACR). 2003. ACR BI-RADS - Magnetic Resonance Imaging.
130 Orel SG, Schnall MD. MR imaging of the breast for the detection, diagnosis, and staging of breast cancer. Radiology. Jul. 2001;220(1):13-30. [pmid: 11425968].
131 Helbich TH. Contrast-enhanced magnetic resonance imaging of the breast. Eur J Radiol. Jun. 2000;34(3):208-19. [pmid: 10927162].
132 Artemov D, Revelon G, Atalar E, et al. Switchable multicoil array for MR micro-imaging of breast lesions. Magn Reson Med. Mar. 1999;41(3):569-74. [pmid: 10204882].
133 Shen GX, Wu J, Boada FE. Multiple channel phased arrays for echo planar imaging. MAGMA. Dec. 2000;11(3):138-43. [pmid: 11154955].
134 Heywang-Kobrunner SH, Bick U, Bradley WG Jr, et al. International investigation of breast MRI: results of a multicentre study (11 sites) concerning diagnostic parameters for contrast-enhanced MRI based on 519 histopathologically correlated lesions. Eur Radiol. 2001;11(4):531-46. [pmid: 11354744].
135 Coulthard A, Potterton AJ. Pitfalls of breast MRI. Br J Radiol. Jun. 2000;73(870):665-71. [pmid: 10911793].
136 Kuhl CK, Schild HH. Dynamic image interpretation of MRI of the breast. J Magn Reson Imaging. Dec. 2000;12(6):965-74. [pmid: 11105038].
137 Lee CH. Problem solving MR imaging of the breast. Radiol Clin North Am. Sep. 2004;42(5):919-34. [pmid: 15337425].
138 Partridge SC, Heumann EJ, Hylton NM. Semi-automated analysis for MRI of breast tumors. Stud Health Technol Inform. 1999;62:259-60. [pmid: 10538368].
139 MedWatch. Information on Gadolinium-Containing Contrast Agents. [internet]. Rockville (MD). U.S. Food and Drug Administration. 2009. Aug. 13. accessed 2010 Mar 17. Available: www.fda.gov/Drugs/DrugSafety/PostmarketDrugSafetyInformationforPatientsandProviders/ucm142882.htm.
140 Sardanelli F, Iozzelli A, Fausto A. Contrast agents and temporal resolution in breast MR imaging. J Exp Clin Cancer Res. Sep. 2002;21(3 Suppl):69-75. [pmid: 12585658].
141 Knopp MV, Bourne MW, Sardanelli F, et al. Gadobenate dimeglumine-enhanced MRI of the breast: analysis of dose response and comparison with gadopentetate dimeglumine. AJR Am J Roentgenol. Sep. 2003;181(3):663-76. [pmid: 12933457].
142 National Cancer Data Base (NCDB) [database online]. Chicago (IL). American College of Surgeons (ACS). accessed 1999 Mar 5. Relative survival of breast cancer patients by AJCC stage of disease at diagnosis, 1985–1990 cases [table]. 1996–1998:3. Available: www.facs.org/about_college/acsdept/cancer_dept/programs/ncdb/breastcancer4.html.
143 Morris EA. Review of breast MRI: indications and limitations. Semin Roentgenol. Jul. 2001;36(3):226-37. [pmid: 11475069].
144 Rieber A, Nussle K, Merkle E, et al. MR mammography: influence of menstrual cycle on the dynamic contrast enhancement of fibrocystic disease. Eur Radiol. 1999;9(6):1107-12. [pmid: 10415244].
145 Morris EA, Bassett LW, Berg WA, et al. ACR practice guideline for the performance of contrast-enhanced magnetic resonance imaging (MRI) of the breast [online publication]. Reston (VA). American College of Radiology (ACR). 2008:7. www.acr.org/SecondaryMainMenuCategories/quality_safety/guidelines/breast/mri_breast.aspx.
146 Medical magnetic resonance (MR) procedures: protection of patients. Health Phys. Aug. 2004;87(2):197-216. [pmid: 15257220].
147 Shellock FG. Radiofrequency energy-induced heating during MR procedures: a review. J Magn Reson Imaging. Jul. 2000;12(1):30-6. [pmid: 10931562].
148 Fiek M, Remp T, Reithmann C, et al. Complete loss of ICD programmability after magnetic resonance imaging. Pacing Clin Electrophysiol. Jul. 2004;27(7):1002-4. [pmid: 15271024].
149 Shellock FG. Magnetic resonance safety update 2002: implants and devices. J Magn Reson Imaging. Nov. 2002;16(5):485-96. [pmid: 12412025].
150 Foster JR, Hall DA, Summerfield AQ, et al. Sound-level measurements and calculations of safe noise dosage during EPI at 3 T. J Magn Reson Imaging. Jul. 2000;12(1):157-63. [pmid: 10931575].
151 Dempsey MF, Condon B, Hadley DM. Investigation of the factors responsible for burns during MRI. J Magn Reson Imaging. Apr. 2001;13(4):627-31. [pmid: 11276109].
152 Feychting M. Health effects of static magnetic fields--a review of the epidemiological evidence. Prog Biophys Mol Biol. Feb–Apr. 2005;87(2–3):241-6. [pmid: 15556662].
153 Hong CZ, Shellock FG. Short-term exposure to a 1.5 tesla static magnetic field does not affect somato-sensory-evoked potentials in man. Magn Reson Imaging. 1990;8(1):65-9. [pmid: 2325519].
154 Shellock FG, Schaefer DJ, Gordon CJ. Effect of a 1.5 T static magnetic field on body temperature of man. Magn Reson Med. Aug. 1986;3(4):644-7. [pmid: 3747826].
155 Budinger TF. Nuclear magnetic resonance (NMR) in vivo studies: known thresholds for health effects. J Comput Assist Tomogr. Dec. 1981;5(6):800-11. [pmid: 7033311].
156 Runge VM. Safety of approved MR contrast media for intravenous injection. J Magn Reson Imaging. Aug. 1. 2000;12(2):205-13. [pmid: 10931582].
157 Sardanelli F, Lozzelli A, Fausto A. MR imaging of the breast: indications, established technique, and new directions. Eur Radiol. Nov. 2003;13(Suppl 3):N28-36. [pmid: 15015878].
158 Centers for Disease Control and Prevention (CDC). Nephrogenic fibrosing dermopathy associated with exposure to gadolinium-containing contrast agents--St. Louis, Missouri, 2002–2006. MMWR Morb Mortal Wkly Rep. Feb. 23. 2007;56(7):137-41. [pmid: 17318112].
159 Marckmann P, Skov L, Rossen K, et al. Nephrogenic systemic fibrosis: suspected causative role of gadodiamide used for contrast-enhanced magnetic resonance imaging. J Am Soc Nephrol. Sep. 2006;17(9):2359-62. [pmid: 16885403].
160 Grobner T. Gadolinium--a specific trigger for the development of nephrogenic fibrosing dermopathy and nephrogenic systemic fibrosis. Nephrol Dial Transplant. Apr. 2006;21(4):1104-8. [pmid: 16431890].
161 Brice J. Experts put MRI accreditation program to the test. Diagn Imaging. Jul. 2001;23(7):44-7. 49.
162 Hachiya J, Seki T, Okada M, et al. MR imaging of the breast with Gd-DTPA enhancement: comparison with mammography and ultrasonography. Radiat Med. Nov-Dec. 1991;9(6):232-40. [pmid: 1668410].
163 Palmedo H, Grunwald F, Bender H, et al. Scintimammography with technetium-99m methoxyisobutylisonitrile: comparison with mammography and magnetic resonance imaging. Eur J Nucl Med. Aug. 1996;23(8):940-6. [pmid: 8753683].
164 Obdeijn IM, Kuijpers TJ, van Dijk P, et al. MR lesion detection in a breast cancer population. J Magn Reson Imaging. Nov–Dec. 1996;6(6):849-54. [pmid: 8956127].
165 Heiberg EV, Perman WH, Herrmann VM, et al. Dynamic sequential 3D gadolinium-enhanced MRI of the whole breast. Magn Reson Imaging. 1996;14(4):337-48. [pmid: 8782170].
166 Tiling R, Sommer H, Pechmann M, et al. Comparison of technetium-99m-sestamibi scintimammography with contrast- enhanced MRI for diagnosis of breast lesions. J Nucl Med. Jan. 1997;38(1):58-62. [pmid: 8998151].
167 Tiling R, Khalkhali I, Sommer H, et al. Role of technetium-99m sestamibi scintimammography and contrast- enhanced magnetic resonance imaging for the evaluation of indeterminate mammograms. Eur J Nucl Med. Oct. 1997;24(10):1221-9. [pmid: 9323262].
168 Del Maschio A, Bazzocchi M, Giuseppetti GM, et al. Breast MRI: report on a multicentric national trial by the Study Section of Magnetic Resonance and Breast Imaging. Radiol Med. Oct. 2002;104(4):262-72. [pmid: 12569307].
169 Peters NH, Borel Rinkes IH, Zuithoff NP, et al. Meta-analysis of MR imaging in the diagnosis of breast lesions. Radiology. Jan. 2008;246(1):116-24. [pmid: 18024435].
170 Blue Cross Blue Shield Association (BCBS). Magnetic resonance imaging of the breast: differential diagnosis of a breast lesion to avoid biopsy. Technol Eval Cent Asses Program. Feb. 2002;16(15):1-29.
171 Breast MRI for detection or diagnosis of primary or recurrent breast cancer. Technol Eval Cent Asses Program Exec Summ. Apr. 2004;19(1):1-9. [pmid: 15314823].
172 Hrung JM, Sonnad SS, Schwartz JS, et al. Accuracy of MR imaging in the work-up of suspicious breast lesions: a diagnostic meta-analysis. Acad Radiol. Jul. 1999;6(7):387-97. [pmid: 10410164].
173 Littenberg B, Moses LE. Estimating diagnostic accuracy from multiple conflicting reports: a new meta-analytic method. Med Decis Making. Oct-Dec. 1993;13(4):313-21. [pmid: 8246704].
174 Bergmann H, Dobrozemsky G, et al. An inter-laboratory comparison study of image quality of PET scanners using the NEMA NU 2-2001 procedure for assessment of image quality. Phys Med Biol. May. 21. 2005;50(10):2193-207. [pmid: 15876661].
175 Avril N, Schelling M, Dose J, et al. Utility of PET in breast cancer. Clin Positron Imaging. Oct. 1999;2(5):261-71. [pmid: 14516650].
176 McDonough MD, DePeri ER, Mincey BA. The role of positron emission tomographic imaging in breast cancer. Curr Oncol Rep. Jan. 2004;6(1):62-8. [pmid: 14664763].
177 Yutani K, Tatsumi M, Uehara T, et al. Effect of patients’ being prone during FDG PET for the diagnosis of breast cancer. AJR Am J Roentgenol. Nov. 1999;173(5):1337-9. [pmid: 10541114].
178 Rosen EL, Eubank WB, Mankoff DA. FDG PET, PET/CT, and breast cancer imaging. Radiographics. Oct. 2007;27(Suppl 1):S215-29. [pmid: 18180228].
179 Brenner DJ, Hall EJ. Computed tomography--an increasing source of radiation exposure. N Engl J Med. Nov. 29. 2007;357(22):2277-84. [pmid: 18046031].
180 Radiation exposure from medical exams and procedures: fact sheet. McLean (VA). Health Physics Society (HPS). 2010. Jan. 4. http://hps.org/documents/Medical_Exposures_Fact_Sheet.pdf.
181 Cronin B, Marsden PK, O’Doherty MJ. Are restrictions to behaviour of patients required following fluorine-18 fluorodeoxyglucose positron emission tomographic studies?. Eur J Nucl Med. Feb. 1999;26(2):121-8. [pmid: 9933345].
182 Silberstein EB. Prevalence of adverse reactions to positron emitting radiopharmaceuticals in nuclear medicine. Pharmacopeia Committee of the Society of Nuclear Medicine. J Nucl Med. Dec. 1998;39(12):2190-2. [pmid: 9867168].
183 Katanick SL. Fundamentals of ICANL accreditation. J Nucl Med Technol. Mar. 2005;33(1):19-23. [pmid: 15731016].
184 Yutani K, Tatsumi M, Shiba E, et al. Comparison of dual-head coincidence gamma camera FDG imaging with FDG PET in detection of breast cancer and axillary lymph node metastasis. J Nucl Med. Jun. 1999;40(6):1003-8. [pmid: 10452318].
185 Palmedo H, Bender H, Grunwald F, et al. Comparison of fluorine-18 fluorodeoxyglucose positron emission tomography and technetium-99m methoxyisobutylisonitrile scintimammography in the detection of breast tumours. Eur J Nucl Med. Sep. 1997;24(9):1138-45. [pmid: 9283107].
186 Crowe JP Jr, Adler LP, Shenk RR, et al. Positron emission tomography and breast masses: comparison with clinical, mammographic, and pathological findings. Ann Surg Oncol. Mar. 1994;1(2):132-40. [pmid: 7834438].
187 Tse NY, Hoh CK, Hawkins RA, et al. The application of positron emission tomographic imaging with fluorodeoxyglucose to the evaluation of breast disease. Ann Surg. Jul. 1992;216(1):27-34. [pmid: 1632699].
188 Holle LH, Trampert L, Lung-Kurt S, et al. Investigations of breast tumors with fluorine-18-fluorodeoxyglucose and SPECT. J Nucl Med. Apr. 1996;37(4):615-22. [pmid: 8691251].
189 Samson DJ, Flamm CR, Pisano ED, et al. Should FDG PET be used to decide whether a patient with an abnormal mammogram or breast finding at physical examination should undergo biopsy. Acad Radiol. Jul. 2002;9(7):773-83. [pmid: 12139091].
190 Agency for Healthcare Research and Quality (AHRQ). FDG positron emission tomography for evaluating breast cancer - systematic review. Rockville (MD). Agency for Healthcare Research and Quality (AHRQ). 2001. www.mrw.interscience.wiley.com/cochrane/clhta/articles/HTA-20020419/frame.html.
191 Escalona S, Blasco JA, Reza MM, et al. A systematic review of FDG-PET in breast cancer. Med Oncol. Mar. 2010;27(1):114-29. [pmid: 19277913].
192 Monticciolo DL. How useful are new radiographic tools for detecting breast cancer. Postgrad Med. Mar. 2004;115(3):76-7. [pmid: 15038257].
193 Prendergast A, Adams J, Delgado M, et al. SPECT vs. Planar Imaging [power point]. [slide set]. Waltham (MA). Daum Communications Corp. accessed 2010 Mar 2. [6 slides]. Available: http://74.125.93.132/search?q=cache:xzGe13cT8CUJ:keiserstudents.tripod.com/sitebuildercontent/sitebuilderfiles/spectvs.ppt+what+is+planar+imaging+AND+prendergast&cd=1&hl=en&ct=clnk&gl=us.
194 Edell SL, Eisen MD. Current imaging modalities for the diagnosis of breast cancer. Del Med J. Sep. 1999;71(9):377-82. [pmid: 10584437].
195 Khalkhali I, Caravaglia G, Abdel-Nabi HH, et al. Society of Nuclear Medicine procedure guideline for breast scintigraphy. version 2.0. Reston (VA). Society of Nuclear Medicine. 2004. Jun. 2. 4 p. http://interactive.snm.org/docs/Breast_v2.0.pdf.
196 Zegel H, Heller L, Edell S, et al. Tc-99m sestamibi scintimammography in the mammographically dense breast. Clin Nucl Med. Dec. 1999;24(12):968-74. [pmid: 10595479].
197 Schillaci O, Buscombe JR. Breast scintigraphy today: indications and limitations. Eur J Nucl Med Mol Imaging. Jun. 2004;31(Suppl 1):S35-45. [pmid: 15103505].
198 BSGI/Molecular breast imaging. [Web site]. Newport News (VA). Dilon Technologies. accessed 2010 Feb 16. [Various p]. Available: www.dilon.com/pages/bsgi__molecular_breast_imaging/34.php.
199 Hendrick RE. Radiation doses and cancer risks from breast imaging studies. Radiology. Oct. 2010;257(1):246-53. [pmid: 20736332].
200 Medical Advisory Secretariat, Ontario Ministry of Health and Long-Term Care. Scintimammography. Toronto. Ontario Ministry of Health and Long-Term Care. 2003. www.mrw.interscience.wiley.com/cochrane/clhta/articles/HTA-20040735/frame.html.
201 Thomson LE, Allman KC. Erythema multiforme reaction to sestamibi. J Nucl Med. Mar. 2001;42(3):534. [pmid: 11337537].
202 Hesslewood SR, Keeling DH. Frequency of adverse reactions to radiopharmaceuticals in Europe. Eur J Nucl Med. Sep. 1997;24(9):1179-82. [pmid: 9283115].
203 Klaus AJ, Klingensmith WC 3rd, Parker SH, et al. Comparative value of 99mTc-sestamibi scintimammography and sonography in the diagnostic workup of breast masses. AJR Am J Roentgenol. Jun. 2000;174(6):1779-83. [pmid: 10845522].
204 Bombardieri E, Crippa F, Baio SM, et al. Nuclear medicine advances in breast cancer imaging. Tumori. Sep-Oct. 2001;87(5):277-87. [pmid: 11765174].
205 Khalkhali I, Vargas HI. The role of nuclear medicine in breast cancer detection: functional breast imaging. Radiol Clin North Am. Sep. 2001;39(5):1053-68. [pmid: 11587058].
206 Bekis R, Derebek E, Balci P, et al. 99mTc sestamibi scintimammography. Screening mammographic non-palpable suspicious breast lesions: preliminary results. Nucl Med (Stuttg). Feb. 2004;43(1):16-20. [pmid: 14978536].
207 Fondrinier E, Muratet JP, Anglade E, et al. Clinical experience with 99mTc-MIBI scintimammography in patients with breast microcalcifications. Breast. Aug. 2004;13(4):316-20. [pmid: 15325666].
208 Krishnaiah G, Sher-Ahmed A, Ugwu-Dike M, et al. Technetium-99m sestamibi scintimammography complements mammography in the detection of breast cancer. Breast J. Jul-Aug. 2003;9(4):288-94. [pmid: 12846862].
209 Maunda KY, Chande H, Mselle TF, et al. 99mTc sestamibi scintimammography in the diagnosis of palpable breast masses. Nucl Med Commun. Feb. 2003;24(2):141-4. [pmid: 12548038].
210 Sampalis FS, Denis R, Picard D, et al. International prospective evaluation of scintimammography with (99m)technetium sestamibi. Am J Surg. Jun. 2003;185(6):544-9. [pmid: 12781883].
211 Sanidas EE, Koukouraki S, Velidaki A, et al. Contribution of 99mTc-anti-carcinoembryonic antigen antibody and 99mTc-sestamibi scintimammography in the evaluation of high risk palpable breast lesions. Nucl Med Commun. Mar. 2003;24(3):291-6. [pmid: 12612470].
212 Wilczek B, Aspelin P, Bone B, et al. Complementary use of scintimammography with 99m-Tc-MIBI to triple diagnostic procedure in palpable and non-palpable breast lesions. Acta Radiol. May. 2003;44(3):288-93. [pmid: 12752000].
213 Khalkhali I, Baum JK, Villanueva-Meyer J, et al. (99m)Tc sestamibi breast imaging for the examination of patients with dense and fatty breasts: multicenter study. Radiology. Jan. 2002;222(1):149-55. [pmid: 11799940].
214 Leidenius MH, Leppanen EA, Tykka HT, et al. The role of Tc99m-sestamibi scintimammography in combination with the triple assessment of primary breast cancer. Eur J Surg Oncol. Mar. 2002;28(2):108-12. [pmid: 11884044].
215 Aguilar J, Andres B, Nicolas F, et al. Value of 99mTc-MIBI scintimammography in women with impalpable breast lesions seen on mammography. Eur J Surg. May. 2001;167(5):344-6. [pmid: 11419548].
216 Alonso O, Massardo T, Delgado LB, et al. Is (99m)Tc-sestamibi scintimammography complementary to conventional mammography for detecting breast cancer in patients with palpable masses. J Nucl Med. Nov. 2001;42(11):1614-21. [pmid: 11696629].
217 Gutfilen B, Fonseca LM. Comparison of Tc-99m THY and Tc-99m MIBI scans for diagnosis of breast lesions. J Exp Clin Cancer Res. Sep. 2001;20(3):385-91. [pmid: 11718219].
218 Lumachi F, Ferretti G, Povolato M, et al. Sestamibi scintimammography in pT1 breast cancer: alternative or complementary to X-ray mammography. Anticancer Res. May-Jun. 2001;21(3C):2201-5. [pmid: 11501847].
219 Lumachi F, Ferretti G, Povolato M, et al. Usefulness of 99m-Tc-sestamibi scintimammography in suspected breast cancer and in axillary lymph node metastases detection. Eur J Surg Oncol. Apr. 2001;27(3):256-9. [pmid: 11373101].
220 Papantoniou V, Christodoulidou J, Papadaki E, et al. 99mTc-(V)DMSA scintimammography in the assessment of breast lesions: comparative study with 99mTc-MIBI. Eur J Nucl Med. Jul. 2001;28(7):923-8. [pmid: 11504092].
221 Chen S, Liu W, Mao Y, et al. 99 mTc-MIBI and 99 mTc-MDP scintimammography for detecting breast carcinoma. Chin Med J. 2000;113(5):400-3. [pmid: 11776092].
222 Danielsson R, Bone B, Gad A, et al. Sensitivity and specificity of planar scintimammography with 99mTc-sestamibi. Acta Radiol. Jul. 1999;40(4):394-9. [pmid: 10394867].
223 Danielsson R, Bone B, Agren B, et al. Comparison of planar and SPECT scintimammography with 99mTc-sestamibi in the diagnosis of breast carcinoma. Acta Radiol. Mar. 1999;40(2):176-80. [pmid: 10080730].
224 Obwegeser R, Berghammer P, Rodrigues M, et al. A head-to-head comparison between technetium-99m-tetrofosmin and technetium-99m-MIBI scintigraphy to evaluate suspicious breast lesions. Eur J Nucl Med. Dec. 1999;26(12):1553-9. [pmid: 10638406].
225 Tofani A, Sciuto R, Semprebene A, et al. 99Tcm-MIBI scintimammography in 300 consecutive patients: factors that may affect accuracy. Nucl Med Commun. Dec. 1999;20(12):1113-21. [pmid: 10664992].
226 De Vincentis G, Gianni W, Pani R, et al. Role of 99 mTc-Sestamibi scintimammography by SPEM camera in the management of breast cancer in the elderly. Breast Cancer Res Treat. 1998;48(2):159-63. [pmid: 9596487].
227 Mekhmandarov S, Sandbank J, Cohen M, et al. Technetium-99m-MIBI scintimammography in palpable and nonpalpable breast lesions. J Nucl Med. Jan. 1998;39(1):86-91. [pmid: 9443742].
228 Uriarte I, Carril JM, Quirce R, et al. Optimization of X-ray mammography and technetium-99m methoxyisobutylisonitrile scintimammography in the diagnosis of non- palpable breast lesions. Eur J Nucl Med. May. 1998;25(5):491-6. [pmid: 9575244].
229 Alonso JC, Soriano A, Zarca MA, et al. Breast cancer detection with sestamibi-Tc-99m and Tl-201 radionuclides in patients with non conclusive mammography. Anticancer Res. May–Jun. 1997;17(3B):1661-5. [pmid: 9179214].
230 Ambrus E, Rajtar M, Ormandi K, et al. Value of 99m-Tc MIBI and 99m-Tc(V) DMSA scintigraphy in evaluation of breast mass lesions. Anticancer Res. May–Jun. 1997;17(3B):1599-605. [pmid: 9179201].
231 Carril JM, Gomez-Barquin R, Quirce R, et al. Contribution of 99mTc-MIBI scintimammography to the diagnosis of non- palpable breast lesions in relation to mammographic probability of malignancy. Anticancer Res. May–Jun. 1997;17(3B):1677-81. [pmid: 9179217].
232 Chen SL, Yin YQ, Chen JX, et al. The usefulness of technetium-99m-MIBI scintimammography in diagnosis of breast cancer: using surgical histopathologic diagnosis as the gold standard. Anticancer Res. May–Jun. 1997;17(3B):1695-8. [pmid: 9179221].
233 Schillaci O, Scopinaro F, Danieli R, et al. 99Tcm-sestamibi scintimammography in patients with suspicious breast lesions: comparison of SPET and planar images in the detection of primary tumours and axillary lymph node involvement. Nucl Med Commun. Sep. 1997;18(9):839-45. [pmid: 9352550].
234 Scopinaro F, Schillaci O, Ussof W, et al. A three center study on the diagnostic accuracy of 99mTc-MIBI scintimammography. Anticancer Res. May–Jun. 1997;17(3B):1631-4. [pmid: 9179208].
235 Scopinaro F, Ierardi M, Porfiri LM, et al. 99mTc-MIBI prone scintimammography in patients with high and intermediate risk mammography. Anticancer Res. May–Jun. 1997;17(3B):1635-8. [pmid: 9179209].
236 Maffioli L, Agresti R, Chiti A, et al. Prone scintimammography in patients with non-palpable breast lesions. Anticancer Res. May–Jun. 1996;16(3A):1269-73. [pmid: 8702249].
237 Palmedo H, Schomburg A, Grunwald F, et al. Scintimammography with Tc-99m MIBI in patients with suspicion of primary breast cancer. Nucl Med Biol. Aug. 1996;23(6):681-4. [pmid: 8940710].
238 Palmedo H, Schomburg A, Grunwald F, et al. Technetium-99m-MIBI scintimammography for suspicious breast lesions. J Nucl Med. Apr. 1996;37(4):626-30. [pmid: 8691253].
239 Villanueva-Meyer J, Leonard MH Jr, Briscoe E, et al. Mammoscintigraphy with technetium-99m-sestamibi in suspected breast cancer. J Nucl Med. Jun. 1996;37(6):926-30. [pmid: 8683313].
240 Yuen-Green M, Wasnich R, Caindec-Ranchez S, et al. New method for breast cancer detection using TC-99m sestamibi scintimammography. Hawaii Med J. Feb. 1996;55(2):26-8. [pmid: 8820628].
241 Burak Z, Argon M, Memis A, et al. Evaluation of palpable breast masses with 99Tcm-MIBI: a comparative study with mammography and ultrasonography. Nucl Med Commun. Aug. 1994;15(8):604-12. [pmid: 7970442].
242 Hussain R, Buscombe JR. A meta-analysis of scintimammography: an evidence-based approach to its clinical utility. Nucl Med Commun. Jul. 2006;27(7):589-94. [pmid: 16794520].
243 Liu M, Guo YM, Guo XJ, et al. Evaluation of 99mTc-MIBI scintimammorgraphy in the diagnosis of primary breast cancer: A meta-analysis. Chi J Evid Based Med. Jul. 2005;5(7):536-42.
244 Liberman M, Sampalis F, Mulder DS, et al. Breast cancer diagnosis by scintimammography: a meta-analysis and review of the literature (Provisional record). Breast Cancer Res Treat. 2003;80(1):115-26. [pmid: 12889605].
245 Allen MW, Hendi P, Schwimmer J, et al. Decision analysis for the cost effectiveness of sestamibi scintimammography in minimizing unnecessary biopsies. Q J Nucl Med. Jun. 2000;44(2):168-85. [pmid: 10967626].
246 Hillner BE. Decision analysis: MIBI imaging of nonpalpable breast abnormalities. J Nucl Med. Nov. 1997;38(11):1772-8. [pmid: 9374352].
247 Skaane P. Ultrasonography as adjunct to mammography in the evaluation of breast tumors. Acta Radiol Suppl. 1999;420:7-47. [pmid: 10693544].
248 Athanasiou A, Tardivon A, Ollivier L, et al. How to optimize breast ultrasound. Eur J Radiol. Jan. 2009;69(1):6-13. [pmid: 18818037].
249 Sehgal CM, Weinstein SP, Arger PH, et al. A review of breast ultrasound. J Mammary Gland Biol Neoplasia. Apr. 2006;11(2):113-23. [pmid: 17082996].
250 Gokhale S. Ultrasound characterization of breast masses. Indian J Radiol Imaging. Aug. 1. 2009;19(3):242-7. [pmid: 19881096].
251 American College of Radiology (ACR). ACR Breast Imaging and Reporting Data System, Breast Imaging Atlas. Reston (VA). American College of Radiology (ACR). 2003. ACR BI-RADS - Ultrasound.
252 Martinoli C, Pretolesi F, Crespi G, et al. Power Doppler sonography: clinical applications. Eur J Radiol. May. 1998;27(Suppl 2):S133-40. [pmid: 9652513].
253 Wink MH, Wijkstra H, De La Rosette JJ, et al. Ultrasound imaging and contrast agents: A safe alternative to MRI. Minim Invasive Ther Allied Technol. Apr. 2006;15(2):93-100. [pmid: 16754192].
254 Boonjunwetwat D, Prathombutr A. Imaging of benign papillary neoplasm of the breast: mammographic, galactographic and sonographic findings. J Med Assoc Thai. Aug. 2000;83(8):832-8. [pmid: 10998834].
255 American College of Radiology. Breast ultrasound accreditation program requirements. Reston (VA). American College of Radiology. 2005. 9 p. www.acr.org/s_acr/bin.asp?CID=591&DID=12137&DOC=FILE.PDF.
256 Chen SC, Cheung YC, Su CH, et al. Analysis of sonographic features for the differentiation of benign and malignant breast tumors of different sizes. Ultrasound Obstet Gynecol. Feb. 2004;23(2):188-93. [pmid: 14770402].
257 McNicholas MM, Mercer PM, Miller JC, et al. Color Doppler sonography in the evaluation of palpable breast masses. AJR Am J Roentgenol. Oct. 1993;161(4):765-71. [pmid: 8372754].
258 van Oord JC, van der Vliet AM, Thyn CJ, et al. The value of ultrasound mammography in palpable breast masses. Rofo. Jul. 1991;155(1):63-6. [pmid: 1854938].
259 Flobbe K, Kessels AG, Severens JL, et al. Costs and effects of ultrasonography in the evaluation of palpable breast masses. Int J Technol Assess Health Care. Fall. 2004;20(4):440-8. [pmid: 15609793].
260 Flobbe K, Bosch AM, Kessels AG, et al. The additional diagnostic value of ultrasonography in the diagnosis of breast cancer. Arch Intern Med. May. 26. 2003;163(10):1194-9. [pmid: 12767956].
261 Wiratkapun C, Bunyapaiboonsri W, Wibulpolprasert B, et al. Biopsy rate and positive predictive value for breast cancer in BI-RADS category 4 breast lesions. J Med Assoc Thai. Jul. 2010;93(7):830-7. [pmid: 20649064].
262 Venkatesan A, Chu P, Kerlikowske K, et al. Positive predictive value of specific mammographic findings according to reader and patient variables. Radiology. Mar. 2009;250(3):648-57. [pmid: 19164116].
263 Liang W, Lawrence WF, Burnett CB, et al. Acceptability of diagnostic tests for breast cancer. Breast Cancer Res Treat. May. 2003;79(2):199-206. [pmid: 12825854].
264 Verkooijen HM, Peeters PH, Buskens E, et al. Diagnostic accuracy of large-core needle biopsy for nonpalpable breast disease: a meta-analysis. Br J Cancer. Mar. 2000;82(5):1017-21. [pmid: 10737383].
265 Antley CM, Mooney EE, Layfield LJ. A comparison of accuracy rates between open biopsy, cutting-needle biopsy, and fine-needle aspiration biopsy of the breast: a 3-year experience. Breast J. 1998;4(1):3-8.
266 Page DL, Dupont WD, Rogers LW, et al. Intraductal carcinoma of the breast: follow-up after biopsy only. Cancer. Feb. 15. 1982;49(4):751-8. [pmid: 6275978].
267 Yen MF, Tabar L, Vitak B, et al. Quantifying the potential problem of overdiagnosis of ductal carcinoma in situ in breast cancer screening. Eur J Cancer. Aug. 2003;39(12):1746-54. [pmid: 12888370].