# Peer Reviewers

Wendie Berg, M.D., Ph.D.

American Radiology Services/Johns Hopkins

Lutherville, MD

Christopher Comstock, M.D.

Memorial Sloan Kettering Cancer Center

New York, NY

Deborah Laxague, R.N.

National Breast Cancer Coalition

Grenada, CA

Carol Lee, M.D.

Memorial Sloan Kettering Cancer Center

New York, NY

Constance Lehman, M.D., Ph.D.

University of Washington

Seattle, WA