# Glossary

Atypical ductal hyperplasia: A condition in which the cells that line the milk ducts of the breast experience abnormal growth. The lesion itself is not malignant but may sometimes contain foci of malignant cells and women with ADH have an elevated risk of developing a malignant lesion.
Doppler ultrasound: A method of using ultrasound to evaluate blood flow through vessels. The speed of blood flow is evaluated by observing changes in the pitch of the reflected sound waves.
Ductal carcinoma in situ: A type of early stage breast cancer that is confined to the breast duct in which it arose.
Harmonic ultrasound: Ultrasound waves develop harmonics as they pass through breast tissue. Digital encoding can be used by computers to construct images from the harmonic frequencies.
High-risk lesion: Any of a number of different types of non-cancerous lesions of the breast that have been observed to sometimes contain foci of malignant cells, and women diagnosed with these types of lesions have an elevated risk of developing a malignant lesion. Some common types of high-risk lesions include atypical ductal hyperplasia (ADH), radial scars, papillary lesions, atypical lobular hyperplasia (ALH), and lobular carcinoma in situ (LCIS). Magnetic resonance imaging: A method of imaging internal anatomy by using strong magnetic fields and radiofrequency energy.
Microcalcification: A tiny deposit of calcium visible as a bright spot on a mammogram. Tight clusters of microcalcifications may be a sign of a malignant lesion.
Negative likelihood ratio: The ability of the diagnostic test to accurately “rule out” the presence of breast cancer.
Negative predictive value: The probability of a woman actually not having breast cancer after testing negative for breast cancer. Negative predictive value = (true negatives)/(false negatives + true negatives).
Palpable lesion: A breast lesion that can be felt by manual manipulation.
Positive likelihood ratio: The ability of the diagnostic test to accurately predict the presence of breast cancer.
Positive predictive value: The probability of a woman actually having breast cancer after testing positive for breast cancer. Positive predictive value = (true positives)/(true positives + false positives).
Positron emission tomography: A method of imaging tissues by tracking the metabolism of a positron-emitting radioactive tracer.
Scintimammography: A method of imaging tissues by tracking the metabolism of a radioactive tracer.
Sensitivity: The proportion of women with breast cancer who test positive for breast cancer. Sensitivity = (true positives)/(true positives + false negatives).
Specificity: The proportion of women with benign lesions who test negative for breast cancer. Specificity = (true negatives)/(false positives + true negatives).
Tomography ultrasound: Multiple ultrasound images from different angles are acquired and a computer used the information to develop a three-dimensional image of the interior anatomy of the breast.
Ultrasound: A method of imaging anatomy by observing the reflections of high-frequency sound waves off of tissues with different acoustic properties. Conventional ultrasound is often referred to as B-mode ultrasound.