# References to Appendixes

1 Akita A, Tanimoto A, Jinno H, et al. The clinical value of bilateral breast MR imaging: is it worth performing on patients showing suspicious microcalcifications on mammography. Eur Radiol. Sep. 2009;19(9):2089-96. [pmid: 19350244].
2 Baltzer PA, Freiberg C, Beger S, et al. Clinical MR-mammography: are computer-assisted methods superior to visual or manual measurements for curve type analysis? A systematic approach. Acad Radiol. Sep. 2009;16(9):1070-6. [pmid: 19523854].
3 Hara M, Watanabe T, Okumura A, et al. Angle between 1 and 4 min gives the most significant difference in time-intensity curves between benign disease and breast cancer: analysis of dynamic magnetic resonance imaging in 103 patients with breast lesions. Clin Imaging. Sep. 2009;33(5):335-42. [pmid: 19712811].
4 Kim IJ, Kim YK, Kim SJ. Detection and prediction of breast cancer using double phase Tc-99m MIBI scintimammography in comparison with MRI. Onkologie. Oct. 2009;32(10):556-60. [pmid: 19816071].
5 Lo GG, Ai V, Chan JK, et al. Diffusion-weighted magnetic resonance imaging of breast lesions: first experiences at 3 T. J Comput Assist Tomogr. Jan. 2009;33(1):63-9. [pmid: 19188787].
6 Imbriaco M, Caprio MG, Limite G, et al. Dual-time-point 18F-FDG PET/CT versus dynamic breast MRI of suspicious breast lesions. AJR Am J Roentgenol. Nov. 2008;191(5):1323-30. [pmid: 18941064].
7 Pediconi F, Catalano C, Padula S, et al. Contrast-enhanced MR mammography: improved lesion detection and differentiation with gadobenate dimeglumine. AJR Am J Roentgenol. Nov. 2008;191(5):1339-46. [pmid: 18941066].
8 Vassiou K, Kanavou T, Vlychou M, et al. Characterization of breast lesions with CE-MR multimodal morphological and kinetic analysis: comparison with conventional mammography and high-resolution ultrasound. Eur J Radiol. Apr. 2009;70(1):69-76. [pmid: 18295425].
9 Brem RF, Petrovitch I, Rapelyea JA, et al. Breast-specific gamma imaging with 99mTc-Sestamibi and magnetic resonance imaging in the diagnosis of breast cancer--a comparative study. Breast J. Sep. 2007;13(5):465-9. [pmid: 17760667].
10 Cilotti A, Iacconi C, Marini C, et al. Contrast-enhanced MR imaging in patients with BI-RADS 3–5 microcalcifications. Radiol Med. Mar. 2007;112(2):272-86. [pmid: 17361370].
11 Pediconi F, Catalano C, Padula S, et al. Contrast-enhanced magnetic resonance mammography: does it affect surgical decision-making in patients with breast cancer. Breast Cancer Res Treat. Nov. 2007;106(1):65-74. [pmid: 17203383].
12 Zhu J, Kurihara Y, Kanemaki Y, et al. Diagnostic accuracy of high-resolution MRI using a microscopy coil for patients with presumed DCIS following mammography screening. J Magn Reson Imaging. Jan. 2007;25(1):96-103. [pmid: 17154376].
13 Bazzocchi M, Zuiani C, Panizza P, et al. Contrast-enhanced breast MRI in patients with suspicious microcalcifications on mammography: results of a multicenter trial. AJR Am J Roentgenol. Jun. 2006;186(6):1723-32. [pmid: 16714666].
14 Gokalp G, Topal U. MR imaging in probably benign lesions (BI-RADS category 3) of the breast. Eur J Radiol. Mar. 2006;57(3):436-44. [pmid: 16316732].
15 Kneeshaw PJ, Lowry M, Manton D, et al. Differentiation of benign from malignant breast disease associated with screening detected microcalcifications using dynamic contrast enhanced magnetic resonance imaging. Breast. Feb. 2006;15(1):29-38. [pmid: 16002292].
16 Ricci P, Cantisani V, Ballesio L, et al. Benign and malignant breast lesions: efficacy of real time contrast-enhanced ultrasound vs. magnetic resonance imaging. Ultraschall Med. Feb. 2007;28(1):57-62. [pmid: 17304413].
17 Pediconi F, Catalano C, Venditti F, et al. Color-coded automated signal intensity curves for detection and characterization of breast lesions: preliminary evaluation of a new software package for integrated magnetic resonance-based breast imaging. Invest Radiol. Jul. 2005;40(7):448-57. [pmid: 15973137].
18 Pediconi F, Catalano C, Occhiato R, et al. Breast lesion detection and characterization at contrast-enhanced MR mammography: gadobenate dimeglumine versus gadopentetate dimeglumine. Radiology. Oct. 2005;237(1):45-56. [pmid: 16126926].
19 Wiener JI, Schilling KJ, Adami C, et al. Assessment of suspected breast cancer by MRI: a prospective clinical trial using a combined kinetic and morphologic analysis. AJR Am J Roentgenol. Mar. 2005;184(3):878-86. [pmid: 15728612].
20 Bluemke DA, Gatsonis CA, Chen MH, et al. Magnetic resonance imaging of the breast prior to biopsy. JAMA. Dec. 8. 2004;292(22):2735-42. [pmid: 15585733].
21 Huang W, Fisher PR, Dulaimy K, et al. Detection of breast malignancy: diagnostic MR protocol for improved specificity. Radiology. Aug. 2004;232(2):585-91. [pmid: 15205478].
22 Bone B, Wiberg MK, Szabo BK, et al. Comparison of 99mTc-sestamibi scintimammography and dynamic MR imaging as adjuncts to mammography in the diagnosis of breast cancer. Acta Radiol. Jan. 2003;44(1):28-34. [pmid: 12630995].
23 drup-Link HE, Kaiser A, Helbich T, et al. Macromolecular contrast medium (feruglose) versus small molecular contrast medium (gadopentetate) enhanced magnetic resonance imaging: differentiation of benign and malignant breast lesions. Acad Radiol. Nov. 2003;10(11):1237-46. [pmid: 14626298].
24 Heinisch M, Gallowitsch HJ, Mikosch P, et al. Comparison of FDG-PET and dynamic contrast-enhanced MRI in the evaluation of suggestive breast lesions. Breast. Feb. 2003;12(1):17-22. [pmid: 14659351].
25 Walter C, Scheidhauer K, Scharl A, et al. Clinical and diagnostic value of preoperative MR mammography and FDG-PET in suspicious breast lesions. Eur Radiol. Jul. 2003;13(7):1651-6. [pmid: 12835981].
26 Guo Y, Cai YQ, Cai ZL, et al. Differentiation of clinically benign and malignant breast lesions using diffusion-weighted imaging. J Magn Reson Imaging. Aug. 2002;16(2):172-8. [pmid: 12203765].
27 Kelcz F, Furman-Haran E, Grobgeld D, et al. Clinical testing of high-spatial-resolution parametric contrast-enhanced MR imaging of the breast. AJR Am J Roentgenol. Dec. 2002;179(6):1485-92. [pmid: 12438042].
28 Schedel H, Oellinger H, Kohlschein P, et al. Magnetic Resonance Female Breast Imaging (MRFBI) - Evaluation of the Changes in Signal Intensity over Time Pre- and Post-administration of 0.2 mmol/kg Gd-DTPA. Zentralbl Gynakol. Feb. 2002;124(2):104-10. [pmid: 11935495].
29 Trecate G, Tess JD, Vergnaghi D, et al. Breast microcalcifications studied with 3D contrast-enhanced high-field magnetic resonance imaging: more accuracy in the diagnosis of breast cancer. Tumori. May. 2002;88(3):224-33. [pmid: 12195761].
30 Kristoffersen WM, Aspelin P, Perbeck L, et al. Value of MR imaging in clinical evaluation of breast lesions. Acta Radiol. May. 2002;43(3):275-81. [pmid: 12100324].
31 Brix G, Henze M, Knopp MV, et al. Comparison of pharmacokinetic MRI and [18F] fluorodeoxyglucose PET in the diagnosis of breast cancer: initial experience. Eur Radiol. 2001;11(10):2058-70. [pmid: 11702142].
32 Cecil KM, Schnall MD, Siegelman ES, et al. The evaluation of human breast lesions with magnetic resonance imaging and proton magnetic resonance spectroscopy. Breast Cancer Res Treat. Jul. 2001;68(1):45-54. [pmid: 11678308].
33 Furman-Haran E, Grobgeld D, Kelcz F, et al. Critical role of spatial resolution in dynamic contrast-enhanced breast MRI. J Magn Reson Imaging. Jun. 2001;13(6):862-7. [pmid: 11382945].
34 Imbriaco M, Del VS, Riccardi A, et al. Scintimammography with 99mTc-MIBI versus dynamic MRI for non-invasive characterization of breast masses. Eur J Nucl Med. Jan. 2001;28(1):56-63. [pmid: 11202453].
35 Malich A, Boehm T, Facius M, et al. Differentiation of mammographically suspicious lesions: evaluation of breast ultrasound, MRI mammography and electrical impedance scanning as adjunctive technologies in breast cancer detection. Clin Radiol. Apr. 2001;56(4):278-83. [pmid: 11286578].
36 Nakahara H, Namba K, Fukami A, et al. Three-dimensional MR imaging of mammographically detected suspicious microcalcifications. Breast Cancer. 2001;8(2):116-24. [pmid: 11342984].
37 Torheim G, Godtliebsen F, Axelson D, et al. Feature extraction and classification of dynamic contrast-enhanced T2*-weighted breast image data. IEEE Trans Med Imaging. Dec. 2001;20(12):1293-301. [pmid: 11811829].
38 Wedegartner U, Bick U, Wortler K, et al. Differentiation between benign and malignant findings on MR-mammography: usefulness of morphological criteria. Eur Radiol. 2001;11(9):1645-50. [pmid: 11511885].
39 Yeung DK, Cheung HS, Tse GM. Human breast lesions: characterization with contrast-enhanced in vivo proton MR spectroscopy--initial results. Radiology. Jul. 2001;220(1):40-6. [pmid: 11425970].
40 Kvistad KA, Rydland J, Vainio J, et al. Breast lesions: evaluation with dynamic contrast-enhanced T1-weighted MR imaging and with T2*-weighted first-pass perfusion MR imaging. Radiology. Aug. 2000;216(2):545-53. [pmid: 10924584].
41 Van GM, De Biltjes IG, Schepper AM. Indications for MR mammography. A Belgian study. JBR-BTR. Jun. 2000;83(3):126-9. [pmid: 11025925].
42 Kaida H, Ishibashi M, Fuji T, et al. Improved breast cancer detection of prone breast fluorodeoxyglucose-PET in 118 patients. Nucl Med Commun. Oct. 2008;29(10):885-93. [pmid: 18769306].
43 Buchmann I, Riedmuller K, Hoffner S, et al. Comparison of 99mtechnetium-pertechnetate and 123iodide SPECT with FDG-PET in patients suspicious for breast cancer. Cancer Biother Radiopharm. Dec. 2007;22(6):779-89. [pmid: 18158769].
44 Schirrmeister H, Kuhn T, Guhlmann A, et al. Fluorine-18 2-deoxy-2-fluoro-D-glucose PET in the preoperative staging of breast cancer: comparison with the standard staging procedures. Eur J Nucl Med. Mar. 2001;28(3):351-8. [pmid: 11315604].
45 Yutani K, Shiba E, Kusuoka H, et al. Comparison of FDG-PET with MIBI-SPECT in the detection of breast cancer and axillary lymph node metastasis. J Comput Assist Tomogr. Mar. 2000;24(2):274-80. [pmid: 10752892].
46 Grosso M, Chiacchio S, Bianchi F, et al. Comparison between 99mTc-sestamibi scintimammography and X-ray mammography in the characterization of clusters of microcalcifications: a prospective long-term study. Anticancer Res. Oct. 2009;29(10):4251-7. [pmid: 19846982].
47 Habib S, Maseeh-uz-Zaman, Hameed A, et al. Diagnostic accuracy of Tc-99m-MIBI for breast carcinoma in correlation with mammography and sonography. J Coll Physicians Surg Pak. Oct. 2009;19(10):622-6. [pmid: 19811712].
48 Kim IJ, Kim SJ, Kim YK. Comparison of double phase Tc-99m MIBI and Tc-99m tetrofosmin scintimammography for characterization of breast lesions: Visual and quantitative analyses. Neoplasma. 2008;55(6):526-31. [pmid: 18999882].
49 Wang F, Wang Z, Wu J, et al. The role of technetium-99m-labeled octreotide acetate scintigraphy in suspected breast cancer and correlates with expression of SSTR. Nucl Med Biol. Aug. 2008;35(6):665-71. [pmid: 18678351].
50 Gommans GM, van der Zant FM, van DA, et al. (99M)Technetium-sestamibi scintimammography in non-palpable breast lesions found on screening X-ray mammography. Eur J Surg Oncol. Feb. 2007;33(1):23-7. [pmid: 17126524].
51 Kim SJ, Bae YT, Lee JS, et al. Diagnostic performances of double-phase tc-99m MIBI scintimammography in patients with indeterminate ultrasound findings: visual and quantitative analyses. Ann Nucl Med. Jun. 2007;21(3):145-50. [pmid: 17561585].
52 Schillaci O, Danieli R, Filippi L, et al. Scintimammography with a hybrid SPECT/CT imaging system. Anticancer Res. Jan. 2007;27(1 B):557-62. [pmid: 17348441].
53 Pinero A, Galindo PJ, Illana J, et al. Diagnostic efficiency of sestamibi gammagraphy and Doppler sonography in the preoperative assessment of breast lesions. Clin Transl Oncol. Feb. 2006;8(2):103-7. [pmid: 16632424].
54 Mathieu I, Mazy S, Willemart B, et al. Inconclusive triple diagnosis in breast cancer imaging: is there a place for scintimammography. J Nucl Med. Oct. 2005;46(10):1574-81. [pmid: 16204705].
55 Gokalp G, Topal U, Kizilkaya E. Power Doppler sonography: anything to add to BI-RADS US in solid breast masses. Eur J Radiol. Apr. 2009;70(1):77-85. [pmid: 18243623].
56 Liu H, Jiang YX, Liu JB, et al. Evaluation of breast lesions with contrast-enhanced ultrasound using the microvascular imaging technique: initial observations. Breast. Oct. 2008;17(5):532-9. [pmid: 18534851].
57 Vade A, Lafita VS, Ward KA, et al. Role of breast sonography in imaging of adolescents with palpable solid breast masses. AJR Am J Roentgenol. Sep. 2008;191(3):659-63. [pmid: 18716091].
58 Cha JH, Moon WK, Cho N, et al. Characterization of benign and malignant solid breast masses: comparison of conventional US and tissue harmonic imaging. Radiology. Jan. 2007;242(1):63-9. [pmid: 17090709].
59 Chala L, Endo E, Kim S, et al. Gray-scale sonography of solid breast masses: diagnosis of probably benign masses and reduction of the number of biopsies. J Clin Ultrasound. Jan. 2007;35(1):9-19. [pmid: 17149763].
60 Zhi H, Ou B, Luo BM, et al. Comparison of ultrasound elastography, mammography, and sonography in the diagnosis of solid breast lesions. J Ultrasound Med. Jun. 2007;26(6):807-15. [pmid: 17526612].
61 Cho N, Moon WK, Cha JH, et al. Differentiating benign from malignant solid breast masses: comparison of two-dimensional and three-dimensional US. Radiology. Jul. 2006;240(1):26-32. [pmid: 16684920].
62 Forsberg F, Goldberg BB, Merritt CR, et al. Diagnosing breast lesions with contrast-enhanced 3-dimensional power Doppler imaging. J Ultrasound Med. Feb. 2004;23(2):173-82. [pmid: 14992354].
63 Meyberg-Solomayer GC, Kraemer B, Bergmann A, et al. Does 3-D sonography bring any advantage to noninvasive breast diagnostics. Ultrasound Med Biol. May. 2004;30(5):583-9. [pmid: 15183222].
64 Zdemir A, Kilic K, Ozdemir H, et al. Contrast-enhanced power Doppler sonography in breast lesions: effect on differential diagnosis after mammography and gray scale sonography. J Ultrasound Med. Feb. 2004;23(2):183-95. [pmid: 14992355].
65 Chen DR, Jeng LB, Kao A, et al. Comparing thallium-201 spect mammoscintigraphy and ultrasonography to detect breast cancer in mammographical dense breasts. Neoplasma. 2003;50(3):222-6. [pmid: 12937857].
66 Kook SH, Kwag HJ. Value of contrast-enhanced power Doppler sonography using a microbubble echo-enhancing agent in evaluation of small breast lesions. J Clin Ultrasound. Jun. 2003;31(5):227-38. [pmid: 12767017].
67 Marini C, Traino C, Cilotti A, et al. Differentiation of benign and malignant breast microcalcifications: mammography versus mammography-sonography combination. Radiol Med. Jan. 2003;105(1–2):17-26. [pmid: 12700541].
68 Caruso G, Ienzi R, Cirino A, et al. Breast lesion characterization with contrast-enhanced US Work in progress. Radiol Med. Nov. 2002;104(5–6):443-50. [pmid: 12589266].
69 Koukouraki S, Koukourakis MI, Vagios E, et al. The role of 99mTc-sestamibi scintimammography and colour Doppler ultrasonography in the evaluation of breast lesions. Nucl Med Commun. Nov. 2001;22(11):1243-8. [pmid: 11606891].
70 Milz P, Lienemann A, Kessler M, et al. Evaluation of breast lesions by power Doppler sonography. Eur Radiol. 2001;11(4):547-54. [pmid: 11354745].
71 Reinikainen H, Rissanen T, Paivansalo M, et al. B-mode, power Doppler and contrast-enhanced power Doppler ultrasonography in the diagnosis of breast tumors. Acta Radiol. Jan. 2001;42(1):106-13. [pmid: 11167342].
72 Moon WK, Im JG, Noh DY, et al. Nonpalpable breast lesions: evaluation with power Doppler US and a microbubble contrast agent-initial experience. Radiology. Oct. 2000;217(1):240-6. [pmid: 11012451].
73 Blohmer JU, Oellinger H, Schmidt C, et al. Comparison of various imaging methods with particular evaluation of color Doppler sonography for planning surgery for breast tumors. Arch Gynecol Obstet. 1999;262(3–4):159-71. [pmid: 10326635].
74 Chao TC, Lo YF, Chen SC, et al. Prospective sonographic study of 3093 breast tumors. J Ultrasound Med. May. 1999;18(5):363-70. [pmid: 10327015].
75 Schroeder RJ, Maeurer J, Vogl TJ, et al. D-galactose-based signal-enhanced color Doppler sonography of breast tumors and tumorlike lesions. Invest Radiol. Feb. 1999;34(2):109-15. [pmid: 9951790].
76 Albrecht T, Patel N, Cosgrove DO, et al. Enhancement of power Doppler signals from breast lesions with the ultrasound contrast agent EchoGen emulsion: subjective and quantitative assessment. Acad Radiol. Apr. 1998;5(Suppl 1):S195-198. [pmid: 9561080].
77 Wilkens TH, Burke BJ, Cancelada DA, et al. Evaluation of palpable breast masses with color Doppler sonography and gray scale imaging. J Ultrasound Med. Feb. 1998;17(2):109-15. [pmid: 9527570].
78 Buadu LD, Murakami J, Murayama S, et al. Colour Doppler sonography of breast masses: a multiparameter analysis. Clin Radiol. 1997;52:917-23. [pmid: 9413965].
79 Stavros AT, Thickman D, Rapp CL, et al. Solid breast nodules: use of sonography to distinguish between benign and malignant lesions. Radiology. Jul. 1995;196(1):123-34. [pmid: 7784555].
80 Ciatto S, Rosselli del TM, Catarzi S, et al. The contribution of ultrasonography to the differential diagnosis of breast cancer. Neoplasma. 1994;41(6):341-5. [pmid: 7870218].
81 Perre CI, Koot VC, de HP, et al. The value of ultrasound in the evaluation of palpable breast tumours: a prospective study of 400 cases. Eur J Surg Oncol. Dec. 1994;20(6):637-40. [pmid: 7995413].
82 Owens DK, Lohr KN, Atkins D, et al. Grading the strength of a body of evidence when comparing medical interventions-Agency for Healthcare Research and Quality and the Effective Health Care Program. J Clin Epidemiol. May. 2010;63(5):513-23. [pmid: 19595577].
83 Owens D, Lohr K, Atkins D, et al. Grading the strength of a body of evidence when comparing medical interventions. Jul. 2009:19.
84 Whiting P, Rutjes AW, Reitsma JB, et al. The development of QUADAS: a tool for the quality assessment of studies of diagnostic accuracy included in systematic reviews. BMC Med Res Methodol. Nov. 10. 2003;3(1):25. [pmid: 14606960].
85 Higgins JP, Thompson SG. Quantifying heterogeneity in a meta-analysis. Stat Med. Jun. 15. 2002;21(11):1539-58. [pmid: 12111919].
86 Higgins JP, Thompson SG, Deeks JJ, et al. Measuring inconsistency in meta-analyses. BMJ. Sep. 6. 2003;327(7414):557-60. [pmid: 12958120].
87 Zhao H, Steinberg GK, Sapolsky RM. General versus specific actions of mild-moderate hypothermia in attenuating cerebral ischemic damage. J Cereb Blood Flow Metab. Dec. 2007;27(12):1879-94. [pmid: 17684517].
88 Innovative radiation therapy may extend survival for inoperable liver cancer patients. Health Technol Trends. Jul. 2002:1-8.
89 Baltzer PA, Benndorf M, Dietzel M, et al. Sensitivity and specificity of unenhanced MR mammography (DWI combined with T2-weighted TSE imaging, ueMRM) for the differentiation of mass lesions. Eur Radiol. May. 2010;20(5):1101-10. [pmid: 19936758].
90 Baltzer PA, Benndorf M, Dietzel M, et al. False-positive findings at contrast-enhanced breast MRI: a BI-RADS descriptor study. AJR Am J Roentgenol. Jun. 2010;194(6):1658-63. [pmid: 20489110].
91 Baltzer PA, Kaiser CG, Dietzel M, et al. Value of ductal obstruction sign in the differentiation of benign and malignant breast lesions at MR imaging. Eur J Radiol. Aug. 2010;75(2):e18-e21. [pmid: 19954911].
92 Belli P, Costantini M, Bufi E, et al. Diffusion-weighted imaging in breast lesion evaluation. Radiol Med. Feb. 2010;115(1):51-69. [pmid: 19902330].
93 Benndorf M, Baltzer PA, Vag T, et al. Breast MRI as an adjunct to mammography: Does it really suffer from low specificity? A retrospective analysis stratified by mammographic BI-RADS classes. Acta Radiol. Sep. 2010;51(7):715-21. [pmid: 20707656].
94 Bhooshan N, Giger ML, Jansen SA, et al. Cancerous breast lesions on dynamic contrast-enhanced MR images: computerized characterization for image-based prognostic markers. Radiology. Mar. 2010;254(3):680-90. [pmid: 20123903].
95 Carbonaro LA, Verardi N, Di LG, et al. Handling a high relaxivity contrast material for dynamic breast MR imaging using higher thresholds for the initial enhancement. Invest Radiol. Mar. 2010;45(3):114-20. [pmid: 20065856].
96 Dietzel M, Baltzer PA, Vag T, et al. The adjacent vessel sign on breast MRI: new data and a subgroup analysis for 1,084 histologically verified cases. Korean J Radiol. Mar. 2010;11(2):178-86. [pmid: 20191065].
97 Dietzel M, Baltzer PA, Vag T, et al. The hook sign for differential diagnosis of malignant from benign lesions in magnetic resonance mammography: experience in a study of 1084 histologically verified cases. Acta Radiol. Mar. 2010;51(2):137-43. [pmid: 20092368].
98 Ei Khouli RH, Jacobs MA, Mezban SD, et al. Diffusion-weighted imaging improves the diagnostic accuracy of conventional 3.0-T breast MR imaging. Radiology. Jul. 2010;256(1):64-73. [pmid: 20574085].
99 Hauth E, Umutlu L, Ku MS, et al. Follow-up of probably benign lesions (BI-RADS 3 category) in breast MR imaging. Breast J. May. 2010;16(3):297-304. [pmid: 20565469].
100 Meeuwis C, van dV, Stapper G, et al. Computer-aided detection (CAD) for breast MRI: evaluation of efficacy at 3.0 T. Eur Radiol. Mar. 2010;20(3):522-8. [pmid: 19727750].
101 Peters NH, Vincken KL, van den Bosch MA, et al. Quantitative diffusion weighted imaging for differentiation of benign and malignant breast lesions: the influence of the choice of b-values. J Magn Reson Imaging. May. 2010;31(5):1100-5. [pmid: 20432344].
102 Weinstein SP, Hanna LG, Gatsonis C, et al. Frequency of malignancy seen in probably benign lesions at contrast-enhanced breast MR imaging: findings from ACRIN 6667. Radiology. Jun. 2010;255(3):731-7. [pmid: 20501712].
103 razi-Kleinman T, Causer PA, Jong RA, et al. Can breast MRI computer-aided detection (CAD) improve radiologist accuracy for lesions detected at MRI screening and recommended for biopsy in a high-risk population?. Clin Radiol. Dec. 2009;64(12):1166-74. [pmid: 19913125].
104 Baltzer PA, Renz DM, Herrmann KH, et al. Diffusion-weighted imaging (DWI) in MR mammography (MRM): Clinical comparison of echo planar imaging (EPI) and half-Fourier single-shot turbo spin echo (HASTE) diffusion techniques. Eur Radiol. 2009;19(7):1612-20. [pmid: 19288109].
105 Baltzer PA, Renz DM, Kullnig PE, et al. Application of computer-aided diagnosis (CAD) in MR-mammography (MRM): do we really need whole lesion time curve distribution analysis. Acad Radiol. Apr. 2009;16(4):435-42. [pmid: 19268855].
106 Calabrese M, Brizzi D, Carbonaro L, et al. Contrast-enhanced breast MR imaging of claustrophobic or oversized patients using an open low-field magnet. Radiol Med. Mar. 2009;114(2):267-85. [pmid: 19194774].
107 Ciatto S, Cascio D, Fauci F, et al. Computer-assisted diagnosis (CAD) in mammography: comparison of diagnostic accuracy of a new algorithm (Cyclopus, Medicad) with two commercial systems. Radiol Med. Jun. 2009;114(4):626-35. [pmid: 19444587].
108 El Khouli RH, Macura KJ, Barker PB, et al. Relationship of temporal resolution to diagnostic performance for dynamic contrast enhanced MRI of the breast. J Magn Reson Imaging. Nov. 2009;30(5):999-1004. [pmid: 19856413].
109 El Khouli RH, Macura KJ, Jacobs MA, et al. Dynamic contrast-enhanced MRI of the breast: quantitative method for kinetic curve type assessment. Am J Roentgenol. Oct. 2009;193(4):W295-300. [pmid: 19770298].
110 Gutierrez RL, Demartini WB, Eby PR, et al. BI-RADS lesion characteristics predict likelihood of malignancy in breast MRI for masses but not for nonmasslike enhancement. Am J Roentgenol. Oct. 2009;193(4):994-1000. [pmid: 19770321].
111 Kim SH, Cha ES, Kim HS, et al. Diffusion-weighted imaging of breast cancer: correlation of the apparent diffusion coefficient value with prognostic factors. J Magn Reson Imaging. Sep. 2009;30(3):615-20. [pmid: 19711411].
112 Kurz KD, Steinhaus D, Klar V, et al. Assessment of three different software systems in the evaluation of dynamic MRI of the breast. Eur J Radiol. Feb. 2009;69(2):300-7. [pmid: 18060715].
113 Palle L, Reddy B. Role of diffusion MRI in characterizing benign and malignant breast lesions. Indian J Radiol Imaging. Nov. 1. 2009;19(4):287-90. [pmid: 19881104].
114 Pediconi F, Catalano C, Roselli A, et al. The challenge of imaging dense breast parenchyma: is magnetic resonance mammography the technique of choice? A comparative study with x-ray mammography and whole-breast ultrasound. Invest Radiol. Jul. 2009;44(7):412-21. [pmid: 19448554].
115 Pereira FP, Martins G, Figueiredo E, et al. Assessment of breast lesions with diffusion-weighted MRI: comparing the use of different b values. Am J Roentgenol. Oct. 2009;193(4):1030-5. [pmid: 19770326].
116 Perfetto F, Fiorentino F, Urbano F, et al. Adjunctive diagnostic value of MRI in the breast radial scar. Radiol Med. Aug. 2009;114(5):757-70. [pmid: 19484584].
117 Pinker K, Grabner G, Bogner W, et al. A combined high temporal and high spatial resolution 3 Tesla MR imaging protocol for the assessment of breast lesions: initial results. Invest Radiol. Sep. 2009;44(9):553-8. [pmid: 19652611].
118 Potente G, Messineo D, Maggi C, et al. Practical application of contrast-enhanced magnetic resonance mammography [CE-MRM] by an algorithm combining morphological and enhancement patterns. Comput Med Imaging Graph. Mar. 2009;33(2):83-90. [pmid: 19095407].
119 Schouten van der Velden AP, Boetes C, Bult P, et al. Magnetic resonance imaging in size assessment of invasive breast carcinoma with an extensive intraductal component. BMC Med Imag. 2009;9:5. [pmid: 19351404].
120 Stadlbauer A, Bernt R, Gruber S, et al. Diffusion-weighted MR imaging with background body signal suppression (DWIBS) for the diagnosis of malignant and benign breast lesions. Eur Radiol. Oct. 2009;19(10):2349-56. [pmid: 19415286].
121 Woodhams R, Kakita S, Hata H, et al. Diffusion-weighted imaging of mucinous carcinoma of the breast: evaluation of apparent diffusion coefficient and signal intensity in correlation with histologic findings. AJR Am J Roentgenol. Jul. 2009;193(1):260-6. [pmid: 19542422].
122 Baek HM, Chen JH, Yu HJ, et al. Detection of choline signal in human breast lesions with chemical-shift imaging. J Magn Reson Imaging. May. 2008;27(5):1114-21. [pmid: 18425841].
123 Ballesio L, Maggi C, Savelli S, et al. Role of breast magnetic resonance imaging (MRI) in patients with unilateral nipple discharge: preliminary study. Radiol Med. Mar. 2008;113(2):249-64. [pmid: 18386126].
124 Choudhury S, Isomoto I, Hyashi K. Magnetic resonance imaging features of breasts in patients with nipple discharge. Bangladesh Med Res Counc Bull. Aug. 2008;34(2):44-7. [pmid: 19119538].
125 Ertas G, Gulcur HO, Tunaci M. An interactive dynamic analysis and decision support software for MR mammography. Comput Med Imaging Graph. Jun. 2008;32(4):284-93. [pmid: 18343634].
126 Hatakenaka M, Soeda H, Yabuuchi H, et al. Apparent diffusion coefficients of breast tumors: clinical application. Magn Reson Med Sci. 2008;7(1):23-9. [pmid: 18460845].
127 Heusner TA, Kuemmel S, Umutlu L, et al. Breast cancer staging in a single session: whole-body PET/CT mammography. J Nucl Med. Aug. 2008;49(8):1215-22. [pmid: 18632831].
128 Lieberman S, Sella T, Maly B, et al. Breast magnetic resonance imaging characteristics in women with occult primary breast carcinoma. Isr Med Assoc J. 2008;10(6):448-52. [pmid: 18669145].
129 Okafuji T, Yabuuchi H, Soeda H, et al. Circumscribed mass lesions on mammography: dynamic contrast-enhanced MR imaging to differentiate malignancy and benignancy. Magn Reson Med Sci. 2008;7(4):195-204. [pmid: 19110514].
130 Veltman J, Stoutjesdijk M, Mann R, et al. Contrast-enhanced magnetic resonance imaging of the breast: the value of pharmacokinetic parameters derived from fast dynamic imaging during initial enhancement in classifying lesions. Eur Radiol. Jun. 2008;18(6):1123-33. [pmid: 18270714].
131 Di Nallo AM, Crecco M, Ortenzia O, et al. The breast dynamic contrast enhanced MRI: preliminary results of a quantitative analysis. J Exp Clin Cancer Res. Jun. 2007;26(2):235-9. [pmid: 17725104].
132 Grunwald S, Heyer H, Paepke S, et al. Diagnostic value of ductoscopy in the diagnosis of nipple discharge and intraductal proliferations in comparison to standard methods. Onkologie. May. 2007;30(5):243-8. [pmid: 17460418].
133 Iglesias A, Arias M, Santiago P, et al. Benign breast lesions that simulate malignancy: magnetic resonance imaging with radiologic-pathologic correlation. Curr Probl Diagn Radiol. Mar. 2007;36(2):66-82. [pmid: 17331838].
134 Klifa CS, Shimakawa A, Siraj Z, et al. Characterization of breast lesions using the 3D FIESTA sequence and contrast-enhanced magnetic resonance imaging. J Magn Reson Imaging. Jan. 2007;25(1):82-8. [pmid: 17173311].
135 Meinel LA, Stolpen AH, Berbaum KS, et al. Breast MRI lesion classification: improved performance of human readers with a backpropagation neural network computer-aided diagnosis (CAD) system. J Magn Reson Imaging. Jan. 2007;25(1):89-95. [pmid: 17154399].
136 Williams TC, Demartini WB, Partridge SC, et al. Breast MR Imaging: computer-aided evaluation program for discriminating benign from malignant lesions. Radiology. Jul. 2007;244(1):94-103. [pmid: 17507720].
137 Bartella L, Morris EA, Dershaw DD, et al. Proton MR spectroscopy with choline peak as malignancy marker improves positive predictive value for breast cancer diagnosis: preliminary study. Radiology. Jun. 2006;239(3):686-92. [pmid: 16603660].
138 Goto M, Ito H, Akazawa K, et al. Diagnosis of breast tumors by contrast-enhanced MR imaging: comparison between the diagnostic performance of dynamic enhancement patterns and morphologic features. J Magn Reson Imaging. Jan. 2007;25(1):104-12. [pmid: 17152054].
139 Liberman L, Mason G, Morris EA, et al. Does size matter? Positive predictive value of MRI-detected breast lesions as a function of lesion size. AJR Am J Roentgenol. Feb. 2006;186(2):426-30. [pmid: 16423948].
140 Penn A, Thompson S, Brem R, et al. Morphologic blooming in breast MRI as a characterization of margin for discriminating benign from malignant lesions. Acad Radiol. Nov. 2006;13(11):1344-54. [pmid: 17070452].
141 Rubesova E, Grell AS, De Maertelaer V, et al. Quantitative diffusion imaging in breast cancer: a clinical prospective study. J Magn Reson Imaging. Aug. 2006;24(2):319-24. [pmid: 16786565].
142 Schnall MD, Blume J, Bluemke DA, et al. Diagnostic architectural and dynamic features at breast MR imaging: multicenter study. Radiology. Jan. 2006;238(1):42-53. [pmid: 16373758].
143 Deurloo EE, Muller SH, Peterse JL, et al. Clinically and mammographically occult breast lesions on MR images: potential effect of computerized assessment on clinical reading. Radiology. Mar. 2005;234(3):693-701. [pmid: 15650040].
144 Van GM, Schelfout K, Kersschot E, et al. Comparison of MRI features of different grades of DCIS and invasive carcinoma of the breast. JBR-BTR. Sep. 2005;88(5):225-32. [pmid: 16302331].
145 Howarth D, Slater S, Lau P, et al. Complementary role of adjunctive breast magnetic resonance imaging and scintimammography in patients of all ages undergoing breast cancer surgery. Australas Radiol. Aug. 2005;49(4):289-97. [pmid: 16026435].
146 Lehman CD, Peacock S, Demartini WB, et al. A new automated software system to evaluate breast MR examinations: improved specificity without decreased sensitivity. Am J Roentgenol. Jul. 1. 2006;187(1):51-6. [pmid: 16794155].
147 Meisamy S, Bolan PJ, Baker EH, et al. Adding in vivo quantitative 1H MR spectroscopy to improve diagnostic accuracy of breast MR imaging: preliminary results of observer performance study at 4.0 T. Radiology. Aug. 2005;236(2):465-75. [pmid: 16040903].
148 Morakkabati-Spitz N, Leutner C, Schild H, et al. Diagnostic usefulness of segmental and linear enhancement in dynamic breast MRI. Eur Radiol. Sep. 2005;15(9):2010-7. [pmid: 15841382].
149 Paakko E, Reinikainen H, Lindholm EL, et al. Low-field versus high-field MRI in diagnosing breast disorders. Eur Radiol. Jul. 2005;15(7):1361-8. [pmid: 15711841].
150 Sardanelli F, Iozzelli A, Fausto A, et al. Gadobenate dimeglumine-enhanced MR imaging breast vascular maps: association between invasive cancer and ipsilateral increased vascularity. Radiology. Jun. 2005;235(3):791-7. [pmid: 15845796].
151 Takeda Y, Yoshikawa K. Contrast-enhanced dynamic MR imaging parameters and histological types of invasive ductal carcinoma of breast. Biomed Pharmacother. Apr. 2005;59(3):115-21. [pmid: 15795104].
152 Wright H, Listinsky J, Rim A, et al. Magnetic resonance imaging as a diagnostic tool for breast cancer in premenopausal women. Am J Surg. Oct. 2005;190(4):572-5. [pmid: 16164923].
153 Boetes C, Veltman J, van DL, et al. The role of MRI in invasive lobular carcinoma. Breast Cancer Res Treat. Jul. 2004;86(1):31-7. [pmid: 15218359].
154 Brix G, Kiessling F, Lucht R, et al. Microcirculation and microvasculature in breast tumors: pharmacokinetic analysis of dynamic MR image series. Magn Reson Med. Aug. 2004;52(2):420-9. [pmid: 15282828].
155 Chen W, Giger ML, Lan L, et al. Computerized interpretation of breast MRI: investigation of enhancement-variance dynamics. Med Phys. May. 2004;31(5):1076-82. [pmid: 15191295].
156 Fischer DR, Baltzer P, Malich A, et al. Is the “blooming sign” a promising additional tool to determine malignancy in MR mammography. Eur Radiol. Mar. 2004;14(3):394-401. [pmid: 14517688].
157 Gibbs P, Liney GP, Lowry M, et al. Differentiation of benign and malignant 1 cm breast lesions using dynamic contrast enhanced MRI. Breast. Apr. 2004;13(2):115-21. [pmid: 15019691].
158 Gibbs P, Liney GP, Lowry M, et al. Differentiation of benign and malignant sub-1 cm breast lesions using dynamic contrast enhanced MRI. Breast. Apr. 2004;13(2):115-21. [pmid: 15019691].
159 Rotaru N, Luciani A. Magnetic resonance imaging of the breast: potential for lesion characterization. J BUON. Jan. 2004;9(1):77-82. [pmid: 17385833].
160 Schelfout K, Van GM, Kersschot E, et al. Contrast-enhanced MR imaging of breast lesions and effect on treatment. Eur J Surg Oncol. Jun. 2004;30(5):501-7. [pmid: 15135477].
161 Szabo BK, Aspelin P, Wiberg MK. Neural network approach to the segmentation and classification of dynamic magnetic resonance images of the breast: comparison with empiric and quantitative kinetic parameters. Acad Radiol. Dec. 2004;11(12):1344-54. [pmid: 15596372].
162 Van GM, Schelfout K, Dijckmans L, et al. MR mammography in the pre-operative staging of breast cancer in patients with dense breast tissue: comparison with mammography and ultrasound. Eur Radiol. May. 2004;14(5):809-16. [pmid: 14615904].
163 Bagni B, Franceschetto A, Casolo A, et al. Scintimammography with 99mTc-MIBI and magnetic resonance imaging in the evaluation of breast cancer. Eur J Nucl Med Mol Imaging. Oct. 2003;30(10):1383-8. [pmid: 12910383].
164 Gibbs P, Turnbull LW. Textural analysis of contrast-enhanced MR images of the breast. Magn Reson Med. Jul. 2003;50(1):92-8. [pmid: 12815683].
165 Knopp MV, Bourne MW, Sardanelli F, et al. Gadobenate dimeglumine-enhanced MRI of the breast: analysis of dose response and comparison with gadopentetate dimeglumine. AJR Am J Roentgenol. Sep. 2003;181(3):663-76. [pmid: 12933457].
166 LaTrenta LR, Menell JH, Morris EA, et al. Breast lesions detected with MR imaging: utility and histopathologic importance of identification with US. Radiology. Jun. 2003;227(3):856-61. [pmid: 12773685].
167 Nakahara H, Namba K, Watanabe R, et al. A comparison of MR imaging, galactography and ultrasonography in patients with nipple discharge. Breast Cancer. 2003;10(4):320-9. [pmid: 14634510].
168 Szabo BK, Aspelin P, Wiberg MK, et al. Dynamic MR imaging of the breast. Analysis of kinetic and morphologic diagnostic criteria. Acta Radiol. Jul. 2003;44(4):379-86. [pmid: 12846687].
169 Baum F, Fischer U, Vosshenrich R, et al. Classification of hypervascularized lesions in CE MR imaging of the breast. Eur Radiol. May. 2002;12(5):1087-92. [pmid: 11976850].
170 Carriero A, Di CA, Mansour M, et al. Maximum intensity projection analysis in magnetic resonance of the breast. J Exp Clin Cancer Res. Sep. 2002;21(3 Suppl):77-81. [pmid: 12585659].
171 Choi BG, Kim HH, Kim EN, et al. New subtraction algorithms for evaluation of lesions on dynamic contrast-enhanced MR mammography. Eur Radiol. Dec. 2002;12(12):3018-22. [pmid: 12439585].
172 Del MA, Bazzocchi M, Giuseppetti GM, et al. Breast MRI: report on a multicentric national trial by the Study Section of Magnetic Resonance and Breast Imaging. Radiol Med. Oct. 2002;104(4):262-72. [pmid: 12569307].
173 Hlawatsch A, Teifke A, Schmidt M, et al. Preoperative assessment of breast cancer: sonography versus MR imaging. AJR Am J Roentgenol. Dec. 2002;179(6):1493-501. [pmid: 12438043].
174 Liberman L, Morris EA, Lee MJ, et al. Breast lesions detected on MR imaging: features and positive predictive value. AJR Am J Roentgenol. Jul. 2002;179(1):171-8. [pmid: 12076929].
175 Nakahara H, Namba K, Wakamatsu H, et al. Extension of breast cancer: comparison of CT and MRI. Radiat Med. Jan. 2002;20(1):17-23. [pmid: 12002599].
176 Nunes LW, Englander SA, Charafeddine R, et al. Optimal post-contrast timing of breast MR image acquisition for architectural feature analysis. J Magn Reson Imaging. Jul. 2002;16(1):42-50. [pmid: 12112502].
177 Reinikainen H, Paakko E, Suramo I, et al. Dynamics of contrast enhancement in MR imaging and power Doppler ultrasonography of solid breast lesions. Acta Radiol. Sep. 2002;43(5):492-500. [pmid: 12423460].
178 Teifke A, Hlawatsch A, Beier T, et al. Undetected malignancies of the breast: dynamic contrast-enhanced MR imaging at 1.0 T. Radiology. Sep. 2002;224(3):881-8. [pmid: 12202728].
179 Alamo L, Fischer U. Contrast-enhanced color Doppler ultrasound characteristics in hypervascular breast tumors: comparison with MRI. Eur Radiol. 2001;11(6):970-7. [pmid: 11419173].
180 Francis A, England DW, Rowlands DC, et al. The diagnosis of invasive lobular breast carcinoma. Does MRI have a role. Breast. 2001;10(1):38-40. [pmid: 14965557].
181 Heywang-Kobrunner SH, Bick U, Bradley WG Jr, et al. International investigation of breast MRI: results of a multicentre study (11 sites) concerning diagnostic parameters for contrast-enhanced MRI based on 519 histopathologically correlated lesions. Eur Radiol. 2001;11(4):531-46. [pmid: 11354744].
182 Khatri VP, Stuppino JJ, Espinosa MH, et al. Improved accuracy in differentiating malignant from benign mammographic abnormalities: a simple, improved magnetic resonance imaging method. Cancer. Aug. 1. 2001;92(3):471-8. [pmid: 11505390].
183 Lucht RE, Knopp MV, Brix G. Classification of signal-time curves from dynamic MR mammography by neural networks. Magn Reson Imaging. Jan. 2001;19(1):51-7. [pmid: 11295347].
184 Malur S, Wurdinger S, Moritz A, et al. Comparison of written reports of mammography, sonography and magnetic resonance mammography for preoperative evaluation of breast lesions, with special emphasis on magnetic resonance mammography. Breast Cancer Res. 2001;3(1):55-60. [pmid: 11250746].
185 Ando Y, Fukatsu H, Ishiguchi T, et al. Diagnostic utility of tumor vascularity on magnetic resonance imaging of the breast. Magn Reson Imaging. Sep. 2000;18(7):807-13. [pmid: 11027873].
186 Kinkel K, Helbich TH, Esserman LJ, et al. Dynamic high-spatial-resolution MR imaging of suspicious breast lesions: diagnostic criteria and interobserver variability. AJR Am J Roentgenol. Jul. 2000;175(1):35-43. [pmid: 10882243].
187 Caprio MG, Cangiano A, Imbriaco M, et al. Dual-time-point [18F]-FDG PET/CT in the diagnostic evaluation of suspicious breast lesions. Radiol Med. Mar. 2010;115(2):215-24. [pmid: 20017002].
188 Zytoon AA, Murakami K, El-Kholy MR, et al. Dual time point FDG-PET/CT imaging... Potential tool for diagnosis of breast cancer. Clin Radiol. Nov. 2008;63(11):1213-27. [pmid: 18929039].
189 Berg WA, Weinberg IN, Narayanan D, et al. High-resolution fluorodeoxyglucose positron emission tomography with compression (“positron emission mammography”) is highly accurate in depicting primary breast cancer. Breast J. Jul. 2006;12(4):309-23. [pmid: 16848840].
190 Kumar R, Chauhan A, Zhuang H, et al. Clinicopathologic factors associated with false negative FDG-PET in primary breast cancer. Breast Cancer Res Treat. Aug. 2006;98(3):267-74. [pmid: 16555126].
191 Mavi A, Urhan M, Yu JQ, et al. Dual time point 18F-FDG PET imaging detects breast cancer with high sensitivity and correlates well with histologic subtypes. J Nucl Med. Sep. 2006;47(9):1440-6. [pmid: 16954551].
192 Tatsumi M, Cohade C, Mourtzikos KA, et al. Initial experience with FDG-PET/CT in the evaluation of breast cancer. Eur J Nucl Med Mol Imaging. Mar. 2006;33(3):254-62. [pmid: 16258765].
193 Kumar R, Loving VA, Chauhan A, et al. Potential of dual-time-point imaging to improve breast cancer diagnosis with 18F-FDG PET. J Nucl Med. Nov. 2005;46(11):1819-24. [pmid: 16269595].
194 Roman CD, Martin WH, Delbeke D. Incremental value of fusion imaging with integrated PET-CT in oncology. Clin Nucl Med. Jul. 2005;30(7):470-7. [pmid: 15965321].
195 Rosen EL, Turkington TG, Soo MS, et al. Detection of primary breast carcinoma with a dedicated, large-field-of-view FDG PET mammography device: initial experience. Radiology. Feb. 2005;234(2):527-34. [pmid: 15671006].
196 Inoue T, Yutani K, Taguchi T, et al. Preoperative evaluation of prognosis in breast cancer patients by [(18)F]2-Deoxy-2-fluoro-D-glucose-positron emission tomography. J Cancer Res Clin Oncol. May. 2004;130(5):273-8. [pmid: 14986112].
197 Marshall C, Mustafa S, Wheatley DC, et al. A comparison of 18F-FDG gamma camera PET, mammography and ultrasonography in demonstrating primary disease in locally advanced breast cancer. Nucl Med Commun. Jul. 2004;25(7):721-5. [pmid: 15208500].
198 Smyczek-Gargya B, Fersis N, Dittmann H, et al. PET with [18F]fluorothymidine for imaging of primary breast cancer: a pilot study. Eur J Nucl Med Mol Imaging. May. 2004;31(5):720-4. [pmid: 14991243].
199 Levine EA, Freimanis RI, Perrier ND, et al. Positron emission mammography: initial clinical results. Ann Surg Oncol. Jan. 2003;10(1):86-91. [pmid: 12513966].
200 Buck A, Schirrmeister H, Kuhn T, et al. FDG uptake in breast cancer: correlation with biological and clinical prognostic parameters. Eur J Nucl Med Mol Imaging. Oct. 2002;29(10):1317-23. [pmid: 12271413].
201 Danforth DN Jr, Aloj L, Carrasquillo JA, et al. The role of 18F-FDG-PET in the local/regional evaluation of women with breast cancer. Breast Cancer Res Treat. Sep. 2002;75(2):135-46. [pmid: 12243506].
202 Paul AK, Tatsumi M, Yutani K, et al. Effects of iterative reconstruction on image contrast and lesion detection in gamma camera coincidence imaging in lung and breast cancers. Nucl Med Commun. Jan. 2002;23(1):103-10. [pmid: 11748445].
203 Avril N, Rose CA, Schelling M, et al. Breast imaging with positron emission tomography and fluorine-18 fluorodeoxyglucose: use and limitations. J Clin Oncol. Oct. 15. 2000;18(20):3495-502. [pmid: 11032590].
204 Murthy K, Aznar M, Thompson CJ, et al. Results of preliminary clinical trials of the positron emission mammography system PEM-I: a dedicated breast imaging system producing glucose metabolic images using FDG. J Nucl Med. Nov. 2000;41(11):1851-8. [pmid: 11079494].
205 Brem RF, Shahan C, Rapleyea JA, et al. Detection of occult foci of breast cancer using breast-specific gamma imaging in women with one mammographic or clinically suspicious breast lesion. Acad Radiol. Jun. 2010;17(6):735-43. [pmid: 20457416].
206 Ozulker T, Ozulker F, Ozpacaci T, et al. The efficacy of (99m)Tc-MIBI scintimammography in the evaluation of breast lesions and axillary involvement: a comparison with X-rays mammography, ultrasonography and magnetic resonance imaging. Hell J Nucl Med. May. 2010;13(2):144-9. [pmid: 20808988].
207 Brem RF, Floerke AC, Rapelyea JA, et al. Breast-specific gamma imaging as an adjunct imaging modality for the diagnosis of breast cancer. Radiology. Jun. 2008;247(3):651-7. [pmid: 18487533].
208 Hruska CB, Phillips SW, Whaley DH, et al. Molecular breast imaging: use of a dual-head dedicated gamma camera to detect small breast tumors. AJR Am J Roentgenol. Dec. 2008;191(6):1805-15. [pmid: 19020253].
209 Sharma R, Tripathi M, Panwar P, et al. 99mTc-methionine scintimammography in the evaluation of breast cancer. Nucl Med Commun. May. 2009;30(5):338-42. [pmid: 19282793].
210 Spanu A, Chessa F, Meloni GB, et al. The role of planar scintimammography with high-resolution dedicated breast camera in the diagnosis of primary breast cancer. Clin Nucl Med. Nov. 2008;33(11):739-42. [pmid: 18936602].
211 Spanu A, Chessa F, Sanna D, et al. Scintimammography with a high resolution dedicated breast camera in comparison with SPECT/CT in primary breast cancer detection. Q J Nucl Med Mol Imaging. Jun. 2009;53(3):271-80. [pmid: 18596669].
212 Spanu A, Cottu P, Manca A, et al. Scintimammography with dedicated breast camera in unifocal and multifocal/multicentric primary breast cancer detection: a comparative study with SPECT. Int J Oncol. Aug. 2007;31(2):369-77. [pmid: 17611694].
213 Bekis R, Degirmenci B, Aydin A, et al. Correlation between 99mTc-MIBI uptake and angiogenesis in MIBI-positive breast lesions. Nucl Med Biol. Jul. 2005;32(5):465-72. [pmid: 15982577].
214 Brem RF, Rapelyea JA, Zisman G, et al. Occult breast cancer: scintimammography with high-resolution breast-specific gamma camera in women at high risk for breast cancer. Radiology. Oct. 2005;237(1):274-80. [pmid: 16126919].
215 Kim SJ, Kim IJ, Bae YT, et al. Comparison of early and delayed quantified indices of double-phase (99m)Tc MIBI scintimammography in the detection of primary breast cancer. Acta Radiol. Apr. 2005;46(2):148-54. [pmid: 15902889].
216 Myslivecek M, Koranda P, Kaminek M, et al. Technetium-99m-MIBI scintimammography by planar and SPECT imaging in the diagnosis of breast carcinoma and axillary lymph node involvement. World J Nucl Med. Jul. 1. 2005;4(3):159-64.
217 Papantoniou V, Tsiouris S, Mainta E, et al. Imaging in situ breast carcinoma (with or without an invasive component) with technetium-99m pentavalent dimercaptosuccinic acid and technetium-99m 2-methoxy isobutyl isonitrile scintimammography. Breast Cancer Res. 2005;7(1):R33-45. [pmid: 15642168].
218 Rhodes DJ, O’Connor MK, Phillips SW, et al. Molecular breast imaging: a new technique using technetium Tc 99m scintimammography to detect small tumors of the breast. Mayo Clin Proc. Jan. 2005;80(1):24-30. [pmid: 15667025].
219 Tiling R, Kessler M, Untch M, et al. Initial evaluation of breast cancer using Tc-99m sestamibi scintimammography. Eur J Radiol. 2005;53(2):206-12. [pmid: 15664284].
220 Kim SJ, Kim IJ, Bae YT, et al. Comparison of quantitative and visual analysis of Tc-99m MIBI scintimammography for detection of primary breast cancer. Eur J Radiol. Feb. 2005;53(2):192-8. [pmid: 15664282].
221 Caproni N, Marchisio F, Pecchi A, et al. Contrast-enhanced ultrasound in the characterisation of breast masses: utility of quantitative analysis in comparison with MRI. Eur Radiol. Jun. 2010;20(6):1384-95. [pmid: 20033178].
222 Dave JK, Forsberg F, Fernandes S, et al. Static and dynamic cumulative maximum intensity display mode for subharmonic breast imaging: a comparative study with mammographic and conventional ultrasound techniques. J Ultrasound Med. Aug. 2010;29(8):1177-85. [pmid: 20660451].
223 Cheng JZ, Chou YH, Huang CS, et al. Computer-aided US diagnosis of breast lesions by using cell-based contour grouping. Radiology. Jun. 2010;255(3):746-54. [pmid: 20501714].
224 Zhao H, Xu R, Ouyang Q, et al. Contrast-enhanced ultrasound is helpful in the differentiation of malignant and benign breast lesions. Eur J Radiol. Feb. 2010;73(2):288-93. [pmid: 19559551].
225 Moon HJ, Kim MJ, Kwak JY, et al. Probably benign breast lesions on ultrasonography: a retrospective review of ultrasonographic features and clinical factors affecting the BI-RADS categorization. Acta Radiol. May. 2010;51(4):375-82. [pmid: 20350247].
226 Moriguchi SM, de Luca LA, Griva BL, et al. Accuracy of 99mTc-sestamibi scintimammography for breast cancer diagnosis. Exp Ther Med. Jan. 2010;1(1):205-9.
227 Sorelli PG, Cosgrove DO, Svensson WE, et al. Can contrast-enhanced sonography distinguish benign from malignant breast masses. J Clin Ultrasound. May. 2010;38(4):177-81. [pmid: 20146214].
228 Wang Y, Jiang S, Wang H, et al. CAD algorithms for solid breast masses discrimination: evaluation of the accuracy and interobserver variability. Ultrasound Med Biol. Aug. 2010;36(8):1273-81. [pmid: 20691917].
229 Baek SE, Kim MJ, Kim EK, et al. Effect of clinical information on diagnostic performance in breast sonography. J Ultrasound Med. Oct. 2009;28(10):1349-56. [pmid: 19778881].
230 Balleyguier C, Opolon P, Mathieu MC, et al. New potential and applications of contrast-enhanced ultrasound of the breast: Own investigations and review of the literature. Eur J Radiol. Jan. 2009;69(1):14-23. [pmid: 18977102].
231 Barr RG, Maldonado RL, Georgian-Smith D. Comparison of conventional, compounding, computer enhancement, and compounding with computer enhancement in ultrasound imaging of the breast. Ultrasound Q. Sep. 2009;25(3):129-34. [pmid: 19730052].
232 volli-Disha E, Manxhuka-Kerliu S, Ymeri H, et al. Comparative accuracy of mammography and ultrasound in women with breast symptoms according to age and breast density. Bosn J Basic Med Sci. May. 2009;9(2):131-6. [pmid: 19485945].
233 Hee YK, Bo KS, Kim HY, et al. Additional breast ultrasound examinations in clustered calcifications: for improving diagnostic performance. J Breast Cancer. Sep. 2009;12(3):142-50.
234 Kotsianos-Hermle D, Hiltawsky KM, Wirth S, et al. Analysis of 107 breast lesions with automated 3D ultrasound and comparison with mammography and manual ultrasound. Eur J Radiol. Jul. 2009;71(1):109-15. [pmid: 18468829].
235 Masroor I, Ahmed MN, Pasha S. To evaluate the role of sonography as an adjunct to mammography in women with dense breasts. J Pak Med Assoc. May. 2009;59(5):298-301. [pmid: 19438134].
236 Masroor I, Afzal S, Sakhawat S, et al. Negative predictive value of mammography and sonography in mastalgia with negative physical findings. J Pak Med Assoc. Sep. 2009;59(9):598-601. [pmid: 19750852].
237 McCavert M, O’Donnell ME, Aroori S, et al. Ultrasound is a useful adjunct to mammography in the assessment of breast tumours in all patients. Int J Clin Pract. Nov. 2009;63(11):1589-94. [pmid: 19686337].
238 Su Y, An T, Wang D, et al. Evaluation of ultrasonic scores in differential diagnosis of breast solid lesions. J Diagn Med Sonogr. Nov. 2009;25(6):310-5.
239 Barnard S, Leen E, Cooke T, et al. A contrast-enhanced ultrasound study of benign and malignant breast tissue. S Afr Med J. May. 2008;98(5):386-91. [pmid: 18637311].
240 Bilali M, Lagoudianakis EE, Peitsidis P, et al. The role of sonography in the diagnosis of cystic lesions of the breast. Eur J Gynaecol Oncol. 2009;30(5):506-8. [pmid: 19899402].
241 Forsberg F, Kuruvilla B, Pascua MB, et al. Comparing contrast-enhanced color flow imaging and pathological measures of breast lesion vascularity. Ultrasound Med Biol. Sep. 2008;34(9):1365-72. [pmid: 18436369].
242 Kang SS, Ko EY, Han BK, et al. Breast US in patients who had microcalcifications with low concern of malignancy on screening mammography. Eur J Radiol. Aug. 2008;67(2):285-91. [pmid: 17703906].
243 Kwak JY, Kim EK, Kim MJ, et al. Power Doppler sonography: evaluation of solid breast lesions and correlation with lymph node metastasis. Clin Imaging. May. 2008;32(3):167-71. [pmid: 18502342].
244 LeCarpentier GL, Roubidoux MA, Fowlkes JB, et al. Suspicious breast lesions: assessment of 3D Doppler US indexes for classification in a test population and fourfold cross-validation scheme. Radiology. Nov. 2008;249(2):463-70. [pmid: 18936310].
245 Park YM, Kim EK, Lee JH, et al. Palpable breast masses with probably benign morphology at sonography: can biopsy be deferred. Acta Radiol. Dec. 2008;49(10):1104-11. [pmid: 18855166].
246 Singh K, Azad T, Gupta GD. The accuracy of ultrasound in diagnosis of palpable breast lumps. Jk Sci. 2008;10(4):186-8.
247 Wenkel E, Heckmann M, Heinrich M, et al. Automated breast ultrasound: lesion detection and BI-RADS classification--a pilot study. ROFO Fortschr Geb Rontgenstr Nuklearmed. Sep. 2008;180(9):804-8. [pmid: 18704878].
248 Abbattista T, Serri L, Busilacchi P. Three-dimensional sonographic study of breast nodules. J Ultrasound. Jun. 2007;10(2):93-8.
249 Ballesio L, Maggi C, Savelli S, et al. Adjunctive diagnostic value of ultrasonography evaluation in patients with suspected ductal breast disease. Radiol Med. Apr. 2007;112(3):354-65. [pmid: 17440697].
250 Mercadante S, Intravaia G, Villari P, et al. Intrathecal treatment in cancer patients unresponsive to multiple trials of systemic opioids. Clin J Pain. Nov. 2007;23(9):793-8. [pmid: 18075407].
251 Costantini M, Belli P, Ierardi C, et al. Solid breast mass characterisation: use of the sonographic BI-RADS classification. Radiol Med. Sep. 2007;112(6):877-94. [pmid: 17885742].
252 Graf O, Helbich TH, Hopf G, et al. Probably benign breast masses at US: is follow-up an acceptable alternative to biopsy. Radiology. Jul. 2007;244(1):87-93. [pmid: 17581897].
253 Jiang YX, Liu H, Liu JB, et al. Breast tumor size assessment: comparison of conventional ultrasound and contrast-enhanced ultrasound. Ultrasound Med Biol. Dec. 2007;33(12):1873-81. [pmid: 17686569].
254 Osako T, Iwase T, Takahashi K, et al. Diagnostic mammography and ultrasonography for palpable and nonpalpable breast cancer in women aged 30 to 39 years. Breast Cancer. 2007;14(3):255-9. [pmid: 17690501].
255 Prasad SN, Houserkova D. A comparison of mammography and ultrasonography in the evaluation of breast masses. Biomed Pap Med Fac Univ Palacky Olomouc Czech Repub. Dec. 2007;151(2):315-22. [pmid: 18345271].
256 Scaperrotta G, Ferranti C, Costa C, et al. Role of sonoelastography in non-palpable breast lesions. Eur Radiol. Nov. 2008;18(11):2381-9. [pmid: 18523780].
257 Thomas A, Warm M, Hoopmann M, et al. Tissue Doppler and strain imaging for evaluating tissue elasticity of breast lesions. Acad Radiol. May. 2007;14(5):522-9. [pmid: 17434065].
258 Costantini M, Belli P, Lombardi R, et al. Characterization of solid breast masses: use of the sonographic breast imaging reporting and data system lexicon. J Ultrasound Med. May. 2006;25(5):649-59. [pmid: 16632790].
259 Del FC, Bestagno A, Cerniato R, et al. Sonographic criteria for differentiation of benign and malignant solid breast lesions: size is of value. Radiol Med. Sep. 2006;111(6):783-96. [pmid: 16896562].
260 Grunwald S, Bojahr B, Schwesinger G, et al. Mammary ductoscopy for the evaluation of nipple discharge and comparison with standard diagnostic techniques. J Minim Invasive Gynecol. Sep. 2006;13(5):418-23. [pmid: 16962525].
261 Malik G, Waqar F, Buledi GQ. Sonomammography for evaluation of solid breast masses in young patients. J Ayub Med Coll Abbottabad. Apr. 2006;18(2):34-7. [pmid: 16977811].
262 Regner DM, Hesley GK, Hangiandreou NJ, et al. Breast lesions: evaluation with US strain imaging--clinical experience of multiple observers. Radiology. Feb. 2006;238(2):425-37. [pmid: 16436810].
263 Thomas A, Kummel S, Fritzsche F, et al. Real-time sonoelastography performed in addition to B-mode ultrasound and mammography: improved differentiation of breast lesions. Acad Radiol. Dec. 2006;13(12):1496-504. [pmid: 17138118].
264 Adepoju LJ, Chun J, El-Tamer M, et al. The value of clinical characteristics and breast-imaging studies in predicting a histopathologic diagnosis of cancer or high-risk lesion in patients with spontaneous nipple discharge. Am J Surg. Oct. 2005;190(4):644-6. [pmid: 16164940].
265 Baez E, Strathmann K, Vetter M, et al. Likelihood of malignancy in breast lesions characterised by ultrasound with a combined diagnostic score. Ultrasound Med Biol. Feb. 2005;31(2):179-84. [pmid: 15708456].
266 Berg WA. Sonographically depicted breast clustered microcysts: is follow-up appropriate. AJR Am J Roentgenol. Oct. 2005;185(4):952-9. [pmid: 16177414].
267 Cawson JN. Can sonography be used to help differentiate between radial scars and breast cancers. Breast. Oct. 2005;14(5):352-9. [pmid: 16216736].
268 Cha JH, Moon WK, Cho N, et al. Differentiation of benign from malignant solid breast masses: conventional US versus spatial compound imaging. Radiology. Dec. 2005;237(3):841-6. [pmid: 16304106].
269 Cho KR, Seo BK, Lee JY, et al. A comparative study of 2D and 3D ultrasonography for evaluation of solid breast masses. Eur J Radiol. Jun. 2005;54(3):365-70. [pmid: 15899337].
270 Eljuga L, Susac I. The value of diagnostic methods to detect pathologic changes in the breast. Libri Oncologici. 2005;33(1–3):7-14.
271 Nagashima T, Hashimoto H, Oshida K, et al. Ultrasound Demonstration of Mammographically Detected Microcalcifications in Patients with Ductal Carcinoma in situ of the Breast. Breast Cancer. 2005;12(3):216-20. [pmid: 16110292].
272 Shahid R, Ghaffar A, Bhatti AM. Role of grey scale ultrasound in benign and malignant breast lesions. J Coll Physicians Surg Pak. Apr. 2005;15(4):193-5. [pmid: 15857587].
273 Szabo BK, Saracco A, Wilczek B, et al. Adjunctive diagnostic value of targeted electrical impedance imaging to conventional methods in the evaluation of breast lesions. Acta Radiol. Dec. 2005;46(8):782-90. [pmid: 16392602].
274 Tohno E, Ueno E. Ultrasound (US) diagnosis of nonpalpable breast cancer. Breast Cancer. 2005;12(4):267-71. [pmid: 16286906].
275 Tumyan L, Hoyt AC, Bassett LW. Negative predictive value of sonography and mammography in patients with focal breast pain. Breast J. Sep. 2005;11(5):333-7. [pmid: 16174154].
276 Benson SR, Blue J, Judd K, et al. Ultrasound is now better than mammography for the detection of invasive breast cancer. Am J Surg. Oct. 2004;188(4):381-5. [pmid: 15474430].
277 Chen SC, Cheung YC, Su CH, et al. Analysis of sonographic features for the differentiation of benign and malignant breast tumors of different sizes. Ultrasound Obstet Gynecol. Feb. 2004;23(2):188-93. [pmid: 14770402].
278 Cid JA, Rampaul RS, Ellis IO, et al. Woman feels breast lump--surgeon cannot: the role of ultrasound in arbitration. Eur J Cancer. Sep. 2004;40(14):2053-5. [pmid: 15341978].
279 del Cura JL, Elizagaray E, Zabala R, et al. The use of unenhanced Doppler sonography in the evaluation of solid breast lesions. AJR Am J Roentgenol. Jun. 2005;184(6):1788-94. [pmid: 15908531].
280 Drukker K, Giger ML, Vyborny CJ, et al. Computerized detection and classification of cancer on breast ultrasound. Acad Radiol. May. 2004;11(5):526-35. [pmid: 15147617].
281 Foxcroft LM, Evans EB, Porter AJ. The diagnosis of breast cancer in women younger than 40. Breast. Aug. 2004;13(4):297-306. [pmid: 15325664].
282 Georgian-Smith D, Kricun B, McKee G, et al. The mammary hamartoma: appreciation of additional imaging characteristics. J Ultrasound Med. Oct. 2004;23(10):1267-73. [pmid: 15448315].
283 Murad M, Bari V. Ultrasound differentiation of benign versus malignant solid breast masses. J Coll Physicians Surg Pak. Mar. 2004;14(3):166-9. [pmid: 15228851].
284 Santamaria G, Velasco M, Farre X, et al. Power Doppler sonography of invasive breast carcinoma: does tumor vascularization contribute to prediction of axillary status. Radiology. Feb. 2005;234(2):374-80. [pmid: 15601892].
285 Sehgal CM, Cary TW, Kangas SA, et al. Computer-based margin analysis of breast sonography for differentiating malignant and benign masses. J Ultrasound Med. Sep. 2004;23(9):1201-9. [pmid: 15328435].
286 Selinko VL, Middleton LP, Dempsey PJ. Role of sonography in diagnosing and staging invasive lobular carcinoma. J Clin Ultrasound. Sep. 2004;32(7):323-32. [pmid: 15293298].
287 Strano S, Gombos EC, Friedland O, et al. Color Doppler imaging of fibroadenomas of the breast with histopathologic correlation. J Clin Ultrasound. Sep. 2004;32(7):317-22. [pmid: 15293297].
288 Yang WT, Tse GM. Sonographic, mammographic, and histopathologic correlation of symptomatic ductal carcinoma in situ. AJR Am J Roentgenol. Jan. 2004;182(1):101-10. [pmid: 14684521].
289 Zonderland HM, Pope TL Jr, Nieborg AJ. The positive predictive value of the breast imaging reporting and data system (BI-RADS) as a method of quality assessment in breast imaging in a hospital population. Eur Radiol. 2004;14(10):1743-50. [pmid: 15243715].
290 Chen WM, Chang RF, Moon WK, et al. Breast cancer diagnosis using three-dimensional ultrasound and pixel relation analysis. Ultrasound Med Biol. Jul. 2003;29(7):1027-35. [pmid: 12878249].
291 Chen SC, Cheung YC, Lo YF, et al. Sonographic differentiation of invasive and intraductal carcinomas of the breast. Br J Radiol. Sep. 2003;76(909):600-4. [pmid: 14500273].
292 Drukker K, Giger ML, Mendelson EB. Computerized analysis of shadowing on breast ultrasound for improved lesion detection. Med Phys. Jul. 2003;30(7):1833-42. [pmid: 12906202].
293 Flobbe K, Bosch AM, Kessels AG, et al. The additional diagnostic value of ultrasonography in the diagnosis of breast cancer. Arch Intern Med. May. 26. 2003;163(10):1194-9. [pmid: 12767956].
294 Szopinski KT, Pajk AM, Wysocki M, et al. Tissue harmonic imaging: utility in breast sonography. J Ultrasound Med. May. 2003;22(5):479-87. [pmid: 12751859].
295 Martinez AM, Medina CJ, Bustos C, et al. Assessment of breast lesions using Doppler with contrast agents. Eur J Gynaecol Oncol. 2003;24(6):527-30. [pmid: 14658595].
296 Mesaki K, Hisa N, Kubota K, et al. Differentiation of benign and malignant breast tumors using Doppler spectral parameters including acceleration time index. Oncol Rep (Athens). Jul. 2003;10(4):945-50. [pmid: 12792750].
297 Park JM, Yoon GS, Kim SM, et al. Sonographic detection of multifocality in breast carcinoma. J Clin Ultrasound. Jul. 2003;31(6):293-8. [pmid: 12811787].
298 Puglisi F, Zuiani C, Bazzocchi M, et al. Role of mammography, ultrasound and large core biopsy in the diagnostic evaluation of papillary breast lesions. Oncology. 2003;65(4):311-5. [pmid: 14707450].
299 Shetty MK, Shah YP, Sharman RS. Prospective evaluation of the value of combined mammographic and sonographic assessment in patients with palpable abnormalities of the breast. J Ultrasound Med. Mar. 2003;22(3):263-8. [pmid: 12636326].
300 Chen DR, Chang RF, Lee JH, et al. Three-dimensional breast ultrasound imaging in patients with nipple discharge: a pictorial review of 27 patients. J Med Ultrasound. 2002;10(2):69-75.
301 Chen DR, Kuo WJ, Chang RF, et al. Use of the bootstrap technique with small training sets for computer-aided diagnosis in breast ultrasound. Ultrasound Med Biol. Jul. 2002;28(7):897-902. [pmid: 12208332].
302 Germer U, Tetzlaff A, Geipel A, et al. Strong impact of estrogen environment on Doppler variables used for differentiation between benign and malignant breast lesions. Ultrasound Obstet Gynecol. Apr. 2002;19(4):380-5. [pmid: 11952968].
303 Gunhan-Bilgen I, Ustun EE, Memis A. Inflammatory breast carcinoma: mammographic, ultrasonographic, clinical, and pathologic findings in 142 cases. Radiology. Jun. 2002;223(3):829-38. [pmid: 12034956].
304 Krestan CR, Riedl C, Memarsadeghi M, et al. 3D-power Doppler ultrasound of breast lesions with a microbubble contrast agent. Acad Radiol. Aug. 2002;9(Suppl 2):S384-385. [pmid: 12188284].
305 Kuo WJ, Chang RF, Lee CC, et al. Retrieval technique for the diagnosis of solid breast tumors on sonogram. Ultrasound Med Biol. Jul. 2002;28(7):903-9. [pmid: 12208333].
306 Kuo WJ, Chang RF, Moon WK, et al. Computer-aided diagnosis of breast tumors with different US systems. Acad Radiol. Jul. 2002;9(7):793-9. [pmid: 12139093].
307 Lee SW, Choi HY, Baek SY, et al. Role of color and power doppler imaging in differentiating between malignant and benign solid breast masses. J Clin Ultrasound. Oct. 2002;30(8):459-64. [pmid: 12242733].
308 Muttarak M, Pojchamarnwiputh S, Chaiwun B. Mammographic and ultrasonographic features of benign and malignant phyllodes tumours. Asian Oceanian J Radiol. 2002;7(1):9-15.
309 Tan SM, Behranwala KA, Trott PA, et al. A retrospective study comparing the individual modalities of triple assessment in the pre-operative diagnosis of invasive lobular breast carcinoma. Eur J Surg Oncol. 2002;28(3):203-8. [pmid: 11944950].
310 Taylor KJ, Merritt C, Piccoli C, et al. Ultrasound as a complement to mammography and breast examination to characterize breast masses. Ultrasound Med Biol. Jan. 2002;28(1):19-26. [pmid: 11879948].
311 Wang HC, Chen DR, Kao CH, et al. Detecting breast cancer in mammographically dense breasts: comparing technetium-99m tetrofosmin mammoscintigraphy and ultrasonography. Cancer Invest. 2002;20(7–8):932-8. [pmid: 12449724].
312 Wang HC, Sun SS, Kao A, et al. Comparison of technetium-99m methoxyisobutylisonitrile scintimammography and ultrasonography in the diagnosis of breast cancer in patients with mammographically dense breast. Cancer Invest. 2002;20(3):318-23. [pmid: 12025226].
313 Yilmaz E, Lebe B, Balci P, et al. Comparison of mammographic and sonographic findings in typical and atypical medullary carcinomas of the breast. Clin Radiol. Jul. 2002;57(7):640-5. [pmid: 12096865].
314 Allen SA, Cunliffe WJ, Gray J, et al. Pre-operative estimation of primary breast cancer size: a comparison of clinical assessment, mammography and ultrasound. Breast. Aug. 2001;10(4):299-305. [pmid: 14965598].
315 Arger PH, Sehgal CM, Conant EF, et al. Interreader variability and predictive value of US descriptions of solid breast masses: pilot study. Acad Radiol. Apr. 2001;8(4):335-42. [pmid: 11293782].
316 Bhatti PT, LeCarpentier GL, Roubidoux MA, et al. Discrimination of sonographically detected breast masses using frequency shift color Doppler imaging in combination with age and gray scale criteria. J Ultrasound Med. Apr. 2001;20(4):343-50. [pmid: 11316312].
317 Chou YH, Tiu CM, Hung GS, et al. Stepwise logistic regression analysis of tumor contour features for breast ultrasound diagnosis. Ultrasound Med Biol. Nov. 2001;27(11):1493-8. [pmid: 11750748].
318 Cwikla JB, Buscombe JR, Holloway B, et al. Can scintimammography with (99m)Tc-MIBI identify multifocal and multicentric primary breast cancer. Nucl Med Commun. Dec. 2001;22(12):1287-93. [pmid: 11711898].
319 Ozdemir A, Ozdemir H, Maral I, et al. Differential diagnosis of solid breast lesions: contribution of Doppler studies to mammography and gray scale imaging. J Ultrasound Med. Oct. 2001;20(10):1091-101. [pmid: 11587016].
320 Rosen EL, Soo MS. Tissue harmonic imaging sonography of breast lesions: improved margin analysis, conspicuity, and image quality compared to conventional ultrasound. Clin Imaging. Nov. 2001;25(6):379-84. [pmid: 11733148].
321 Soo MS, Rosen EL, Baker JA, et al. Negative predictive value of sonography with mammography in patients with palpable breast lesions. AJR Am J Roentgenol. Nov. 2001;177(5):1167-70. [pmid: 11641195].
322 Whitehouse PA, Baber Y, Brown G, et al. The use of ultrasound by breast surgeons in outpatients: an accurate extension of clinical diagnosis. Eur J Surg Oncol. Nov. 2001;27(7):611-6. [pmid: 11669586].
323 Chaudhari MH, Forsberg F, Voodarla A, et al. Breast tumor vascularity identified by contrast enhanced ultrasound and pathology: initial results. Ultrasonics. Mar. 2000;38(1–8):105-9. [pmid: 10829638].
324 Choi HY, Kim HY, Baek SY, et al. Significance of resistive index in color Doppler ultrasonogram: differentiation between benign and malignant breast masses. Clin Imaging. Sep. 1999;23(5):284-8. [pmid: 10665344].
325 Evans N, Lyons K. The use of ultrasound in the diagnosis of invasive lobular carcinoma of the breast less than 10 mm in size. Clin Radiol. Apr. 2000;55(4):261-3. [pmid: 10767184].
326 Klaus AJ, Klingensmith WC III, Parker SH, et al. Comparative value of 99mTc-sestamibi scintimammography and sonography in the diagnostic workup of breast masses. AJR Am J Roentgenol. Jun. 2000;174(6):1779-83. [pmid: 10845522].
327 Madjar H, Prompeler HJ, Del FC, et al. A new Doppler signal enhancing agent for flow assessment in breast lesions. Eur J Ultrasound. Dec. 2000;12(2):123-30. [pmid: 11118919].
328 Stuhrmann M, Aronius R, Schietzel M. Tumor vascularity of breast lesions: potentials and limits of contrast-enhanced Doppler sonography. AJR Am J Roentgenol. Dec. 2000;175(6):1585-9. [pmid: 11090380].
329 Thibault F, Meunier M, Klijanienko J, et al. Diagnostic accuracy of sonography and combined sonographic assessment and sonographically guided cytology in nonpalpable solid breast lesions. J Clin Ultrasound. Oct. 2000;28(8):387-98. [pmid: 10993966].
330 Baker JA, Kornguth PJ, Soo MS, et al. Sonography of solid breast lesions: observer variability of lesion description and assessment. AJR Am J Roentgenol. Jun. 1999;172(6):1621-5. [pmid: 10350302].
331 Blohmer JU, Oellinger H, Grineisen Y, et al. Changes in spectral Doppler measurement of V(max) after administration of an ultrasound contrast agent - A possible new variable for the differential diagnosis of breast lesions. Tumordiagn Ther. Dec. 1999;20(6):164-70.
332 Chao TC, Lo YF, Chen SC, et al. Color Doppler ultrasound in benign and malignant breast tumors. Breast Cancer Res Treat. Sep. 1999;57(2):193-9. [pmid: 10598046].
333 Eltahir A, Jibril JA, Squair J, et al. The accuracy of ‘one-stop’ diagnosis for 1,110 patients presenting to a symptomatic breast clinic. J R Coll Surg Edinb. Aug. 1999;44(4):226-30. [pmid: 10453144].
334 Huang CS, Wu CY, Chu JS, et al. Microcalcifications of non-palpable breast lesions detected by ultrasonography: correlation with mammography and histopathology. Ultrasound Obstet Gynecol. Jun. 1999;13(6):431-6. [pmid: 10423808].
335 Kook SH, Park HW, Lee YR, et al. Evaluation of solid breast lesions with power Doppler sonography. J Clin Ultrasound. Jun. 1999;27(5):231-7. [pmid: 10355886].
336 Moss HA, Britton PD, Flower CDR, et al. How reliable is modern breast imaging in differentiating benign from malignant breast lesions in the symptomatic population. Clin Radiol. 1999;54(10):676-82. [pmid: 10541394].
337 Obwegeser R, Berghammer P, Kubista E. Accuracy of 99mTc-sestamibi scintimammography for breast cancer diagnosis. Lancet. Jun. 5. 1999;353(9168). 1938. [pmid: 10371578].
338 Rahbar G, Sie AC, Hansen GC, et al. Benign versus malignant solid breast masses: US differentiation. Radiology. Dec. 1999;213(3):889-94. [pmid: 10580971].
339 Rotten D, Levaillant JM, Zerat L. Analysis of normal breast tissue and of solid breast masses using three-dimensional ultrasound mammography. Ultrasound Obstet Gynecol. Aug. 1999;14(2):114-24. [pmid: 10492871].
340 Skaane P. The additional value of US to mammography in the diagnosis of breast cancer. A prospective study. Acta Radiol. Sep. 1999;40(5):486-90. [pmid: 10485236].
341 Zonderland HM, Coerkamp EG, Hermans J, et al. Diagnosis of breast cancer: contribution of US as an adjunct to mammography. Radiology. Nov. 1999;213(2):413-22. [pmid: 10551221].
342 Brnic Z, Drinkovic I, Hebrang A. High-resolution ultrasound and power-Doppler - advances in pre-invasive diagnosis of solid breast lesions: our one-year experience. Radiol Oncol. 1998;32(4):353-61.
343 Carson PL, Fowlkes JB, Roubidoux MA, et al. 3-D color Doppler image quantification of breast masses. Ultrasound Med Biol. Sep. 1998;24(7):945-52. [pmid: 9809628].
344 Delorme S, Zuna I, Huber S, et al. Colour Doppler sonography in breast tumours: an update. Eur Radiol. 1998;8(2):189-93. [pmid: 9477264].
345 Giuseppetti GM, Baldassarre S, Marconi E. Color Doppler sonography. Eur J Radiol. May. 1998;27(Suppl 2):S254-258. [pmid: 9652531].
346 Hayashi N, Miyamoto Y, Nakata N, et al. Breast masses: color Doppler, power Doppler, and spectral analysis findings. J Clin Ultrasound. Jun. 1998;26(5):231-8. [pmid: 9608365].
347 Huber S, Helbich T, Kettenbach J, et al. Effects of a microbubble contrast agent on breast tumors: computer-assisted quantitative assessment with color Doppler US--early experience. Radiology. Aug. 1998;208(2):485-9. [pmid: 9680580].
348 Wright IA, Pugh ND, Lyons K, et al. Power Doppler in breast tumours: a comparison with conventional colour Doppler imaging. Eur J Ultrasound. Aug. 1998;7(3):175-81. [pmid: 9700212].
349 Cabasares HV. Office-based breast ultrasonography in a small community surgical practice. Am Surg. Aug. 1997;63(8):716-9. [pmid: 9247440].
350 Jain M, Bhargava SK, Narang P. Color doppler ultrasonography study of palpable breast lumps - a pilot study. Indian J Radiol Imaging. 1997;7(2):79-82.
351 Madjar H, Sauerbrei W, Prompeler HJ, et al. Color Doppler and duplex flow analysis for classification of breast lesions. Gynecol Oncol. Mar. 1997;64(3):392-403. [pmid: 9062140].
352 Muller-Schimpfle M, Stoll P, Stern W, et al. Do mammography, sonography, and MR mammography have a diagnostic benefit compared with mammography and sonography. AJR Am J Roentgenol. May. 1997;168(5):1323-9. [pmid: 9129436].
353 Raza S, Baum JK. Solid breast lesions: evaluation with power Doppler US. Radiology. Apr. 1997;203(1):164-8. [pmid: 9122386].
354 Schelling M, Gnirs J, Braun M, et al. Optimized differential diagnosis of breast lesions by combined B-mode and color Doppler sonography. Ultrasound Obstet Gynecol. Jul. 1997;10(1):48-53. [pmid: 9263423].
355 Skaane P, Engedal K, Skjennald A. Interobserver variation in the interpretation of breast imaging. Comparison of mammography, ultrasonography, and both combined in the interpretation of palpable noncalcified breast masses. Acta Radiol. Jul. 1997;38(4 Pt 1):497-502. [pmid: 9240666].
356 Yang WT, Suen M, Ahuja A, et al. In vivo demonstration of microcalcification in breast cancer using high resolution ultrasound. Br J Radiol. Jul. 1997;70(835):685-90. [pmid: 9245879].
357 Edde DJ. Whole-breast compression ultrasonography with the patient in the sitting position. Can Assoc Radiol J. Aug. 1994;45(4):324-6. [pmid: 8062127].
358 Saitoh R, Kojima R, Ito K, et al. Real-time high resolution ultrasonography of solid breast masses: use of a 10-MHz mechanical sector transducer with a water bag. Radiat Med. Sep. 1994;12(5):201-8. [pmid: 7863023].