# List of Excluded Studies

## MRI Exclusions

103 total excluded

### Reasons for Exclusion

Did not enroll the patient population of interest: 54 studies

Did not use an acceptable reference standard to verify diagnoses of at least 85% of patients: 12 studies

Study of experimental methods not clinically relevant: 14 studies

Did not address any of the Key Questions: 9 studies

Did not report sufficient data to calculate the outcomes of interest: 6 studies

Duplicate reports of the same studies/patients: 4 studies

Retrospective study that did not enroll all or consecutive patients: 3 studies

Reported data from fewer than 50% of the enrolled patients: 1 study

Table D1 Studies of MRI that did not meet the inclusion criteria

Study | Reason for Exclusion
Baltzer et al. 2010^89^ | Exploratory study of experimental diagnostic methods
Baltzer et al. 2010^90^ | Did not enroll the patient population of interest
Baltzer et al. 2010^91^ | Exploratory study of experimental diagnostic methods
Belli et al. 2010^92^ | Did not use an acceptable reference standard
Benndorf et al. 2010^93^ | Did not enroll the patient population of interest
Bhooshan et al. 2010^94^ | Exploratory study of experimental diagnostic methods
Carbonaro et al. 2010^95^ | Did not enroll the patient population of interest
Dietzel et al. 2010^96^ | Exploratory study of experimental diagnostic methods
Dietzel et al. 2010^97^ | Exploratory study of experimental diagnostic methods
El Khouli et al. 2010^98^ | Exploratory study of experimental diagnostic methods
Hauth et al. 2010^99^ | Did not address any of the Key Questions
Meeuwis et al. 2010^100^ | Did not enroll the patient population of interest
Peters et al. 2010^101^ | Exploratory study of experimental diagnostic methods
Weinstein et al. 2010^102^ | Did not enroll the patient population of interest
Arazi-Kleinman et al. 2009^103^ | Enrolled only patients at very high risk of breast cancer
Baltzer et al. 2009^104^ | Enrolled only patients at very high risk of breast cancer
Baltzer et al. 2009^105^ | Did not enroll the patient population of interest
Baltzer et al. 2009^105^ | Enrolled only patients at very high risk of breast cancer
Bluemke et al. 2009^20^ | Duplicate patient population as in Bluemke et al.20
Calabrese et al. 2009^106^ | Enrolled only patients at very high risk of breast cancer
Ciatto et al. 2009^107^ | Exploratory study of experimental diagnostic methods
El Khouli et al. 2009^108^ | Does not address any of the Key Questions
El Khouli et al. 2009^109^ | Retrospective study that did not enroll all or consecutive patients
Gutierrez et al. 2009^110^ | Does not address any of the Key Questions
Kim et al. 2009^111^ | Enrolled only patients diagnosed with invasive breast cancer
Kurz et al. 2009^112^ | Does not address any of the Key Questions
Palle and Reddy et al. 2009^113^ | Did not report how or if the MRI diagnoses were verified
Pediconi et al. 2009^114^ | Fewer than 85% of the lesions had their diagnoses verified with an acceptable reference standard
Pereira et al. 2009^115^ | Exploratory study of experimental diagnostic methods
Perfetto et al. 2009^116^ | Retrospective study that did not enroll all or consecutive patients
Pinker et al. 2009^117^ | Did not report data for patients with diagnosis verified by followup instead of histopathology (45% of enrolled patients)
Potente et al. 2009^118^ | Enrolled only patients at very high risk of breast cancer
Schuten et al. 2009^119^ | Only enrolled patients diagnosed with breast cancer
Stadlbauer et al. 2009^120^ | Only 60% of diagnoses were verified with an acceptable reference standard
Woodhams et al. 2009^121^ | Does not address any of the Key Questions
Baek et al. 2008^122^ | Enrolled only patients at very high risk of breast cancer
Ballesio et al. 2008^123^ | Did not enroll the patient population of interest
Choudhury et al. 2008^124^ | Did not enroll the patient population of interest
Ertas et al. 2008^125^ | Did not report sufficient data to calculate the outcomes of interest
Hatakenaka et al. 2008^126^ | Did not enroll the patient population of interest
Heusner et al. 2008^127^ | Enrolled only patients diagnosed with breast cancer
Lieberman et al. 2008^128^ | Enrolled only patients diagnosed with breast cancer
Okafuji et al. 2008^129^ | Enrolled only patients at very high risk of breast cancer
Veltman et al. 2008^130^ | Does not address any of the Key Questions
Di Nallo et al. 2007^131^ | Did not report sufficient data to calculate the outcomes of interest
Grunwald 2007^132^ | Reported MRI results for fewer than 50% of the enrolled patients
Iglesias et al. 2007^133^ | Enrolled only patients with benign lesions
Klifa et al. 2007^134^ | Retrospective study that did not enroll all or consecutive patients
Meinel et al. 2007^135^ | The results of the MRI examination were used to decide which patients to enroll
Williams et al. 2007^136^ | Enrolled only patients at very high risk of breast cancer
Bartella et al. 2006^137^ | Enrolled only patients at very high risk of breast cancer
Goto et al. 2006^138^ | The results of the MRI examination were used to decide which patients to enroll
Liberman et al. 2006^139^ | The results of the MRI examination were used to decide which patients to enroll
Penn et al. 2006^140^ | Did not report sufficient data to calculate the outcomes of interest
Rubesova et al. 2006^141^ | The results of the MRI examination were used to decide which patients to enroll
Schnall et al. 2006^142^ | Did not report sufficient data to calculate the outcomes of interest
Deurloo et al. 2005^143^ | The results of the MRI examination were used to decide which patients to enroll
Goethem et al. 2005^144^ | Enrolled only patients with breast cancer
Howarth et al. | Enrolled only patients at very high risk of breast cancer
2005^145^
Lehman et al. 2005^146^ | The results of the MRI examination were used to decide which patients to enroll
Meisamy et al. 2005^147^ | Did not enroll the patient population of interest
Morakkabati-Spitz 2005^148^ | Did not report sufficient data to calculate the outcomes of interest
Paakko et al. 2005^149^ | Fewer than 85% of the lesions had their diagnoses verified with an acceptable reference standard
Sardanelli et al. 2005^150^ | Enrolled only patients at very high risk of breast cancer
Takeda et al. 2005^151^ | Enrolled only patients with breast cancer
Wright et al. 2005^152^ | Enrolled only patients with breast cancer
Boetes et al. 2004^153^ | Enrolled only women diagnosed with invasive lobular carcinoma
Brix et al. 2004^154^ | Does not address any of the Key Questions
Chen et al. 2004^155^ | Does not address any of the Key Questions
Fischer et al. 2004^156^ | Verified diagnoses of only 76% of the enrolled patients using an acceptable reference standard
Gibbs et al. 2004^157^ | Did not enroll the patient population of interest
Gibbs et al. 2004^158^ | The results of the MRI examination were used to decide which patients to enroll
Rotaru et al. 2004^159^ | Did not enroll the patient population of interest
Schelfout et al. 2004^160^ | Did not enroll the patient population of interest
Szabo et al. 2004^161^ | The results of the MRI examination were used to decide which patients to enroll
Van Goethem et al. 2004^162^ | Did not enroll the patient population of interest
Bagni et al. 2003^163^ | Fewer than 85% of the lesions had their diagnoses verified with an acceptable reference standard
Gibbs and Turnbull 2003^164^ | Did not report sufficient data to calculate the outcomes of interest
Knopp et al. 2003^165^ | Fewer than 85% of the lesions had their diagnoses verified with an acceptable reference standard
LaTrenta et al. 2003^166^ | Enrolled only patients at very high risk of breast cancer
Nakahara et al. 2003^167^ | Did not enroll the patient population of interest
Szabo et al. 2003^168^ | Exploratory study of experimental diagnostic methods
Baum et al. 2002^169^ | Enrolled only patients at very high risk of breast cancer
Carriero et al. 2002^170^ | Exploratory study of experimental diagnostic methods
Choi et al. 2002^171^ | Exploratory study of experimental diagnostic methods
Del Maschio et al. 2002^172^ | Discussion of the study Bazzocchi et al.13
Hlawatsch et al. 2002^173^ | Did not enroll the patient population of interest
Liberman et al. 2002^174^ | Enrolled only patients at very high risk of breast cancer
Nakahara et al. 2002^175^ | Enrolled only patients diagnosed with breast cancer
Nunes et al. 2002^176^ | Fewer than 85% of the lesions had their diagnoses verified with an acceptable reference standard
Reinikainen et al. 2002^177^ | Did not enroll the patient population of interest
Teifke et al. 2002^178^ | Only 48% of diagnoses were verified with an acceptable reference standard
Trecate et al. 2002^29^ | Duplicate report of the same patients enrolled in Trecate et al.29
Alamo et al. 2001^179^ | Did not enroll the patient population of interest
Francis et al. 2001^180^ | Enrolled only patients diagnosed with invasive lobular carcinoma
Hewwang-Kobrunner et al. 2001^181^ | Exploratory study of experimental diagnostic methods
Khatri et al. 2001^182^ | Excluded patients without evidence of a lesion at MRI
Lucht et al. 2001^183^ | Exploratory study of experimental diagnostic methods
Malur et al. 2001^184^ | Did not enroll the patient population of interest
Ando et al. 2000^185^ | Only reported data for patients with MRI images suggestive of malignancy
Imbriaco et al. 2000^34^ | Duplicate report of the same patients enrolled in Imbracio et al.34
Kinkel et al. 2000^186^ | Retrospective study that did not enroll all or consecutive patients

MRI Magnetic resonance imaging

## PET Exclusions

19 total excluded

### Reasons for Exclusion

Did not enroll the patient population of interest: 13 studies

Study of experimental methods not clinically relevant: 3 studies

Did not report sufficient information to calculate the outcomes of interest: 1 study

Duplicate report of the same studies/patients: 2 studies

Table D2 Studies of PET that did not meet the inclusion criteria

Study | Reason
Caprio et al. 2010^187^ | Duplicate report of data found in Imbracio et al.34
Heusner et al. 2008^127^ | Did not study the population of interest. Enrolled only patients with confirmed breast cancer.
Zytoon et al. 2008^188^ | Did not study the population of interest. Enrolled only patients with confirmed breast cancer.
Berg et al. 2006^189^ | Did not study the population of interest. Forty-three percent (43%) of patients had a confirmed diagnosis of breast cancer and had undergone prior diagnostic biopsies.
Kumar et al. 2006^190^ | Did not study the population of interest. Most of the enrolled patients had a confirmed diagnosis of breast cancer and had undergone prior diagnostic/excision biopsies.
Mavi et al. 2006^191^ | Did not study the population of interest. Enrolled only patients with confirmed breast cancer.
Tatsumi et al. 2006^192^ | Did not study the population of interest. Enrolled only patients with confirmed breast cancer.
Kumar et al. 2005^193^ | Did not study the population of interest. Most enrolled patients had a confirmed diagnosis of breast cancer and had undergone prior diagnostic/excision biopsies
Roman et al. 2005^194^ | Did not study the population of interest. Enrolled only patients with confirmed breast cancer.
Rosen et al. 2005^195^ | Did not study the technology of interest-- experimental methods.
Inoue et al. 2004^196^ | Did not study the population of interest. Enrolled only patients with confirmed breast cancer.
Marshall et al. 2004^197^ | Did not study the population of interest. Enrolled only patients with confirmed breast cancer.
Smyczek-Gargya et al. 2004^198^ | Did not study the population of interest. Enrolled only patients with confirmed breast cancer.
Levine et al. 2003^199^ | Did not study the technology of interest-- experimental methods.
Buck et al. 2002^200^ | Did not report any of the outcomes of interest.
Danforth et al. 2002^201^ | Did not study the population of interest. Enrolled only patients with confirmed breast cancer.
Paul et al. 2002^202^ | Did not study the population of interest. Enrolled only patients with confirmed breast cancer.
Avril et al. 2000^203^ | Update, with additional patients, of Avril et al.,203 which reports that it studied a mixed population of patients (some patients had a history of breast cancer).
Murthy et al. 2000^204^ | Did not study the technology of interest-- experimental methods.

## Scintimammography

18 total excluded

### Reasons for Exclusion

Did not use the tracer of interest: 5 studies

Did not use an acceptable reference standard to verify diagnoses of at least 85% of the patients: 5 studies

Did not enroll the patient population of interest: 3 studies

Did not address any of the Key Questions: 3 studies

Study of experimental methods not clinically relevant: 2 studies

Table D3 Studies of scintimammography that did not meet the inclusion criteria

Study | Reason for Exclusion
Brem et al. 2010^205^ | Did not address any of the Key Questions
Ozulker et al. 2010^206^ | Did not use an acceptable reference standard
Brem et al. 2008^207^ | Did not enroll the patient population of interest
Hruska et al. 2008^208^ | Exploratory study of experimental diagnostic methods
Sharma et al. 2008^209^ | 99mTc-methionine tracer
Spanu et al. 2008^210^ | Tc99m tetrofosmin tracer
Spanu et al. 2008^211^ | Tc99m tetrofosmin tracer
Buchmann et al. 2007^43^ | 99mTechnetium-Perechnetate or Iodide
Spanu et al. 2007^212^ | Tc99m tetrofosmin
Bekis et al. 2005^213^ | Does not address any of the Key Questions
Brem et al. 2005^214^ | Patients were at high-risk for breast cancer with normal mammograms/ clinical examination
Howarth et al. 2005^145^ | 26% of subjects had previous breast surgery/29% were positive for a family history of breast cancer
Kim et al. 2005^215^ | Did not use an acceptable reference standard to verify diagnoses of at least 85% of the patients
Myslivecek et al. 2005^216^ | Did not use an acceptable reference standard to verify diagnoses of at least 85% of the patients
Papantoniou et al. 2005^217^ | Does not address any of the Key Questions
Rhodes et al. 2005^218^ | Prototype device
Tiling et al. 2005^219^ | Did not use an acceptable reference standard to verify diagnoses of at least 85% of the patients
Kim et al. 2003^220^ | Did not use an acceptable reference standard to verify diagnoses of at least 85% of the patients

Tc Technetium

## Ultrasound Exclusions

153 total excluded

### Reasons for Exclusion

Did not enroll the patient population of interest: 63 studies

Did not address any of the Key Questions: 27 studies

Did not use an acceptable reference standard to verify diagnoses of at least 85% of patients: 27 studies

Retrospective study that did not enroll all or consecutive patients: 11 studies

Did not report sufficient information to calculate the outcomes of interest: 8 studies

Study of experimental methods not clinically relevant: 9 studies

Duplicate reports of the same studies/patients: 3 articles

Reported data for fewer than 50% of the enrolled patients: 3 studies

Retrospective case-control design: 1 study

Did not report sufficient details of the US methods to permit analysis: 1 study

Table D4 Studies of ultrasound that did not meet the inclusion criteria

Study | Primary Reason for Exclusion
Caproni et al. 2010^221^ | Did not use an acceptable reference standard
Dave et al. 2010^222^ | Study of experimental technology
Cheng et al. 2010^223^ | Study of experimental technology
Hongjia et al. 2010^224^ | Did not enroll the patient population of interest
Moon et al. 2010^225^ | Retrospective study that did not enroll all or consecutive patients
Moriguchi et al. 2010^226^ | Did not use an acceptable reference standard
Sorelli et al. 2010^227^ | Did not use an acceptable reference standard
Wang et al. 2010^228^ | Study of experimental technology
Baek et al. 2009^229^ | Retrospective study that did not enroll all or consecutive patients
Balleyguier et al. 2009^230^ | Did not verify the diagnoses with an acceptable reference standard
Barr et al. 2009^231^ | Does not address any of the Key Questions
Devolli-Disha et al. 2009^232^ | Did not enroll the patient population of interest
Habib et al. 2009^47^ | Did not report any details of the US methods
Kim et al. 2009^233^ | Data was reported for fewer than 50% of the enrolled patients
Kotsianos-Hermle et al. 2009^234^ | Did not enroll the patient population of interest
Masroor et al. 2009^235^ | Did not enroll the patient population of interest
Masroor et al. 2009^236^ | Did not enroll the patient population of interest
McCavert et al. 2009^237^ | Did not verify the diagnoses with an acceptable reference standard
Su et al. 2009^238^ | Retrospective study that did not enroll all or consecutive patients
Barnard et al. 2008^239^ | Did not report sufficient data to calculate the outcomes of interest
Bilali et al. 2008^240^ | Did not report sufficient data to calculate the outcomes of interest
Choudhury et al. 2008^124^ | Did not enroll the patient population of interest
Forsberg et al. 2008^241^ | Exploratory study of experimental diagnostic methods
Kang et al. 2008^242^ | Data was reported for fewer than 50% of the enrolled patients
Kwak et al. 2008^243^ | Data was reported for fewer than 50% of the enrolled patients
LeCarpentier et al. 2008^244^ | Did not report sufficient data to calculate the outcomes of interest
Park et al. 2008^245^ | Did not enroll the patient population of interest
Singh et al. 2008^246^ | Did not verify the diagnoses with an acceptable reference standard
Wenkel et al. 2008^247^ | Only 65% of diagnoses were verified with an acceptable reference standard
Abbattista et al. 2007^248^ | Did not verify the diagnoses with an acceptable reference standard
Ballesio et al. 2007^249^ | Did not enroll the patient population of interest
Ciatto and Houssami 2007^250^ | Only enrolled patients diagnosed with carcinomas
Constantini et al. 2007^251^ | Only 72% of diagnoses were verified with an acceptable reference standard
Graf et al. 2007^252^ | Did not enroll the patient population of interest
Jiang et al. 2007^253^ | Does not address any of the Key Questions
Osako et al. 2007^254^ | Only enrolled patients diagnosed with carcinomas
Prasad and Houserkova 2007^255^ | Only 10% of diagnoses were verified with an acceptable reference standard
Scaperrotta et al. 2007^256^ | Did not report data for patients diagnosed as “clearly benign” on the diagnostic test of interest (US)
Thomas et al. 2007^257^ | Did not enroll the patient population of interest
Constantini et al. 2006^258^ | Duplicate report of data from Constantini et al.251
Del Frate et al. 2006^259^ | Did not enroll the patient population of interest
Grunwald et al. 2006^260^ | Did not enroll the patient population of interest
Malik et al. 2006^261^ | Did not verify the diagnoses with an acceptable reference standard
Regner et al. 2006^262^ | Does not address any of the Key Questions
Thomas et al. 2006^263^ | Did not enroll the patient population of interest
Adepoju et al. 2005^264^ | Did not enroll the patient population of interest
Baez et al. 2005^265^ | Only 37% of diagnoses were verified with an acceptable reference standard
Berg 2005^266^ | Did not enroll the patient population of interest
Cawson et al. 2005^267^ | Enrolled only patients diagnosed with radial scars
Cha et al. 2005^268^ | Did not report sufficient data to calculate the outcomes of interest
Cho et al. 2005^269^ | Did not verify the diagnoses of lesions diagnosed on US as benign
Cho et al. 2005^269^ | Only 40% of diagnoses were verified with an acceptable reference standard
Eljuga and Susac 2005^270^ | Retrospective study that did not enroll all or consecutive patients
Nagashima et al. 2005^271^ | Enrolled only patients diagnosed with ductal carcinoma in situ
Shahid et al. 2005^272^ | Did not enroll the patient population of interest
Szabo et al. 2005^273^ | Only 62.7% of diagnoses were verified with an acceptable reference standard
Tohno and Ueno 2005^274^ | Only enrolled patients diagnosed with carcinomas
Tumyan et al. 2005^275^ | Did not enroll the patient population of interest
Benson et al. 2004^276^ | Mixed patient population; primarily a study of screening asymptomatic patients
Boetes et al. 2004^153^ | Enrolled only women diagnosed with invasive lobular carcinoma
Chen et al. 2004^277^ | Retrospective study that did not enroll all or consecutive patients
Cid et al. 2004^278^ | Did not enroll the patient population of interest
Cura et al. 2004^279^ | Exploratory study of experimental diagnostic methods
Drukker et al. 2004^280^ | Does not address any of the Key Questions
Foxcroft et al. 2004^281^ | Enrolled only women diagnosed with breast cancer
Georgian-Smith 2004^282^ | Enrolled only patients diagnosed with hamartoma
Gibbs et al. 2004^157^ | Did not enroll the patient population of interest
Murad and Bari 2004^283^ | Only 70% of diagnoses were verified with an acceptable reference standard
Rotaru and Luciani 2004^159^ | Only enrolled patients that were difficult to diagnose by US
Santamaria et al. 2004^284^ | Enrolled only patients diagnosed with invasive carcinoma
Schelfout et al. 2004^160^ | Did not enroll the patient population of interest
Sehgal et al. 2004^285^ | Does not address any of the Key Questions
Selinko et al. 2004^286^ | Enrolled only women diagnosed with invasive lobular carcinoma
Strano et al. 2004^287^ | Does not address any of the Key Questions
Van Goethem et al. 2004^162^ | Did not enroll the patient population of interest
Yang and Tse 2004^288^ | Enrolled only women with DCIS
Zonderland et al. 2004^289^ | Does not address any of the Key Questions
Chen et al. 2003^290^ | Does not address any of the Key Questions
Chen et al. 2003^291^ | Enrolled only women diagnosed with carcinoma
Drukker and Giger 2003^292^ | Does not address any of the Key Questions
Flobbe et al. 2003^293^ | Did not report sufficient data to calculate the outcomes of interest
Kazimierz et al. 2003^294^ | Did not verify the diagnoses with an acceptable reference standard
Martinez et al. 2003^295^ | Did not enroll the patient population of interest
Mesaki et al 2003^296^ | Only 40% of diagnoses were verified with an acceptable reference standard
Nakahara et al. 2003^167^ | Did not enroll the patient population of interest
Park et al. 2003^297^ | Does not address any of the Key Questions
Puglisi et al. 2003^298^ | Enrolled only women with papillary breast lesions
Shetty et al. 2003^299^ | Did not report sufficient data to calculate the outcomes of interest
Chen et al. 2002^300^ | Did not enroll the patient population of interest
Chen et al. 2002^301^ | Does not address any of the Key Questions
Germer et al. 2002^302^ | Does not address any of the Key Questions
Gunhan-Bilgen et al. 2002^303^ | Enrolled only women diagnosed with inflammatory carcinoma
Hlawatsch et al. 2002^173^ | Did not enroll the patient population of interest
Krestan et al. 2002^304^ | Does not address any of the Key Questions
Kuo et al. 2002^305^ | Does not address any of the Key Questions
Kuo et al. 2002^306^ | Does not address any of the Key Questions
Lee et al. 2002^307^ | Retrospective study that did not enroll all or consecutive patients
Muttarak et al. 2002^308^ | Enrolled only patients diagnosed with phyllodes tumors
Reinikainen et al. 2002^177^ | Did not enroll the patient population of interest
Tan et al. 2002^309^ | Enrolled only patients diagnosed with invasive lobular carcinoma
Taylor et al. 2002^310^ | Did not report sufficient data to calculate the outcomes of interest
Teifke et al. 2002^178^ | Only 48% of diagnoses were verified with an acceptable reference standard
Wang et al. 2002^311^ | Duplicate report of data from Chen et al.311
Wang et al. 2002^312^ | Duplicate report of data from Chen et al.311
Yilmaz et al. 2002^313^ | Enrolled only women diagnosed with medullary carcinomas
Alamo et al. 2001^179^ | Did not enroll the patient population of interest
Allen et al. 2001^314^ | Does not address any of the Key Questions
Arger et al. 2001^315^ | Does not address any of the Key Questions
Bhatti et al. 2001^316^ | Did not enroll the patient population of interest
Chou et al. 2001^317^ | Does not address any of the Key Questions
Cwikla et al. 2001^318^ | Enrolled only patients diagnosed with multi-focal carcinomas
Francis et al. 2001^180^ | Enrolled only patients diagnosed with invasive lobular carcinoma
Malur et al. 2001^184^ | Did not enroll the patient population of interest
Ozdemir et al. 2001^319^ | Did not report sufficient data to calculate the outcomes of interest
Rosen and Soo 2001^320^ | Does not address any of the Key Questions
Soo et al. 2001^321^ | Enrolled only patients with negative US findings who were later diagnosed with carcinomas
Whitehouse et al. 2001^322^ | Does not address any of the Key Questions
Chaudhari et al. 2000^323^ | Does not address any of the Key Questions
Choi et al. 2000^324^ | Retrospective study that did not enroll all or consecutive patients
Evans and Lyons 2000^325^ | Enrolled only patients diagnosed with small invasive lobular carcinomas
Klaus et al. 2000^326^ | Only enrolled patients who underwent a biopsy because of findings on the diagnostic test of interest (ultrasound)
Madjar et al. 2000^327^ | Does not address any of the Key Questions
Stuhrmann et al. 2000^328^ | Did not enroll the patient population of interest
Thibault et al. 2000^329^ | Only 31% of diagnoses were verified with an acceptable reference standard
Baker et al. 1999^330^ | Does not address any of the Key Questions
Blohmer et al. 1999^331^ | Exploratory study of experimental diagnostic methods
Chao et al. 1999^332^ | Exploratory study of experimental diagnostic methods
Eltahir et al. 1999^333^ | Retrospective study with only 33.7% of the consecutively enrolled patients examined by ultrasound
Huang et al. 1999^334^ | Did not enroll the patient population of interest
Kook et al. 1999^335^ | Retrospective study that did not enroll all or consecutive patients
Moss et al. 1999^336^ | Only 33% of diagnoses were verified with an acceptable reference standard
Obwegeser et al. 1999^337^ | Did not verify the diagnoses with an acceptable reference standard
Rahbar et al. 1999^338^ | Does not address any of the Key Questions
Rotten et al. 1999^339^ | Did not enroll the patient population of interest
Skaane 1999^340^ | Enrolled only patients diagnosed with malignant tumors
Zonderland et al. 1999^341^ | Did not enroll the patient population of interest
Brnic et al. 1998^342^ | Only 13% of diagnoses were verified with an acceptable reference standard
Carson et al. 1998^343^ | Does not address any of the Key Questions
Delorme et al. 1998^344^ | Exploratory study of experimental diagnostic methods
Giuseppetti et al. 1998^345^ | Only 70% of diagnoses were verified with an acceptable reference standard
Hayashi et al. 1998^346^ | Retrospective study that did not enroll all or consecutive patients
Huber et al. 1998^347^ | Does not address any of the Key Questions
Wright et al. 1998^348^ | Did not report what reference standard, if any, was used to verify the diagnoses
Cabasares et al. 1997^349^ | Did not enroll the patient population of interest
Jain et al. 1997^350^ | Did not verify the diagnoses with an acceptable reference standard
Madjar et al. 1997^351^ | Did not enroll the patient population of interest
Muller-Schimpfle et al. 1997^352^ | Does not address any of the Key Questions
Raza and Baum 1997^353^ | Only enrolled patients that were referred for biopsy on the basis of the US examinations
Schelling et al. 1997^354^ | Exploratory study of experimental diagnostic methods
Skaane et al. 1997^355^ | Retrospective case-control study
Yang et al. 1997^356^ | Only enrolled patients diagnosed with carcinomas
Edde 1994^357^ | Did not enroll the patient population of interest
Saitoh et al. 1994^358^ | Retrospective study that did not enroll all or consecutive patients

US Ultrasound

## ECRI Institute Personnel

All ECRI Institute personnel involved in the preparation of this report may be contacted at:

ECRI Institute

5200 Butler Pike

Plymouth Meeting, PA 19462

Telephone: (610) 825-6000

Facsimile: (610) 834-1275

Karen M. Schoelles, M.D., S.M., F.A.C.P.

Director, Evidence-based Practice Center

Medical Director, Health Technology Assessment Group

Wendy Bruening, Ph.D.

Associate Director, Evidence-based Practice Center and Health Technology Assessment Group

Stacey Uhl, M.S.S.

Senior Research Analyst, Evidence-based Practice Center and Health Technology Assessment Group

Joann Fontanarosa, Ph.D.

Research Analyst, Evidence-based Practice Center and Health Technology Assessment Group

James T. Reston, Ph.D., M.P.H.

Associate Director, Evidence-based Practice Center and Health Technology Assessment Group

Jonathan R. Treadwell, Ph.D.

Associate Director, Evidence-Based Practice Center and Health Technology Assessment Group