# Evidence Tables

## Characteristics of Studies

### Magnetic Resonance Imaging (MRI)

Total of 41 studies

Total of 3,882 patients; 4,202 lesions

1 study of 3.0T; 2 studies of 0.5T; 3 studies of 1.0T; 33 studies of 1.5T; 1 study of mixed 1.0T and 1.5T; and 1 study NR

1 study comparing CAD assistance to not

26 studies of gadopentetic acid; 8 studies of gadodiamide; 3 studies of gadobenic acid; 2 studies of gadoteridol; 2 studies mixed or not reported; 2 studies compared gadopentetic acid to gadobenic acid.

Table C1 Included studies of MRI

Table C2 MRI studies: patient and lesion details

Table C3 Details of MRI methodology

Table C4 MRI studies: Information for meta-regressions

### Positron Emission Tomography (PET)

Total of 8 studies

Total of 438 patients, 459 lesions

7 studies of PET; 1 study of PET/CT

Table C5 Included studies of PET

Table C6 PET studies: patient and lesion details

Table C7 Details of PET methodology

Table C8 PET Studies: information for meta-regressions

### Scintimammography (SMM)

Total of 11 studies

Total of 1,074 patients, 1,074 lesions

10 studies of conventional SMM, 1 study of BSG1

Table C9 Included studies of scintimammography

Table C10 Scintimammography studies: patient and lesion details

Table C11 Details of scintimammography methods

Table C12 Scintimammography studies: information for meta-regression

### Ultrasound

#### Included Studies of Ultrasound

Total of 31 studies

Total of 8,642 patients; 9,044 lesions

Types of Ultrasound Studied: (many articles studied more than one type of ultrasound)

B-mode 2D grayscale: 21 studies

B-mode 2D grayscale contrast enhanced: 2 studies

B-mode 3D grayscale: 1 study

Color Doppler: 6 studies

Color Doppler, contrast enhanced: 2 studies

Combination of methods: 4 studies

Power Doppler: 9 studies

Power Doppler, contrast enhanced: 7 studies

Tissue harmonics: 1 study

Table C13 Included studies of ultrasound

Table C14 Ultrasound studies: patient and lesion details

Table C15 Ultrasound studies: details of methods

Table C16 Ultrasound studies: information for meta-regressions

## Data Analysis

### MRI

Table C17 MRI accuracy data

#### Accuracy of MRI in General

##### META-ANALYTIC INTEGRATION OF DIAGNOSTIC TEST ACCURACY STUDIES

SUMMARY DATA AND PERFORMANCE ESTIMATES

[underlined: Bivariate Binomial Mixed Model]

Number of studies = 41

Reference-positive Subjects = 2,209

Reference-negative Subjects = 1,843

Pretest Prob of Disease = 0.545

Between-study variance (varlogitSEN) = 0.831 (95% CI: 0.402 to 1.718)

Between-study variance (varlogitSPE) = 0.901 (95% CI: 0.493 to 1.649)

Correlation (Mixed Model) = −0.607

ROC Area, AUROC = 0.93 (95% CI: 0.90 to 0.95)

Heterogeneity (Chi-square): LRT_Q = 128.856, df = 2.00, LRT_p = 0.000

Inconsistency (I-square): LRT_I^2^ = 98.4% (95% CI: 97.6 to 99.3%)

[underlined: Summary Parameter Estimates (95% CI)]

Sensitivity: 91.7% (88.5 to 94.1%)

Specificity: 77.5% (71.0 to 82.9%)

Positive Likelihood Ratio: 4.08 (3.10 to 5.30)

Negative Likelihood Ratio: 0.11 (0.079 to 0.15)

Diagnostic Score: 3.638 (3.253 to 4.023)

Diagnostic Odds Ratio: 38.008 (25.864 to 55.856)

Figure C1 Summary ROC of MRI accuracy: all data

Figure 1 depicts the summary ROC model of the accuracy of the entire MRI database. It is a graph in ROC space (sensitivity on the y axis, 1-specificity on the x axis) with a curve describing the ROC, a summary point describing the estimate of accuracy, and small points describing the reported accuracy from each of the studies.

###### Exploration of Heterogeneity: Accuracy of MRI

###### Meta-regressions of All Data

Bivariate Model

Variable | p-Value
Prevalence of disease | 0.02
Readers blinded to clinical information | 0.03
Geographical location | 0.08
Enrolled consecutive or all patients | 0.13
Prospective design | 0.18
All diagnoses verified by histopathology | 0.28
Funding source | 0.36
Multi-centered | 0.52
Accounted for inter-reader differences | 0.56
Spectrum bias | 0.64
Magnet strength | 0.87
Contrast agent | 0.97

Statistically Significant Models

Parameter | Prevalence of Disease | Readers Blinded to Clinical Information
I^2^ (95% CI) | 74.4% (43.5 to 100.0%) | 70.2% (33.7 to 100.0%)
Heterogeneity (LRTChi) | 7.80 | 6.72
[underlined: Sensitivity:] | 96% | 87%
95% CI | 91 to 98% | 80 to 92%
Coefficient | 3.23 | 1.93
z | 2.69 | −2.04
p of z | 0.01 | 0.04
[underlined: Specificity:] | 56% | 75%
95% CI | 36 to 73% | 63 to 85%
Coefficient | 0.23 | 1.12
z | −3.55 | −0.39
p of z | 0.00 | 0.70

#### Subgroup Analyses of Statistically Significant Models

##### Accuracy of Studies with Readers Blinded to Clinical Information vs. Not

###### META-ANALYTIC INTEGRATION OF DIAGNOSTIC TEST ACCURACY STUDIES

SUMMARY DATA AND PERFORMANCE ESTIMATES

Bivariate Binomial Mixed Model

Parameter | Blinded | Not Blinded (or Not Reported)
Number of studies | 13 | 28
Number of patients | 1,289 | 2,763
Prevalence of disease | 63.4% | 50.4%
I^2^ | 89.9% | 98.1%
Sensitivity (95% CI) | 86.8% (82.1 to 90.4%) | 93.9% (90.0 to 96.4%)
Specificity (95% CI) | 74.7% (64.4 to 82.9%) | 78.0% (70.0 to 84.5%)
AUROC (95% CI) | 0.89 (0.86 to 0.92) | 0.94 (0.91 to 0.96)

Figure C2 Graph of MRI sensitivity and specificity relative to prevalence of disease

Figure 2 is a graph of reported MRI sensitivity, on the y axis, the prevalence of disease in the studies on the x axis. The pattern of data shows no apparent correlation between the two variables.

Figure C3 Accuracy of MRI: blinded study design vs. not

Figure 3 is a graph in ROC space (sensitivity on the y axis, 1-specificity on the x axis) with the accuracy of MRI studies that had blinded readers and the accuracy of studies that had non-blinded readers shown as bubbles encompassing the summary estimate of accuracy and the surrounding 95% confidence interval. The blinded studies can be seen to have a slightly lower overall sensitivity.

##### Accuracy of Studies with Disease Prevalence Greater or Less than 60%

###### META-ANALYTIC INTEGRATION OF DIAGNOSTIC TEST ACCURACY STUDIES

SUMMARY DATA AND PERFORMANCE ESTIMATES

Bivariate Binomial Mixed Model

Parameter | Prevalence >60% | Prevalence 60% or less^a^
Number of studies | 17 | 24
Number of patients | 1,430 | 2,622
Prevalence of disease | 65.5% | 44.5%
I^2^ | 96.0% | 64.1 sensitivity; 82.3 specificity
Sensitivity (95% CI) | 93.8% (89.1% to 96.6%) | 86.3% (84.3% to 88.2%)
Specificity (95% CI) | 70.3% (58.1% to 80.1%) | 76.1% (73.7% to 78.3%)
AUROC (95% CI) | 0.91 (0.88 to 0.93) | 0.91

a Could not fit a bivariate model; individual parameters estimated using Meta-Disc

#### Subgroup Analyses of MRI Data

##### Methods Factors

CAD assistance in interpreting images

Table C18 Accuracy of MRI: CAD

Study | Category | TP | FP | FN | TN | Sensitivity (95% CI) | Specificity (95% CI)
Baltzer et al. 2009^2^ | Readers alone | 202 | 51 | 59 | 139 | 77.4% (71.9% to 82.0%) | 73.2% (66.4% to 78.9%)
Baltzer et al. 2009^2^ | CAD assistance | 220 | 51 | 59 | 139 | 78.9% (73.7% to 83.2%) | 73.2% (66.4% to 78.9%)

FN False negative

FP False positive

TN True negative

TP True positive

Contrast agent

Table C19 MRI accuracy: studies directly comparing different contrast agents

Study | Category | TP | FP | FN | TN | Sensitivity (95% CI) | Specificity (95% CI)
Pediconi et al. 2008^7^ | Gadopentetic acid | 24 | 8 | 8 | 10 | 75.0% (57.8% to 86.6%) | 55.6% (33.8% to 75.3%)
Pediconi et al. 2008^7^ | Gadobenic acid | 31 | 5 | 1 | 13 | 96.9% (84.0% to 99.3%) | 72.2% (49.1% to 87.3%)
Pediconi et al. 2005^18^ | Gadopentetic acid | 29 | 0 | 9 | 8 | 76.3% (60.7% to 86.9%) | 100.0% (67.0% to 99.7%)
Pediconi et al. 2005^18^ | Gadobenic acid | 36 | 1 | 2 | 7 | 94.7% (82.5% to 98.4%) | 87.5% (52.6% to 97.4%)

FN False negative

FP False positive

TN True negative

TP True positive

###### Accuracy of Studies: Subgroup analysis comparison of Contrast Agents

META-ANALYTIC INTEGRATION OF DIAGNOSTIC TEST ACCURACY STUDIES

SUMMARY DATA AND PERFORMANCE ESTIMATES

Bivariate Binomial Mixed Model

Parameter | Gadopentetic Acid | Gadodiamide | Gadobenic Acid | Gadoteridol^a^
Number of studies | 28 | 8 | 5 | 2
Number of patients | 2,918 | 618 | 445 | 167
Prevalence of disease | 52.1% | 46.0% | 83.8% | 60.5%
I^2^ | 96.7% | 76.2% | 92.8% | 57.6% (sensitivity) 0.0% (specificity)
Sensitivity (95% CI) | 91.8% (88.0 to 94.4%) | 86.5% (81.4 to 90.4%) | 98.3% (90.9 to 99.7%) | 83.2% (74.4 to 89.9%)
Specificity (95% CI) | 74.4% (66.0 to 80.9%) | 87.8% (79.2 to 93.1%) | 75.5% (44.9 to 92.1%) | 71.2% (58.7 to 81.7%)
AUROC (95% CI) | 0.92 (0.89 to 0.94) | 0.91 (0.89 to 0.94) | 0.97 (0.95 to 0.98) | NA with only 2 studies

a Could not fit a bivariate model; individual parameters estimated using Meta-Disc

Patient Factors

Table C20 Accuracy of MRI: miscellaneous patient factors

Study | Category | TP | FP | FN | TN | Sensitivity (95% CI) | Specificity (95% CI)
Bluemke et al. 2004^20^ | All | 356 | 136 | 48 | 281 | 88.1% (84.6% to 90.9%) | 67.4% (62.7% to 71.7%)
Bluemke et al. 2004^20^ | Premenopausal | 123 | 68 | 21 | 134 | 85.4% (78.7% to 90.2%) | 66.3% (59.6% to 72.5%)
Bluemke et al. 2004^20^ | Postmenopausal | 222 | 72 | 38 | 142 | 85.4% (80.6% to 89.1%) | 66.4% (59.8% to 72.3%)
Imbriaco et al. 2001^34^ | All | 24 | 6 | 1 | 22 | 96.0% (80.2% to 99.1%) | 78.6% (60.4% to 89.6%)
Imbriaco et al. 2001^34^ | Younger than 50 years | 11 | 3 | 0 | 9 | 100.0% (73.6% to 99.7%) | 75.0% (46.7% to 90.8%)
Imbriaco et al. 2001^34^ | 50 and older years | 13 | 3 | 1 | 9 | 92.9% (68.2% to 98.5%) | 75.0% (46.7% to 90.8%)

FN False negative

FP False positive

TN True negative

TP True positive

Lesion Factors

###### Microcalcifications on mammography

###### Accuracy of Studies: Subgroup analysis comparison of studies that enrolled patients with microcalcifications to all studies

META-ANALYTIC INTEGRATION OF DIAGNOSTIC TEST ACCURACY STUDIES

SUMMARY DATA AND PERFORMANCE ESTIMATES

Bivariate Binomial Mixed Model

Parameter | All | Microcalcifications
Number of studies | 41 | 8
Number of patients | 4,052 | 692
Prevalence of disease | 54.5% | 45.7%
I^2^ | 98.4% | 3.86%
Sensitivity (95% CI) | 91.7% (88.5% to 94.1%) | 84.0% (79.5% to 88.3%)
Specificity (95% CI) | 77.5% (71.0% to 82.9%) | 79.4% (71.5% to 85.6%)
AUROC (95% CI) | 0.93 (0.90 to 0.95) | 0.88 (0.85 to 0.91)

Figure C4 Summary ROC MRI: patients with microcalcifications on mammography

Figure 4 depicts the summary ROC model of the accuracy of MRI to diagnose lesions with microcalcifications. It is a graph in ROC space (sensitivity on the y axis, 1-specificity on the x axis) with a curve describing the ROC, a summary point describing the estimate of accuracy, and small points describing the reported accuracy from each of the studies.

Table C21 Accuracy of MRI for microcalcifications: studies that directly compared microcalcifications to other

Study | Category | TP | FP | FN | TN | Sensitivity (95% CI) | Specificity (95% CI)
Bluemke et al. 2004^20^ | No microcalcifications | 232 | 84 | 25 | 129 | 90.3% (86.0% to 93.3%) | 60.6% (53.9% to 66.9%)
Bluemke et al. 2004^20^ | Microcalcifications | 106 | 42 | 21 | 131 | 83.5% (76.0% to 88.9%) | 75.7% (68.8% to 81.5%)
Van Goethem et al. 2000^41^ | All | 19 | 8 | 1 | 29 | 95.0% (76.1% to 98.9%) | 78.4% (62.7% to 88.5%)
Van Goethem et al. 2000^41^ | Microcalcifications | 6 | 2 | 1 | 8 | 85.7% (48.4% to 97.0%) | 80.0% (48.9% to 94.0%)

FN False negative

FP False positive

TN True negative

TP True positive

Table C22 Accuracy of MRI: miscellanous lesion factors

Study | Category | TP | FP | FN | TN | Sensitivity (95% CI) | Specificity (95% CI)
Gokalp and Topal 2006^14^ | BIRADS 3 | 1 | 2 | 0 | 53 | 100.0% (20.8% to 99.2%) | 96.4% (87.5% to 98.9%)
Bluemke et al. 2004^20^ | All | 356 | 136 | 48 | 281 | 88.1% (84.6% to 90.9%) | 67.4% (62.7% to 71.7%)
Bluemke et al. 2004^20^ | Palpable | 194 | 51 | 19 | 81 | 91.1% (86.5% to 94.2%) | 61.4% (52.8% to 69.2%)
Bluemke et al. 2004^20^ | Nonpalpable | 162 | 85 | 29 | 198 | 84.8% (79.0% to 89.2%) | 70.0% (64.4% to 75.0%)
Bluemke et al. 2004^20^ | Mostly fat | 49 | 25 | 5 | 27 | 90.7% (80.0% to 95.9%) | 51.9% (38.7% to 64.9%)
Bluemke et al. 2004^20^ | Dense | 32 | 17 | 5 | 25 | 86.5% (71.9% to 94.0%) | 59.5% (44.5% to 72.9%)
Wiberg et al. 2002^30^ | All | 77 | 17 | 5 | 15 | 93.9% (86.4% to 97.3%) | 46.9% (30.9% to 63.5%)
Wiberg et al. 2002^30^ | Dense breasts | 17 | 9 | 1 | 5 | 94.4% (73.9% to 98.8%) | 35.7% (16.5% to 61.2%)
Imbriaco et al. 2001^34^ | All | 24 | 6 | 1 | 22 | 96.0% (80.2% to 99.1%) | 78.6% (60.4% to 89.6%)
Imbriaco et al. 2001^34^ | Lesion 10 mm or larger | 19 | 3 | 1 | 13 | 95.0% (76.1% to 98.9%) | 81.3% (56.8% to 93.2%)
Imbriaco et al. 2001^34^ | Lesion smaller than 10 mm | 5 | 3 | 0 | 5 | 100.0% (56.0% to 99.6%) | 62.5% (30.6% to 86.0%)

FN False negative

FP False positive

TN True negative

TP True positive

### PET

Table C23 PET accuracy data

Study | Position | Patient Subgroup | TP | FP | FN | TN | Sensitivity (95% CI) | Specificity (95% CI)
Kaida et al. 2008^42^ | Supine | All | 81 | 12 | 17 | 12 | 82.7% (73.7% to 89.6%) | 50.0% (29.1% to 70.9%)
Kaida et al. 2008^42^ | Prone | All | 109 | 4 | 5 | 4 | 95.6% (90% to 98.6%) | 50.0% (15.7% to 84.3%)
Buchmann et al. 2007^43^ | Prone | All | 25 | 0 | 3 | 1 | 89.3% (71.8% to 97.7%) | 100.0% (02.5% to 100.0%)
Hienisch et al. 2003^24^ | Prone | All | 17 | 4 | 8 | 11 | 68.0% (46.5% to 85.1%) | 73.3% (44.9% to 92.2%)
Walter et al. 2003^25^ | Prone | All | 12 | 2 | 7 | 21 | 63.2% (38.4% to 83.7%) | 91.3% (72.0% to 98.9%)
Brix et al. 2001^31^ | Prone | All | 8 | 2 | 1 | 2 | 88.9% (51.8% to 99.7%) | 50.0% (06.8% to 93.2%)
Schirrmeister et al. 2001^44^ | Prone | All | 83 | 7 | 6 | 21 | 93.3% (85.9% to 97.5%) | 75.0% (55.1% to 89.3%)
Yutani et al. 2000^45^ | Supine | All | 30 | 0 | 8 | 2 | 78.9 (62.7% to 90.4%) | 100.0% (15.8% to 100.0%)
Yutani et al. 2000^45^ | Supine | BIRADS 5 | 26 | 0 | 2 | 2 | 93% (76.5% to 99.1%) | 100.0% (15.7% to 84.3%)
Yutani et al. 2000^45^ | Supine | Lesion 1.5 cm or larger | 27 | 0 | 1 | 1 | 79.4% (62.1% to 91.3%) | 100.0% (02.5% to 100.0%)
Yutani et al. 2000^45^ | Supine | Palpable lesion | 29 | 0 | 7 | 1 | 80.6% (64.0% to 91.8%) | 100.0% (02.5% to 100.0%)
Yutani et al. 2000^45^ | Supine | Younger than 65 | 25 | 0 | 7 | 2 | 78.1% (60.0% to 90.7%) | 100.0% (15.8% to 100.0%)

FN False negative

FP False positive

TN True negative

TP True positive

Table C24 PET/CT accuracy data

Study | Time of Scan | Patient Subgroup | True Positive | False Positive | False Negative | True Negative | Sensitivity (95% CI) | Specificity (95% CI)
Imbriaco et al. 2007^6^ | Early | All | 22 | 0 | 14 | 8 | 61.1% (43.5% to 76.9%) | 100% (63.1% to 100%)
Imbriaco et al. 2007^6^ | Late | All | 29 | 0 | 7 | 8 | 80.6% (64.0% to 91.8%) | 100% (63.1% to 100%)
Imbriaco et al. 2007^6^ | Early | Lesions >10 mm | NR | NR | NR | NR | 74.1% (53.7% to 88.9%) Reported by authors | 100.0% (63.1% to 100.0%) Reported by authors
Imbriaco et al. 2007^6^ | Late | Lesions >10 mm | NR | NR | NR | NR | 87.1% (70.2% to 96.4%) Reported by authors | 100.0% (39.8% to 100.0%) Reported by authors
Imbriaco et al. 2007^6^ | Early | Lesions <10 mm | NR | NR | NR | NR | 27.3% (06.0% to 61.0%) Reported by authors | 100.0% (66.4% to 100.0%) Reported by authors
Imbriaco et al. 2007^6^ | Late | Lesions <10 mm | NR | NR | NR | NR | 60.0% (32.3% to 83.7%) Reported by authors | 100.0% (47.8% to 100.0%) Reported by authors

FN False negative

FP False positive

TN True negative

TP True positive

#### Accuracy of PET

##### META-ANALYTIC INTEGRATION OF DIAGNOSTIC TEST ACCURACY STUDIES

SUMMARY DATA AND PERFORMANCE ESTIMATES

[underlined: Bivariate Binomial Mixed Model]

Number of studies = 7

Reference-positive Subjects = 306

Reference-negative Subjects = 97

Pretest Prob of Disease = 0.759

Between-study variance (varlogitSEN) = 0.308 (95% CI: 0.051–1.868)

Between-study variance (varlogitSPE) = 0.393 (95% CI: 0.043–3.623)

Correlation (Mixed Model) = −0.456

ROC Area, AUROC = 0.86 (95% CI: 0.82 to 0.89)

Heterogeneity (Chi-square): LRT_Q = 5.623, df = 2.00, LRT_p = 0.030

Inconsistency (I-square): LRT_I^2^ = 64.4% (95% CI: 19.99 to 100.00%)

[underlined: Summary Parameter Estimates (95% CI)]

Sensitivity: 82.6% (73.5 to 89.1%)

Specificity: 73.9% (57.5 to 85.5%)

Positive Likelihood Ratio: 3.16 (1.86 to 5.38)

Negative Likelihood Ratio: 0.235 (0.15 to 0.37)

Diagnostic Score: 2.599 (1.794 to 3.404)

Diagnostic Odds Ratio: 13.449 (6.011 to 30.090)

Figure C5 Summary ROC of PET

Figure 5 depicts the summary ROC model of the accuracy of PET. It is a graph in ROC space (sensitivity on the y axis, 1-specificity on the x axis) with a curve describing the ROC, a summary point describing the estimate of accuracy, and small points describing the reported accuracy from each of the studies.

Table C25 PET studies: results of meta-regression

Variable | p-Value
Patient postion | 0.52
Palpable lesions only | 0.25
Readers blinded to clinical information | 0.05
All diagnoses verified by histopathology | 0.08

### Scintimammography

Table C26 Accuracy of scintimammography

Study | Patient Subgroup | True Positive | False Negative | False Positive | True Negative | Sensitivity (95% CI) | Specificity (95% CI)
Brem et al. 2007^9^ | All patients | 8 | 1 | 7 | 17 | 88.9% (51.8 to 99.7) | 70.8% (48.9 to 87.4)
Grosso et al. 2009^46^ | Nonpalpable lesions | 25 | 7 | 44 | 207 | 78.1% (60.0 to 90.7) | 82.5% (77.2 to 87.0)
Habib et al. 2009^47^ | Palpable lesions | 14 | 1 | 2 | 5 | 93.3% (68.1 to 99.8) | 71.4% (29.0 to 96.3)
Kim et al. 2009^4^ | All patients | 169 | 34 | 10 | 26 | 83.3% (77.4 to 88.1) | 72.2% (54.8 to 85.8)
Wang et al. 2008^49^ | Palpable lesions | 34 | 3 | 12 | 6 | 91.9% (78.1 to 98.3) | 33.3% (13.3 to 59.0)
Kim et al. 2008^48^ | All patients | 30 | 19 | 5 | 21 | 61.2% (46.2 to 74.8) | 80.8% (60.6 to 93.4)
Gommans et al. 2007^50^ | Non-palpable lesions | 37 | 8 | 4 | 52 | 82.2% (67.9 to 92.0) | 92.9% (82.7 to 98.0)
Kim et al. 2007^51^ | All patients | 57 | 9 | 0 | 12 | 86.4% (75.7 to 93.6) | 100% (75.3 to 100.0)
Schillaci et al. 2007^52^ | All patients | 27 | 10 | 1 | 15 | 73.0% (55.9 to 86.2) | 93.8% (69.8 to 99.8)
Pinero et al. 2006^53^ | All patients | 63 | 5 | 10 | 10 | 92.6% (83.7 to 97.6) | 50.0% (27.2 to 72.8)
Mathieu et al. 2005^54^ | All patients | 19 | 1 | 5 | 12 | 95.0% (75.1 to 99.9) | 70.6% (44.0 to 89.7)

FN False negative

FP False positive

TN True negative

TP True positive

#### META-ANALYTIC INTEGRATION OF DIAGNOSTIC TEST ACCURACY Planar Scintimammography

SUMMARY DATA AND PERFORMANCE ESTIMATES

[underlined: Bivariate Binomial Mixed Model]

Number of studies = 9

Reference-positive Units = 552

Reference-negative Units = 442

Pretest Prob of Disease = 0.56

Between-study variance in sensitivity (ICC_SEN) = 0.09 (95% CI: 0.00–0.21)

Between-study variance in sensitivity (MED_SEN) = 0.63 (95% CI: 0.56–0.75)

Between-study variance in specificity (ICC_SPE) = 0.23 (95% CI: 0.00–0.46)

Between-study variance in specificity (MED_SPE) = 0.72 (95% CI: 0.62–0.86)

Correlation (Mixed Model) = −0.76

ROC Area, AUROC = 0.88 (95% CI: 0.85 to 0.91)

Heterogeneity (Chi-square): LRT_Q = 27.288, df = 2.00, LRT_p = 0.000

Inconsistency (I-square): 93.0 % (95% CI: 86.0% to 99.0%)

[underlined: Summary Parameter Estimates (95% CI)]

Sensitivity: 84.0% (76.0% to 89.0%)

Specificity: 79.0% (63.0% to 89.0%)

Positive Likelihood Ratio: 3.9 (2.2 to 6.8)

Negative Likelihood Ratio: 0.21 (0.15 to 0.29)

Diagnostic Odds Ratio: 19 (10 to 35)

Figure C6 Summary ROC of scintimammography

Figure 6 depicts the summary ROC model of the accuracy of scintimammography. It is a graph in ROC space (sensitivity on the y axis, 1-specificity on the x axis) with a curve describing the ROC, a summary point describing the estimate of accuracy, and small points describing the reported accuracy from each of the studies.

Table C27 Scintimammography studies: results of meta-regression

Variable | p-Value
Consecutive or all enrollment | 0.11
All diagnoses verified by histopathology | 0.24
Readers blinded to clinical information | 0.93

### Ultrasound

#### Ultrasound B-mode 2D grayscale

21 studies, 8,199 lesions

Table C28 Ultrasound accuracy data: B-mode 2D grayscale

Study | Category | TP | FP | FN | TN | Sensitivity (95% CI) | Specificity (95% CI)
Gokalp et al. 2009^55^ | All | 39 | 23 | 0 | 32 | 100.0% (91.0% to 100.0%) | 58.2% (44.1% to 71.3%)
Vassiou et al. 2009^8^ | All | 44 | 6 | 9 | 19 | 83.0% (70.7% to 90.7%) | 76.0% (56.5% to 94.3%)
Liu et al. 2008^56^ | All | 41 | 15 | 2 | 46 | 95.3% (84.2% to 99.4%) | 75.4% (62.7% to 85.5%)
Vade et al. 2008^57^ | Palpable lesions | 0 | 6 | 0 | 15 | Not calculated | Not calculated
Cha et al. 2007^58^ | All | 29 | 23 | 1 | 38 | 96.7% (82.8% to 99.9% | 62.3% (49.0% to 74.4%)
Chala et al. 2007^59^ | All | 51 | 96 | 1 | 81 | 98.1% (89.7% to 100.0%) | 45.8% (38.3% to 53.4%)
Zhi et al. 2007^60^ | All | 62 | 56 | 25 | 153 | 71.3% (60.6% to 80.5%) | 73.2% (66.7% to 79.1%)
Cho et al. 2006^61^ | All | 58 | 32 | 2 | 59 | 96.7% (88.5% to 99.6%) | 64.8% (54.1% to 74.6%)
Ricci et al. 2006^16^ | All | 26 | 4 | 12 | 8 | 68.4% (51.3% to 82.5%) | 66.7% (34.9% to 90.1%)
Forsberg et al. 2004^62^ | All | 10 | 5 | 14 | 24 | 41.7% (22.1% to 63.4%) | 82.8% (64.2% to 94.2%)
Meyberg-Solomayer et al. 2004^63^ | All | 42 | 0 | 0 | 23 | 100.0% (91.6% to 100.0%) | 100.0% (85.2% to 100.0%)
Chen et al. 2003^65^ | Palpable lesions | 22 | 5 | 2 | 3 | 91.7% (73.0% to 99.0%) | 37.5% (8.5% to 75.5%)
Kook and Kwag 2003^66^ | 2 cm or less | 17 | 10 | 0 | 9 | 100.0% (80.5% to 100.0%) | 47.4% (24.4% to 71.1%)
Marini et al. 2003^67^ | Microcalcifications | 81 | 96 | 13 | 48 | 86.2% (77.5% to 92.4%) | 33.3% (25.7% to 41.7%)
Reinikainen et al. 2001^71^ | All | 34 | 28 | 0 | 3 | 100.0% (89.7% to 100.0%) | 9.7% (2.0% to 25.8%)
Blohmer et al. 1999^73^ | All | 76 | 4 | 81 | 70 | 48.45 (40.4% to 56.5%) | 94.6% (86.7% to 98.5%)
Chao et al. 1999^74^ | All | 639 | 797 | 103 | 1,554 | 86.1% (83.4% to 88.5%) | 66.1% (64.1% to 68.0%)
Wilkens et al. 1998^77^ | Palpable lesions | 19 | 0 | 3 | 33 | 86.4% (65.1% to 97.1%) | 100.0% (89.4% to 100.0%)
Stavros et al. 1995^79^ | All | 123 | 202 | 2 | 424 | 98.4% (94.3% to 99.8%) | 67.7% (63.9% to 71.4%)
Ciatto et al. 1994^80^ | All | 176 | 42 | 84 | 1,777 | 76.7% (61.6% to 73.3%) | 97.7% (96.%9 to 98.3%)
Perre et al. 1994^81^ | Palpable lesions | 168 | 4 | 4 | 211 | 97.7% (94.2% to 99.4%) | 98.1% (95.3% to 99.5%)

FN False negative

FP False positive

TN True negative

TP True positive

##### Accuracy of Ultrasound B-mode Grayscale 2D in General

###### META-ANALYTIC INTEGRATION OF DIAGNOSTIC TEST ACCURACY STUDIES

SUMMARY DATA AND PERFORMANCE ESTIMATES

[underlined: Bivariate Binomial Mixed Model]

Number of studies = 21

Reference-positive Subjects = 2,115

Reference-negative Subjects = 6,084

Pretest Prob of Disease = 0.258

Between-study variance (varlogitSEN) = 2.662 (95% CI: 1.162 to 6.096)

Between-study variance (varlogitSPE) = 2.455 (95% CI: 1.200 to 5.022)

Correlation (Mixed Model) = −0.331

ROC Area, AUROC = 0.92 (95% CI: 0.90 to 0.94)

Heterogeneity (Chi-square): LRT_Q = 612.405, df = 2.00, LRT_p = 0.000

Inconsistency (I-square): 99.7 % (95% CI: 99.6% to 99.78%)

[underlined: Summary Parameter Estimates (95% CI)]

Sensitivity: 92.4% (84.6% to 96.4%)

Specificity: 75.8% (60.8% to 86.3%)

Positive Likelihood Ratio: 3.814 (2.272 to 0.964)

Negative Likelihood Ratio: 0.100 (0.049 to 0.203)

Diagnostic Score: 3.64 (2.738 to 6.403)

Diagnostic Odds Ratio: 38.083 (15.458 to 93.824)

Figure C7 Bivariate binomial mixed-effects model of ultrasound B-mode grayscale 2D: summary ROC

Figure 7 depicts the summary ROC model of the accuracy of 2D grayscale ultrasound. It is a graph in ROC space (sensitivity on the y axis, 1-specificity on the x axis) with a curve describing the ROC, a summary point describing the estimate of accuracy, and small points describing the reported accuracy from each of the studies.

###### Exploration of Heterogeneity

Bivariate Model

Variable | p-Value
Accounted for inter-reader differences | 0.01
Readers blinded to clinical information | 0.03
All diagnoses verified by histopathology | 0.06
Prospective design | 0.18
Funding source | 0.20
Enrolled consecutive or all patients | 0.40
Geographical location | 0.53
Type of lesion enrolled | 0.85
Prevalence of disease | 0.86

Statistically Significant Models

Parameter | Accounted for Inter-reader Differences | Readers Blinded to Clinical Information
I^2^ (95% CI) | 76.8% (49.44 to 100.0%) | 72.1% (38.05% to 100.0%)
Heterogeneity (LRTChi) | 8.63 | 7.16
[underlined: Sensitivity]: | 94% | 98%
95% CI | 82% to 98% | 92% to 99%
Coefficient | 2.80 | 3.70
z | 0.33 | 2.46
p of z | 0.74 | 0.01
[underlined: Specificity]: | 52% | 59%
95% CI | 30% to 73% | 33% to 81%
Coefficient | 0.08 | 0.38
z | −3.10 | −1.84
p of z | 0.00 | 0.07

##### Subgroup Analyses of Statistically Significant Models

###### Accuracy of Studies with Readers Blinded to Clinical Information vs. Not

###### META-ANALYTIC INTEGRATION OF DIAGNOSTIC TEST ACCURACY STUDIES

SUMMARY DATA AND PERFORMANCE ESTIMATES

Bivariate Binomial Mixed Model

Parameter | Blinded | Not Blinded (or Not Reported)
Number of studies | 8 | 12
Number of patients | 1,301 | 6,820
Prevalence of disease | 38.6% | 22.9%
I^2^ | 90.7% | 99.6%
Sensitivity (95% CI) | 96.6% (92.3% to 98.5%) | 87.0% (69.7% to 95.1%)
Specificity (95% CI) | 59.5% (32.2% to 82.0%) | 85.1% (69.0% to 93.6%)
AUROC (95% CI) | 0.96 (0.94 to 0.97) | 0.93 (0.90 to 0.95)

###### Accuracy of Studies with Interreader Differences Accounted for vs. Not

###### META-ANALYTIC INTEGRATION OF DIAGNOSTIC TEST ACCURACY STUDIES

SUMMARY DATA AND PERFORMANCE ESTIMATES

Bivariate Binomial Mixed Model

Parameter | Accounted for | Not
Number of studies | 9 | 11
Number of patients | 1,063 | 7,037
Prevalence of disease | 40.2% | 23.2%
I^2^ | 96.7% | 99.6%
Sensitivity (95% CI) | 93.4% (83.1% to 97.6%) | 93.0% (77.3% to 98.1%)
Specificity (95% CI) | 52.7% (36.6% to 68.3%) | 90.1% (74.3% to 96.6%)
AUROC (95% CI) | 0.83 (0.79 to 0.86) | 0.97 (0.95 to 0.98)

#### Ultrasound B-mode 3D Grayscale

1 study, 150 lesions

Table C29 Ultrasound accuracy data: B-mode 3D grayscale

Study | Category | TP | FP | FN | TN | Sensitivity (95% CI) | Specificity (95% CI)
Cho et al. 2006^61^ | All | 59 | 27 | 1 | 63 | 98.3% (91.1 to 100.0%) | 70.0% (59.4 to 79.2%)

FN False negative

FP False positive

TN True negative

TP True positive

#### Ultrasound B-mode Grayscale: 2D vs. 3D

1 study, 150 lesions

Table C30 Ultrasound accuracy data: B-mode grayscale, 2D vs. 3D

Study | Technology | TP | FP | FN | TN | Sensitivity (95% CI) | Specificity (95% CI)
Cho et al. 2006^61^ | 2D | 58 | 32 | 2 | 59 | 96.7% (88.5 to 99.6%) | 64.8% (54.1 to 74.6%)
Cho et al. 2006^61^ | 3D | 59 | 27 | 1 | 63 | 98.3% (91.1 to 100.0%) | 70.0% (59.4 to 79.2%)

FN False negative

FP False positive

TN True negative

TP True positive

#### Ultrasound B-mode 2D Contrast Enhanced

2 studies, 154 lesions

Table C31 Ultrasound accuracy data: B-mode 2D grayscale contrast enhanced

Study | Category | TP | FP | FN | TN | Sensitivity (95% CI) | Specificity (95% CI)
Liu et al. 2008^56^ | All | 41 | 7 | 2 | 54 | 95.3% (84.2% to 99.4%) | 88.5% (77.8% to 95.3%)
Ricci et al. 2006^16^ | All | 38 | 10 | 0 | 2 | 100.0% (90.7% to 100.0%) | Not calculated
Summary (random-effects) | | | | | | 97.5% (91.4% to 99.7%) I^2^ = 61.2% | 76.7% (65.4% to 85.8%) I^2^ = 96.0%

FN False negative

FP False positive

TN True negative

TP True positive

#### Ultrasound B-mode 2D Contrast Enhanced vs. Not Enhanced

2 studies, 154 lesions

Table C32 Ultrasound accuracy data: B-mode 2D grayscale contrast enhanced vs. not enhanced

Study | Category | TP | FP | FN | TN | Sensitivity (95% CI) | Specificity (95% CI)
Liu et al. 2008^56^ | Contrast Enhanced | 41 | 7 | 2 | 54 | 95.3% (84.2% to 99.4%) | 88.5% (77.8% to 95.3%)
Liu et al. 2008^56^ | Not Enhanced | 41 | 15 | 2 | 46 | 95.3% (84.2% to 99.4%) | 75.4% (62.7% to 85.5%)
Ricci et al. 2006^16^ | Contrast Enhanced | 38 | 10 | 0 | 2 | 100.0% (90.7% to 100.0%) | Not calculated
Ricci et al. 2006^16^ | Not Enhanced | 26 | 4 | 12 | 8 | 68.4% (72.7% to 90.2%) | 66.7% (34.9% to 90.1%)
Summary (random-effects) Contrast Enhanced | | | | | | 97.5% (91.4% to 99.7%) I^2^ = 61.2% | 76.7% (65.4% to 85.8%) I^2^ = 96.0%
Summary (random effects) Not Enhanced | | | | | | 82.7% (72.7% to 90.2%) I^2^ = 90.9% | 74.0% (62.4% to 83.5%) I^2^ = 0.0%

FN False negative

FP False positive

TN True negative

TP True positive

#### Ultrasound Color Doppler

6 studies, 718 lesions

Table C33 Ultrasound accuracy data: color doppler

Study | Category | TP | FP | FN | TN | Sensitivity (95% CI) | Specificity (95% CI)
Caruso et al. 2002^68^ | All | 16 | 1 | 4 | 15 | 80.0% (56.3% to 94.3%) | 93.8% (69.8% to 99.8%)
Koukouraki et al. 2001^69^ | All | 76 | 4 | 9 | 26 | 89.4% (80.8% to 95.0%) | 86.7% (69.3% to 96.2%)
Koukouraki et al. 2001^69^ | Palpable lesions | 61 | 2 | 6 | 9 | 91.0% (81.5% to 96.6%) | 81.8% (48.2% to 97.7%)
Koukouraki et al. 2001^69^ | Non-palpable lesions | 14 | 2 | 5 | 17 | 73.7% (48.8% to 90.9%) | 89.5% (66.9% to 98.7%)
Blohmer et al. 1999^73^ | All | 58 | 13 | 20 | 79 | 74.4% (63.2% to 83.6%) | 85.9% (77.0% to 92.3%)
Schroeder et al. 1999^75^ | All | 72 | 23 | 0 | 15 | 100.0% (95.0% to 100.0%) | 39.5% (24.0% to 56.6%)
Wilkens et al. 1998^77^ | Palpable lesions | 16 | 7 | 6 | 26 | 72.7% (49.8% to 89.3%) | 78.8% (61.1% to 91.0%)
Buadu et al. 1997^78^ | All | 73 | 11 | 9 | 23 | 89.0% (80.2% to 94.9%) | 67.6% (49.5% to 82.6%)

FN False negative

FP False positive

TN True negative

TP True positive

##### META-ANALYTIC INTEGRATION OF DIAGNOSTIC TEST ACCURACY STUDIES Ultrasound Color Doppler

Using All Lesions data from Koukouraki et al. 2001^69^ and including Wilkens et al. 1998^77^ (reported data from palpable lesions only)

SUMMARY DATA AND PERFORMANCE ESTIMATES

[underlined: Bivariate Binomial Mixed Model]

Number of studies = 6

Reference-positive Subjects = 359

Reference-negative Subjects = 243

Pretest Prob of Disease = 0.596

Between-study variance (varlogitSEN) = 1.201 (95% CI: 0.224 to 6.443)

Between-study variance (varlogitSPE) = 0.591 (95% CI: 0.149 to 2.352)

Correlation (Mixed Model) = −1.000

ROC Area, AUROC = 0.89 (95% CI: 0.86 to 0.91)

Heterogeneity (Chi-square): LRT_Q = 41.754, df = 2.00, LRT_p = 0.000

Inconsistency (I-square): 95.2% (95% CI: 91.4 to 99.1)

[underlined: Summary Parameter Estimates (95% CI)]

Sensitivity: 88.5% (74.4% to 95.4%)

Specificity: 76.4% (61.7% to 86.7%)

Positive Likelihood Ratio: 3.760 (2.399 to 5.892)

Negative Likelihood Ratio: 0.150 (0.072 to 0.314)

Diagnostic Score: 3.223 (2.635 to 3.811)

Diagnostic Odds Ratio: 25.096 (13.938 to 45.187)

###### Exploration of Heterogeneity

Ultrasound Color Doppler

Using All data from Koukouraki et al. 2001^69^ and not including Wilkens et al. 1998^77^ (reported data from palpable lesions only)

SUMMARY DATA AND PERFORMANCE ESTIMATES

[underlined: Bivariate Binomial Mixed Model]

Number of studies = 5

Reference-positive Subjects = 337

Reference-negative Subjects = 210

Heterogeneity (Chi-square): LRT_Q = 42.292, df = 2.00, LRT_p = 0.000

Inconsistency (I-square): 95.3% (95% CI: 91.48 to 99.06)

Compare to Inconsistency from full data set including Wilkens et al. 1998;^77^ I-square: 95.2%, 95% CI (91.4 to 99.1)

Figure C8 Bivariate binomial mixed-effects model of ultrasound color doppler: summary ROC

Too few studies to perform meta-regression

Figure 8 depicts the summary ROC model of the accuracy of color doppler ultrasound. It is a graph in ROC space (sensitivity on the y axis, 1-specificity on the x axis) with a curve describing the ROC, a summary point describing the estimate of accuracy, and small points describing the reported accuracy from each of the studies.

#### Ultrasound Color Doppler Contrast Enhanced

2 studies, 146 lesions

Table C34 Ultrasound accuracy data: color doppler contrast enhanced

Study | Category | TP | FP | FN | TN | Sensitivity (95% CI) | Specificity (95% CI)
Caruso et al. 2002^68^ | All | 18 | 3 | 2 | 13 | 90.0% (68.3% to 98.8%) | 81.3% (54.4% to 96.0%)
Schroeder et al. 1999^75^ | All | 72 | 2 | 0 | 36 | 100.0% (95.0% to 100.0%) | 94.7% (82.3% to 99.4%)
Summary (random-effects) | | | | | | 97.8% (92.4% to 99.7%) I^2^ = 84.0% | 90.7% (79.7% to 96.9%) I^2^ = 54.6%

FN False negative

FP False positive

TN True negative

TP True positive

#### Ultrasound Color Doppler Contrast Enhanced vs. Not Enhanced

2 studies, 146 lesions

Table C35 Ultrasound accuracy data: color doppler contrast enhanced vs. not enhanced

Study | Category | TP | FP | FN | TN | Sensitivity (95% CI) | Specificity (95% CI)
Caruso et al. 2002^68^ | Contrast Enhanced | 18 | 3 | 2 | 13 | 90.0% (68.3% to 98.8%) | 81.3% (54.4% to 96.0%)
Caruso et al. 2002^68^ | Not Enhanced | 16 | 1 | 4 | 15 | 80.0% (56.3% to 94.3%) | 93.8% (69.8% to 99.8%)
Schroeder et al. 1999^75^ | Contrast Enhanced | 72 | 2 | 0 | 36 | 100.0% (95.0% to 100.0%) | 94.7% (82.3% to 99.4%)
Schroeder et al. 1999^75^ | Not Enhanced | 72 | 23 | 0 | 15 | 100.0% (95.0% to 100.0%) | 39.5% (24.0% to 56.6%)
Summary (random-effects) Contrast Enhanced | | | | | | 97.8% (92.4% to 99.7%) I^2^ = 84.0% | 90.7% (79.7% to 96.9%) I^2^ = 54.6%
Summary (random-effects) Not Enhanced | | | | | | 95.7% (89.2% to 98.8%) I^2^ = 92.2% | 55.6% (41.4% to 69.1%) I^2^ = 93.6%

FN False negative

FP False positive

TN True negative

TP True positive

#### Ultrasound Color Doppler vs. B-mode Grayscale 2D

2 studies, 225 lesions

Table C36 Ultrasound accuracy data: color doppler vs. B-mode grayscale 2D

Study | Category | TP | FP | FN | TN | Sensitivity (95% CI) | Specificity (95% CI)
Blohmer et al. 1999^73^ | Color Doppler | 58 | 13 | 20 | 79 | 74.4% (63.2% to 83.6%) | 85.9% (77.0% to 92.3%)
Blohmer et al. 1999^73^ | B-mode | 76 | 4 | 81 | 70 | 48.4% (40.4% to 56.5%) | 94.6% (86.7% to 98.5%)
Wilkens et al. 1998^77^ | Color Doppler; palpable lesions only | 16 | 7 | 6 | 26 | 72.7% (49.8% to 89.3%) | 78.8% (61.1% to 91.0%)
Wilkens et al. 1998^77^ | B-mode; palpable lesions only | 19 | 0 | 3 | 33 | 86.4% (65.1% to 97.1%) | 100.0% (89.4% to 100.0%)
Summary (random-effects) Color Doppler | | | | | | 74.0% (64.3% to 82.3%) I^2^ = 0.0% | 84.0% (76.4% to 89.9%) I^2^ = 0.0%
Summary (random-effects) B-mode | | | | | | 53.1% (45.5% to 60.6%) I^2^ = 92.0% | 96.3% (90.7% to 99.0%) I^2^ = 66.9%

FN False negative

FP False positive

TN True negative

TP True positive

#### Ultrasound Power Doppler

9 studies, 614 lesions

Table C37 Ultrasound accuracy data: power doppler

Study | Category | TP | FP | FN | TN | Sensitivity (95% CI) | Specificity (95% CI)
Gokalp et al. 2009^55^ | All | 28 | 10 | 11 | 45 | 71.8% (55.1% to 85.0%) | 81.8% (69.1% to 90.9%)
Forsberg et al. 2004^62^ | All | 11 | 4 | 16 | 22 | 40.7% (22.4% to 61.2%) | 84.6% (65.1% to 95.6%)
Ozdemir et al. 2004^64^ | All | 23 | 26 | 5 | 14 | 82.1% (63.1% to 93.9%) | 35.0% (20.6% to 51.7%)
Kook and Kwag 2003^66^ | 2 cm or less | 5 | 5 | 12 | 14 | 29.4% (10.3% to 56.0%) | 73.7% (48.8% to 90.9%)
Milz et al. 2001^70^ | All | 41 | 16 | 14 | 47 | 74.5% (61.0% to 85.3%) | 74.6% (62.1% to 84.7%)
Reinikainen et al. 2001^71^ | All | 20 | 8 | 14 | 23 | 58.8% (40.7% to 75.45) | 74.2% (55.4% to 88.1%)
Moon et al. 2000^72^ | Non-palpable lesions | 8 | 4 | 14 | 24 | 36.4% (17.2% to 59.3%) | 85.7% (67.3% to 96.0%)
Schroeder et al. 1999^75^ | All | 72 | 21 | 0 | 17 | 100.0% (95.0% to 100.0%) | 44.7% (28.6% to 61.7%)
Albrecht et al. 1998^76^ | All | 9 | 1 | 2 | 8 | 81.8% (48.2% to 97.7%) | 88.9% (51.8% to 99.7%)

FN False negative

FP False positive

TN True negative

TP True positive

##### META-ANALYTIC INTEGRATION OF DIAGNOSTIC TEST ACCURACY STUDIES Ultrasound Power Doppler

SUMMARY DATA AND PERFORMANCE ESTIMATES

[underlined: Bivariate Binomial Mixed Model]

Number of studies = 9

Reference-positive Subjects = 305

Reference-negative Subjects = 309

Pretest Prob of Disease = 0.497

Between-study variance (varlogitSEN) = 1.995 (95% CI: 0.606–6.566)

Between-study variance (varlogitSPE) = 0.576 (95% CI: 0.178–1.870)

Correlation (Mixed Model) = −0.797

ROC Area, AUROC = 0.77 (95% CI: 0.74 to 0.81)

Heterogeneity (Chi-square): LRT_Q = 76.788, df = 2.00, LRT_p = 0.000

Inconsistency (I-square): 97.4% (95% CI: 95.7%–99.1%)

[underlined: Summary Parameter Estimates (95% CI)]

Sensitivity: 70.8% (47.5% to 86.6%)

Specificity: 72.6% (59.9% to 82.5%)

Positive Likelihood Ratio: 2.586 (1.882 to 3.555)

Negative Likelihood Ratio: 0.402 (0.219 to 0.738)

Diagnostic Score: 1.860 (1.110 to 2.611)

Diagnostic Odds Ratio: 6.426 (3.035 to 13.606)

Figure C9 Bivariate binomial mixed-effects model of ultrasound power doppler: summary ROC

Figure 9 depicts the summary ROC model of the accuracy of power doppler ultrasound. It is a graph in ROC space (sensitivity on the y axis, 1-specificity on the x axis) with a curve describing the ROC, a summary point describing the estimate of accuracy, and small points describing the reported accuracy from each of the studies.

#### Ultrasound Power Doppler vs. B-mode 2D grayscale

4 studies, 248 lesions

Table C38 Ultrasound accuracy data: power doppler vs. B-mode 2D grayscale

Study | Category | TP | FP | FN | TN | Sensitivity (95% CI) | Specificity (95% CI)
Gokalp et al. 2009^55^ | B-mode | 39 | 23 | 0 | 32 | 100.0% (91.0% to 100.0%) | 58.2% (44.1% to 71.3%)
Gokalp et al. 2009^55^ | Power Doppler | 28 | 10 | 11 | 45 | 71.8% (55.1% to 85.0%) | 81.8% (69.1% to 90.9%)
Forsberg et al. 2004^62^ | B-mode | 10 | 5 | 14 | 24 | 41.7% (22.1% to 63.4%) | 82.8% (64.2% to 94.2%)
Forsberg et al. 2004^62^ | Power Doppler | 11 | 4 | 16 | 22 | 40.7% (22.4% to 61.2%) | 84.6% (65.1% to 95.6%)
Kook and Kwag 2003^66^ | B-mode, lesions 2 cm or less | 17 | 10 | 0 | 9 | 100.0% (80.5% to 100.0%) | 47.4% (24.4% to 71.1%)
Kook and Kwag 2003^66^ | Power Doppler, lesions 2 cm or less | 5 | 5 | 12 | 14 | 29.4% (10.3% to 56.0%) | 73.7% (48.8% to 90.9%)
Reinikainen et al. 2001^71^ | B-mode | 34 | 28 | 0 | 3 | 100.0% (89.7% to 100.0%) | 9.7% (2.0% to 25.8%)
Reinikainen et al. 2001^71^ | Power Doppler | 20 | 8 | 14 | 23 | 58.8% (40.7% to 75.45) | 74.2% (55.4% to 88.1%)
Summary (random effects) B-mode | | | | | | 87.7% (80.3% to 93.1%) I^2^ = 94.3% | 50.7% (42.0% to 59.5%) I^2^ = 92.2%
Summary (random effects) Power Doppler | | | | | | 54.7% (45.2% to 63.9%) I^2^ = 74.1% | 79.4% (71.4% to 86.0%) I^2^ = 0.0%

FN False negative

FP False positive

TN True negative

TP True positive

#### Ultrasound Power Doppler with Contrast Agent

7 studies, 403 lesions

Table C39 Ultrasound accuracy data: power doppler with contrast agent

Study | Category | TP | FP | FN | TN | Sensitivity (95% CI) | Specificity (95% CI)
Forsberg et al. 2004^62^ | All | 8 | 7 | 23 | 15 | 25.8% (11.9% to 44.6%) | 68.2% (45.1% to 86.1%)
Ozdemir et al. 2004^64^ | All | 23 | 14 | 5 | 27 | 82.1% (63.1% to 93.9%) | 65.9% (49.4% to 79.9%)
Kook and Kwag 2003^66^ | 2 cm or less | 12 | 8 | 5 | 11 | 70.6% (44.0% to 89.7%) | 57.9% (33.5% to 79.7%)
Reinikainen et al. 2001^71^ | All | 19 | 17 | 15 | 14 | 55.9% (37.9% to 72.8%) | 45.2% (27.3% to 64.0%)
Moon et al. 2000^72^ | Non-palpable lesions | 21 | 6 | 1 | 22 | 95.5% (77.2% to 99.9%) | 78.6% (59.0% to 91.7%)
Schroeder et al. 1999^75^ | All | 72 | 2 | 0 | 36 | 100.0% (95.0% to 100.0%) | 94.7% (82.3% to 99.4%)
Albrecht et al. 1998^76^ | All | 11 | 4 | 0 | 5 | 100.0% (71.5% to 100.0%) | 55.6% (21.2% to 86.3%)

FN False negative

FP False positive

TN True negative

TP True positive

##### META-ANALYTIC INTEGRATION OF DIAGNOSTIC TEST ACCURACY STUDIES Ultrasound Power Doppler with Contrast

SUMMARY DATA AND PERFORMANCE ESTIMATES

[underlined: Bivariate Binomial Mixed Model]

Number of studies = 7

Reference-positive Subjects = 215

Reference-negative Subjects = 188

Pretest Prob of Disease = 0.533

Between-study variance (varlogitSEN) = 5.785 (95% CI: 1.218–27.486)

Between-study variance (varlogitSPE) = 0.548 (95% CI: 0.117–2.560)

Correlation (Mixed Model) = 0.947

ROC Area, AUROC = 0.81 (95% CI: 0.77 to 0.84)

Heterogeneity (Chi-square): LRT_Q = 16.015, df = 2.00, LRT_p = 0.000

Inconsistency (I-square): 87.51% (95% CI: 74.55 to 100.00)

[underlined: Summary Parameter Estimates (95% CI)]

Sensitivity: 89.3% (52.4% to 98.4%)

Specificity: 70.4% (55.4% to 82.0%)

Positive Likelihood Ratio: 3.016 (1.603 to 5.675)

Negative Likelihood Ratio: 0.153 (0.022 to 1.072)

Diagnostic Score: 2.984 (0.452 to 5.517)

Diagnostic Odds Ratio: 19.772 (1.571 to 248.893)

Figure C10 Bivariate binomial mixed-effects model of ultrasound power doppler with contrast: summary ROC

Figure 10 depicts the summary ROC model of the accuracy of power doppler ultrasound with contrast. It is a graph in ROC space (sensitivity on the y axis, 1-specificity on the x axis) with a curve describing the ROC, a summary point describing the estimate of accuracy, and small points describing the reported accuracy from each of the studies.

#### Ultrasound Power Doppler vs. Color Doppler

1 study, 110 lesions

Table C40 Ultrasound accuracy data: power doppler vs. color doppler

Study | Category | TP | FP | FN | TN | Sensitivity (95% CI) | Specificity (95% CI)
Schroeder et al. 1999^75^ | Power Doppler Contrast Enhanced | 72 | 2 | 0 | 36 | 100.0% (95.0% to 100.0%) | 94.7% (82.3% to 99.4%)
Schroeder et al. 1999^75^ | Power Doppler Non enhanced | 72 | 21 | 0 | 17 | 100.0% (95.0% to 100.0%) | 44.7% (28.6% to 61.7%)
Schroeder et al. 1999^75^ | Color Doppler Contrast Enhanced | 72 | 2 | 0 | 36 | 100.0% (95.0% to 100.0%) | 94.7% (82.3% to 99.4%)
Schroeder et al. 1999^75^ | Color Doppler Non enhanced | 72 | 23 | 0 | 15 | 100.0% (95.0% to 100.0%) | 39.5% (24.0% to 56.6%)

FN False negative

FP False positive

TN True negative

TP True positive

#### Ultrasound Tissue Harmonics

1 study, 91 lesions

Table C41 Ultrasound accuracy data: tissue harmonics

Study | Category | TP | FP | FN | TN | Sensitivity (95% CI) | Specificity (95% CI)
Cha et al. 2007^58^ | All | 29 | 23 | 1 | 38 | 96.7% (82.8% to 99.9%) | 62.3% (49.0% to 74.4%)

FN False negative

FP False positive

TN True negative

TP True positive

#### Ultrasound Tissue Harmonics vs. B-mode Grayscale

1 study, 91 lesions

Table C42 Ultrasound accuracy data: tissue harmonics vs. B-mode grayscale

Study | Category | TP | FP | FN | TN | Sensitivity (95% CI) | Specificity (95% CI)
Cha et al. 2007^58^ | Tissue harmonics | 29 | 23 | 1 | 38 | 96.7% (82.8% to 99.9%) | 62.3% (49.0% to 74.4%)
Cha et al. 2007^58^ | B-mode grayscale | 29 | 23 | 1 | 38 | 96.7% (82.8% to 99.9%) | 62.3% (49.0% to 74.4%)

FN false negative

FP false positive

TN true negative

TP true positive

#### Ultrasound Combination Methods

4 studies that used multiple ultrasound methods, in combination, to diagnose breast lesions

Table C43 Ultrasound accuracy data: combination methods

Study | Category | TP | FP | FN | TN | Sensitivity (95% CI) | Specificity (95% CI)
Gokalp et al. 2009^55^ | Combination of B-mode 2D grayscale and power Doppler | 39 | 26 | 0 | 29 | 100.0% (91.0% to 100.0%) | 52.7% (38.8% to 66.3%)
Liu et al. 2008^56^ | Combination of B-mode and contrast-enhanced B-mode 2D grayscale | 42 | 6 | 1 | 55 | 97.7% (87.7% to 99.9%) | 90.2% (79.8% to 96.3%)
Pinero et al. 2006^53^ | Combination power Doppler and color Doppler, contrast enhanced
Pinero et al. 2006^53^ | All lesions | 60 | 9 | 8 | 11 | 88.2% (78.1% to 94.8%) | 55.0% (31.5% to 76.9%)
Pinero et al. 2006^53^
Pinero et al. 2006^53^ | Palpable lesions | 42 | 2 | 5 | 8 | 89.4% (76.9% to 96.5%) | 80.0% (44.4% to 97.5%)
Pinero et al. 2006^53^
Pinero et al. 2006^53^ | Non-palpable lesions | 17 | 6 | 4 | 4 | 81.0% (58.1% to 94.6%) | 40.0% (12.2% to 73.8%)
Malich et al. 2001^35^ | Combination of B-mode, power Doppler, and color Doppler | 48 | 4 | 14 | 34 | 77.4% (65.0% to 87.1%) | 89.5% (75.2% to 97.1%)

FN false negative

FP false positive

TN true negative

TP true positive

Table C44 Ultrasound accuracy: accuracy of different types of ultrasound

Type of Ultrasound | N Studies | N Lesions | Risk of Bias | Consistency | Precision | Summary Sensitivity (95% CI) | Summary Specificity (95% CI) | Strength of Evidence
B-mode grayscale 2D | 21 | 8,199 | Low | Inconsistent | Imprecise | 92.4% (84.6% to 96.4%) | 75.8% (60.8% to 86.3%) | Low
B-mode grayscale 2D contrast enhanced | 2 | 154 | Low | Inconsistent | Imprecise | 97.5% (91.4% to 99.7%) | 76.7% (65.4% to 85.8%) | Low
B-mode grayscale 3D | 1 | 150 | Low | Unknown | Imprecise | 98.3% (91.1% to 100.0%) | 70.0% (59.4% to 79.2%) | Insufficient
Color Doppler | 6 | 718 | Low | Inconsistent | Imprecise | 88.5% (74.4% to 95.4%) | 76.4% (61.% to 86.7%) | Low
Color Doppler contrast enhanced | 2 | 146 | Low | Inconsistent | Imprecise | 97.8% (92.4% to 99.7%) | 90.7% (79.7% to 96.9%) | Low
Power Doppler | 9 | 614 | Low | Inconsistent | Imprecise | 70.8% (47.5% to 86.6%) | 72.6% (59.9% to 82.5%) | Low
Power Doppler contrast enhanced | 7 | 403 | Low | Inconsistent | Imprecise | 89.3% (52.4% to 98.4%) | 70.4% (55.4% to 82.0%) | Low
Tissue harmonics | 1 | 91 | Low | Unknown | Imprecise | 96.7% (82.8% to 99.9%) | 62.3% (49.0% to 74.4%) | Insufficient

Table C45 Ultrasound accuracy: indirect and direct comparisons of different types of ultrasound

Type of Ultrasound | B-mode Grayscale 2D | B-mode Grayscale 2D Contrast Enhanced | B-mode Grayscale 3D | Color Doppler | Color Doppler Contrast Enhanced | Power Doppler | Power Doppler Contrast Enhanced | Tissue Harmonics
B-mode grayscale 2D | NA | Contrast-enhanced has a higher sensitivity Strength of evidence: Low | Insufficient evidence | B-mode grayscale is more sensitive Strength of evidence: Low | Insufficient evidence | B-mode grayscale is more sensitive Strength of evidence: Low | Insufficient evidence | Insufficient evidence
B-mode grayscale 2D contrast enhanced | NA | NA | Insufficient evidence | Insufficient evidence | Insufficient evidence | Insufficient evidence | Insufficient evidence | Insufficient evidence
B-mode grayscale 3D | NA | NA | NA | Insufficient evidence | Insufficient evidence | Insufficient evidence | Insufficient evidence | Insufficient evidence
Color Doppler | NA | NA | NA | NA | Contrast-enhanced is more accurate Strength of evidence: Low | Color doppler is more accurate Strength of evidence Low | Insufficient evidence | Insufficient evidence
Color Doppler contrast enhanced | NA | NA | NA | NA | NA | Insufficient evidence | Insufficient evidence | Insufficient evidence
Power Doppler | NA | NA | NA | NA | NA | NA | Insufficient evidence | Insufficient evidence
Power Doppler contrast enhanced | NA | NA | NA | NA | NA | NA | NA | Insufficient evidence
Tissue harmonics | NA | NA | NA | NA | NA | NA | NA | NA

### Direct Comparisons

Table C46 Direct comparison of PET and MRI

Study | Category | TP | FP | FN | TP | Sensitivity (95% CI) | Specificity (95% CI)
Heinisch et al. 2003^24^ | PET | 17 | 4 | 8 | 11 | 68.0% (46.5% to 85.1%) | 73.3% (44.9% to 92.2%)
Heinisch et al. 2003^24^ | MRI | 23 | 2 | 4 | 11 | 85.2% (67.4% to 93.9%) | 84.6% (57.6% to 95.4%)
Walter et al. 2003^25^ | PET | 12 | 2 | 7 | 21 | 63.2% (38.4% to 83.7%) | 91.3% (72.0% to 98.9%)
Walter et al. 2003^25^ | MRI | 17 | 2 | 6 | 17 | 73.9% (53.4% to 87.3%) | 89.5% (68.4% to 96.8%)
Brix et al. 2001^31^ | PET | 8 | 2 | 1 | 2 | 88.9% (51.8% to 99.7%) | 50.0% (06.8% to 93.2%)
Brix et al. 2001^31^ | MRI | 8 | 1 | 2 | 2 | 80.0% (48.9% to 94.0%) | 66.7% (21.0% to 93.3%)
Imbriaco et al. 2007^6^ | PET-CT | 29 | 0 | 7 | 8 | 80.6% (64.0% to 91.8%) | 100% (63.1% to 100%)
Imbriaco et al. 2007^6^ | MRI | 44 | 2 | 1 | 8 | 97.8% (88.3% to 99.5%) | 80.0% (48.9% to 94.0%)

FN False negative

FP False positive

TN True negative

TP True positive

Table C47 Direct comparison of MRI and ultrasound

Study | Category | TP | FP | FN | TN | Sensitivity (95% CI) | Specificity (95% CI)
Vassiou et al. 2009^8^ | MRI | 52 | 14 | 1 | 11 | 98.1% (89.9% to 99.6%) | 44.0% (26.7% to 62.9%)
Vassiou et al. 2009^8^ | US, B-mode 2D grayscale | 44 | 6 | 9 | 19 | 83.0% (70.7 to 90.7%) | 76.0% (56.5 to 94.3%)
Ricci et al. 2006^16^ | MRI | 38 | 2 | 0 | 11 | 100.0% (90.6% to 99.9%) | 84.6% (57.6% to 95.4%)
Ricci et al. 2006^16^ | US, B mode grayscale, contrast enhanced | 38 | 10 | 0 | 2 | 100.0% (90.7 to 100.0%) | Not calculated
Ricci et al. 2006^16^ | US, B mode grayscale, not enhanced | 26 | 4 | 12 | 8 | 68.4% (72.7 to 90.2%) | 66.7% (34.9 to 90.1%)
Malich et al. 2001^35^ | MRI | 53 | 7 | 1 | 29 | 98.1% (90.1% to 99.6%) | 80.6% (64.9% to 90.1%)
Malich et al. 2001^35^ | Combination of B-mode, power Doppler, and color Doppler | 48 | 4 | 14 | 34 | 77.4% (65.0 to 87.1%) | 89.5% (75.2 to 97.1%)

FN False negative

FP False positive

TN True negative

TP True positive

US Ultrasound

Table C48 Direct comparison of scintimammography to doppler ultrasound (combined method)

Study | Category | Patient Subgroup | TP | FP | FN | TN | Sensitivity (95% CI) | Specificity (95% CI)
Pinero et al. 2006^53^ | Double phase SMM | All, mixed population | 63 | 10 | 5 | 10 | 92.6% (83.7 to 97.6) | 50.0% (27.2 to 72.8)
Pinero et al. 2006^53^ | Combination power Doppler and color Doppler, contrast enhanced | All, mixed population | 60 | 8 | 9 | 11 | 88.2% (78.1 to 94.8) | 55.0% (31.5 to 76.9)
Pinero et al. 2006^53^ | Double phase SMM | Palpable lesions only | 43 | 3 | 4 | 7 | 91.5% (79.6 to 97.6) | 70.0% (34.8 to 93.3)
Pinero et al. 2006^53^ | Combination power Doppler and color Doppler, contrast enhanced | Palpable lesions only | 42 | 2 | 5 | 8 | 89.4% (76.9 to 96.5) | 80.0% (44.4 to 97.5)
Pinero et al. 2006^53^ | Double phase SMM | Non-palpable | 20 | 1 | 6 | 4 | 95.2% (76.2 to 99.9) | 40.0% (12.2 to 73.8)
Pinero et al. 2006^53^ | Combination power Doppler and color Doppler, contrast enhanced | Non-palpable | 17 | 4 | 6 | 4 | 81.0% (58.1 to 94.6) | 40.0% (12.2 to 73.8)

FN False negative

FP False positive

TN True negative

TP True positive

Table C49 Comparison of scintimammography with MRI

Study | Category | TP | FP | FN | TN | Sensitivity (95% CI) | Specificity (95% CI)
Kim et al. 2009^4^ | Double phase SMM | 169 | 10 | 34 | 26 | 83.3% (77.4 to 88.1) | 72.2% (54.8 to 85.8)
Kim et al. 2009^4^ | Dynamic contrast enhanced MRI | 196 | 14 | 8 | 21 | 96.1% (92.4 to 98.3) | 60.0% (42.1 to 76.1)

FN False negative

FP False positive

TN True negative

TP True positive

Table C50 Comparison of BSGI to MRI

Study | Type of Scanner | TP | FP | FN | TN | Sensitivity (95% CI) | Specificity (95% CI)
Brem et al. 2007^9^ | BSGI | 8 | 7 | 1 | 17 | 88.9% (51.8 to 99.7) | 70.8% (48.9 to 87.4)
Brem et al. 2007^9^ | Dynamic contrast enhanced MRI | 9 | 18 | 0 | 6 | 100% (66.4 to 100) | 25.0% (10.0 to 46.7)

FN False negative

FP False positive

TN True negative

TP True positive

## Grading the Strength of Evidence

We applied a formal grading system that conforms with the CER Methods Guide Manual recommendations on grading the strength of evidence.82,83

The overall strength of evidence supporting each major conclusion was graded as High, Moderate, Low, or Insufficient. The grade was developed by considering four important domains: the risk of bias in the evidence base, the consistency of the findings, the precision of the results, and the directness of the evidence. The grading system moves stepwise to consider each important domain. These steps are described below.

### Risk of Bias

According to the Methods Guide:82

Risk of bias is the degree to which the included studies for a given outcome or comparison have a high likelihood of adequate protection against bias (i.e., good internal validity) assessed through two main elements:

- Study design of individual studies
- Aggregate quality of the studies under consideration.

The risk of bias of each individual study was rated as being Low, Medium, or High; and the risk of bias of the aggregate evidence base supporting each major conclusion was similarly rated as being Low, Medium, or High.

We used our inclusion/exclusion criteria to eliminate studies with designs known to be prone to bias from the evidence base. Namely, case reports, case-control studies, and retrospective studies that did not enroll all or consecutive patients were not included for analysis. Because we eliminated all studies with a High risk of bias from the evidence base, we consider the remaining evidence base to have either a Low or Medium risk of bias.

We initially used an internal validity rating instrument for diagnostic studies to grade the internal validity of the individual studies (Table 51). This instrument is based on a modification of the QUADAS instrument.84 Each question in the instrument addresses an aspect of study design or conduct that can help to protect against bias. Each question can be answered “yes,” “no,” or “not reported,” and each is phrased such that an answer of “yes” indicates that the study reported a protection against bias on that aspect. See Table 52 through Table 55 for application of the instrument to the included studies.

Table C51 Quality assessment instrument

N | Question
1 | Was patient recruitment either consecutive or random?
2 | Was the study prospective in design?
3 | Were more than 85% of the patients approached for recruitment enrolled in the study?
4 | Were the patient inclusion/exclusion criteria consistently applied to all patients?
5 | Was the study free from obvious spectrum bias? Obvious spectrum bias was defined as more than 40% or less than 10% of the breast lesions were diagnosed as malignant; and/or the mean or median age of the enrolled population was less than 50 or greater than 70.
6 | Did the study account for inter-reader/scorer differences?
7 | Were the reader(s) of the biopsies blinded to the results of the reference standard?
8 | Were readers of the reference standard blinded to the results of the biopsy?
9 | Were the readers of the biopsy blinded to all other clinical information?
10 | Were readers of the reference standard blinded to all other clinical information?
11 | Were patients assessed by a reference standard regardless of the biopsy results?
12 | Were the patients assessed by the gold standard (open surgical procedure) regardless of the initial biopsy results?
13 | Was a diagnostic threshold chosen a priori by the study?
14 | Were there no intervening treatments or interventions conducted between the time the diagnostic test was performed and the reference standard was performed?
15 | Was a complete set of data reported for at least 85% of enrolled lesions?
16 | Was funding for this study provided by a source that doesn’t have an obvious financial interest in the findings of the study?
17 | Was the report of the study free from unresolvable discrepancies?

We conducted meta-regressions investigating the correlation between key individual items on the quality rating instrument and the results reported by the studies (see Appendix C for details). We consistently found that the majority of the items on the instrument had no statistically significant correlation with the reported results. Some (but not most) of the evidence bases were found to have a statistically significant impact of “reader blinded to other clinical information” and “accounted for inter-reader differences” on the study results.

We concluded that the quality instrument was not adequately capturing the potential for bias of the studies. Unlike studies of interventions, diagnostic cohort studies are quite simple in design- one group of patients acting as their own controls. As long as all enrolled patients receive both the diagnostic test and the reference standard test, opportunities for bias to affect the results are limited. As mentioned above, we eliminated all studies with a High risk of bias due to their study design from the evidence base. We did not identify any design flaws in the remaining studies that suggested they were at Medium risk of bias; therefore, we rated all of the included studies, and the aggregate evidence bases, as being at Low risk of bias.

### Consistency

According to the Methods Guide:82

The principal definition of consistency is the degree to which the reported effect sizes from included studies appear to have the same direction of effect. This can be assessed through two main elements:

- Effect sizes have the same sign (that is, are on the same side of “no effect”)
- The range of effect sizes is narrow.

The first definition, effect sizes being on the same side of “no effect,” is not applicable to meta-analyses of the accuracy of a diagnostic test. Therefore, for these cases, we used the second definition, the range of effect sizes being narrow. We measured the “narrowness” of the range of effect sizes with the statistic I^2^.85,86 Data sets that were found to have an I^2^ of less than 50% were rated as being “Consistent”; 50% or greater were rated as being “Inconsistent”; and data sets for which I^2^ could not be calculated (e.g., a single study) were rated as “Consistency Unknown.”

For qualitative comparisons between different diagnostic tests we used the first definition, that of effect sizes being on the same side of an effect. For example, when comparing the accuracy of ultrasound without a contrast agent to the accuracy of ultrasound with a contrast agent, if the estimates of sensitivity of the individual studies are consistently higher for studies that used a contrast agent, then the evidence base would be rated as “consistent.”

### Precision

According to the Methods Guide:82

Precision is the degree of certainty surrounding an effect estimate…if a meta-analysis was performed, this will be the confidence interval around the summary effect size.

A precise estimate is an estimate that would allow a clinically useful conclusion.

Diagnostic test characteristics (sensitivity, specificity) are reported on a scale from 0.0 to 100.0%. We defined a “precise” estimate of sensitivity or specificity as one for which the upper AND lower bound of the 95% confidence interval was no more than 5 points away from the summary estimate; for example, sensitivity 98% (95% CI: 97 to 100%) would be a precise estimate of sensitivity, whereas sensitivity 95% (95% CI: 88 to 100%) would be an imprecise estimate of sensitivity. Precision could be rated separately for summary estimates of sensitivity and specificity for each major conclusion.

For qualitative comparisons between different diagnostic tests, the conclusion is Precise if the confidence intervals around the summary estimates being compared do not overlap.

### Directness

According to the Methods Guide:82

The rating of directness relates to whether the evidence links the interventions directly to health outcomes.

For studies of diagnostic test accuracy, the evidence is always rated as “Indirect” because the outcome of test accuracy is indirectly related to health outcomes. However, the Key Questions in this particular comparative effectiveness review do not ask about the impact of test accuracy on health outcomes. We therefore did not incorporate the “Indirectness” of the evidence into the overall rating of strength of evidence for Key Questions that did not ask about health outcomes.

### Overall Rating of Strength of Evidence

The initial rating is based on the risk of bias. If the evidence base has a Low risk of bias, the initial strength of evidence rating is High; if the evidence base has a Moderate risk of bias, the initial strength of evidence rating is Moderate; if the evidence base has a High risk of bias, the initial strength of evidence rating is Low. For this particular comparative effectiveness review, as explained above, the rating of risk of bias was Low for all evidence bases, and therefore the initial strength of evidence rating is High.

The remaining two domains are used to up- or down- grade the initial rating as per the following flow charts:

- Consistent, Precise: High
- Inconsistent, Precise: Moderate
- Consistent, Imprecise: Moderate
- Inconsistent, Imprecise: Low
- “Consistency Unknown,” Precise: Low
- “Consistency Unknown,” Imprecise: Insufficient

### Quality Assessments

#### MRI

Table C52 MRI studies: quality evaluation

#### PET

Table C53 Quality assessment of studies of PET

#### Scintimammography

Table C54 Quality assessment of studies of scintimammography

#### Ultrasound

Table C55 Ultrasound studies: quality evaluation