# Sample Data Abstraction Forms

## Abstract Screening Form

1. Is the topic of the article “diagnosis of breast cancer”?
2. Is the article a full-length published journal article?
3. Is the article written in English?
4. Is the article describing a clinical study?
5. Does the study use one of the technologies being considered in the report?
6. Does the study appear to address at least one of the Key Questions?
7. Is the study about diagnosis and not about screening asymptomatic individuals?
8. Did the study enroll at least 10 female humans?

## Inclusion/Exclusion Screening Form

2 Did the study directly compare the test of interest to an acceptable reference standard- core-needle biopsy, open surgery, or patient followup- in the same group of patients?
3 Were at least 85% of the originally enrolled patients evaluated by both the non-invasive imaging technology and an acceptable reference standard?
4 If the study is retrospective in design, did it enroll all patients, consecutive patients, or a randomized sample of patients? Retrospective case-control and case studies are excluded.
5 The studies must have used current generation scanners and protocols of the selected technologies only, as defined in the following list of technologies and cut-off publication dates (to present):
  - Ultrasound (B-mode grayscale, tissue harmonics, power Doppler, color Doppler, tomography): 1994+
  - Magnetic resonance imaging (MRI), without computer aided-detection (CADx), using breast-specific coils and gadolinium-based contrast agents: 2000+
  - Magnetic resonance imaging (MRI), with computer aided-detection (CADx) (breast-specific coils and gadolinium-based contrast agents, CAD package FDA approved): 2000+
  - Positron emission imaging (PET), with or without computed tomography (PET/CT), using 18-flurodeoxyglucose (FDG) as the tracer: 2000+
  - Scintimammography, including breast specific gamma imaging (BSG1) and single photon emission computed tomography (SPECT), using technetium-99m sestamibi (sestamibi or MIBI) as the tracer: 2005+
6 Did the study enrolled female human subjects? If male subjects were enrolled, the majority (90%+) of the patients must have been female.
7 Did the study enroll patients referred for the purpose of primary diagnosis of a breast abnormality detected by routine screening (mammography and/or physical examination)? Studies that enrolled subjects that were undergoing evaluation for any of the following purposes were excluded as being out of scope of the report: screening of asymptomatic women; breast cancer staging; evaluation for a possible recurrence of breast cancer; monitoring response to treatment; evaluation of the axillary lymph nodes; evaluation of metastatic or suspected metastatic disease; or diagnosis of types of cancer other than primary breast cancer. Studies that enrolled patients from high-risk populations such as BRCA1/2 mutation carriers, or patients with a strong family history of breast cancer, are also out of scope. If a study enrolled a mixed patient population and did not report data separately, it was excluded if more than 15% of the subjects did not fall into the “primary diagnosis of women at average risk presenting with an abnormality detected on routine screening” category.
8 Did the study report test sensitivity, specificity, or sufficient data to calculate these measures of diagnostic test performance; or (for Key Question 3) reported factors that affected the accuracy of the non-invasive test being evaluated.
9 Was a complete set of data reported for at least 50% or more of the originally enrolled patients? Studies with extremely high rates of attrition are prone to bias and were excluded.
10 Was the study published in English?
11 Study must be published as a peer-reviewed full article. Meeting abstracts were not included.
12 Did the study enroll 10 or more individuals per arm?
13 Does the study include data that was also published in a different manuscript?

## Quality Assessment (Risk of Bias) Form

1. Was patient recruitment either consecutive or random?
2. Was the study prospective in design?
3. Were more than 85% of the patients approached for recruitment enrolled in the study?
4. Were the patient inclusion/exclusion criteria consistently applied to all patients?
5. Was the study free from obvious spectrum bias? Obvious spectrum bias was defined as more than 40% or less than 10% of the breast lesions were diagnosed as malignant; and/or the mean or median age of the enrolled population was less than 50 or greater than 70.
6. Did the study account for inter-reader/scorer differences?
7. Were the reader(s) of the biopsies blinded to the results of the reference standard?
8. Were readers of the reference standard blinded to the results of the biopsy?
9. Were the readers of the biopsy blinded to all other clinical information?
10. Were readers of the reference standard blinded to all other clinical information?
11. Were patients assessed by a reference standard regardless of the biopsy results?
12. Were the patients assessed by the gold standard (open surgical procedure) regardless of the initial biopsy results?
13. Was a diagnostic threshold chosen a priori by the study?
14. Were there no intervening treatments or interventions conducted between the time the diagnostic test was performed and the reference standard was performed?
15. Was a complete set of data reported for at least 85% of enrolled lesions?
16. Was funding for this study provided by a source that doesn’t have an obvious financial interest in the findings of the study?
17. Was the report of the study free from unresolvable discrepancies?

## Study Design and Patients Data Abstraction Form

Study design:

Multi-center:

Country set in:

Source of funding:

Patient recruitment methods:

Patient enrollment criteria:

N patients enrolled:

N lesions enrolled:

N lesions completing study:

Patient age, mean or median, range:

Describe imaging methods:

Describe imaging operators/readers:

Care setting:

Reference standard:

% lesions malignant:

% lesions palpable:

Tumor size:

Other lesion descriptors:

## Data Abstraction Form

Category/type/descriptors:

Number TP | Number FP
Number FN | Number TN