# Search Strategy and Exact Search Strings

Table A1 Electronic database searches

Name | Date Limits | Platform/Provider
The Cochrane Central Register of Controlled Trials (CENTRAL) | Through September 9, 2010 | www.thecochranelibrary.com
The Cochrane Database of Methodology Reviews (Methodology Reviews) | Through September 9, 2010 | www.thecochranelibrary.com
The Cochrane Database of Systematic Reviews (Cochrane Reviews) | Through September 9, 2010 | www.thecochranelibrary.com
Database of Abstracts of Reviews of Effects (DARE) | Through September 9, 2010 | www.thecochranelibrary.com
EMBASE (Excerpta Medica) | Through September 9, 2010 | OVID
Health Technology Assessment Database (HTA) | Through September 9, 2010 | www.thecochranelibrary.com
Healthcare Standards | Through September 9, 2010 | www.ecri.org
MEDLINE | Through September 9, 2010 | OVID
U.K. National Health Service Economic Evaluation Database (NHS EED) | Through 2009, Issue 4 | www.thecochranelibrary.com
U.S. National Guideline Clearinghouse™ (NGC) | Searched December 1, 2009 | www.ngc.gov

## Search Strategies

The search strategies employed combinations of freetext keywords as well as controlled vocabulary ps including (but not limited to) the following concepts. The strategy below is presented in OVID syntax; the search was simultaneously conducted across Embase, MEDLINE, and PsycINFO. A parallel strategy was used to search the databases comprising the Cochrane Library.

### Medical Subject Headings (MeSH), EMTREE, PsycINFO and Keywords

Conventions
- OVID
  - $ = truncation character (wildcard)
  - exp = “explodes” controlled vocabulary p (e.g., expands search to all more specific related ps in the vocabulary’s hierarchy)
  - .de. = limit controlled vocabulary heading
  - .fs. = floating subheading
  - .hw. = limit to heading word
  - .md. = type of methodology (PsycINFO)
  - .mp. = combined search fields (default if no fields are specified)
  - .pt. = publication type
  - .ti. = limit to title
  - .tw. = limit to title and abstract fields
- PubMed
  - [mh] = MeSH heading
  - [majr] = MeSH heading designated as major topic
  - [pt] = publication type
  - [sb] = subset of PubMed database (PreMEDLINE, Systematic, OldMEDLINE)
  - [sh] = MeSH subheading (qualifiers used in conjunction with MeSH headings)
  - [tiab] = keyword in title or abstract
  - [tw] = text word

Table A2 Topic specific search ps

Concept | Controlled Vocabulary | Keywords
Breast diseases | breast cancer breast carcinoma breast diseases breast neoplasms | breast cancer breast carcinoma breast lesions breast lumps breast neoplasms breast tumors breast tumours
Diagnosis | diagnosis diagnostic accuracy diagnostic imaging diagnostic procedure diagnostic value early diagnosis sensitivity and specificity tumor diagnosis | accuracy diagnosis false negative false positive gold standard likelihood precision predictive value receiver operating characteristic ROC sensitivity specificity true negative true positive
Non-invasive technique | | noninvasive non-invasive
Ultrasonography | echomammography ultrasonography ultrasonography, mammary ultrasound | echography echomammography sonography sonomammography ultrasonic ultrasonography ultrasound
Magnetic resonance imaging | magnetic resonance imaging nuclear magnetic resonance imaging | magnet strength magnetic resonance MR MRI NMR nuclear magnetic resonance pulse sequence
Positron emission tomography | fluorodeoxyglucose F 18 positron emission tomography tomography,emission-computed | computed tomography F18 F-18 FDG f-fluorodeoxyglucose PET positron emission tomography
Scintimammography | gamma cameras gamma spectrometry methoxy isobutyl isonitrile technetium tc-99 nuclear medicine organotechnetium compounds [diagnostic use] radionuclide imaging radiopharmaceuticals scintillation camera scintimammography spectrometry, gamma technetium Tc 99m Sestamibi [diagnostic use] | BSGI gamma camera gammagraphy gammagraphy MIBI miraluma nuclear medicine pem tetrofosomin radionuclide radiotracers scintimammography sestamibi technetium tetrofosmin
SPECT | single photon emission computer tomography spectrometry, x-ray emission | SPECT SPET
Tomosynthesis | three dimensional imaging | 3D 3-D three dimensional tomosynthesis
Computer-aided detection | computer assisted diagnosis diagnosis, computer-assisted digital mammography image analysis image interpretation, computer-assisted image processing, computer-assisted radiographic image interpretation, computer-assisted | CAD computer aided detection computer aided diagnosis computer assisted detection computer assisted diagnosis digital mammography
Doppler ultrasound | doppler echography ultrasonography, Doppler ultrasonography, doppler, color ultrasonography, doppler, duplex | doppler echography doppler ultrasonography
Combined PET/CT | computer assisted tomography positron-emission tomography tomography, emission-computed tomography, x-ray computed | PET/CT positron emission tomography and computed tomography

Table A3 CINAHL/EMBASE/MEDLINE

Set N | Concept | Search Statement
1 | Breast diseases | exp Breast neoplasms/or exp breast diseases/or exp breast cancer/or breast carcinoma/or ((breast or mammary) and (cancer$ or neoplasm$ or carcinoma$ or tumor$ or tumour$ or lump$ or lesion$)).mp.
2 | Diagnosis | “sensitivity and specificity”/or early diagnosis/or diagnostic imaging/or diagnostic value/or diagnostic accuracy/or diagnostic procedure/or tumor diagnosis/or diagnos$.mp. or di.xs. or “gold standard”.mp. or ROC.mp. or “receiver operating characteristic”.mp. or likelihood.mp. or ((false or true) adj (positive or negative)).tw. or “predictive value”.mp. or accuracy.mp. or precision.mp. or sensitivity.mp. or specificity.mp.
3 | Combine sets | 1 and 2
4 | Non-invasive technique (2005–2009) | 3 and (noninvasive or non-invasive).mp.
5 | Ultrasonography (2005–2009) | 3 and (ultrasonography.fs. or ultrasonography, mammary/or echogra$.mp. or echomammog$.mp. or sonogra$.mp. or sonomammogr$.mp. or ultrasound.mp. or ultrason$.mp. or echomammography/or ultrasound/)
6 | Magnetic resonance imaging (2000–2009) | 3 and (exp magnetic resonance imaging/or “magnet strength”.mp. or pulse sequence.mp. or MR.mp. or MRI.mp. or nuclear magnetic resonance.mp. or NMR.mp. or nuclear magnetic resonance imaging/or magnetic resonance.mp.)
7 | Positron emission tomography (2000–2009) | 3 and ((FDG$ or f-fluorodeoxyglucose or f18 or f-18).mp. or fluorodeoxyglucose F 18/or PET.ti. or positron emission tomography.mp. or exp tomography,emission-computed/or (comput$ ADJ tomograph$).tw. or positron emission tomography/)
8 | Scintimammography (2005–2009) | 3 and ((gamma camera$ or gammagraph$ or nuclear medicine or radionuclide$).mp. or radionuclide imaging.fs. or radiotracer$.mp. or radiopharmaceuticals/or sestamibi.mp. or technetium Tc 99m Sestamibi/du or gammagraph$.mp. or pem tetrofosomin.mp. or technetium.mp. or miraluma.mp. or tetrofosmin.mp. or scintimammogr$.mp. or spectrometry, gamma/or methoxy isobutyl isonitrile technetium tc-99/or nuclear medicine/or scintillation camera/or scintimammography/or gamma spectrometry/or exp organotechnetium compounds/du or MIBI.mp. or BSGI.mp. or gamma cameras/)
9 | SPECT (2005–2009) | 3 and (exp spectrometry, x-ray emission/or SPET.mp. or SPECT.mp. or single photon emission computer tomography/)
10 | Tomosynthesis 2007–2009) | 3 and (tomosynthesis.mp. or three dimensional imaging/or 3-D.mp. or 3D.mp. or imaging, three dimensional/or ((three or 3) ADJ dimension$)).tw.
11 | Computer-aided detection (2001–2009) | 3 and (diagnosis, computer-assisted/or image interpretation, computer-assisted/or radiographic image interpretation, computer-assisted/or computer assisted diagnosis/or digital mammography/or (comput$ ADJ (aided or assisted) ADJ (detection or diagnos$)).tw. or digital mammogra$.mp. or CAD.mp. or exp image processing, computer-assisted/or image analysis/)
12 | Doppler ultrasound (1997–2009) | 3 and (ultrasonography, doppler/or ultrasonography, doppler, duplex/or ultrasonography, doppler, color/or doppler echography/or (doppler ADJ2 (ultraso$ or echograph$)).tw.)
13 | Combined PET/CT (2000–2009) | 3 and (((positron-emission tomography/or tomography, emission-computed/) and (tomography, x-ray computed/or computer assisted tomography.mp.)) or (pet ADJ ct).tw. or pet/ct or (positron emission tomograph$ and comput$ tomograph$).mp.)
14 | Combine sets | or/4–13
15 | Limit by publication type | 15 not ((letter or editorial or news or comment or case reports or note or conference paper).de. or (letter or editorial or news or comment or case reports).pt.)