# Acknowledgments

The Evidence-based Practice Center would like to thank Eileen Erinoff, M.S.L.I.S., and Helen Dunn for providing literature retrieval and documentation management support; and Lydia Dharia for her assistance with the final preparations of the report.