# Acronyms and Abbreviations

ADH: Atypical ductal hyperplasia
AHRQ: Agency for Healthcare Research and Quality
ALH: Atypical lobular hyperplasia
BI-RADS^®^: Breast Imaging Reporting and Data System
BSGI: Breast specific gamma imaging
CER: Comparative Effectiveness Review
CI: Confidence interval
CT: Computed tomography
2D: Two dimensional
3D: Three dimensional
DCIS: Ductal carcinoma in situ
FDG: fluorodeoxyglucose
FN: False negative
FP: False positive
LCIS: Lobular carcinoma in situ
MIBI: Sestamibi
MRI: Magnetic resonance imaging
NA: Not applicable
NR: Not reported
PET: Positron emission tomography
SMM: Scintimammography
SPECT: Single photon emission computed tomography
TEP: Technical expert panel
TN: True negative
TP: True positive
UK: United Kingdom
US: Ultrasound
USA: United States of America