# Technical Expert Panel

James H. Bray, Ph.D.

2009 President

American Psychological Association

Washington, DC

Susan G. Kornstein, M.D.

Professor of Psychiatry and Obstetrics and Gynecology

Virginia Commonwealth University

Richmond, Virginia

John Santa, M.D., M.P.H.

Director

Consumer Reports Health Rating Center

Consumers Union

Greg Simon, M.D., M.P.H.

Psychiatrist

Group Health Research Institute

Seattle, Washington

John W. Williams, Jr., M.D.

Primary Care Physician

Former Director, Duke Evidence-based Practice Center

Duke University and Durham VA Medical Center

Durham, North Carolina